# Appendix D

## Peer Reviewers

We gratefully acknowledge the following individuals who reviewed the initial draft of this Report and provided us with constructive feedback. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report.

- William M. Bennett, MD
- Medical Director
- Legacy Transplant Services
- 1015 NW 22nd Avenue
- Portland, OR 97210

- Bruce Bistrian, MD, PhD
- Professor of Medicine
- Harvard Medical School
- Beth Israel Deaconess Medical Center
- One Deaconess Road, Baker - 605
- Boston, MA 02215

- Philip Calder, MD
- Division of Human Nutrition
- School of Biological Sciences
- University of Southampton
- Bassett Crescent East
- Southampton SO16 7PX UK

- Sven O. E. Ebbesson, PhD
- Professor of Marine Biology and Neuroscience
- Institute of Marine Science
- 200 O'Neill Building
- University of Alaska, Fairbanks
- Fairbanks, Alaska 99775-1080

- R. Michael Hofmann, MD
- University of Wisconsin Medical School, Madison
- Department of Nephrology
- 3034 Fish Hatchery Rd Ste B
- Madison, WI 53713

Representative for the American Society of Transplantation

- John Scandling, MD
- Medical Director
- Adult Kidney and Pancreas Transplant Program
- Stanford University Medical Center
- 750 Welch Road, Suite 200
- Palo Alto, CA 94304-1509

- Artemis P. Simopoulos, MD
- President
- The Center for Genetics, Nutrition and Health
- 2001 S Street, NW, Suite 530
- Washington, DC 20009

- Elizabeth A. Yetley, Ph.D.
- Senior Nutrition Research Scientist
- Office of Dietary Supplements
- National Institutes of Health
- 6100 Executive Boulevard, Suite 3B01
- Bethesda MD 20892-7517