# Appendix C Evidence Tables

Evidence Table 1a . Study Characteristics for Omega-3 Fatty Acids and Kidney Transplantation

Author, year | Study Characteristics | Graft | Eligibility Criteria | Omega-3 FA Intervention | Compliance | Control
UI#
Design
Bennett, 1995 | N3 enrolled: 40 | C or L | Inclusion criteria: patients between 18 and 70 years of age could be of either sex with either cadaveric or living related renal transplants. Patients could have had a previous unsuccessful renal transplantation. | High dose MaxEPA® | Total plasma EPA levels | Corn oil
7871564 | Control enrolled: 50 | | Exclusion criteria: (i) myocardial infarction or cardiac arrhythmia within the previous 6 months, (ii) acute or chronic liver disease, or a history of malignancy within the past 2 years, (iii) any investigational drug use within the past 3 months, (iv) severe gastrointestinal malabsorptive diseases or severe chronic obstructive lung diseases, pregnancy or lactation, (v) experienced a rejection episode within the 2-week interval prior to period 2; (vi) active infection | EPA: 3.24 g/d
RCT: Parallel | Age (yr), N3: ND | | | DHA: 2.16 g/d
| Age (yr), control: ND | | | Low dose MaxEPA®
| %Male, N3: ND | | | EPA: 1.62 g/d
| %Male, control: ND | | | DHA: 1.08 g/d
| Duration: 26 weeks | | | Start: 16 weeks post-operatively
| Country: USA
| sites: 3
Berthoux, 1992 | N3 enrolled: 17 | C: all | Inclusion criteria: recipients of cadaveric donor transplant | MaxEPA® | ND | No placebo
1465872 | Control enrolled: 15 | | Exclusion criteria: none reported | EPA: 1.62 g/d
RCT: Parallel | Age (yr), N3: 46.0±13.9 SD (14 patients) | | | DHA: 1.08 g/d
| Age (yr), control: 42.9±10.7 SD | | | Start: day 3 post-operatively
| % Male, N3: 43 (14 patients)
| % Male, control: 73
| Duration: 1 yr
| Country: France
| Site: 1
Busnach, 1998 | N3 enrolled: 21 | C or L | Inclusion criteria: all kinds of kidney grafts without clinically significant lipid disorders | Esapent® | ND | Olive oil
9589380 | Control enrolled: 21 | | Exclusion criteria: patients who had been treated with hypolipemic drugs in the three months preceding transplantation | EPA + DHA: 5.1 g/d then changed to 2.55 g/d from day 30
RCT: Parallel | Age (yr), N3: 44±2.6 SE | | | Start: day 1 post-operatively
| Age (yr), control: 39±2.1 SE
| % Male, N3: 48
| % Male, control: 67
| Duration: 1 yr
| Country: Italy
| Site: 1
Butani, 2000 | One 12 yr-old boy | ND | Kidney transplant | MaxEPA® | ND | ND
10910466 | Duration: 1 yr | | | EPA: 2.16 g
Case report | Country: USA | | | DHA: 1.44 g
| | | | Start: not clear
Castro, 1997 | N3 enrolled: 18 | ND | Inclusion criteria: >=1 year post-renal transplant stable renal function and with persistent hypercholesterolemia (total cholesterol > 200 mg/dL, mean 292±48 mg/dL) after cholesterol reduction diet for 12 weeks | EPA: 1.8 g/d | ND | Simvastatin 10mg/d
9351079 | Control enrolled: 25 | | Exclusion criteria: none reported | DHA: 1.2 g/d
RCT: Parallel | Age (yr), N3: 43.4±11.7SD | | | Start: >=1 year
| Age (yr), control: 45.6±9.4 SD
| % Male, N3: 33
| %Male, control: 44
| Duration: 3 months
| Country: Portugal
| Sites: 1
Grekas, 2001 | N3 enrolled: 24 | L: all | Inclusion criteria: renal transplant patients with stable renal function (serum creatinine<2mg/dl) and persistent hypercholesterolemia (total cholesterol>200mg/dl) after 4-week lipid lowering diet | Prolipid | ND | No control
11474227 | Age: 45.0±10.4 SD | | Exclusion criteria: diabetic or receiving beta-blocker therapy patients | EPA: 0.18 g/d
Single-arm cohort | % Male: 63 | | | DHA: 0.12 g/d
| Duration: 8 weeks | | | Start: 8.7±2.9 SD years
| Country: Greece
| Site: 1
Hansen, 1995a | N3 enrolled: 12 | ND | Inclusion criteria: non-diabetic renal transplant recipients. Serum creatinine below 180 umol/l. No acute or chronic rejection. | Pikasol® | Pill counting and measurements of the plasma composition of fatty acids. | ND
8559499 | Age (yr), CsA: 42 (rang 22–56) | | Exclusion criteria: received dihydropyridine calcium antagonists | EPA: 2.1 g/d
Single-arm cohort | %Male, CsA: 58 | | | DHA: 1.38 g/d
| Duration: 12 weeks | | | Start: 16 months (range 6–71 months)
| Country: Denmark
| Sites: 1
Hansen, 1995b | CsA enrolled: 9 | ND | Inclusion criteria: non-diabetic renal transplant; serum creatinine below 160 umol/L for more than 22 months before study | Pikasol® | Pill counting and measurements of the plasma composition of fatty acids. | ND
7703381 | Aza enrolled: 9 | | Exclusion criteria: received dihydropyridine calcium antagonists | EPA: 2.1 g/d
Multiple-arm cohorts | Age (yr), CsA: 49±9 SD | | | DHA: 1.38 g/d
| Age (yr), Aza: 50 ±11 SD | | | Start: 42±17 (SD) months CsA group
| % Male, CsA: 78 | | | 149±44 (SD) months Aza group
| %Male, Aza: 44
| Duration: 10 weeks
| Country: Denmark
| Site: 1
Hernandez, 2002 | N3 enrolled: 49 | C: all | Inclusion criteria: consecutive patients and (i) 18–70 yr, (ii) no fish oil or immunosuppressive treatment in the 6 months prior to the study, (iii) no hemorrhagic disorders. | Epaleo® | Pill counting at each clinic visit | Soy oil: 6 g/d
11981081 | Control enrolled: 42 | | Exclusion criteria: (i) any investigational drug used within the past 3 months, (ii) acute liver disease, (iii) Hx malignancy the past 2 yr, (iv) fish or iodine allergy, (v) pregnancy or lactation (vi) patients who experienced severe side-effects during follow-up | EPA: 1.26 g/d
RCT: Parallel | Age (yr), N3: 46.8±12.1SD | | | DHA: 0.66 g/d
| Age (yr), control: 45.3±14.5 SD | | | Start: 2 days post-operatively
| % Male, N3: 58
| % Male, control: 70
| Duration: 12 months
| Treatment duration: 3 months
| Country: Spain
| Site: 1
Homan van der Heide, 1990a | N3 enrolled: 14 | ND | Inclusion criteria: patients who received kidney allografts | EPA: 1.8 g/d | ND | Coconut oil: 6 g/d
2271089 | Control enrolled: 17 | | Exclusion criteria: none reported | DHA: 1.2 g/d | | fish flavoring
RCT: Parallel | Age (yr), N3: 49 (range 28–63) | | | Start: 3 days post-operatively
| Age (yr), control: 47(range 22–64)
| % Male, N3: ND
| % Male, control: ND
| Duration: 1 month
| Country: Netherlands
| Sites: 3
Homan van der Heide, 1990b | N3 enrolled: 12 | ND | Inclusion criteria: patients who received kidney allografts, were treated with CsA and had stable renal function | Super-EPA® | Plasma phospholipid fatty acids measured | Corn oil: 6 g/d
2316014 | Control enrolled: 12 | | Exclusion criteria: none reported | EPA: 1.8 g/d
RCT: Parallel | Age (yr), N3: 40 (range 27–66) | | | DHA: 1.2 g/d
| Age (yr), control: 37(range 17–62) | | | Start: at least 9 months post-transplant
| % Male, N3: 60
| % Male, control: 45
| Duration: 3 months
| Country: Netherlands
| Sites: 2
Homan van der Heide, 1992 | N3 enrolled: 40 | C: all | Inclusion criteria: consecutive patients who received kidney allografts | EPA: 1.8 g/d | ND | Coconut oil: 6 g/d
1496538 | Control enrolled: 48 | | Exclusion criteria: none reported | DHA: 1.2 g/d | | fish flavoring
RCT: Parallel | Age (yr), N3: 48 (range 17–68) | | | Start: 3 days post-operatively
| Age (yr), control: 44(range 19–68)
| % Male, N3: 64
| % Male, control: 59
| Duration: 1 month
| Country: Netherlands
| Sites: 3
Homan van der Heide, 1993 | N3 enrolled:33 | C: all | Inclusion criteria: patients who received kidney allografts, were treated with CsA and had stable renal function | EPA: 1.8 g/d | plasma cholesterol esters measured | Coconut oil: 6 g/d
8350886 | Control enrolled: 33 | | Exclusion criteria: patients receiving NSAIDS | DHA: 1.2 g/d | | fish flavoring
RCT: Parallel | Age (yr), N3: 41 (range 17–69) | | | Start: 3 days post-operatively
| Age (yr), control: 47(range 19–67)
| % Male, N3: 64
| % Male, control: 59
| Duration: 12 months
| Country: Netherlands
| Sites: 4
Kooijmans-Coutinho, 1996 | N3 enrolled: 25 | C: all | Inclusion criteria: patients who received kidney allografts and were treated with CsA | EPA: 1.8 g/d | ND | coconut oil: 6 g/d
8704119 | Control enrolled: 25 | | Exclusion criteria: fish oil or iodine allergy; NSAIDS taken; previous non-compliance; DM | DHA: 1.2 g/d | | fish flavoring
RCT: Parallel | Age (yr), N3: 43.5 (range 22–71) | | | Start: 3 days post-operatively
| Age (yr), control: 47(range 27–68)
| % Male, N3: 52
| % Male, control: 68
| Duration: 12 months
| Treatment duration: 3 months
| Country: Netherlands
| Sites: 1
Maachi, 1995 | N3 enrolled: 40 | C: all | Inclusion criteria: patients who received kidney allografts | MaxEPA® | ND | No placebo
7879202 | Control enrolled: 40 | | Exclusion criteria: none reported | EPA: 1.44 g/d
RCT: Parallel | Age (yr), N3: 44.7±12.7 SD | | | DHA: 0.96 g/d
| Age (yr), control: 42.8±11.2 SD | | | Start: day 3 post-operatively
| % Male, N3: 75
| % Male, control: 75
| Duration: 1 yr
| Country: France
| Site: 1
Ng, 2003 | One 34 yr old man | C | Kidney transplant | EPA: 2.16 g | ND | ND
12809474 | Duration: 5 years | | | DHA: 1.44 g
Case report | Country: USA | | | Start: not clear
Rodriguez, 1997 | N3 enrolled: 18 | C | Inclusion criteria:>=6 month post-RT stable function, total cholesterol >240 mg/dl after hypolipemic diet lasting 3 mo | Beromegan^®^ | ND | Lovastatin 20 mg/d
Cochrane 00197406 | Control enrolled: 16 | | Exclusion criteria: diabetes, nephrotic syndrome, change in hepatic function, creatinine >3 mg/dl | 2 g/d
RCT: Parallel | Age (yr), N3: 43.83±9.38 SD | | | EPA: 1.8 g/d
| Age (yr), control: 42.78±12.45 SD | | | DHA: 1.2 g/d
| % Male, N3: 72 | | | Start: >= 6 months post-operatively
| %Male, control: 69
| Duration: 6 months
| Country: Spain
| Sites: 1
Santos, 2000 | N3 enrolled: 15 | C: all | Inclusion criteria: patients treated with CsA who had delayed graft function | EPA: 1.8 g/d | ND | Placebo
11134724 | Control enrolled: 15 | | Exclusion criteria: primary renal nonfunction; DM | DHA: 1.2 g/d
RCT: Parallel | Age (yr), N3: 37.4±10.9 SD | | | Start: 2 days post-operatively
| Age (yr), control: 37.8±11.8 SD
| % Male, N3: 47
| % Male, control: 60
| Duration: 12 months
| Country: Portugal
| Sites: 1
Schut, 1993 | N3 enrolled: 29 | C: all | Inclusion criteria: patients with good and stable renal function who had no signs of transplant rejection | Super-EPA® | Plasma phospholipid fatty acids measured | Corn oil: 6 g/d
8210973 | Control enrolled: 29 (cross-over) | | Exclusion criteria: none reported | EPA: 1.8 g/d | | Super-EPA
Schut,1993 | Age (yr), N3: 52.3 | | | DHA: 1.2 g/d | | Pharmacaps®
EMBASE | Age (yr), control: 52.3 | | | Start: at least 1 yr post-transplant
1993223288 | % Male, N3: 62
Schut, 1992 | % Male, control: 62
14621869 | Duration: 8 months
Levi, 1992 | Treatment duration: 4 months
1465791 | Country: Netherlands
RCT: Cross-over | Sites: 2
Sweny, 1993 | N3 enrolled: 14 | C: 13 | Inclusion criteria: patients who received kidney allografts and had chronic vascular rejection | MaxEPA® | ND | No control arm
8470281 | Control enrolled: 0 | L: 1 | Exclusion criteria: none reported | EPA: 0.036 g/k g/d
Sweny, 1989 | Age (yr), N3: 40.8 (19–59) | | | DHA: 0.024 g/k g/d
2517328 | % Male, N3: 57 | | | Mean start: 57.9 (range 13–132) months post-transplant
Single-arm cohort | Duration: 6 months
| Country: UK
| Sites: 1
Urakaze, 1989 | N3 enrolled: 14 | C: 15 | Inclusion criteria: patients who received first kidney allografts and had stable graft function | EPA: 1.5 g/d | EPA content in RBC | No placebo
2812166 | Control enrolled: 16 | L: 15 | Exclusion criteria: Diabetes | DHA: 0.7 g/d
Urakaze, 1989 | Age (yr), N3: 30± 6 SD | | | N3 mean start: 28±19 SD months post-transplant
2652688 | Age (yr), control: 33± 7 SD | | | Controls mean start: 22±20 SD months post-transplant
RCT: Parallel | % Male, N3: 79
| % Male, control: 56
| Duration: 6 months
| Country: Japan
| Sites: 3
Yoa, 1994 | N3 enrolled: 12 | ND | Inclusion criteria: patients who had stable graft function for at least 3 months before the trial | MaxEPA® | Plasma phospholipid fatty acids measured | Olive oil: 6 caps
EMBASE | Control enrolled: 11 | | Exclusion criteria: none reported | EPA: 0.72g
1994288697 | Age (yr), N3: 38.5±11.01 SD | | | DHA: 0.48g
RCT: Parallel | Age (yr), control: 37± 14.15 SD | | | Start: at least 5 months post-transplant
| % Male, N3: 50 | | | Mean start: 36.13±20.72 months post-transplant
| % Male, control: 64
| Duration: 6 months
| Country: France
| Sites: 1
Zolotarski, 2003 | N3 enrolled: 8 | ND | ND | 1g/kg MLF 541 20% emulsion | ND | No control arm
12644071 | Control enrolled: 0 | | | (MCT:LCT:fish oil: 5:4:1) ~ 0.1 g/kg BW/d Fish oil
Single-arm cohort | Age (yr), N3: 46±17 SD | | | Only during the first 5 days post-transplant
| % Male, N3: 50
| Duration: 6 months
| Treatment duration: 5 days
| Country: Israel
| Sites: 1

RCT = randomized controlled trial; nRCT = non-randomized-placebo-controlled trial; C = cadaver donor; L = living donor; Aza = azathiopine; CsA = cyclosporine; DM = diabetes mellitus; N3 = omegas-3 fatty acids

Evidence Table Ib. Concomitant Treatments for Omega-3 Fatty Acids and Kidney Transplantation

Author, year | Immunosuppressive therapy | | | | Co-Treatments
UI# | Induction therapy | Maintenance | Trough CsA levels | Anti-rejection therapy | Anti-hypertensive: Dose | Lipid-lowering: Dose
Design
Bennett, 1995 | ND | CsA, prednisone, Aza given the optimal maintenance dosages. | ND | ND | Calcium antagonists, ACE inhibitors | ND
7871564 | | | | | Dose:
RCT: Parallel | | | | | ND
Berthoux, 1992 | CsA mean initial dose of 11 mg/kg/d | CsA was daily adjusted during first month to maintain a whole-blood trough level | 268 to 640 ng/mL | ND | ND | ND
1465872 | Steroids 30 mg/24hours
RCT: Parallel | 16 patients received Aza of 1 to 1.5 mg/kg/24hours
Busnach, 1998 | Antilymphocyte globulin, 100 mg/d iv from day 0 to 7 | Aza dose depending on blood cell counts | N3: mean 322 ng/ml (range 252±98 to 1831±940) | ND | ND | ND
9589380 | Aza 1–1.5mg/kg/d from day 1, oral CsA 10 mg/kg before graft, and 8 mg/kg in two doses from day1: | CsA doses in order to achieve blood concentrations of 150–350ng/ml | Control: mean 311ng/ml (range 226±90 to 1524±670)
RCT: Parallel | 6-methylprednsolone 500mg i.v. from day 0 tapered to 60 mg on day 6, then 16mg orally from day 7, with 2 mg-tapering every two weeks down to 8 mg/kg from day 75 onwards.
Butani, 2000 | ND | Aza, Csa, or Prednisolone, after biopsy, was increased from 10mg daily to 80mg every other day for 3 months. Then it was gradually tapered to 40mg once every other day by 1 year post-biopsy. | ND | ND | ND | ND
10910466
Case report
Castro, 1997 | ND | N3, 18/18 patients: CsA (3.8+-1.1 mg/kg/d (SD)) plus prednisolone(394+-179mg/kg SD) | 189+-30ng/ml baseline | ND | Enalapril 11/13 in FO group, 14/17 in statin group | No other lipid lowering Rx
9351079 | | 24/25 patients: CsA (3.8+-1.2 mg/kg/d) plus prednisolonedose 388+-145mg/kg (SD) | 186+-38ng/ml baseline | | 2 drugs: 6/13 in FO group, 5/17 in statin group
RCT: Parallel | | | | | 3 drugs: 2/13 in FO group, 2/13 in statin group
| | | | | Other drugs incl: nifedipine, diltiazem, minoxidil, amlodipine etc beta blockers as 2^nd^ line drug
Grekas, 2001 | ND | CsA 4mg/kg BW daily | ND | ND | ND | Pravastatin daily
11474227 | | Aza 2 mg/kg BW daily
Single-arm cohort | | methylprednisolone 8 mg daily
Hansen, 1995a | ND | CsA ( mean 2.6 mg/kg; range 1.7–4.0 mg/kg) | Cmin | ND | ACE inhibitors, calcium antagonist, beta blockers, diuretics, hydralazine: | ND
8559499 | | Aza | before: 261±20 ng/ml | | dose:
Single-arm cohort | | Prednisone | after 251±20 | | ND
| | | Cmax
| | | before 1635 ± 120
| | | after 1540 ± 132
Hansen, 1995b | ND | CsA 9/9 patients: 3.0±0.6mg/kg | Before 285±46 ng/mL | ND | Diuretics, Diltiazem, beta blockers, ACE inhibitor | ND
7703381 | | | After 302± ng/mL
Multiple-arm cohorts
Hernandez, 2002 | ATg (for 7 days) | CsA 8mg/kg/d started when creatinine<3mg/dl to achieve initial trough levels then tapered and adjusted according to total blood levels) | [underlined: initial:] 250 to 350ng/ml | methylprednisolone 500mg iv for 3 consecutive days | Beta blocker, α-adrenergic antagonists, calcium channel blockers | ND
11981081 | | Prednisone 0.3mg/kg/d (for 3 mo) then gradually reduced to 10m g/d for 1y) | | if resistant OKT3 5mg/d for 10-day course | plus diuretics (if necessary)
RCT: Parallel | | Aza (1.25–1.50mg/kg/d )
Homan van der Heide, 1990a | CsA 3mg/kg/d iv (for 72h) | CsA 10mg/kg for 2 weeks then adjusted to reach trough levels | ND | methylprednisolone 1g iv for 3–6 days | ND | ND
2271089 | prednisolone20 mg/d (for 2 weeks) and then tapered by 2.5 mg every two weeks to reach maintenance dose | prednisolone10mg/d | | if resistant ATg 4mg/kg every other day for 5 doses
RCT: Parallel
Homan van der Heide, 1990b | ND | CsA N3: 5 mg/kg (4.0–8.5) | [underlined: initial and in 3 mo:] | ND | Diuretics 6 patients, Beta blocker 8 patients: ND | ND
2316014 | | CsA control: 5 mg/kg (4.5–8.0) | N3: 90 (65–125)
RCT: Parallel | | Prednisolone 10mg/d | [underlined: initial:]
| | | control: 133 (45–26)
Homan van der Heide, 1992 | CsA 3mg/kg/d iv (for 72h) | CsA 10mg/kg per os for 2 weeks then adjusted to reach trough levels | ND | methylprednisolone 1g iv for 3–6 days | ND | ND
1496538 | prednisolone 20 mg/d (for 2 weeks) and then tapered by 2.5 mg every two weeks to reach maintenance dose | prednisolone10mg/d | | if resistant ATg 4mg/kg every other day for 5 doses
RCT: Parallel
Homan van der Heide, 1993 | CsA 3mg/kg/d iv (for 72h) | CsA 10mg/kg for 2 weeks then adjusted to reach trough levels | [underlined: initial:] 200ng/ml | methylprednisolone 1g iv for 3–6 days | [underlined: persistent HT (DBP>95mmHg):] diuretics, beta blocker, centrally acting vasodilatory agent (e.g. clonidine) | ND
8350886 | prednisolone 20 mg/d (for 2 weeks) and then tapered by 2.5 mg every two weeks to reach maintenance dose | prednisolone10mg/d | | if resistant ATg 4mg/kg every other day for 5 doses | [underlined: rescue therapy]: calcium channel blockers
RCT: Parallel
Kooijmans-Coutinho, 1996 | CsA 3mg/kg iv (for 48h) | CsA 10mg/kg/d per os plus | 250 to 500 ng/ml | methylprednisolone 1 g/d iv for 3 consecutive days | [underlined: first choice]: beta blockers, plus diuretics (if necessary) or centrally acting vasodilators | ND
8704119 | | prednisolone 20mg/d tapered to 10mg/d | | if resistant ATg 5mg/d for 10-day course | [underlined: rescue therapy]: calcium channel blockers
RCT: Parallel
Maachi, 1995 | ND | CsA 7.5 mg/kg/d | 268 to 640 ng/mL | ND | ND | ND
7879202 | | prednisolone 0.5 mg/kg/d (max: 30 mg/d) azathioprine 1.5 mg/kg/d
RCT: Parallel
Ng, 2003 | prednisone and CsA from March 1986 till IgA nephropathy in 1991. After 1 yr 5 mos PD and 2^nd^ transplant in May 1997, same regimen of immunosuppresion continued | ND | ND | ND | ND | ND
12809474
Case report
Rodriguez, 1997 | ND | N3: CsA (3.07+-0.77 mg/kg/d (SD) plus prednisolone(9.09+-1.7 mg/kg) | ND | ND | beta blockers diuretics | No other lipid lowering Rx but lovastatin 20 mg/d as control
Cochrane 00197406 | | Controls: CsA (3.8+-1.52mg/kg/d) plus prednisolone (8.75+-1.29 mg/d)
RCT: Parallel
Santos, 2000 | CsA 6mg/Kg subsequently tapered to maintenance levels | CsA | 100 to 300 ng/ml | ND | 21/30 patients | ND
11134724 | Methylprednisolone gradually reduced from 1 to 0.25g/d (for 5 days) | prednisolone10 mg/d | | | [underlined: first choice:] beta blockers, plus diuretics (if necessary) or centrally acting vasodilators
RCT: Parallel | [underlined: 5 N3 patients, 4 controls:] | | | | [underlined: second line:] calcium channel blockers, ACE inhibitors
| ATg 4mg/kg (for 7–10d)
Schut, 1993 | ND | [underlined: 10/29 patients]: CsA mean dose 2.8±0.9mg/kg SD | 75–150 μg/l | ND | not specified | ND
8210973
Schut,1993 | | [underlined: 10/29 patients]: CsA mean dose 3.3mg/Kg ±0.7 SD plus prednisolone(10 mg)
EMBASE 1993223288
Schut, 1992 | | [underlined: 9/29 patients]: Aza 100–150 mg/d plus prednisolone 5–10 mg/d
14621869
Levi, 1992
1465791
RCT: Cross-over
Sweny, 1993 | ND | [underlined: 9 patients:] CsA plus prednisolone(0.15 mg/kg) | 75–150 ng/ml | ND | not specified | ND
8470281
Sweny, 1989 | | [underlined: 5 patients:] Aza (2mg/kg) plus prednisolone (0.15 mg/kg)
2517328
Single-arm cohort
Urakaze, 1989 | ND | 18 patients: CsA 5mg/Kg/d | ND | ND | 19 patients: Metoprolol 120mg/d | ND
2812166 | | | | | 16 patients: Nifedipine 30mg/d
Urakaze, 1989 | | 11 patients: Aza 53.1+/-31.1 mg/d | | | 8 patients: Captopril 37.5mg/d
2652688 | | all patients: prednisolone 10.4+/-3.9 mg/d
RCT: Parallel
Yoa, 1994 | ND | CsA 283 +/-80 mg/d | ND | ND | ND | ND
EMBASE 1994288697 | | Corticosteroids 11.5 +/-2.5 mg/d
RCT: Parallel | | Aza 101 +/-29 mg/d
Zolotarski, 2003 | ND | Steroids plus Tacrolimus | ND | ND | ND | ND
12644071 | | Steroids plus CsA
Single-arm cohort

ACE = angiotensin-converting enzyme; Aza = azathiopine; CsA = cyclosporine

Evidence Table Ic. Major Outcomes for Omega-3 Fatty Acids and Kidney Transplantation

Author, year | Major Outcomes
UI# | GFR (method) | Other Renal Function: method | BP | Hyper-tension: definition | Rejection episodes: definition | Patient survival | Graft survival | Total Chol | Tg | LDL and/or VLDL | HDL | CsA dose | CsA levels
Design
Bennett, 1995 | GFR (DTPA clearance) | PAH clearance | SBP | ND | yes | yes | yes | ND | ND | yes | yes | yes | yes
7871564 | Creatinine clearance | | DBP
RCT: Parallel
Berthoux, 1992 | GFR (inulin clearance) | ERPF by PAH clearance | ND | ND | yes | yes | yes | yes | yes | ND | ND | yes | yes
1465872 | Serum creatinine
RCT: Parallel | Calculated creatinine clearance
Busnach, 1998 | Plasma creatinine | ND | ND | ND | yes | yes | yes | yes | yes | ND | yes | yes | yes
9589380
RCT: Parallel
Butani, 2000 | Serum creatinine | Microhematuria | ND | ND | ND | ND | yes | ND | ND | ND | ND | ND | ND
10910466 | | Urinary protein to creatinine ratio
Case report | | Proteinuria
Castro, 1997 | Serum creatinine | ND | SBP | ND | yes | ND | yes | yes | yes | yes | yes | ND | ND
9351079 | | | DBP
RCT: Parallel
Grekas, 2001 | Serum creatinine | Urine sodium | MAP | ND | ND | ND | yes | yes | yes | yes | yes | ND | yes
11474227
Single-arm cohort
Hansen, 1995a | GFR (99mTc-DTPA in a total dose of 54MBq) | ERPF measured by a constant infusion technique with 131I hippuran in a total dose of 7.2MBq | MAP | ND | Yes | ND | yes | ND | ND | ND | ND | ND | yes
8559499 | Serum creatinine | Clearance of sodium | | | Dx method: ND
Single-arm cohort | | Clearance of lithium
| | Fractional clearance of lithium
Hansen, 1995b | GFR (99mTc-DTPA in a total dose of 7.2MBq and 54MBq) | ERPF measured by a constant infusion technique with 131I hippuran. | MAP | ND | Yes | ND | yes | ND | ND | ND | ND | ND | yes
7703381 | Serum creatinine | Sodium (24-hour urinary excretion rates) | | | Dx method: ND
Multiple-arm cohorts | Creatinine (24-hour urinary excretion rates) | Potassium (24-hour urinary excretion rates)
| | Albumin (24-hour urinary excretion rates)
| | Urinary excretion rate of β2-microglobulin
| | Fractional excretion of β2-microglobulin
| | Renal clearance of Cu
| | Renal clearance of sodium
| | Renal clearance of lithium
Hernandez, 2002 | GFR (Cr-EDTA) | Proteinuria | MAP | ND | yes | ND | yes | yes | yes | ND | ND | yes | yes
11981081 | Cr-clearance | | | | clinical Dx confirmed by percutaneous renal biopsy or FNA
RCT: Parallel | Serum creatinine
Homan van der Heide, 1990a | GFR (125I iothalamate clearance) | ERPF | MAP | ND | yes | ND | ND | ND | ND | ND | ND | yes | yes
2271089 | Stimulated GFR (by dopamine, amino acids and both) | 131I hippuran | | | Dx method: ND
RCT: Parallel | Cr-clearance | Stimulated ERPF by dopamine, amino acids and both
| Serum creatinine | Filtration fraction
Homan van der Heide, 1990b | GFR (125I iothalamate clearance) | ERPF: 131I hippuran | MAP | ND | ND | ND | ND | ND | ND | ND | ND | ND | yes
2316014 | Cr-clearance | Filtration fraction
RCT: Parallel | Serum creatinine
Homan van der Heide, 1992 | Cr-clearance | ND | MAP | ND | yes | ND | ND | ND | ND | ND | ND | yes | yes
1496538 | Serum creatinine | | | | histologically confirmed as cellular (interstitial) rejection
RCT: Parallel
Homan van der Heide, 1993 | GFR (125I iothalamate clearance) | ERPF | MAP | DBP repeatedly >95mmHg | yes | ND | ND | ND | ND | ND | ND | yes | yes
8350886 | | 125I iothalamate | | | creatinine rise or no improvement for 3 consecutive days in the absence of excessive CsA levels; graft swelling and tenderness, blood eosinophilia, Na retention and fever; results of U/S; confirmed by percutaneous renal biopsy or FNA
RCT: Parallel | | Proteinuria
| | Filtration fraction
Kooijmans-Coutinho, 1996 | GFR (125I iothalamate clearance) | ERPF: 131I hippuran | MAP: HRZMS | ND | yes | yes | yes | ND | ND | ND | ND | yes | yes
8704119 | Cr-clearance | ERBF | | | abnormalities detected by graft palpation, increased serum Cr, Na retention and fever; confirmed by percutaneous renal biopsy or FNA
RCT: Parallel | | ERPFx(1-Ht)
| | Filtration fraction
Maachi, 1995 | GFR (inulin clearance) | RPF | ND | number of patients taking anti-hypertensive drugs | yes | yes | yes | yes | yes | ND | ND | yes | ND
7879202 | Measured creatinine clearance | PAH clearance | | | Dx method: ND
RCT: Parallel | Calculated creatinine clearance | Filtration fraction
| Serum Creatinine
Ng, 2003 | Serum Creatinine | Proteinuria | ND | ND | ND | yes | yes | ND | ND | ND | ND | ND | ND
12809474
Case report
Rodriguez, 1997 | ND | ND | ND | ND | ND | ND | ND | yes | yes | yes | yes | ND | ND
Cochrane 00197406
RCT: Parallel
Santos, 2000 | GFR (Cr-EDTA) | ND | SBP: ND | ND | Yes | ND | yes | ND | ND | yes | yes | yes | yes
11134724 | Cr-clearance | | DBP: ND | | increased serum Cr; confirmed by percutaneous renal biopsy
RCT: Parallel | Serum creatinine concentration
Schut, 1993 | GFR (125I iothalamate clearance) | ERPF: 131I hippuran | MAP: HRZMS | ND | ND | ND | ND | ND | ND | ND | ND | ND | ND
8210973 | | Filtration fraction
Schut, 1993
EMBASE
1993223288
Schut, 1992
14621869
Levi, 1992
1465791
RCT: Cross-over
Sweny, 1993 | ND | RF decline: | ND | ND | ND | ND | ND | yes | yes | ND | ND | ND | ND
8470281 | | Reciprocal plasma creatinine was plotted against time (mmol/lt per month)
Sweny, 1989 | | Proteinuria
2517328
Single-arm cohort
Urakaze, 1989 | Serum creatinine | ND | SBP: ND | ND | yes | ND | ND | yes | yes | ND | ND | ND | ND
2812166 | | | DBP: ND | | Dx method: ND
Urakaze, 1989
2652688
RCT: Parallel
Yoa, 1994 | ND | ND | ND | ND | ND | ND | ND | yes | yes | yes | yes | ND | ND
EMBASE
1994288697
RCT: Parallel
Zolotarski, 2003 | Serum creatinine: ND | BUN: ND | ND | ND | ND | ND | ND | ND | yes | ND | ND | ND | ND
12644071
Single-arm cohort

MAP = mean arterial pressure; SBP = systolic blood pressure; DBP = diastolic blood pressure; HRZMS = Hawksley random zero mercury sphygmomanometer; Dx = diagnostic; GFR = glomerulus's filtration rate

Evidence Table Id. Other Outcomes for Omega-3 Fatty Acids and Kidney Transplantation

Author, year | Other Outcomes | Definitions or measures
UI#
Design
Bennett, 1995 | • Thromboxane B2 (pg/mg) | Thromboxane B2 measurement from urine by negative ion gas chromatograph mass spectroscopy, twice in each period.
7871564 | • Platelet function | Platelet function was estimated by ADP, epinephrine, and collagen-induced platelet aggregation, twice in each period. Bleeding time.
RCT: Parallel
Berthoux, 1992 | None | None
1465872
RCT: Parallel
Busnach, 1998 | • CD4+ lymphocytes | Defined by flow cytometic analysis
9589380
RCT: Parallel
Butani, 2000 | None | None
10910466
Case report
Castro, 1997 | • Serum transaminase
9351079 | • CPK
RCT: Parallel | • Lipoprotein (a) mg%
| • ApoA1 mg%
| • ApoB mg%
| • Mean body weight
Grekas, 2001 | • Serum potassium | mg/dL
11474227 | • Serum sodium | mEq/L
Single-arm cohort | • Lipoprotein (a) | mEq/L
| • ApoA1 | mg/dL
| • ApoB | mg/dL
| • CPK | mg/dL
Hansen, 1995a | • Sodium excretion | beats/min
8559499 | • Heart rate
Single-arm cohort
Hansen, 1995b | • Urine (24-hour urinary excretion rates) | L
7703381 | • 6-Keto-prostaglandin F1α (24-hour urinary excretion rates) | ng
Multiple-arm cohorts | • Thromboxane B2 (24-hour urinary excretion rates) | ng
| • Body weight | kg
| • Heart rate | beats/min
Hernandez, 2002 | • Delayed graft function | Urine volume <1000cc in the absence of a fall in serum Cr concentration and with optimal hydration (described as %proportion)
11981081 | • Episodes of AR per patient | number of episodes
RCT: Parallel | • OKT3 rescue therapy | administered or not
| • TNF-α | % optical density between cytokines and β-actin
| • IL-1β | % optical density between cytokines and β-actin
| • IL-2 m-RNA | % optical density between cytokines and β-actin
Homan van der Heide, 1990a | None | None
2271089
RCT: Parallel
Homan van der Heide, 1990b | • TRVR (= total renal vascular resistance) | [MAP/RBF]*80 (dyn*sec/cm5), RBF=RPF/(1-ht) platelet / lt
2316014 | • Platelets
RCT: Parallel
Homan van der Heide, 1992 | • Median day of rejection onset | Dose (g) /rejection
1496538 | • Additional methylprednisolone needed | % /rejection
RCT: Parallel | • ATg treatment
Homan van der Heide, 1993 | • Use of antihypertensive drugs | dose (g)
8350886 | • Additional methylprednisolone per patient | dose (g)
RCT: Parallel | • Methylprednisolone per rejection episode | (median) days
| • Length of hospitalization during 1 year | Mean number
| • Number of second admissions
Kooijmans-Coutinho, 1996 | None | None
8704119
RCT: Parallel
Maachi, 1995 | None | None
7879202
RCT: Parallel
Ng, 2003 | None | None
12809474
Case report
Rodriguez, 1997 | • Apo A | mg%
Cochrane 00197406 | • Apo B | mg%
RCT: Parallel
Santos, 2000 | • Number of anti-hypertensive drugs | absolute number
11134724
RCT: Parallel
Schut, 1993 | • Elongation index | Indicate deformable RBC
8210973 | • Endothelin level | When increased indicate stimulation of endothelial cell production to synthesize endothelin during CsA treatment (pg/ml)
Schut, 1993 | • Plasma arachidonic acid | Analysis of plasma fatty acid composition (mol%)
EMBASE | • Plasminogen activator activity | Ratio of activity before/after DDAVP
1993223288 | • Plasmin-α2-antiplasmin ratio | Ratio of complexes before/after DDAVP- indication of plasmin generation t-PA Ag - u-PA Ag - PAI-1 Ag measurements
Schut, 1992 | • Defects for impaired increase in plasminogen activator activity
14621869
Levi, 1992
1465791
RCT: Cross-over
Sweny, 1993 | • Total platelet count | % fall in optical density resulted from the addition of the aggregating agents ADP, adrenaline and collagen release by platelets incubated with aggregating agents at 37oC
8470281 | • platelet aggregation
Sweny, 1989 | • Thromboxane A2 release
2517328
Single-arm cohort
Urakaze, 1989 | • Blood cell count | mg/dl
2812166 | • SGOT | mg/dl
Urakaze, 1989 | • Uric acid | Max OD%
2652688 | • platelet aggregation | ml/min
RCT: Parallel | • RBC filterability | [PGI 2/3-M / TXB 2/3-M] ratio
| • Urinary metabolites of eicosanoids
Yoa, 1994 | • Deformability index of RBC | Ability of RBC to cross the capillary system (hemorheological modification that explain CsA nephrotoxicity)
EMBASE | • Apo A1 | g/lt
1994288697 | • Apo B | g/lt
RCT: Parallel
Zolotarski, 2003 | • Sodium
12644071 | • Potassium
Single-arm cohort | • Ionized Calcium
| • Liver function

DTPA, diethylenetriamine pentoacetic acid; PAH, para-aminohippurate; CPK, creatinine phosphokinase

Evidence Table Ie. Results for Omega-3 Fatty Acids and Kidney Transplantation

Author, year | Results | | | | | | | | | Bias/Limitations/Comments
UI# | Outcome | Cohort | N | Baseline | Unit | SD/SE/range | Follow-up | P W/in | P Btw
Design
Bennett, 1995 | SBP | Fish oil 9 g/d | 22 | 140±19 | mmHg | SD | 148±21 | NS | ND | Results for high and low dose placebo groups were combined.
7871564 | | Fish oil 18 g/d | 18 | 145±23 | | | 137±10 | NS | ND | Authors conclude that delayed administration appears to have only minor clinical benefits.
RCT: Parallel | | Placebo | 50 | 138±22 | | | 134±18 | NS | | Poor compliance may have contributed to negative results. Paper had poor reporting but study appeared to be conducted carefully.
| DBP | Fish oil 9 g/d | 22 | 86±13 | mmHg | SD | 76±13 | <0.05 | ND
| | Fish oil 18 g/d | 18 | 91±11 | | | 82±8 | <0.05 | ND
| | Placebo | 50 | 83±13 | | | 85±9 | NS
| GFR (DTPA) | Fish oil 9 g/d | 22 | 73±26 | ml/min | SD | 59±28 | NS | ND
| | Fish oil 18 g/d | 18 | 68±38 | | | 54±24 | NS | ND
| | Placebo | 50 | 62±20 | | | 58±13 | NS
| LDL | Fish oil 9 g/d | 22 | 176±26 | mg/dl | SD | 187±18 | <0.05 | ND
| | Fish oil 18 g/d | 18 | 133±18 | | | 141±19 | NS | ND
| | Placebo | 50 | 146±27 | | | 144±24 | NS
| VLDL | Fish oil 9 g/d | 22 | 46±10 | mg/dl | SD | 38±9 | NS | ND
| | Fish oil 18 g/d | 18 | 39±8 | | | 36±10 | NS | ND
| | Placebo | 50 | 39±10 | | | 43±8 | NS
| HDL | Fish oil 9 g/d | 22 | 59±11 | mg/dl | SD | 56±9 | NS | ND
| | Fish oil 18 g/d | 18 | 58±7 | | | 52±8 | NS | ND
| | Placebo | 50 | 59±8 | | | 52±9 | NS
| Rejection episodes | Fish oil 9 g/d | 22 | 0 episodes | | | | | ND
| | Fish oil 18 g/d | 18 | 8 episodes in 2 patients. However, plasma EPA values in these patients were not different from values in placebo, indicating noncompliance. | | | | | ND
| | Placebo | 50 | 5 episodes in 2 patients (5 physician-diagnosed episodes of acute CsA nephrotoxicity.)
| Graft survival | All grafts functioned for the entire 6-month period.
| There was a weak negative correlation (r=-0.36, p<0.01) b/w percentage of plasma EPA levels and urinary thromboxane B2. After intervention, plasma EPA levels were different from placebo (p<0.01), but not different b/w the two fish-oil treatment groups.
| Bleeding time at baseline in the patients randomized to high dose EPA was significantly higher than that in low dose EPA patients and in placebo patients. After intervention, this group had a further increased bleeding time, while the changes in other groups did not differ.
Berthoux, 1992 | Outcome | Cohort | N | 3 months | Unit | SD/SE/range | Follow-up | P W/in | P Btw | No baseline measures. All outcomes compared 12-month to 3-month measures.
1465872 | GFR | Fish oil | 14 | 44.6±16.2 | ml/min/1.73m^2^ | SD | 42±15.1 | ND | ND | ANOVA 2 factors (time and fish oil) analysis is equal to multiple t-test adjusting for time. A significant p-value means that fish oil and control arms are significantly different at any time point. It's not a test for the significance of net change.
RCT: Parallel | | Control | 15 | 31.8±10.7 | | | 29.0±11.9 | ND | | Compliance not specifically checked.
| CsA level | Fish oil | 14 | 433±210 | ng/mL | SD | 462±193 | NS | ND | No blinding. No placebo used.
| | Control | 15 | 472±212 | | | 530±217 | NS | | 1-year graft survival lower than would be expected.
| CsA dose | Fish oil | 14 | 449±89 | mg/24h | SD | 385±72 | NS | ND | Two CsA protocols used, initially high-dose and then a low dose.
| | Control | 15 | 453±127 | | | 378±104 | NS
| Tg | Fish oil | 14 | 1.56±0.88 | mmol/L | SD | 1.87±1.08 | ND | ND
| | Control | 15 | 2.27±0.87 | | | 2.59±1.66 | ND
| Total cholesterol | Fish oil | 14 | 6.26±0.58 | mmol/L | SD | 6.76±1.20 | ND | ND
| | Control | 15 | 6.05±1.28 | | | 7.12±1.85 | ND
| Graft survival | Fish oil | 11/14 | | | | | | NS
| | Control | 11/15
| Rejection episodes | Fish oil | 15 rejections in 9 patients (out of 14 total) | | | | | | NS
| | Control | 13 rejections in 10 patients (out of 15 total)
| HNT* | Fish oil | 7/11 | | | | | | ND
| | Control | 8/11
| * Hypertension was not defined other than by use of antihypertension drugs
| Patient acceptance excellent except one patient developed vomiting and nausea and dropped out.
Busnach, 1998 | Total cholesterol | Fish oil | 16 | 202±13.1 | mg/dl | SE | 228±11 | ND | ND
9589380 | | Olive oil | 19 | 188±8.9 | | | 223±11 | ND
RCT: Parallel | Tg | Fish oil | 16 | 208±41.9 | mg/dl | SE | 120±12 | <0.05 | ND
| | Olive oil | 19 | 147±15.1 | | | 166±21 | NS
| HDL | Fish oil | 16 | 45.7±3.7 | mg/dl | SE | 59±4 | NS | ND
| | Olive oil | 19 | 52.7±4.8 | | | 52±2 | NS
| CsA dose | Fish oil | 16 | 6.76±0.28 | mg/kg | SE | 4.30±0.16 | ND | ND
| | Olive oil | 19 | 7.28±0.27 | | | 4.38±0.15 | ND
| CsA level (max) | Fish oil | 16 | 1329±647 | ng/ml | SE | 976±367 | ND | ND
| | Olive oil | 19 | 1049±468 | | | 934±345 | ND
| CsA level (min) | Fish oil | 16 | 252±98 | ng/ml | SE | 252±59 | ND | ND
| | Olive oil | 19 | 260±131 | | | 226±90 | ND
| Graft survival | Fish oil | 17/19 | | | | | | ND
| | Control | 19/21
| Rejection episodes | Fish oil | 3 patients (out of 16 total) within month 1 | | | | | | ND
| | Control | 2 patients (out of 19 total) within month 1; 1 @ month 9
| Mean number of HTN agents | Fish oil | 1.7 (range 0–4) | | | | | | ND
| | Control | 1.8 (range 0–4)
| No significant differences in systolic and diastolic blood pressure at any evaluation point in the two groups, number of antihypertensive agents per patients was similar in each group
| No significant difference in total and CD4 cell counts between groups.
| Five patients in treatment group did not complete study due to noncompliance (1), irreversible acute rejection (1), primary graft not function (1), death due to unrelated causes (hemorrhagic shock from removal of native polycystic kidney and intestinal infarction) (2).
| Two patients in placebo group did not complete the study due to irreversible acute rejection (1) and late irreversible arterial graft
Butani, 2000 | Case report of a 12-year-old boy who underwent a renal treatment for IgA nephropathy . Patient was treated with Aza, corticosteroids and CsA. Two years after treatment, he developed new onset proteinuria and microscopic hematuria. Kidney biopsy showed recurrent IgA nephropathy. Patient treated with prednisone with partial response and side-effects. Thus, he was treated with Max EPA 6 g twice daily. Within 8 weeks, proteinuria declined. By one year, creatinine normalized, with normal urinary protein to creatinine ratio. Patient did not receive ACE inhibitor or NSAIDs. | | | | | | | | | Case report
10910466
Case report
Castro, 1997 | Total cholesterol | Fish oil | 18 | 266±25 | mg/dl | SD | 240±31 | <0.001 | ND | Not specifically designed to measure equivalence.
9351079 | | Simvastatin | 25 | 271±46 | | | 228±49 | <0.001 | | Compliance was not assessed.
RCT: Parallel | HDL | Fish oil | 18 | 63±15 | mg/dl | SD | 53±12 | <0.01 | ND
| | Simvastatin | 25 | 58±14 | | | 56±16 | NS
| LDL | Fish oil | 18 | 162±21 | mg/dl | SD | 158±30 | NS | ND
| | Simvastatin | 25 | 177±40 | | | 144±43 | <0.01
| Tg | Fish oil | 18 | 203±105 | mg/dl | SD | 156±72 | 0.02 | ND
| | Simvastatin | 25 | 180±78 | | | 134±45 | <0.01
| Graft survival | Fish oil | | 18/18
| | Simvastatin | | 25/25
| In fish oil group, there was significant reduction in TC (9.8%), Tg (14.1%), HDL (16.9%). LDL, Lp(a), Apo A1, Apo B remained stable. In simvastatin group after 3 months, significant reductions in TC (15.9%), Tg (15.6%), LDL 18.6%), and Apo B (15.6%). Apo A1 increased(10.4%), no significant changes in HDL and Lp(a).
| Mean body weight remained stable.
| CPK and serum creatinine values remained stable.
| No adverse events with respect to “digestive, musculoskeletal or respiratory systems, skin and skin appendages, special senses or bleeding episodes.”
Grekas, 2001 | Tg | Fish oil | 24 | 169±49 | mg/dl | SD | 124±40 | P<0.03 | - | Same group of patients underwent 2 different treatment protocols with a 4 weeks washout period. May have cumulative therapeutic effects.
11474227 | Total cholesterol | Fish oil | 24 | 229±49 | mg/dl | SD | 187±70 | P<0.02 | - | No data on the EPA and DHA contents of the fish oil (Prolipid) reported. Information was then obtained through personal communication with the primary author.
Single-arm cohort | LDL | Fish oil | 24 | 151±67 | mg/dl | SD | 124±45 | <0.03 | -
| HDL | Fish oil | 24 | 46±16 | mg/dl | SD | 49±12 | NS | -
| CsA level | Fish oil | 24 | 120±50 | ng/ml | SD | No change
| MAP | Fish oil | 24 | 107±3.2 | mmHg | SD | No change
| Graft survival | Fish oil | | 24/24
| Diet and pravastatin significantly lowered total and LDL cholesterol. Diet plus pravastatin plus fish oil significantly lowered total cholesterol, triglycerides, LDL, Apo A1 and Apo B. After reapeated measures analysis of variance, only significant difference was in plasma triglyceride levels after addition of fish oil.
| All patients able to complete the six-month study. None reported adverse effects with respect to the digestive, musculoskeletal and respiratory systems or bleeding episodes. No adverse hepatic effects seen.
| Renal function and blood CSA levels were not changed during and after the study (DATA NOT SHOWN). CPK increased in only one patient.
Hansen, 1995a | GFR | Fish oil | 10 | 61.9±4.8 | ml/min | SE | 64.1±6.3 | NS | - | Reasons for dropouts (2 patients) unclear
8559499 | ERPF | Fish oil | 10 | 277±24 | ml/min | SE | 286±31 | NS | -
Single-arm cohort | MAP | Fish oil | 10 | 106±2 | mmHg | SE | 106±2 | NS | -
| Heart rate | Fish oil | 10 | 63±3 | beats | SE | 61±2 | NS | -
| CsA level | Fish oil | 10 | 245±19 | ng/ml | SE | 237±19 | NS | -
| Fasting serum creatinine | Fish oil | 10 | 124±7 | mmol/L | SE | 125±10 | NS | -
| Fish oil was well tolerated except for a fishy aftertaste.
| ANOVA revealed an overall significant difference in the GFR and ERPF time response between the study days with CsA intake and the study day without CsA intake.
| Two patients dropped out.
Hansen 1995b | CsA level | Fish oil + CsA | 9 | 285±46 | ng/ml | SD | 302±32 | NS | ND | Like their companion study, negative results may reflect that treatment was begun late rather than immediately after transplant.
7703381 | | Fish oil + Aza | 9 | | | | | | | Not randomized and no blinding.
Multiple-arm cohorts | MAP | Fish oil + CsA | 9 | 121±9 | mmHg | SD | 119±9 | NS | ND
| | Fish oil + Aza | 9 | 110±14 | | | 103±12 | <0.05
| Graft survival | Fish oil + CsA | | 9/9
| | Fish oil + Aza | | 9/9
| Fish oil had no effect on ERPF, GFR or clearance of lithium in any group
| No significant difference in urinary excretion of sodium, potassium, creatinine, albumin, 6-Keto-prostaglandin F1a, or thromboxane B2 before and during supplementation.
| No affect on bioavailability of CsA.
| GFR and lithium clearance increased significantly to the same extent before and during fish oil supplementation.
| Fish oils were well-tolerated, excellent compliance, fishy aftertaste only problem.
Hernandez 2002 | GFR (Cr-EDTA) | Fish oil | 45 | 50.8±17 | ml/min/1.73m^2^ | SD | 61±35 | ND | ND | ATg was used as induction therapy.
11981081 | | Soy oil | 40 | 51.6±22 | | | 59±14.4 | ND | | Only patients who had surviving allografts at any time during the study were included in the final analysis of interleukin expression and renal function.
RCT: Parallel | Total cholesterol | Fish oil | 45 | 187±49 | mg/dl | SD | 234.4±34 | ND | ND | 4 patients in the fish oil group were excluded from final analysis: 1 patient in the fish oil group lost the allograft due to acute postoperative arterial thrombosis and 3 additional patients lost their grafts due to acute rejection.
| | Soy oil | 40 | 175.6±44 | | | 251.4±42.2 | ND | | 2 patients in the control group were excluded from the final analysis due to lost grafts as a consequence of acute rejection.
| Tg | Fish oil | 45 | 203±102 | mg/dl | SD | 167±82 | ND | ND
| | Soy oil | 40 | 164±65.7 | | | 174±78.5 | ND
| MAP | Fish oil | 45 | 106±8.9 | mmHg | SD | 105.3±11.8 | ND | ND
| | Soy oil | 40 | 109±9.3 | | | 110±11.7 | ND
| CsA dose | Fish oil | 45 | 4.2±1.7 | mg/kg/d | SD | 3.8±1.4 | ND | ND
| | Soy oil | 40 | 4.1±1.3 | | | 4.1±1.7 | ND
| CsA levels | Fish oil | 45 | 244.1±103 | ng/ml | SD | 239.1±87.1 | ND | ND
| | Soy oil | 40 | 263.7±104.7 | | | 258.2±63 | ND
| Rejection episodes | Fish oil | 45 | 16 @ month 1, 4 b/w months 1 and 3; 0 b/w months 4 and 12 | | | | | NS
| | Soy oil | 40 | 12 @ month 1, 4 b/w months 1 and 3; 3 b/w months 4 and 12
| 1-year Graft survival | Fish oil | 86% (39/45) | | | | | | NS
| | Soy oil | 89% (36/40)
| Expression of TNF-alpha, IL-1beta and IL-2 mRNA in those without acute rejection did not differ.
| TNF alpha at rejection episodes significantly lower in fish oil group.
| IL-1 beta after rejection episodes (2 weeks) significantly lower in fish oil group.
| No differences in serum creatinine, GFR, or proteinuria in those with and without rejection episodes in fish oil or control groups.
| No major adverse events observed; only complaint was a fishy aftertaste. No clinical bleeding or any prolonged episode of hematuria following biopsy.
Homan van der Heide, 1990a | GFR (^125^I) | Fish oil | 14 | ND | ml/min | range | 44 (26–60) | ND | ND | All renal hemodynamic studies were performed after 1 month of oil supplement.
2271089 | | Coconut oil | 17 | ND | | | 40 (10–80) | ND | | Multiple subgroup analyses, which appear to be post-hoc without appropriate adjustment.
RCT: Parallel | | Fish oil (no rej episode) | 11 | ND | ml/min | range | 45 (26–60) | ND | ND | Randomization and blinding not described.
| | Coconut oil (no rej episode) | 11 | ND | | | 51 (20–80) | ND
| MAP | Fish oil | 14 | ND | ml/min | range | 106 (82–137) | ND | ND
| | Coconut oil | 17 | ND | | | 107 (80–132) | ND
| | Fish oil (no rej episode) | 11 | ND | mmHg | range | 85 (60–115) | ND | ND
| | Coconut oil (no rej episode) | 11 | ND | | | 90 (75–105) | ND
| CsA levels | Fish oil | 14 | ND | ng/ml | range | 207 (90–275) | ND | ND
| | Coconut oil | 17 | ND | | | 180 (40–295) | ND
| | Fish oil (no rej episode) | 11 | ND | ng/ml | range | 235 (135–275) | ND | ND
| | Coconut oil (no rej episode) | 11 | ND | | | 200 (40–240) | ND
| CsA dose | Fish oil | 14 | ND | mg/kg/d | range | 5.8 (3–10) | ND | ND
| | Coconut oil | 17 | ND | | | 6.0 (2–9) | ND
| | Fish oil (no rej episode) | 11 | ND | mg/kg/d | range | 5.6 (3–8) | ND | ND
| | Coconut oil (no rej episode) | 11 | ND | | | 6.0 (2–9) | ND
| Rejection episodes | Fish oil | 3 (out of 14) @ month 1 | | | | | | ND
| | Coconut oil | 6 (out of 17) @ month 1
| GFR, ERPF and FF were measured at 1-month post-treatment, after dopamine, following amino acids, and during the combination of both. No significant differences in GFR and ERPF. Same values provided after stratifying patients as having had a rejection episode or not. There was a significant difference in the increase in the GFR following amino acid infusion between the treatment patients without rejection and control patients without rejection.
Homan van der Heide, 1990b | GFR (^125^I) | Fish oil | 11 | 56 (24–79) | ml/min | range | 68 (29–93) | <0.01 | <0.01
2316014 | | Corn oil | 10 | 64.5 (30–92) | | | 60 (32–84) | NS
RCT: Parallel | MAP | Fish oil | 11 | 106 (93–116) | mmHg | range | 98 (76–106) | <0.01 | <0.01
| | Corn oil | 10 | 106.5 (103–116) | | | 109 (103–116) | NS
| CsA levels | Fish oil | 11 | 90 (65–125) | ng/ml | range | 90 (65–125) | ND | NS
| | Corn oil | 10 | 133 (45–265) | | | 136 (55–235) | ND
| There was no change in platelet count.
| 2 of the 12 patients in the corn oil group withdrew from the study because they suffered from a histologically confirmed rejection episode.
| 1 of the 12 patients in the fish oil group was excluded from further analysis because of noncompliance.
Homan van der Heide, 1992 | Outcome | Cohort | N | Baseline | Unit | SD/SE/range | Follow-up Median value | P W/in | P Btw | Significant difference in the number of mismatches on HLA-A and B in the coconut oil-treated patients receiving more poorly matched grafts.
1496538 | GFR (Cr-clearance) | Fish oil | 39 | ND | ml/min | range | 53 (22–80) | ND | ND
RCT: Parallel | | Coconut oil | 47 | ND | | | 49 (12–88) | ND
| | Fish oil (rejection episode) | 14 | 41.5 | ml/min | range | 43 (22–69) | NS | ND
| | Coconut oil (rej episode) | 12 | 39 | | | 27 (12–50) | <0.05
| | Fish oil (no rej episode) | 25 | ND | ml/min | range | 59 (25–80) | ND | ND
| | Coconut oil (no rej episode) | 35 | ND | | | 58 (24–88) | ND
| MAP | Fish oil | 39 | ND | mmHg | range | 105 (76–137) | ND | ND
| | Coconut oil | 47 | ND | | | 108 (76–142) | ND
| | Fish oil (rejection episode) | 14 | ND | mmHg | range | 107 (90–120) | ND | ND
| | Coconut oil (rej episode) | 12 | ND | | | 112 (100–130) | ND
| | Fish oil (no rej episode) | 25 | ND | mmHg | range | 106 (76–137) | ND | ND
| | Coconut oil (no rej episode) | 35 | ND | | | 106 (76–142) | ND
| CsA levels | Fish oil | 39 | ND | ng/ml | range | 222 (75–565) | ND | ND
| | Coconut oil | 47 | ND | | | 200 (35–490) | ND
| | Fish oil (rejection episode) | 14 | ND | ng/ml | range | 150 (75–390) | ND | ND
| | Coconut oil (rej episode) | 12 | ND | | | 182 (70–295) | ND
| | Fish oil (no rej episode) | 25 | ND | ng/ml | range | 251 (80–565) | ND | ND
| | Coconut oil (no rej episode) | 35 | ND | | | 200 (35–490) | ND
| CsA dose | Fish oil | 39 | ND | ng/ml | range | 6 (3–9) | ND | ND
| | Coconut oil | 47 | ND | | | 6 (2–9) | ND
| | Fish oil (rejection episode) | 14 | ND | mg/kg/d | range | 6 (2–10) | ND | ND
| | Coconut oil (rej episode) | 12 | ND | | | 5.5 (3–11) | ND
| | Fish oil (no rej episode) | 25 | ND | mg/kg/d | range | 6 (2–10) | ND | ND
| | Coconut oil (no rej episode) | 35 | ND | | | 6 (3–11) | ND
| Graft survival | Fish oil | 40 | 1/40 @ month 1 | | | | | NS
| | Coconut oil | 48 | 1/48 @ month 1
| Rejection episodes | Fish oil | 40 | 15/40 @ month 1 | | | | | NS
| | Coconut oil | 48 | 12/48 @ month 1
Homan van der Heide, 1993 | GFR (^125^I) | Fish oil | 30 | 42 | ml/min | ND | 53 | ND | ND | In discussion section, authors note that the greatest difference in the incidence of acute rejection occurred between days 30 and 90, a fact that may be attributed to the time lag needed to incorporate n-3 fatty acids into the phospholipids of various cell membranes.
8350886 | | Coconut oil | 28 | 32 | | | 40 | ND | | Acute postoperative oliguria or anuria significantly less frequent in the fish oil group. Perhaps they had better grafts to begin with?
RCT: Parallel | MAP | Fish oil | 30 | 100 (75–138) | mmHg | range | 103 (80–141) | ND | ND | In discussion section authors state that results were similar when such patients were excluded. Second part of study not placebo controlled. Outcomes such as need for rehospitalization may be subject to bias.
| | Coconut oil | 28 | 108 (89–135) | | | 118 (98–131) | ND
| CsA levels | Fish oil | 30 | 245 (55–565) | ng/ml | range | 140 (50–321) | ND | ND
| | Coconut oil | 28 | 285 (90–490) | | | 143 (80–245) | ND
| CsA dose | Fish oil | 30 | 6 (3–8) | mg/kg/d | range | 5 (2–7) | ND | ND
| | Coconut oil | 28 | 6 (3–8) | | | 4 (1–10) | ND
| Graf survival | Fish oil | 33 | 30/31 | | | | | 0.097
| | Coconut oil | 33 | 28/32
| Rejection episodes | Fish oil | 33 | 6 episodes @ month 1, 1 episode b/w month 2 and 3; 0 episode b/w month 4 and 6; 1 episode b/w month 6 and 12
| | Coconut oil | 33 | 10 episodes @ month 1, 9 episodes b/w month 2 and 3; 0 episode b/w month 4 and 6; 1 episode b/w month 6 and 12
| One-year graft survival tended to be better in fish oil group but results did not achieve statistical significance.
| Fish oil group had significantly lower MAP and required significantly less antihypertensive therapy at all times.
| Median length of hospitalization shorter in fish oil group but did not achieve statistical significance.
| Mean number of second admissions significantly less in fish oil group.
| One patient stopped because of pyrosis, swallowing problems and fishy aftertaste.
| All patient with surviving grafts were included in the analysis of renal function and MAP (n=58), whereas the analysis of graft survival included all patients (n=66).
| In the fish-oil group, 1 patient lost the renal graft because of acute postoperative arterial thrombosis, 1 patient stopped taking fish oil because of its fishy aftertaste, and 1 patient declined to undergo renal-function tests during follow-up.
| In the control group, 1 patient lost the graft because of a technical failure, 3 patients lost their grafts because of therapy-resistant rejection, and 1 patient died of myocardial infarction.
Kooijmans-Coutinho, 1996 | GFR (^125^I) | Fish oil | 14 | 46.1± 18.9 | ml/min/1.73m^2^ | SD | 54.4± 21.6 | ND | ND | Compliance was not measured.
8704119 | | Coconut oil | 17 | 43.2 ±16.9 | | | 52.5 ±18.9 | ND | | Of the 50 patients included in the trial, 31 were evaluated 12 months after transplantation. The 19 patients were lost to follow-up because of various reasons including graft loss, death, non-compliance, pregnancy or concomitant illness.
RCT: Parallel | MAP | Fish oil | 20 | 103.8 ±14.4 | mmHg | SD | 104.3 ±10.8 | ND | ND | Graft-survival analysis was based on the intention to treat (N=50)
| | Coconut oil | 18 | 106.8± 9.9 | | | 106.3 ±11.7 | ND
| CsA levels | Fish oil | 20 | 288.3± 124.5 | ng/ml | SD | 109 ±37.6 | ND | ND
| | Coconut oil | 18 | 341.7 ±137.5 | | | 113.6± 31.6 | ND
| CsA dose | Fish oil | 20 | 6.5± 1.8 | mg/kg/d | SD | 3.9 ±1.4 | ND | ND
| | Coconut oil | 18 | 7.2 ±2.6 | | | 4.4 ±1.6 | ND
| Graft survival | Fish oil | | 20/24 | | | | | ND
| | Coconut oil | | 20/23
| Incidence of acute rejection after one month same for both groups (fish oil vs. control: 11/25 vs. 11/25 respectively). Between months 1 and 3 significantly more patients in the fish oil group experience rejection (13/24 vs. 3/23 respectively, p=0.003). Between months 3 and 12, rejection occurred in 14% in both groups (3/22 vs. 3/22 respectively).
| Three patients stopped because of gastric complaints and swallowing problems. One complained of fishy aftertaste and stopped taking drug (on coconut oil, however).
| 5 patients in each group experienced graft loss within 1 yr of transplantation. In fish oil group, one graft was lost because of primary function failure, 3 were lost as a result of therapy-resistant rejection, and 1 patient died with a functional graft. In placebo group, 2 patients died with a functioning graft and 3 patients lost their graft as a result of rejection resistant to treatment.
Maachi, 1995 | GFR | Fish oil | 40 | 47.5±18.1 (3months) | ml/min/1.73m^2^ | SD | 50.1±18.0 | NS | ND | No specific measurement of blood EPA or DHA to assure compliance.
7879202 | | Control | 40 | 42.5±18.1 (3months) | | | 43.0±14.0 | NS | | No placebo controlled arm.
RCT: Parallel | CsA dose | Fish oil | 40 | 5.7±1.8 (3months) | mg/kg/d | SD | 4.5±1.4 | NS | ND
| | Control | 40 | 6.3±2.0 (3months) | | | 5.1±1.6 | NS
| CsA levels | Fish oil | 40 | 437.6±171 (3months) | ng/ml | SD | 438.2±160 | NS | ND
| | Control | 40 | 420.0±142 (3months) | | | 418.5±133 | NS
| Tg | Fish oil | 40 | 1.55±0.71 (3months) | mmol/L | SD | 1.34±0.62 | ND | ND
| | Control | 40 | 1.91±0.75 (3months) | | | 2.00±1.14 | ND
| Total cholesterol | Fish oil | 40 | 6.03±1.11 (3months) | mmol/L | SD | 6.01±1.20 | ND | ND
| | Control | 40 | 5.66±1.15 (3months) | | | 6.12±1.41 | ND
| Rejection episodes | Fish oil | | 29 episodes in 20 patients | | | | | NS
| | Control | | 32 episodes in 25 patients
| Graft survival | Fish oil | | 35/40 | | | | | ND
| | Control | | 35/40
Ng 2003 | Case report of a 34 year old man who had a kidney transplant in May 1996. He did well till 1991 when he developed IgA nephropathy. After 1 year 5 months peritoneal dialysis, he received a 2^nd^ transplant. Immunosuppressive medications of prednisone and CsA were identical to his prior regimen. After 5 years his nephrotic syndrome recurred, verified by biopsy. Fish oil treatment commenced and stabilized his proteinuria. His kidney function is “well preserved”. He began angiotensin-receptor blocker in 1999 but this did not further improve his proteinuria. | | | | | | | | | Case report
12809474
Case report
Rodriguez, 1997 | Tg | Fish oil | 18 | 260.88±99.14 | mg/dl | SD | 197.37±90.15 | <0.01 | <0.05
Cochrane 00197406 | | lovastatin | 16 | 235.26±102.5 | | | 199.7±96.3 | NS
RCT: Parallel | HDL | Fish oil | 18 | 48.12±15.56 | mg/dl | SD | 49.23±11.14 | NS | NS
| | lovastatin | 16 | 60.23±15.77 | | | 60.36±13 | NS
| LDL | Fish oil | 18 | 104.59±46.12 | mg/dl | SD | 97.86±52.94 | NS | <0.01
| | lovastatin | 16 | 120.64±52.6 | | | 78.17±42.98 | <0.01
| Total cholesterol | Fish oil | 18 | 271.5±29.73 | mg/dl | SD | 237.25±33.77 | <0.001 | <0.01
| | lovastatin | 16 | 278±43.15 | | | 221±38.38 | <0.001
| Total cholesterol decreased significantly in both groups but to a greater extent and faster in the lovastatin group.
| Both groups showed rise in HDL cholesterol ratio and a significant decrease in the Apo B/Apo A ratio. Only lovastatin group had a significant decrease of LDL-cholesterol. Only fish oil had significant decrease in Tg.
| One dropout in fish oil group due to GI intolerance.
Santos, 2000 | Outcome | Cohort | N | Baseline | Unit | SD/SE/range | Follow-up change | P W/in | P Btw | Randomization and blinding methods not described explicitly.
11134724 | CsA levels | Fish oil | 15 | ND | ng/mL | SD | 171± 31 | ND | ND
RCT: Parallel | | Placebo | 15 | ND | | | 151 ±32 | ND
| CsA dose | Fish oil | 15 | ND | mg/kg/d | SD | 3.8 ± 0.6 | ND | ND
| | Placebo | 15 | ND | | | 4.0 ± 2.0 | ND
| GFR (Cr-EDTA) | Fish oil | 15 | ND | ml/min | SD | 92.6±37.6 | ND | ND
| | Placebo | 15 | ND | | | 88.5±20.4 | ND
| Total cholesterol | Fish oil | 15 | 155±35 | mg/dl | SD | 210±41 | ND | ND
| | Placebo | 15 | 150±33 | | | 218±43 | ND
| Tg | Fish oil | 15 | 150±83 | mg/dl | SD | 165±46 | ND | ND
| | Placebo | 15 | 161±91 | | | 130±61 | ND
| LDL | Fish oil | 15 | 100±37 | mg/dl | SD | 131±38 | ND | ND
| | Placebo | 15 | 118±29 | | | 140±38 | ND
| HDL | Fish oil | 15 | 36±9 | mg/dl | SD | 5015 | ND | ND
| | Placebo | 15 | 39±9 | | | 46±13 | ND
| SBP | Fish oil | 15 | 139.3±14.8 | mmHg | SD | 134±18 | ND | ND
| | Placebo | 15 | 143.8 ±21.2 | | | 133±20 | ND
| DBP | Fish oil | 15 | 82.3 ±9.5 | mmHg | SD | 80±28 | ND | ND
| | Placebo | 15 | 83.5 ±13.2 | | | 78±12 | ND
| Rejection episodes | Fish oil | 15 | 5 episodes in 4 patients | | | | | ND
| | Placebo | 15 | 8 episodes in 6 patients
| All grafts survived.
| Use of antihypertensives significantly less in fish oil group.
| None reported adverse effects with respect to digestive systems or bleeding episodes. There were no variations in the hematologic profile and glycemic control in both groups.
Schut, 1993 | Outcome | Cohort | N | Baseline | Unit | SD/SE/range | Follow-up @ 4 months | Follow-up @ 8 months | P Win | Originally the study was crossover design (fish oil crossover to corn oil), but results were not analyzed properly.
8210973 | GFR (^125^I) | F-C + CsA | 10 | 57 ±16 | ml/min | SD | 46±14 | 48± 21 | NS | No washout period (crossover @ 4months). Therefore, for the purpose of this review, only data from baseline to 4 months should be used. Data should be treated as a 4-month fish oil vs. corn oil parallel trial.
Schut, 1993 | | C-F + CsA | 10 | 58± 19 | | | 57±16 | 65 ±19 | NS
EMBASE 1993223288 | | F-C + CsA + Pred | 10 | 50±19 | ml/min | SD | 56±20 | 52± 20 | NS
Schut, 1992 | | C-F + CsA + Pred | 10 | 67±7 | | | 70±8 | 73± 10 | NS
14621869 | | F-C + Aza + Pred | 9 | 62±11 | ml/min | SD | 63±7 | 65 ±11 | NS
Levi, 1992 | | C-F + Aza + Pred | 9 | 76±17 | | | 72±13 | 74 ±16 | NS
1465791 | F-C = subgroup which is supplemented first with fish oil, afterwards with corn oil; C-F = subgroup which is supplemented first with corn oil, afterwards with fish oil.
RCT: Crossover | Blood pressure: In none of patients was antihypertensive treatment changed during the study.
| Plasma phospholipids concentration showed significant increase in omega-3 fatty acids suggesting good compliance.
Sweny, 1993 | Outcome | Cohort | N | Baseline | Unit | SD/SE/range | Follow-up change | P W/in | P Btw
8470281 | Tg | Fish oil | 14 | 3.14±1.69 | mmol/l | SD | 1.98± 0.78 | <0.003 | -
Sweny, 1989 | Total cholesterol | Fish oil | 14 | 7.52±2.09 | mmol/l | SD | 7.99 ±2.05 | NS | -
2517328 | Proteinuria | Fish oil | 14 | 1.21±1.78 | g/24 | SD | 1.64±2.43 | NS
Single-arm cohort | Mean decline of renal function demonstrates a slowing of the rate of decline during the 6-month period on fish oil supplements.
| Fish oil did not affect total platelet count but platelet aggregation reduced.
Urakaze, 1989 | Tg | Fish oil | 14 | 148 (96, 228) | mg/dl | (-SD +SD) | 116 (90, 151) | <0.05 | NS | Urakaze 1989 (UI#2652688) was published in Transplantation Proceedings.
2812166 | | Control | 16 | 137 (90, 211) | | | 142 (104, 194) | NS | | Control received no placebo or treatment.
Urakaze, 1989 | SBP | Fish oil | 14 | 141± 11 | mmHg | SD | 144± 13 | NS | NS
2652688 | | Control | 16 | 147± 19 | | | 149 ±24 | NS
RCT: Parallel | DBP | Fish oil | 14 | 85± 9 | mmHg | SD | 87 ±11 | <0.05 | NS
| | Control | 16 | 85 ±10 | | | 92±12 | <0.05
| Serum Creatinine | Fish oil | 14 | 1.80 (1.35, 2.39) | mg/dl | (-SD +SD) | 1.78 (1.32, 2.23) | NS | NS
| | Control | 16 | 1.78 (1.26, 2.52) | | | 1.79 (1.22, 2.65) | NS
| Rejection episodes | Fish oil | | 0/14
| | Control | | 0/16
| The levels of total cholesterol were not changed in either group [data not shown].
| “Good compliance in fish oil concentrate confirmed in each patient in treatment group by checking increase in EPA in RBC membrane lipids”. Values were not given.
| Change in epinephrine-induced platelet aggregation (but not collagen or ADP induced platelet aggregation) significantly different.
| RBC filterability increased significantly in treatment group.
| Ratio of PGI-m to TXB-M significantly higher in treated versus control group.
| No significant differences in those treated and not treated with CsA.
| Patients complained of fishy eructation and one patient suffered from diarrhea for the first few days, but all soon began to tolerate the fish oil capsules well.
Yoa, 1994 | Total cholesterol | Fish oil | 12 | 208±65 | mg/dl | SD | 216±67 | NS | ND
EMBASE 1994288697 | | Olive oil | 11 | 235±36 | | | 235±37 | NS
RCT: Parallel | HDL | Fish oil | 12 | 62±30 | mg/dl | SD | 64±39 | NS | ND
| | Olive oil | 11 | 53±14 | | | 56±16 | NS
| LDL+VLDL | Fish oil | 12 | 146±54 | mg/dl | SD | 153±49 | NS | ND
| | Olive oil | 11 | 182±36 | | | 178±32 | NS
| Tg | Fish oil | 12 | 133±76 | mg/dl | SD | 119±66 | NS | ND
| | Olive oil | 11 | 145±70 | | | 122±46 | NS
| Apo A1 decreased after olive oil. Apo B increased after fish oil.
| RBC deformability increased significantly after fish oil.
Zolotarski, 2003 | Serum Creatinine | Fish oil | 8 | 4.35±1.2 | mg/dl | ND | 1.59±0.73 | <0.05 | - | Published in Transplantation Proceedings
12644071 | BUN | Fish oil | 8 | 122±61 | mg/dl | ND | 102±47 | NS | -
Single-arm cohort | Tg | Fish oil | 8 | 159±101 | mg/dl | ND | 170±45 | NS | -

MAP = mean arterial pressure; SBP = systolic blood pressure; DBP = diastolic blood pressure; HDL = high density lipoprotein; LDL = low density lipoprotein; VLDL = very low density lipoprotein; HTN = hypertension; Tg = triglyceride

Table II Evidence Table. Studies for Omega-3 Fatty Acids and Heart Transplantation

Study Characteristics | Eligibility Criteria | Omega-3 FA Intervention | Compliance | Control
1. Andreassen, 1997 (UI#9137231)
Part I. Study Characteristics
N3 enrolled: 15 | Inclusion criteria: consecutive orthotopic heart transplant recipients | Omacor, Pronova AS, Oslo, Norway | Capsule counts and determination of serum phospholipid fatty acids | Corn oil
Control enrolled: 15 | Exclusion criteria: ND | EPA: 1.86 g/day
Age, N3: 29±2 SE (14 patients) | | DHA: 1.512 g/day
Age, control: 33±3 SE (14 patients) | | Start: day 4 posttransplant
% Male, N3: 73 (14 patients)
% Male, control: 85 (14 patients)
Duration: 6 months
Country: Norway
Site: 1
Study Design: RCT: Parallel
Concomitant Treatments | | | | Outcome Metric
1. Andreassen, 1997 (UI#9137231)
Part II. Concomitant Treatments and Outcomes Studied
Immunosuppressive therapy: | | | | A. Survival and rejection episodes | Died of vascular rejection
Induction therapy | Maintenance | Trough CsA levels | Anti-rejection therapy | B. Renal function | Creatinine clearance
CsA 6mg/kg body weight | CsA tapered off according to the department rejection protocol | ND | boluses of methylprednisolone and, if necessary, rabbit anti-thymocyte globulin. | C. New onset diseases or conditions: | ND
Aza 2mg/kg/day | Prednisolone tapered off to 0.1mg/kg/day over 2 months | | | D. CVD risk factors | SBP (mm Hg), DBP (mm Hg)
Prednisolone 0.2mg/kg/day | | | | | 24-hr hypertensive load (mm Hg)
Anti-hypertensive Drugs | | | | | Total cholesterol (mg/dl), HDL (mg/dl), TG (mg/dl)
Enalapril as needed Dose: ND | | | | E. Infections: | ND
Lipid-lowering Drugs: | | | | F. Drug pharmacokinetics: | Additional antihypertensive treatment after 6 months treatment
ND | | | | | CsA dose
| | | | | Prednisolone dose
| | | | G. Other outcomes: | Hyperemia response, including rest perfusion, peak hyperemia, time to recovery, and perfusion debt repayment area.
Results | | | | | | | | | Bias / Limitations / Comments
Outcome | Cohort | N | Baseline | Unit | SD /SE /range | Follow-up | P W/in | P Btw
1. Andreassen, 1997 (UI#9137231)
Part III. Results
Cr clearance | Fish oil | 14 | 57±5 | ml/min | SE | 81±5 | P<0.05 | ND
| Corn oil | 14 | 55±4 | | | 74±8 | P<0.05
SBP | Fish oil | 14 | 134±5 | mmHg | SE | 135±5 | ND | P<0.01
| Corn oil | 14 | 126±5 | | | 140±4 | ND
DBP | Fish oil | 14 | 73±3 | mmHg | SE | 85±4 | ND | P<0.01
| Corn oil | 14 | 70±2 | | | 89±3 | ND
Total cholesterol | Fish oil | 14 | 193±15 | mg/dl | SE | 247±16 | <0.01 | NS
| Corn oil | 14 | 208±19 | | | 290±16 | <0.01
Triglycerides | Fish oil | 14 | 181±29 | mg/dl | SE | 124±27 | P<0.05 | P<0.05
| Corn oil | 14 | 183±11 | | | 197±31 | NS
HDL | Fish oil | 14 | 30±3 | mg/dl | SE | 52±5 | P<0.01 | NS
| Corn oil | 14 | 32±4 | | | 52±4 | P<0.01
CsA dose | Fish oil | 14 | 5.1±0.3 | mg/kg | SE | 3.7±0.3 | ND | NS
| Corn oil | 14 | 5.5±0.4 | | | 3.5±0.2 | ND
CsA level | Fish oil | 14 | 342±12 | ng/ml | SE | 190±11 | ND | NS
| Corn oil | 14 | 341±19 | | | 183±5 | ND
Graft survival | Fish oil | 14/15
| Corn oil | 14/15
One patient in each group (n=2) died of vascular rejection 7 and 8 weeks postoperatively and were therefore excluded from the final analyses.
One patient in treated group and three patients in placebo group experienced minor strokes.
The relation b/w the change in 24-hr BP and that in serum phospholipids was studied in the treatment group (n=14, but only 12 dots are shown in the figure 4). The change in 24-hr SBP were significantly related to those in EPA and DHA taken together (mg/L) (r=-0.69, p=0.04). There is no significant relationship b/w changes in the hyperemic response and changes in EPA+DHA (mg/L)
Study Characteristics | Eligibility Criteria | Omega-3 FA Intervention | Compliance | Control
2. Barbir, 1992 (UI#1466329)
Part I. Study Characteristics
N3 enrolled: 44 | Inclusion criteria: consecutive cardiac transplant recipients with hyperlipidemia (cholesterol > 6.5 or TG > 2.8 mmol/l or both). | MaxEPA | ND | Bezafibrate 400 mg/day
Control enrolled: 43 | Exclusion criteria: DM, abnormal thyroid function, significant hepatic or renal dysfunction, or symptomatic gallbladder disease with or without cholelithiasis, or those receiving anticoagulants (excluding antiplatelet drugs) or therapy with diuretics or prednisolone where dosage had been changed in the 3 months prior to the study. | EPA: 1.8 g/day
Age, N3: 53±7 SE | | DHA: 1.2 g/day
Age, control: 52±6 SE | | Start: ND
% Male, N3: 91
% Male, control: 88
Duration: 3 months
Country: U.K.
Site: 1
Study Design: non-RCT
Concomitant Treatments | | | | Outcome Metric
2. Barbir, 1992 (UI#1466329)
Part II. Concomitant Treatments and Outcomes Studied
Immunosuppressive therapy: | | | | A. Survival and rejection episodes: | Patient survival, Rejection episodes
Induction therapy | Maintenance | Trough CsA levels | Anti-rejection therapy | B. Renal function: | Serum creatinine
ND | CsA+Aza | ND | ND | | Serum alkaline phosphatase, AST, Urea, Hemoglobin: hemostatic variables, Fibrinogen, Factor II, VII, VIII, IX, X, Antithrombin, Euglobin clot lysis time, TPA, PTA
| N3: 37/44 | | | C. New onset diseases or conditions: | ND
| Control: 38/43 | | | D. CVD risk factors: | Total cholesterol, TG, HDL, LDL
| CsA+Aza+ Prednisone | | | | Apo B, Apo B1, Lpa
| N3: 2/44 | | | E. Infections:
| Control: 2/43 | | | F. Drug pharmacokinetics: | CsA blood levels
| Aza+ Prednisone | | | G. Other outcomes:
| N3: 5/44
| Control: 3/43
Anti-hypertensive Drugs:
ND
Lipid-lowering Drugs:
ND
Results | | | | | | | | | | Bias / Limitations / Comments
Outcome | Cohort | N | Baseline | Unit | SD /SE /range | Follow-up% change | Follow-up | P W/in | P Btw
2. Barbir, 1992 (UI#1466329)
Part III. Results
Total cholesterol | Fish oil | 44 | 7.4±0.2 | mmol/l | SE | 0% | ND | ND | 0.0003 | “open, controlled study”
| Bezafibrate | 43 | 7.2±0.2 | | | -12% | ND | ND
TG | Fish oil | 44 | 3.3±0.2 | mmol/l | SE | -33% | ND | ND | 0.61
| Bezafibrate | 43 | 2.9±0.2 | | | -33% | ND | ND
HDL | Fish oil | 44 | 1.07±0.1 | mmol/l | SE | 0% | ND | ND | 0.0023
| Bezafibrate | 43 | 1.05±0.1 | | | +30% | ND | ND
LDL | Fish oil | 44 | 5.2±0.2 | mmol/l | SE | 0% | ND | ND | 0.0002
| Bezafibrate | 43 | 5.0±0.1 | | | -18% | ND | ND
CsA levels | Fish oil | 44 | 199±16 | ng/mll | SE | ND | 183±12 | ND | 0.12
| Bezafibrate | 43 | 198±12 | | | ND | 144.2±12 | ND
Serum Creatinine | Fish oil | 44 | 139±4 | mmol/l | SE | ND | 140±5 | ND | <0.0001
| Bezafibrate | 43 | 140±4 | | | ND | 176±4 | ND
1 patient died from CHD and 13 patients reported adverse events in fish oil group. Adverse events included dizziness, gastric intolerance, skin irritation, tonsilitis and fatigue. 2 withdrawals because of nausea.
1 acute rejection episode in the Bezafibrate group. 15 of the 43 patients reported adverse events, including nausea, leg cramps, headaches, tonsilitis, and precipitation of gouty arthritis.
Study Characteristics | Eligibility Criteria | Omega-3 FA Intervention | Compliance | Control
3. Fleischhauer, 1993 (UI#8450169)
Part I. Study Characteristics
N3 enrolled: 9 | Inclusion criteria: serum creatinine <2mg/dl. No prior evidence of coronary artery disease, clinically stable condition without evidence of recent rejection, infection or other illness. No history of a bleeding diathesis. | Viking Cod Liver Oil or Multi-EPA caps, Multiway Associates | Bottle and capsule counts and was determined to be >=90% ingested. | No fish oil
Control enrolled: 7 | Control group consisted of 7 heart transplant recipients selected to match the treatment group with respect to the age of the cardiac allograft and baseline clinical and lipid profiles. | EPA: 3.4 g/day
Age, N3: 46.7±3.6SE (7pts) | Exclusion criteria: ND | DHA: 2.3 g/day
Age, control: 48.7±2.4SE | | start: 1–6 years posttransplant
% Male, N3: 86 | | N3: 1.1±0.1 SE
% Male, control: 100 | | control: 1.4±0.2 SE
Duration: 3 weeks
Country: USA
Site: 1
Study Design: non-RCT
Concomitant Treatments | | | | Outcome Metric
3. Fleischhauer, 1993 (UI#8450169)
Part II. Concomitant Treatments and Outcomes Studied
Immunosuppressive therapy: | | | | A. Survival and rejection episodes: | ND
Induction therapy | Maintenance | Trough CsA levels | Anti-rejection therapy | B. Renal functions: | ND
ND | Prednisone mg/day | ND | ND | C. New onset diseases or conditions: | ND
| N3: 9.0±2SE | | | D. CVD risk factors: | Blood pressure (BP)
| Control: 12.3±5.8 | | | | Heart rate
| Immuran mg/day | | | E. Infections: | ND
| N3: 182±29 | | | F. Drug pharmacokinetics:
| Control: 162±22 | | | G. Other outcomes: | % change mean left anterior descending artery diameter vs. baseline: Serial biplane angiography. Compare acetylcholine infused segment with control segment.
| CsA mg/day
| N3: 246±49
| Control: 316±86
Anti-hypertensive Drugs:
Diltiazem mg/day (N3: 3/7pts 200±30SE; control: 2/7pts 180±0)
Hydralazine mg/day (N3: 3/7pts 183±60;) control: 3/7pts 133±17
Enalapril mg/day (N3: 1/7pt 180±0; control: 2/7pts 65±35)
Captopril mg/day (N3: 2/7pts 88±13; control: 0/7)
Clonidine mg/day (N3: 3/7pts 0.3±0; control: 2/7pts 0.3±0)
Lipid-lowering Drugs:
ND
Results | | | | | | | | | Bias / Limitations / Comments
Outcome | Cohort | N | Baseline | Unit | SD /SE /range | Follow-up | P W/in | P Btw
3. Fleischhauer, 1993 (UI#8450169)
Part III. Results
MAP | Fish oil | 7 | 116±4 | mmHg | SE | 107±3 | NS | NS | Control group consisted of 7 heart transplant recipients selected to match the treatment group with respect to the age of the cardiac allograft and baseline clinical and lipid profiles
| Control | 7 | 114±4 | | | 109±3 | NS
Heart rate | Fish oil | 7 | 98±6 | beats/min | SE | 88±4 | NS | NS
| Control | 7 | 93±3 | | | 89±3 | NS
Mean left anterior descending artery diameter | Fish oil | 7
| Control | 7 | | | | 31% less | P<0.01
2 patients in fish oil group were excluded because they had angiographically evident transplant coronary artery disease precluding acetylcholine infusion.
Significant gastrointestinal distress and frequent belching in 1 patient
Study Characteristics | Eligibility Criteria | Omega-3 FA Intervention | Compliance | Control
4. Holm, 2001 (UI#11544435; EMBASE2001241336)
Part I. Study Characteristics
N3 enrolled: 23 | Inclusion criteria: heart transplant patients who were clinically and hemodynamically stable in New York Heart Association functional class I without signs of ongoing rejection or significant concomitant disease. | Omacor, Pronova AS, Oslo, Norway | Capsule counts and determination of serum phospholipid fatty acids | Corn oil
Control enrolled: 22 | Exclusion criteria: ND | EPA: 1.86 g/day
Age, N3: 57±2 SE (21pts) | | DHA: 1.512 g/day
Age, control: 57±2 SE (20pts) | | start: mean 6 years post-transplant, range 1–12 y
% Male, N3: 95 (21pts)
% Male, control: 95 (20pts)
Duration: 12 months
Country: Norway
Site: 1
Study Design: RCT Parallel
Concomitant Treatments | | | | Outcome Metric
4. Holm, 2001 (UI#11544435; EMBASE2001241336)
Part II. Concomitant Treatments and Outcomes Studied
Immunosuppressive therapy: | | | | A. Survival and rejection episodes: | ND
Induction therapy | Maintenance | Trough CsA levels | Anti-rejection therapy | B. Renal functions: | Serum creatinine (mmol/L)
ND | CsA mg/kg/day | ND | ND | | GFR (ml/min): Calculated according to Cockroft and Gaults formula
| N3: 2.4±0.1 control: 2.3±0.1 | | | C. New onset diseases or conditions: | % normotensive after 12-month Rx
| Aza mg/kg/day | | | D. CVD markers: | SBP (mm Hg), DBP (mm Hg), Systemic vascular resistance, TG (mmol/L), Total cholesterol (mmol/L), HDL-c (mmol/L), LDL-c (mmol/L), Hemodynamics (Including SVR, LVEF, LVEDPm MAP, PCW and CI) , TNF-α, IL-10,
| N3: 1.2±0.1 control: 1.1±0.1 | | | E. Infections: | ND
| Prednisolone mg/kg/day | | | F. Drug pharmacokinetics: | CsA dose
| N3: 0.1±0.01 control: 0.1±0.02 | | | G. Other outcomes: | Echocardiography (Including LVEDD, FS, septal thickness, posterior wall, E/A ratio, and deceleration time)
Anti-hypertensive Drugs: | | | | | Endothelium-dependent and -independent vasodilation
ACE inhibitors, calcium-channel antagonist, beta blockers, diuretics
Lipid-lowering Drugs:
Statins
Results | | | | | | | | | Bias / Limitations / Comments
Outcome | Cohort | N | Baseline | Unit | SD /SE /range | Follow-up | P W/in | P Btw
4. Holm, 2001 (UI#11544435; EMBASE2001241336)
Part III. Results
SBP | Fish oil | 21 | 138±3 | mmHg | SE | No change | NS | 0.02
| Corn oil | 20 | 139±3 | | | +8±2 | 0.01
DBP | Fish oil | 21 | 89±1 | mmHg | SE | No change | NS | 0.07
| Corn oil | 20 | 90±2 | | | +3±2 | 0.1
TG | Fish oil | 21 | 2.2±0.3 | mmol/l | SE | 1.7±0.2 | <0.001 | 0.07
| Corn oil | 20 | 1.9±0.3 | | | 2.0±0.3 | NS
Total cholesterol | Fish oil | 21 | 6.9±0.3 | mmol/l | SE | 6.8±0.3 | NS | 0.5
| Corn oil | 20 | 6.2±0.2 | | | 6.1±0.2 | NS
HDL | Fish oil | 21 | 1.3±0.1 | mmol/l | SE | 1.5±0.1 | NS | 0.38
| Corn oil | 20 | 1.4±0.1 | | | 1.4±0.1 | NS
LDL | Fish oil | 21 | 4.4±0.1 | mmol/l | SE | 4.4±0.1 | NS | 057
| Corn oil | 20 | 3.9±0.1 | | | 3.9±0.1 | NS
% normaltensive after 12-month Rx | Fish oil | 9/21
| Corn oil | 0/20
Graft survival | Fish oil | 21/23
| Corn oil | 20/22
Adverse effects were not described. Three patients died: 2 in the placebo group (cerebral infarction and amyotrophic lateral sclerosis) and 1 in the treatment group (prostate cancer) and one patient in the treatment group withdrew for personal reasons.
None of the patients withdrew from the study because of side effects.
There is a significant relationship b/w changes in SBP and serum EPA and DHA in 21 heart transplant recipients during 12 months Rx with omega-3 fatty acids (r= -0.52, p=0.02)
Serum creatinine increased significantly (121±6 to 130±5 mmol/l, p<0.01) in the placebo group but there was no increase in the fish oil group (data in figure 4)
Calculated GFR decreased significantly (74±5 to 68±4 ml/min, p=0.02 in the placebo group but there was no increase in the fish oil group (data in figure 4).
Study Characteristics | Eligibility Criteria | Omega-3 FA Intervention | Compliance | Control
5. Salen, 1994 (EMBASE1994139060)
Part I. Study Characteristics
N3: enrolled: 41 | Inclusion criteria: heart transplant patients with hypercholesterolemia (total cholesterol >6.5 mmol/L) | French Meditteranean diet | Dietary surveys and counseling | ND
Age, N3: 50±9 SE | Exclusion criteria: ND | N3: 0.24±0.02
% Male: 100 | | After 1 year: 0.63±0.08
Duration: 1 year | | P=0.0001
Country: France | | Start: ND
Site: 1
Study Design: Single-arm cohort
Concomitant Treatments | | | | Outcome Metric
5. Salen, 1994 (EMBASE1994139060)
Part II. Concomitant Treatments and Outcomes Studied
Immunosuppressive therapy: | | | | A. Survival and rejection episodes: | ND
Induction therapy | Maintenance | Trough CsA levels | Anti-rejection therapy | B. Renal functions: | ND
ND | Corticosteroid dose baseline 17.6±1.0 mg/day after 1 year 12.5±0.8 (p=0.0001) | ND | ND | C. New onset diseases or conditions: | ND
Anti-hypertensive Drugs: | | | | D. CVD risk factors: | Total cholesterol, TG, HDL, LDL, Apo B-100, Apo A-1, Lipoprotein (a), Uric acid, Thrombin-induced platelet aggregation (Only performed in the last 25 consecutive patients)
ND | | | | E. Infections: | ND
Lipid-lowering Drugs: | | | | F. Drug pharmacokinetics: | CsA dose, Corticosteroid dose
ND | | | | G. Other outcomes: | ND
Results | | | | | | | | | Bias / Limitations / Comments
Outcome | Cohort | N | Baseline | Unit | SD/SE/range | Follow-up change | P W/in | P Btw
5. Salen, 1994 (EMBASE1994139060)
Part III. Results
Total cholesterol | ALA | 41 | 8.2±1.6 | mmol/L | SE | 7.2±1.5 | P=0.005 | - | Diet composition was estimated from 24-hour recall. Although the intake of linolenic acid increased, total calories and % saturated fats from calories were significantly decreased at the same time. The observed effects could not be solely attributed to ALA.
Triglycerides | ALA | 41 | 3.1±2.2 | mmol/L | SE | 2.9±2.5 | NS | - | Platelet aggregation analyses were only performed in the last 25 consecutive patients without further explanation.
HDL | ALA | 41 | 1.4±0.4 | mmol/L | SE | 1.42±0.5 | NS | -
LDL | ALA | 41 | 6.2±1.5 | mmol/L | SE | 5.3±1.3 | P=0.004 | -
Weight | ALA | 41 | 75.5±1.8 | kg | SE | 74.0±1.6 | NS | -
Platelet aggregation | ALA | 41 | 19.1±1.4% | | SE | 13.5±1.7% | P=0.02 | -
Uric acid | ALA | 41 | 333±20.1 | umol/L | SE | 399±19.8 | P=0.02 | -
CsA dose | ALA | 41 | 392±29 | mg/day | SE | 338±25 | NS | -
Arterial pressure did not decrease significantly, although immunosuppressive treatment was progressively reduced (p<0.0001)
There was an inverse correlation between linolenic acid intake and platelet aggregation (r=-0.44; p=0.03) after the diet intervention. This analysis was only performed in the last 25 consecutive patients.
All grafts survived.
Study Characteristics | Eligibility Criteria | Omega-3 FA Intervention | Compliance | Control
6. Ventura, 1993 (UI#8222166)
Part I. Study Characteristics
N3: enrolled: 10 | Inclusion criteria: hypertensive orthotopic cardiac transplant recipients | EPA+DHA: 3 g/day | ND | Corn oil
Control enrolled: 10 | Exclusion criteria: ND | start: 3.5±1.5months posttransplant
Age, N3: 53±7
Age, control: 52±7
51±6 (6 pts)
% Male, N3: 90
% Male, control: 90
83 (6 pts)
Duration: 12 weeks
Country: USA
Site: 1
Study Design: RCT Parallel
Concomitant Treatments | | | | Outcome Metric
6. Ventura, 1993 (UI#8222166)
Part II. Concomitant Treatments and Outcomes Studied
Immunosuppressive therapy: | | | | A. Survival and rejection episodes: | ND
Induction therapy | Maintenance | Trough CsA levels | Anti-rejection therapy | B. Renal functions: | ND
ND | CsA | ND | ND | C. New onset diseases or conditions: | ND
| Prednisone | | | D. CVD risk factors: | MAP
| Aza | | | | Systemic vascular resistance (SVR)
Anti-hypertensive Drugs: | | | | E. Infections: | ND
Calcium-channel blocking agent, ACE inhibitor, or both | | | | F. Drug pharmacokinetics: | ND
Lipid-lowering Drugs: | | | | G. Other outcomes: | Echocardiographic indexes of myocardial structure and function: Septal thickness, posterior wall thickness, left ventricular end-diastolic diameter, left ventricular mass, ejection fraction %
ND
Results | | | | | | | | | Bias / Limitations / Comments
Outcome | Cohort | N | Baseline | Unit | SD/SE/range | Follow-up | P W/in | P Btw
6. Ventura, 1993 (UI#8222166)
Part III. Results
MAP | Fish oil | 10 | 120±7 | mmHg | SE | 102±7 | <0.01 | ND
| Corn oil | 6 | 121±4 | | | No change | NS
Systemic vascular resistance | Fish oil | 10 | 2107±45 | dynes.sec.cm-5 | SE | 1426±60 | <0.0001 | ND
| Corn oil | 6 | ND | | | No change | NS
Septal thickness | Fish oil | 10 | 1.0±0.2 | cm | SE | 1.0±0.2 | NS | ND
| Corn oil | 6 | 0.9±0.1 | | | 0.9±0.1 | NS
Posterior wall thickness | Fish oil | 10 | 0.98±0.1 | cm | SE | 0.96±0.1 | NS | ND
| Corn oil | 6 | 0.8±0.1 | | | 0.8±0.1 | NS
Left ventricular end-diastolic diameter | Fish oil | 10 | 4.5±0.1 | cm | SE | 4.4±0.1 | NS | ND
| Corn oil | 6 | 3.9±0.2 | | | 4.0±0.1 | NS
Left ventricular mass | Fish oil | 10 | 210±10 | g | SE | 182±12 | P=0.1 | ND
| Corn oil | 6 | 173±9 | | | 169±10 | NS
Left ventricular mass/height | Fish oil | 10 | 117±5 | g/m | SE | 102±4 | NS | ND
| Corn oil | 6 | 97±4 | | | 95±5 | NS
Total cholesterol | Fish oil | 10 | 275±15 | mg/dl | SE | 264±14 | NS | ND
| Corn oil | 6 | 265±16 | | | 286±15 | NS
Triglycerides | Fish oil | 10 | 157±20 | mg/dl | SE | 149±12.1 | NS | ND
| Corn oil | 6 | 180±172 | | | 178±14 | NS
HDL | Fish oil | 10 | 47±4 | mg/dl | SE | 47±4 | NS | ND
| Corn oil | 6 | 42±14 | | | 44±12 | NS
LDL | Fish oil | 10 | 185±14 | mg/dl | SE | 176±14 | NS | ND
| Corn oil | 6 | 174±14 | | | 187±14 | NS
Four patients in the placebo group did not finish the study: 2 because of acute allograft rejection and 2 because of an intolerance to omega-6 fatty acids.
Three patients who continued oral supplementation with fish oil after completion of the study were able to discontinue antihypertensive agents.

Table III Evidence Table. Study for omega-3 Fatty Acids and Bone Marrow Transplantation

Study Characteristics | | Eligibility Criteria | | Omega-3 FA Intervention | Compliance | Control
1. Takatsuka, 2001 (UI#11781629); Takatsuka, 2002 (EMBASE 2003001292)
Part I. Study Characteristics
N3: enrolled: 8 | | Inclusion criteria: consecutive patients who underwent unrelated allogeneic bone marrow transplant | | EPA: 1.8 g/day ethyl icosapentate, Mochida Pharmaceutical Co., Ltd., Tokyo, Japan | ND | No placebo
Control enrolled: 9 | | Exclusion criteria: ND | | start: day 21 before BMT
Age, N3: 25.9
Age, control: 31.1
% Male, N3: 62.5
% Male, control: 11.1
Duration: 201 days
Country: Japan
Site: 1
Study Design: RCT Parallel
Part II. Concomitant Treatments and Outcomes Studied
Concomitant Treatments | | | | Outcome Metric
Immunosuppressive therapy: | | | | A. Survival and rejection episodes: | Patient survival
Induction therapy | Maintenance | Trough CsA levels | Anti-rejection therapy | B. Renal functions: | ND
ND | CsA methotrexate methylprednisolone | 400–600 ng/ml | ND | C. New onset diseases or conditions: | ND
| | | If GVHD worsened, CsA and methylprednisolone increased, or CsA replaced by FK506 | D. CVD risk factors: | LTB4
Anti-hypertensive Drugs: | | | | | TNF-alpha
ND | | | | | IFN-gamma
Lipid-lowering Drugs: | | | | | IL-2
ND | | | | E. Infections: | ND
| | | | F. Drug pharmacokinetics: | ND
| | | | G. Other outcomes: | The risk of graft-versus-host disease (GVHD): High-risk: LTB4 >= 20 FU/ml, Moderate-risk: 6 <= LTB4 < 20 FU/ml, Low-risk: LTB4 < 6 FU/ml
Part III. Results
Results | | | | | | Bias / Limitations / Comments
In the non-EPA group, 5 out of 9 patients died whereas all of the patients in the EPA group survived (p<0.01, log-rank test) | | | | | | No blinding. No description of how the 17 consecutive patients were selected.
There was a significant difference between the two groups with respect to the severity of colonic GVHD (p=0.041). No control patients changed in the risk levels after BMT, while 3 EPA treated patients were in the moderate-risk group became low-risk group after BMT.
Compared to controls, there was a significant decrease in LTB4 and TNF-alpha in EPA-treated group (p<0.05)
Compared to controls, there was a significant decrease IFN-gamma in EPA-treated group (p<0.05) during recovery phase only.
Compared to controls, there was no significant change.

Table IV Evidence Table. Study for Omega-3 Fatty Acids and Liver Transplantation

Study Characteristics | Eligibility Criteria | Omega-3 FA Intervention | Compliance | Control
1. Badalamenti, 1995 (UI#7489976)
Part I. Study Characteristics
N3 enrolled: 14 | Inclusion criteria: stable normal serum creatinine and urine analyses before transplantation; time since OLT>6 months; stable liver function and serum creatinine and stable CsA dosage for at least 3 months before the study | Total: 12 gram/day | measure the plasma fatty acid | Corn oil
Control enrolled: 13 | Exclusion criteria: ND | Max-Epa, Zyma, Saronno, Italy
Age, N3: 44.8±9SE (13pts) | | EPA: 2.16 g/day
Age, control: 47.8±3 SE | | DHA: 1.44 g/day
% Male N-3: 62 (13pts) | | Start: ND
% Male control: 54
Duration: 2 months
Country: Italy
Site: 1
Study Design: RCT Parallel
Concomitant Treatments | | | | Outcome Metric
1. Badalamenti, 1995 (UI#7489976)
Part II. Concomitant Treatments and Outcomes Studied
Immunosuppressive therapy: | | | | A. Survival and rejection episodes: | ND
Induction therapy | Maintenance | Trough CsA levels | Anti-rejection therapy | B. Renal functions: | ND
ND | 8 patients (4 from fish oil group and 4 from corn oil group) received only CsA. | ND | ND | C. New onset diseases or conditions: | ND
| 4 patients (1 and 3) received CsA plus prednisone (5 to 10 mg/day), | | | D. CVD risk factors: | LTB4
| 7 patients (4 and 3) received CsA plus Aza (50 to 100 mg/day) | | | | TNF-alpha
| 7 patients (5 and 2) received CsA plus prednisone (5 to 12.5 mg/day) plus Aza (50 to 100 mg/day) | | | | IFN-gamma
Anti-hypertensive Drugs: | | | | | IL-2
ND | | | | E. Infections: | ND
Lipid-lowering Drugs: | | | | F. Drug pharmacokinetics: | ND
ND | | | | G. Other outcomes: | The risk of graft-versus-host disease (GVHD): High-risk: LTB4 >= 20 FU/ml, Moderate-risk: 6 <= LTB4 < 20 FU/ml, Low-risk: LTB4 < 6 FU/ml
Results | | | | | | | | | Bias / Limitations / Comments
Outcome | Cohort | N | Baseline | Unit | SD /SE /range | Follow-up | P W/in | P Btw
1. Badalamenti, 1995 (UI#7489976)
Part III. Results
GFR | Fish oil | 13 | 71 ±6 | mL/min | SE | 86.5±6.6 | NS | ND
| Corn oil | 13 | 70.4±11 | | | 65.5±8 | NS
MAP | Fish oil | 13 | 101±3 | mmHg | SE | 99±3 | NS | ND
| Corn oil | 13 | 94±2 | | | 95±2 | NS
Blood CsA | Fish oil | 13 | 480±18 | ng/mL | SE | 450±22 | NS | ND
| Corn oil | 13 | 523±43 | | | 471±29 | NS
RBF | Fish oil | 13 | 0.54±0.07 | L/min | SE | 0.64±0.07 | P<0.03 | ND
| Corn oil | 13 | 0.54±0.05 | | | 0.51±0.03 | NS
PA | Fish oil | 13 | 140±29 | pg/ml | SE | 145±25 | NS | ND
| Corn oil | 13 | 228±78 | | | 300±99 | NS
Bilirubin | Fish oil | 13 | 0.9±0.1 | mg/dL | SE | 0.9±0.1 | NS | ND
| Corn oil | 13 | 1.4±0.2 | | | 1.6±0.3 | NS
Prothrombin | Fish oil | 13 | 92±4.1 | % | SE | 99.7±0.3 | NS | ND
| Corn oil | 13 | 86±5 | | | 86.1±3.5 | NS
Serum albumin | Fish oil | 13 | 3.65±0.15 | g/dL | SE | 3.67±0.11 | NS | ND
| Corn oil | 13 | 3.42±0.2 | | | 3.45±0.2 | NS
Urine urea | Fish oil | 13 | 19.3±2.6 | g/24hr | SE | 18.1±2.2 | NS | ND
| Corn oil | 13 | 19.3±2.7 | | | 19.3±3 | NS
Urine TxB2 | Fish oil | 13 | 707±192 | pg/hr | SE | 276±76 | P<0.03 | ND
| Corn oil | 13 | 428±195 | | | 870±310 | P<0.03
Fishy taste, leading to unblinding