# Appendix B. Transplant Form

## Transplant Form Part I

## Transplant Form Part II