# Appendix A. Literature Search Strings

## MEDLINE AND EMBASE: Omega 3 and drugs with controlled trial filter

1. exp fatty acids, omega-3/
2. fatty acids, essential/
3. Dietary Fats, Unsaturated/
4. linolenic acids/
5. exp fish oils/
6. (n 3 fatty acid$ or omega 3).tw.
7. docosahexa?noic.tw,hw,rw.
8. eicosapenta?noic.tw,hw,rw.
9. alpha linolenic.tw,hw,rw.
10. (linolenate or cervonic or timnodonic).tw,hw,rw.
11. menhaden oil$.tw,hw,rw.
12. (mediterranean adj diet$).tw.
13. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.
14. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.
15. (fish adj2 oil$).tw.
16. (cod liver oil$ or marine oil$ or marine fat$).tw.
17. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.
18. (fish consumption or fish intake or (fish adj2 diet$)).tw.
19. diet$ fatty acid$.tw.
20. or/1–19
21. dietary fats/
22. (randomized controlled trial or clinical trial or controlled clinical trial or evaluation studies or multicenter study).pt.
23. random$.tw.
24. exp clinical trials/ or evaluation studies/
25. follow-up studies/ or prospective studies/
26. or/22–25
27. 21 and 26
28. (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega).tw.
29. (omega 3 or n 3).mp.
30. (polyunsaturated fat$ or pufa or dha or epa or long chain or longchain or lc$).mp.
31. 29 and 30
32. 20 or 27 or 28 or 31
33. follow up studies/
34. (follow up or followup).tw.
35. exp case-control studies/ or case control study/
36. (case adj20 control).tw.
37. exp longitudinal studies/ or longitudinal study/
38. longitudinal.tw.
39. exp cohort studies/ or cohort analysis/
40. cohort.tw.
41. (random$ or rct).tw.
42. exp randomized controlled trials/ or randomized controlled trial/
43. exp random allocation/
44. exp double-blind method/ or double blind procedure/
45. exp single-blind method/ or single blind procedure/
46. randomized controlled trial.pt.
47. clinical trial.pt. or exp clinical trial/
48. (clin$ adj trial$).tw.
49. ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).ti,ab.
50. exp placebos/ or placebo/
51. placebo$.tw.
52. exp research design/ or exp methodology/
53. exp evaluation studies/ or exp postmarketing surveillance/
54. exp prospective studies/ or prospective study/
55. exp comparative study/
56. or/33–55
57. exp glucocorticoids/ or exp glucocorticoids, synthetic/ or exp glucocorticoid/
58. (glucocorticoids or hydroxycorticosteroids or 11-hydroxycorticosteroids or corticosterone or hydrocortisone or 18-hydroxycorticosterone or tetrahydrocortisol or 17-hydroxycorticosteroids or cortisone or cortodoxone or hydroxypregnenolone or tetrahydrocortisone).mp. [mp=title, abstract, subject headings, drug trade name, original title, device manufacturer, drug manufacturer name]
59. (glucocorticoids, synthetic or beclomethasone or betamethasone or betamethasone 17-valerate or clobetasol or desoximetasone or dexamethasone or dexamethasone isonicotinate or diflucortolone or flumethasone or fluocinolone acetonide or fluocinonide or fluocortolone or fluorometholone or fluprednisolone or flurandrenolone or melengestrol acetate or methylprednisolone or methylprednisolone hemisuccinate or paramethasone or prednisolone or prednisone or triamcinolone or triamcinolone acetonide).mp. [mp=title, abstract, subject headings, drug trade name, original title, device manufacturer, drug manufacturer name]
60. exp immunosuppressive agents/ or exp immunosuppressive agent/
61. (immunosuppressive agents or 6-mercaptopurine or antilymphocyte serum or azaserine or azathioprine or busulfan or cladribine or coformycin or cyclophosphamide or cyclosporine or cyclosporins or cytarabine or ellipticines or fluorouracil or gliotoxin or ifosfamide or methotrexate or muromonab-cd3 or pentostatin or razoxane or sirolimus or tacrolimus or thalidomide or thiamphenicol or thioinosine or triamcinolone acetonide).mp. [mp=title, abstract, subject headings, drug trade name, original title, device manufacturer, drug manufacturer name]
62. okt3.mp. [mp=title, abstract, subject headings, drug trade name, original title, device manufacturer, drug manufacturer name]
63. fk506.mp. [mp=title, abstract, subject headings, drug trade name, original title, device manufacturer, drug manufacturer name]
64. rs-61443.mp. [mp=title, abstract, subject headings, drug trade name, original title, device manufacturer, drug manufacturer name]
65. mycophenolic acid.mp. [mp=title, abstract, subject headings, drug trade name, original title, device manufacturer, drug manufacturer name]
66. rapamycin.mp. [mp=title, abstract, subject headings, drug trade name, original title, device manufacturer, drug manufacturer name]
67. acyclovir.mp. [mp=title, abstract, subject headings, drug trade name, original title, device manufacturer, drug manufacturer name]
68. or/57–67
69. 32 and 56 and 68
70. 69
71. limit 70 to human
72. 71
73. limit 72 to english language
74. 71 not 73

## MEDLINE AND EMBASE: Omega3 and Transplant

1. exp fatty acids, omega-3/
2. fatty acids, essential/
3. Dietary Fats, Unsaturated/
4. linolenic acids/
5. exp fish oils/
6. (n 3 fatty acid$ or omega 3).tw.
7. docosahexa?noic.tw,hw,rw.
8. eicosapenta?noic.tw,hw,rw.
9. alpha linolenic.tw,hw,rw.
10. (linolenate or cervonic or timnodonic).tw,hw,rw.
11. menhaden oil$.tw,hw,rw.
12. (mediterranean adj diet$).tw.
13. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.
14. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.
15. (fish adj2 oil$).tw.
16. (cod liver oil$ or marine oil$ or marine fat$).tw.
17. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.
18. (fish consumption or fish intake or (fish adj2 diet$)).tw.
19. diet$ fatty acid$.tw.
20. or/1–19
21. dietary fats/
22. (randomized controlled trial or clinical trial or controlled clinical trial or evaluation studies or multicenter study).pt.
23. random$.tw.
24. exp clinical trials/ or evaluation studies/
25. follow-up studies/ or prospective studies/
26. or/22–25
27. 21 and 26
28. (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega).tw.
29. (omega 3 or n 3).mp.
30. (polyunsaturated fat$ or pufa or dha or epa or long chain or longchain or lc$).mp.
31. 29 and 30
32. 20 or 27 or 28 or 31
33. exp transplants/
34. exp transplantation immunology/
35. exp transplantation/
36. (posttransplant$ or pretransplant$ or pre transplant$ or post transplant$).tw.
37. transplant$.mp.
38. transplant$.hw.
39. tr.fs.
40. graft$.mp,hw.
41. exp graft rejection/
42. (allotransplant$ or xenotransplant$ or heterotransplant$ or autotransplant$ or isotransplant$).mp. [mp=title, abstract, subject headings, drug trade name, original title, device manufacturer, drug manufacturer name]
43. (allograft$ or xenograft$ or homograft$ or heterograft$ or autograft$ or isograft$).mp.
44. exp postoperative complications/ or exp postoperative complication/
45. or/33–44
46. 32 and 45
47. limit 46 to human
48. 47
49. limit 48 to english language
50. 48 not 49