# Appendixes

Appendix A. Literature Search Strings

Appendix B. Transplant Form

Appendix C Evidence Tables

Appendix D