# Acronyms

AA | Arachidonic acid | Mo | Month
Ab | Antibody | MS | Multiple sclerosis
AHRQ | Agency for Healthcare Research and Quality | n | Number
AI | Adequate intake | n-3 | Omega-3
ALA | Alpha-linolenic acid | n-6 | Omega-6
AMDR | Acceptable macronutrient distribution ranges | NA | Not applicable
ANCOVA | Analysis of covariance | NHANES III | The Third National Health and Nutrition Examination
ANOVA | Analysis of variance | NCI | National Cancer Institute
Ca | Calcium | NEI | National Eye Institute
CCT | Controlled clinical trial | NEMC | New England Medical Center
CI | Confidence interval | NHANES | National Health and Nutrition Examination
CP | Cerebral palsy | NHLBI | National Heart, Lung and Blood Institute
CRP | C-reactive protein | NIAAA | National Institute of Alcohol Abuse and Alcoholism
CSFII | Continuing Food Survey of Intakes by Individuals | NIAID | National Institute of Allergy and Infectious Diseases
d | day | NIAMS | National Institute of Arthritis and Musculoskeletal and Skin Diseases
D6D | Delta-6 Desaturase | NICHD | National Institute of Child Health and Human Development
DGLA | Dihomo-gamma-linolenic acid | NIDDK | National Institute of Diabetes and Digestive and Kidney Diseases
DHA | Docosahexaenoic acid | NIH | National Institutes of Health
DPA | Docosapentaenoic acid | NINCDS Criteria | National Institute of Neurological and Communicative Disorders and Alzheimer's Disease and Related Disorders Criteria
DRI | Dietary Reference Intake | NNH | Number needed to harm
Ds-DNA | Double-stranded DNA | NR | Not reported
EDSS | Expanded Disability Status Scale | ODS | Office of Dietary Supplements
EF | Effect size | PG | Prostaglandin
EFA | Essential fatty acid | PGD | Prostaglandin-D
EPA | Eicosapentaenoic acid | PGE | Prostaglandin-E
EPC | Evidence-Based Practice Center | PGF | Prostaglandin-F
ESR | Erythrocyte sedimentation rate | PGL | Prostaglandin-L
FNB | Food and Nutrition Board | PGH | Prostaglandin-H
FFQ | Food Frequency Questionnaire | PUFA | Polyunsaturated fatty acid
g | Grams | QRF | Quality review form
GLA | Gamma-linolenic acid | RCT | Randomized controlled trial
HDL | High density lipoprotein | RDA | Recommended daily allowances
| | RXT | Randomized crossover trial
IL-1β | Interleukin 1β | Sd | Standard deviation
IOM | Institute of Medicine | SCEPC | Southern California Evidence-Based Practice Center
LA | Linoleic acid | SEM | Standard errors of the means
LC PUFA | Long-chain polyunsaturated fatty acid | TEP | Technical expert panel
LDL | Low density lipoprotein | TNF-a | Tumor necrosis factor-a
MA | Metaanalysis | TX | Treatment
MANOVA | Multivariable analysis of variance | TXA | Thromboxane-A
MeSH Term | Medical Subject Headings Term | UCLA | University of California, Los Angeles
mg/dl | Milligrams per deciliter | VLCFA | Very long chain fatty acid
min | Minutes | VLN-3FA | Very long chain n-3 fatty acids
| | Wk | Week