# Listing of Excluded Studies

### Rejected Search Unsuccessful (n = 5)

1 Anonymous. East fish reduces risk of dementia. Pharmaceutical Journal 2002; 269(7221):595.
2 Haveman Nies A. Dietary-Quality,-Lifestyle-Factors-and-Healthy-Ageing-in-Europe. 2001, 128 Pp.; Many Ref.
3 Meydani M. Protective role of dietary vitamin E on oxidative stress in aging. Age. 1992;15(3):89-93.
4 Thiebaut AC, Clavel-Chapelon F. {French} Bulletin Du Cancer 2001; 88(10):954–8.
5 Wong E K J, Enomoto H, Leopold I H, Williams J L, Kladde L, Hollander D H. Intestinal absorption of dietary fat in patients with multiple sclerosis. Metabolic, Pediatric & Systemic Ophthalmology. 1993;16(34):39-42.

### Rejected Condition (n = 144)

1 Agostoni C, Giovannini M. Cognitive and visual development: influence of differences in breast and formula fed infants. Nutrition-and-Health. 2001;15(34):183-8. [pmid: 12003083].
2 Agostoni C, Riva E, Trojan S, Bellu R, Giovannini M. Docosahexaenoic acid status and developmental quotient of healthy term infants. Lancet. 1995;346(8975):638. [pmid: 7651024].
3 Agostoni C, Trojan S, Bellu R, Riva E, Giovannini M. Neurodevelopmental quotient of healthy term infants at 4 months and feeding practice: The role of long-chain polyunsaturated fatty acids. Pediatric Research. 1995;38(2):262-6. [pmid: 7478826].
4 Alfin-Slater R B, Aftergood L. Essential fatty acids reinvestigated. {Review} Physiological Reviews. 1968;48(4):758-84.
5 Arnold L E. Alternative treatments for adults with attention-deficit hyperactivity disorder (ADHD). Annals of the New York Academy of Sciences. 2001;Vol 931:Pp 310-341. [pmid: 11462750].
6 Auestad N. Infant nutrition--brain development--disease in later life. An introduction. Developmental Neuroscience. 2000;22(56):472-3. [pmid: 11111164].
7 Auestad N, Halter R, Hall R T, et al. Growth and development in term infants fed long-chain polyunsaturated fatty acids: A double-masked, randomized, parallel, prospective, multivariate study. Pediatrics. 2001;108(2 II):372-81. [pmid: 11483802].
8 Auestad N, Scott D T, Janowsky J S, et al. Visual, cognitive, and language assessments at 39 months: a follow-up study of children fed formulas containing long-chain polyunsaturated fatty acids to 1 year of age. Pediatrics. 2003;112(3 Pt 1):e177-83. [pmid: 12949309].
9 Bakker E C, Ghys A J A, Kester A D M, et al. Long-chain polyunsaturated fatty acids at birth and cognitive function at 7 y of age. European-Journal-of-Clinical-Nutrition. 2003;57(1):89-95. [pmid: 12548302].
10 Beblo S, Reinhardt H, Muntau A C, Mueller-Felber W, Roscher A A, Koletzko B. Fish oil supplementation improves visual evoked potentials in children with phenylketonuria. Neurology. 2001;Vol 57(8):Pp 1488-1491. 23 OCT 2001. [pmid: 11673596].
11 Beisiegel U, Spector A A. Lipids and lipoproteins in the brain. Current Opinion in Lipidology. 2001;12(3):243-4. [pmid: 11353325].
12 Bentzen A J, Jacobsen P A, Munch Petersen S. An investigation of the platelet adhesiveness by Hellem's method in elderly patients under longterm psychiatric care, on a controlled diet with an unsaturated fatty acid load. An evaluation of the accuracy and clinical reproducibility of the method. Gerontologia-Clinica. 1972;14(4):217-34. [pmid: 4564276].
13 Birch D G, Birch E E, Hoffman D R, Uauy R D. Retinal development in very-low-birth-weight infants fed diets differing in omega-3 fatty acids. Investigative Ophthalmology & Visual Science. 1992;33(8):2365-76. [pmid: 1386065].
14 Birch E E, Garfield S, Hoffman D R, Uauy R, Birch D G. A randomized controlled trial of early dietary supply of long-chain polyunsaturated fatty acids and mental development in term infants. Developmental-Medicine-and-Child-Neurology. 2000;42(3):174-81. [pmid: 10755457].
15 Bistrian B R. Clinical aspects of essential fatty acid metabolism: Jonathan Rhoads Lecture. {Review} Jpen: Journal of Parenteral & Enteral Nutrition. 2003;27(3):168-75.
16 Bjerve K S, Brubakk A M, Fougner K J, et al. Omega-3 fatty acids: Essential fatty acids with important biological effects, and serum phospholipid fatty acids as markers of dietary omega3-fatty acid intake. American Journal of Clinical Nutrition. 1993;57(5 SUPPL.):801S-6S. [pmid: 8475898].
17 Bjerve K S, Fougner K J, Midthjell K, Bonaa K. n-3 Fatty acids in old age. Journal-of-Internal-Medicine. 1989;225(supp 1):191-66. [pmid: 2539428].
18 Brue A W, Oakland T D, Evans R A. The use of a dietary supplement combination and an essential fatty acid as an alternative and complementary treatment for children with attention-deficit/hyperactivity disorder. Scientific Review of Alternative Medicine. 2001;5(4):187-94.
19 Budowski P. Review: nutritional effects of omega 3-polyunsaturated fatty acids. {Review} Israel Journal of Medical Sciences. 1981;17(4):223-31.
20 Caramazza N, Damele M, Parente G, Alessandrini A, Cellini M. Use of polyunsatured fatty acids in the treatment of glaucomatous optic neuropathy (GON). Annali Di Ottalmologia e Clinica Oculistica. 1999;125(1112):329-38.
21 Carlson S E. Docosahexaenoic acid and arachidonic acid in infant development. Seminars in Neonatology. 2001;6(5):437-49. [pmid: 11988033].
22 Carlson S E. Lessons learned from randomizing infants to marine oil-supplemented formulas in nutrition trials. Journal-of-Pediatrics. 1994;125(supp 2):S33-S38. [pmid: 7965451].
23 Carlson SE, Gibson RA, Knapp HR, Carlson SE (ed.), Gibson RA (ed.), Knapp HR. Symposium on PUFA in maternal and child health, Kansas City, Missouri, USA, 10–13 September 2000. Lipids 2001; 36(9):859–1076.
24 Carlson S E, Neuringer M. Polyunsaturated fatty acid status and neurodevelopment: A summary and critical analysis of the literature. Lipids. 1999;34(2):171-8. [pmid: 10102243].
25 Carlson S E, Werkman S H. A randomized trial of visual attention of preterm infants fed docosahexaenoic acid until two months. Lipids. 1996;31(1):85-90. [pmid: 8649239].
26 Carlson S E, Werkman S H, Peeples J M, Wilson W M. Long-chain fatty acids and early visual and cognitive development of preterm infants. European-Journal-of-Clinical-Nutrition. 1994;42(supp 2):S27-S30. [pmid: 7995262].
27 Cellini M, Caramazza N, Mangiafico P, Possati G L, Caramazza R. Fatty acid use in glaucomatous optic neuropathy treatment. Acta Ophthalmologica Scandinavica Supplement. 1998;(227):41-2. [pmid: 9972342].
28 Cendrowski W. MaxEpa in multiple sclerosis. {Review} {Polish} Wiadomosci Lekarskie. 1985;38(21):1522-5.
29 Chalon S. N-3 polyunsaturated fatty acids, neurotransmission and cognitive function. Body Fat, Nutrition and Health, Topical Questions. 2000;7(1):68-73.
30 Chalon S. Polyunsaturated fatty acids and cognitive functions. OCL -Oleagineux,-Corps-Gras,-Lipides. 2001;8(4):317-20.
31 Chamberlain J G. The possible role of long-chain, omega-3 fatty acids in human brain phylogeny. Perspectives in Biology & Medicine. 1996;39(3):436-45. [pmid: 8657555].
32 Charlton K E. Eating well: ageing gracefully!. {Review} Asia Pacific Journal of Clinical Nutrition. 2002;11(Suppl 3):S607-17.
33 Cheruku S R, Montgomery Downs H E, Farkas S L, Thoman E B, Lammi Keefe C J. Higher maternal plasma docosahexaenoic acid during pregnancy is associated with more mature neonatal sleep-state patterning. American-Journal-of-Clinical-Nutrition. 2002;76(3):608-13. [pmid: 12198007].
34 Cho E, Hung S, Willett W C, et al. Prospective study of dietary fat and the risk of age-related macular degeneration. American Journal of Clinical Nutrition. 2001;73(2):209-18. [pmid: 11157315].
35 Colombo J, Carlson SE (ed.), Gibson RA (ed.), Knapp HR. Recent advances in infant cognition: implications for long-chain polyunsaturated fatty acid supplementation studies. Symposium on PUFA in Maternal and Child Health, Kansas City, Missouri, USA, 10–13 September 2000. Lipids 2001; 36(9):919–26.
36 Crawford M A. Essential fatty acids and neurodevelopmental disorder. {Review} Advances in Experimental Medicine & Biology. 1992;318:307-14.
37 Crawford M A. The role of essential fatty acids in neural development: implications for perinatal nutrition. American Journal of Clinical Nutrition. 1993;57(5 Suppl):703S-9S. discussion 709S–710S. [pmid: 7682751].
38 Crawford M A, Doyle W, Leaf A, Leighfield M, Ghebremeskel K, Phylactos A C. Nutrition and neurodevelopmental disorders. Nutrition-and-Health. 1993;9(2):81-97. [pmid: 7510860].
39 Crawford M A, Golfetto I, Ghebremeskel K, et al. The potential role for arachidonic and docosahexaenoic acids in protection against some central nervous system injuries in preterm infants. 5th Congress of the International Society for the Study of Fatty Acids and Lipids, Montreal, Canada, May 7–11, 2002. 2003;38(4):303-15.
40 Crawford MA, Sinclair AJ, Msuya PM et al. Dietary lipids and postnatal development. 1973: 278.
41 Cunnane S C, Francescutti V, Brenna J T. Docosahexaenoate requirement and infant development. Nutrition. 1999;15(10):801-2. [pmid: 10501301].
42 do Nascimento C M, Oyama L M. Long-chain polyunsaturated fatty acids essential for brain growth and development. {comment} Nutrition. 2003;19(1):66.
43 Driss F, Darcet P, Lagarde M, et al. Polyunsaturated fatty acids: drug or food?. World Review of Nutrition & Dietetics. 1984;43:170-3. [pmid: 6089448].
44 Dusseldorp M. Diet of the elderly. Voeding. 1986;47:11. 312–316; 24 Ref.
45 Elvevoll EO, James DG. Potential benefits of fish for maternal, foetal and neonatal nutrition: a review of the literature. Food,-Nutrition-and-Agriculture. 2000, No. 27, 28–39.
46 Fenton W S, Dickerson F, Boronow J, Hibbeln J R, Knable M. A placebo-controlled trial of omega-3 fatty acid (ethyl eicosapentaenoic acid) supplementation for residual symptoms and cognitive impairment in schizophrenia. American-Journal-of-Psychiatry. 2001;158:12. 2071–2074; 12 Ref.
47 Fernandes G, Meydani S N, Makinodan T, Weindruch R, Miller R A, Bendich A. Effects of calorie restriction and omega-3 fatty acids on autoimmunity and aging. Nutrition Reviews. 1995;53(4 II):S72-S79. [pmid: 7644158].
48 Fernstrom J D. Can nutrient supplements modify brain function?. American Journal of Clinical Nutrition. 2000;71(6 SUPPL.):1669S-75S. [pmid: 10837313].
49 Fewtrell M S, Morley R, Abbott R A, et al. Double-blind, randomized trial of long-chain polyunsaturated fatty acid supplementation in formula fed to preterm infants. Pediatrics. 2002;110:1. 73–82; 36 Ref. [pmid: 12093940].
50 Forsyth J S, Carlson S E. Long-chain polyunsaturated fatty acids in infant nutrition: effects on infant development. Current-Opinion-in-Clinical-Nutrition-and-Metabolic-Care. 2001;4:2. 123–126; 28 Ref.
51 Foxall G, Leek S, Maddock S. Cognitive antecedents of consumers' willingness to purchase fish rich in polyunsaturated fatty acids (PUFA). Appetite. 1998;31:3. 391–402; 42 Ref.
52 Ghys A, Bakker E, Hornstra G, Hout M van den, den Hout M van, van den Hout M. Red blood cell and plasma phospholipid arachidonic and docosahexaenoic acid levels at birth and cognitive development at 4 years of age. Early-Human-Development 2002; 1–2, 83–90.
53 Gibson R A, Makrides M. n-3 polyunsaturated fatty acid requirements of term infants. {Review} American Journal of Clinical Nutrition. 2000;71(1 Suppl):251S-5S.
54 Gil A, Ramirez M, Gil M. Role of long-chain polyunsaturated fatty acids in infant nutrition. European Journal of Clinical Nutrition. 2003;57(SUPPL. 1):S31-S34. [pmid: 12947449].
55 Gillingham M, Calcar S, Ney D, Wolff J, Harding C, van Calcar S. Dietary management of long-chain 3-hydroxyacyl-CoA dehydrogenase deficiency (LCHADD). A case report and survey. Journal-of-Inherited-Metabolic-Disease. 1999;22:2. 123–131; 12 Ref.
56 Gillum R F, Mussolino M, Madans J H. The relation between fish consumption, death from all causes, and incidence of coronary heart disease: The NHANES I Epidemiologic Follow-up Study. Journal of Clinical Epidemiology. 2000;53(3):237-44. [pmid: 10760632].
57 Greatrex J C, Drasdo N, Dresser K. Scotopic sensitivity in dyslexia and requirements for DHA supplementation. Lancet. 2000;355(9213):1429-30. [pmid: 10791530].
58 Guesnet P, Alessandri J M. Milk essential fatty acids and central nervous system development in the newborn. Cahiers-De-Nutrition-Et-De-Dietetique. 1995;30:2. 109–116; 47 Ref.
59 Guesry P. The role of nutrition in brain development. Preventive Medicine. 1998;27(2):189-94. [pmid: 9578993].
60 Halat K M, Dennehy C E. Botanicals and dietary supplements in diabetic peripheral neuropathy. {Review} Journal of the American Board of Family Practice. 2003;16(1):47-57.
61 Hamazaki T, Itomura M, Sawazaki S, Nagao Y. Anti-stress effects of DHA. Biofactors. 2000;13(14):41-5. [pmid: 11237197].
62 Helland I B, Smith L, Saarem K, Saugstad O D, Drevon C A. Maternal supplementation with very-long-chain n-3 fatty acids during pregnancy and lactation augments children's IQ at 4 years of age. Pediatrics. 2003;111:1. 189–190; Full Paper Electronic-Only Http:-Www.Pediatrics.Org-Cgi-Content-Full-111-1-E39. [pmid: 12509546].
63 Hoffman D R, Birch D G. Docosahexaenoic acid in red blood cells of patients with X-linked retinitis pigmentosa. Investigative Ophthalmology & Visual Science. 1995;36(6):1009-18. [pmid: 7730010].
64 Hoffman D R, Uauy R, Birch D G. Red blood cell fatty acid levels in patients with autosomal dominant retinitis pigmentosa. Experimental Eye Research. 1993;57(3):359-68. [pmid: 8224023].
65 Holman R T. The slow discovery of the importance of omega 3 essential fatty acids in human health. {comment} {Review} Journal of Nutrition. 1998;128(2 Suppl):427S-33S.
66 Horrobin D F. The relationship between schizophrenia and essential fatty acid and eicosanoid metabolism. {Review} Prostaglandins Leukotrienes & Essential Fatty Acids. 1992;46(1):71-7.
67 Horrobin D F. The roles of essential fatty acids in the development of diabetic neuropathy and other complications of diabetes mellitus. {Review} Prostaglandins Leukotrienes & Essential Fatty Acids. 1988;31(3):181-97.
68 Horrobin D F, Glen A I, Hudson C J. Possible relevance of phospholipid abnormalities and genetic interactions in psychiatric disorders: the relationship between dyslexia and schizophrenia. {Review} Medical Hypotheses. 1995;45(6):605-13.
69 Infante J P, Huszagh V A. Secondary carnitine deficiency and impaired docosahexaenoic (22:6n-3) acid synthesis: a common denominator in the pathophysiology of diseases of oxidative phosphorylation and beta-oxidation. {Review} FEBS Letters. 2000;468(1):1-5.
70 Innis S M. Plasma and red blood cell fatty acid values as indexes of essential fatty acids in the developing organs of infants fed with milk or formulas. Journal-of-Pediatrics. 1992;120:4. II, S78–S86; 47 Ref.
71 Innis S M, Gilley J, Werker J. Are human milk long-chain polyunsaturated fatty acids related to visual and neural development in breast-fed term infants?. Journal of Pediatrics. 2001;139(4):532-8. [pmid: 11598600].
72 Innis S M, Nelson C M, Lwanga D, Rioux F M, Waslen P. Feeding formula without arachidonic acid and docosahexaenoic acid has no effect on preferential looking acuity or recognition memory in healthy full-term infants at 9 mo of age. American-Journal-of-Clinical-Nutrition. 1996;64:1. 40–46; 52 Ref. [pmid: 8669403].
73 Kahn E. Perspective on tuna fish. New England Journal of Medicine. 1971;285(1):49-50. [pmid: 5104410].
74 Kaplan R J, Greenwood C E. Dietary saturated fatty acids and brain function. {Review} Neurochemical Research. 1998;23(5):615-26.
75 Kenny D. Adverse effects of fish oil (I). Archives of Internal Medicine 1990; 150(9):1967+1971.
76 Kinjo Y, Beral V, Akiba S, et al. Possible protective effect of milk, meat and fish for cerebrovascular disease mortality in Japan. Journal of Epidemiology. 1999;9(4):268-74. [pmid: 10510585].
77 Koletzko B. Fats for brains. European Journal of Clinical Nutrition. 1992;46(SUPPL. 1):S51-S62. [pmid: 1612052].
78 Koletzko B. Parenteral lipid infusion in infancy: physiological basis and clinical relevance. Clinical-Nutrition. 2002;21(Supplement 2):53-65. 108 Ref.
79 Koo W W K. Efficacy and safety of docosahexaenoic acid and arachidonic acid addition to infant formulas: Can one buy better vision and intelligence?. Journal of the American College of Nutrition. 2003;22(2):101-7. [pmid: 12672705].
80 Kretchmer N, Beard J L, Carlson S. The role of nutrition in the development of normal cognition. American-Journal-of-Clinical-Nutrition. 1996;63:6. 997S–1001S; 52 Ref.
81 Kunze D. On the essential nature of polyunsaturated fatty acids. Fett-Wissenschaft-Technologie. 1993;95:12. 442–447; 46 Ref.
82 Lands W E. Eicosanoids and health. {Review} Annals of the New York Academy of Sciences. 1993;676:46-59. Mar 15.
83 Lapillonne A, Picaud J C, Chirouze V, et al. The use of low-EPA fish oil for long-chain polyunsaturated fatty acid supplementation of preterm infants. Pediatric-Research. 2000;48:6. 835–841; 25 Ref. [pmid: 10879793].
84 Larque E, Demmelmair H, Koletzko B. Perinatal supply and metabolism of long-chain polyunsaturated fatty acids: importance for the early development of the nervous system. {Review} Annals of the New York Academy of Sciences. 2002;967:299-310. Jun.
85 Lauritzen L, Hansen H S. Which of the n-3 FA should be called essential?. Lipids. 2003;38(8):889-91. [pmid: 14577670].
86 Lauritzen L, Hansen H S, Jorgensen M H, Michaelsen K F. The essentiality of long chain n-3 fatty acids in relation to development and function of the brain and retina. Progress in Lipid Research. 2001;40(12):1-94. [pmid: 11137568].
87 Lehtonen A, Raiha I, Puumalainen R, Seppanen A, Marniemi J. The effect of the short-term administration of fish oil on serum lipoproteins in old people. Gerontology. 1989;35(56):311-4. [pmid: 2630386].
88 Lucas A, Stafford M, Morley R, et al. Efficacy and safety of long-chain polyunsaturated fatty acid supplementation of infant-formula milk: a randomised trial. Lancet-British-Edition. 1999;354:9194. 1948–1954; 42 Ref.
89 Lutz M. Diet as a determinant of the central nervous system development: role of essential fatty acids. Archivos-Latinoamericanos-De-Nutricion. 1998;48:1. 29–34; 31 Ref.
90 Mahadik S P, Evans D R. Is schizophrenia a metabolic brain disorder? Membrane phospholipid dysregulation and its therapeutic implications. Psychiatric Clinics of North America. 2003;26(1):85-102. [pmid: 12683261].
91 Mehta V R. ‘Side effects of eicosapentaenoic acid and docosahexaenoic acid (maxepa)’. Journal of the Association of Physicians of India. 1992;40(7):486. [pmid: 1484043].
92 Mimura G, Murakami K, Gushiken M. Nutritional factors for longevity in Okinawa-present and future. Nutrition-and-Health. 1992;8:2-3. 159–163; 2 Ref.
93 Mitchell D C, Gawrisch K, Litman B J, Salem N Jr. Why is docosahexaenoic acid essential for nervous system function?. Biochemical-Society-Transactions. 1998;26:3. 365–370; 43 Ref.
94 More J. Long chain polyunsaturated fatty acid levels in chronic illness. Journal of Family Health Care. 2002;12(6 Suppl):3. [pmid: 12630148].
95 Morley R. Breast feeding and cognitive outcome in children born prematurely. Advances in Experimental Medicine & Biology. 2002;Vol 503:Pp 77-82. [pmid: 12026030].
96 Morley R, Thomas AGed, Ryan S. Nutrition and cognitive development. Third International Meeting on Advances in Perinatal and Pediatric Nutrition, Manchester, UK, September 1997. 1998;14:10. 752–754; 24 Ref.
97 Neuringer M, Reisbick S, Janowsky J. The role of n-3 fatty acids in visual and cognitive development: current evidence and methods of assessment. Journal-of-Pediatrics. 1994;125:5. 2 Suppl., S39–S47; 52 Ref.
98 Nourooz-Zadeh J, Pereira P. Age-related accumulation of free polyunsaturated fatty acids in human retina. Ophthalmic Research. 1999;31(4):273-9. [pmid: 10325542].
99 O'Connor D L, Hall R, Adamkin D, et al. Growth and development in preterm infants fed long-chain polyunsaturated fatty acids: A prospective, randomized controlled trial. Pediatrics. 2001;108(2 II):359-71. [pmid: 11483801].
100 Ogden P, Piziak V K, Cain P T, Carpentier W R, Havemann D F. Reactive lymphoid hyperplasia after omega-3 fatty acid supplementation. {comment} Annals of Internal Medicine. 1988;109(10):843-4.
101 Okuda Y, Mizutani M, Ogawa M, et al. Long-term effects of eicosapentaenoic acid on diabetic peripheral neuropathy and serum lipids in patients with type II diabetes mellitus. Journal of Diabetes & Its Complications. 1996;10(5):280-7. [pmid: 8887017].
102 Overgaauw P. {Dutch}. Tijdschrift Voor Diergeneeskunde. 2003;128(6):191-2. [pmid: 12674797].
103 Patterson J. Introduction - Comparative dietary risk: Balance the risk and benefits of fish consumption. Comments on Toxicology. 2002;8(46):337-43.
104 Peet M, Edwards R W. Lipids, depression and physical diseases. Current Opinion in Psychiatry. 1997;10(6):477-80.
105 Pelton R. Omega-3: Essential for good health. American Druggist. 1997;214(7):52-3.
106 Pilitsis J G, Diaz F G, Wellwood J M, et al. Quantification of free fatty acids in human cerebrospinal fluid. Neurochemical Research. 2001;26(12):1265-70. [pmid: 11885776].
107 Ponder D L. Long chain polyunsaturated fatty acids in infancy. International Pediatrics. 1992;7(4):312-9.
108 Rask-Nissila L, Jokinen E, Terho P, et al. Neurological development of 5-year-old children receiving a low-saturated fat, low-cholesterol diet since infancy: A randomized controlled trial. Journal of the American Medical Association. 2000;Vol 284(8):Pp 993-1000. Date of Publication: 23 AUG 2000 :993–1000. [pmid: 10944645].
109 Reich E E, Zackert W E, Brame C J, et al. Formation of novel D-ring and E-ring isoprostane-like compounds (D4/E4-neuroprostanes) in vivo from docosahexaenoic acid. Biochemistry. 2000;39(9):2376-83. [pmid: 10694406].
110 Richardson A J. The importance of omega-3 fatty acids for behaviour, cognition and mood. Scandinavian Journal of Nutrition/Naringsforskning. 2003;47(2):92-8.
111 Richardson A J, Puri B K. A randomized double-blind, placebo-controlled study of the effects of supplementation with highly unsaturated fatty acids on ADHD-related symptoms in children with specific learning difficulties. Progress in Neuro-Psychopharmacology & Biological Psychiatry. 2002;26(2):233-9. [pmid: 11817499].
112 Rodriguez Palmero M, Lopez Sabater M C, Castellote Bargallo A I, Torre Boronat MCdl, Rivero Urgell M, De la Torre Boronat M C. Administration of low doses of fish oil derived N-3 fatty acids to elderly subjects. European-Journal-of-Clinical-Nutrition. 1997;51:8. 554–560; 43 Ref.
113 Sanders T A B, Haines A P, Wormald R, Wright L A, Obeid O. Essential fatty acids, plasma cholesterol, and fat-soluble vitamins in subjects with age-related maculopathy and matched control subjects. American-Journal-of-Clinical-Nutrition. 1993;57:3. 428–433; 27 Ref. [pmid: 8257461].
114 Saugstad L F. Marine fat and human health. Introduction. Nutrition & Health. 2002;16(1):7-10. [pmid: 12083415].
115 Saugstad L F, Crawford Med, Kirby E. Human nature is unique in the mismatch between the usual diet and the need for “food for the brain” (marine fat, DHA). Adding marine fat is beneficial in schizophrenia and manic-depressive psychosis. This underlines brain dysfunction in these neurological disorders is associated with deficient intake of marine fat(DHA). Marine Fat and Human Health: The Letten F. Saugstad Symposium in Honour of Elaine Morgan, Oslo, Norway, 4th November 2000. Nutrition-and-Health. 2002;16:1. 41–44; 32 Ref.
116 Seddon J M, Rosner B, Sperduto R D, et al. Dietary fat and risk for advanced age-related macular degeneration. Archives of Ophthalmology. 2001;119(8):1191-9. [pmid: 11483088].
117 Shibuya T, Fukuo Y, Kobayashi Y, et al. Influence of the preventive effect of eicosapentaenoic acid on cerebrovascular disorders. Nippon Ika Daigaku Zasshi - Journal of the Nippon Medical School. 1985;52(2):222-4.
118 Simopoulos A P. New products from the agri-food industry: the return of n-3 fatty acids into the food supply. {Review} Lipids. 1999;34(Suppl):S297-301.
119 Singh M. Nutrition, brain and environment: How to have smarter babies?. Indian Pediatrics. 2003;40(3):213-20. [pmid: 12657753].
120 Skinner ERed, Postle A D. Brain lipids and mental disorders. A colloquium from the 664th Meeting of the Biochemical Society, University of Reading , Reading, UK, 15–17 December, 1997. Biochemical-Society-Transactions. 1998;26:2. 243–277; Many Ref.
121 Smith W, Mitchell P, Leeder S R. Dietary fat and fish intake and age-related maculopathy. Archives-of-Ophthalmology. 2000;118:3. 401–404; 38 Ref.
122 Stansby M E. Nutritional properties of fish oils. {Review} World Review of Nutrition & Dietetics. 1969;11:46-105.
123 Stordy B J. Dark adaptation, motor skills, docosahexaenoic acid, and dyslexia. American Journal of Clinical Nutrition. 2000;71(1 Suppl):323S-6S. [pmid: 10617990].
124 Tamura Y, Hirai A, Terano T, Saitoh H, Yoshida S. Clinical and epidemiological study of eicosapentaenoic acid (EPA) in Japan. Journal of Nutritional Science & Vitaminology. Spec No:140–3, 1992.
125 Temple N J. Nutrition and disease: challenges of research design. {comment} {Review} Nutrition. 2002;18(4):343-7.
126 Thorpe M. Infant formula supplemented with DHA: are there benefits?. Journal of the American Dietetic Association. 2003;103(5):551-2. [pmid: 12733531].
127 Totlandsdal J K, Tvedt N, Breilid R, Ronning T B, Kogstad E K, Myhren K J. {Review} {Norwegian}. Tidsskrift for Den Norske Laegeforening. 2001;121(21):2504-9. [pmid: 11875928].
128 Uauy R, Calderon F, Mena P, Simopoulos APed, Pavlou KN. Essential fatty acids in somatic growth and brain development. Nutrition-and-Fitness-1:-Diet,-Genes,-Physical-Activity-and-Health.-4th-International-Conference-on-Nutrition-and-Fitness,-Athens,-Greece,-25–29-May,-2000. 2001, 134–160; 135 Ref.
129 Uauy R, Hoffman D R, Peirano P, et al. Essential fatty acids in visual and brain development. Symposium on PUFA in Maternal and Child Health, Kansas City, Missouri, USA, 10–13 September 2000. 2001;36(9):885-95.
130 Uauy R, Mena P, DeSantiago S, Arroya Ped, Gutierrez Robledo LMed, Loria A. Lipids and neurodevelopment. Third Nestle Nutrition Conference. Nutrition and Brain Function From Infancy to Old Age, Mexico City, Mexico, 30–31 March, 2000. Nutrition-Reviews. 2001;59(8):2.
131 Vaddadi K S, Gilleard C J, Soosai E, Polonowita A K, Gibson R A, Burrows G D. Schizophrenia, tardive dyskinesia and essential fatty acids. Schizophrenia Research. 1996;20(3):287-94. [pmid: 8827855].
132 Vobecky JS, Iglesias JR, Preedy VRed, Grimble Ged, Watson R. Essential fatty acid requirements: implication for neural development. Nutrition-in-the-Infant:-Problems-and-Practical-Procedures. 2001, 133–138; 24 Ref.
133 Voigt R G, Llorente A M, Jensen C L, Fraley J K, Berretta M C, Heird W C. A randomized, double-blind, placebo-controlled trial of docosahexaenoic acid supplementation in children with attention-deficit/hyperactivity disorder. Journal of Pediatrics. 2001;139(2):189-96. [pmid: 11487742].
134 Wainwright P. Nutrition and behaviour: The role of n-3 fatty acids in cognitive function. British Journal of Nutrition. 2000;83(4):337-9. [pmid: 10858691].
135 Wainwright P E. Alpha-linolenic acid, long-chain n-3 fatty acids, and neonatal brain development. {Review} Nutrition. 1991;7(6):443-6.
136 Wainwright P E. Dietary essential fatty acids and brain function: a developmental perspective on mechanisms. {Review} Proceedings of the Nutrition Society. 2002;61(1):61-9.
137 Wainwright P E. Do essential fatty acids play a role in brain and behavioral development?. Neuroscience & Biobehavioral Reviews. 1992;16(2):193-205. [pmid: 1630730].
138 Werkman S H, Carlson S E. A randomized trial of visual attention of preterm infants fed docosahexaenoic acid until nine months. Lipids. 1996;31(1):91-7. [pmid: 8649241].
139 Willatts P. Long chain polyunsaturated fatty acids improve cognitive development. Journal of Family Health Care. 2002;12(6 Suppl):5. [pmid: 12630150].
140 Willatts P, Forsyth J S. The role of long-chain polyunsaturated fatty acids in infant cognitive development. Prostaglandins Leukotrienes and Essential Fatty Acids. 2000;Vol 63(12):Pp 95-100.
141 Willatts P, Forsyth J S, DiModugno M K, Varma S, Colvin M. Influence of long-chain polyunsaturated fatty acids on infant cognitive function. Lipids. 1998;33:10. 973–980; 57 Ref.
142 Williams L L, Horrocks L A, Leguire L E, Shannon B T. Serum fatty acid proportions in retinitis pigmentosa may be affected by a number of factors. Progress in Clinical & Biological Research. 1989;314:49-56. [pmid: 2608675].
143 Woodbury M M, Woodbury M A. Neuropsychiatric development: Two case reports about the use of dietary fish oils and/or choline supplementation in children. Journal of the American College of Nutrition. 1993;Vol 12(3):Pp 239-245. [pmid: 7691914].
144 Yehuda S, Rabinovitz S, Mostofsky D I. Essential fatty acids and sleep: mini-review and hypothesis. {Review} Medical Hypotheses. 1998;50(2):139-45.

### Rejected Topic (n = 161)

1 Anderson J W, Johnstone B M, Remley D T. Breast-feeding and cognitive development: A meta-analysis. American Journal of Clinical Nutrition. 1999;70(4):525-35. [pmid: 10500022].
2 Anonymous. Diet and Alzheimer's disease. Harvard Mental Health Letter 2003; 19(8):4–7.
3 Anonymous. Evidence and controversies concerning the association between diet and cancer. EPIC (European Prospective Investigation into Cancer) Group in Spain. Medicina Clinica 1996; 107(6):224–30.
4 Anonymous. Fat intake, antioxidants and Alzheimer's disease. Health News 2003; 9(4):7–8.
5 Arnaud J, Fleites P, Chassagne M, et al. Seasonal variations of antioxidant imbalance in Cuban healthy men. European Journal of Clinical Nutrition. 2001;55(1):29-38. [pmid: 11303492].
6 Askanas V, Engel W K, Kwan H H, et al. Autosomal dominant syndrome of lipid neuromyopathy with normal carnitine: successful treatment with long-chain fatty-acid-free diet. Neurology. 1985;35(1):66-72. [pmid: 3966003].
7 BAKER R W, SANDERS H, THOMPSON R H, ZILKHA K J. SERUM CHOLESTEROL LINOLEATE LEVELS IN MULTIPLE SCLEROSIS. J Neurol Neurosurg Psychiatry. Jun. 1965;28:212-7. [pmid: 14347622].
8 Bataille R, Donadio D, Morlock G, et al. {French}. Revue Du Rhumatisme Et Des Maladies Osteo-Articulaires. 1979;46(2):77-83. [pmid: 432517].
9 Bates G P, Hockly E. Experimental therapeutics in Huntington's disease: Are models useful for therapeutic trials?. Current Opinion in Neurology. 2003;16(4):465-70. [pmid: 12869804].
10 Bautista D, Obrador A, Moreno V, et al. Ki-ras mutation modifies the protective effect of dietary monounsaturated fat and calcium on sporadic colorectal cancer. Cancer Epidemiology, Biomarkers & Prevention. 1997;6(1):57-61.
11 Ben-Yosef R, Or R, Naparstek E, et al. Should soybean agglutinin purging be performed in breast cancer patients undergoing autologous stem cell transplantation?. American Journal of Clinical Oncology-Cancer Clinical Trials. 1997;20(4):419-23.
12 Bowen D J, Kestin M, McTiernan A, Carrell D, Green P. Effects of dietary fat intervention on mental health in women. Cancer Epidemiology, Biomarkers & Prevention. 1995;4(5):555-9.
13 Boyd N F, Cousins M, Lockwood G, Tritchler D. Dietary fat and breast cancer risk: the feasibility of a clinical trial of breast cancer prevention. Lipids. 1992;27(10):821-6. [pmid: 1435102].
14 Boyd N F, Cousins M, Lockwood G, Tritchler D. The feasibility of testing experimentally the dietary fat-breast cancer hypothesis. Progress in Clinical & Biological Research. 1990;346:231-41. [pmid: 2197628].
15 Boyd N F, Martin L J, Beaton M, Cousins M, Kriukov V. Long-term effects of participation in a randomized trial of a low-fat, high-carbohydrate diet. Cancer Epidemiology, Biomarkers & Prevention. 1996;5(3):217-22.
16 Bravo M P, Castellanos E, del Rey Calero J. Dietary factors and prostatic cancer. Urologia Internationalis. 1991;46(2):163-6. [pmid: 2053225].
17 Brawley O W, Thompson I M. Chemoprevention of prostate cancer. Urology. 1994;43(5):594-9. [pmid: 8165761].
18 Bruce W R, Eyssen G M, Ciampi A, Dion P W, Boyd N. Strategies for dietary intervention studies in colon cancer. Cancer. 1981;47(5 Suppl):1121-5. [pmid: 6263443].
19 Calandre L, Martinez Martin P, Campos Castello J. Treatment of lennox syndrome with medium chain triglycerides. Anales Espanoles De Pediatria. 1978;11(3):189-94. [pmid: 96716].
20 Cameron N E, Cotter M A. Metabolic and vascular factors in the pathogenesis of diabetic neuropathy. Diabetes. 1997;46(Suppl 2):S31-7. Sep. [pmid: 9285496].
21 Carli P M, Bailly F, Tavernier C, Milan C, Heudes D, Lavault J F. Multiple myeloma: epidemiological features in a well-defined population in Burgundy, France. International Journal of Epidemiology. 1989;18(2):330-3. [pmid: 2767846].
22 Chan M J A. Alzheimer's disease and vegetable oils. New-Zealand-Medical-Journal. 1993;106:481. [pmid: 8233198].
23 Chlebowski R T, Blackburn G L, Buzzard I M, et al. Current status: evaluation of dietary fat reduction as secondary breast cancer prevention. The Nutrition Adjuvant Study. Progress in Clinical & Biological Research. 1990;339:201-9. [pmid: 2202991].
24 Chlebowski R T, Blackburn G L, Buzzard I M, et al. Adherence to a dietary fat intake reduction program in postmenopausal women receiving therapy for early breast cancer. The Women's Intervention Nutrition Study. Journal of Clinical Oncology. 1993;11(11):2072-80. [pmid: 8229121].
25 Chlebowski R T, Nixon D W, Blackburn G L, et al. A breast cancer Nutrition Adjuvant Study (NAS): protocol design and initial patient adherence. Breast Cancer Research & Treatment. 1987;10(1):21-9. [pmid: 3318957].
26 Cohen L A, Rose D P, Wynder E L. A rationale for dietary intervention in postmenopausal breast cancer patients: an update. Nutrition & Cancer. 1993;19(1):1-10. [pmid: 8446511].
27 Converse C A, Hammer H M, Packard C J, Shepherd J. Plasma lipid abnormalities in retinitis pigmentosa and related conditions. Transactions of the Ophthalmological Societies of the United Kingdom. 1983;103(Pt 5):508-12. [pmid: 6591588].
28 Cornu P, Benavides J, Scatton B, Hauw J J, Philippon J. Increase in omega 3 (peripheral-type benzodiazepine) binding site densities in different types of human brain tumours. A quantitative autoradiography study. Acta Neurochirurgica. 1992;119(14):146-52. [pmid: 1336303].
29 Corrigan F M, Van Rhijn A, Horrobin D F. Essential fatty acids in Alzheimer's disease. Annals of the New York Academy of Sciences. 1991;640:250-2. [pmid: 1776746].
30 Cravo M L, Pinto A G, Chaves P, et al. Effect of folate supplementation on DNA methylation of rectal mucosa in patients with colonic adenomas: correlation with nutrient intake. Clinical Nutrition. 1998;17(2):45-9. [pmid: 10205316].
31 de la Taille A, Katz A, Vacherot F, et al. {Review} {French}. Presse Medicale. 2001;30(11):554-6.
32 Denson K W. Re: Multicenter case-control study of exposure to environmental tobacco smoke and lung cancer in Europe. {comment} Journal of the National Cancer Institute. 1999;91(9):803-4.
33 Enstrom J E. Assessing human epidemiologic data on diet as an etiologic factor in cancer development. {Review} Bulletin of the New York Academy of Medicine. 1982;58(3):313-22.
34 Ewertz M, Gill C. Dietary factors and breast-cancer risk in Denmark. International Journal of Cancer. 1990;46(5):779-84.
35 Farooqui A A, Horrocks L A, Farooqui T. Glycerophospholipids in brain: Their metabolism, incorporation into membranes, functions, and involvement in neurological disorders. Chemistry & Physics of Lipids. 2000;106(1):1-29. [pmid: 10878232].
36 Field E J, Joyce G. Steroid therapy and the erythrocyte unsaturated fatty acid (E-UFA) test for multiple sclerosis (MS). IRCS Medical Science. 1980;8(2):82.
37 Field E J, Shenton B K. Inhibitory effect of unsaturated fatty acids on lymphocyte-antigen interaction with special reference to multiple sclerosis. Acta Neurologica Scandinavica. 1975;52(2):121-36. [pmid: 1155030].
38 Flood A, Velie E M, Sinha R, et al. Meat, fat, and their subtypes as risk factors for colorectal cancer in a prospective cohort of women. American Journal of Epidemiology. 2003;158(1):59-68. [pmid: 12835287].
39 Fradet Y, Meyer F, Bairati I, Shadmani R, Moore L. Dietary fat and prostate cancer progression and survival. {Review} European Urology. 1999;35(56):388-91.
40 Freeman J M, Vining E P, Pillas D J, Pyzik P L, Casey J C, Kelly L M. The efficacy of the ketogenic diet-1998: a prospective evaluation of intervention in 150 children. Pediatrics. 1998;102(6):1358-63. [pmid: 9832569].
41 Gennari C, Chierichetti M S, Gonnelli S, et al. Migraine prophylaxis with salmon calcitonin: a cross-over double-blind, placebo-controlled study. Headache. 1986;26(1):13-6. [pmid: 3781818].
42 Ghadirian P, Boyle P, Simard A, Baillargeon J, Maisonneuve P, Perret C. Reported family aggregation of pancreatic cancer within a population-based case-control study in the Francophone Community in Montreal, Canada. International Journal of Pancreatology. 1991;10(34):183-96. [pmid: 1787333].
43 Ghadirian P, Lacroix A, Maisonneuve P, et al. Nutritional factors and prostate cancer: a case-control study of French Canadians in Montreal, Canada. Cancer Causes & Control. 1996;7(4):428-36. [pmid: 8813431].
44 Ghadirian P, Lacroix A, Maisonneuve P, et al. Nutritional factors and colon carcinoma: a case-control study involving French Canadians in Montreal, Quebec, Canada. Cancer. 1997;80(5):858-64. [pmid: 9307184].
45 Gillespie N G, Mena I, Cotzias G C, Bell M A. Diets affecting treatment of parkinsonism with levodopa. Journal of the American Dietetic Association. 1973;62(5):525-8. [pmid: 4572702].
46 Goldberg M J, Smith J W, Nichols R L. Comparison of the fecal microflora of Seventh-Day Adventists with individuals consuming a general diet. Implications concerning colonic carcinoma. Annals of Surgery. 1977;186(1):97-100. [pmid: 327955]. [pmcid: 1396198].
47 Goldbohm R A, Van Den Brandt P A, Brants H A M, et al. Validation of a dietary questionnaire used in a large-scale prospective cohort study on diet and cancer. European Journal of Clinical Nutrition. 1994;48(4):253-65. [pmid: 8039485].
48 Gordon N. Nutrition and cognitive function. {Review} Brain & Development. 1997;19(3):165-70.
49 Graham S, Hellmann R, Marshall J, et al. Nutritional epidemiology of postmenopausal breast cancer in western New York. {comment} American Journal of Epidemiology. 1991;134(6):552-66.
50 Gregorio D I, Emrich L J, Graham S, Marshall J R, Nemoto T. Dietary fat consumption and survival among women with breast cancer. Journal of the National Cancer Institute. 1985;75(1):37-41. [pmid: 3859694].
51 Haider W, Steinbereithner K. {German} Internationale Zeitschrift Fur Vitamin- Und Ernahrungsforschung - Beiheft. 12:172–83, 1972 .
52 Hanash K A, Al-Othaimeen A, Kattan S, et al. Prostatic carcinoma: A nutritional disease? Conflicting data from the Kingdom of Saudi Arabia. Journal of Urology. 2000;164(5):1570-2. [pmid: 11025706].
53 Hebert J R, Ebbeling C B, Olendzki B C, et al. Change in women's diet and body mass following intensive intervention for early-stage breast cancer. Journal of the American Dietetic Association. 2001;101(4):421-31. [pmid: 11320947].
54 Hebert J R, Hurley T G, Ma Y. The effect of dietary exposures on recurrence and mortality in early stage breast cancer. Breast Cancer Research & Treatment. 1998;51(1):17-28. [pmid: 9877026].
55 Hemingway C, Freeman J M, Pillas D J, Pyzik P L. The ketogenic diet: a 3- to 6-year follow-up of 150 children enrolled prospectively. Pediatrics. 2001;108(4):898-905. [pmid: 11581442].
56 Hiatt R A, Friedman G D, Bawol R D, Ury H K. Breast cancer and serum cholesterol. Journal of the National Cancer Institute. 1982;68(6):885-9. [pmid: 6953271].
57 Holm L E, Nordevang E, Hjalmar M L, Lidbrink E, Callmer E, Nilsson B. Treatment failure and dietary habits in women with breast cancer. Journal of the National Cancer Institute. 1993;85(1):32-6. [pmid: 8416253].
58 Horn-Ross P L, Hoggatt K J, West D W, et al. Recent diet and breast cancer risk: The California Teachers Study (USA). Cancer Causes & Control. 2002;13(5):407-15. [pmid: 12146845].
59 Horrobin D F. Essential fatty acids in the management of impaired nerve function in diabetes. {Review} Diabetes. 1997;46(Suppl 2):S90-3. Sep.
60 Howe G R, Friedenreich C M, Jain M, Miller A B. A cohort study of fat intake and risk of breast cancer. {comment} Journal of the National Cancer Institute. 1991;83(5):336-40.
61 Isbir T, Agachan B, Yilmaz H, et al. Apolipoprotein-E gene polymorphism and lipid profiles in Alzheimer's disease. Am. 2001;16(2):77-81.
62 Jones D Y, Schatzkin A, Green S B, et al. Dietary fat and breast cancer in the National Health and Nutrition Examination Survey I Epidemiologic Follow-up Study. Journal of the National Cancer Institute. 1987;79(3):465-71. [pmid: 3476789].
63 Katyal N G, Koehler A N, McGhee B, Foley C M, Crumrine P K. The ketogenic diet in refractory epilepsy: the experience of Children's Hospital of Pittsburgh. Clinical Pediatrics. 2000;39(3):153-9. [pmid: 10752008].
64 Katz E B, Boylan E S. Effects of reciprocal changes of diets differing in fat content on pulmonary metastasis from the 13762 rat mammary tumor. Cancer. 1989;49(9):2477-84.
65 Katz E B, Boylan E S. Stimulatory effect of high polyunsaturated fat diet on lung metastasis from the 13762 mammary adenocarcinoma in female retired breeder rats. J. 1987;79(2):351-8.
66 Kesse E, Clavel-Chapelon F, Slimani N, van Liere M. E3N Group. Do eating habits differ according to alcohol consumption? Results of a study of the French cohort of the European Prospective Investigation into Cancer and Nutrition (E3N-EPIC). {comment} American Journal of Clinical Nutrition. 2001;74(3):322-7.
67 Kohlmeier L, Simonsen N, van't Veer P, et al. Adipose tissue trans fatty acids and breast cancer in the European Community Multicenter Study on Antioxidants, Myocardial Infarction, and Breast Cancer. {comment} Cancer Epidemiology, Biomarkers & Prevention. 1997;6(9):705-10.
68 Kritchevsky S B. Dietary lipids and the low blood cholesterol-cancer association. American Journal of Epidemiology. 1992;135(5):509-20. [pmid: 1570817].
69 Kushi L H, Mink P J, Folsom A R, et al. Prospective study of diet and ovarian cancer. American Journal of Epidemiology. 1999;149(1):21-31. [pmid: 9883790].
70 Kushi L H, Potter J D, Bostick R M, et al. Dietary fat and risk of breast cancer according to hormone receptor status. Cancer Epidemiology, Biomarkers & Prevention. 1995;4(1):11-9.
71 Kushi L H, Sellers T A, Potter J D, et al. Dietary fat and postmenopausal breast cancer. {comment} Journal of the National Cancer Institute. 1992;84(14):1092-9.
72 Lange H W. Huntington's disease: Clinical, diagnostic and therapeutic aspects. Psycho. 2002;28(9):479-86.
73 Lasheras C, Fernandez S, Patterson A M. Mediterranean diet and age with respect to overall survival in institutionalized, nonsmoking elderly people. American Journal of Clinical Nutrition. 2000;71(4):987-92. [pmid: 10731507].
74 Little J, Logan R F, Hawtin P G, Hardcastle J D, Turner I D. Colorectal adenomas and diet: a case-control study of subjects participating in the Nottingham faecal occult blood screening programme. British Journal of Cancer. 1993;67(1):177-84. [pmid: 8381298].
75 Logroscino G, Marder K, Cote L, Tang M X, Shea S, Mayeux R. Dietary lipids and antioxidants in Parkinson's disease: a population-based, case-control study. Ann Neurol. 1996;39(1):89-94. [pmid: 8572672].
76 Love RR. Prevention of breast cancer in premenopausal women. {Review}. Journal of the National Cancer Institute. Monographs 1994; (16):61–5.
77 Love W C, Cashell A, Reynolds M, Callaghan N. Linoleate and fatty-acid patterns of serum lipids in multiple sclerosis and other diseases. Br. 1974;2(922):18-21.
78 Luchsinger J A, Tang M X, Shea S, Mayeux R. Caloric intake and the risk of Alzheimer disease. Archives of Neurology. 2002;59(8):1258-63. [pmid: 12164721].
79 MacLennan R, Macrae F, Bain C, et al. Randomized trial of intake of fat, fiber, and beta carotene to prevent colorectal adenomas. The Australian Polyp Prevention Project. {comment} Journal of the National Cancer Institute. 1995;87(23):1760-6.
80 Marshall E. Third strike for NCI breast cancer study. Science. 1990;250(4987):1503-4. [pmid: 2274777].
81 McKeown-Eyssen G E, Bright-See E, Bruce W R, et al. A randomized trial of a low fat high fibre diet in the recurrence of colorectal polyps. Journal of Clinical Epidemiology. 1994;47(5):525-36. [pmid: 7730878].
82 Meletis C D. Natural approaches to the treatment of Parkinson's disease. Alternative & Complementary Therapies. 1999;5(5):271-4.
83 Meletis C D, Bramwell B. Natural therapies to preserve and enhance cognition and memory. Alternative & Complementary Therapies. 2001;7(5):273-6.
84 Mertin J, Shenton B K, Field E J. Unsaturated fatty acids in multiple sclerosis. British Medical Journal. 1973;2(5869):777-8. [pmid: 4718333].
85 Messina M, Gardner C, Barnes S. Gaining insight into the health effects of soy but a long way still to go: commentary on the fourth International Symposium on the Role of Soy in Preventing and Treating Chronic Disease. {Review} Journal of Nutrition. 2002;132(3):547S-51S.
86 Meyer F, Bairati I, Shadmani R, Fradet Y, Moore L. Dietary fat and prostate cancer survival. Cancer Causes & Control. 1999;10(4):245-51. [pmid: 10482482].
87 Moreno L A, Sarria A, Popkin B M. The nutrition transition in Spain: A European Mediterranean country. European Journal of Clinical Nutrition. 2002;56(10):992-1003. 01 OCT 2002. [pmid: 12373620].
88 Moser A E, Singh I, Brown FR3, et al. The cerebrohepatorenal (Zellweger) syndrome. Increased levels and impaired degradation of very-long-chain fatty acids and their use in prenatal diagnosis. N. 1984;310(18):1141-6.
89 Moser H W. Clinical and therapeutic aspects of adrenoleukodystrophy and adrenomyeloneuropathy. {Review} Journal of Neuropathology & Experimental Neurology. 1995;54(5):740-5.
90 Moysich K B, Freudenheim J L, Baker J A, et al. Apolipoprotein E genetic polymorphism, serum lipoproteins, and breast cancer risk. Molecular Carcinogenesis. 2000;27(1):2-9. [pmid: 10642431].
91 Mulder I, Jansen M, Smit H A, et al. Role of smoking and diet in the cross-cultural variation in lung-cancer mortality: The seven countries study. International Journal of Cancer. 2000;88(4):665-71.
92 Nebeling L C, Miraldi F, Shurin S B, Lerner E. Effects of a ketogenic diet on tumor metabolism and nutritional status in pediatric oncology patients: two case reports. Journal of the American College of Nutrition. 1995;14(2):202-8. [pmid: 7790697].
93 Nettleton JA. Omega-3 fatty acids and health. 1995, Xiii + 359 Pp.
94 Neu I. {German}. Fortschritte Der Medizin. 1982;100(45):2110. [pmid: 7173796].
95 Newman P E. Alzheimer's disease revisited. Medical Hypotheses. 2000;54(5):774-6. [pmid: 10859685].
96 Okamoto K, Tanaka M, Kondo S. Treatment of vascular dementia. Annals of the New York Academy of Sciences. 2002;977:507-512. [pmid: 12480793].
97 Orlowski G, Brand R, Holsten P, Pohlau D. Food consumption, nutrient density of the food and nutrient supply in patients with multiple sclerosis. Ernahrungs-Umschau. 1996;43:1. 14–18; 18 Ref.
98 Palosaari P M, Kilponen J M, Hiltunen J K. Peroxisomal diseases. Annals of Medicine. 1992;24(3):163-6. [pmid: 1627308].
99 Pansari K, Gupta A, Thomas P. Alzheimer's disease and vascular factors: Facts and theories. International Journal of Clinical Practice. 2002;56(3):197-203. [pmid: 12018826].
100 Paty D W, Cousin H K, Read S, Adlakha K. Linoleic acid in multiple sclerosis: failure to show any therapeutic benefit. Acta. 1978;58(1):53-8.
101 Peluso M, Airoldi L, Magagnotti C, et al. White blood cell DNA adducts and fruit and vegetable consumption in bladder cancer. Carcinogenesis. 2000;21(2):183-7. [pmid: 10657956].
102 Pettegrew J W, Klunk W E, Kanal E, Panchalingam K, McClure R J. Changes in brain membrane phospholipid and high-energy phosphate metabolism precede dementia. Neurobiol. 1995;16(6):973-5.
103 Posada de la Paz M, Philen R M, Gerr F, et al. Neurologic outcomes of toxic oil syndrome patients 18 years after the epidemic. Environmental Health Perspectives. 2003;111(10):1326-34. [pmid: 12896854]. [pmcid: 1241614].
104 Poser S. Recent developments in multiple sclerosis research. Nervenarzt. 1979;50(10):611-25. [pmid: 395445].
105 Powell I J, Meyskens F L J. African American men and hereditary/familial prostate cancer: Intermediate-risk populations for chemoprevention trials. Urology. 2001;57(4 Suppl 1):178-81. [pmid: 11295621].
106 Powers J M, Moser H W. Peroxisomal disorders: Genotype, phenotype, major neuropathologic lesions, and pathogenesis. Brain Pathology. 1998;8(1):101-20. [pmid: 9458170].
107 Pradignac A, Schlienger J L, Velten M, Mejean L. Relationships between macronutrient intake, handicaps, and cognitive impairments in free living elderly people. Aging-Clinical & Experimental Research. 1995;7(1):67-74.
108 Prentice R L. Aspects of the science of cancer prevention trials: lessons from the conduct and planning of clinical trials of a low-fat diet intervention among women. Preventive Medicine. 1991;20(1):147-57. [pmid: 2008423].
109 Prentice R L. Measurement error and results from analytic epidemiology: dietary fat and breast cancer. {comment} Journal of the National Cancer Institute. 1996;88(23):1738-47.
110 Prentice R L, Sheppard L. Feasibility and importance of clinical trials of a low fat diet to reduce cancer risk. {Review} Progress in Clinical & Biological Research. 1990;346:205-15.
111 Puri B K, Bydder G M, Counsell S J, et al. MRI and neuropsychological improvement in Huntington disease following ethyl-EPA treatment. Neuroreport. 2002;13(1):123-6. [pmid: 11924873].
112 Reynish W, Andrieu S, Nourhashemi F, Vellas B. Nutritional factors and Alzheimer's disease. Journal-of-Gerontology.-Series-A,-Biological-Sciences-and-Medical-Sciences. 2001;11:M675-M680.
113 Rhijn A G v, Prior C A, Corrigan F M, Van Rhijn A G. Dietary supplementation with zinc sulphate, sodium selenite and fatty acids in early dementia of Alzheimer's type. Journal-of-Nutritional-Medicine. 1990;1:4. 259–266; 35 Ref.
114 Riboli E, Kaaks R. The EPIC Project: Rationale and study design. International Journal of Epidemiology. 1997;26(SUPPL. 1):S6-S14. [pmid: 9126529].
115 Risch H A, Jain M, Marrett L D, Howe G R. Dietary fat intake and risk of epithelial ovarian cancer. Journal of the National Cancer Institute. 1994;86(18):1409-15. [pmid: 8072035].
116 Risch H A, Marrett L D, Jain M, Howe G R. Differences in risk factors for epithelial ovarian cancer by histologic type. Results of a case-control study. American Journal of Epidemiology. 1996;144(4):363-72. [pmid: 8712193].
117 Rohan T E, Hiller J E, McMichael A J. Dietary factors and survival from breast cancer. Nutrition & Cancer. 1993;20(2):167-77. [pmid: 8233982].
118 Rohan T E, Howe G R, Burch J D, Jain M. Dietary factors and risk of prostate cancer: a case-control study in Ontario, Canada. Cancer Causes & Control. 1995;6(2):145-54. [pmid: 7749054].
119 Rohan T E, Jain M, Miller A B. A case-cohort study of diet and risk of benign proliferative epithelial disorders of the breast (Canada). Cancer Causes & Control. 1998;9(1):19-27. [pmid: 9486460].
120 Rose D P, Connolly J M, Meschter C L. Effect of dietary fat on human breast cancer growth and lung metastasis in nude mice. J. 1991;83(20):1491-5.
121 Ruiz-Torres A, Gimeno A, Munoz F J, Vicent D. Are anthropometric changes in healthy adults caused by modifications in dietary habits or by aging?. Gerontology. 1995;41(5):243-51. [pmid: 8537007].
122 Saxe G A, Rock C L, Wicha M S, Schottenfeld D. Diet and risk for breast cancer recurrence and survival. Breast Cancer Research & Treatment. 1999;53(3):241-53. [pmid: 10369070].
123 Schatzkin A, Subar A F, Thompson F E, et al. Design and serendipity in establishing a large cohort with wide dietary intake distributions : the National Institutes of Health-American Association of Retired Persons Diet and Health Study. American Journal of Epidemiology. 2001;154(12):1119-25. [pmid: 11744517].
124 Seidel D. {German}. Nervenarzt. 1981;52(8):489-90. [pmid: 7279082].
125 Shekelle R B, Rossof A H, Stamler J. Dietary cholesterol and incidence of lung cancer: the Western Electric Study. {comment} American Journal of Epidemiology. 1991;134(5):480-4. discussion 543–4.
126 Sibley W A. Current methods of therapy in multiple sclerosis. {Review} Modern Treatment. 1970;7(5):918-29.
127 Simon M S, Heilbrun L K, Boomer A, et al. A randomized trial of a low-fat dietary intervention in women at high risk for breast cancer. Nutrition & Cancer. 1997;27(2):136-42. [pmid: 9121940].
128 Singh R B, Kartik C, Otsuka K, Pella D, Pella J. Brain-heart connection and the risk of heart attack. Biomedicine & Pharmacotherapy. 2002;56(SUPPL. 2):257s-65s.
129 Slattery M L, Curtin K, Anderson K, et al. Associations between dietary intake and Ki-ras mutations in colon tumors: A population-based study. Cancer Research. 2000;60(24):6935-41. [pmid: 11156393].
130 Small E J. Update on the diagnosis and treatment of prostate cancer. {Review} Current Opinion in Oncology. 1998;10(3):244-52.
131 Smith-Warner S A, Ritz J, Hunter D J, et al. Dietary fat and risk of lung cancer in a pooled analysis of prospective studies. Cancer Epidemiology, Biomarkers & Prevention. 2002;11(10 I):987-92.
132 Solfrizzi V, Panza F, Torres F, et al. High monounsaturated fatty acids intake protects against age-related cognitive decline. Neurology. 1999;52(8):1563-9. [pmid: 10331679].
133 Speizer F E, Colditz G A, Hunter D J, Rosner B, Hennekens C. Prospective study of smoking, antioxidant intake, and lung cancer in middle-aged women (USA). Cancer Causes & Control. 1999;10(5):475-82. [pmid: 10530619].
134 Stemmermann G N, Nomura A M, Heilbrun L K. Dietary fat and the risk of colorectal cancer. Cancer Research. 1984;44(10):4633-7. [pmid: 6467218].
135 Svoboda K, Juhasz A, Hampson J. The bioactivity of essential oils and their components on human nervous system. Aroma-Research. 2000;1:4. 92–98; 17 Ref.
136 Swank R L, Goodwin J. Review of MS patient survival on a Swank low saturated fat diet. Nutrition. 2003;19(2):161-2. [pmid: 12591551].
137 Tichy J, Vymazal J. Changes of some serum fatty acids and lipids in relation to the clinical course of multiple sclerosis. Acta Neurologica Scandinavica. 1973;49(3):345-54. [pmid: 4747021].
138 Tichy J, Vymazal J. {Czech}. Casopis Lekaru Ceskych. 1978;117(3839):1184-90. [pmid: 709590].
139 Tobiasz-Adamczyk B. Health beliefs and health behaviours in subpopulation of stomach cancer families and in the control group. Cancer Letters. 1997;114(12):301-4. [pmid: 9103316].
140 Tremblay A, Drapeau V, Doucet E, Almeras N, Despres J P, Bouchard C. Fat balance and ageing: results from the Quebec Family Study. British Journal of Nutrition. 1998;79(5):413-8. [pmid: 9682659].
141 Twyman D. Nutritional management of the critically ill neurologic patient. {Review} Critical Care Clinics. 1997;13(1):39-49.
142 Uauy Dagach R, Mena P, Hoffman D, Perman JAed, Rey J. Nutrition, diet, and infant development: long-chain polyunsaturated fatty acids in infant neurodevelopment. Clinical Trials in Infant Nutrition: Methodology, Statistics and Ethical Issues. Nestle-Nutrition-Workshop-Series. 1998;40:153-180. 56 Ref.
143 Vaddadi K S. Essential fatty acids and neuroleptic drug-associated tardive dyskinesia: Preliminary clinical observations. IRCS Medical Science. 1984;12(8):678.
144 Vaddadi K S, Courtney P, Gilleard C J, Manku M S, Horrobin D F. A double-blind trial of essential fatty acid supplementation in patients with tardive dyskinesia. Psychiatry Research. 1989;27(3):313-23. [pmid: 2565585].
145 van den Brandt P A, van't Veer P, Goldbohm R A, et al. A prospective cohort study on dietary fat and the risk of postmenopausal breast cancer. Cancer Research. 1993;53(1):75-82. [pmid: 8416752].
146 Van Wezel-Meijler G, Van der Knaap M S, Huisman J, Jonkman E J, Valk J, Lafeber H N. Dietary supplementation of long-chain polyunsaturated fatty acids in preterm infants: Effects on cerebral maturation. Acta Paediatrica. 2002;91(9):942-50. [pmid: 12412870].
147 Vymazal J, Tichy J. {Czech}. Ceskoslovenska Neurologie. 1972;35(4):195-201. [pmid: 5044148].
148 Wasantwisut E. Nutrition and development: other micronutrients' effect on growth and cognition. {Review} Southeast Asian Journal of Tropical Medicine & Public Health. 1997;28(Suppl 2):78-82.
149 Weitzel K W, Thomas M L, Small R E, Goode J - V. Migraine: A comprehensive review of new treatment options. Pharmacotherapy. 1999;19(8):957-73. [pmid: 10453967].
150 West D W, Slattery M L, Robison L M, et al. Dietary intake and colon cancer: sex- and anatomic site-specific associations. American Journal of Epidemiology. 1989;130(5):883-94. [pmid: 2554725].
151 Whalley L J, Fox H C, Lemmon H A, et al. Dietary supplement use in old age: Associations with childhood IQ, current cognition and health. International Journal of Geriatric Psychiatry. 2003;18(9):769-76. [pmid: 12949843].
152 Willett W C, Hunter D J. Prospective studies of diet and breast cancer. {Review} Cancer. 1994;74(3 Suppl):1085-9.
153 Willett W C, Hunter D J, Stampfer M J, et al. Dietary fat and fiber in relation to risk of breast cancer. An 8-year follow-up. {comment} JAMA. 1992;268(15):2037-44.
154 Williams L L, O'Dougherty M M, Wright F S, et al. Dietary essential fatty acids, vitamin E, and Charcot-Marie-Tooth disease. Neurology. 1986;36(9):1200-5. [pmid: 3748386].
155 Willis M S, Wians F H Jr. The role of nutrition in preventing prostate cancer: A review of the proposed mechanism of action of various dietary substances. Clinica Chimica Acta. 2003;330(12):57-83.
156 Wolff A C, Donehower R C, Carducci M K, et al. Phase I study of docosahexaenoic acid-paclitaxel: A taxane-fatty acid conjugate with a unique pharmacology and toxicity profile. Clinical Cancer Research. 2003;9(10 I):3589-97. [pmid: 14506145].
157 Wolfgarten E, Rosendahl U, Nowroth T, et al. Coincidence of nutritional habits and esophageal cancer in Germany. Onkologie. 2001;24(6):546-51. [pmid: 11799309].
158 Wolk A, Bergstrom R, Hunter D, et al. A prospective study of association of monounsaturated fat and other types of fat with risk of breast cancer. {comment} Archives of Internal Medicine. 1998;158(1):41-5.
159 Wolkin A, Jordan B, Peselow E, Rubinstein M, Rotrosen J. Essential fatty acid supplementation in tardive dyskinesia. American Journal of Psychiatry. 1986;143(7):912-4. [pmid: 3013033].
160 Young S N. Lifestyle drugs, mood, behaviour and cognition. Journal of Psychiatry & Neuroscience. 2003;28(2):87-9. [pmid: 12670125]. [pmcid: 161729].
161 Zureik M, Ducimetiere P, Warnet J M, Orssaud G. Fatty acid proportions in cholesterol esters and risk of premature death from cancer in middle aged French men. BMJ. British Medical Journal. 1995;311(7015):1251-1254. [pmid: 7496232].

### Rejected Population (n = 15)

1 Black K L, Hoff J T. Eicosapentaenoic acid: Effect on brain prostaglandins, cerebral blood flow and edema in ischemic gerbils. Stroke. 1984;15(1):65. [pmid: 6320504].
2 Bourre J M, Bonneil M, Clement M, et al. Function of dietary polyunsaturated fatty acids in the nervous system. Prostaglandins Leukotrienes & Essential Fatty Acids. 1993;48(1):5-15.
3 Bourre JM, Dumont O, Piciotti M et al. Essentiality of omega-3 fatty acids for brain structure and function. In: Simopoulos AP, Kifer RR, Martin RE, Barlow SM, eds. Health effects of omega-3 polyunsaturated fatty acids in seafoods. Vol. 66. Basel, Karger: World Rev Nutr Diet, 1991: 103–17.
4 Chalon S, Vancassel S, Zimmer L, et al. Polyunsaturated fatty acids and cerebral function: focus on monoaminergic neurotransmission. Symposium on PUFA in Maternal and Child Health, Kansas City, Missouri, USA, 10–13 September 2000. Lipids. 2001;36(9):937-44. [pmid: 11724466].
5 Christensen E, Woldseth B, Hagve T A, et al. Peroxisomal beta-oxidation of polyunsaturated long chain fatty acids in human fibroblasts. The polyunsaturated and the saturated long chain fatty acids are retroconverted by the same acyl-CoA oxidase. Scandinavian Journal of Clinical and Laboratory Investigation Supplement. 1993;215:61-74. [pmid: 8327852].
6 Fernstrom JD. Effects of dietary polyunsaturated fatty acids on neuronal function. PUFA in Infant Nutrition: Consensus and Controversies, 7–9, November, 1996, Barcelona, Spain. Lipids. 1999, 34: 2, 161–169; 62 Ref.
7 Gerbi A, Maixent JM, Barbey O et al. Neuroprotective effect of fish oil in diabetic neuropathy. Lipids 1999; 7.
8 Kim HeeYong, Edsall L, Kim H Y. The role of docosahexaenoic acid (22:6n-3) in neuronal signaling. Lipids. 1999;34(Supplement):S249-S250. 1 Ref. [pmid: 10419168].
9 Leaf A. The electrophysiologic basis for the antiarrhythmic and anticonvulsant effects of n-3 polyunsaturated fatty acids: Heart and brain. Lipids. 2001;36(SUPPL.):S107-S110. [pmid: 11837982].
10 Okuyama H. Minimum requirements of n-3 and n-6 essential fatty acids for the function of the central nervous system and for the prevention of chronic disease. Proceedings of the Society for Experimental Biology & Medicine. 1992;200(2):174-6. [pmid: 1579578].
11 Phillis J W, O'Regan M H. The role of phospholipases, cyclooxygenases, and lipoxygenases in cerebral ischemic/traumatic injuries. {Review} Critical Reviews in Neurobiology. 2003;15(1):61-90.
12 Roberts L J2, Montine T J, Markesbery W R, et al. Formation of isoprostane-like compounds (neuroprostanes) in vivo from docosahexaenoic acid. Journal of Biological Chemistry. 1998;273(22):13605-12. [pmid: 9593698].
13 Rodriguez de Turco E B, Belayev L, Liu Y, et al. Systemic fatty acid responses to transient focal cerebral ischemia: influence of neuroprotectant therapy with human albumin. Journal of Neurochemistry. 2002;83(3):515-24. [pmid: 12390513].
14 Salem N, Edmond J, Kyle D, et al. Brain uptake and utilization of fatty acids: Applications to peroxisomal biogenesis disorders (An International Workshop): Roundtable discussion of session 2: Brain uptake, transport, and metabolism of PUFA: In vivo and in vitro studies. Journal of Molecular Neuroscience. 2001;16(23):215-21.
15 Yehuda S, Rabinovitz S, Mostofsky D I. Essential fatty acids are mediators of brain biochemistry and cognitive functions. Journal of Neuroscience Research. 1999;56(6):565-70. [pmid: 10374811].

### Rejected Study Design Descriptive (n = 24)

1 Agranoff B W. Multiple sclerosis. Dietary fats and health. AOCS-Monograph. 1983;10:941-50.
2 Anonymous. Fatty acids and multiple sclerosis. Lancet 1967; 2(7518):708–9.
3 Anonymous. Feeding the aging brain. Newsweek 2003; 141(3):54.
4 Anonymous. Lipids and multiple sclerosis. Lancet 1990; 336(8706):25–6.
5 Anonymous. More evidence that eating fish often can reduce risk of Alzheimer's disease. Pharmaceutical Journal Vol 271(7259) (Pp 109) , 2003. 26 JUL 2003.
6 Anonymous. Omega 3 fatty acids as additive in multiple sclerosis. Deutsche Apotheker Zeitung 1998; 138(3):43–4.
7 Anonymous. Polyunsaturated fatty acids and colchicine in multiple sclerosis. British Medical Journal 1979; 1(6160):411–2.
8 Das U N. Is there a role for saturated and long-chain fatty acids in multiple sclerosis?. Nutrition. 2003;19(2):163-6. [pmid: 12591552].
9 Field E J. Multiple sclerosis: treatment and prophylaxis. Journal of the Royal Society of Medicine. 1979;72(7):487-8. [pmid: 552545]. [pmcid: 1436957].
10 Field E J. Polyunsaturated fatty acids in multiple sclerosis. British Medical Journal. 1979;1(6169):1016-7. [pmid: 435921].
11 Field E J, Joyce G. Clinical trials of unsaturated fatty acids in multiple sclerosis. IRCS Medical Science. 1981;9(12):1081.
12 Field E J, Joyce G. Multiple sclerosis: what can and cannot be done. British Medical Journal. 1979;2(6204):1571-2. [pmid: 534872]. [pmcid: 1597463].
13 Fisher M. Adverse effects of fish oil (I: Reply). Archives of Internal Medicine. 1990;150(9):1971. [pmid: 2393333].
14 Friedland R. Fish consumption and the risk of Alzheimer disease: is it time to make dietary recommendations?. Archives of Neurology. 2003;60(7):923-4. [pmid: 12873846].
15 Grant W B. Diet and risk of dementia: Does fat matter? The Rotterdam study. Neurology. 2003;60(12):2020-1. [pmid: 12821765].
16 Hansen H S. New biological and clinical roles for the n-6 and n-3 fatty acids. Nutrition Reviews. 1994;52(5):162-7. [pmid: 8052455].
17 Johnson S. The possible role of gradual accumulation of copper, cadmium, lead and iron and gradual depletion of zinc, magnesium, selenium, vitamins B2, B6, D, and E essential fatty acids in multiple sclerosis. Medical Hypotheses. 2000;55(3):239-41. [pmid: 10985916].
18 Katz R, Hamilton J A, Spector A A, et al. Brain uptake and utilization of fatty acids. Journal of Molecular Neuroscience. 2001;16(23):333-5. [pmid: 11478387].
19 Marshall B H. Lipids and neurological diseases. Medical-Hypotheses. 1991;34:3. 272–274; 8 Ref.
20 Newman P E. Could diet be one of the causal factors of Alzheimer's disease?. Medical Hypotheses. 1992;39(2):123-6. [pmid: 1461171].
21 Noetzel M J. Fish oil and myelin: Cautious optimism for treatment of children with disorders of peroxisome biogenesis. Neurology. 1998;51(1):5-7. [pmid: 9674767].
22 Peers R. Fatty diet, mitochondria and Parkinson's disease. New Zealand Medical Journal. 1997;110(1041):132. [pmid: 9140421].
23 Spirer Z, Koren L, Finkelstein A, Jurgenson U. Prevention of febrile seizures by dietary supplementation with N-3 polyunsaturated fatty acids. {Review} Medical Hypotheses. 1994;43(1):43-5.
24 Voskuyl R A. Is marine fat anti-epileptogenic?. Nutrition & Health. 2002;16(1):51-3. [pmid: 12083414].

### Rejected Study Design Review/Meta-Analysis (n = 63)

1 Fish oil supplements. Geneesmiddelenbulletin 1999; 33(4 ):37–42.
2 Anonymous. Fish oil supplements. Geneesmiddelenbulletin 1999; 33(4):37–42.
3 Bates D. Dietary lipids and multiple sclerosis. {Review} Upsala Journal of Medical Sciences - Supplement. 1990;48:173-87.
4 Bates D. Lipids and multiple sclerosis. Biochemical Society Transactions. 1989;17(2):289-91. [pmid: 2546837].
5 Bazan N G, Palacios-Pelaez R, Lukiw W J. Hypoxia signaling to genes: significance in Alzheimer's disease. {Review} Molecular Neurobiology. 2002;26(23):283-98.
6 Belluzzi A. N-3 and n-6 fatty acids for the treatment of autoimmune diseases. European.Journal.of.Lipid.Science.and.Technology. 2001;103:399-407.
7 Ben-Shlomo Y, Davey Smith G, Marmot M G. Dietary fat in the epidemiology of multiple sclerosis: has the situation been adequately assessed?. Neuroepidemiology. 1992;11(46):214-25. [pmid: 1291885].
8 Benda W. Alternative medicine research report - Brief citations. Journal of Herbal Pharmacotherapy. 2003;3(2):61-7.
9 Berrino F. {Review} {Italian} Epidemiologia e Prevenzione 2002; 26(3):107–15.
10 Biase A di, Salvati S, Di Biase A. Exogenous lipids in myelination and demyelination. Kaohsiung-Journal-of-Medical-Sciences. 1997;13(1):19-29. [pmid: 9130819].
11 Bryan J, Calvaresi E, Hughes D. Foods for thinking and memory. Food-Australia. 2001;53(11):477-9.
12 Calder P. n-3 polyunsaturated fatty acids and cytokine production in health and disease. Annals of Nutrition & Metabolism. 1997;41(4):203-34. [pmid: 9363294].
13 Caldis-Coutris N, Namaka M, Melanson M. Nutritional management of multiple sclerosis. Canadian Pharmaceutical Journal. 2002;135(5):31-840.
14 Carroll K K. Biological effects of fish oils in relation to chronic diseases. Lipids. 1986;21(12):731-2. [pmid: 3821385].
15 Clausen J. Demential syndromes and the lipid metabolism. Acta Neurologica Scandinavica. 1984;70(5):345-55. [pmid: 6507044].
16 Clayton P, Watson DH. Mood, cognitive function and nutritional and other supplements. Performance-Functional-Foods 2003; 21–37.
17 Cooper J L. Dietary lipids in the aetiology of Alzheimer's disease: implications for therapy. Drugs & Aging. 2003;20(6):399-418. [pmid: 12710861].
18 Das U N. Estrogen, statins, and polyunsaturated fatty acids: similarities in their actions and benefits -- is there a common link?. Nutrition. 2002;18(2):178-88. [pmid: 11844650].
19 Das U N. Long-chain polyunsaturated fatty acids in the growth and development of the brain and memory. Nutrition. 2003;19:1. 62–65; 71 Ref. [pmid: 12507630].
20 de Andres C, Lledo A. Fatty diet and multiple sclerosis. {Review} {Spanish} Revista De Neurologia. 1997;25(148):2032-5.
21 Di Biase A, Salvati S. Exogenous lipids in myelination and myelination. {Review} Kaohsiung Journal of Medical Sciences. 1997;13(1):19-29.
22 Farkas E, de Wilde M C, Kiliaan A J, Luiten P G. Chronic cerebral hypoperfusion-related neuropathologic changes and compromised cognitive status: window of treatment. {Review} Drugs of Today. 2002;38(5):365-76.
23 Fernandez O. {Spanish} Neurologia 1991; 6(7):235–7
24 French J M. MaxEPA in multiple sclerosis. British Journal of Clinical Practice. 1984;31(Supplement):117-21. [pmid: 6091716].
25 Gallai V, Sarchielli P, Trequattrini A, Murasecco D. Supplementation of polyunsaturated fatty acids in multiple sclerosis. {Review} Italian Journal of Neurological Sciences. 1992;13(5):401-7.
26 Gerster H. Can adults adequately convert alpha-linolenic acid (18:3n-3) to eicosapentaenoic acid (20:5n-3) and docosahexaenoic acid (22:6n-3)?. {Review} International Journal for Vitamin & Nutrition Research. 1998;68(3):159-73.
27 Gibson R A. The effect of diets containing fish and fish oils on disease risk factors in humans. Australian & New Zealand Journal of Medicine. 1988;18(5):713-22. [pmid: 3072953].
28 Grant W B. Dietary links to Alzheimer's disease: 1999 Update. Journal of Alzheimer's Disease. 1999;1(45):197-201.
29 Grant W B, Campbell A, Itzhaki R F, Savory J. The significance of environmental factors in the etiology of Alzheimer's disease. Challenging Views of Alzheimer's Disease, Cincinnati, USA, 28–29 July 2001. JAD,-Journal-of-Alzheimer's-Disease. 2002;4:3. 179–189; 124 Ref.
30 Haag M. Essential fatty acids and the brain. Canadian Journal of Psychiatry - Revue Canadienne De Psychiatrie. 2003;48(3):195-203. [pmid: 12728744].
31 Hibbeln J R, Salem N Jr. Dietary polyunsaturated fatty acids and depression: When cholesterol does not satisfy. American Journal of Clinical Nutrition. 1995;62(1):1-9. [pmid: 7598049].
32 Huntley A, Ernst E. Complementary and alternative therapies for treating multiple sclerosis symptoms: A systematic review. Complementary Therapies in Medicine. 2000;8(2):97-105. [pmid: 10859602].
33 Hutter C. On the causes of multiple sclerosis. {Review} Medical Hypotheses. 1993;41(2):93-6.
34 Hutter C D, Laing P. Multiple sclerosis: sunlight, diet, immunology and aetiology. {Review} Medical Hypotheses. 1996;46(2):67-74.
35 Infante J P, Huszagh V A. On the molecular etiology of decreased arachidonic (20:4n-6), docosapentaenoic (22:5n-6) and docosahexaenoic (22:6n-3) acids in Zellweger syndrome and other peroxisomal disorders. {Review} Molecular & Cellular Biochemistry. 1997;168(12):101-15.
36 Irving G F. Nutrition and cognitive function in the elderly. Scandinavian Journal of Nutrition/Naringsforskning. 2003;47(3):139-42.
37 Kalmijn S. Fatty acid intake and the risk of dementia and cognitive decline: a review of clinical and epidemiological studies. Journal of Nutrition, Health & Aging. 2000;4(4):202-7.
38 Kidd P M. Multiple sclerosis, an autoimmune inflammatory disease: prospects for its integrative management. {Review} Alternative Medicine Review. 2001;6(6):540-66.
39 Martinez M. Developmental profiles of polyunsaturated fatty acids in the brain of normal infants and patients with peroxisomal diseases: severe deficiency of docosahexaenoic acid in Zellweger's and pseudo-Zellweger's syndromes. World Review of Nutrition & Dietetics. 1991;66:87-102. [pmid: 1828923].
40 Martinez M. Polyunsaturated fatty acids in the developing human brain, erythrocytes and plasma in peroxisomal disease: therapeutic implications. {Review} Journal of Inherited Metabolic Disease. 1995;18(Suppl 1):61-75.
41 Martinez Regulez M. The importance of docosahexaenoic acid (DHA) on brain development in the normal child and in the patient with Zellweger's syndrome. Ciencia-Pediatrika. 2002;22(8):275-88.
42 Mayer M. Essential fatty acids and related molecular and cellular mechanisms in multiple sclerosis: new looks at old concepts. Folia-Biologica-Praha. 1999;45:4. 133–141; 130 Ref.
43 McCarty M F. Magnesium taurate and fish oil for prevention of migraine. {Review} Medical Hypotheses. 1996;47(6):461-6.
44 McCarty M F. Vascular nitric oxide, sex hormone replacement, and fish oil may help to prevent Alzheimer's disease by suppressing synthesis of acute-phase cytokines. Medical-Hypotheses. 1999;53:5. 369–374; 85 Ref.
45 Newman P E. Could diet be used to reduce the risk of developing Alzheimer's disease?. {Review} Medical Hypotheses. 1998;50(4):335-7.
46 Payne A. Nutrition and diet in the clinical management of multiple sclerosis. Journal of Human Nutrition & Dietetics. 2001;14(5):349-57. [pmid: 11906575].
47 Pohlau D, Hoffmann V, Orlowski G, et al. Fats and multiple sclerosis. Ernahrungs-Umschau. 1997;44:4. 136–142; 63 Ref.
48 Qi K, Hall M, Deckelbaum R J. Long-chain polyunsaturated fatty acid accretion in brain. Curr. 2002;5(2):133-8.
49 Raymond G V. Peroxisomal disorders. {Review} Current Opinion in Pediatrics. 1999;11(6):572-6.
50 Rogers P J. A healthy body, a healthy mind: long-term impact of diet on mood and cognitive function. The Summer Meeting of the Nutrition Society, University College, Cork, Republic of Ireland, 27–30 June 2000. Proceedings-of-the-Nutrition-Society. 2001;60:1. 135–143; 86 Ref.
51 Rondanelli M, Opizzi A, Bonisio A, Trotti R, Magnani B. Dietary habits and migraine: Which are the links?. Confinia Cephalalgica. 2002;11(2):79-93.
52 Salem N Jr, Litman B, Kim H Y, et al. Mechanisms of action of docosahexaenoic acid in the nervous system. Symposium on PUFA in Maternal and Child Health, Kansas City, Missouri, USA, 10–13 September 2000. Lipids. 2001;36:9. 945–959; 149 Ref.
53 Segasothy M, Phillips P A. Vegetarian diet: panacea for modern lifestyle diseases?. {comment} {Review} Qjm. 1999;92(9):531-44.
54 Seidel D. {German} Fortschritte Der Neurologie-Psychiatrie 1982; 50(6):173–89.
55 Shapiro H. Could n-3 polyunsaturated fatty acids reduce pathological pain by direct actions on the nervous system?. Prostaglandins,-Leukotrienes-and-Essential-Fatty-Acids. 2003;3:219-24.
56 Solfrizzi V, Panza F, Capurso A. The role of diet in cognitive decline. {Review} Journal of Neural Transmission. 2003;110(1):95-110.
57 Spector A A. Plasma free fatty acid and lipoproteins as sources of polyunsaturated fatty acid for the brain. J. 2001;16(23):159-65. discussion 215–21.
58 Spigai C. Basic theory and practical conditions for adopting in old age a diet with the correct amount of essential polyunsaturated fatty acids. Minerva-Dietologica. 1973;3:110-7.
59 Swank R L. Multiple sclerosis: twenty years on low fat diet. Archives of Neurology. 1970;23(5):460-74. [pmid: 5471652].
60 Uauy R, Peirano P, Hoffman D, Mena P, Birch D, Birch E. Role of essential fatty acids in the function of the developing nervous system. Lipids. 1996;31(SUPPL):S167-S176. 84 Ref. [pmid: 8729114].
61 Vaddadi K. Dyskinesias and their treatment with essential fatty acids: a review. {Review} Prostaglandins Leukotrienes & Essential Fatty Acids. 1996;55(12):89-94.
62 Yoshida S, Sato A, Okuyama H. Pathophysiological effects of dietary essential fatty acid balance on neural systems. Japanese Journal of Pharmacology. 1998;77(1):11-22. [pmid: 9639056].
63 Youdim K A, Martin A, Joseph J A. Essential fatty acids and the brain: possible health implications. International Journal of Developmental Neuroscience. 2000;18(45):383-99. [pmid: 10817922].

### Rejected Inappropriate Study Design (n = 23)

1 Auada M P, Taube M B P, Collares E F, Tanaka A M U, Cintra M L. Sjogren-Larsson syndrome: Biochemical defects and follow up in three cases. European Journal of Dermatology. 2002;12(3):263-6. [pmid: 11978568].
2 Bennett MJ, Hosking GP, Gayton R, Thompson G, Galloway JH, Cartwright IJ. Therapeutic modification of membrane lipid abnormalities in juvenile neuronal ceroid-lipofuscinosis (Batten disease). American Journal of Medical Genetics 1988; Supp 5:275–81.
3 Bjerve KS. n-3 fatty acid deficiency in man. Journal of Internal Medicine. Supplement 1989; 225(731)171–5.
4 Bower B D, Newsholme E A. Treatment of idiopathic polyneuritis by a polyunsaturated fatty-acid diet. Lancet. 1978;8064:583-5. [pmid: 76125].
5 Djoenaidi W, Notermans S L H, Verbeek A L M. Subclinical beriberi polyneuropathy in the low income group: An investigation with special tools on possible patients with suspected complaints. European Journal of Clinical Nutrition. 1996;50(8):549-55. [pmid: 8863016].
6 Esparza M L, Sasaki S, Kesteloot H. Nutrition, latitude, and multiple sclerosis mortality: an ecologic study. Am J Epidemiol. 1995;142(7):733-7. [pmid: 7572944].
7 Ferry P, Johnson M, Wallis P. Use of complementary therapies and non-prescribed medication in patients with Parkinson's disease. Postgraduate Medical Journal. 2002;78(924):612-4. [pmid: 12415085].
8 Harper M E, Patrick J, Kramer J K, Wolynetz M S. Erythrocyte membrane lipid alterations in undernourished cerebral palsied children during high intakes of a soy oil-based enteral formula. {comment} Lipids. 1990;25(10):639-45.
9 Hewson D C, Phillips M A, Simpson K E, Drury P, Crawford M A. Food intake in multiple sclerosis. Human-Nutrition:-Applied-Nutrition. 1984;38A:5. 355–367; 37 Ref. [pmid: 6706685].
10 Lauer K. The risk of multiple sclerosis in the U.S.A. in relation to sociogeographic features: a factor-analytic study. Journal of Clinical Epidemiology. 1994;47(1):43-8. [pmid: 8283194].
11 Lee L, Kang S A, Lee H O, et al. Relationships between dietary intake and cognitive function level in Korean elderly people. Public Health. 2001;115(2):133-8. [pmid: 11406779].
12 Martinez M. Docosahexaenoic acid therapy in docosahexaenoic acid-deficient patients with disorders of peroxisomal biogenesis. Lipids. 1996;31(supp):S145-S152. [pmid: 8729110].
13 Martinez M. Treatment with docosahexaenoic acid favorably modifies the fatty acid composition of erythrocytes in peroxisomal patients. Progress in Clinical & Biological Research. 1992;375:389-97. [pmid: 1438383].
14 Martinez M, Pineda M, Vidal R, Conill J, Martin B. Docosahexaenoic acid - A new therapeutic approach to peroxisomal-disorder patients: Experience with two cases. Neurology. 1993;43(7):1389-97. [pmid: 8327143].
15 Martinez M, Vazquez E. MRI evidence that docosahexaenoic acid ethyl ester improves myelination in generalized peroxisomal disorders. {comment} Neurology. 1998;51(1):26-32.
16 Peers. Alzheimer's disease and omega-3 fatty acids: Hypothesis (Comment II). Medical Journal of Australia. 1990;153(9):564.
17 Petroni A, Bertagnolio B, La Spada P, et al. The beta-oxidation of arachidonic acid and the synthesis of docosahexaenoic acid are selectively and consistently altered in skin fibroblasts from three Zellweger patients versus X-adrenoleukodystrophy, Alzheimer and control subjects. Neuroscience Letters. 1998;250(3):145-8. [pmid: 9708853].
18 Schlanger S, Shinitzky M, Yam D. Diet enriched with omega-3 fatty acids alleviates convulsion symptoms in epilepsy patients. Epilepsia. 2002;43(1):103-4. [pmid: 11879394].
19 Singh R B, Kartikey K, Moshiri M. Effect of omega Qgel<inf>T</inf> (coenzyme Q10 and fish oil) in a patient with tuberous sclerosis. Journal of Nutritional & Environmental Medicine. 2002;12(4):295-9.
20 Sovik O, Mansson J E, Bjorke Monsen A L, Jellum E, Berge R K. Generalized peroxisomal disorder in male twins: fatty acid composition of serum lipids and response to n-3 fatty acids. Journal of Inherited Metabolic Disease. 1998;21(6):662-70. [pmid: 9762602].
21 Suzuki Y, Shimozawa N, Imamura A, et al. Trial of docosahexaenoic acid supplementation on a Japanese patient with a peroxisome biogenesis defect. Acta Paediatrica Japonica. 1996;38(5):520-3. [pmid: 8942014].
22 Tein I, Vajsar J, MacMillan L, Sherwood W G. Long-chain L-3-hydroxyacyl-coenzyme A dehydrogenase deficiency neuropathy: response to cod liver oil. Neurology. 1999;52(3):640-3. [pmid: 10025805].
23 Tilvis R S, Erkinjuntti T, Sulkava R, Miettinen T A. Fatty acids of plasma lipids, red cells and platelets in Alzheimer's disease and vascular dementia. Atherosclerosis. 1987;65:3. 237–245; 37 Ref.

### Rejected Duplicate (n = 1)

1 Bates D, Cartlidge N, French J. Results of a trial of N-3 polyunsaturated fatty acids in the treatment of multiple sclerosis. Irish Journal of Medical Science. 1988;157(8):277.

### Rejected Not Omega-3 (n = 1)

1 Bates D, Fawcett P R W, Shaw D A, Weightman D. Polyunsaturated fatty acids in treatment of acute remitting multiple sclerosis. British-Medical-Journal. 1978;2(6149):1390-1. [pmid: 363236]. [pmcid: 1608620].

### Rejected No Difference in Omega-3 (n = 3)

1 Swank R L. Multiple sclerosis: fat-oil relationship. Nutrition. 1991;7(5):368-76. [pmid: 1804476].
2 Swank R L, Dugan B B. Effect of low saturated fat diet in early and late cases of multiple sclerosis. Lancet. 1990;336(8706):37-9. [pmid: 1973220].
3 Swank R L, Grimsgaard A. Multiple sclerosis: the lipid relationship. Am J Clin Nutr. 1988;48(6):1387-93. [pmid: 3202088].

### Rejected Cannot Ascertain Omega-3 Effect Across Arms (n = 6)

1 Engelhart M J, Geerlings M I, Ruitenberg A, et al. Diet and risk of dementia: Does fat matter?: The Rotterdam Study. Neurology. 2002;59(12):1915-21. [pmid: 12499483].
2 Fitzgerald G, Harbige L S, Forti A, Crawford M A. The effect of nutritional counselling on diet and plasma EFA status in multiple sclerosis patients over 3 years. Human-Nutrition:-Applied-Nutrition. 1987;41A:5. 297–310; 61 Ref.
3 Kyle DJ, Schaefer E, Patton G, Beiser A. Low serum docosahexaenoic acid is a significant risk factor for Alzheimer's dementia. Lipids 1999; Supplement, S245.
4 Morris M C, Evans D A, Bienias J L, et al. Dietary fats and the risk of incident Alzheimer disease. Archives of Neurology. 2003;60(2):194-200. [pmid: 12580703].
5 Requejo A M, Ortega R M, Robles F, Navia B, Faci M, Aparicio A. Influence of nutrition on cognitive function in a group of elderly, independently living people. European Journal of Clinical Nutrition. 2003;57(SUPPL. 1):S54-S57. [pmid: 12947454].
6 Yehuda S, Rabinovitz S, Carasso R L, Mostorfsky D I. Essential fatty acids preparation (SR-3) improves Alzhaimer's patients quality of life. Int J Neurosci. 1996;87(34):141-149. [pmid: 9003975].

### Rejected No Outcomes or Criteria of Interest (n = 44)

1 Brooksbank B W, Martinez M, Balazs R. Altered composition of polyunsaturated fatty acyl groups in phosphoglycerides of Down's syndrome fetal brain. Journal of Neurochemistry. 1985;44(3):869-74. [pmid: 3156210].
2 Conquer J A, Tierney M C, Zecevic J, Bettger W J, Fisher R H. Fatty acid analysis of blood plasma of patients with Alzheimer's disease, other types of dementia, and cognitive impairment. Lipids. 2000;35(12):1305-12. [pmid: 11201991].
3 Corrigan F M, Horrobin D F, Skinner E R, Besson J A O, Cooper M B. Abnormal content of n-6 and n-3 long-chain unsaturated fatty acids in the phosphoglycerides and cholesterol esters of parahippocampal cortex from Alzheimer's disease patients and its relationship to acetyl CoA content. International-Journal-of-Biochemistry-and-Cell-Biology. 1998;30(2):197-207. [pmid: 9608673].
4 Corrigan F M, Mowat B, Skinner E R, Van Rhijn A G, Cousland G. High density lipoprotein fatty acids in dementia. Prostaglandins Leukotrienes & Essential Fatty Acids. 1998;58(2):125-7.
5 Crawford M A, Budowski P, Hassam A G. Dietary management in multiple sclerosis. Proceedings of the Nutrition Society. 1979;38(3):373-89. [pmid: 531030].
6 Crawford M A, Stevens P. A study on essential fatty acids and multiple sclerosis. Progress in Lipid Research. 1981;20:255-8. [pmid: 7342090].
7 Cunnane S C, Ho S Y, Dore Duffy P, Ells K R, Horrobin D F. Essential fatty acid and lipid profiles in plasma and erythrocytes in patients with multiple sclerosis. American-Journal-of-Clinical-Nutrition. 1989;50(4):801-6. [pmid: 2801584].
8 Diboune M, Ferard G, Ingenbleek Y, et al. Composition of phospholipid fatty acids in red blood cell membranes of patients in intensive care units: effects of different intakes of soybean oil, medium-chain triglycerides, and black-currant seed oil. Jpen: Journal of Parenteral & Enteral Nutrition. 1992;16(2):136-41. [pmid: 1556808].
9 Doidge M J. Evaluation of a nutrition education programme for people with multiple sclerosis. Journal-of-Human-Nutrition-and-Dietetics. 1993;6(2):131-47.
10 Evans P, Dodd G. Erythrocyte fatty acids in multiple sclerosis. Acta Neurologica Scandinavica. 1989;80(6):501-3. [pmid: 2618575].
11 Gallai V, Sarchielli P, Trequattrini A, et al. Cytokine secretion and eicosanoid production in the peripheral blood mononuclear cells of MS patients undergoing dietary supplementation with n-3 polyunsaturated fatty acids. Journal of Neuroimmunology. 1995;56(2):143-53. [pmid: 7860710].
12 Gronn M, Christensen E, Hagve T A, Christophersen B O. The Zellweger syndrome: deficient conversion of docosahexaenoic acid (22:6(n-3)) to eicosapentaenoic acid (20:5(n-3)) and normal delta 4-desaturase activity in cultured skin fibroblasts. Biochimica Et Biophysica Acta. 1990;1044(2):249-54. [pmid: 2140517].
13 Hals J, Bjerve K S, Nilsen H, Svalastog A G, Ek J. Essential fatty acids in the nutrition of severely neurologically disabled children. British Journal of Nutrition. 2000;83(3):219-25. [pmid: 10884709].
14 Harbige L S, Jones R, Jenkins R, Fitzgerald G, Forti A, Budowski P. Nutritional management in multiple sclerosis with reference to experimental models. Ups J Med Sci Suppl. 1990;48:189-207. [pmid: 2077694].
15 Harel Z, Gascon G, Riggs S, Vaz R, Brown W, Exil G. Supplementation with omega-3 polyunsaturated fatty acids in the management of recurrent migraines in adolescents. Journal of Adolescent Health. 2002;31(2):154-61. [pmid: 12127385].
16 Holman R T, Johnson S B, Kokmen E. Deficiencies of polyunsaturated fatty acids and replacement by nonessential fatty acids in plasma lipids in multiple sclerosis. Proceedings of the National Academy of Sciences of the United States of America. 1989;86(12):4720-4. [pmid: 2734316]. [pmcid: 287343].
17 Karlsson I, Alling C, Svennerholm L. Major plasma lipids and their fatty acid composition in multiple sclerosis and other neurological diseases. Acta Neurologica Scandinavica. 1971;47(4):403-12. [pmid: 5123482].
18 Kohlschutter A, Schade B, Blomer B, Hubner C. Low erythrocyte plasmalogen and plasma docosahexaenoic acid (DHA) in juvenile neuronal ceroid-lipofuscinosis (JNCL). Journal of Inherited Metabolic Disease. 1993;16(2):299-304. [pmid: 8411986].
19 Manzato E, della Rovere G R, Zambon S, et al. Cognitive functions are not affected by dietary fatty acids in elderly subjects in the Pro.V.A. study population. Aging-Clinical & Experimental Research. 2003;15(1):83-6. [pmid: 12841423].
20 Martinez M. Abnormal profiles of polyunsaturated fatty acids in the brain, liver, kidney and retina of patients with peroxisomal disorders. Brain Research. 1992;583(12):171-82. [pmid: 1504825].
21 Martinez M. Polyunsaturated fatty acid changes suggesting a new enzymatic defect in Zellweger syndrome. Lipids. 1989;24(4):261-5. [pmid: 2755305].
22 Martinez M. Polyunsaturated fatty acids in the developing human brain, red cells and plasma: influence of nutrition and peroxisomal disease. World Review of Nutrition & Dietetics. 1994;75:70-8. [pmid: 7871835].
23 Martinez M. Restoring the DHA levels in the brains of Zellweger patients. Journal of Molecular Neuroscience. 2001;16(23):309-16. discussion 317–21. [pmid: 11478386].
24 Martinez M. Severe deficiency of docosahexaenoic acid in peroxisomal disorders: a defect of delta 4 desaturation?. Neurology. 1990;40(8):1292-8. [pmid: 2143272].
25 Martinez M, Mougan I. Fatty acid composition of brain glycerophospholipids in peroxisomal disorders. Lipids. 1999;34(7):733-40. [pmid: 10478932].
26 Martinez M, Mougan I, Roig M, Ballabriga A. Blood polyunsaturated fatty acids in patients with peroxisomal disorders. A multicenter study. Lipids. 1994;29(4):273-80. [pmid: 8177020].
27 Martinez M, Vazquez E, Garcia-Silva MT et al. {Spanish} Revista De Neurologia. 28 Suppl 1:S59–64, 1999 Jan.
28 Martinez M, Vazquez E, Teresa Garcia Silva M, et al. Therapeutic effects of docosahexaenoic acid ethyl ester in patients with generalized peroxisomal disorders. Highly Unsaturated Fatty Acids in Nutrition and Disease Prevention. Proceedings of an International Conference, Barcelona, Spain, 4–6 November 1996. American-Journal-of-Clinical-Nutrition. 2000;71(Supplement 1):376S-385S. 37 Ref. [pmid: 10618001].
29 Neu I. {German} Nervenarzt 1981; 52(2):100–7.
30 Nightingale S, Woo E, Smith A D, et al. Red blood cell and adipose tissue fatty acids in mild inactive multiple sclerosis. Acta Neurologica Scandinavica. 1990;82(1):43-50. [pmid: 2239137].
31 Nourooz-Zadeh J, Liu E H, Yhlen B, Anggard E E, Halliwell B. F4-isoprostanes as specific marker of docosahexaenoic acid peroxidation in Alzheimer's disease. Journal of Neurochemistry. 1999;72(2):734-40. [pmid: 9930747].
32 Orlowski G, Brand R, Pohlau D. Nutrient intake in patients with multiple sclerosis. Aktuelle-Ernahrungsmedizin. 1995;20:4. 207–214; 19 Ref.
33 Otsuka M. Analysis of dietary factors in Alzheimer's disease: clinical use of nutritional intervention for prevention and treatment of dementia. {Japanese} Nippon Ronen Igakkai Zasshi - Japanese Journal of Geriatrics. 2000;37(12):970-3.
34 Otsuka M, Yamaguchi K, Ueki A. Similarities and differences between Alzheimer's disease and vascular dementia from the viewpoint of nutrition. Annals of the New York Academy of Sciences. 2002;977:155-61. Nov. [pmid: 12480746].
35 Pilitsis J G, Coplin W M, O'Regan M H, et al. Free fatty acids in cerebrospinal fluids from patients with traumatic brain injury. Neuroscience Letters. 2003;349(2):136-8. [pmid: 12946571].
36 Pradalier A, Bakouche P, Baudesson G, et al. Failure of omega-3 polyunsaturated fatty acids in prevention of migraine: A double-blind study versus placebo. Cephalalgia. 2001;21(8):818-22. [pmid: 11737007].
37 Prasad M R, Lovell M A, Yatin M, Dhillon H, Markesbery W R. Regional membrane phospholipid alterations in Alzheimer's disease. Neurochemical Research. 1998;23(1):81-8. [pmid: 9482271].
38 Rosnowska M, Piesio B, Cendrowski W. Blood serum linoleic, linolenic and arachidonic acids in patients with multiple sclerosis. Acta Medica Polona. 1979;20(3):273-80. [pmid: 517165].
39 Tully A M, Roche H M, Doyle R, et al. Low serum cholesteryl ester-docosahexaenoic acid levels in Alzheimer's disease: a case-control study. British-Journal-of-Nutrition. 2003;89:4. 483–489; 44 Ref.
40 Vaddadi K S, Soosai E, Chiu E, Dingjan P. A randomised, placebo-controlled, double blind study of treatment of Huntington's disease with unsaturated fatty acids. Neuroreport. 2002;13(1):29-33. [pmid: 11924889].
41 Wagner W, Nootbaar-Wagner U. Prophylactic treatment of migraine with gamma-linolenic and alpha-linolenic acids. Cephalalgia. 1997;17(2):127-30. discussion 102. [pmid: 9137851].
42 Williams J H, O'Connell T C. Differential relations between cognition and 15N isotopic content of hair in elderly people with dementia and controls. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2002;57(12):M797-802.
43 Wilson R, Tocher D R. Lipid and fatty acid composition is altered in plaque tissue from multiple sclerosis brain compared with normal brain white matter. Lipids. 1991;26(1):9-15. [pmid: 2051890].
44 Yehuda S, Rabinovtz S, Carasso R L, Mostofsky D I. Essential fatty acids preparation (SR-3) improves Alzheimer's patients quality of life. Int J Neurosci. 1996;87(34):141-9. [pmid: 9003975].