# References and Included Studies

1 American Dietetic A, Dietitians of C. Position of the American Dietetic Association and Dietitians of Canada: vegetarian diets. Canadian Journal of Dietetic Practice & Research. 2003;64(2):62-81. [pmid: 12826028].
2 Newman V, Rock C L, Faerber S, Flatt S W, Wright F A, Pierce J P. Dietary supplement use by women at risk for breast cancer recurrence. The Women's Healthy Eating and Living Study Group. Journal of the American Dietetic Association. 1998;98(3):285-92. [pmid: 9508010].
3 Cade J, Thomas E, Vail A. Case-control study of breast cancer in south east England: nutritional factors. Journal of Epidemiology & Community Health. 1998;52(2):105-10. [pmid: 9578857].
4 Marcheselli V L, Hong S, Lukiw W J, et al. Novel docosanoids inhibit brain ischemia-reperfusion-mediated leukocyte infiltration and pro-inflammatory gene expression. J Biol Chem. 2003;278(44):43807-17. [pmid: 12923200].
5 Serhan C N, Hong S, Gronert K, et al. Resolvins: a family of bioactive products of omega-3 fatty acid transformation circuits initiated by aspirin treatment that counter proinflammation signals. J Exp Med. 2002;196(8):1025-37. [pmid: 12391014].
6 Hong S, Gronert K, Devchand P R, Moussignac R L, Serhan C N. Novel docosatrienes and 17S-resolvins generated from docosahexaenoic acid in murine brain, human blood, and glial cells. Autacoids in anti-inflammation. J Biol Chem. 2003;278(17):14677-87. [pmid: 12590139].
7 Niu S L, Mitchell D C, Lim S Y, et al. Reduced G protein-coupled signaling efficiency in retinal rod outer segments in response to n-3 fatty acid deficiency. J Biol Chem. 2004;279(30):31098-104. [pmid: 15145938].
8 White E, Shattuck A L, Kristal A R, et al. Maintenance of a low-fat diet: follow-up of the Women's Health Trial. Cancer Epidemiology, Biomarkers & Prevention. 1992;1(4):315-23.
9 Richardson A J. The importance of omega-3 fatty acids for behaviour, cognition and mood. Scandinavian Journal of Nutrition/Naringsforskning. 2003;47(2):92-8.
10 Lauritzen L, Hansen H S, Jorgensen M H, Michaelsen K F. The essentiality of long chain n-3 fatty acids in relation to development and function of the brain and retina. Progress in Lipid Research. 2001;40(12):1-94. [pmid: 11137568].
11 Yehuda S, Rabinovitz S, Mostofsky D I. Essential fatty acids are mediators of brain biochemistry and cognitive functions. Journal of Neuroscience Research. 1999;56(6):565-70. [pmid: 10374811].
12 Jones C, Arai T, Rapoport S. Evidence for the involvement of docosahexaenoic acid in cholinergic stimulated signal transduction at the synapse. Neurochem. Res. 1997;22:663-70. [pmid: 9178948].
13 Uauy R, Hoffman DR, Peirano P et-al. Essential fatty acids in visual and brain development. Symposium on PUFA in Maternal and Child Health, Kansas City, Missouri, USA, 10–13 September 2000 2001; 36(9):885–95.
14 Tapiero H, Nguyen Ba G, Couvreur P, Tew K D. Polyunsaturated fatty acids (PUFA) and eicosanoids in human health and pathologies. Biomedicine & Pharmacotherapy. 2002;56(5):215-22.
15 Bourre JM, Dumont O, Piciotti M et al. Essentiality of omega-3 fatty acids for brain structure and function. In: Simopoulos AP, Kifer RR, Martin RE, Barlow SM, eds. Health effects of omega-3 polyunsaturated fatty acids in seafoods. Vol. 66. Basel, Karger: World Rev Nutr Diet, 1991: 103–17.
16 Salem NJr, Litman B, Kim HY et al. Mechanisms of action of docosahexaenoic acid in the nervous system. Symposium on PUFA in Maternal and Child Health, Kansas City, Missouri, USA, 10–13 September 2000. Lipids. 2001, 36: 9, 945–959; 149 Ref.
17 Hashimoto M, Hossain S, Shimada T, et al. Docosahexaenoic acid provides protection from impairment of learning ability in Alzheimer's disease model rats. Journal of Neurochemistry. 2002;81(5):1084-91. [pmid: 12065621].
18 Favrelere S, Stadelmann-Ingrand S, Huguet F, et al. Age-related changes in ethanolamine glycerophospholipid fatty acid levels in rat frontal cortex and hippocampus. Neurobiol Aging. 2000;21:653-60. [pmid: 11016534].
19 Westerman M, Cooper-Blacketer D, Mariash A, et al. The relationship between Abeta and memory in the Tg2576 mouse model of Alzheimer's disease. J. Neurosci. 2002;22:1858-67. [pmid: 11880515].
20 Calon F, Lim G, Yang F, et al. Docosahexaenoic acid protects from dendritic pathology in an Alzheimer's disease mouse model. Neuron. 2004;43:633-45. [pmid: 15339646].
21 Barberger-Gateau P, Letenneur L, Deschamps V, Peres K, Dartigues J F, Renaud S. Fish, meat, and risk of dementia: cohort study. BMJ. 2002;325(7370):932-3. [pmid: 12399342]. [pmcid: 130057].
22 Cooper J L. Dietary lipids in the aetiology of Alzheimer's disease: implications for therapy. Drugs & Aging. 2003;20(6):399-418. [pmid: 12710861].
23 Morris M C, Evans D A, Bienias J L, et al. Consumption of fish and n-3 fatty acids and risk of incident Alzheimer disease. Archives of Neurology. 2003;60(7):940-6. [pmid: 12873849].
24 Terano T, Fujishiro S, Ban T, et al. Docosahexaenoic acid supplementation improves the moderately severe dementia from thrombotic cerebrovascular diseases. Lipids. 1994;34(supp):S345-S346. [pmid: 10419198].
25 Friedland R. Fish consumption and the risk of Alzheimer disease: is it time to make dietary recommendations?. Archives of Neurology. 2003;60(7):923-4. [pmid: 12873846].
26 Yehuda S, Rabinovtz S, Carasso R L, Mostofsky D I. Essential fatty acids preparation (SR-3) improves Alzheimer's patients quality of life. Int J Neurosci. 1996;87(34):141-9. [pmid: 9003975].
27 Martinez Regulez M. The importance of docosahexaenoic acid (DHA) on brain development in the normal child and in the patient with Zellweger's syndrome. Ciencia-Pediatrika. 2002;22(8):275-88.
28 Salem N, Edmond J, Kyle D, et al. Brain uptake and utilization of fatty acids: Applications to peroxisomal biogenesis disorders (An International Workshop): Roundtable discussion of session 2: Brain uptake, transport, and metabolism of PUFA: In vivo and in vitro studies. Journal of Molecular Neuroscience. 2001;16(23):215-21.
29 Martinez M. Restoring the DHA levels in the brains of Zellweger patients. Journal of Molecular Neuroscience. 2001;16(23):309-16. ; discussion 317–21. [pmid: 11478386].
30 Martinez M. Docosahexaenoic acid therapy in docosahexaenoic acid-deficient patients with disorders of peroxisomal biogenesis. Lipids. 1996;31(supp):S145-S152. [pmid: 8729110].
31 Martinez M. Polyunsaturated fatty acid changes suggesting a new enzymatic defect in Zellweger syndrome. Lipids. 1989;24(4):261-5. [pmid: 2755305].
32 Martinez M. Developmental profiles of polyunsaturated fatty acids in the brain of normal infants and patients with peroxisomal diseases: severe deficiency of docosahexaenoic acid in Zellweger's and pseudo-Zellweger's syndromes. World Review of Nutrition & Dietetics. 1991;66:87-102. [pmid: 1828923].
33 Logan A. Neurobehavioral aspects of omega-3 fatty acids: possible mechanisms and therapeutic value in major depression. Aternative Medicine Review. 2003;8:410-25.
34 Chen H, Zhang S M, Hernan M A, Willett W C, Ascherio A. Dietary intakes of fat and risk of Parkinson's disease. American Journal of Epidemiology. 2003;157(11):1007-14. [pmid: 12777364].
35 Logroscino G, Marder K, Cote L, Tang M X, Shea S, Mayeux R. Dietary lipids and antioxidants in Parkinson's disease: a population-based, case-control study. Ann Neurol. 1996;39(1):89-94. [pmid: 8572672].
36 Youdim K A, Martin A, Joseph J A. Essential fatty acids and the brain: possible health implications. International Journal of Developmental Neuroscience. 2000;18(45):383-99. [pmid: 10817922].
37 Bates G P, Hockly E. Experimental therapeutics in Huntington's disease: Are models useful for therapeutic trials?. Current Opinion in Neurology. 2003;16(4):465-70. [pmid: 12869804].
38 Lange H W. Huntington's disease: Clinical, diagnostic and therapeutic aspects. Psycho. 2002;28(9):479-86.
39 Puri B K, Bydder G M, Counsell S J, et al. MRI and neuropsychological improvement in Huntington disease following ethyl-EPA treatment. Neuroreport. 2002;13(1):123-6. [pmid: 11924873].
40 Bates D, Cartlidge N E, French J M, et al. A double-blind controlled trial of long chain n-3 polyunsaturated fatty acids in the treatment of multiple sclerosis. J Neurol Neurosurg Psychiatry. 1989;52(1):18-22. [pmid: 2540285].
41 Bates D, Fawcett P R W, Shaw D A, Weightman D. Polyunsaturated fatty acids in treatment of acute remitting multiple sclerosis. British-Medical-Journal. 1978;2(6149):1390-1. [pmid: 363236]. [pmcid: 1608620].
42 Doidge M J. Evaluation of a nutrition education programme for people with multiple sclerosis. Journal-of-Human-Nutrition-and-Dietetics. 1993;6(2):131-47.
43 Ghadirian P, Meera Jain, Ducic S, Shatenstein B, Morisset R, Jain M. Nutritional factors in the aetiology of multiple sclerosis: a case-control study in Montreal, Canada. International-Journal-of-Epidemiology. 1998;27(5):845-52. [pmid: 9839742].
44 Agranoff B W. Multiple sclerosis. Dietary fats and health. AOCS-Monograph. 1983;10:941-50.
45 Anonymous. Fatty acids and multiple sclerosis. Lancet 1967; 2(7518):708–9.
46 Anonymous. Lipids and multiple sclerosis. Lancet 1990; 336(8706):25–6.
47 Bates D, Cartlidge N, French J. Results of a trial of N-3 polyunsaturated fatty acids in the treatment of multiple sclerosis. Irish Journal of Medical Science. 1988;157(8):277.
48 Field E J. Polyunsaturated fatty acids in multiple sclerosis. British Medical Journal. 1979;1(6169):1016-7. [pmid: 435921].
49 Field E J, Joyce G. Clinical trials of unsaturated fatty acids in multiple sclerosis. IRCS Medical Science. 1981;9(12):1081.
50 Haag M. Essential fatty acids and the brain. Canadian Journal of Psychiatry - Revue Canadienne De Psychiatrie. 2003;48(3):195-203. [pmid: 12728744].
51 Bretler M. Vascular risk factors for Alzheimer's disease: an epidemiologic perspective. Neurobiology of Aging. 2000;21:153-60. [pmid: 10867200].
52 Kalmijn S. Fatty acid intake and the risk of dementia and cognitive decline: a review of clinical and epidemiological studies. Journal of Nutrition, Health & Aging. 2000;4(4):202-7.
53 Blok W, Katan M, Van der Meer J. Modulation of inflammation and cytokine production by dietary (n-3) fatty acids. Journal of Nutrition. 1996;126(6):1515-33. [pmid: 8648424].
54 Uauy R, Mena P, DeSantiago S, Arroya Ped, Gutierrez Robledo LMed, Loria A. Lipids and neurodevelopment. Third Nestle Nutrition Conference. Nutrition and Brain Function From Infancy to Old Age, Mexico City, Mexico, 30–31 March, 2000. Nutrition-Reviews. 2001;59(8):2.
55 San Giovanni J, Parra-Cabrera S, Colditz G, Berkey C, Dwyer J. Metaanalysis of dietary essential fatty acids and long-chain polyunsaturated fatty acids as they relate to visual resolution acuity in health preterm infants. Pediatrics. 2000;62:761-8.
56 Schatzkin A, Lanza E. Polyp Prevention Trial Study G. Polyps and vegetables (and fat, fibre): the polyp prevention trial. IARC Scientific Publications. 2002;156:463-6. [pmid: 12484235].
57 Downs S, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. 1998;52:377-84. [pmid: 9764259].
58 Saunders L, Soomro G, Buckingham J, Jamtvedt G, Raina P. Assessing the methodological quality of nonrandomized intervention studies. Western Journal of Nursing Research. 2003;25:223-37. [pmid: 12666645].
59 Kalmijn S, Feskens E J M, Launer L J, Kromhout D. Polyunsaturated fatty acids, antioxidants, and cognitive function in very old men. American-Journal-of-Epidemiology. 1997;145(1):33-41. [pmid: 8982020].
60 Petridou E, Koussouri M, Toupadaki N, et al. Diet during pregnancy and the risk of cerebral palsy. British Journal of Nutrition. 1998;79(5):407-12. [pmid: 9682658].
61 Zhang S M, Willett W C, Hernan M A, Olek M J, Ascherio A. Dietary fat in relation to risk of multiple sclerosis among two large cohorts of women. American Journal of Epidemiology. 2000;152(11):1056-64. [pmid: 11117615].
62 Cendrowski W. Multiple sclerosis and MaxEPA. British-Journal-of-Clinical-Practice. 1986;40(9):365-7. [pmid: 3542002].
63 Nordvik I, Myhr K M, Nyland H, Bjerve K S. Effect of dietary advice and n-3 supplementation in newly diagnosed MS patients. Acta-Neurologica-Scandinavica. 2000;102(3):143-9. [pmid: 10987373].
64 Swank R L. Multiple sclerosis: fat-oil relationship. Nutrition. 1991;7(5):368-76. [pmid: 1804476].
65 Swank R L, Dugan B B. Effect of low saturated fat diet in early and late cases of multiple sclerosis. Lancet. 1990;336(8706):37-9. [pmid: 1973220].
66 Swank R L, Grimsgaard A. Multiple sclerosis: the lipid relationship. Am J Clin Nutr. 1988;48(6):1387-93. [pmid: 3202088].
67 Kalmijn S, Launer L J, Ott A, Witteman J C M, Hofman A, Breteler M M B. Dietary fat intake and the risk of incident dementia in the Rotterdam study. Annals of Neurology. 1997;42(5):776-82. [pmid: 9392577].
68 Willet W. Overview of nutritional epidemiology. Nutritional Epidemiology. 2nd edition. New York: Oxford University Press, 1998: 3–17.
69 Grimes D, Schulz K. Cohort studies: marching towards outcomes. Lancet. 2002;359:341-5. [pmid: 11830217].
70 Grimes D, Schulz K. Bias and causal associations in observational research. Lancet. 2002;359:248-52. [pmid: 11812579].