# Acknowledgments

We thank Herbert D. Woolf of BASF Corporation for providing us with unpublished data on omega-3 fatty acids. We thank Di Valentine for providing translation of Italian studies, Takahiro Higashi for providing translation of Japanese studies, Matthius Schonlau for providing translation of German studies, and Grazyna Besser for providing translation of Polish studies.

Chapter 1 was written in collaboration with the New England Medical Center Evidence-based Practice Center.