# Discussion

## Overview

We screened 5,868 titles, from which we reviewed 500 full-text articles. Among these, 62 articles met our inclusion criteria for further review. Fifty were rejected and 12 met our inclusion criteria and were reviewed further for data abstraction. Among these, two articles were randomized controlled trials, six articles were prospective cohort studies, two articles were case-controls, and two were one-arm open label trials.

## Main Findings

### Effects of omega-3 fatty acids

Cognitive function in normal aging. In a single prospective cohort study^59^ that evaluated the effects of omega-3 fatty acid on cognitive function in normal aging, there was no significant association between omega-3 FA intake in the form of fish consumption and cognitive decline.

Incidence of dementia. Among three prospective cohort studies^21,^ ^23,^ ^67^ that assessed the effects of omega-3 FA on the incidence of dementia, fish consumption was associated with a statistically and clinically significant reduction in the incidence of non-Alzheimer's dementia in all three.^67^ Fish consumption was associated with a reduced risk of Alzheimer's dementia in all three of the studies; the association was statistically significant in one^67^ and nearly so in the other two^21,^ ^23^ (Table 3.2). Total omega-3 FA consumption and consumption of DHA were associated with a significant reduction in the incidence of Alzheimer's disease for the general population; consumption of ALA and EPA were not.^23^ Among individuals who were APOE-4 positive, ALA was associated with a reduced risk.

Treatment of dementia. One RCT^24^ assessed omega-3 fatty acids as a treatment for dementia. This study demonstrated statistically significant improvements on both Hasegawa's Dementia rating scale and the MMSE scores with omega-3 supplementation. However, the sample size was small and the methodologic quality was poor.

Incidence of neurological diseases. We identified four studies that assessed the association of omega-3 FA consumption with risk or incidence of particular neurological diseases other than dementia: two assessed the incidence of MS,^43,^ ^61^ one assessed the risk of Parkinson's disease,^34^ and one assessed the risk of cerebral palsy.^60^ Overall, there was no significant association between omega-3 FA and the incidence of MS in either a study that pooled data across two cohort studies^61^ or in a case-control study.^43^ However, the case-control study did demonstrate a reduced risk of MS with fish consumption, but only among women. A single observational cohort study^34^ found that ALA was associated with a reduced risk of Parkinson's disease when comparing highest and lowest quintile of intake in a pooled analysis of men and women; among women, but not men, there was a trend for risk reduction. There was no significant association between dietary intake of other omega-3 FAs and Parkinson's disease. A single case-control study^60^ found a reduced risk of cerebral palsy in offspring of women who consumed fish at least once a week throughout pregnancy, relative to women who did not.

Progression of multiple sclerosis. We identified one RCT^40^ and two single arm, open-label clinical trials^62,^ ^63^ that assessed the effect of omega-3 fatty acids on the progression of MS.^63–66^ There were no significant differences in disability or relapse rates between the treatment and placebo groups in the RCT.^40^ The one-arm open label trials both reported a significant reduction on the Expanded Disability Status Scale (EDSS) after treatment with the omega-3 supplement; one also reported improvement on an index of disease progression.^62^

Dose, source, duration effects and sustainment of effect. Data were insufficient to draw conclusions about source or duration effects or about sustainment of effect.

Quality and applicability. The quality of the clinical trials was generally poor. Among the two RCTs that met our inclusion criteria, one^33^ was of good quality with an overall summary quality of B (Jadad score 3, no concealment of allocation), and the other^24^ was of poor quality with an overall summary quality of C (Jadad score1, no concealment of allocation). The two open-label one-arm trials^62,^ ^63^ were both of poor methodologic quality: there was no comparison group or blinding; additionally there was no description of withdrawals or dropouts. The applicability ratings for all four of these clinical trials were II, meaning that the study populations were representative of a subgroup of the general population; these subjects had either MS or dementia.

The quality of the eight observational studies was generally good. Among these six prospective observational cohort and two case-control studies, all eight adjusted for confounders, reported using valid methods to ascertain outcomes, and confirmed that the exposure occurred prior to the outcome. The methods used to enroll subjects in one study would be expected to introduce selection bias.^60^ All but one study described withdrawals and dropouts^34^ or a valid method to ascertain dietary intake^21^ (method used was not described). Only three of the studies explicitly described whether the investigators were blinded to information on exposure when obtaining data on outcome or on outcome when obtaining data on exposure.^23,^ ^34,^ ^61^ For the two case-control studies, we also assessed whether the case and control groups were comparable, and they were in both studies.^43,^ ^60^ The applicability ratings were I (representative of the US population) for one study^23^ and II for all other studies. The studies with applicability ratings of II either had subjects that were part of a subpopulation^34,^ ^43,^ ^60,^ ^61^ and/ or were population-based, but the populations were not from the United States.^21,^ ^59,^ ^67^

## Limitations

It is important to point out that a major limitation of studies of omega-3 FA and disease is the lack of standardized methods to measure nutrient intakes.^68^ Thus, it is possible to overestimate or underestimate true associations with outcomes, because of errors in measurement of nutrients.

Furthermore, the studies we reviewed lacked a uniform or consistent approach to quantifying the type of omega-3 FA. For example, some measured nutrient intake from food frequency questionnaires without reporting type of fish or method of preparation; other studies defined omega-3 fatty acid supplements. This issue will increasingly become important in the design of future studies of omega-3 fatty acids and disease.

Another major limitation with respect to studies relating omega-3 FA interventions to dementia, particularly Alzheimer's disease, is that the majority of studies have been done in subjects aged 60 and older. Since the length of the latency period for AD is unknown and may precede the presentation of any symptoms by several decades, the potential effect of implementing dietary interventions aimed at prevention at an advanced age may be limited. Furthermore, in studies that assessed the effects of omega-3 fatty acids on cognitive function in normal aging or dementia, standard measures often are not used or the instruments used to assess cognitive function lack uniformity.

It is also important to note that in observational studies, it is not possible to control exposure,^69^ which can lead to confounding.^70^

An additional limitation is the possibility of publication bias. For large observational studies, this issue is slightly different than that observed for randomized trials. Publication bias for the latter generally means that no results of the trial are published at all. For the former, which are the main source of evidence for this report, findings may be published, but only for outcomes that achieve statistical significance, with no regard for whether such outcomes were secondary in nature. Results for primary outcomes may not be published. We must interpret our findings in light of such possible publication bias.

It is possible that additional information that would change our conclusions is available in reports that we were unable to locate or for which we were unable to find a translator. However, among 505 requested articles, only five were not found, and we were able to screen all 500 articles retrieved.

## Conclusions

For each of the conditions assessed in this report, conclusions can be drawn from a few studies on the effects of Omega-3 FA. Additionally, the strength of evidence for effects of omega-3 FA on outcomes in the conditions assessed varies greatly. The evidence suggests a possible association between omega- 3 FA and reduced risk of dementia. However, due to the small number of studies that inform this topic, further research is necessary before a strong conclusion can be drawn. Data are insufficient to draw conclusions about the effects of omega-3 FA on incidence of Parkinson's disease, cerebral palsy, or MS. In addition, the evidence regarding the progression of MS is inconsistent and inconclusive. There was insufficient evidence in the studies that met our systematic inclusion criteria to draw any substantive conclusions on omega-3 fatty acid intake. The paucity of evidence in this area suggests that further epidemiological and clinical research remains to be done before any conclusions can be drawn or policy recommendations can be made in this area.

## Future Research

We offer the following observations and recommendations regarding future research on the effects of omega-3 FA on the various neurological conditions reviewed.

1. Additional research on the effects of omega-3 FA needs to be performed on all of the conditions reviewed in this report before recommendations regarding the use of omega-3 FA can be made for these conditions.
2. Of particular importance, properly designed randomized clinical trials that are sufficiently powered and of an adequate length (e.g. three to five years of follow-up) need to be conducted for dementia, especially Alzheimer's disease, as distinct from vascular dementia.
3. Given the concern described above regarding the possible difficulty of conducting valid studies on dementia, due to a lengthy presymptomatic latency period, it would be of interest to conduct intervention clinical trials of omega-3 fatty acids in middle-aged adults as well as in populations of cognitively-impaired adults prior to a dementia diagnosis, such as individuals with various sub-types of mild cognitive impairment (MCI).
4. Properly designed randomized clinical trials that are sufficiently powered and of an adequate length (e.g. three to five years of follow-up) need to be conducted for multiple sclerosis.
5. Studies should address the effects of different types of omega-3 fatty acids (i.e. DHA, EPA, ALA, and total omega-3 FA) as well as the ratio of omega-3 to omega-6 FA.
6. Studies that assess the effects of omega-3 FA should be designed to evaluate the effect of source, dose, treatment duration, and the sustainment of effect after discontinuation of omega-3 FA consumption.
7. Trials of omega-3 FA should include a baseline assessment of dietary omega-3 and omega-6 FA intake.
8. In controlled trials that assess the effects of omega-3 FA, analysis should include and report explicit testing of the effects of the omega-3 FA relative to the control substance.
9. All studies that assess the effects of omega-3 FA should use standard validated instruments to assess clinical outcomes.
10. Studies that investigate the effects of omega-3 FA on cognition should include repeated measures of cognitive function using standard validated instruments to evaluate within-person cognitive change.
11. All studies that assess the effects of omega-3 FA should use standard validated dietary assessment instruments to assess nutritional intake.
12. Observational studies should report data about type of fish consumed and method of preparation.
13. Observational studies focused on repeated measures of diet for long-term intake, and sub-group analysis among persons with cardiovascular conditions (including history of stroke or myocardial infarction) also need to be performed in order to determine whether change in diet among these sub-groups results is confounding.