# Results

## Results of Literature Search

Figure 3.1 displays the flow of the literature review. The University of Ottawa EPC e-mailed us 5,848 citations as a result of their computerized library searches, our reviewers found 17 additional citations as a result of reference mining, and peer reviewers suggested three citations not identified by these sources for a total of 5,868 citations. Our two reviewers considered 505 of these article titles to be relevant to our research topics. We were able to retrieve 500 (99%) of these articles.

Figure 3.1 Literature Flow

Of the 500 articles retrieved, 438 were rejected (Figure 3.1). We identified 62 studies that passed the preliminary screening criteria and went on to the QRF stage. At this stage of review, we further excluded studies from our final analysis set based on study design and whether the study assessed effects of omega-3 fatty acids on topics relevant to this report, i.e. the incidence and treatment of dementia, cognitive decline with normal aging, the incidence of other neurological diseases, and the progression of MS. Among the 62 studies reviewed with a QRF, 50 were rejected. Among the rejected studies, six had no difference in omega-3 fatty acid content among study arms. The other 44 articles that were rejected did not describe a condition, population, or outcome that was relevant to this report. The remaining 12 articles met our inclusion criteria and are described in detail in this report.

## Effects of Omega-3 Fatty Acids

Summaries of all evaluated neurological studies can be found in Appendix C (Tables C.1 through C.4).

### Cognitive Function in Normal Aging

Overall effect. We identified one study that evaluated the effect of omega-3 FA on cognitive function in community-dwelling elderly persons. This study^59^ investigated the association between omega-3 FA and cognitive function in a cohort of 818 community-dwelling men (ranging in age from 64 to 84 years old) living in the Dutch town of Zutphen, who were participants in the Zutphen Elderly Study, a longitudinal study on risk factors for various chronic diseases. Data about dietary intake were collected by trained interviewers in 1985, 1990, and 1993, and data about cognitive function were collected in 1990 and 1993. Complete dietary information was collected on 476 men, and complete information regarding cognitive function was collected on 342 men. The relationship between both fish consumption and total omega-3 fatty acid consumption and both cognitive impairment and cognitive decline were assessed. Cognitive impairment was defined as a MMSE score ≤ 25; cognitive decline was defined as a drop of more than two points in the MMSE over a 3-year period, which corresponds to the 15^th^ percentile of change. Compared with no fish consumption, fish consumption was inversely associated with cognitive impairment in crude analyses, but not after adjustment for multiple variables (Table 3.1). Fish consumption was also inversely associated with development of cognitive decline, though not significantly so (Table 3.1). Total omega-3 fatty acid consumption was not related to cognitive impairment or cognitive decline (Table 3.1).

Table 3.1 Risk of cognitive impairment or decline in normal aging reported in a cohort study with consumption of omega-3 fatty acids, by categorization of omega-3 fatty acid intake.*

Author, Year | Outcome | Study arm (quartile, quintile or dose group) | n | Amount | Estimates of effect
Cohort | | | | | Age-adjusted OR (95% CI) | | Multivariable RR (95% CI) | | Multivariable Adjustors
Fish
Kalmijn, 1997^59^ | Cognitive impairment | None | NR | none | 1.0 | | 1.0 | | Age, education, cigarette smoking, alcohol consumption, energy intake, baseline MMSE score.
Zutphen Elderly Study | | High | NR | > 0–20 g/day | 0.43 | (0.23–0.78) | 0.63 | (0.33–1.21)
| | Total 476 | | | | p = 0.004‡ | | p = 0.13‡
| Cognitive decline | None | NR | none | NR | | 1.0
| | High | NR | > 0–20 g/day | NR | | 0.45 | (0.17–1.16)
| | Total 342 | | | | | | p = 0.09‡
Omega-3 fatty acids†
Kalmijn, 1997^59^ | Cognitive impairment | Low | NR | 0–37.5 mg/day | 1.00 | | NR | | Age, education, cigarette smoking, alcohol consumption, energy intake, baseline MMSE score.
Zutphen Elderly Study | | Medium | NR | 37.5–155.5 mg/day | 1.09 | (0.65–1.80) | NR
| | High | NR | 155.5–2,110.5 mg/d | 0.96 | (0.57–1.62) | NR
| | Total 476 | | | | p = 0.9‡
| Cognitive decline | Low | NR | 0–37.5 mg/day | 1.00 | NR | NR
| | Medium | NR | 37.5–155.5 mg/day | 0.85 | (0.40–1.82) | NR
| | High | NR | 155.5–2,110.5 mg/d | 0.78 | (0.35–1.73) | NR
| | Total 342 | | | | p=0.5

* NR= not reported;

† EPA and DHA;

‡ test for trend.

Sub-populations. This study did not evaluate the differential effects of omega-3 FA on distinct subpopulations.

Covariates. Although analyses adjusted for a number of different covariates in a multivariable regression model (Table 3.1), the effects of specific covariates on the association between omega-3 fatty acid consumption and cognitive function were not described.

#### Effects of source, dose, and exposure duration

Source: This study assessed omega-3 fatty acid effects in terms of fish consumption and total omega-3 fatty acid consumption. Fish consumption was associated with a reduced risk of cognitive impairment but had no association with cognitive decline; omega-3 fatty acid consumption was not associated with either outcome.

Dose: Dose effect was not assessed for fish. A dose effect was observed for omega-3 fatty acid consumption and cognitive impairment on unadjusted analyses (p for trend = 0.9), but not on adjusted analyses. No dose effect was found with omega-3 fatty acid consumption and cognitive decline.

Exposure Duration: Effects of exposure duration were not assessed.

Sustainment of Effect. Sustainment of effect was not reported.

Quality and Applicability. Parameters of methodologic quality are as follows:

This study adjusted for confounders, had valid ascertainment of exposures and outcomes, ascertained that exposure occurred before outcome measurement, and described withdrawals and drop outs. It did not blind to exposure/outcome and did not describe selection bias.

This study had an applicability rating of II because the population sampled included only males. Thus, although this study represented a relevant sub-group of the target population, it was not representative of the entire target population because of its exclusive sampling of one gender.

### Incidence of Dementia

Overall effect. We identified three prospective cohort studies^21,^ ^23,^ ^67^ that evaluated the effect of omega-3 FA on the incidence of dementia (Table 3.2). All three of the studies assessed the incidence of dementia relative to fish consumption; one also assessed risk relative to total omega-3 fatty consumption and relative to consumption of ALA, EPA, and DHA, individually.^23^ Fish intake was associated with a significant reduction in the incidence of non-Alzheimer's dementia in all three studies,^21,^ ^67^ although in one,^21^ statistical significance was barely lost with multivariable adjustment^21^ (Table 3.2). Fish consumption was associated with a reduced risk of Alzheimer's dementia in all three of the studies; the association was statistically significant in one^67^ and nearly so in the other two^21,^ ^23^ (Table 3.2). Total omega-3 fatty acid consumption and consumption of DHA were associated with a significant reduction in the incidence of Alzheimer's disease; consumption of ALA and EPA were not^23^ (Table 3.2).

Table 3.2 Risk of dementia reported in prospective cohort studies for different categories of consumption of omega-3 fatty acids, by category of consumption.*

Author, Year | Type of dementia | Study arm (quartile, quintile or dose group) | Total n | No. of Cases | Amount by category | Estimates of effect
Cohort | | | | | | Age adjusted RR (95% CI) | | Multivariable adjusted RR (95% CI) | | Multivariable Adjustors
FISH
Barberger-Gateau, 2002^21^ | Dementia | 1 | NR | NR | NR | 1.0 | | 1.0 | | Age, sex, education
PAQUID (Personnes Agées QUID) Study | | 2 | 1122 | 124 | At least once a week | 0.66† | (0.47–0.93) | 0.73† | (0.52–1.03)
| Alzheimer's disease | 1 | NR | NR | NR | 1.0 | | NR
| | 2 | 1122 | 99 | At least once a week | 0.69† | (0.47–1.01) | NR
| | Total 1122 | | 223
Kalmijn, 1997^67^ | Total dementia | 1 | 1807 | 58 | ≤ 3 g/day | NR | | 1.0 | | Age, sex, education, total energy intake.
Rotterdam Study | | 2 | 1773 | 58 | 3.0–18.5 g/day | NR | | 0.8 | (0.4–1.4)
| | 3 | 1806 | 58 | > 18.5 g/day | NR | | 0.4 | (0.2–0.9)
| | | | 58 | | | | | p = 0.03‡
| Alzheimer's disease without vascular component | 1 | 1807 | 37 | ≤ 3 g/day | NR | | 1.0
| | 2 | 1773 | 37 | 3.0–18.5 g/day | NR | | 0.9 | (0.4–1.8)
| | 3 | 1806 | 37 | > 18.5 g/day | NR | | 0.3 | (0.1–0.9)
| | | | 37 | | | | | p = 0.005‡
| Dementia with a vascular component | 1 | 1807 | 12 | ≤ 3 g/day | NR | | 1.0
| | 2 | 1773 | 12 | 3.0–18.5 g/day | NR | | 0.6 | (0.2–2.5)
| | 3 | 1806 | 12 | > 18.5 g/day | NR | | 0.7 | (0.2–2.8)
| | Total 5386 | | 12 | | | | | p = 0.39‡
Morris, 2003^23^ | Alzheimer's disease | 1 | 121 | 32 | never | 1.0 | | 1.0 | | Age, sex, race, education, vitamin E intake, other fat intake, cardiovascular disease, APO-ε 4 status.
Chicago Health and Aging Project | | 2 | 250 | 39 | 1–3 servings/ month | 0.7 | (0.3–1.6) | 0.6 | (0.3–1.3)
| | 3 | 296 | 43 | 1 serving/ week | 0.5 | (0.2–1.0) | 0.4 | (0.2–0.9)
| | 4 | 148 | 26 | ≥ 2 servings/week | 0.6 | (0.2–0.9) | 0.4 | (0.2–0.9)
| | Total 815 | | 140 | | | p = 0.18‡ | | p = 0.07‡
Omega-3 fatty acids
Morris, 2003^23^ | Alzheimer's disease | 1 | NR | 32 | 0.9 g/day | 1.0 | | 1.0 | | Age, sex, race, education, vitamin E intake, other fat intake, cardiovascular disease, APO-ε 4 status.
Chicago Health and Aging Project | | 2 | NR | 30 | 1.13 g/day | 1.1 | (0.4–2.9) | 1.2 | (0.5–3.0)
| | 3 | NR | 22 | 1.30 g/day | 0.5 | (0.2–1.4) | 0.6 | (0.2–1.7)
| | 4 | NR | 24 | 1.49 g/day | 0.6 | (0.2–1.5) | 0.7 | (0.3–1.6)
| | 5 | NR | 23 | 1.75 g/day | 0.3 | (0.1–0.7) | 0.4 | (0.1–0.9)
| | Total 815 | | 131 | | | p = 0.01‡ | | p = 0.01‡
ALA
Morris, 2003^23^ | Alzheimer's disease | 1 | NR | 26 | 0.72 g/day | 1.0 | | 1.0 | | Age, sex, race, education, vitamin E intake, other fat intake, cardiovascular disease, APO-ε 4 status.
Chicago Health and Aging Project | | 2 | NR | 33 | 0.92g/day | 1.7 | (0.7–3.8) | 1.8 | (0.8–3.8)
| | 3 | NR | 24 | 1.06g/day | 0.8 | (0.4–1.9) | 0.8 | (0.4–2.0)
| | 4 | NR | 25 | 1.23g/day | 0.8 | (0.4–1.7) | 0.9 | (0.4–2.0)
| | 5 | NR | 23 | 1.46g/day | 0.5 | (0.2–1.1) | 0.7 | (0.3–1.6)
| | Total 815 | | 131 | | | p = 0.01‡ | | p = 0.10‡
DHA
Morris, 2003 ^23^ | Alzheimer's disease | 1 | NR | 28 | 0.03 g/day | 1.0 | | 1.0 | | Age, sex, race, education, vitamin E intake, other fat intake, cardiovascular disease, APO-ε 4 status.
Chicago Health and Aging Project | | 2 | NR | 45 | 0.05 g/day | 0.8 | (0.3–2.1) | 0.8 | (0.3–2.1)
| | 3 | NR | 14 | 0.06 g/day | 0.4 | (0.1–1.1) | 0.4 | (0.1–1.0)
| | 4 | NR | 19 | 0.07 g/day | 0.3 | (0.1–0.9) | 0.2 | (0.1–0.8)
| | 5 | NR | 25 | 0.10 g/day | 0.4 | (0.2–1.1) | 0.3 | (0.1–0.9)
| | Total 815 | | 131 | | | p = 0.05‡ | | p = 0.02‡
EPA
Morris, 2003 ^23^ | Alzheimer's disease | 1 | NR | 55 | 0.0 g/day | 1.0 | | 1.0 | | Age, sex, race, education, vitamin E intake, other fat intake, cardiovascular disease, APO-ε 4 status.
Chicago Health and Aging Project | | 2 | NR | NR§ | 0.0 g/day | NR§ | NR§ | NR§ | NR§
| | 3 | NR | 35 | 0.01 g/day | 1.0 | (0.4–2.4) | 1.1 | (0.4–2.8)
| | 4 | NR | 14 | 0.02 g/day | 0.5 | (0.2–1.2) | 0.5 | (0.2–1.2)
| | 5 | NR | 27 | 0.03 g/day | 0.9 | (0.4–2.1) | 0.9 | (0.4–2.3)
| | Total 815 | | 131 | | | p = 0.40‡ | | p = 0.40‡

* NR = not reported, g = grams;

† hazard ratio;

‡ age and sex adjusted; test for trend;

§ Authors report that 40% of participants had 0 g/day of intake.

Sub-populations. One study assessed whether gender modified the effect of total omega-3 fatty acid consumption or consumption of fish, ALA, EPA, or DHA.^23^ Total intake of omega-3 fatty acids was protective in females only (p for interaction= 0.02); gender did not modify the effect of fish, ALA, EPA, or DHA.

Covariates. Two of the studies^23,^ ^67^ assessed the influence of covariates on the effect of omega-3 FA on incidence of dementia.

In one study,^23^ the multivariable relative risks for intakes of total omega-3 fatty acids, DHA, and EPA did not change when adjusted for vitamin E intake, other fat intake, and cardiovascular disease. In the same study, multivariable risks for intake of ALA were reported as approximately 1.0 with adjustment for vitamin E but not affected by adjustment for cardiovascular disease; intake of ALA was strongly protective among people with the APO-E-4 genotype (RR = 0.08 per natural log {milligram} increase in ALA, p = 0.02).

In the other study,^67^ estimates of relative risk did not change with adjustment for cigarette smoking, alcohol consumption, fiber consumption, antioxidant intake, stroke, myocardial infarction, or serum total and high-density lipoprotein cholesterol.

#### Effects of source, dose, and exposure duration

Source: Fish consumption was associated with a significantly reduced risk of dementia in three of the studies.^21^ In the one study that assessed the effect of total omega-3 fat consumption, ALA, DHA, and EPA on the incidence of dementia, total omega-3 and DHA were associated with significant reduced risk in multivariable analyses; ALA and EPA were not.

Dose: Dose effects were observed for fish in one study^67^ and for total omega-3 consumption and DHA in another^23^ (p for trend <0.05 for each) (Table 3.2).

Exposure Duration: None of the studies addressed exposure duration.

Sustainment of effect. Sustainment of effect was not assessed in any of the studies.

Quality and applicability. Among these three studies, all adjusted for confounders, reported using valid methods to ascertain outcomes, and confirmed that the exposure occurred prior to the outcome.

One study did not describe a valid method to ascertain dietary intake^21^ (method used was not described). One of the studies explicitly described whether the investigators were blinded to information on exposure when obtaining data on outcome or on outcome when obtaining data on exposure.^23,^ ^34,^ ^61^

Of the three studies, two^23,^ ^67^ had an applicability rating of I (applicable to the general target population of adults). One study received an applicability rating of II because it was performed in France.^21^

### Treatment of Dementia

Overall effect. We identified one study^24^ that assessed the efficacy of omega-3 FA as a treatment for dementia. This RCT assessed the effect of supplementation with DHA on cognitive function among 20 elderly nursing home residents with vascular dementia. Cognitive functioning was evaluated using Hasegawa's Dementia rating scale (HDS-R) and MMSE scores at baseline, and after 3, 6, and 12 months. Baseline Hasegawa's Dementia rating scale and MMSE scores were 15 to 22, consistent with mild to moderate dementia. HDS-R and MMSE scores improved in the DHA-treated group but not among patients who were not treated with DHA (Table 3.3). Comparisons between groups were significant at 3 and 6 months for the HDS-R and at 6 months for the MMSE.

Table 3.3 The effect of omega-3 fatty acids on the treatment of dementia in one randomized controlled trial stratified by outcome.*

Author, Year | Results
Terano, 1994^24^ | Total n | Before | After 3 months | After 6 months | After 12 months
Mean scores of HDS-R
Standard nursing home diet | 10 | 16.3 | 16.7 | 16.7 | 15.3
Standard nursing home diet PLUS DHA 4.3 grams/day | 10 | 17.2 | 20.6† | 19.9† | 20.2
Mean scores of MMSE
Standard nursing home diet | 10 | 19.7 | 19.4 | 19.6† | 19.1
Standard nursing home diet PLUS DHA 4.3 grams/day | 10 | 20.1 | 21.3 | 22.2 | 21.9

* HDS-R = Hasegawa's Dementia rating scale;

MMSE = Mini Mental Status Exam;

† p < 0.05 for comparisons between groups with paired t-test.

Sub-populations. The study did not evaluate the differential effects of omega-3 FA on distinct subpopulations.

Covariates. The study did not evaluate covariates.

#### Effects of source, dose, and exposure duration

Source: The source assessed was DHA.

Dose: A single dose of 4.3 g of DHA was administered; dose effect was not assessed.

Exposure Duration: The duration of exposure was 12 months. Significant differences between study groups were observed after 3 months and after 6 months, but not after 12 months.

Sustainment of effect. Sustainment of effect was not assessed in either report.

Quality and applicability. Although this trial is described as randomized, the randomization is not described as double-blind, and there is no description regarding blinding or withdrawals/dropouts. The study^24^ had an applicability rating of II with a summary quality score of C (Jadad score = 1; concealment of allocation was not reported); thus it can be considered of poor quality (Table 3.4).

Table 3.4 Relationship between methodologic quality and applicability for estimates of effect of omega-3 fatty acid consumption on treatment of dementia in randomized controlled trials (RCTs)

| | Methodologic Quality
Applicability | | A | B | C
| I
| II | | | Terano^24^
| III

### Incidence of Neurological Diseases

Overall effect. We identified four studies^34,^ ^43,^ ^60,^ ^61^ that specifically addressed the association of omega-3 FA consumption with risk or incidence of particular neurological diseases other than dementia: two assessed the incidence of MS,^43,^ ^61^ one assessed the risk of Parkinson's disease,^34^ and one assessed the risk of cerebral palsy^60^ (Table 3.6).

Table 3.6 Risk of neurological diseases reported in prospective cohort or case-control studies for different categories of consumption of fish, by disease.*

Disease | Author, Year | | Study arm (quartile; quintile; dose group; case or control) | n† | Amount | Estimates of effect
| Study Design | | | | | Multivariable adjusted RR (95% CI) | | Multivariable Adjustors,
| | | | | | | | Matching parameters
Fish
Multiple sclerosis | Zhang, 2000^61^ | | Dose Groups | | | | | Multivariable adjustors: Age, smoking (cigarettes/day), energy intake (quintiles), alcohol consumption
| Cohort Study: The Nurses' Health Study I and II | | 1 | 81 | < 1/week | 1.0 | | Matching: NA
| | | 2 | 77 | 1–2.9/week | 1.0 | (0.8–1.4)
| | | 3 | 37 | 3–4.9/week | 0.9 | (0.6–1.3)
| | | | | | | | | p = 0.79‡
Multiple sclerosis | Ghadirian, 1998,^43^ | Men | Control | 64 | - | 1.0 | | Multivariable adjustors: Total energy, body mass index
| Case control study | | Case | 61 | - | 1.08§ | (0.84–1.40) | Matching: Age, sex, phone number
| | Women | Control | 138 | - | 1.0
| | | Case | 136 | - | 0.83§ | (0.69–1.00)
| | All | Control | 202 | - | 1.0
| | | Case | 197 | - | 0.91§ | (0.78–1.05)
Cerebral palsy | Petridou, 1998,^60^ | | Control | 166 | 1/week | 1.0 | | Multivariable adjustors: ‘Core’ variables\|\| plus total energy intake, body mass index
| Case control study | | Case | 58 | 1/week | 0.63 | (0.37–1.08) | Matching: Age, neighborhood or age, physician
Omega-3 fat from fish
Parkinson's Disease | Chen, 2003^34^ | Men | Quintiles | | | | | Multivariable adjustors: Age, smoking (cigarettes/day), energy intake (quintiles), alcohol consumption
| Cohort Study: Health Professional Follow-up Study and The Nurses' Health Study | | 1 | NR | 0.03 % of energy | 1.0 | | Matching: NA
| | | 2 | NR | 0.07% of energy | 0.84 | (0.52–1.37)
| | | 3 | NR | 0.1% of energy | 1.08 | (0.69–1.69)
| | | 4 | NR | 0.2% of energy | 0.88 | (0.55–1.40)
| | | 5 | NR | 0.3 % of energy | 0.99 | (0.63–1.55)
| | | Total 47,331 | | p = 0.9‡
| | Women | Quintiles
| | | 1 | NR | 0.03 % of | 1.0
| | | 2 | NR | 0.05 % of energy | 0.70 | (0.41–1.19)
| | | 3 | NR | 0.08 % of energy | 0.76 | (0.45–1.29)
| | | 4 | NR | 0.1% of energy | 0.75 | (0.45–1.26)
| | | 5 | NR | 0.2 % of energy | 0.90 | (0.55–1.47)
| | | Total 88,653 | | | | p = 0.9‡
| | Pooled men and women | Quintiles
| | | 1 | NR | NR | 1.0
| | | 2 | NR | NR | 0.77 | (0.54–1.11)
| | | 3 | NR | NR | 0.93 | (0.66–1.31)
| | | 4 | NR | NR | 0.82 | (0.58–1.16)
| | | 5 | NR | NR | 0.94 | (0.68–1.32)
| | | Total 135,894 | | | | p = 0.9‡
ALA
Multiple Sclerosis | Zhang, 2000^61^ | | Groups | | | | | Multivariable adjustors: Age, smoking (cigarettes/day), energy intake (quintiles), alcohol consumption
| Cohort Study: The Nurses' Health Study I and II | | 1 | NR | < 1% of energy | 1.0 | | Matching: NA
| | | 2 | NR | ≥ 1% of energy | 0.3 | (0.1–1.1)
Parkinson's Disease | Chen, 2003^34^ | Men | Quintiles | | | | | Multivariable adjustors: Age, smoking (cigarettes/day), energy intake (quintiles), alcohol consumption
| Cohort Study: Health Professional Follow-up Study and The Nurses' Health Study | | 1 | NR | 0.05 % of energy | 1.0 | | Matching: NA
| | | 2 | NR | 0.06% of energy | 0.54 | (0.34–0.87)
| | | 3 | NR | 0.08% of energy | 0.75 | (0.49–1.15)
| | | 4 | NR | 0.09% of energy | 0.88 | (0.58–1.32)
| | | 5 | NR | 0.1 % of energy | 0.69 | (0.45–1.07)
| | | Total 47,331 | | | | p = 0.4‡
| | Women | Quintiles
| | | 1 | NR | 0.04 % of energy | 1.0
| | | 2 | NR | 0.06 % of energy | 0.83 | (0.51–1.34)
| | | 3 | NR | 0.07 % of energy | 0.71 | (0.43–1.17)
| | | 4 | NR | 0.09% of energy | 0.68 | (0.41–1.13)
| | | 5 | NR | 0.1 % of energy | 0.60 | (0.35–1.01)
| | | Total 88,563 | | | | p = 0.04‡
| | Pooled men and women | Quintiles
| | | 1 | NR | NR | 1.0
| | | 2 | NR | NR | 0.67 | (0.47–0.93)
| | | 3 | NR | NR | 0.73 | (0.53–1.01)
| | | 4 | NR | NR | 0.79 | (0.57–1.09)
| | | 5 | NR | NR | 0.65 | (0.46–0.91)
| | | Total 135,894 | | | | p = 0.05‡
EPA
Parkinson's Disease | Chen, 2003^34^ | Men | Quintiles
| Cohort Study: Health Professional Follow-up Study and The Nurses' Health Study | | 1 | NR | 0.009 % of energy | 1.0 | | Multivariable adjustors: Age, smoking (cigarettes/day), energy intake (quintiles), alcohol consumption
| | | 2 | NR | 0.02 % of energy | 0.77 | (0.48–1.25)
| | | 3 | NR | 0.04 % of energy | 0.88 | (0.56–1.39)
| | | 4 | NR | 0.06 % of energy | 0.92 | (0.59–1.44)
| | | 5 | NR | 0.1 % of energy | 0.91 | (0.59–1.42)
| | | Total 47,331 | | | | p = 0.9‡
| | Women | Quintiles
| | | 1 | NR | 0.007 % of energy | 1.0
| | | 2 | NR | 0.01 % of energy | 0.67 | (0.39–1.16)
| | | 3 | NR | 0.02 % of energy | 0.80 | (0.48–1.34)
| | | 4 | NR | 0.04 % of energy | 0.74 | (0.44–1.24)
| | | 5 | NR | 0.07 % of energy | 0.91 | (0.56–1.49)
| | | Total 88,563 | | | | p = 0.8‡
| | Pooled men and women | Quintiles
| | | 1 | NR | NR | 1.0
| | | 2 | NR | NR | 0.73 | (0.51–1.04)
| | | 3 | NR | NR | 0.84 | (0.60–1.19)
| | | 4 | NR | NR | 0.84 | (0.60–1.18)
| | | 5 | NR | NR | 0.91 | (0.66–1.27)
| | | Total 135,894 | | | | p = 0.9‡
DHA
Parkinson's Disease | Chen, 2003^34^ | Men | Quintiles | | | | | Multivariable adjustors: Age, smoking (cigarettes/day), energy intake (quintiles), alcohol consumption
| Cohort Study: Health Professional Follow-up Study and The Nurses' Health Study | | 1 | NR | 0.02 % of energy | 1
| | | 2 | NR | 0.05 % of energy | 0.79 | (0.49–1.28)
| | | 3 | NR | 0.07 % of energy | 1.05 | (0.67–1.64)
| | | 4 | NR | 0.1 % of energy | 0.90 | (0.57–1.42)
| | | 5 | NR | 0.2 % of energy | 0.92 | (0.58–1.44)
| | | Total 47,331 | | | | p = 0.9‡
| | Women | Quintiles
| | | 1 | NR | 0.02 % of energy | 1
| | | 2 | NR | 0.04 % of energy | 0.62 | (0.36–1.07)
| | | 3 | NR | 0.06 % of energy | 0.65 | (0.38–1.09)
| | | 4 | NR | 0.08 % of energy | 0.81 | (0.49–1.32)
| | | 5 | NR | 0.1 % of energy | 0.76 | (0.46–1.26)
| | | Total 88,563 | | | | p = 0.8‡
| | Pooled men and women | Quintiles
| | | 1 | NR | NR | 1
| | | 2 | NR | NR | 0.71 | (0.49–1.02)
| | | 3 | NR | NR | 0.86 | (0.61–1.21)
| | | 4 | NR | NR | 0.86 | (0.61–1.20)
| | | 5 | NR | NR | 0.84 | (0.60–1.18)
| | | Total 135,894 | | | | p = 0.8‡

* NR = Not Reported;

† Number of people included in analysis;

‡ test for trend.

|| Core variables = Age of child, sex, maternal age at menarche, maternal age at delivery, maternal chronic disease, previous spontaneous abortion, persistent vomiting during index pregnancy, multiple pregnancy, number of obstetric visits, timing of membrane rupture, use of general anesthesia, mode of delivery, abnormal placenta, head circumference, evident congenital malformation, place of deliver, use of iron during pregnancy, intentional physical exercise during pregnancy, painless delivery classes;

§ Risk of MS per 100 grams of fish per day (log transformation).

The relationship between dietary intake of omega-3 FA and incidence of MS was assessed in two reports; one pooled data from two large cohorts of women from the Nurses' Health Study (NHS) and the Nurses' Health Study II (NHS II),^61^ and the other used a case-control design.^43^ The prospective cohort study assessed the effect of omega-3 fatty acids in terms of fish consumption, fish omega-3 FA, ALA, EPA, and DHA (Table 3.6). ALA was associated with a reduced risk of MS in both cohorts that did not reach statistical significance (pooled RR = 0.3; 95% C.I. 0.1–1.1) (Table 3.6). Intakes of omega-3 FA, EPA, or DHA were not associated with MS incidence. Relative risk estimates pooled for both NHS and NHS II cohorts for omega-3 FA intake (fish) were 1.1 (95% C.I. 0.9–1.3), for EPA intake, 1.3 (95% 0.9–1.9), and 1.1 (95% C.I. 0.9–1.5) for DHA intake (Table 3.6). The case-control study^43^ evaluated 197 incident MS cases and 202 age-, sex- and neighborhood-matched controls and found no significant association between fish consumption and risk of MS overall (OR = 0.91, 95% C.I. 0.78–1.05). However, fish consumption was significantly associated with a lower risk of MS in females only (OR = 0.83, 95% C.I. 0.69–1.00; p<0.05) (Table 3.6).

The relationship between dietary intake of omega-3 FA and incidence of Parkinson's disease was assessed in one report that pooled data from two large prospective cohorts, the Health Professionals Follow-up Study and the Nurses' Health Study. This study assessed the effect of omega-3 FA in terms of omega-3 fats from fish, ALA, EPA, and DHA over a six- to eight-year period (Table 3.6). There was no significant association between fish omega-3 FA, ALA, EPA, or DHA intake and risk of Parkinson's disease (p for trend = 0.9, 0.9, 0.9 and 0.8, respectively).

In a pooled analysis of men and women across two cohorts, ALA was associated with a reduced risk of developing Parkinson's disease (RR = 0.65, 95% CI 0.46, 0.91 for comparison of highest to lowest quintiles of risk). Among women, there was a significant trend but no significant risk reduction for any individual quintile of consumption. This finding is particularly noteworthy given the statistical power of the Health Professionals Follow-up Study and the Nurses' Health Study and the longitudinal analysis of dietary intake in these studies.

One study^60^ evaluated the effects of maternal dietary intake on the risk of cerebral palsy in offspring in a case-control study of 91 cases of cerebral palsy identified from statistics of hospitals and rehabilitation centers in Greece and 246 neighborhood controls. Mothers of cases and controls were interviewed about their dietary habits during pregnancy using a food-frequency questionnaire. Consumption of fish once a week throughout pregnancy was associated with a lower risk of cerebral palsy (OR= 0.63, 95% C.I. 0.37–1.08; p < 0.09) compared with no fish intake.

Sub-populations. Two studies^34,^ ^43^ stratified the effects of omega-3 FA by gender. The study that investigated the relationship between dietary intake of fat and Parkinson's disease found no apparent association between omega-3 FA intake and risk of Parkinson's disease for either males or females (p for trend = 0.9 for males and 0.8 for females).

In the other study,^43^ which used a case-control design, fish consumption was associated with a reduced risk of MS among females, (OR = 0.83, 95% C.I. 0.69–1.00) but not males (OR = 1.08, 95% C.I. 0.84–1.40) (Table 3.6).

Covariates. Effects of any specific covariates on the observed omega-3 associations were not reported in any of the studies.

#### Effects of source, dose, and exposure duration

Source: The effect of fish consumption on the incidence of two different neurological diseases was assessed in three different reports. Fish consumption was associated with a reduced risk of cerebral palsy;^60^ it had no overall effect on the incidence of MS in two studies,^43,^ ^61^ but was associated with a reduced risk for women in one.^43^ Omega-3 FA from fish had no effect on the incidence of MS^43^ or Parkinson's disease.^34^ ALA was associated with a reduced risk of MS in one study^61^ and had no effect on the incidence of Parkinson's disease in another.^34^ EPA and DHA had no effect on the incidence of MS^61^ or Parkinson's disease.^34^

Dose: Dose effect was assessed in two studies.^34,^ ^61^ One study^34^ assessed the effect of fish dose on the incidence of MS and found no dose (or other) effect. A dose effect for ALA on the incidence of MS was reported in one study,^34^ but no dose effect for ALA on the incidence of Parkinson's disease was found in the other study.^61^ There was no dose effect for EPA or DHA in either study.

Exposure Duration: None of the studies assessed the effect of exposure duration.

Sustainment of effect. Sustainment of effect was not assessed in any of the reports.

Quality and applicability. Parameters of methodologic quality are detailed in Table 3.5. All four of the studies^34,^ ^43,^ ^60,^ ^61^ had an applicability rating of II.

Table 3.5 Parameters of methodological quality.*

Parameters | Chen, 2003^34^ | Ghadirian, 1998^43^ | Petridou, 1998^60^ | Zhang, 2000^61^
Adjustment for confounders | Y | Y | Y | Y
Blinding of exposure/outcome | Y | Y | Y | Y
Valid ascertainment of outcome | Y | Y | Y | Y
Valid ascertainment of exposure | Y | Y | Y | Y
Exposure before outcome | Y | Y | Y | Y
Selection bias | N | N | Y | N
Description of withdrawals and dropouts | NR | Y | Y | Y

* NR = not reported.

### Progression of Multiple Sclerosis

Overall effect. We identified three studies that evaluated the effect of omega-3 FA on the treatment and progression of MS. Among these, one study was an RCT^40^ and two were single arm, open-label clinical trials.^62,^ ^63^ The RCT assessed the effect of treatment with an omega-3 FA supplement (MaxEPA) on disability and relapse rates (Table 3.7). There were no significant differences in disability or relapse rates between the treatment and placebo groups. Results for disability did not differ on subgroup analyses of patients with disease duration of 5 years or less and baseline Kurtzke disability scores of 2 or less (Table 3.7).

Table 3.7 The effect of omega-3 fatty acids on progression of multiple sclerosis reported in one randomized controlled trial (RCT).*

Author, Year | Treatment Group | Disability, number (%)of patients | | | | | | Mean relapse rates
Bates, 1989^40^ | | Overall | | Kurtzke ≤ 2 | | Duration ≤ 5 years | | Kurtzke ≤ 2 | | Kurtzke > 2
| | Better/same | Worse | Better/same | Worse | Better/same | Worse | Better/same | Worse | Better/same | Worse
| Max EPA 10 grams/day for 24 months | 79 (51) | 66 (43) | 50 (59) | 35 (41) | 30 (57) | 23 (43) | 0.44 | 0.15 | 0.55 | 0.05
| Olive oil 10 grams/day for 24 months | 65 (42) | 82 (52) | 41 (46) | 49 (54) | 24 (42) | 33 (58) | 0.55 | 0.16 | 0.63 | 0.70

* No significant difference between groups for any comparisons.

The one-arm open-label studies^62,^ ^63^ described the effects of supplementation with omega-3 FA on disability and progression among patients with MS (Table 3.8). Both studies reported a significant reduction on the Expanded Disability Status Scale (EDSS) after treatment with the omega-3 supplement; one also reported improvement on an index of disease progression.^62^

Table 3.8 The effect of omega-3 fatty acids on progression of multiple sclerosis in open-label trials stratified by outcome

Author, Year | Intervention | Mean EDSS Scores* | Mean Progression Index
| | n, clinical diagnosis | Before | After | Before | After
Cendrowski, 1986^62^ | MaxEPA (4.2 g/day EPA; 2.8 g/day DHA) | 5, acute remitting MS | 3.30 | 2.70 | 0.59 | 0.44†
Cendrowski, 1986^62^ | MaxEPA (4.2 g/day EPA; 2.8 g/day DHA) | 7; slowly progressive MS | 6.92 | 7.07 | 0.35 | 0.36
Nordvik, 2000^63^ | Fish oil supplement (0.4 g/day EPA; 05 g/day DHA) | 16; MS | 2.16 | 1.63‡ | NA | NA

NA = Not Applicable;

* EDSS = Expanded Disability Status Scale;

† p < 0.05;

‡ = p = 0.005.

Sub-populations. The effects of omega-3 FA on subpopulations were not assessed.

Covariates. The effects of covariates on omega-3 FA effects were not assessed.

#### Effects of source, dose, and exposure duration

Source: The source of omega-3 FA was fish oil in one study^63^ and fish oil capsules in the other.^62^

Dose: A single dose was assessed in each study; hence, dose effect was not assessed.

Exposure Duration: The effect of exposure duration was not assessed.

Sustainment of effect. Sustainment of effect was not assessed.

Quality and applicability. The RCT^40^ had an applicability rating of II-B and a summary quality score of B (Jadad score = 3); concealment of allocation was not reported. This study is applicable to the general population of adult patients with multiple sclerosis (Table 3.9). The two open label one-arm trials^62,^ ^63^ were both of poor methodologic quality: there was no comparison group or blinding; additionally there was no description of withdrawals or dropouts. Both of these trials had a Jadad score of 0. The applicability rating of these studies was II-B.

Table 3.9 Relationship between methodologic quality and applicability for estimates of effect of omega-3 fatty acid consumption on progression of multiple sclerosis in randomized controlled trials (RCTs)

| | Methodologic Quality
Applicability | | A | B | C
| I
| II | | Bates^40^
| III