# Methodology

## Objectives

The topic of this report was nominated by the NIH ODS. The three participating Evidence-Based Practice Centers (EPCs) were asked to examine the effects of omega-3 fatty acids, in general, and on the following conditions: Cardiovascular Disease, Transplantation, Immune-Mediated Diseases, Gastrointestinal/Renal Diseases, Cancer, Neurological conditions, Asthma, Child/Maternal Health, Eye Health, and Mental Health. The Southern California EPC (SCEPC) was responsible for examining Immune-Mediated Diseases and Gastrointestinal/Renal Diseases in Year-one of the project and Cancer and Neurological conditions in Year-two of the project.

## Scope of Work

The methodology that we used for this study included the following:

- Refining the preliminary questions provided by AHRQ,
- Convening a technical expert panel to advise the SCEPC on the study,
- Identifying sources of evidence in the scientific literature,
- Establishing inclusion/exclusion criteria for the studies identified in the scientific literature,
- Identifying potential evidence with attention to controlled clinical trials using omega-3 fatty acids,
- Evaluating potential evidence for methodological quality and relevance,
- Extracting data from studies meeting methodological and clinical criteria,
- Synthesizing the results,
- Performing further statistical analysis on selected studies, as appropriate,
- Performing meta-analyses where appropriate,
- Submitting the results to technical experts for peer review,
- Incorporating reviewers' comments into a final report for submission to AHRQ.

## Original Proposed Key Questions

Preliminary questions for the project were developed by ODS in collaboration with the following NIH Institutes: (a) National Cancer Institute (NCI); (b) National Eye Institute (NEI); (c) National Heart, Lung, and Blood Institute (NHLBI); (d) National Institute of Alcohol Abuse and Alcoholism (NIAAA); (e) National Institute of Allergy and Infectious Diseases (NIAID); (f) National Institute of Arthritis and Musculoskeletal and Skin Diseases (NIAMS); (g) National Institute of Child Health and Human Development (NICHD); (h) National Institute of Diabetes and Digestive and Kidney Diseases (NIDDK); (i) National Institute of Mental Health; and (j) National Institute of Neurological Disorders and Stroke (NINDS). The general and disease-specific questions that were originally proposed are detailed in Appendix A.1.

## Technical Expert Panel

Each AHRQ evidence report is guided by a Technical Expert Panel (TEP). The TEP advises the SCEPC on refining the preliminary questions, determining the proper inclusion/exclusion criteria for the studies, determining populations of interest, establishing proper outcome measures, and conducting appropriate analyses.

We convened a TEP that focused on neurological diseases and conditions. The TEP was composed of distinguished basic scientists and clinicians, with established expertise in omega-3 FA, human nutrition, dietary assessment methods, and neurology. In addition to the experts that we identified, AHRQ and the NIH Institute of Neurological Disorders and Stroke (NINDS) and Institute on Aging (NIA) recommended a number of industry experts. The members of our technical expert panel are listed by name along with a summary of their key comments and recommendations in Appendix A.2.

## Key Questions Addressed in this Report

Based on input from our TEP, the preliminary disease-specific questions were revised. The questions that are addressed in this report are as follows:

- What is the evidence that omega-3 fatty acids play a role in maintaining cognitive function in normal aging?
- What is the evidence that omega-3 fatty acids affect the incidence of dementia including Alzheimer's disease?
- What is the evidence that omega-3 fatty acids are effective in the treatment of dementia including Alzheimer's disease?
- What is the evidence that omega-3 fatty acids affect the incidence of neurological diseases?
- What is the evidence that omega-3 fatty acids prevent the progression of multiple sclerosis?

## Identification of Literature Sources

Potential evidence for our study came from three sources: on-line library databases, the reference lists of all relevant articles, and industry experts.

Jessie McGowan, Senior Information Scientist, and Nancy Santesso, Knowledge Translation Specialist, at the University of Ottawa were responsible for developing a common search strategy for omega-3 FA for the 3 participating EPCs. Nancy Santesso developed a core omega-3 search strategy in collaboration with project librarians, biochemists, nutritionists, and clinicians, who also provided biochemical names, abbreviations, food sources, and commercial product names for omega-3 FA. The literature search was not restricted by language of publication or by study design, in order to increase sensitivity. When possible, the searches were limited to studies involving human subjects. The core search strategy is detailed in Appendix A.4.

For the SCEPC, this core search strategy was incorporated into a search for cognitive function with aging, Alzheimer's disease, and other neurological diseases/conditions. The strategy for this search is detailed in Appendix A.4.

The following databases were searched: Medline (1966-2003), Premedline (December, 2003), Embase (1980-2003), Cochrane Central Register of Controlled Trials (4th Quarter, 2003), CAB Health (1973-2003), Dissertation Abstracts (1861-2003). All of these databases were searched using the Ovid interface, except CAB Health, which was searched through SilverPlatter. Any duplicate records were identified and removed within each search question using Reference Manager software. The citations obtained from these literature searches were sent to the SCEPC via e-mail.

Two experienced reviewers, Walter Mojica and Amalia Issa, who were blinded to study authors and sources independently evaluated the citations and corresponding abstracts, if available. The reviewers selected article titles that focused on omega-3 FA and normal cognitive function with aging, dementia, and other neurologic diseases/conditions. In addition, they selected article titles that pertained to the disease conditions of the other participating EPCs. Language was not a barrier to inclusion. Articles that either reviewer selected were ordered, as well as those articles whose relevance could not be determined from the title or abstract. The articles were ordered from the UCLA library, or Infotrieve, a Los Angeles-based literature retrieval firm with contacts around the world. The literature was tracked using ProCite and Access software.

In addition, we sent letters to industry experts recommended by the ODS to obtain any unpublished data (Figure A.3.1).

## Evaluation of Evidence

Two experienced reviewers, Walter Mojica and Amalia Issa, independently reviewed each article that was ordered, to determine whether it should be accepted for further study, using a structured screening form (shown in Figure B.1, Appendix B) that included a defined set of inclusive/exclusive criteria (Table A.5.1, Appendix A.5). Walter Mojica is a physician with extensive experience in the science of systematic reviews and evidence-based medicine. Amalia Issa is a clinical neuroscientist with a background in AD research. Briefly, human controlled clinical trials (randomized and non-randomized), prospective cohort studies, case-control studies and case series were included; case reports were excluded. For inclusion, studies also had to describe assessing a difference between omega-3 fatty acids content in study arms for all study designs except case series, and describe the effect of omega-3 fatty acids on any of the following outcomes: cognitive decline with normal aging, incidence of dementia, progression of dementia, incidence of neurological disease, progression of MS. The reviewers resolved any disagreements by consensus. Reviewers were blinded to author and journal when reviewing titles and abstracts, but not when reviewing articles.

## Extraction of Data

For the studies that passed our screening criteria, two reviewers independently abstracted detailed data onto a specialized quality review form (QRF) (Figure B.2, Appendix B).

Walter Mojica and Amalia Issa independently reviewed all of the studies. The reviewers resolved differences through consensus, and a senior physician researcher, Catherine MacLean, resolved any disagreements that could not be resolved through this method.

The QRF included questions about the study design; the outcomes of interest; study sample characteristics; details on the intervention, such as the dose, frequency, and duration; adverse events; the elapsed time between the intervention and outcome measurements, and, the types of outcome measures.

We consulted with several outside scientists to complete QRFs for foreign-language articles. Foreign language articles were reviewed as follows. Spanish-language articles were reviewed by Walter Mojica, French-language articles by Amalia Issa who are fluent in these languages. For other foreign-language articles, a single reviewer who is fluent in the language worked with Catherine MacLean to complete the standard abstraction form.

## Grading Evidence

### Methodologic Quality of Randomized Controlled Trials

To evaluate the quality of the design and execution of trials, we also collected information about the study design, appropriateness of randomization, blinding, description of withdrawals and dropouts, and concealment of allocation. A score for quality was calculated for each trial using a system developed by Jadad (Appendix A.6, Figure A.6.1). The Jadad score rates studies on a scale of 0 to 5. Empirical evidence has shown that studies scoring 2 or less report exaggerated results compared with studies scoring 3 or more.^56^ Thus, studies with a Jadad score of 3 or more are referred to as “high quality,” and studies scoring 2 or less are referred to as “poor quality.” For our purposes, if a trial was associated with more than one study, its quality score was equal to the maximum score calculated across its associated studies. Additionally, a generic summary quality score (A, B, C) was assigned to each study based on the combination of its Jadad score and reporting of concealment of allocation (Appendix A.6, Table A.6.1).

### Methodologic Quality of Observational Studies

To evaluate the quality of the design and execution of observational studies, we collected information about the validity of ascertainment of cases and exposure, description of withdrawals and dropouts, and adjustment for confounders and blinded assessment of exposure and case status when ascertaining case and exposure status, respectively.^57,^ ^58^ We also described whether exposure occurred prior to the outcome, whether study groups were comparable, and whether there appeared to be selection bias. A score for quality was not calculated for observational studies, as there is no validated method to do so.

### Applicability

This report focuses on the U.S. population as a whole. To capture the potential applicability of studies to the different populations of interest as defined in the scope of work (namely aging Americans or Americans with dementia or other neurological diseases/conditions), we categorized the populations in the studies we reviewed in terms of 1) applicability to the U.S. population and 2) health state (Appendix A.6, Table A.6.2). In the summary tables, each study receives a combined applicability grade based on the applicability and health state.

## Data Synthesis

Because too few studies were identified to perform pooled analyses (meta-analysis), we performed a qualitative synthesis of the evidence.

This report is organized by five different study questions. For each study question we describe the number and design of studies identified that pertained to the question and describe the overall effect of omega-3 fatty acids across the studies. We describe the unit of analysis for omega-3 consumption, i.e. fish, total omega-3, DHA, EPA or ALA. We summarized the point estimates and statistical testing that were described in the original studies and state when these parameters were not reported. We specifically comment on whether the studies assessed the effects of omega-3 fatty acids on sub-populations, the effects of covariates on outcomes, the effects of omega-3 fatty acid source, dose and exposure duration and sustainment of effect after treatment with omega-3 fatty acids. When these parameters were assessed they were described. We also describe the quality and applicability of the studies for each topic. Of note, we describe whether information on covariates was reported in two ways and for two reasons. First, we report whether covariates had a specific effect on the outcome of interest and the magnitude of the effect if it was significant. Second, we report whether there was adjustment for covariates as a measure of methodologic quality.

## Peer Review

This draft report was sent for review to a select group of experts in omega-3 fatty acids, epidemiology, nutrition, and cancer. The names, expertise, and affiliations of the peer reviewers are listed in Table A.7.1, Appendix A. Additionally, this draft report was sent to the members of the TEP for review. Service as a peer reviewer or as a technical expert panelist does not imply agreement or endorsement of the findings of this report.