# Appendix C. Evidence Tables

Evidence Table C.1.1 Part A. Evidence table of the effects of omega-3 fatty acids on cognitive function and dementia in cohort studies.*

First Author, Year | Study Characteristics | Duration | Eligibility criteria | Disease | Applicability
Cohort | | | | Ascertainment | Funding source
| | | | | Quality
Barberger-Gateau, 2002^21^ | Sample size (people/person years): 1,416/NR | Duration: 7 years | Inclusion: Age = 68/Normal cognition/Living at home | Disease: Dementia | Applicability: II
PAQUID (Personnes Agées QUID) Study | Age (mean/range): NR/68–99 | | Exclusion: Dementia | Ascertainment: MMSE; neurological exam | Funding source: Industry and private
| Race: NR | | | | Quality:
| % male: NR | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinding of exposure/outcome: N
| Location: France | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: NR
| | | | | Exposure before outcome: Y
| | | | | Selection bias: N
| | | | | Description of withdrawals and dropouts: Y
Kalmijn, 1997^59^ | Sample size (people/person years): 818/NR | Duration: 3 years | Inclusion: NR | Disease: cognitive function, normal aging and incidence of dementia | Applicability: II
Zutphen Elderly Study | Age (mean/range): NR/69–89 | | Exclusion: NR | Ascertainment: Clinical exam; MMSE | Funding source: Government
| Race: NR | | | | Quality:
| % male: 100 | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinding of exposure/outcome: N
| Location: Netherlands | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Exposure before outcome: Y
| | | | | Selection bias: N
| | | | | Description of withdrawals and dropouts: Y
Kalmijn, 1997^67^ | Sample size (people/person years): 5,386/NR | Duration: 2.1 years | Inclusion: Residents of a suburb in Rotterdam, age ≥ 55 | Disease: Dementia | Applicability: II
Rotterdam Cohort | Age (mean/range): 67.7/NR | | Exclusion: Cambridge Mental Disorders of the Elderly Examination (CAMDEX) score below 80; illogical answers to food pattern questionnaire | Ascertainment: Medical records or medical examination | Funding source: Government
| Race: NR | | | | Quality:
| % male: 41 | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinding of exposure/outcome: NR
| Location: Netherlands | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Exposure before outcome: Y
| | | | | Selection bias: N
| | | | | Description of withdrawals and dropouts: Y
Morris, 2003^23^ | Sample size (people/person years): 815/NR | Duration: 3.9 years | Inclusion: Normal cognition | Disease: Alzheimer's disease | Applicability: I
Chicago Health and Aging Project | Age (mean/range): 73/NR | | Exclusion: NR | Ascertainment: NINCDS criteria, neurological exam | Funding source: Government
| Race: Caucasian and Black | | | | Quality:
| % male: 39 | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinding of exposure/outcome: Y
| Location: U.S. | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Exposure before outcome: Y
| | | | | Selection bias: N
| | | | | Description of withdrawals and dropouts: Y

* NR = not reported.

Evidence Table C.1.1 Part B. Evidence table of the effects of omega-3 fatty acids on cognitive function and dementia in cohort studies by category of omega-3 consumption.*

Author, Year | Type of dementia | Study arm (quartile, quintile or dose group) | Total n | Amount by category | Estimates of effect
Cohort | | | | | Age adjusted RR (95% CI) | | Multivariable RR (95% CI) | | Multivariable Adjustors
FISH
Barberger-Gateau, 2002^21^ | Dementia | 1 | NR | NR | 1.0 | | 1.0 | | Age, sex, education
PAQUID (Personnes Agées QUID) Study | | 2 | 1122 | At least once a week | 0.66† | (0.47–0.93) | 0.73† | (0.52–1.03)
| Alzheimer's disease | 1 | NR | NR | 1.0 | | NR
| | 2 | 1122 | At least once a week | 0.69† | (0.47–1.01) | NR
| | Total 1122
Kalmijn, 1997^67^ | Total dementia | 1 | 1807 | ≤ 3 g/day | NR | | 1.0 | | Age, sex, education, total energy intake.
Rotterdam Study | | 2 | 1773 | 3.0–18.5 g/day | NR | | 0.8 | (0.4–1.4)
| | 3 | 1806 | > 18.5 g/day | NR | | 0.4 | (0.2–0.9)
| | | | | | | | p = 0.03‡
| Alzheimer's disease without vascular component | 1 | 1807 | ≤ 3 g/day | NR | | 1.0
| | 2 | 1773 | 3.0–18.5 g/day | NR | | 0.9 | (0.4–1.8)
| | 3 | 1806 | > 18.5 g/day | NR | | 0.3 | (0.1–0.9)
| | | | | | | | p = 0.005‡
| Dementia with a vascular component | 1 | 1807 | ≤ 3 g/day | NR | | 1.0
| | 2 | 1773 | 3.0–18.5 g/day | NR | | 0.6 | (0.2–2.5)
| | 3 | 1806 | > 18.5 g/day | NR | | 0.7 | (0.2–2.8)
| | Total 5386 | | | | | | p = 0.39‡
Morris, 2003^23^ | Alzheimer's disease | 1 | 121 | never | 1.0 | | 1.0 | | Age, sex, race, education, vitamin E intake, other fat intake, cardiovascular disease, APO-ε4 status.
Chicago Health and Aging Project | | 2 | 250 | 1–3 servings/months | 0.7 | (0.3–1.6) | 0.6 | (0.3–1.3)
| | 3 | 296 | 1 serving/ week | 0.5 | (0.2–1.0) | 0.4 | (0.2–0.9)
| | 4 | 148 | ≥ 2 servings/week | 0.6 | (0.2–0.9) | 0.4 | (0.2–0.9)
| | Total 815 | | | | p = 0.18‡ | | p = 0.07‡
Omega-3 fatty acids
Morris, 2003^23^ | Alzheimer's disease | 1 | NR | 0.9 g/day | 1.0 | | 1.0 | | Age, sex, race, education, vitamin E intake, other fat intake, cardiovascular disease, APO-ε4 status.
Chicago Health and Aging Project | | 2 | NR | 1.13 g/day | 1.1 | (0.4–2.9) | 1.2 | (0.5–3.0)
| | 3 | NR | 1.30 g/day | 0.5 | (0.2–1.4) | 0.6 | (0.2–1.7)
| | 4 | NR | 1.49 g/day | 0.6 | (0.2–1.5) | 0.7 | (0.3–1.6)
| | 5 | NR | 1.75 g/day | 0.3 | (0.1–0.7) | 0.4 | (0.1–0.9)
| | Total 815 | | | | p = 0.01‡ | | p = 0.01‡
ALA
Morris, 2003^23^ | Alzheimer's disease | 1 | NR | 0.72 g/day | 1.0 | | 1.0 | | Age, sex, race, education, vitamin E intake, other fat intake, cardiovascular disease, APO-ε4 status.
Chicago Health and Aging Project | | 2 | NR | 0.92g/day | 1.7 | (0.7–3.8) | 1.8 | (0.8–3.8)
| | 3 | NR | 1.06g/day | 0.8 | (0.4–1.9) | 0.8 | (0.4–2.0)
| | 4 | NR | 1.23g/day | 0.8 | (0.4–1.7) | 0.9 | (0.4–2.0)
| | 5 | NR | 1.46g/day | 0.5 | (0.2–1.1) | 0.7 | (0.3–1.6)
| | Total 815 | | | | p = 0.01‡ | | p = 0.10‡
DHA
Morris, 2003^23^ | Alzheimer's disease | 1 | NR | 0.03 g/day | 1.0 | | 1.0 | | Age, sex, race, education, vitamin E intake, other fat intake, cardiovascular disease, APO-ε4 status.
Chicago Health and Aging Project | | 2 | NR | 0.05 g/day | 0.8 | (0.3–2.1) | 0.8 | (0.3–2.1)
| | 3 | NR | 0.06 g/day | 0.4 | (0.1–1.1) | 0.4 | (0.1–1.0)
| | 4 | NR | 0.07 g/day | 0.3 | (0.1–0.9) | 0.2 | (0.1–0.8)
| | 5 | NR | 0.10 g/day | 0.4 | (0.2–1.1) | 0.3 | (0.1–0.9)
| | Total 815 | | | | p = 0.05‡ | | p = 0.02‡
EPA
Morris, 2003^23^ | Alzheimer's disease | 1 | NR | 0.0 g/day | 1.0 | | 1.0 | | Age, sex, race, education, vitamin E intake, other fat intake, cardiovascular disease, APO-ε4 status.
Chicago Health and Aging Project | | 2 | NR | 0.0.g/day | NR§ | NR§ | NR§ | NR§
| | 3 | NR | 0.01 g/day | 1.0 | (0.4–2.4) | 1.1 | (0.4–2.8)
| | 4 | NR | 0.02 g/day | 0.5 | (0.2–1.2) | 0.5 | (0.2–1.2)
| | 5 | NR | 0.03 g/day | 0.9 | (0.4–2.1) | 0.9 | (0.4–2.3)
| | Total 815 | | | | p = 0.40‡ | | p = 0.40‡

* NR = not reported, g = grams;

† hazards ratio;

‡ age and sex adjusted; test for trend;

§ Authors report that 40% of participants had 0 g/day of intake.

Evidence Table C.2.1 Part A. Evidence table of the effects of omega-3 fatty acids on the treatment of dementia in RCTs.*

First Author, Year | Study Characteristics | Study Design Duration | Eligibility criteria | Concurrent Disease Condition Medication | Arm | Interventions Dosage/Duration
Terano, 1994^24^ | Sample size (people/person years): 20/NR | Design: RCT | Inclusion: Other dementia | NR | 1 | Intervention: Standard hospital diet
| Age (mean/range): 83/NR | Duration: 12 months | Exclusion: NR | | | Dosage: NR
| Race: NR | | | | 2 | Intervention: DHA
| % male: NR | | | | | Dosage: 4.3 grams/day for 12 months
| # sites: 1
| Location: Japan

* NR = not reported

Evidence Table C.2.1 Part B. Evidence table of the effects of omega-3 fatty acids on the treatment of dementia in RCTs.*

First Author, Year | Outcomes | | | | | Quality
| Results | | | | | Applicability
| | | | | | Funding Source
Terano, 1994^24^ | Study arms | Results | | | | Quality
| | Before | After 3 months | After 6 months | After 12 months | Jadad: 1
| Mean scores of HDS-R | | | | | Concealment of Allocation: NR
| Standard nursing home diet | 16.3 | 16.7 | 16.7 | 15.3 | Applicability: II-B
| Standard nursing home diet PLUS DHA 4.3 grams/day | 17.2 | 20.6† | 19.9† | 20.2 | Funding Source: NR
| Mean scores of MMSE
| Standard nursing home diet | 19.7 | 19.4 | 19.6† | 19.1
| Standard nursing home diet PLUS DHA 4.3 grams/day | 20.1 | 21.3 | 22.2 | 21.9

* NR = not reported, HDS-R = Hasegawa's Dementia rating scale; MMSE = Mini Mental Status Exam.

† p < 0.05 with paired t-test.

Evidence Table C.3.1 Part A. Evidence table of the effects of omega-3 fatty acids on incidence of neurological diseases in cohort and case control studies.*

First Author, Year | Study Characteristics | Duration | Eligibility criteria | Disease Ascertainment | Applicability
Cohort | | | | | Funding source
| | | | | Quality
Chen, 2003^34^ | Study Design: Cohort | Duration: Variable years | Inclusion: NR | Disease: Parkinson's | Applicability: II
Health Professionals Follow-up Study Cohort and The Nurses' Health Study Cohort | Sample size (people/person years): 135,894/NR | | Exclusion: Cancer (other than non-melanoma skin cancer)/Incomplete food frequency questionnaire/Dietary questionnaire with implausible total energy intake | Ascertainment: neurological exam | Funding source: Government and private (non-industry)
| Age (mean/range): NR/30–75 | | | | Quality:
| Race: NR | | | | Adjustment for confounders: Y
| % male: 35 | | | | Blinding of exposure/outcome: Y
| # sites: 1 | | | | Valid ascertainment of outcome: Y
| Location: US | | | | Valid ascertainment of exposure: Y
| | | | | Exposure before outcome: Y
| | | | | Selection bias: N
| | | | | Description of withdrawals and dropouts: NR
Ghadirian, 1998^43^ | Study Design: Case-Control | Duration: NR | Inclusion: Multiple sclerosis | Disease: MS | Applicability: II
| Sample size (people/person years): 399/NR | | Exclusion: NR | Ascertainment: Neurological exam, Kurtzke/EDSS | Funding source: NR
| Age (mean/range): NR/NR | | | | Quality:
| Race: NR | | | | Adjustment for confounders: Y
| % male: 31 | | | | Blinding of exposure/outcome: Y
| # sites: 1 | | | | Valid ascertainment of outcome: Y
| Location: Canada | | | | Valid ascertainment of exposure: Y
| | | | | Exposure before outcome: Y
| | | | | Groups comparable: Y
| | | | | Selection bias: N
| | | | | Description of withdrawals and dropouts: Y
Petridou, 1998^60^ | Stdy Design: Case-Control | Duration: NR | Inclusion: NR | Disease: CP | Applicability: II
| Sample size (people/person years): 337/NR | | Exclusion: NR | Ascertainment: Clinical exam; registry | Funding source: Government and private
| Age (mean/range): 5/4–8 | | | | Quality:
| Race: NR | | | | Adjustment of confounders: Y
| % male: 53 | | | | Blinding of exposure/outcome:
| # sites: 1 | | | | Valid ascertainment of outcome: Y
| Location: Greece | | | | Valid ascertainment of exposure: Y
| | | | | Exposure before outcome: Y
| | | | | Groups comparable: Y
| | | | | Selection bias: Y
| | | | | Description of withdrawals and dropouts: Y
Zhang, 2000^61^ | Study Design: Cohort | Duration: 14 years | Inclusion: NR | Disease: MS | Applicability: II
Nurses' Health Study Cohort | Sample size (people/person years): 187,811/NR | | Exclusion: Cancer (other than non-melanoma skin cancer)/Incomplete food frequency questionnaire/Dietary questionnaire with implausible total energy intake | Ascertainment: neurological exam; Poser criteria | Funding source: Government
| Age (mean/range): NR/25–55 | | | | Quality:
| Race: NR | | | | Adjustment of confounders: Y
| % male: NR | | | | Blinding of exposure/outcome: Y
| # sites: 1 | | | | Valid ascertainment of outcome: Y
| Location: US | | | | Valid ascertainment of exposure: Y
| | | | | Exposure before outcome: Y
| | | | | Selection bias: N
| | | | | Description of withdrawals and dropouts: Y

* NR = not reported

Evidence Table C.3.1 Part B. Evidence table of the effects of omega-3 fatty acids on incidence of neurological diseases in cohort and case control studies.*

Author, Year | | Study arm (quartile: quintile: dose group; case or control) | n† | Amount by category | Estimates of effect
Cohort Disease | | | | | Multivariable RR (95% CI) | | Multivariable Adjustors, Matching parameters
Fish
Zhang, 2000^61^ | | 1 | 81 | < 1/week | 1.0 | | Multivariable adjustors: Age, smoking (cigarettes/day), energy intake (quintiles), alcohol consumption
The Nurses' Health Study I and II | | 2 | 77 | 1–2.9/week | 1.0 | (0.8–1.4) | Matching: NA
Multiple Sclerosis | | 3 | 37 | 3–4.9/week | 0.9 | (0.6–1.3)
| | | | | | p = 0.79‡
Ghadirian, 1998,^43^ | Men | Control | 64 | | 1.0 | | Multivariable adjustors: Total energy, body mass index
Multiple sclerosis | | Case | 61 | | 1.08 | (0.84–1.40) | Matching: Age, sex, phone number
| Women | Control | 138 | | 1.0
| | Case | 136 | | 0.83 | (0.69–1.00)
| All | Control | 202 | | 1.0
| | Case | 197 | | 0.91 | (0.78–1.05)
Petridou, 1998,^60^ | | Control | 166 | 1/week | 1.0 | | Multivariable adjustors: ‘Core’ variables§ plus total energy intake, body mass index
Cerebral palsy | | Case | 58 | 1/week | 0.63 | (0.37–1.08) | Matching: Age, neighborhood or age, physician
Omega-3 fat from fish
Chen, 2003^34^ | Men | 1 | NR | 0.03 % of energy | 1.0 | | Multivariable adjustors: Age, smoking (cigarettes/day), energy intake (quintiles), alcohol consumption
Health Professional Follow-up Study and The Nurses' Health Study, Parkinson's Disease | | 2 | NR | 0.07% of energy | 0.84 | (0.52–1.37) | Matching: NA
| | 3 | NR | 0.1% of energy | 1.08 | (0.69–1.69)
| | 4 | NR | 0.2% of energy | 0.88 | (0.55–1.40)
| | 5 | NR | 0.3 % of energy | 0.99 | (0.63–1.55)
| | Total 47,331 | | p = 0.9‡
| Women | 1 | NR | 0.03 % of energy | 1.0
| | 2 | NR | 0.05 % of energy | 0.70 | (0.41–1.19)
| | 3 | NR | 0.08 % of energy | 0.76 | (0.45–1.29)
| | 4 | NR | 0.1% of energy | 0.75 | (0.45–1.26)
| | 5 | NR | 0.2 % of energy | 0.90 | (0.55–1.47)
| | Total 88,563 | | | | p = 0.9‡
| Pooled men and women | 1 | NR | NR | 1.0
| | 2 | NR | NR | 0.77 | (0.54–1.11)
| | 3 | NR | NR | 0.93 | (0.66–1.31)
| | 4 | NR | NR | 0.82 | (0.58–1.16)
| | 5 | NR | NR | 0.94 | (0.68–1.32)
| | Total 135,894 | | | | p = 0.9‡
ALA
Chen, 2003^34^ | Men | 1 | NR | 0.05 % of energy | 1.0 | | Multivariable adjustors: Age, smoking (cigarettes/day), energy intake (quintiles), alcohol consumption
Health Professional Follow-up Study and The Nurses' Health Study, Parkinson's Disease | | 2 | NR | 0.06% of energy | 0.54 | (0.34–0.87) | Matching: NA
| | 3 | NR | 0.08% of energy | 0.75 | (0.49–1.15)
| | 4 | NR | 0.09% of energy | 0.88 | (0.58–1.32)
| | 5 | NR | 0.1 % of energy | 0.69 | (0.45–1.07)
| | Total 47,331 | | | | p = 0.4‡
| Women | 1 | NR | 0.04 % of energy | 1.0
| | 2 | NR | 0.06 % of energy | 0.83 | (0.51–1.34)
| | 3 | NR | 0.07 % of energy | 0.71 | (0.43–1.17)
| | 4 | NR | 0.09% of energy | 0.68 | (0.41–1.13)
| | 5 | NR | 0.1 % of energy | 0.60 | (0.35–1.01)
| | Total 88,563 | | | | p = 0.04‡
| Pooled men and women | 1 | NR | NR | 1.0
| | 2 | NR | NR | 0.67 | (0.47–0.93)
| | 3 | NR | NR | 0.73 | (0.53–1.01)
| | 4 | NR | NR | 0.79 | (0.57–1.09)
| | 5 | NR | NR | 0.65 | (0.46–0.91)
| | Total 135,894 | | | | p = 0.05‡
EPA
Chen, 2003^34^ | Men | 1 | NR | 0.009 % of energy | 1.0 | | Multivariable adjustors: Age, smoking (cigarettes/day), energy intake (quintiles), alcohol consumption
Health Professional Follow-up Study and The Nurses' Health Study, Parkinson's Disease | | 2 | NR | 0.02 % of energy | 0.77 | (0.48–1.25)
| | 3 | NR | 0.04 % of energy | 0.88 | (0.56–1.39)
| | 4 | NR | 0.06 % of energy | 0.92 | (0.59–1.44)
| | 5 | NR | 0.1 % of energy | 0.91 | (0.59–1.42)
| | Total 47,331 | | | | p = 0.9‡
| Women | 1 | NR | 0.007 % of energy | 1.0
| | 2 | NR | 0.01 % of energy | 0.67 | (0.39–1.16)
| | 3 | NR | 0.02 % of energy | 0.80 | (0.48–1.34)
| | 4 | NR | 0.04 % of energy | 0.74 | (0.44–1.24)
| | 5 | NR | 0.07 % of energy | 0.91 | (0.56–1.49)
| | Total 88,563 | | | | p = 0.8‡
| Pooled men and women | 1 | NR | NR | 1.0
| | 2 | NR | NR | 0.73 | (0.51–1.04)
| | 3 | NR | NR | 0.84 | (0.60–1.19)
| | 4 | NR | NR | 0.84 | (0.60–1.18)
| | 5 | NR | NR | 0.91 | (0.66–1.27)
| | Total 135,894 | | | | p = 0.9‡
DHA
Chen, 2003^34^ | Men | 1 | NR | 0.02 % of energy | 1 | | Multivariable adjustors: Age, smoking (cigarettes/day), energy intake (quintiles), alcohol consumption
Health Professional Follow-up Study and The Nurses' Health Study Parkinson's Disease | | 2 | NR | 0.05 % of energy | 0.79 | (0.49–1.28)
| | 3 | NR | 0.07 % of energy | 1.05 | (0.67–1.64)
| | 4 | NR | 0.1 % of energy | 0.90 | (0.57–1.42)
| | 5 | NR | 0.2 % of energy | 0.92 | (0.58–1.44)
| | Total 47,331 | | | | p = 0.9‡
| Women | 1 | NR | 0.02 % of energy | 1
| | 2 | NR | 0.04 % of energy | 0.62 | (0.36–1.07)
| | 3 | NR | 0.06 % of energy | 0.65 | (0.38–1.09)
| | 4 | NR | 0.08 % of energy | 0.81 | (0.49–1.32)
| | 5 | NR | 0.1 % of energy | 0.76 | (0.46–1.26)
| | Total 88,563 | | | | p = 0.8‡
| Pooled men and women | 1 | NR | NR | 1
| | 2 | NR | NR | 0.71 | (0.49–1.02)
| | 3 | NR | NR | 0.86 | (0.61–1.21)
| | 4 | NR | NR | 0.86 | (0.61–1.20)
| | 5 | NR | NR | 0.84 | (0.60–1.18)
| | Total 135,894 | | | | | p = 0.8‡

* NR = Not Reported;

>† Number of people included in analysis;

‡ test for trend.

§ Core variables = Age of child, sex, maternal age at menarche, maternal age at delivery, maternal chronic disease, previous spontaneous abortion, persistent vomiting during index pregnancy, multiple pregnancy, number of obstetric visits, timing of membrane rupture, use of general anesthesia, mode of delivery, abnormal placenta, head circumference, evident congenital malformation, place of deliver, use of Fe during pregnancy, intention al physical exercise during pregnancy, painless delivery classes.

Evidence Table C.4.1 Part A. Evidence table of the effects of omega-3 fatty acids on the progression of multiple sclerosis in clinical trials.*

First Author, Year | Study Characteristics | Study Design Duration | Eligibility criteria | Concurrent Disease Condition Medication | Arm | Interventions Dosage/Duration
Bates, 1989^40^ | Sample size (people/person years): 312/NR | Design: RCT | Inclusion: MS defined by specific criteria/Acute relapsing/Kurtzke Disability Scale=6 | Vitamin E, N6 polyunsaturated fat, Dodecylgallate | 1 | Intervention: Olive oil
| Age (mean/range): 34/16–35 | Duration: 24 months | Exclusion: Chronic disease history | | | Dosage: 10 grams/day for 24 months
| Race: NR | | | | 2 | Intervention: Max EPA
| % male: 32 | | | | | Dosage: 10 grams/day for 24 months
| # sites: 3
| Location: UK
Cendrowski, 1986^62^ | Sample size (people/person years): 12/NR | Design: Single arm open label trial | Inclusion: MS defined by specific criteria | None | 1 | Intervention: w-3 and w-6 polyunsaturated fatty acids (MaxEPA)
| Age (mean/range): NR/33–64 | Duration: Variable months | Exclusion: NR | | | Dosage: 20–30 ml/day
| Race: NR
| % male: 50
| # sites: 1
| Location: UK
Nordvik, 2000^63^ | Sample size (people/person years): 16/NR | Design: Single arm open label trial | Inclusion: Relapsing/remitting MS/Stable neurological status | None | 1 | Intervention: Long-chain marine fatty acids and vitamins
| Age (mean/range): 32/22–37 | Duration: 2 years | Exclusion: Immunosuppressive medications use/Vitamins use/Fish supplements/Steroids use/Change in diet | | | Dosage: 0.9 g/day
| Race: NR
| % male: 35
| # sites: 1
| Location: Norway

* NR = not reported.

Evidence Table C.4.1 Part B. Evidence table of the effects of omega-3 fatty acids on the progression of multiple sclerosis in clinical trials.*

First Author, Year | Outcomes | Quality
| Results | Applicability
| | Funding Source
Bates, 1989^40^ | Outcome 1: Kurtzke Disability Scale scores | Quality
| Arm 1 = Olive oil 10 grams/day for 24 months | Jadad: 3
| Arm 2 =Max EPA 10 grams/day for 24 months | Concealment of Allocation: NR
| Reported testing: p = 0.07 (not statistically significant) for comparison between groups | Applicability: II-B
| Outcome 2: Duration and number of relapses | Funding Source: Private
| Arm 1 = Olive oil 10 grams/day for 24 months
| Arm 2 =Max EPA 10 grams/day for 24 months
| Reported testing: Not statistically significant for comparison between groups; statistics not reported
| Outcome 3: Fatty acid analysis
| Arm 1 = Olive oil 10 grams/day for 24 months
| Arm 2 =Max EPA 10 grams/day for 24 months
| Reported testing: Significant increases in EPA and DHA in arm 2 subjects in comparison with controls (arm 1) but point estimates not reported.
Cendrowski, 1986^62^ | Outcome 1:Mean EDSS Scores† | Quality
| Arm 1: MaxEPA (4..2 g/day EPA; 2.8 g/day DHA) | Comparison groups: None
| Reported testing: p<0.05 significant for reduction on EDSS | Blinding: NR
| Outcome 2: Mean Progression Index | Description of withdrawals/dropouts: NR
| Arm 1: MaxEPA (4..2 g/day EPA; 2.8 g/day DHA) | Applicability: II-B
| Reported testing: p<0.05 significant for improvement on index of disease progression | Funding Source: NR
Nordvik, 2000^63^ | Outcome 1:Mean EDSS Scores† | Quality
| Arm 1: Fish oil supplement (0.4 g/day EPA; 05 g/day DHA) | Comparison groups: None
| Reported testing: p<0.05 significant for reduction on EDSS | Blinding: NR
| | Description of withdrawals/dropouts: NR
| | Applicability: II-B
| | Funding Source: Government and Private

* NR = not reported.

† EDSS = Expanded Disability Status Scale.