# Appendix B. Coding/Data Abstraction Forms

## B.1 Literature Screener Form

[image]

[image]

## B.2 Quality Review Form

[image]

[image]

[image]

[image]

[image]

[image]

[image]

[image]

[image]