# Appendix A. Methologic Approach

## Preliminary Research Questions

Table A.1.1 Preliminary research questions

GENERAL QUESTIONS: Questions posed for all three participating EPCs, for years 1 and 2.
1. What is the evidence that variable clinical effects may reflect differences in:
• Serving size (fish vs. dietary supplement);
• Source (fish, food, plant) vs. dietary supplement (fish oil, plant oil);
• Specific type(s) of omega-3 fatty acids (docosahexaenoic acid (DHA), eicosapentaenoic acid (EPA), docosapentaenoic acid (DPA), and alpha-linolenic acid (ALA), fish, fish oil), or the ratio of omega-6/omega-3 fatty acids used;
• Manufacturer (different purity, presence of other potentially active agents)?
2. What is the evidence for adverse events, side effects, or counter-indications associated with omega-3 fatty acids (DHA, EPA, DPA, ALA, fish oil, fish)?
3. What is the evidence that omega-3 fatty acids are associated with adverse events in specific subpopulations such as diabetics?
4. What are the mean and median intakes of DHA, EPA, DPA, ALA, fish, fish oil, omega-6, omega-6/omega-3 ratio in the US population?
5. What is the evidence that omega-3 fatty acids influence overall energy balance?
6. What is the evidence that accurate interpretation of the results of clinical studies is dependent on knowing the absolute fatty acid content of the baseline data, the relative fatty acid content of the baseline diet, or the tissue ratios of fatty acids (omega-6/omega-3) during the investigative period?
DISEASE-SPECIFIC QUESTIONS: questions posed to the SCEPC for Year 2 of the project:
Neurology:
1. What is the evidence that omega-3 fatty acids play a role in maintaining cognitive function with aging?
2. What is the evidence that the level of brain or retinal DHA levels affect the incidence of neurological diseases?

## Technical Expert Panel

The members of our technical expert panel are listed in Table A.2.1. We conducted our TEP meetings via teleconference on December 18, 2003. Dr. Beth Collins-Sharp, the Task Order Officer, and Jacqueline Besteman, Director of the Evidence-Based Practice Center Program, represented AHRQ on these calls; Dr. Anne Thurn, Director of the Evidence-Based Review Program, represented ODS; and Dr. Catherine MacLean, the Task Order Director, and Rena Hasenfeld, the Project Manager, represented the SCEPC. The key comments and recommendations of the TEP are summarized in Table A.2.2. The TEP continued to advise the SCEPC throughout the project via mail, fax, e-mail, and phone calls.

Table A.2.1 Technical expert panel members

Neurology
Name | Area of Expertise | Institution
Alberto Ascherio, M.D., M.P.H., Dr. P.H. | Neurology | Harvard Medical School
Julie Conquer, M.S., Ph.D. | Neurological Disorders/Nutrition | University of Guelph
William S. Harris, PhD | Omega-3 Fatty Acids | University of Missouri-Kansas City School of Medicine
Irwin Rosenberg, M.D. | Nutrition/Aging | Tufts University
Paul Sheehy, Ph.D. | Neurology | National Institute of Neurological Disorders and Stroke
Molly Wagster, Ph.D. | Neurology/Aging | Neuroscience and Neuropsychology of Aging Program

Table A.2.2 Key TEP comments and recommendations

Neurology
1. What is the evidence that omega-3 fatty acids play a role in maintaining cognitive function with aging?
• This question pertains to 1) both maintenance and gains in cognitive functioning with normal aging, and 2) the prevention of dementia..
• The literature primarily includes studies on Alzheimers' disease, but other forms of dementia are also of interest.
• Normative data should be used to measure cognitive function.
• Focus on domains of cognitive function rather than specific tests. Domains of function include 1) general memory, 2) working memory, and 3) executive function.
• Part B of the Trail Making Test and praxis components of the ADAS-Cog are scales that can be used to define normal cognitive function.
• The following instruments can be used to screen for or assess cognitive function in dementia: the Folstein Mini Mental Status Exam, the Alzheimer's Disease Assessment Scale, the Modified Mini-Mental State Examination, and the Telephone Interview of Cognitive Status.
• Look at cognitive domains that are likely to change with aging: executive function, concentration, perceptual/motor processing, verbal learning and memory, verbal and spatial working memory and semantic memory.
• There is no single answer regarding the time frame within which an improvement or decline in cognitive function would occur. Most studies range from 6 months to 1–2 years. To determine the impact of a treatment, you would need to look at the impact over a period of years.
• To determine an effect over time, it may be necessary to look at large observational studies.
• There is more likely to be data on decline over time than on improvement.
• For mild cognitive impairment where there is a significant problem with memory only, look for a change in the conversion rate and at historical cohort studies.
• Look at whether omega-3 fatty acids are both preventing and staving the course of dementia.
• A new set of measurements was published two years ago to assess the rate of change. Do not restrict to these criteria, however, since all of the data should be examined.
• The minimum age limit to assess cognitive function with aging should be 50 years. Other neurological diseases have earlier onset so the age limit should be 45 years for those diseases.
2. What is the evidence that the level of brain or retinal DHA levels affect the incidence of neurological diseases?
• Do not restrict the review to studies that assess brain or retinal levels of DHA.
• Look at brain levels separate from blood levels
• This question is marginal compared to Question #1 and could be limited.
• The mechanisms that affect DHA levels are unknown.
• It would be helpful to have data on blood levels to show the link between dietary intake of omega-3 fatty acids and blood levels.
• If a study doesn't report blood levels, it should not be included.
• The accuracy of dietary intake data is not as effective as blood levels, but dietary intake studies should not be excluded.
• It is critical to include information on studies that have negative results.
• For studies that compare supplements versus placebo, it is important to get information on dose effect.
• The evidence available for dementia is disproportionate to other neurological diseases. Other diseases to consider include Attention Deficit Disorder and non-verbal learning disabilities.
• This question is not necessarily restricted to adults.
• Focus on the effects of omega-3 fatty acids on disease incidence rather than on the effects of omega-3 fatty acids on prevalent disease, except for multiple sclerosis. For multiple sclerosis, the effects of omega-3 fatty acids is of interest.
• Revise the key questions as follows:
ο What is the evidence that omega-3 fatty acids play a role in maintaining cognitive function in normal aging?
ο What is the evidence that omega-3 fatty acids affect the incidence of dementia including Alzheimer's disease?
ο What is the evidence that omega-3 fatty acids are effective in the treatment of dementia including Alzheimer's disease?
ο What is the evidence that omega-3 fatty acids affect the incidence of neurological diseases?
ο What is the evidence that omega-3 fatty acids prevent the progression of multiple sclerosis?

## Industry Experts

Table A.3.1 Industry experts that were contacted for data about efficacy of omega-3 fatty acids

Name | Affiliation
Ian Newton | Roche Vitamins
Herb Woolf, PhD | BASF Corporation
Annette Dickinson | Council for Responsible Nutrition

## Figure A.3.1 Letter sent to industry experts

[image]

## Search Strategies

Table A.4.1 Core search strategy

1. exp fatty acids, omega-3/
2. fatty acids, essential/
3. Dietary Fats, Unsaturated/
4. linolenic acids/
5. exp fish oils/
6. (n 3 fatty acid$ or omega 3).tw.
7. docosahexa?noic.tw,hw,rw.
8. eicosapenta?noic.tw,hw,rw.
9. alpha linolenic.tw,hw,rw.
10. (linolenate or cervonic or timnodonic).tw,hw,rw.
11. menhaden oil$.tw,hw,rw.
12. (mediterranean adj diet$).tw.
13. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.
14. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.
15. (fish adj2 oil$).tw.
16. (cod liver oil$ or marine oil$ or marine fat$).tw.
17. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.
18. (fish consumption or fish intake or (fish adj2 diet$)).tw.
19. diet$ fatty acid$.tw.
20. or/1–19
21. dietary fats/
22. (randomized controlled trial or clinical trial or controlled clinical trial or evaluation studies or multicenter study).pt.
23. random$.tw.
24. exp clinical trials/ or evaluation studies/
25. follow-up studies/ or prospective studies/
26. or/22–25
27. 21 and 26
28. (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega).tw.
29. (omega 3 or n 3).mp.
30. (polyunsaturated fat$ or pufa or dha or epa or long chain or longchain or lc$).mp.
31. 29 and 30
32. 20 or 27 or 28 or 31

Table A.4.2 Literature searches by disease category

Neurology
1. exp fatty acids, omega-3/
2. fatty acids, essential/
3. Dietary Fats, Unsaturated/
4. linolenic acids/
5. exp fish oils/
6. (n 3 fatty acid$ or omega 3).tw.
7. docosahexa?noic.tw,hw,rw.
8. eicosapenta?noic.tw,hw,rw.
9. alpha linolenic.tw,hw,rw.
10. (linolenate or cervonic or timnodonic).tw,hw,rw.
11. menhaden oil$.tw,hw,rw.
12. (mediterranean adj diet$).tw.
13. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.
14. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.
15. (fish adj2 oil$).tw.
16. (cod liver oil$ or marine oil$ or marine fat$).tw.
17. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.
18. (fish consumption or fish intake or (fish adj2 diet$)).tw.
19. diet$ fatty acid$.tw.
20. or/1–19
21. dietary fats/
22. (randomized controlled trial or clinical trial or controlled clinical trial or evaluation studies or multicenter study).pt.
23. random$.tw.
24. exp clinical trials/ or evaluation studies/
25. follow-up studies/ or prospective studies/
26. or/22–25
27. 21 and 26
28. exp Aging/
29. Aged/
30. (aging or aged or geriatric$).tw.
31. or/28–30
32. 27 and 31
33. limit 27 to “all aged <65 and over>”
34. 32 or 33
35. exp Nervous System Diseases/
36. Alzheimer Disease/
37. exp Dementia/
38. parkinson disease/ or Parkinson disease, secondary/
39. parkinson disease/ or Parkinson disease, secondary/
40. exp Multiple Sclerosis/
41. exp Guillain-Barre Syndrome/
42. (alzheimer or parkinson or dementia or multiple sclerosis or guillain barre).tw.
43. (neurological disease$ or neurological disorder$).tw.
44. (neurological disease$ or neurological disorder$).tw.
45. exp Optic Nerve Diseases/
46. (myopathy or neuropathy).tw.
47. Cognition Disorders/
48. exp Cognition/
49. (cognition or cognitive).tw.
50. or/35–49
51. 27 and 50
52. exp fatty acids, omega-3/
53. fatty acids, essential/
54. Dietary Fats, Unsaturated/
55. linolenic acids/
56. exp fish oils/
57. (n 3 fatty acid$ or omega 3).tw.
58. docosahexa?noic.tw,hw,rw.
59. eicosapenta?noic.tw,hw,rw.
60. alpha linolenic.tw,hw,rw.
61. (linolenate or cervonic or timnodonic).tw,hw,rw.
62. menhaden oil$.tw,hw,rw.
63. (mediterranean adj diet$).tw.
64. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.
65. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.
66. (fish adj2 oil$).tw.
67. (cod liver oil$ or marine oil$ or marine fat$).tw.
68. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.
69. (fish consumption or fish intake or (fish adj2 diet$)).tw.
70. diet$ fatty acid$.tw.
71. or/52–70
72. dietary fats/
73. (randomized controlled trial or clinical trial or controlled clinical trial or evaluation studies or multicenter study).pt.
74. random$.tw.
75. exp clinical trials/ or evaluation studies/
76. follow-up studies/ or prospective studies/
77. or/73–76
78. 72 and 77
79. (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega).tw.
80. (omega 3 or n 3).mp.
81. (polyunsaturated fat$ or pufa or dha or epa or long chain or longchain or lc$).mp.
82. 80 and 81
83. 71 or 78 or 79 or 82
84. 83 and 50
85. 84 not 51
86. 83 and 31
87. 86 not 34
88. limit 87 to “all aged <65 and over>”

## Inclusion/Exclusion Criteria

Table A.5.1 Inclusion/Exclusion Criteria at Screening Stage for Neurology.*

Assessed the effect of omega-3 fatty acids on neurology
Presented research on human subjects
Reported the results of randomized or controlled clinical trials or controlled clinical trials or case-control trials or case series or prospective cohort studies†
Exclusion criteria: cross-sectional studies, case reports

* Language was not a barrier to inclusion;

† We defined a randomized controlled trial (RCT) as one in which the participants were assigned to one of two (or more) study groups using a process of random allocation (e.g., random number generation, coin flips); we defined a controlled clinical trial (CCT) as one in which participants were either: (1) assigned to one of two (or more) study groups using a quasi-random allocation method (e.g., alternation, date of birth, patient identifier), or (2) possibly assigned to one of two (or more) study groups using a process of random or quasi-random allocation.

## Evidence Grading System

Table A.6.1 Summary Score for Methodologic Quality

Summary Score | Jadad Score | Concealment of Allocation
A | 5 | Performed
B | 5 | Not performed, or Not reported
| 3 or 4 | Performed, Not performed, or Not reported
| 0,1, or 2 | Performed
C | 0, 1, or 2 | Not performed or not reported

Even though a study may focus on a specific target population, limited study size, eligibility criteria and patient recruitment process may result in a narrow population sample that is of limited applicability, even to the target population. To capture this parameter, we categorize studies into the applicability scale described in Table A.6.1.

Table A.6.2 Applicability ratings

Applicability | | Health state
I | Sample is representative of the U.S. population. | A General population. Typical healthy people similar to Americans without known neurological diseases/conditions.
II | Sample is representative of a relevant sub-group of the target population, but not the entire population. For example, a study that is restricted to women or a fish oil study in Japan where the background diet is very different from that of the US would fall into this category. | B Diseased population. Subjects with neurological disease/condition.
III | Sample is representative of a narrow subgroup of subjects only, and not well applicable to other subgroups. For example, a study of oldest old men or a study of a population on highly controlled diet.

## Figure A.6.1 Jadad score of methodologic quality.*

[image]

## External Peer Reviewers

Table A.7.1 Peer Reviewers

Peer Reviewer | Area of Expertise | Affiliation
Judith Ashley, Ph.D., M.S.P.H., R.D. | Nutrition | University of Nevada, Reno
Mona Baumgarten, Ph.D. | Epidemiology | University of Maryland
Graham Colditz, M.D., DR.P.H. | Neurology | Harvard
David Heber, M.D., Ph.D. | Nutrition | UCLA
Martha Clare Morris, Sc.D. | Neurology | Rush Institute for Healthy Aging
Lon Schneider, M.D. | Geriatric Psychiatry/Clinical Neuroscience | University of Southern California
Philip A. Wolf, M.D. | Neurology | Boston University
Christina Wolfson Ph.D. | Neurology | McGill University