# Appendixes

Appendix A. Methologic Approach

Appendix B. Coding/Data Abstraction Forms

Appendix C. Evidence Tables