# Acronyms

AA | Arachidonic acid | n-3 | Omega-3
Ab | Antibody | n-6 | Omega-6
AHRQ | Agency for Healthcare Research and Quality | NA | Not applicable
AI | Adequate intake | NHANES III | The Third National Health and Nutrition Examination
ALA | Alpha-linolenic acid | NCI | National Cancer Institute
AMDR | Acceptable macronutrient distribution ranges | NEI | National Eye Institute
ANCOVA | Analysis of covariance | NEMC | New England Medical Center
ANOVA | Analysis of variance | NHANES | National Health and Nutrition Examination
Ca | Calcium | NHLBI | National Heart, Lung and Blood Institute
CCT | Controlled clinical trial | NIAAA | National Institute of Alcohol Abuse and Alcoholism
CI | Confidence interval | NIAID | National Institute of Allergy and Infectious Diseases
CRP | C-reactive protein | NIAMS | National Institute of Arthritis and Musculoskeletal and Skin Diseases
CSFII | Continuing Food Survey of Intakes by Individuals | NICHD | National Institute of Child Health and Human Development
d | day | NIDDK | National Institute of Diabetes and Digestive and Kidney Diseases
D6D | Delta-6 Desaturase | NIH | National Institutes of Health
DGLA | Dihomo-gamma-linolenic acid | NNH | Number needed to harm
DHA | Docosahexaenoic acid | NR | Not reported
DPA | Docosapentaenoic acid | ODS | Office of Dietary Supplements
DRI | Dietary Reference Intake | PG | Prostaglandin
Ds-DNA | Double-stranded DNA | PGD | Prostaglandin-D
EF | Effect size | PGE | Prostaglandin-E
EFA | Essential fatty acid | PGF | Prostaglandin-F
EPA | Eicosapentaenoic acid | PGL | Prostaglandin-L
EPC | Evidence-Based Practice Center | PGH | Prostaglandin-H
ESR | Erythrocyte sedimentation rate | PUFA | Polyunsaturated fatty acid
FNB | Food and Nutrition Board | QRF | Quality review form
g | grams | RCT | Randomized controlled trial
GLA | Gamma-linolenic acid | RDA | Recommended daily allowances
HDL | High density lipoprotein | RXT | Randomized crossover trial
IL-1β | Interleukin 1β | Sd | Standard deviation
IOM | Institute of Medicine | SCEPC | Southern California Evidence-Based Practice Center
LA | Linoleic acid | SLE | Systemic lupus erythematosus
LC PUFA | Long-chain polyunsaturated fatty acid | SEM | Standard errors of the means
LDL | Low density lipoprotein | TEP | Technical expert panel
MA | Metaanalysis | TNF-a | Tumor necrosis factor-a
MANOVA | Multivariate analysis of variance | TX | Treatment
MeSH Term | Medical Subject Headings Term | TXA | Thromboxane-A
mg/dl | Milligrams per deciliter | UCLA | University of California, Los Angeles
min | Minutes | VLCFA | Very long chain fatty acid
Mo | Month | VLN-3FA | Very long chain n-3 fatty acids
n | Number | wk | Week