# Listing of Excluded Studies

### Tumor Incidence and Treatment

### Rejected: Search Unsuccessful (n = 28)

1 Amaral T, Almeida MDV de, Barros H, de Almeida MDV, Riboli E (ed.), Lambert R. Diet and post menopausal breast cancer in Portugal. Nutrition-and-Lifestyle:-Opportunities-for-Cancer-Prevention.-European-Conference-on-Nutrition-and-Cancer-Held-in-Lyon,-France-on-21–24-June,-2003. 2002, 297–299; 5 Ref.
2 Anonymous. EPA helps cancer patients gain weight. Pharmaceutical Journal 2001; 267(7172):636.
3 Anonymous. Flaxseed provides protection against postmenopausal breast cancer. Pharmaceutical Journal 2001; 267(7163):284.
4 Bennink M R. Soybean in the prevention and treatment of cancer. I Simposio Brasileiro Sobre Os Beneficios Da Soja Para a Saude Humana, 27–18 April 2001, Londrina, PR, Brazil. Documentos-Embrapa-Soja. 2001;No.169:24-27. 25 Ref.
5 Chaj A[spacing diaeresis]s V, Bougnoux P. Omega-6/omega-3 polyunsaturated fatty acid ratio and cancer. World Review of Nutrition & Dietetics. 92:133–51, 2003.
6 Cunnane S (ed.), Thompson LU. Flaxseed in human nutrition. 1995, x + 384 Pp.
7 Dayton S, Pearce M, Hashimoto S, Dixon W, Tomiyasu U. Circulation 1969; 40(supp II).
8 Downs S, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. 1998;52:377-84. [pmid: 9764259].
9 Flynn M A T. Dietary fat and chronic diseases. Bahrain Medical Bulletin. 1998;20(3):77-80.
10 Gaard M, Tretli S, Loken E B. Dietary factors and risk of colon cancer: a prospective study of 50,535 young Norwegian men and women. Eur. 1996;5(6):445-54.
11 Hong S, Gronert K, Devchand P R, Moussignac R L, Serhan C N. Novel docosatrienes and 17S-resolvins generated from docosahexaenoic acid in murine brain, human blood, and glial cells. Autacoids in anti-inflammation. J Biol Chem. 2003;278(17):14677-87. [pmid: 12590139].
12 Key T J, Allen N E. Nutrition and breast cancer. Breast. 2001;10(Supplement 3):9-13. 48 ref.
13 Krumwiede K H. Malnutrition in tumor patients - Possibilities and limits of oral alimentation. MMW Fortschritte Der Medizin. 2003;145(11):35-8. [pmid: 12688193].
14 Lund E, Riboli E (ed.), Lambert R. Fish and cancer. Nutrition-and-Lifestyle:-Opportunities-for-Cancer-Prevention.-European-Conference-on-Nutrition-and-Cancer-Held-in-Lyon,-France-on-21–24-June,-2003. 2002, 187–189; 23 Ref.
15 McEntee M, Whelan J. The role of arachidonate and prostaglandins in colorectal carcinogenesis -- the case for NSAIDs and fish oil. Veterinary-Cancer-Society-Newsletter. 2001;25(2):8-9.
16 Meydani SN (ed.), Ansari AA. Conference on nutrition and immunity, Atlanta, Georgia, USA, May 5–7 1997. Nutrition-Reviews 1998; 56(1):2, S1–S186; many ref.
17 Muir AD, Westcott ND, Muir AD (ed.), Westcott ND. Flax:-the-Genus-Linum. 2003, Xii + 307 Pp.; Many Ref.
18 Nelson GJ. Health effects of dietary fatty acids. 1991, Vii + 274 Pp.
19 Prentice R L, Sheppard L. Dietary fat and cancer: consistency of the epidemiologic data, and disease prevention that may follow from a practical reduction in fat consumption. Cancer. 1990;1(1):81-97. discussion 99–109.
20 Sanders T, Emery P, Saunders T (ed.), Emery P. Molecular-Basis-of-Human-Nutrition. 2003, x + 165 Pp.
21 Saunders L, Soomro G, Buckingham J, Jamtvedt G, Raina P. Assessing the methodological quality of nonrandomized intervention studies. Western Journal of Nursing Research. 2003;25:223-37. [pmid: 12666645].
22 Seventh-day Adventist Church. Available at www.adventist.org.
23 Seventh-day Adventist Church. Available atwww.religioustolerance.org/sda.htm.
24 Shibamoto T, Terao J, Osawa T. Functional foods for disease prevention I. Fruits, vegetables, and teas. Symposium sponsored by the Division of Agricultural and Food Chemistry at the 213th National Meeting of the American Chemical Society, San Francisco, California, USA, April 13–17, 1997. 1998, 253 Pp.
25 Stampfer M, Willett W, Colditz G, Speizer F. Intake of cholesterol, fish and specific types of fat in relation to risk of breast cancer. In: Proceedings of the AOCS Short Course on Polyunsaturated Fatty Acids and Eicosanoids 1987; Biloxi, Mississippi(Lands, WE (ed)):248–52.
26 Stillwell W. Docosahexaenoic acid and membrane lipid domains. Current Organic Chemistry. 2000;4(11):1169-83.
27 USA AIfCR. Dietary fat and cancer genetic and molecular interactions. 1997, Xvi+252 Pp.; Advances in Experimental Medicine and Biology; Vol. 422.
28 Willett WC, Bendich A (ed.), Deckelbaum RJ. Potential benefits of preventive nutrition strategies: lessons for the United States. Preventive-Nutrition:-the-Comprehensive-Guide-for-Health-Professionals. 2001, Ed.2, 447–464; 181 Ref.

### Rejected Subject (n = 43)

1 American Dietetic A, Dietitians of C. Position of the American Dietetic Association and Dietitians of Canada: vegetarian diets. Canadian Journal of Dietetic Practice & Research. 2003;64(2):62-81. [pmid: 12826028].
2 Amiano P, Dorronsoro M, Larranaga N et al. Very-long-chain omega-3 fatty acids as markers for habitual fish intake in Spain. Nutrition-and-Lifestyle:-Opportunities-for-Cancer-Prevention.-European-Conference-on-Nutrition-and-Cancer-Held-in-Lyon,-France-on-21–24-June,-2003. 2002, 201–202; 5 Ref.
3 Anonymous. Food labeling: health claims and labeling statements; dietary fiber and cancer; antioxidant vitamins and cancer; omega-3 fatty acids and coronary heart disease; folate and neural tube defects; revocation. Food and Drug Administration, HHS. Final rule. Federal Register 2000; 65(192):58917–8.
4 Bartram H P, Gostner A, Scheppach W, et al. Effects of fish oil on fecal bile acid excretion in healthy volunteers. Zeitschrift Fur Ernahrungswissenschaft. 1995;34(3):231-5. [pmid: 7502546].
5 Bates C, Van Dam C, Horrobin D F, et al. Plasma essential fatty acids in pure and mixed race American Indians on and off a diet exceptionally rich in salmon. Prostaglandins Leukotrienes and Medicine. 1985;Vol 17(1):(Pp 77-84).
6 Bates E J. Eicosanoids, fatty acids and neutrophils: Their relevance to the pathophysiology of disease. Prostaglandins Leukotrienes & Essential Fatty Acids. 1995;53(2):75-86.
7 Bell S J, Bradley D, Forse R A, Bistrian B R. The new dietary fats in health and disease, [Review] [37 refs]. Journal of the American Dietetic Association. 1997;97(3):280-6. quiz 287–8. [pmid: 9060945].
8 De Deckere E A M, Korver O, Verschuren P M, Katan M B. Health aspects of fish and n-3 polyunsaturated fatty acids from plant and marine origin. European Journal of Clinical Nutrition. 1998;52(10):749-53. [pmid: 9805223].
9 de Lorgeril M, Renaud S, Mamelle N, et al. Mediterranean alpha-linolenic acid-rich diet in secondary prevention of coronary heart disease. Lancet. 1994;343(8911):1454-9. [pmid: 7911176].
10 De Lorgeril M, Salen P, Martin J L, et al. Effect of a mediterranean type of diet on the rate of cardiovascular complications in patients with coronary artery disease. Insights into the cardioprotective effect of certain nutriments. J. 1996;28(5):1103-8.
11 Elmstahl S, Holmqvist O, Gullberg B, Johansson U, Berglund G. Dietary patterns in high and low consumers of meat in a Swedish cohort study. Appetite. 1999;32(2):191-206. 41 ref. [pmid: 10097025].
12 Endres S, Ghorbani R, Kelley V E, et al. The effect of dietary supplementation with n-3 polyunsaturated fatty acids on the synthesis of interleukin-1 and tumor necrosis factor by mononuclear cells. N Engl J Med. 1989;320(5):265-71. [pmid: 2783477].
13 Gerber M J, Scali J D, Michaud A, et al. Profiles of a healthful diet and its relationship to biomarkers in a population sample from Mediterranean southern France. Journal of the American Dietetic Association. 2000;100(10):1164-71. [pmid: 11043701].
14 Gohlke H. Diet and body weight. Zeitschrift Fur Kardiologie. 2002;91:12-24. [pmid: 12436761].
15 Goodman M, Hankin J, Wilkens L, Kolonel L. Dietary phytoestrogens and the risk of endometrial cancer. Am J Clin Nutr. 1998;68(supp):1531S.
16 Han S N, Leka L S, Lichtenstein A H, Ausman L M, Schaefer E J, Meydani S N. Effect of hydrogenated and saturated, relative to polyunsaturated, fat on immune and inflammatory responses of adults with moderate hypercholesterolemia. Journal of Lipid Research. 2002;43(3):445-52. [pmid: 11893781].
17 Hu F B. The Mediterranean diet and mortality--olive oil and beyond. [comment]. New England Journal of Medicine. 2003;348(26):2595-6. [pmid: 12826632].
18 Hubbard R W, Mejia A, Horning M. The potential of diet to alter disease processes. Nutrition Research. 1994;14(12):1853-95.
19 Koletzko B. Relevance of essential fatty acids in medicine and nutrition. Aktuelle Endokrinologie Und Stoffwechsel. 1986;7(1):18-27.
20 Kudo Y, Falciglia G A, Couch S C. Evolution of meal patterns and food choices of Japanese-American females born in the United States. Eur. 2000;54(8):665-70.
21 Lenn J, Uhl T, Mattacola C, et al. The effects of fish oil and isoflavones on delayed onset muscle soreness. Medicine & Science in Sports & Exercise. 2002;34(10):1605-13. [pmid: 12370562].
22 Meydani M. Nutrition interventions in aging and age-associated disease. [Review] [54 refs]. Annals of the New York Academy of Sciences. 2001;928:226-35. Apr. [pmid: 11795514].
23 Meydani S N, Endres S, Woods M M, et al. Oral (n-3) fatty acid supplementation suppresses cytokine production and lymphocyte proliferation: comparison between young and older women. J. 1991;121(4):547-55.
24 Netherlands W E O N. Abstracts of the 13th meeting of the Netherlands Epidemiological Study Group in Maastricht. Voeding. 1987;48(4):125-33. 17 absts.
25 Phillipson B E, Rothrock D W, Connor W E, Harris W S, Illingworth D R. Reduction of plasma lipids, lipoproteins, and apoproteins by dietary fish oils in patients with hypertriglyceridemia. N Engl J Med. 1985;312(19):1210-6. [pmid: 3990714].
26 Pischon T, Hankinson S E, Hotamisligil G S, Rifai N, Willett W C, Rimm E B. Habitual dietary intake of n-3 and n-6 fatty acids in relation to inflammatory markers among US men and women. Circulation. 2003;108(2):155-60. [pmid: 12821543].
27 Rackett S C, Rothe M J, Grant-Kels J M. Diet and dermatology: The role of dietary manipulation in the prevention and treatment of cutaneous disorders. Journal of the American Academy of Dermatology. 1993;Vol 29(3):(Pp 447-461). [pmid: 8349862].
28 Romieu I, Trenga C. Diet and obstructive lung diseases [Review]. Epidemiologic Reviews. 2001;23(2):268-87. [pmid: 12192737].
29 Simopoulos A P. Omega-3 fatty acids in inflammation and autoimmune diseases. [Review] [100 refs]. Journal of the American College of Nutrition. 2002;21(6):495-505. [pmid: 12480795].
30 Simopoulos A P. Summary of the conference on the health effects of polyunsaturated fatty acids in seafoods. Journal of Nutrition. 1986;116(12):2350-4. [pmid: 3806233].
31 Singh R, Gopalan S, Sibal A. Immunonutrition. [Review] [32 refs]. Indian Journal of Pediatrics. 2002;69(5):417-9. [pmid: 12061676].
32 Stachowska E, Chlubek D, Ciechanowski K. [Review] [30 refs] [Polish]. Polski Merkuriusz Lekarski. 2001;11(63):279-81. [pmid: 11761830].
33 Thies F, Miles E A, Nebe-von-Caron G, et al. Influence of dietary supplementation with long-chain n-3 or n-6 polyunsaturated fatty acids on blood inflammatory cell populations and functions and on plasma soluble adhesion molecules in healthy adults. Lipids. 2001;36(11):1183-93. [pmid: 11795850].
34 Toft A D, Thorn M, Ostrowski K, et al. N-3 polyunsaturated fatty acids do not affect cytokine response to strenuous exercise. Journal of Applied Physiology. 2000;89(6):2401-6. [pmid: 11090595].
35 Tolkachev O N, Zhuchenko A A J. Biologically active substances of flax: Medicinal and nutritional properties: (A review). Pharmaceutical Chemistry Journal (English Translation of Khimiko-Farmatsevticheskii Zhurnal). 2000;34(7):360-7.
36 Trebble T, Arden N K, Stroud M A, et al. Inhibition of tumour necrosis factor-alpha and interleukin 6 production by mononuclear cells following dietary fish-oil supplementation in healthy men and response to antioxidant co-supplementation. British Journal of Nutrition. 2003;90(2):405-12. [pmid: 12908901].
37 Ursin G, Ziegler R G, Subar A F, Graubard B I, Haile R W, Hoover R. Dietary patterns associated with a low-fat diet in the national health examination follow-up study: identification of potential confounders for epidemiologic analyses. [comment]. American Journal of Epidemiology. 1993;137(8):916-27. [pmid: 8484383].
38 Vysotskii VG, Zilova IS. Role of soybean proteins in human nutrition [Review][45 refs][Russian]. Voprosy Pitaniia 1995; (5):20–7.
39 Wallace F A, Miles E A, Calder P C. Comparison of the effects of linseed oil and different doses of fish oil on mononuclear cell function in healthy human subjects. British Journal of Nutrition. 2003;89(5):679-89. [pmid: 12720588].
40 Wallstrom P, Elmstahl S, Johansson U, Ostergren P O, Hanson B S. Usage and users of natural remedies in a middle-aged population: Demographic and psychosocial characteristics. Results from the Malmo Diet and Cancer Study. Pharmacoepidemiology & Drug Safety. 1996;5(5):303-14. [pmid: 15073816].
41 Watkins B A, Li Y, Seifert M F. Dietary omega-3 fatty acids and bone health. Current Organic Chemistry. 2000;4(11):1125-44.
42 Weber P C. n-3 Fatty acids and human disease. Scandinavian Journal of Clinical and Laboratory Investigation Supplement. 1990;50(202):14-9. [pmid: 2075429].
43 Welch A A, Lund E, Amiano P, Dorronsoro M. EPIC Working Group on Dietary P. Variability in fish consumption in 10 European countries. IARC Scientific Publications. 2002;156:221-2. [pmid: 12484172].

### Rejected Topic (n = 285)

1 Diet and breast cancer: the cure may be in milk. Revue-Laitiere-Francaise. 1995, No. 546, 13.
2 Adami H O, Wolk A. [Swedish]. Lakartidningen. 1996;93(7):557-8. [pmid: 8642914].
3 Adami H O, Wolk A. Relationship between fat intake and breast cancer. Nordisk-Medicin. 1996;111(5):145-50. 20 ref.
4 Adlercreutz H. Phytoestrogens: epidemiology and a possible role in cancer protection. [Review]. Environmental Health Perspectives. 1995;103(Suppl 7):103-12. Oct. [pmid: 8593855].
5 Akaza H, Miyanaga N, Takashima N, et al. Is daidzein non-metabolizer a high risk for prostate cancer? A case-controlled study of serum soybean isoflavone concentration. Japanese Journal of Clinical Oncology. 2002;32(8):296-300. [pmid: 12411567].
6 Alarcon de la Lastra C, Barranco M D, Motilva V, Herrerias J M. Mediterranean diet and health: biological importance of olive oil. [Review] [120 refs]. Current Pharmaceutical Design. 2001;7(10):933-50. [pmid: 11472248].
7 Anonymous. Editorial: Are PUFA harmful? British Medical Journal 1973; 4(5883):1–2.
8 Anonymous. Fruit and vegetable are the best protectors against cancer. Arztezeitschrift Fur Naturheilverfahren 2001; 42(3):153–4.
9 Anonymous. n-3 polyunsaturated fatty acids, interleukin-1, and tumor necrosis factor. [comment]. New England Journal of Medicine 1989; 321(1):55–6.
10 Anonymous. Prospective “decades long” studies needed to settle dietary fat/breast cancer risk controversy. Oncology (Huntington) 1994; 8(3):89–90.
11 Ansari M S. Prostate cancer and nutritional issues. Indian-Journal-of-Nutrition-and-Dietetics. 2002;39(5):237-44. 35 ref.
12 Bachmann GA. Nonhormonal alternatives for the management of early menopause in younger women with breast cancer. [Review][107 refs]. Journal of the National Cancer Institute. Monographs 1994; (16):161–7.
13 Ballard-Barbash R, Forman M R, Kipnis V. Dietary fat, serum estrogen levels, and breast cancer risk: a multifaceted story. J. 1999;91(6):492-4.
14 Ballmer P E. [German]. Therapeutische Umschau. 2000;57(3):167-72. [pmid: 10756697].
15 Bander E V, Freudenheim J L, Marshall J R, et al. Diet and alcohol consumption and lung cancer risk in the New York State Cohort (United states). Cancer Causes & Control. 1997;8(6):828-40. [pmid: 9427425].
16 Barnard N D, Nicholson A. Beliefs about dietary factors in breast cancer prevention among American women, 1991 to 1995. Preventive Medicine. 1997;26(1):109-13. [pmid: 9010905].
17 Bartsch H, Nair J, Owen R W. Exocyclic DNA adducts as oxidative stress markers in colon carcinogenesis: potential role of lipid peroxidation, dietary fat and antioxidants. [Review] [41 refs]. Biological Chemistry. 2002;383(6):915-21. [pmid: 12222681].
18 Beardshall K, Frost G, Morarji Y, Domin J, Bloom S R, Calam J. Saturation of fat and cholecystokinin release: implications for pancreatic carcinogenesis. [comment]. Lancet. 1989;2(8670):1008-10. [pmid: 2572741].
19 Belury M A. Dietary conjugated linoleic acid in health: physiological effects and mechanisms of action. [Review]. Annual Review of Nutrition. 2002;22:505-31. [pmid: 12055356].
20 Beno I. Gastric carcinoma and nutrition. 2. Diet and carcinogenesis. Ceskoslovenska-Gastroenterolgie-a-Vyziva. 1992;46(6):417-23. 50 ref.
21 Berrino F, Muti P. Mediterranean diet and cancer. European Journal of Clinical Nutrition. 1989;43(SUPPL. 2):49-55. [pmid: 2557204].
22 Bingham S A, Luben R, Welch A, et al. Are imprecise methods obscuring a relation between fat and breast cancer?. Lancet-British-Edition. 2003;362(9379):212-4. 5 ref.
23 Black H S. Influence of dietary factors on actinically-induced skin cancer. [Review] [31 refs]. Mutation Research. 1998;422(1):185-90. [pmid: 9920444].
24 Black H S, Herd J A, Goldberg L H, et al. Effect of a low-fat diet on the incidence of actinic keratosis. New England Journal of Medicine. 1994;330(18):1272-5. [pmid: 8145782].
25 Black H S, Thornby J I, Wolf J E Jr, et al. Evidence that a low-fat diet reduces the occurrence of non-melanoma skin cancer. International Journal of Cancer. 1995;62(2):165-9.
26 Blackburn G L, Copeland T, Khaodhiar L, Buckley R B. Diet and breast cancer. Journal of Women's Health. 2003;12(2):183-92.
27 Bosetti C, Altieri A, La Vecchia C. Diet and environmental carcinogenesis in breast/gynaecological cancers. Current Opinion in Obstetrics & Gynecology. 2002;14(1):13-8. [pmid: 11801871].
28 Bosetti C, Gallus S, Trichopoulou A, et al. Influence of the Mediterranean diet on the risk of cancers of the upper aerodigestive tract. Cancer Epidemiology, Biomarkers & Prevention. 2003;12(10):1091-4.
29 Bosetti C, Tzonou A, Lagiou P, Negri E, Trichopoulos D, Hsieh C C. Fraction of prostate cancer incidence attributed to diet in Athens, Greece. European-Journal-of-Cancer-Prevention. 2000;9(2):119-23. 24 ref. [pmid: 10830579].
30 Bostick R M, Potter J D, Fosdick L, et al. Calcium and colorectal epithelial cell proliferation: a preliminary randomized, double-blinded, placebo-controlled clinical trial. Journal of the National Cancer Institute. 1993;85(2):132-41. [pmid: 8418302].
31 Boyd N F, Cousins M, Kriukov V. A randomized controlled trial of dietary fat reduction: the retention of subjects and characteristics of drop outs. Journal of Clinical Epidemiology. 1992;45(1):31-8. [pmid: 1738009].
32 Boyd N F, Greenberg C, Lockwood G, et al. Effects at two years of a low-fat, high-carbohydrate diet on radiologic features of the breast: results from a randomized trial. Canadian Diet and Breast Cancer Prevention Study Group. [comment]. Journal of the National Cancer Institute. 1997;89(7):488-96. [pmid: 9086005].
33 Boyd N F, Cousins M, Lockwood G, Tritchler D. The feasibility of testing experimentally the dietary fat-breast cancer hypothesis. British-Journal-of-Cancer. 1990;62(6):878-81. 35 ref. [pmid: 2257214].
34 Brisson GJ, Serrano Rios M (ed.), Sastre A (ed.), Perez Juez MA (ed.), Estrala A (ed.), Sebastian C de. Fatty acids, cis and trans: a metabolic enigma - role in disease causation. Dairy Products in Human Health and Nutrition. Proceedings of the 1st World Congress, Madrid, Spain, 7–10 June 1993. 1994, 255–261; 74 Ref.
35 Britton J A, Westhoff C, Howe G, Gammon M D. Diet and benign ovarian tumors (United States). Cancer Causes & Control. 2000;11(5):389-401. [pmid: 10877332].
36 Brown J K. A systematic review of the evidence on symptom management of cancer-related anorexia and cachexia. Oncol. 2002;29(3):517-32.
37 Buist R A. Malignant melanoma and dietary polyunsaturated fats. International-Clinical-Nutrition-Review. 1988;8(2):53-4. 9 ref.
38 Butrum RR, Dickson J, Butrum RR (ed.), Dickson J. The role of nutrition in preventing and treating breast and prostate cancer. Proceedings of the American Institute for Cancer Research 10th Annual Research Conference, Washington, DC, USA, 31 August-1 September 2000. Journal-of-Nutrition 2001; 131(1):151S–203S.
39 Byar D P, Freedman L S. Clinical trials in diet and cancer. Preventive Medicine. 1989;18(2):203-19. [pmid: 2740291].
40 Byers T. Nutritional risk factors for breast cancer. [Review] [100 refs]. Cancer. 1994;74(1 Suppl):288-95. [pmid: 8004599].
41 Byrne C, Rockett H, Holmes M D. Dietary fat, fat subtypes, and breast cancer risk: lack of an association among postmenopausal women with no history of benign breast disease. Cancer Epidemiology, Biomarkers & Prevention. 2002;11(3):261-5.
42 Byrne C, Ursin G, Ziegler R G. A comparison of food habit and food frequency data as predictors of breast cancer in the NHANES I/NHEFS cohort. Journal of Nutrition. 1996;126(11):2757-64. [pmid: 8914946].
43 Cade J, Thomas E, Vail A. Case-control study of breast cancer in south east England: nutritional factors. Journal of Epidemiology & Community Health. 1998;52(2):105-10. [pmid: 9578857].
44 Cambie RC, Ferguson LR. Potential functional foods in the traditional Maori diet. Mutation Research. 523–524:109–17, 2003 Feb-Mar.
45 Chlebowski R T. Breast cancer risk reduction: Strategies for women at increased risk. Annual Review of Medicine. 2002;Vol 53:(Pp 519-540). [pmid: 11818488].
46 Chlebowski R T, Grosvenor M. The scope of nutrition intervention trials with cancer-related endpoints. Cancer. 1994;74(9 SUPPL.):2734-8. [pmid: 7954294].
47 Clifford C K, Butrum R R, Greenwald P, Yates J W. Clinical trials of low fat diets and breast cancer prevention. [Review] [57 refs]. Progress in Clinical & Biological Research. 1986;222:93-115. [pmid: 3097662].
48 Clinton S K, Beck M A, et al. Diet, anthropometry and breast cancer: integration of experimental and epidemiologic approaches. American Society for Nutritional Sciences Annual Meeting. 1997;127(5SUPPL):916S-20S. 25 ref.
49 Cohen L A, Wu A H, Stram D O, Pike M C. Re: Meta-analysis: Dietary fat intake, serum estrogen levels, and the risk of breast cancer [3] (multiple letters). Journal of the National Cancer Institute. 2000;Vol 92(1):(Pp 78). Date of Publication: 05 JAN 2000. [pmid: 10620640].
50 Cohen L A, Thompson D O, Choi K, Karmali R A, Rose D P. Dietary fat and mammary cancer. 2. Modulation of serum and tumor lipid composition and tumor prostaglandins by different dietary fats: association with tumour incidence patterns. Journal-of-the-National-Cancer-Institute. 1986;77(1):43-51. 58 ref. [pmid: 3459925].
51 Comstock GW, Helzlsouer KJ, Bendich A (ed.), Deckelbaum RJ. Preventive nutrition and lung cancer. Preventive-Nutrition:-the-Comprehensive-Guide-for-Health-Professionals. 2001, Ed.2, 97–129; 122 Ref.
52 Conrath S M. The use of epidemiology, scientific data, and regulatory authority to determine risk factors in cancers of some organs of the digestive system. 6. Pancreatic cancer. Regulatory Toxicology & Pharmacology. 1986;6(3):193-210. [pmid: 3775080].
53 Cottrell R. Dietary patterns and cancer. Ann Nutr Metab. 1991;35(supp 1):98-102. [pmid: 1888135].
54 D'Amicis A, Farchi S. Olive oil consumption and cancer mortality in Italy. A correlation study. Advances in Experimental Medicine & Biology. 1999;472:67-71. [pmid: 10736617].
55 D'Avanzo B, Negri E, Gramenzi A, et al. Fats in seasoning and breast cancer risk: an Italian case-control study. European Journal of Cancer. 1991;27(4):420-3. [pmid: 1828170].
56 Dagnelie P C. [Review] [23 refs] [Dutch]. Nederlands Tijdschrift Voor Geneeskunde. 2003;147(27):1308-13. [pmid: 12868158].
57 Das U N. Nutrients, essential fatty acids and prostaglandins interact to augment immune responses and prevent genetic damage and cancer. [Review] [81 refs]. Nutrition. 1989;5(2):106-10. [pmid: 2520267].
58 Das U N, Prasad V V, Reddy D R. Local application of gamma-linolenic acid in the treatment of human gliomas. Cancer. 1995;94(2):147-55.
59 de Lorenzo A, Andreoli A, Sorge R P, et al. Modification of dietary habits (Mediterranean diet) and cancer mortality in a southern Italian village from 1960 to 1996. Annals of the New York Academy of Sciences. 1999;889:224-9. [pmid: 10668497].
60 De Stefani E, Mendilaharsu M, Deneo Pellegrini H, Ronco A, de Stefani E. Influence of dietary levels of fat, cholesterol, and calcium on colorectal cancer. Nutrition-and-Cancer. 1997;29(1):83-9. 30 ref. [pmid: 9383789].
61 Demark Wahnefried W, Clipp E C, McBride C, et al. Design of FRESH START: a randomized trial of exercise and diet among cancer survivors. Medicine-and-Science-in-Sports-and-Exercise. 2003;35(3):415-24. 32 ref. [pmid: 12618570].
62 Denis L, Morton M S, Griffiths K. Diet and its preventive role in prostatic disease. [Review] [87 refs]. European Urology. 1999;35(56):377-87. [pmid: 10325492].
63 DeWys W D, Malone W F, Butrum R R, Sestili M A. Clinical trials in cancer prevention. Cancer. 1986;58(8 Suppl):1954-62. [pmid: 3756815].
64 Djuric Z, Poore K M, Depper J B, et al. Methods to increase fruit and vegetable intake with and without a decrease in fat intake: compliance and effects on body weight in the nutrition and breast health study. Nutrition & Cancer. 2002;43(2):141-51. [pmid: 12588694].
65 Djuric Z, Uhley V E, Depper J B, Brooks K M, Lababidi S, Heilbrun L K. A clinical trial to selectively change dietary fat and/or energy intake in women: the Women's Diet Study. Nutrition & Cancer. 1999;34(1):27-35. [pmid: 10453438].
66 Dokkum W van, Boer BCJ de, Faassen A van, Pikaar NA, Hermus RJJ. Diet, faecal pH and colorectal cancer. British-Journal-of-Cancer 1983; 48(1):109–10; 6 ref.
67 Doll R. The use of meta-analysis in epidemiology: diet and cancers of the breast and colon. Nutrition Reviews. 1994;52(7):233-7. [pmid: 8090374].
68 Dragsted L O, Strube M, Larsen J C. Cancer-protective factors in fruits and vegetables: Biochemical and biological background. Pharmacology & Toxicology, Supplement. 1993;72(1):116-35.
69 Drasar B S, Jenkins D J. Bacteria, diet, and large bowel cancer. American Journal of Clinical Nutrition. 1976;29(12):1410-6. [pmid: 998551].
70 Dworkin R H, Bates D, Millar J H, Paty D W. Linoleic acid and multiple sclerosis: a reanalysis of three double-blind trials. Neurology. 1984;34(11):1441-5. [pmid: 6387534].
71 Ekwere P D, Egbe S N. The changing pattern of prostate cancer in Nigerians: current status in the southeastern states. Journal of the National Medical Association. 2002;94(7):619-27. [pmid: 12126288].
72 Elmadfa I, Park E. Impact of diets with corn oil or olive/sunflower oils on DNA damage in healthy young men. European Journal of Nutrition. 1999;38(6):286-92. [pmid: 10784385].
73 Enig M G, Munn R J, Keeney M. Dietary fat and cancer trends - a critique. Feedstuffs,-USA. 1979;51(6):36-8. 45 ref.
74 Favero A, Parpinel M, Montella M. Energy sources and risk of cancer of the breast and colon-rectum in Italy. Adv Exp Med Biol. 1999;472:51-5. [pmid: 10736615].
75 Fearon K C, Falconer J S, Ross J A, et al. An open-label phase I/II dose escalation study of the treatment of pancreatic cancer using lithium gammalinolenate. Anticancer. 1996;16(2):867-74.
76 Ferro-Luzzi A, Ghiselli A. Protective aspects of the Mediterranean diet. [Review] [45 refs]. Advances in Experimental Medicine & Biology. 1993;348:137-44. [pmid: 8172016].
77 Field E J, Joyce G. Multiple sclerosis: effect of gamma linolenate administration upon membranes and the need for extended clinical trials of unsaturated fatty acids. Eur Neurol. 1983;22(1):78-83. [pmid: 6301844].
78 Fitzgibbon M L, Gapstur S M, Knight S J. Mujeres Felices por ser Saludables: A breast cancer risk reduction program for Latino women. Preventive Medicine. 2003;36(5):536-46. [pmid: 12689798].
79 Fortes C, Forastiere F, Anatra F, Schmid G. Re: Consumption of olive oil and specific food groups in relation to breast cancer risk in Greece. [comment]. Journal of the National Cancer Institute. 1995;87(13):1020-1. author reply 1022. [pmid: 7629873].
80 Franceschi S, Russo A, Vecchia C la, la Vecchia C. Carbohydrates, fat and cancer of the breast and colon-rectum. Journal-of-Epidemiology-and-Biostatistics 1998; 3(2):217–8; 8 ref.
81 Franceschi S, Vecchia C la, Russo A et al. Macronutrient intake and risk of colorectal cancer in Italy. International-Journal-of-Cancer 1998; 76(3):321–4; 27 ref.
82 Franke A A, Custer L J. Daidzein and genistein concentrations in human milk after soy consumption. [comment]. Clinical Chemistry. 1996;42(6 Pt 1):955-64. [pmid: 8665689].
83 Freeman V L, Meydani M, Yong S, et al. Assessing the effect of fatty acids on prostate carcinogenesis in humans: does self-reported dietary intake rank prostatic exposure correctly?. American Journal of Clinical Nutrition. 2001;73(4):815-20. [pmid: 11273858].
84 Gaard M, Tretli S, Loken E B. Dietary fat and the risk of breast cancer: a prospective study of 25,892 Norwegian women. International Journal of Cancer. 1995;63(1):13-7.
85 Gadducci A, Cosio S, Fanucchi A, Genazzani A R. Malnutrition and cachexia in ovarian cancer patients: pathophysiology and management. [Review] [92 refs]. Anticancer Research. 2001;21(4B):2941-7. [pmid: 11712791].
86 Gao Y T, Blot W J, Zheng W, et al. Lung cancer among Chinese women. International Journal of Cancer. 1987;40(5):604-9.
87 Gerber B. Personal lifestyle and risk of breast cancer. Journal Fur Menopause. 2003;10(3):13-20.
88 Gerber M, Richardson S. Re: Consumption of olive oil and specific food groups in relation to breast cancer risk in Greece. [comment]. Journal of the National Cancer Institute. 1995;87(13):1021-2. [pmid: 7629874].
89 Ghafar M A, Golliday E, Bingham J, Mansukhani M M, Anastasiadis A G, Katz A E. Regression of prostate cancer following administration of Genistein Combined Polysaccharide (GCP), a nutritional supplement: a case report. Journal of Alternative & Complementary Medicine. 2002;8(4):493-7.
90 Giovannucci E. Diet, body weight, and colorectal cancer: A summary of the epidemiologic evidence. Journal of Women's Health. 2003;12(2):173-82.
91 Giovannucci E, Rimm E B, Liu Y, Stampfer M J, Willett W C. A prospective study of tomato products, lycopene, and prostate cancer risk. Journal of the National Cancer Institute. 2002;94(5):391-8. [pmid: 11880478].
92 Giovannucci E, Stampfer M J, Colditz G, Rimm E B, Willett W C. Relationship of diet to risk of colorectal adenoma in men. [comment]. Journal of the National Cancer Institute. 1992;84(2):91-8. [pmid: 1310511].
93 Giovannucci E, Stampfer M J, Colditz G A, et al. A comparison of prospective and retrospective assessments of diet in the study of breast cancer. [comment]. American Journal of Epidemiology. 1993;137(5):502-11. [pmid: 8465802].
94 Glauert HP, Chow CK. Dietary fatty acids and cancer. Fatty-Acids-in-Foods-and-Their-Health-Implications. 2000, Ed.2, 865–882; 200 Ref.
95 Gonder U, Truswell A S, Barber M D, Gurr M I, Cummings J H, Bingham S A. Diet and the prevention of cancer (multiple letters) [2]. BMJ. British Medical Journal. 1999;Vol 318(7203):(Pp 186-188). Date of Publication: 17 JUL 1999. [pmid: 9888921]. [pmcid: 1114667].
96 Graham S, Zielezny M, Marshall J, et al. Diet in the epidemiology of postmenopausal breast cancer in the New York State Cohort. American-Journal-of-Epidemiology. 1992;136(11):1327-37. 51 ref. [pmid: 1336931].
97 Greenwald P. Clinical trials of breast and prostate cancer prevention. Journal of Nutrition. 2001;131(1):176S-8S. [pmid: 11208959].
98 Greenwald P. Strengths and limitations of methodologic approaches to the study of diet and cancer: summary and future perspectives with emphasis on dietary fat and breast cancer. Preventive Medicine. 1989;18(2):163-6. [pmid: 2662174].
99 Greenwald P, Clifford C, Butrum R, Iverson D C. Feasibility studies of a low-fat diet to prevent or retard breast cancer. American Journal of Clinical Nutrition. 1987;45(1 Suppl):347-53. [pmid: 3541571].
100 Greenwald P, Sondik E, Lynch B S. Diet and chemoprevention in NCI's research strategy to achieve national cancer control objectives. [Review] [78 refs]. Annual Review of Public Health. 1986;7:267-91. [pmid: 3013230].
101 Grodstein F, Newcomb P A, Stampfer M J. Postmenopausal hormone therapy and the risk of colorectal cancer: a review and meta-analysis. Am. 1999;106(5):574-82.
102 Gunnell D, Oliver S E, Peters T J, et al. Are diet-prostate cancer associations mediated by the IGF axis? A cross-sectional analysis of diet, IGF-I and IGFBP-3 in healthy middle-aged men. British-Journal-of-Cancer. 2003;88(11):1682-6. 36 ref. [pmid: 12771980].
103 Hara N, Sakata K, Nagai M, Fujita Y, Hashimoto T, Yanagawa H. Geographical difference of mortality of digestive cancers and food consumption. [Japanese]. Gan No Rinsho - Japanese Journal of Cancer Clinics. 1984;30(13):1665-74.
104 Harrison R A, Waterbor J W. Understanding meta-analysis in cancer epidemiology: dietary fat and breast cancer. Cancer Detection & Prevention. 1999;23(2):97-106. [pmid: 10101590].
105 Hasle H, Rose C. Ugeskrift for Laeger. 1991;153(5):343-6. [pmid: 1994557].
106 Hawkes JSBD-LMMNMaGR. A randomized trial of supplementation with docosahexaenoic acid-rich tuna oli and its effects on the human milk cytokines interleukin 1b, interleukin 6, and tumour necrosis factor a 1–3. American Journal of Clinical Nutrition. 75(4):754–760, 2002.
107 Helsing E. Traditional diets and disease patterns of the Mediterranean, circa 1960. American Journal of Clinical Nutrition. 1995;61(6 SUPPL.):1329S-37S. [pmid: 7754984].
108 Henderson M M. Nutritional aspects of breast cancer. Cancer. 1995;76(10 Suppl):2053-8. [pmid: 8634999].
109 Herman C, Adlercreutz C H, Goldin B R, et al. Soybean phytoestrogen intake and cancer risk. [Review]. Journal of Nutrition. 1995;125(3 Suppl):757S-70S. [pmid: 7884562].
110 Hill M, Carr T (ed.), Descheemaeker K. Review of diet and cancer: what is the evidence? Nutrition-and-Health.-1st-Nutrition-and-Health-Conference,-London,-2000. 2002, 85–88; 10 Ref.
111 Hirayama T. Epidemiology of stomach cancer in Japan. With special reference to the strategy for the primary prevention. Japanese Journal of Clinical Oncology. 1984;14(2):159-68. [pmid: 6737706].
112 Hirayama T. A large scale cohort study on cancer risks by diet--with special reference to the risk reducing effects of green-yellow vegetable consumption. [Review] [13 refs]. Princess Takamatsu Symposia. 1985;16:41-53. [pmid: 3916204].
113 Holborow P. Melanoma and polyunsaturated fat. [comment]. New Zealand Medical Journal. 1991;104(907):104. [pmid: 2006066].
114 Holborow P L. Fats and melanoma. New Zealand Medical Journal. 1992;105(946):482-3. [pmid: 1436884].
115 Holborow P L. Melanoma patients consume more polyunsaturated fat than people without melanoma. New Zealand Medical Journal. 1991;104(924):502. [pmid: 1745467].
116 Hopkins S, Burrows E, Bowen D J, Tinker L F. Differences in eating pattern labels between maintainers and nonmaintainers in the Women's Health Initiative. Journal-of-Nutrition-Education. 2001;33(5):278-83. 20 ref. [pmid: 12031178].
117 Horan P. Dietary habits of the population of the southern region of the Czech Republic. Relation between colorectal cancer and diet. Ceskoslovenska-Gastroenterologie-a-Vyziva. 1992;46(4):255-60. 24 ref.
118 Huncharek M, Kupelnick B. Dietary fat intake and risk of epithelial ovarian cancer: A meta-analysis of 6,689 subjects from 8 observational studies. Nutrition & Cancer. 2001;40(2):87-91. [pmid: 11962260].
119 Hunter D J, Colditz G A, Stampfer M J, Rosner B, Willett W C, Speizer F E. Diet and risk of basal cell carcinoma of the skin in a prospective cohort of women. Annals of Epidemiology. 1992;2(3):231-9. [pmid: 1342273].
120 Hunter D J, Spiegelman D, Adami H O, et al. Non-dietary factors as risk factors for breast cancer, and as effect modifiers of the association of fat intake and risk of breast cancer. Cancer Causes & Control. 1997;8(1):49-56. [pmid: 9051322].
121 Hunter D J, Willett W C. Nutrition and breast cancer. Cancer Causes & Control. 1996;7(1):56-68. [pmid: 8850435].
122 Ishikawa H. Interventional trial for colorectal cancer prevention in Osaka. [Japanese]. Gan to Kagaku Ryoho. 2000;27(8):1185-90. [pmid: 10945015].
123 Jaakkola K, Lahteenmaki P, Laakso J, Harju E, Tykka H, Mahlberg K. Treatment with antioxidant and other nutrients in combination with chemotherapy and irradiation in patients with small-cell lung cancer. Anticancer Research. 1992;12(3):599-606. [pmid: 1320355].
124 Jaax S, Scott L W, Wolf J E J, Thornby J I, Black H S. General guidelines for a low-fat diet effective in the management and prevention of nonmelanoma skin cancer. Nutrition & Cancer. 1997;27(2):150-6. [pmid: 9121942].
125 Jacotot B. Nutritional interest in the consumption of olive oil. OCL -Oleagineux,-Corps-Gras,-Lipides. 1997;4(5):373-4. 14 ref.
126 Jalili T, Wildman R E C, Medeiros D M. Nutraceutical roles of dietary fiber. Journal of Nutraceuticals, Functional & Medical Foods. 2000;2(4):19-34.
127 James W P, Duthie G G, Wahle K W. The Mediterranean diet: protective or simply non-toxic?. [Review] [29 refs]. European Journal of Clinical Nutrition. 1989;43(Suppl 2):31-41. [pmid: 2689163].
128 Jarvinen R, Knekt P, Hakulinen T, Rissanen H, Heliovaara M. Dietary fat, cholesterol and colorectal cancer in a prospective study. British Journal of Cancer. 2001;85(3):357-61. [pmid: 11487265].
129 Jenkins D J, Jenkins A L, Rao A V, Thompson L U. Cancer risk: possible protective role of high carbohydrate high fiber diets. [Review] [44 refs]. American Journal of Gastroenterology. 1986;81(10):931-5. [pmid: 3020971].
130 Kaaks R, Riboli E. The role of multi-centre cohort studies in studying the relation between diet and cancer. Cancer Letters. 1997;114(12):263-70. [pmid: 9103307].
131 Kampman E, Giovannucci E, van't Veer P, et al. Calcium, vitamin D, dairy foods, and the occurrence of colorectal adenomas among men and women in two prospective studies. Am. 1994;139(1):16-29.
132 Keller J E, Howe H L. Case-control studies of cancer in Illinois farmers using data from the Illinois State Cancer Registry and the U.S. Census of Agriculture. European Journal of Cancer. 1994;30A(4):469-73. [pmid: 8018404].
133 Kelloff G J, Boone C W, Crowell J A, et al. New agents for cancer chemoprevention. [Review]. Journal of Cellular Biochemistry - Supplement. 1996;26:1-28. [pmid: 9154166].
134 Key T J. EPIC Working Group on Prostate C. Prostate cancer: rates in Europe, dietary hypotheses, and plans for EPIC. IARC Scientific Publications. 2002;156:197-200. [pmid: 12484163].
135 Khallouki F, Younos C, Soulimani R, et al. Consumption of argan oil (Morocco) with its unique profile of fatty acids, tocopherols, squalene, sterols and phenolic compounds should confer valuable cancer chemopreventive effects. European-Journal-of-Cancer-Prevention. 2003;12(1):67-75. 21 ref. [pmid: 12548113].
136 Khlat M. Cancer in Mediterranean migrants--based on studies in France and Australia. Cancer Causes & Control. 1995;6(6):525-31. [pmid: 8580301].
137 Kinjo J. Phytoestrogens. [Review] [20 refs] [Japanese]. Nippon Rinsho - Japanese Journal of Clinical Medicine. 2000;58(12):2434-8. [pmid: 11187733].
138 Kinlen L J. Fat and breast cancer. [Review] [56 refs]. Cancer Surveys. 1987;6(4):585-99. [pmid: 3330681].
139 Knauf V C, Facciotti D. Genetic engineering of foods to reduce the risk of heart disease and cancer. [Review] [10 refs]. Advances in Experimental Medicine & Biology. 1995;369:221-8. [pmid: 7598011].
140 Kolars J C, Kurth C L. Influence of diet, vitamins and chemotherapeutic agents on gastrointestinal cancer. Journal of Gastroenterology & Hepatology. 1998;13(SUPPL. NOV.):S173-S177.
141 Kolonel L N. Dietary fat and breast cancer: the evidence in perspective. Nutrition. 1994;10(6):578-9. [pmid: 7703615].
142 Kreienberg R, Kafka A. [German]. MMW Fortschritte Der Medizin. 2003;145(24):32-3. [pmid: 12866296].
143 Kristal A R, Hedderson M M, Patterson R E, Neuhouser M, Neuhauser M L. Predictors of self-initiated, healthful dietary change.]. Journal of the American Dietetic Association. 2001;101(7):762-6. [pmid: 11478472].
144 Kritchevsky D. The effect of over- and undernutrition on cancer. [Review] [70 refs]. European Journal of Cancer Prevention. 1995;4(6):445-51. [pmid: 8580779].
145 Kritchevsky S B, Morris D L. Changes in dietary fat intake preceding the diagnosis of cancer. Epidemiology. 1995;6(5):506-10. [pmid: 8562627].
146 Kromann N, Green A. Epidemiological studies in the Upernavik district, Greenland. Incidence of some chronic diseases 1950-1974. Acta. 1980;208(5):401-6.
147 Kuller L H. Breast cancer study. Science. 1988;239(4842):848. [pmid: 3277282].
148 Kushi L, Giovannucci E. Dietary fat and cancer. American-Journal-of-Medicine 2002; 113(9):Supplement 2, 63–70.
149 La Guardia M, Giammanco M. Breast cancer and obesity. [Review]. Panminerva Medica. 2001;43(2):123-33. [pmid: 11449184].
150 La Vecchia C. Fruit, vegetables and cancer. Ricerca e Pratica. 1997;Vol 13(77):(Pp 198-202).
151 La Vecchia C. Mediterranean epidemiological evidence on tomatoes and the prevention of digestive-tract cancers. Proceedings of the Society for Experimental Biology & Medicine. 1998;218(2):125-8. [pmid: 9605210].
152 La Vecchia C, Favero A, Franceschi S, la Vecchia C. Monounsaturated and other types of fat, and the risk of breast cancer. European-Journal-of-Cancer-Prevention. 1998;7(6):461-4. 14 ref. [pmid: 9926294].
153 La Vecchia C, Negri E. Fats in seasoning and the relationship to pancreatic cancer. European Journal of Cancer Prevention. 1997;6(4):370-3. [pmid: 9370100].
154 LaFollette S, Cobleigh M. Dietary and chemoprevention strategies for breast cancer prevention. Cancer Control. 1995;2(3):218-22. [pmid: 10887032].
155 Lamisse F, May M A, Couet C, et al. Changes in nutritional status in the initial phase of treatment of cancers and malignant blood diseases. Revue De Medecine Interne. 1987;8(3):257-61. [pmid: 3616232].
156 Lanier A, Bender T, Talbot M, et al. Nasopharyngeal carcinoma in Alaskan Eskimos Indians, and Aleuts: a review of cases and study of Epstein-Barr virus, HLA, and environmental risk factors. Cancer. 1980;46(9):2100-6. [pmid: 6253051].
157 Lanier A P, Bender T R, Blot W J, Fraumeni J F J, Hurlburt W B. Cancer incidence in Alaska natives. Int. 1976;18(4):409-12.
158 Lanier A P, Bulkow L R, Ireland B. Cancer in Alaskan Indians, Eskimos, and Aleuts, 1969-83: implications for etiology and control. Public. 1989;104(6):658-64.
159 Lanier A P, Kelly J J, Smith B, et al. Alaska Native cancer update: incidence rates 1989-1993. Cancer. 1996;5(9):749-51.
160 Larking P W. Cancer and low levels of plasma cholesterol: the relevance of cholesterol precursors and products to incidence of cancer. [Review] [75 refs]. Preventive Medicine. 1999;29(5):383-90. [pmid: 10564630].
161 Lewis C E, George V, Fouad M, Porter V, Bowen D, Urban N. Recruitment strategies in the women's health trial: feasibility study in minority populations. WHT:FSMP Investigators Group. Women's Health Trial:Feasibility Study in Minority Populations. Controlled Clinical Trials. 1998;19(5):461-76. [pmid: 9741867].
162 Lin M T, Saito H, Fukushima R, et al. Preoperative total parenteral nutrition influences postoperative systemic cytokine responses after colorectal surgery. Nutrition. 1997;13(1):8-12. [pmid: 9058440].
163 Lindstrom M, Hanson B S, Brunner E, et al. Socioeconomic differences in fat intake in a middle-aged population: report from the Malmo Diet and Cancer Study. International Journal of Epidemiology. 2000;29(3):438-48. [pmid: 10869315].
164 London S, Willett W. Diet and the risk of breast cancer. [Review] [72 refs]. Hematology - Oncology Clinics of North America. 1989;3(4):559-76.
165 Mackie B S, Mackie L E. Cancer and dietary lipids. [comment]. New Zealand Medical Journal. 1991;104(916):322. [pmid: 1824039].
166 Mackie B S, Johnson A R, Mackie L E, Fogerty A C, Ferris M, Baxter R I. Dietary polyunsaturated fats and malignant melanoma. Medical-Journal-of-Australia. 1980;1(4):159-63. 7 ref. [pmid: 7374545].
167 MacLennan R. Diet and colorectal cancer. International Journal of Cancer. 1997;72(SUPPL.):10-2.
168 Mahoney BP, Inserra P, Watson RR. Breast cancer prevention. Functional-Foods-and-Nutraceuticals-in-Cancer-Prevention. 2003, 289–296; Many Ref.
169 Martin-Moreno J M. The role of olive oil in lowering cancer risk: is this real gold or simply pinchbeck?[comment]. Journal of Epidemiology & Community Health. 2000;54(10):726-7. [pmid: 10990470].
170 Mayne S T, Risch H A, Dubrow R, et al. Nutrient intake and risk of subtypes of esophageal and gastric cancer. Cancer-Epidemiology,-Biomarkers-and-Prevention. 2001;10(10):1055-62. 37 ref.
171 McCann S E, Weiner J, Graham S, Freudenheim J L. Is principal components analysis necessary to characterise dietary behaviour in studies of diet and disease?. Public-Health-Nutrition. 2001;4(4):903-8. 15 ref. [pmid: 11527514].
172 McKelvey W, Greenland S, Chen MiaoJung, et al. A case-control study of colorectal adenomatous polyps and consumption of foods containing partially hydrogenated oils. Cancer-Epidemiology,-Biomarkers-and-Prevention. 1999;8(6):519-24. 35 ref.
173 McKelvey W, Greenland S, Sandler R S. A second look at the relation between colorectal adenomas and consumption of foods containing partially hydrogenated oils. Epidemiology. 2000;11(4):469-73. 13 ref. [pmid: 10874557].
174 McKeown-Eyssen G E. Dietary approaches to the prevention of large bowel cancer. Progress in Clinical & Biological Research. 1985;186:277-84. [pmid: 3898144].
175 Meng L, Maskarinec G, Wilkens L. Ethnic differences and factors related to breast cancer survival in Hawaii. Int. 1997;26(6):1151-8.
176 Metayer C, Wang Z, Kleinerman R A, et al. Cooking oil fumes and risk of lung cancer in women in rural Gansu, China. Lung Cancer. 2002;35(2):111-7. [pmid: 11804682].
177 Millar J H, Zilkha K J, Langman M J, et al. Double-blind trial of linoleate supplementation of the diet in multiple sclerosis. Br Med J. 1973;1(5856):765-8. [pmid: 4571680]. [pmcid: 1588925].
178 Mohler K. Cancer and nutrition. Umschau-in-Wissenschaft-Und-Technik. 1977;77(8):236-40. 18 ref.
179 Momas I, Daures J P, Festy B, Bontoux J, Gremy F. Relative importance of risk factors in bladder carcinogenesis: some new results about Mediterranean habits. Cancer Causes & Control. 1994;5(4):326-32. [pmid: 8080944].
180 Mori M, Harabuchi I, Miyake H. Host and environmental risk factors of ovarian cancer. [Japanese]. Gan No Rinsho - Japanese Journal of Cancer Clinics. 1987;33(5 Suppl):469-76.
181 Morris D H, Sorenesen G, Stoddard A M, Fitzgerald G. Comparison between food choices of working adults and dietary patterns recommended by the National Cancer Institute. Journal-of-the-American-Dietetic-Association. 1992;92(10):1272-4. 16 ref. [pmid: 1401670].
182 Moyad M A. Emphasizing and promoting overall health and nontraditional treatments after a prostate cancer diagnosis. [Review] [95 refs]. Seminars in Urologic Oncology. 1999;17(2):119-24. [pmid: 10332926].
183 Naidu M R, Das U N, Kishan A. Intratumoral gamma-linoleic acid therapy of human gliomas. Prostaglandins. 1992;45(3):181-4.
184 Nelson R L. Diet and adenomatous polyp risk. Seminars in Surgical Oncology. 1994;10(3):165-75. [pmid: 8085093].
185 Newmark H L. Squalene, olive oil, and cancer risk: a review and hypothesis. Cancer-Epidemiology,-Biomarkers-and-Prevention. 1997;6(12):1101-3. 36 ref.
186 Nielsen N H, Hansen J P. Breast cancer in Greenland--selected epidemiological, clinical, and histological features. J. 1980;98(3):287-99.
187 Nixon D W. Cancer prevention clinical trials. In Vivo. 1994;8(5):713-6. [pmid: 7727717].
188 Nixon D W. Nutrition and cancer: American Cancer Society guidelines, programs, and initiatives. Ca - A-Cancer-Journal-for-Clinicians. 1990;40(2):71-5. 6 ref. [pmid: 2155046].
189 Ornish D M, Lee K L, Fair W R, Pettengill E B, Carroll P R. Dietary trial in prostate cancer: Early experience and implications for clinical trial design. Urology. 2001;57(4 Suppl 1):200-1. [pmid: 11295627].
190 Owen R W, Giacosa A, Hull W E, Haubner R, Spiegelhalder B, Bartsch H. The antioxidant/anticancer potential of phenolic compounds isolated from olive oil. European Journal of Cancer. 2000;36(10):1235-47. [pmid: 10882862].
191 Owen R W, Giacosa A, Hull W E, et al. Olive-oil consumption and health: the possible role of antioxidants. [Review] [35 refs]. Lancet Oncology. 2000;1:107-12. Oct. [pmid: 11905662].
192 Palli D, Russo A, Saieva C, Salvini S, Amorosi A, Decarli A. Dietary and familial determinants of 10-year survival among patients with gastric carcinoma. Cancer. 2000;89(6):1205-13. 36 ref. [pmid: 11002214].
193 Pariza M W. Dietary fat and cancer risk: evidence and research needs. Annual-Review-of-Nutrition. 1988;8:167-183. 71 Ref. [pmid: 3060163].
194 Pfau W. Cancer and nutrition: The importance of food storage and preparation. Aktuelle Ernahrungsmedizin. 2001;26(4):144-7.
195 Phinney S D. Metabolism of exogenous and endogenous arachidonic acid in cancer. [Review] [30 refs]. Advances in Experimental Medicine & Biology. 1996;399:87-94. [pmid: 8937550].
196 Ponholzer A, Struhal G, Madersbacher S. Frequent use of complementary medicine by prostate cancer patients. European Urology. 2003;43(6):604-8. [pmid: 12767359].
197 Prasad K N, Cole W, Hovland P. Cancer prevention studies: past, present, and future directions. [Review] [91 refs]. Nutrition. 1998;14(2):197-210. discussion 237–8. [pmid: 9530648].
198 Prentice R, Thompson D, Clifford C, Gorbach S, Goldin B, Byar D. Dietary fat reduction and plasma estradiol concentration in healthy postmenopausal women. The Women's Health Trial Study Group. J. 1990;82(2):129-34.
199 Roberts D C K. Dietary trans fatty acids and cancer: a review of the evidence. Food-Australia. 1995;47(6):263-5.
200 Rock C L, Flatt S W, Wright F A, et al. Responsiveness of carotenoids to a high vegetable diet intervention designed to prevent breast cancer recurrence. Cancer Epidemiology, Biomarkers & Prevention. 1997;6(8):617-23.
201 Rock C L, Thomson C, Caan B J, et al. Reduction in fat intake is not associated with weight loss in most women after breast cancer diagnosis: evidence from a randomized controlled trial. Cancer. 2001;91(1):25-34. [pmid: 11148556].
202 Rodler I, Zajkas G. Hungarian cancer mortality and food availability data in the last four decades of the 20th century. Annals-of-Nutrition-and-Metabolism. 2002;46(2):49-56. 30 ref. [pmid: 12011572].
203 Rose D P, Connolly J M, Liu X H. Dietary fatty acids and human breast cancer cell growth, invasion, and metastasis. [Review] [45 refs]. Advances in Experimental Medicine & Biology. 1994;364:83-91. [pmid: 7725962].
204 Rudan I, Vadla D, Strnad M, Biloglav Z, Vorko-Jovic A.. Lijecnicki Vjesnik 2003; 125(3–4):60–7.
205 Saadatian-Elahi M, Norat T, Bueno-de-Mesquita H B, et al. Plasma concentrations of fatty acids in nine European countries: cross-sectional study within the European Prospective Investigation into Cancer and Nutrition (EPIC). IARC Scientific Publications. 2002;156:215-8. [pmid: 12484170].
206 Salazar-Martinez E, Lazcano-Ponce E C, Gonzalez Lira-Lira G, Escudero-De los Rios P, Hernandez-Avila M. Nutritional determinants of epithelial ovarian cancer risk: a case-control study in Mexico. Oncology. 2002;63(2):151-7. [pmid: 12239450].
207 Salminen E K, Lagstrom H K, Heikkila S P, Salminen S J. Does breast cancer change patients' dietary habits?. European Journal of Clinical Nutrition. 2000;54(11):844-8. [pmid: 11114679].
208 Sandal N N, Marcker K A. Similarities between a soybean nodulin, Neurospora crassa sulphate permease II and a putative human tumour suppressor. [Review] [8 refs]. Trends in Biochemical Sciences. 1994;19(1):19. [pmid: 8140616].
209 Sane S, Baba M, Kusano C, Shirao K, Kamada T, Aikou T. Fat emulsion administration in the early postoperative period in patients undergoing esophagectomy for carcinoma depresses arachidonic acid metabolism in neutrophils. Nutrition. 1999;15(5):341-6. [pmid: 10355845].
210 Santiago E, Gonzalez M J, Matos M I, Perez C M. Association between dietary fat and breast cancer in Puerto Rican postmenopausal women attending a breast cancer clinic. Puerto Rico Health Sciences Journal. 1998;17(3):235-41. [pmid: 9883469].
211 Sartori H E. Nutrients and cancer: an introduction to cesium therapy. Pharmacology, Biochemistry & Behavior. 1984;21(Suppl 1):7-10.
212 Satia-Abouta J, Patterson R E, Schiller R N, Kristal A R. Energy from fat is associated with obesity in U.S. men: results from the Prostate Cancer Prevention Trial. Preventive Medicine. 2002;34(5):493-501. [pmid: 11969348].
213 Schatzkin A, Greenwald P, Byar D P, Clifford C K. The dietary fat--breast cancer hypothesis is alive.[comment]. [Review] [25 refs]. JAMA. 1989;261(22):3284-7. [pmid: 2654436].
214 Schatzkin A, Lanza E. Polyp Prevention Trial Study G. Polyps and vegetables (and fat, fibre): the polyp prevention trial. IARC Scientific Publications. 2002;156:463-6. [pmid: 12484235].
215 Scheppach W, Boxberger F, Luhrs H, Melcher R, Menzel T. [German]. Zentralblatt Fur Chirurgie. 2000;125(Suppl 1):5-7. [pmid: 10929638].
216 Shah M, Baxter J E, McGovern P G, Garg A. Nutrient and food intake in obese women on a low-fat or low-calorie diet. American Journal of Health Promotion. 1996;10(3):179-82. [pmid: 10163296].
217 Shen Z, Wu M, Elson P, et al. Fatty acid composition of lysophosphatidic acid and lysophosphatidylinositol in plasma from patients with ovarian cancer and other gynecological diseases. Gynecologic Oncology. 2001;83(1):25-30. [pmid: 11585410].
218 Shike M, Latkany L, Riedel E, et al. Lack of effect of a low-fat, high-fruit, -vegetable, and -fiber diet on serum prostate-specific antigen of men without prostate cancer: results from a randomized trial. Journal-of-Clinical-Oncology. 2002;20(17):3592-8. 39 ref. [pmid: 12202659].
219 Simonsen N R, Fernandez-Crehuet Navajas J, Martin-Moreno J M, et al. Tissue stores of individual monounsaturated fatty acids and breast cancer: the EURAMIC study. European Community Multicenter Study on Antioxidants, Myocardial Infarction, and Breast Cancer. American Journal of Clinical Nutrition. 1998;68(1):134-41. [pmid: 9665107].
220 Singh N K, Das U N, Srivastava P K. Essential fatty acids and cancer with particular reference to Hodgkin's disease. Journal of the Association of Physicians of India. 1987;35(2):137-8. [pmid: 3693269].
221 Smoliar VI. Likarska Sprava 2001; (4):10–5.
222 Soran A. Protective effect of monounsaturated fat against breast cancer. [Review] [15 refs]. Kobe Journal of Medical Sciences. 1998;44(4):141-7. [pmid: 10352493].
223 Sparreboom A, Wolff A C, Verweij J, et al. Disposition of docosahexaenoic acid-paclitaxel, a novel taxane, in blood: in vitro and clinical pharmacokinetic studies. Clinical Cancer Research. 2003;9(1):151-9. [pmid: 12538463].
224 Spaziani E, Neri T, Guarino E, et al. [Italian]. Minerva Gastroenterologica e Dietologica. 1995;41(4):265-8. [pmid: 8664412].
225 Spector A A. Fatty acid metabolism in tumors. [Review]. Progress in Biochemical Pharmacology. 1975;10:42-75. [pmid: 165554].
226 Stangl G I. Cancer and the preventive potential of nutrition. Part I: Mechanistic effects of nutritional factors for instance on carcinoma of the breast. Ernahrungs-Umschau. 2001;48(7):268-73. 266; 35 ref.
227 Stark A H, Madar Z. Olive oil as a functional food: epidemiology and nutritional approaches. [Review] [61 refs]. Nutrition Reviews. 2002;60(6):170-6. [pmid: 12078915].
228 Stemmermann G N, Nomura A M, Heilbrun L K. Cancer risk in relation to fat and energy intake among Hawaii Japanese: a prospective study. [Review] [32 refs]. Princess Takamatsu Symposia. 1985;16:265-74. [pmid: 3916198].
229 Stevens V J, Glasgow R E, Toobert D J, Karanja N, Smith K S. Randomized trial of a brief dietary intervention to decrease consumption of fat and increase consumption of fruits and vegetables. American Journal of Health Promotion. 2002;16(3):129-34. [pmid: 11802257].
230 Stoll B A. Diet and exercise regimens to improve breast carcinoma prognosis. Cancer. 1996;78(12):2465-70. [pmid: 8952552].
231 Stoll B A. Nutrition and breast cancer risk: can an effect via insulin resistance be demonstrated? [Review] [58 refs]. Breast Cancer Research & Treatment. 1996;38(3):239-46. [pmid: 8739075].
232 Stone K J, Willis A L, Hart W M, Kirtland S J, Kernoff P B, McNicol G P. The metabolism of dihomo-gamma-linolenic acid in man. Lipids. 1979;14(2):174-80. [pmid: 423720].
233 Sutherland H J, Carlin K, Harper W, et al. A study of diet and breast cancer prevention in Canada: why healthy women participate in controlled trials. Cancer Causes & Control. 1993;4(6):521-8. [pmid: 8280829].
234 Teas J. The dietary intake of Laminaria, a brown seaweed, and breast cancer prevention. [Review] [55 refs]. Nutrition & Cancer. 1983;4(3):217-22. [pmid: 6302638].
235 Terashima S, Takano Y, Ohori T, et al. Soybean agglutinin binding as a useful prognostic indicator in stomach cancer. Surgery Today. 1997;27(4):293-7. [pmid: 9086542].
236 Trichopoulos D, Tzonou A, Katsouyanni K, Trichopoulou A. Diet and Cancer: The role of case-control studies. Ann Nutr Metab. 1991;35(supp 1):89-92. [pmid: 1888133].
237 Trichopoulou A. Olive oil and breast cancer. [comment]. Cancer Causes & Control. 1995;6(6):475-6. [pmid: 8580293].
238 Trichopoulou A, Lagiou P. Re: Correlating nutrition to recent cancer mortality statistics. [comment]. Journal of the National Cancer Institute. 1997;89(22):1725-6. [pmid: 9390545].
239 Trichopoulou A, Lagiou P. Worldwide patterns of dietary lipids intake and health implications. Am J Clin Nutr. 1997;66(supp):961S-4S. [pmid: 9322574].
240 Trichopoulou A, Lagiou P, Kuper H, Trichopoulos D. Cancer and Mediterranean dietary traditions. [Review] [25 refs]. Cancer Epidemiology, Biomarkers & Prevention. 2000;9(9):869-73.
241 Tuck K L, Hayball P J. Major phenolic compounds in olive oil: Metabolism and health effects. Journal of Nutritional Biochemistry. 2002;13(11):636-44. [pmid: 12550060].
242 Urban N, White E, Anderson G L, Curry S, Kristal A R. Correlates of maintenance of a low-fat diet among women in the Women's Health Trial. Preventive Medicine. 1992;21(3):279-91. [pmid: 1614990].
243 Van Aswegen C H, Du Plessis D J. Can linoleic acid and gamma-linolenic acid be important in cancer treatment?. Medical Hypotheses. 1994;43(6):415-7. [pmid: 7739415].
244 van den Brandt P A, Goldbohm R A, van't Veer P, Volovics A, Hermus R J, Sturmans F. A large-scale prospective cohort study on diet and cancer in The Netherlands. J. 1990;43(3):285-95.
245 van der Merwe C F, Booyens J, Joubert H F, van der Merwe C A. The effect of gamma-linolenic acid, an in vitro cytostatic substance contained in evening primrose oil, on primary liver cancer. A double-blind placebo controlled trial. Prostaglandins Leukotrienes & Essential Fatty Acids. 1990;40(3):199-202.
246 Van der Merwe C F, Booyens J, Katzeff I E. Oral gamma-linolenic acid in 21 patients with untreatable malignancy. An ongoing pilot open clinical trial. Br. 1987;41(9):907-15.
247 van't Veer P. Diet and breast cancer: trial and error?. [Review] [60 refs]. Annals of Medicine. 1994;26(6):453-60. [pmid: 7695872].
248 Van't Veer P, van Leer E M, Rietdijk A, et al. Combination of dietary factors in relation to breast-cancer occurrence. International Journal of Cancer. 1991;47(5):649-53.
249 Varela G, Hill MJ (ed.), Giacosa A (ed.), Caygill CPJ. Mediterranean diet and cancer: a Spanish perspective. Epidemiology-of-Diet-and-Cancer. 1994, 237–249; 24 Ref.
250 Vargas P A, Alberts D S. Primary prevention of colorectal cancer through dietary modification. [Review] [96 refs]. Cancer. 1992;70(5 Suppl):1229-35. [pmid: 1324781].
251 Veer P van't, Vet HCW de, Gilse HA van. Nutrition and breast cancer. 1. Epidemiology. Voeding 1984; 45(2):39–45; 71 ref.
252 Velie E, Kulldorff M, Schairer C, Block G, Albanes D, Schatzkin A. Dietary fat, fat subtypes, and breast cancer in postmenopausal women: a prospective cohort study. Journal of the National Cancer Institute. 2000;92(10):833-9. [pmid: 10814679].
253 Verhoeven D T H, Assen N, Goldbohm R A, et al. Vitamins C and E, retinol, beta-carotene and dietary fibre in relation to breast cancer risk: a prospective cohort study. British-Journal-of-Cancer. 1997;75(1):149-55. 47 ref. [pmid: 9000614].
254 Verreault R, Brisson J, Deschenes L, Naud F, Meyer F, Belanger L. Dietary fat in relation to prognostic indicators in breast cancer. J. 1988;80(11):819-25.
255 Visiol F, Galli C. Biological properties of olive oil phytochemicals. [Review] [82 refs]. Critical Reviews in Food Science & Nutrition. 2002;42(3):209-21. [pmid: 12058980].
256 Visioli F, Galli C. The role of antioxidants in the Mediterranean diet. [Review] [30 refs]. Lipids. 2001;36(Suppl):S49-52. [pmid: 11837993].
257 Voirol M, Infante F, Raymond L, et al. [French]. Schweizerische Medizinische Wochenschrift. Journal Suisse De Medecine. 1987;117(29):1101-4. [pmid: 3672063].
258 Wahlqvist M , Hsu-Hage B, Kouris-Blazos A, Lukito W. Food habits in later life. A cross-cultural study (CD ROM). Melbourne: Asia Pacific Journal of Clinical Nutrition & United Nations University Press 1995.
259 Wahrburg U, Kratz M, Cullen P. Mediterranean diet, olive oil and health. European-Journal-of-Lipid-Science-and-Technology. 2002;104(910):698-705. 75 ref.
260 Walker A R, Burkitt D P. Colonic cancer--hypotheses of causation, dietary prophylaxis, and future research. American Journal of Digestive Diseases. 1976;21(10):910-7. [pmid: 1015500].
261 Walker A R, Walker B F, Stelma S. Is breast cancer avoidable? Could dietary changes help? [Review] [78 refs]. International Journal of Food Sciences & Nutrition. 1995;46(4):373-81. [pmid: 8574864].
262 Weisburger J H, Horn C L. Human and laboratory studies on the causes and prevention of gastrointestinal cancer. Scandinavian-Journal-of-Gastroenterology. 1984;19(Suppl. 104):15-26. 69 ref.
263 White E, Shattuck A L, Kristal A R, et al. Maintenance of a low-fat diet: follow-up of the Women's Health Trial. Cancer Epidemiology, Biomarkers & Prevention. 1992;1(4):315-23.
264 Willett WC. Diet and cancer: a whirlwind odyssey through a sea of inconsistency. [Review][39 refs]. Bibliotheca Nutritio Et Dieta 1986; (37):121–9.
265 Willett W C. Diet and cancer: one view at the start of the millennium. Cancer Epidemiology, Biomarkers & Prevention. 2001;10(1):3-8.
266 Willett W C. Dietary fat intake and cancer risk: a controversial and instructive story. Seminars in Cancer Biology. 1998;8(4):245-53. [pmid: 9870031].
267 Willett W C. Micronutrients and cancer risk. American Journal of Clinical Nutrition. 1994;59(5 SUPPL.):1162S-5S. [pmid: 8172117].
268 Willett W C. Polyunsaturated fat and the risk of cancer. [comment]. BMJ. 1995;311(7015):1239-40. [pmid: 7496216].
269 Willett W C, Sacks F, Trichopoulou A, et al. Mediterranean diet pyramid: a cultural model for healthy eating. [Review] [19 refs]. American Journal of Clinical Nutrition. 1995;61(6 Suppl):1402S-6S. [pmid: 7754995].
270 Willett W C, Stampfer M J, Colditz G A, Rosner B A, Hennekens C H, Speizer F E. Dietary fat and the risk of breast cancer. New England Journal of Medicine. 1987;316(1):22-8. [pmid: 3785347].
271 Willett W C, Beck M A, et al. Fat, energy and breast cancer. American Society for Nutritional Sciences Annual Meeting. 1997;127(5SUPPL):921S-3S. 32 ref.
272 Witte J S, Ursin G, Siemiatycki J, Thompson W D, Paganini Hill A, Haile R W. Diet and premenopausal bilateral breast cancer: a case-control study. Breast-Cancer-Research-and-Treatment. 1997;42(3):243-51. 47 ref. [pmid: 9065608].
273 Wu A H, Pike M C, Stram D O. Meta-analysis: dietary fat intake, serum oestrogen levels, and the risk of breast cancer. Journal-of-the-National-Cancer-Institute. 1999;91(6):529-34. 51 ref. [pmid: 10088623].
274 Wynder E L. Re: Randomized trial of intake of fat, fiber, and beta carotene to prevent colorectal adenomas. [comment]. Journal of the National Cancer Institute. 1996;88(6):377-8. [pmid: 8609649].
275 Wynder E L, Hebert J R, Kabat G C. Association of dietary fat and lung cancer. Journal-of-the-National-Cancer-Institute. 1987;79(4):631-7. 39 ref. [pmid: 2821310].
276 Yamasaki Y, Satomi S, Murai N, Tsuzuki S, Fushiki T. Inhibition of membrane-type serine protease 1/matriptase by natural and synthetic protease inhibitors. Journal of Nutritional Science & Vitaminology. 2003;49(1):27-32. [pmid: 12882393].
277 Zaridze D, Evstifeeva T, Babaeva M, Boyle P. Fats used in seasoning and breast cancer risk: a case-control study in Moscow, Russia. Annals of Oncology. 1993;4(6):495-8. [pmid: 8353092].
278 Zaridze D G, Muir C S, McMichael A J. Diet and cancer: value of different types of epidemiological studies. Nutrition & Cancer. 1985;7(3):155-66. [pmid: 3001657].
279 Zhang J, Go V L. High fat diet, lipid peroxidation, and pancreatic carcinogenesis. [Review] [53 refs]. Advances in Experimental Medicine & Biology. 1996;399:165-72. [pmid: 8937556].
280 Zhang S, Folsom A R, Sellers T A, Kushi L H, Potter J D. Better breast cancer survival for postmenopausal women who are less overweight and eat less fat. The Iowa Women's Health Study. Cancer. 1995;76(2):275-83. [pmid: 8625103].
281 Zhang S M, Hunter D J, Rosner B A, et al. Intakes of fruits, vegetables, and related nutrients and the risk of non-Hodgkin's lymphoma among women. Cancer-Epidemiology,-Biomarkers-and-Prevention. 2000;9(5):477-85. 36 ref.
282 Zhou J R, Mukherjee P, Gugger E T, Tanaka T, Blackburn G L, Clinton S K. Inhibition of murine bladder tumorigenesis by soy isoflavones via alterations in the cell cycle, apoptosis, and angiogenesis. Cancer. 1998;58(22):5231-8.
283 Ziegler R G, Hoover R N, Pike M C, et al. Migration patterns and breast cancer risk in Asian-American women. J. 1993;85(22):1819-27.
284 Ziegler R G, Mayne S T, Swanson C A. Nutrition and lung cancer. [Review]. Cancer Causes & Control. 1996;7(1):157-77. [pmid: 8850443].
285 Zock P L, Katan M B. Linoleic acid intake and cancer risk: A review and meta-analysis. American Journal of Clinical Nutrition. 1998;68(1):142-53. [pmid: 9665108].

### Rejected Population (n = 112)

1 Aguilera J. [Review] [99 refs] [French]. Annales De Medecine Interne. 1994;145(1):44-9. [pmid: 8192281].
2 Alexander J W. Immunoenhancement via enteral nutrition. [Review] [20 refs]. Archives of Surgery. 1993;128(11):1242-5. [pmid: 7694565].
3 Anonymous [comment]. [Spanish] Medicina Clinica 1999 112 (4) 125–32.
4 Avula C P R, Lawrence R A, Jolly C A, Fernandes G. Role of n-3 polyunsaturated fatty acids (PUFA) in autoimmunity, inflammation, carcinogenesis, and apoptosis. Recent-Research-Developments-in-Lipids. 2000;4(2):303-19. 216 ref.
5 Babcock T A, Kurland A, Helton W S, Rahman A, Anwar K N, Espat N J. Inhibition of activator protein-1 transcription factor activation by omega-3 fatty acid modulation of mitogen-activated protein kinase signaling kinases. Jpen: Journal of Parenteral & Enteral Nutrition. 2003;27(3):176-80. discussion 181. [pmid: 12757110].
6 Baronzio G F, Galante F, Gramaglia A, Barlocco A, de Grandi S, Freitas I. Tumor microcirculation and its significance in therapy: possible role of omega-3 fatty acids as rheological modifiers. [Review] [58 refs]. Medical Hypotheses. 1998;50(2):175-82. [pmid: 9572573].
7 Baronzio G F, Solbiati L, Ierace T, et al. Adjuvant therapy with essential fatty acids (EFAs) for primary liver tumors: Some hypotheses. Medical Hypotheses. 1995;44(3):149-54. [pmid: 7609665].
8 Beck S A, Smith K L, Tisdale M J. Anticachectic and antitumor effect of eicosapentaenoic acid and its effect on protein turnover. Cancer. 1991;51(22):6089-93.
9 Begin M E. Tumor cytotoxicity of essential fatty acids. Nutrition. 1989;5(4):258-60. [pmid: 2520305].
10 Berry E M. Who's afraid of n-6 polyunsaturated fatty acids? Methodological considerations for assessing whether they are harmful. [Review] [64 refs]. Nutrition Metabolism & Cardiovascular Diseases. 2001;11(3):181-8.
11 Booyens J, Maguire L, Katzeff I E. Dietary fats and cancer. Medical Hypotheses. 1985;17(4):351-62. [pmid: 3930928].
12 Borgeson C E, Pardini L, Pardini R S, Reitz R C. Effect of dietary fish oil on human mammary carcinoma and on lipid-metabolizing enzymes. Lipids. 1989;24(4):290-5. [pmid: 2502698].
13 Bougnoux P, Germain E, Lavillonniere F, et al. Polyunsaturated fatty acids and breast cancer. Lipids. 1999;34(Suppl):S99. [pmid: 10419106].
14 Burns C P, Spector A A. Biochemical effects of lipids on cancer therapy. Journal of Nutritional Biochemistry. 1994;5(3):114-23.
15 Burns C P, Wagner B A. Effects of exogenous lipids on cancer and cancer chemotherapy. Implications for treatment. [Review] [89 refs]. Drug Safety. 1993;8(1):57-68. [pmid: 8471188].
16 Cantrill R C, Huang Y S. Fatty acids and cancer. [comment]. Nutrition. 1998;14(2):235-7. [pmid: 9530654].
17 Carroll K K. Dietary fat in relation to mammary carcinogenesis. [Review] [37 refs]. Princess Takamatsu Symposia. 1985;16:255-63. [pmid: 3916197].
18 Carroll K K, Hopkins G J, Kennedy T G, Davidson M B. Essential fatty acids in relation to mammary carcinogenesis. Progress in Lipid Research. 1981;20:685-90. [pmid: 6804981].
19 Carroll K K, Khor H T. Dietary fat in relation to tumorigenesis. Prog Biochem Pharmacol. 1975;10:308-53. [pmid: 165553].
20 Cave W T Jr. Dietary omega-3 polyunsaturated fats and breast cancer. Nutrition. 1996;12(1 Suppl):S39-42. [pmid: 8850219].
21 Chamorro G, Salazar M, Araujo K G, dos Santos C P, Ceballos G, Castillo L F. [Review] [73 refs] [Spanish]. Archivos Latinoamericanos De Nutricion. 2002;52(3):232-40. [pmid: 12448336].
22 Chen Z Y, Istfan N W. Docosahexaenoic acid is a potent inducer of apoptosis in HT-29 colon cancer cells. Prostaglandins. 2000;63(5):301-8.
23 Cohen L A, Wynder E I. Do dietary monounsaturated fatty acids play a protective role in carcinogenesis and cardiovascular disease?. [Review] [51 refs]. Medical Hypotheses. 1990;31(2):83-9. [pmid: 2182987].
24 Constantinou A, Krygier A, Mehta R. Genistein induces maturation of cultured human breast cancer cells and prevents tumor growth in nude mice. Am J Clin Nutr. 1998;68(supp):1426S-30S. [pmid: 9848511].
25 Cukier C, Waitzberg DL. Biological activity of fish oil. Arquivos. De Gastroenterologia. 1996; (3):173–8.
26 Dagnelie PCvdBJBJFCRTaSG. Fish oil: a new therapeutic modality in cancer cachexia? [abstract]. Clinical Nutrition. Vol.12 Suppl 2, Pp.50, 1993.
27 Danbara N, Yuri T , Tsujita M, Senzaki H, Tsubura A. Nippon Rinsho - Japanese Journal of Clinical Medicine. 61 Suppl 7:519–21, 2003 September.
28 Das U N. Essential fatty acids and their metabolites and cancer.[comment]. [Review] [33 refs]. Nutrition. 1999;15(3):239-40. [pmid: 10198921].
29 Das U N. Essential fatty acids, lipid peroxidation and apoptosis. [Review] [41 refs]. Prostaglandins Leukotrienes & Essential Fatty Acids. 1999;61(3):157-63.
30 Das U N. Gamma-linolenic acid, arachidonic acid, and eicosapentaenoic acid as potential anticancer drugs. [Review] [85 refs]. Nutrition. 1990;6(6):429-34. [pmid: 1966883].
31 Das U N. Reversal of tumor cell drug resistance by essential fatty acids. Lipids. 1999;34(Suppl):S103. [pmid: 10419108].
32 Das U. Essential fatty acids: Biology and their clinical implications. Asia Pacific Journal of Pharmacology. 1991;6(4):317-30.
33 de Mejia E G, Bradford T, Hasler C. The anticarcinogenic potential of soybean lectin and lunasin. [Review] [74 refs]. Nutrition Reviews. 2003;61(7):239-46. [pmid: 12918876].
34 de Rooij P D, Visser J J, Meijer S, Wesdorp R I. [Review] [39 refs] [Dutch]. Nederlands Tijdschrift Voor Geneeskunde. 1991;135(19):833-6. [pmid: 2046779].
35 De Vries C E E, Van Noorden C J F. Effects of dietary fatty acid composition on tumor growth and metastasis. Anticancer Research. 1992;12(5):1513-22. [pmid: 1444214].
36 Deschner E E, Lytle J S, Wong G, Ruperto J F, Newmark H L. The effect of dietary omega-3 fatty acids (fish oil) on azoxymethanol-induced focal areas of dysplasia and colon tumor incidence. Cancer. 1990;66(11):2350-6. [pmid: 2245391].
37 Dooper M M, Wassink L, M'Rabet L, Graus Y M. The modulatory effects of prostaglandin-E on cytokine production by human peripheral blood mononuclear cells are independent of the prostaglandin subtype. Immunology. 2002;107(1):152-9. [pmid: 12225374]. [pmcid: 1782765].
38 Drnek F, Rydlo O. [Czech]. Ceskoslovenska Gynekologie. 1982;47(10):770. [pmid: 7159953].
39 du Toit P J, van Aswegen C H, du Plessis D J. The effect of gamma-linolenic acid and eicosapentaenoic acid on urokinase activity. Prostaglandins Leukotrienes & Essential Fatty Acids. 1994;51(2):121-4.
40 Erickson K L. Is there a relation between dietary linoleic acid and cancer of the breast, colon, or prostate?[comment]. American Journal of Clinical Nutrition. 1998;68(1):5-7. [pmid: 9665090].
41 Erickson K, Hubbard N. Dietary fish oil modulation of macrophage tumoricidal activity. Nutrition. 1996;12(1 supp):S34-S38. [pmid: 8850218].
42 Eritsland J. Safety considerations of polyunsaturated fatty acids. [Review] [73 refs]. American Journal of Clinical Nutrition. 2000;71(1 Suppl):197S-201S. [pmid: 10617971].
43 Fan Y Y, Spencer T E, Wang N, Moyer M P, Chapkin R S. Chemopreventive n-3 fatty acids activate RXRalpha in colonocytes. Carcinogenesis. 2003;24(9):1541-8. [pmid: 12844485].
44 Funahashi H, Imai T, Mase T, et al. Seaweed prevents breast cancer?. Japanese Journal of Cancer Research. 2001;92(5):483-7. [pmid: 11376555].
45 Gonzalez M J. Dietary fat, fish oil and tumor growth: A perspective. Journal of Optimal Nutrition. 1995;4(1):5-8.
46 Gonzalez M J. The emerging field of nutritional tumorigenesis: The role of omega-3 fatty acids. Journal of Orthomolecular Medicine. 1994;9(1):51-3.
47 Hauenschild A, Zygmunt M, Munstedt K. Diet. Gynakologe. 2000;33(1):11-7.
48 Hawkins R A, Sangster K, Arends M J. The apoptosis-inducing effects of polyunsaturated fatty acids (PUFAs) on benign and malignant breast cells in vitro. Breast. 1999;8(1):16-20.
49 Hellerstein M. Antimitotic peptide characterized from soybean: role in protection from cancer?. [Review] [73 refs]. Nutrition Reviews. 1999;57(11):359-61. [pmid: 10628189].
50 Hilakivi Clarke L, Clarke R, Lippman M. The influence of maternal diet on breast cancer risk among female offspring. Nutrition. 1999;15(5):392-401. 148 ref. [pmid: 10355854].
51 Hirose M, Masuda A, Ito N, Kamano K, Okuyama H. Effects of dietary perilla oil, soybean oil and safflower oil on 7,12-dimethylbenz[a]anthracene (DMBA) and 1,2-dimethyl-hydrazine (DMH)-induced mammary gland and colon carcinogenesis in female SD rats. Carcinogenesis. 1990;11(5):731-5. [pmid: 2110511].
52 Holborow P. Melanoma and fatty acids. [comment]. New Zealand Medical Journal. 1991;104(904):19. [pmid: 2008253].
53 Hoskins J. Symposium on nutrition, environment and cancer: Meeting held at Sheraton Hotel, Ankara, Turkey on 31st March to 3rd April, 2002. Indoor & Built Environment. 2002;11(3):178-9.
54 Istfan N W, Wan J M, Bistrian B R. Nutrition and tumor promotion: in vivo methods for measurement of cellular proliferation and protein metabolism. [Review] [61 refs]. Jpen: Journal of Parenteral & Enteral Nutrition. 1992;16(6 Suppl):76S-82S. [pmid: 1287229].
55 Kamano K, Okuyama H, Konishi R, Nagasawa H. Effects of a high-linoleate and a high-alpha-linolenate diet on spontaneous mammary tumourigenesis in mice. Anticancer Res. 1989;9(6):1903-8. [pmid: 2627137].
56 Karmali R A, Reichel P, Cohen L A, et al. The effects of dietary omega-3 fatty acids on the DU-145 transplantable human prostatic tumor. Anticancer. 1987;7(6):1173-9.
57 Karmali RA, Nelson GJ. Fatty acid metabolism and biochemical mechanisms in cancer. Health Effects of Dietary Fatty Acids. 1991, 150–156; 28 Ref.
58 Kehn P, Fernandes G. The importance of omega-3 fatty acids in the attenuation of immune-mediated diseases. Journal of Clinical Immunology. 2001;21(2):99-101. [pmid: 11332659].
59 Kelly F J. The metabolic role of n-3 polyunsaturated fatty acids: relationship to human disease. [Review] [36 refs]. Comparative Biochemistry & Physiology A-Comparative Physiology. 1991;98(34):581-5.
60 Khoo D E, Habib N A. Fats and cancer. [Review] [37 refs]. West of England Medical Journal. 1990;105(1):18-9. [pmid: 2194554].
61 Lamartiniere C A. Protection against breast cancer with genistein: a component of soy. [Review] [24 refs]. American Journal of Clinical Nutrition. 2000;71(6 Suppl):1705S-7S. discussion 1708S–9S. [pmid: 10837323].
62 Lindner M A. A fish oil diet inhibits colon cancer in mice. Nutr Cancer. 1991;15(1):1-11. [pmid: 2017394].
63 Llor X, Pons E, Roca A, et al. The effects of fish oil, olive oil, oleic acid and linoleic acid on colorectal neoplastic processes. Clinical Nutrition. 2003;22(1):71-9. [pmid: 12553953].
64 Lowell J A, Parnes H L, Blackburn G L. Dietary immunomodulation: beneficial effects on oncogenesis and tumor growth. [Review] [41 refs]. Critical Care Medicine. 1990;18(2 Suppl):S145-8. [pmid: 2404668].
65 Maehle L, Eilertsen E, Mollerup S, Schonberg S, Krokan H E, Haugen A. Effects of n-3 fatty acids during neoplastic progression and comparison of in vitro and in vivo sensitivity of two human tumour cell lines. British Journal of Cancer. 1995;71(4):691-6. [pmid: 7710930].
66 Marshall L A, Szczesniewski A, Johnston P V. Dietary alpha-linolenic acid and prostaglandin synthesis: a time course study. Am J Clin Nutr. 1983;38(6):895-900. [pmid: 6316775].
67 McCarty M F. Fish oil may impede tumour angiogenesis and invasiveness by down-regulating protein kinase C and modulating eicosanoid production. [Review] [120 refs]. Medical Hypotheses. 1996;46(2):107-15. [pmid: 8692033].
68 McEntee M F, Whelan J. Dietary polyunsaturated fatty acids and colorectal neoplasia. [Review] [78 refs]. Biomedicine & Pharmacotherapy. 2002;56(8):380-7.
69 Narisawa T, Fukaura Y, Yazawa K, Ishikawa C, Isoda Y, Nishizawa Y. Colon cancer prevention with a small amount of dietary perilla oil high in alpha-linolenic acid in an animal model. Cancer. 1994;73(8):2069-75. [pmid: 7908858].
70 Nishino H. Study on cancer preventive substances in soybeans. Soy-Protein-Research,-Japan. 2000;3:59-62. 1 Ref.
71 Nordoy A. Fish oils in clinical medicine. Journal of Internal Medicine. 1989;225(3):145-6. [pmid: 2703796].
72 O'Connor T P. Dietary fat, calories and cancer. Boletin - Asociacion Medica De Puerto Rico. 1986;78(1):26-8. [pmid: 3006716].
73 Onogi N, Okuno M, Komaki C, et al. Suppressing effect of perilla oil on azoxymethane-induced foci of colonic aberrant crypts in rats. Carcinogenesis. 1996;17(6):1291-6. [pmid: 8681445].
74 Pandalai P K, Pilat M J, Yamazaki K, Naik H, Pienta K J. The effects of omega-3 and omega-6 fatty acids on in vitro prostate cancer growth. Anticancer Res. 1996;16(2):815-20. [pmid: 8687134].
75 Pritchard G A, Jones D L, Mansel R E. Lipids in breast carcinogenesis. British Journal of Surgery. 1989;76(10):1069-73. [pmid: 2557113].
76 Przybyszewski W M, Widel M. [Review] [52 refs] [Polish]. Postepy Higieny i Medycyny Doswiadczalnej. 2002;56(5):589-602. [pmid: 12587427].
77 Rao G N, Ney E, Herbert R A. Effect of melatonin and linolenic acid on mammary cancer in transgenic mice with c-neu breast cancer oncogene. Breast Cancer Research & Treatment. 2000;64(3):287-96. [pmid: 11200779].
78 Reddy B S. Dietary fat, calories, and fiber in colon cancer. Preventive Medicine. 1993;22(5):738-49. [pmid: 8234214].
79 Reddy B S, Burill C, Rigotty J. Effects of diets high in omega-3 and omega-6 fatty acids on initiation and postinitiation stages of colon carcinogenesis. Cancer-Research-Baltimore. 1991;51(2):487-91. 43 ref.
80 Roebuck B D. Dietary fat and the development of pancreatic cancer. [Review] [37 refs]. Lipids. 1992;27(10):804-6. [pmid: 1435099].
81 Rogers A E, Zeisel S H, Groopman J. Diet and carcinogenesis. [Review]. Carcinogenesis. 1993;14(11):2205-17. [pmid: 8242845].
82 Romero Cagigal I, Ferruelo Alonso A, Berenguer Sanchez A. Diet and prostate cancer. Actas Urologicas Espanolas. 2003;27(6):399-409. [pmid: 12918146].
83 Rose D P, Connolly J M. Effects of fatty acids and inhibitors of eicosanoid synthesis on the growth of a human breast cancer cell line in culture. Cancer. 1990;50(22):7139-44.
84 Rose D P, Connolly J M. Regulation of tumor angiogenesis by dietary fatty acids and eicosanoids. [Review] [115 refs]. Nutrition & Cancer. 2000;37(2):119-27. [pmid: 11142082].
85 Rose D P, Connolly J M, Liu X H. Diet and breast cancer: opportunities for prevention and intervention. [Review] [51 refs]. Progress in Clinical & Biological Research. 1997;396:147-58. [pmid: 9108596].
86 Sauer L A, Dauchy R T, Blask D E. Polyunsaturated fatty acids, melatonin, and cancer prevention. Biochemical-Pharmacology. 2001;61(12):1455-62. 61 ref. [pmid: 11377374].
87 Scholar E M, Violi L A, Newland J, Bresnick E, Birt D F. The effect of dietary fat on metastasis of the Lewis lung carcinoma and the BALB/c mammary carcinoma. Nutr. 1989;12(2):109-19.
88 Senzaki H, Iwamoto S, Ogura E, et al. Dietary effects of fatty acids on growth and metastasis of KPL-1 human breast cancer cells in vivo and in vitro. Anticancer Research. 1998;18(3A):1621-7. [pmid: 9673380].
89 Senzaki H, Tsubura A, Takada H. Effect of eicosapentaenoic acid on the suppression of growth and metastasis of human breast cancer cells in vivo and in vitro. [Review] [53 refs]. World Review of Nutrition & Dietetics. 2001;88:117-25. [pmid: 11935944].
90 Simopoulos A P. Summary of the NATO advanced research workshop on dietary omega 3 and omega 6 fatty acids: biological effects and nutritional essentiality. [Review] [56 refs]. Journal of Nutrition. 1989;119(4):521-8. [pmid: 2564887].
91 Smyth P P. The thyroid, iodine and breast cancer.[comment]. [Review] [45 refs]. Breast Cancer Research. 2003;5(5):235-8. [pmid: 12927031]. [pmcid: 314438].
92 Spiers M. An ancient bean: a review of soybeans and their possible role in chemoprevention and treatment. Journal-of-the-New-Zealand-Dietetic-Association. 1998;52(1):43-5. 24 ref.
93 Stavric B. Role of chemopreventers in human diet. [Review]. Clinical Biochemistry. 1994;27(5):319-32. [pmid: 7867212].
94 Stillwell W, Jenski L. International workshop on cellular and molecular aspects of omega-3 fatty acids and cancer. Journal of Lipid Research. 2002;43(9):1579-80. [pmid: 12235190].
95 Stoll B A. Essential fatty acids, insulin resistance, and breast cancer risk. Nutrition & Cancer. 1998;31(1):72-7. [pmid: 9682252].
96 Su S J, Yeh T M, Lei H Y, Chow N H. The potential of soybean foods as a chemoprevention approach for human urinary tract cancer. Clinical Cancer Research. 2000;6(1):230-6. [pmid: 10656454].
97 Tezabwala B U, Bennett M, Grundy S M. Immunotoxicity of polyunsaturated fatty acids in serum-free medium. Immunopharmacology & Immunotoxicology. 1995;17(2):365-83. [pmid: 7650296].
98 Tinsley I J, Schmitz J A, Whanger P D. Effect of dietary fatty acids on tumorigenesis. Federation-Proceedings. 1980;39(3):I-647.
99 Tisdale M J. Mechanism of lipid mobilization associated with cancer cachexia: interaction between the polyunsaturated fatty acid, eicosapentaenoic acid, and inhibitory guanine nucleotide-regulatory protein. [Review] [37 refs]. Prostaglandins Leukotrienes & Essential Fatty Acids. 1993;48(1):105-9.
100 Tisdale M. Inhibition of lipolysis and muscle protein degredation by EPA in cancer cachexia. Nutrition. 1996;12(1 supp):S31-S33. [pmid: 8850217].
101 Tiwari R K, Mukhopadhyay B, Telang N T, Osborne M P. Modulation of gene expression by selected fatty acids in human breast cancer cells. Anticancer Research. 1991;11(4):1383-8. [pmid: 1684095].
102 Utsunomiya T, Shimada M, Rikimaru T, et al. Correspondence re: M. Kondo et al., Increased expression of COX-2 in nontumor liver tissue is associated with shorter disease-free survival in patients with hepatocellular carcinoma. Clin. Cancer Res., 5: 4005–4012, 1999. [comment]. Clinical Cancer Research. 2000;6(12):4965-6. [pmid: 11156258].
103 Wahle K W, Heys S D. Cell signal mechanisms, conjugated linoleic acids (CLAs) and anti-tumorigenesis. [Review] [44 refs]. Prostaglandins Leukotrienes & Essential Fatty Acids. 2002;67(23):183-6.
104 Weaver B J, Holob B J. Health effects and metabolism of dietary eicosapentaenoic acid. [Review]. Progress in Food & Nutrition Science. 1988;12(2):111-50. [pmid: 2849141].
105 Weisburger J H. Lifestyle, health and disease prevention: the underlying mechanisms. [Review] [43 refs]. European Journal of Cancer Prevention. 2002;11(Suppl 2):S1-7. Aug. [pmid: 12570328].
106 Welsch C. The role of lipid peroxidation in growth suppression of human breast carcinoma by dietary fish oil. [Review] [36 refs]. Advances in Experimental Medicine & Biology. 1997;400B:849-60. [pmid: 9547638].
107 Welsch C W. Dietary fat, calories, and mammary gland tumorigenesis. [Review]. Advances in Experimental Medicine & Biology. 1992;322:203-22. [pmid: 1442296].
108 Yagasaki K. Dietary control of abnormal lipid metabolism secondary to hypothyroidism, cancer and inflammatory diseases. Recent-Research-Developments-in-Lipids-Research. 1998;2(1):21-7. 51 ref.
109 Yagasaki K. Evaluation of therapeutic potential of dietary manipulations and food factors against nephritis and cancer by in vivo and in vitro disease models. Nippon Eiyo Shokuryo Gakkaishi = Journal of the Japanese Society of Nutrition and Food Science 2000; 45.
110 Yetiv J. Clinical applications of fish oils. Journal of the American Medical Association. 1988;260(5):665-70. [pmid: 3292794].
111 Yonekura I, Sato A. Igakuno Ayuni. 1989;150:233-4.
112 Zevenbergen J L, Rudrum M. The role of polyunsaturated fatty acids in the prevention of chronic diseases. Fett-Wissenschaft-Technologie. 1993;95(12):456-60. 40 ref.

### Rejected Study Design Descriptive (n = 26)

1 Anonymous. Abbott Symposium. New developments in management of tumor-induced weight loss. [German]. Krankenpflege Journal 2002;40(10–12)318–21.
2 Anonymous. Good for the heart but not for the prostate? The alpha-linolenic acid dilemma. [Review]. Harvard Mens Health Watch 2002; 6(6)1–3
3 Anonymous. Mediterranean diet for cancer prevention. Health News 1998; 4(9):7.
4 Ansari M S, Gupta N P, Hemal A K. Chemoprevention of carcinoma prostate: A review. International Urology & Nephrology. 2002;34(2):207-14. [pmid: 12775097].
5 Barber M D. Diet and prevention of cancer. Consumption of oily fish should be encouraged. [comment]. BMJ. 1999;319(7203):187. author reply 187–8. [pmid: 10498414].
6 Bruce W R, Wolever T M, Giacca A. Mechanisms linking diet and colorectal cancer: the possible role of insulin resistance. [Review]. Nutrition & Cancer. 2000;37(1):19-26. [pmid: 10965515].
7 Duprey P A. High-fiber diet and colorectal adenomas. [comment]. New England Journal of Medicine. 2000;343(10):737. author reply 737–8. [pmid: 10979769].
8 Eastwood GL. Colon cancer: polyps, prevention, and politics. [Review]. Transactions of the American Clinical & Climatological Association. 109:107–26; Discussion 126–8, 1998.
9 Ente G. Alternative medicine: An update, number 7. Children's Hospital Quarterly. 2000;11(4):155-9.
10 Foran J A, Glenn B S, Silverman W. Increased fish consumption may be risky. JAMA. 1989;262(1):28. [pmid: 2733118].
11 Gottlieb N. “Soybean” in a Haystack? pinpointing an anti-cancer effect. Journal of the National Cancer Institute. 1999;91(19):1610-2. [pmid: 10511585].
12 Jatoi A, Thomas C R J. Esophageal cancer and the esophagus: challenges and potential strategies for selective cytoprotection of the tumor-bearing organ during cancer treatment. Seminars in Radiation Oncology. 2002;12(1 Suppl 1):62-7. [pmid: 11917287].
13 Joossens J V. Dietary fat and cancer. Acta Cardiologica. 1989;44(6):457-9. [pmid: 2626904].
14 Kasper H. Mediterranean diet lowers the cancer-related mortality rate. Medizinische Welt. 2001;52(3):47a-8a.
15 Lechky O. Researchers hope to determine if link exists between high-fat diet, breast cancer. CMAJ Canadian Medical Association Journal. 1997;156(5):693-4.
16 Leitzmann M F, Giovannucci E L. Commentary: Can dietary fatty acids affect colon cancer risk?. International Journal of Epidemiology. 2003;32(2):209-10. [pmid: 12714538].
17 Messina M, Barnes S. The role of soy products in reducing risk of cancer. J. 1991;83(8):541-6.
18 Morison I M. Comments on a published paper: Abe ‘Infantile Leukemia and Soybeans’. [comment]. Leukemia. 2000;14(3):524-5. [pmid: 10720157].
19 Pienta K J, Esper P S. Is dietary fat a risk factor for prostate cancer?. Journal of the National Cancer Institute. 1993;85(19):1538-1540. [pmid: 8411222].
20 Simopoulos A P. Fat intake, obesity, and cancer of the breast and endometrium. Medical Oncology & Tumor Pharmacotherapy. 1985;2(3):125-35. [pmid: 4068799].
21 Simpson L O. Melanoma and fatty acids. [comment]. New Zealand Medical Journal. 1991;104(905):48. [pmid: 1996191].
22 Tokudome S, Yokoyama Y, Kamiya T, et al. Rationale and study design of dietary intervention in patients polypectomized for tumors of the colorectum. Japanese-Journal-of-Clinical-Oncology. 2002;32(12):550-3. [pmid: 12578906].
23 Wall L. Fish oil supplementation in patients with advanced cancer. [comment]. Journal of Clinical Oncology. 2003;21(18):3545. author reply 3545–6. [pmid: 12972541].
24 Weisburger J H. Eat to live, not live to eat. [Review] [59 refs]. Nutrition. 2000;16(9):767-73. [pmid: 11032452].
25 Wigmore S J, Falconer J S, Fearon K C. Fatty acids for treating pancreatic cancer. BMJ. 1994;309(6953):544. [pmid: 8086935].
26 Ziegler J. Soybeans show promise in cancer prevention. Journal of the National Cancer Institute. 1994;86(22):1666-7. [pmid: 7966389].

### Rejected Study Design Review/Meta-Analysis (n = 283)

1 Fish oil. Alterdnative Medicine Review 2000; 5(6)576–80.
2 Abascal K, Yarnell E. Herbs and breast cancer: Research review of Seaweed, Rosemary, and Ginseng. Alternative & Complementary Therapies. 2001;7(1):32-6.
3 Ahn YO. Diet and stomach cancer in Korea. International Journal of Cancer. Suppl 10:7–9, 1997.
4 Alarcon de la Lastra Barranco M, Motilva V, Herrerias J. Mediterranean diet and health: Biological importance of olive oil. Current Pharmaceutical Design. 2001;7(10):933-50. [pmid: 11472248].
5 Alexander J. Immunonutrition: The role of omega-3 fatty acids. Nutrition. 1998;14(8):627-33. [pmid: 9684267].
6 Anderson J W, Smith B M, Washnock C S. Cardiovascular and renal benefits of dry bean and soybean intake. American Journal of Clinical Nutrition. 1999;70:464S-74S. [pmid: 10479219].
7 Anonymous. Fat intake and breast cancer: a controversial association. European Prospective Investigation on Cancer group in Spain. [Review][64 refs][Spanish]. Medicina Clinica 1997; 108(2):68–74.
8 Anonymous. Fish-oil supplementation reduces intestinal hyperproliferation in persons at risk for colon cancer. Nutrition Reviews 1993; 51(8):241–3.
9 Anonymous. Omega-3 white book. Omega-3 polyunsaturated fatty acids and oleic monounsaturated acids: Their role in health. Nutricion Clinica: Dietetica Hospitalaria 2002; 22(3):23–33.
10 Arab L, Mendez M, Eisenbrand G (ed.) et al. Controversies surrounding diet and breast cancer. Carcinogenic-Anticarcinogenic-Factors-in-Food:-Novel-Concepts?,-DFG-Symposium,-Kaiserslauten,-Germany,-4-7-October,-1998. 2000, 75–93; 86 Ref.
11 Assmann G, Backer Gde Bagnara S, Betteridge J et al. International consensus statement on olive oil and the Mediterranean diet: implications for health in Europe. European Journal of Cancer Prevention 1997; 30.
12 Babcock T, Helton W S, Espat N J. Eicosapentaenoic acid (EPA): an antiinflammatory omega-3 fat with potential clinical applications. [Review] [16 refs]. Nutrition. 2000;16(1112):1116-8. [pmid: 11118844].
13 Barber M D. Cancer cachexia and its treatment with fish-oil-enriched nutritional supplementation. [Review] [95 refs]. Nutrition. 2001;17(9):751-5. [pmid: 11527672].
14 Barber M D, Ross J A, Fearon K C. The anti-cachectic effect of fatty acids. [Review] [95 refs]. Proceedings of the Nutrition Society. 1998;57(4):571-6. [pmid: 10096118].
15 Barber MD, Hwang TL. Cancer cachexia and its treatment with fish-oil-enriched nutritional supplementation. Proceedings of the 21st Annual Meeting of the Parenteral and Enteral Nutrition Society of Asia, Taipei, Taiwan, November 9–12 2000 2001; 17(9):751–5; 95 ref.
16 Barre D. Potential of evening primrose, borage, black currant, and fungal oils in human health. Annals of Nutrition and Metabolism. 2001;45:47-57. [pmid: 11359029].
17 Bartram H P. Dietary fat and colon cancer development: problem of overfeeding or pharmacological effects?. Aktuelle-Ernahrungsmedizin. 1997;22(6):333-7. 32 ref.
18 Bartram H P, Kasper H. Impact of polyunsaturated fatty acids on development of colon cancer. Aktuelle-Ernahrungsmedizin. 1995;20(1):31-5. 34 ref.
19 Bartsch H, Nair J, Owen R W. Dietary polyunsaturated fatty acids and cancers of the breast and colorectum: emerging evidence for their role as risk modifiers. [Review] [84 refs]. Carcinogenesis. 1999;20(12):2209-18. [pmid: 10590211].
20 Biasco G, Paganelli G M. European trials on dietary supplementation for cancer prevention. [Review] [15 refs]. Annals of the New York Academy of Sciences. 1999;889:152-6. [pmid: 10668492].
21 Biasco G, Paganelli GM, Bradlow HL (ed.), Fishman J (ed.), Osborne MP. European trials on dietary supplementation for cancer prevention. Cancer Prevention: Novel Nutrient and Pharmaceutical Developments. Proceedings of the Strang International Cancer Prevention Conference Held in New York City, USA, 13–14 November 1998. Annals-of-the-New-York-Academy-of-Sciences. 1999, 889: 152–156; 15 Ref
22 Birt D F. Soybeans and cancer prevention: a complex food and a complex disease. [Review] [20 refs]. Advances in Experimental Medicine & Biology. 2001;492:1-10. [pmid: 11480658].
23 Blok W, Katan M, Van der Meer J. Modulation of inflammation and cytokine production by dietary (n-3) fatty acids. Journal of Nutrition. 1996;126(6):1515-33. [pmid: 8648424].
24 Boeing H. Epidemiological research in stomach cancer: progress over the last ten years. [Review] [93 refs]. Journal of Cancer Research & Clinical Oncology. 1991;117(2):133-43. [pmid: 2036128].
25 Booyens J, van der Merwe C F, Katzeff I E. Chronic arachidonic acid eicosanoid imbalance: a common feature in coronary artery disease, hypercholesterolemia, cancer and other important diseases. Significance of desaturase enzyme inhibition and of the arachidonic acid desaturase-independent pathway. Medical Hypotheses. 1985;18(1):53-60. [pmid: 2866439].
26 Borlak J T, Welch V A. Health implications of fatty acids. Arzneimittel-Forschung. 1994;44(8):976-81. [pmid: 7945546].
27 Bosetti C, Kolonel L, Negri E, et al. A pooled analysis of case-control studies of thyroid cancer. VI. Fish and shellfish consumption. Cancer Causes & Control. 2001;12(4):375-82. [pmid: 11456234].
28 Bougnoux P. n-3 polyunsaturated fatty acids and cancer [Review] [50 refs]. Current Opinion in Clinical Nutrition & Metabolic Care. 1999;2(2):121-6. [pmid: 10453342].
29 Bougnoux P. Polyunsaturated fatty acids and breast cancer. Cancer Radiotherapie. 1999;3(SUPPL. 1):184-95.
30 Bougnoux P. [Polyunsaturated fatty acids and cancer]. [French]. Revue Du Praticien. 2000;50(14):1513-5. [pmid: 11068612].
31 Bradlow H L, Sepkovic D W. Diet and breast cancer. Annals of the New York Academy of Sciences. 2002;963:(Pp 247-267). [pmid: 12095951].
32 Briese V. Nutrition factors and breast cancer. Phyto-estrogens and trans-fatty acids as potentially protective substances. [German]. Krankenpflege Journal. 1998;36(3):57-60. [pmid: 9592475].
33 Brown J, Byers T, Thompson K, Eldridge B, Doyle C, Williams A M. Nutrition during and after cancer treatment: A guide for informed choices by cancer survivors. Ca: a Cancer Journal for Clinicians. 2001;51(3):153-87. [pmid: 11577495].
34 Brown J K, Byers T, Doyle C, et al. Nutrition and physical activity during and after cancer treatment: An American Cancer Society Guide for informed choices. Ca: a Cancer Journal for Clinicians. 2003;53(5):268-91. [pmid: 14570227].
35 Brown R O. Immune-enhancing diets: Improving outcomes in multiple trauma and gastrointestinal cancer resection. P & T. 2001;26(9):468-72.
36 Buzina R, Suboticanec K, Saric M. Diet patterns and health problems: Diet in southern europe. Ann Nutr Metab. 1991;35(supp 1):32-40. [pmid: 1888126].
37 Byers T, Gieseker K, Ip C (ed.), Carroll K. Issues in the design and interpretation of studies of fatty acids and cancer in humans. Workshop on Individual Fatty Acids and Cancer Proceedings of a symposium held in Washington; DC, USA, June 4–5, 1996. American-Journal-of-Clinical-Nutrition. 1997, 66(Supplement 6): 1541S–7S; 52 ref.
38 Byers T, Nestle M, McTiernan A, et al. American Cancer Society guidelines on nutrition and physical activity for cancer prevention: Reducing the risk of cancer with healthy food choices and physical activity. Ca: a Cancer Journal for Clinicians. 2002;52(2):92-119. [pmid: 11929008].
39 Capone S L, Bagga D, Glaspy J A. Relationship between omega-3 and omega-6 fatty acid ratios and breast cancer. Nutrition. 1997;13(9):822-4. [pmid: 9290101].
40 Carpentier Y A. Omega-3 fatty acids: From nutrition to pharmacological properties. Clinical Nutrition. 2001;20(SUPPL. 4):6-7.
41 Carroll K K. Dietary fats and cancer. [Review] [60 refs]. American Journal of Clinical Nutrition. 1991;53(4 Suppl):1064S-7S. [pmid: 2012020].
42 Carroll K K. Neutral fats and cancer. Cancer Research. 1981;41(9 Pt 2):3695-9. [pmid: 7260926].
43 Carroll K K, Braden L M. Dietary fat and mammary carcinogenesis. Nutrition & Cancer. 1984;6(4):254-9. [pmid: 6443636].
44 Carroll K K, Braden L M, Bell J A, Kalamegham R. Fat and cancer. Cancer. 1986;58(8 Suppl):1818-25. [pmid: 3756806].
45 Carter J P, Saxe G P, Newbold V, Peres C E, Campeau R J, Bernal-Green L. Hypothesis: dietary management may improve survival from nutritionally linked cancers based on analysis of representative cases. J. 1993;12(3):209-26.
46 Casimiro C. Etiopathogenic factors in colorectal cancer. Nutritional and life-style aspects. 2 [Review] [63 refs] [Spanish]. Nutricion Hospitalaria. 2002;17(3):128-38. [pmid: 12149812].
47 Castro Gonzalez M I. Omega 3 fatty acids: benefits and sources. Interciencia. 2002;27(3):128-36. many ref.
48 Castronovo V. [Nutrition and cancer]. [Review] [54 refs] [French]. Revue Medicale De Liege. 2003;58(4):231-9. [pmid: 12868327].
49 Chen W J, Yeh S L. Effects of fish oil in parenteral nutrition. Nutrition. 2003;19(3):275-9. [pmid: 12620534].
50 Chlebowski R, Palomares M, Lillington L, Grosvenor M. Recent implications of weight loss in lung cancer management. Nutrition. 1996;12(1 supp):S43-S47. [pmid: 8850220].
51 Choi S W, Mason J B. Nutritional chemoprevention of colorectal cancer. Clinical Perspectives in Gastroenterology. 2000;3(5):259-66.
52 Cohen L A. Nutrition and prostate cancer: a review. [Review] [75 refs]. Annals of the New York Academy of Sciences. 2002;963:148-55. Jun. [pmid: 12095940].
53 Colditz G A. Changing dietary patterns and cancer prevention: Alpha-linolenic acid health risks and benefits. Cancer Causes & Control. 2000;11(8):677-8. [pmid: 11065003].
54 Collett E D, Davidson L A, Lupton J R, Chapkin R S. Dietary fish oil reduces colon cancer risk. Current Organic Chemistry. 2000;4(11):1157-68.
55 Conklin K A. Dietary polyunsaturated fatty acids: impact on cancer chemotherapy and radiation. [Review] [119 refs]. Alternative Medicine Review. 2002;7(1):4-21. [pmid: 11896743].
56 Corliss J. Seafood fatty acids may lower cancer risk. Journal of the National Cancer Institute. 1989;81(20):1530-1. [pmid: 2795676].
57 Cowing B E, Saker K E. Polyunsaturated fatty acids and epidermal growth factor receptor/mitogen-activated protein kinase signaling in mammary cancer. Journal-of-Nutrition. 2001;131(4):1125-8. 44 ref. [pmid: 11285312].
58 Craig WJ. Phytochemicals: guardians of our health. Journal of the American Dietetic Association 1997; 97(10):Suppl-204.
59 Dajani E Z. Omega-3 fatty acids and bowel cancer. [comment]. Gastroenterology. 1993;104(4):1239-41. [pmid: 8462820].
60 Das U N, Ramos E J, Meguid M M. Metabolic alterations during inflammation and its modulation by central actions of omega-3 fatty acids. Current Opinion in Clinical Nutrition & Metabolic Care. 2003;6(4):413-9. [pmid: 12806215].
61 Das U N. Essential fatty acids in health and disease. Journal of the Association of Physicians of India. 1999;47(9):906-11. [pmid: 10778663].
62 Das U. Hypothesis: can glucose-insulin-potassium regimen in combination with polyunsaturated fatty acids suppress lupus and other inflammatory conditions? Prostaglandins,.Leukotrienes.and.Essential.Fatty.Acids 2001; 55.
63 Daviglus M, Sheeshka J, Murkin E. Health benefits from eating fish. Comments on Toxicology. 2002;8(6):345-74.
64 de Deckere E A. Possible beneficial effect of fish and fish n-3 polyunsaturated fatty acids in breast and colorectal cancer. [Review] [80 refs]. European Journal of Cancer Prevention. 1999;8(3):213-21. [pmid: 10443950].
65 de Lorgeril M, Salen P. Modified Cretan Mediterranean diet in the prevention of coronary heart disease and cancer. [Review]. World Review of Nutrition & Dietetics. 2000;87:1-23. [pmid: 10929524].
66 Demark-Wahnefried W. Prostate cancer and diet [7]. Urology. 1999;53(1):241-2.
67 Denisov L E, Prokhorovich E A, Vertkin A L, Odintsov S V, Martynov A I. [Fatty acids and malignant tumors]. [Review] [47 refs] [Russian]. Klinicheskaia Meditsina. 1992;70(78):20-3. [pmid: 1460819].
68 DePrimo S E, Shinghal R, Vidanes G, Brooks J D. Prevention of prostate cancer. [Review] [79 refs]. Hematology - Oncology Clinics of North America. 2001;15(3):445-57.
69 Dinarello C A, Endres S, Meydani S N, Meydani M, Hellerstein M K. Interleukin-1, anorexia, and dietary fatty acids. [Review] [11 refs]. Annals of the New York Academy of Sciences. 1990;587:332-8. [pmid: 2193579].
70 Dommels Y E M, Alink G M, Van Bladeren P J, Van Ommen B. Dietary n-6 and n-3 polyunsaturated fatty acids and colorectal carcinogenesis: Results from cultured colon cells, animal models and human studies. Environmental Toxicology & Pharmacology. 2002;11(34):297-308.
71 Drevon C A, Nenseter M S, Brude I R, Finstad H S, Kolset S O, Rustan A C. Omega-3 fatty acids - Nutritional aspects. Canadian Journal of Cardiology. 1995;11(SUPPL. G):47G-54G.
72 Dupertuis Y M, Genton L, Uldry C, Maisonneuve N, Karsegard V, Pichard C. [Review] [27 refs] [French]. Revue Medicale De La Suisse Romande. 2002;122(7):325-8. [pmid: 12212487].
73 Dupertuis Y M, Raguso C A, Buchegger F, Pichard C. [Review] [46 refs] [French]. Revue Medicale De La Suisse Romande. 2002;122(7):319-23. [pmid: 12212486].
74 Dwyer J T. Dietary fat and breast cancer: testing interventions to reduce risks. Advances in Experimental Medicine & Biology. 1992;Vol.322:Pp.155-83. [pmid: 1442293].
75 Dwyer JT, Ip C (ed.), Carroll K. Human studies on the effects of fatty acids on cancer: summary, gaps, and future research. Workshop on Individual Fatty Acids and Cancer Proceedings of a symposium held in Washington; DC, USA, June 4–5, 1996. American-Journal-of-Clinical-Nutrition. 1997, 66(Supplement 6): 1581S–6S; 32 ref.
76 Eastwood G L. Pharmacologic prevention of colonic neoplasms. Effects of calcium, vitamins, omega fatty acids, and nonsteroidal anti-inflammatory drugs. [Review] [124 refs]. Digestive Diseases. 1996;14(2):119-28. [pmid: 8653938].
77 Eastwood G L. A review of gastrointestinal epithelial renewal and its relevance to the development of adenocarcinomas of the gastrointestinal tract. Journal of Clinical Gastroenterology. 1995;21(SUPPL. 1):S1-S11. [pmid: 8774983].
78 Ellison N M, Chevlen E, Still C D, Dubagunta S. Supportive care for patients with pancreatic adenocarcinoma: symptom control and nutrition. [Review] [89 refs]. Hematology - Oncology Clinics of North America. 2002;16(1):105-21.
79 Eynard A R. Does chronic essential fatty acid deficiency constitute a pro-tumorigenic condition? [Review] [67 refs]. Medical Hypotheses. 1997;48(1):55-62. [pmid: 9049990].
80 Eynard A R. Potential of essential fatty acids as natural therapeutic products for human tumors. Nutrition. 2003;19(4):386-8. [pmid: 12679177].
81 Fair W R, Fleshner N E, Heston W. Cancer of the prostate: A nutritional disease?. Urology. 1997;50(6):840-8. [pmid: 9426711].
82 Fearon K C H. The anticancer and anticachectic effects of n-3 fatty acids. Clinical Nutrition. 2002;21(SUPPL. 2):73-7. [pmid: 11884016].
83 Fearon K C H. Nutritional support in cancer. Clinical Nutrition. 2001;20(SUPPL. 1):187-90. [pmid: 11327750].
84 Feldman E B. Dietary intervention and chemoprevention--1992 perspective. [Review] [17 refs]. Preventive Medicine. 1993;22(5):661-6. [pmid: 8234205].
85 Feldman E B. Breast cancer risk and intake of fat. Nutrition-Reviews. 1999;57(11):353-6. 8 ref. [pmid: 10628187].
86 Fernandes G, Troyer D A, Jolly C A. The effects of dietary lipids on gene expression and apoptosis. [Review] [60 refs]. Proceedings of the Nutrition Society. 1998;57(4):543-50. [pmid: 10096114].
87 Fernandes G, Venkatraman J. Role of omega-3 fatty acids in health and disease. Nutrition Research. 1993;13(1):S19-S45.
88 Fisher D, Watson RR. Cancer and nutrition. Functional-Foods-and-Nutraceuticals-in-Cancer-Prevention. 2003, 27–36; 33 Ref.
89 Forti G, Selli C. Prospects for prostatic cancer incidence and treatment by the year 2000. International Journal of Andrology. 1996;19(1):1-10. [pmid: 8698531].
90 Fournier D B, Erdman J W J, Gordon G B. Soy, its components, and cancer prevention: a review of the in vitro, animal, and human data. Cancer. 1998;7(11):1055-65.
91 Frascio F, Giacosa A. Pharmacological management of anorexia and cachexia in gastrointestinal cancer patients. Acta Endoscopica. 2001;31(4):509-14.
92 Friedman M, Brandon D L. Nutritional and health benefits of soy proteins. Journal of Agricultural & Food Chemistry. 2001;49(3):1069-86. [pmid: 11312815].
93 Galli C, Butrum R. Dietary omega 3 fatty acids and cancer: an overview. [Review] [61 refs]. World Review of Nutrition & Dietetics. 1991;66:446-61. [pmid: 2053362].
94 Gerber B, Muller H, Reimer T, Krause A, Friese K. Nutrition and lifestyle factors on the risk of developing breast cancer. Breast-Cancer-Research-and-Treatment. 2003;79(2):265-76. 136 ref. [pmid: 12825861].
95 German J B, Dillard C J, Whelan J. Biological effects of dietary arachidonic acid. Introduction. Journal of Nutrition. 1996;126(4 Suppl):1076S-80S. [pmid: 8642436].
96 Giacosa A, Frascio F, Sukkar S G, Roncella S. Food intake and body composition in cancer cachexia. [Review] [36 refs]. Nutrition. 1996;12(1 Suppl):S20-3. [pmid: 8850214].
97 Giovannucci E, Goldin B, Ip C 9 (ed.), Carroll K. The role of fat, fatty acids, and total energy intake in the etiology of human colon cancer. Workshop on Individual Fatty Acids and Cancer Proceedings of a symposium held in Washington; DC, USA, June 4–5, 1996. American-Journal-of-Clinical-Nutrition. 1997, 66(Supplement 6): 1564S–71S; 104 ref.
98 Godley P A. Essential fatty acid consumption and risk of breast cancer. Breast Cancer Research & Treatment. 1995;35(1):91-5. [pmid: 7612909].
99 Gogos C A, Skoutelis A, Kalfarentzos F. The effects of lipids on the immune response of patients with cancer. [Review] [38 refs]. Journal of Nutrition, Health & Aging. 2000;4(3):172-5.
100 Gomez Candela C. Paper on n-3 fatty acids: clinical studies. 1er Encuentro Nacional De Nutricion y Cancer, Madrid, 28–29 De Noviembre De 2002 2002; 22(6)56–8; 26 ref.
101 Gonzalez M J. Fish oil, lipid peroxidation and mammary tumor growth. Journal of the American College of Nutrition. 1995;Vol 14(4):(Pp 325-335). [pmid: 8568108].
102 Grant W B. Fish consumption, cancer, and Alzheimer disease. [comment]. American Journal of Clinical Nutrition. 2000;71(2):599-600. [pmid: 10648277].
103 Greenwald P. NCI cancer prevention and control research. Preventive Medicine. 1993;22(5):642-60. [pmid: 8234204].
104 Greenwald P, Clifford C, Pilch S, Heimendinger J, Kelloff G. New directions in dietary studies in cancer: the National Cancer Institute. [Review] [47 refs]. Advances in Experimental Medicine & Biology. 1995;369:229-39. [pmid: 7598012].
105 Greenwald P, Clifford C K, Milner J A. Diet and cancer prevention. [Review]. European Journal of Cancer. 2001;37(8):948-65. [pmid: 11334719].
106 Greenwald P, Sherwood K, McDonald S S. Fat, caloric intake, and obesity: lifestyle risk factors for breast cancer. [Review] [76 refs]. Journal of the American Dietetic Association. 1997;97(7 Suppl):S24-30. [pmid: 9216564].
107 Grimble R F. Modification of inflammatory aspects of immune function by nutrients. Nutrition Research. 1998;18(7):1297-317.
108 Guthrie N, Carroll K K. Specific versus non-specific effects of dietary fat on carcinogenesis. [Review] [124 refs]. Progress in Lipid Research. 1999;38(3):261-71. [pmid: 10664796].
109 Haggerty W J. Flax. Ancient herb and modern medicine. HerbalGram. 1999;No. 45:51-50. 50 Ref.
110 Hakim I. Mediterranean diets and cancer prevention. [comment]. Archives of Internal Medicine. 1998;158(11):1169-70. [pmid: 9625394].
111 Hardman W E. Omega-3 fatty acids to augment cancer therapy. [Review] [72 refs]. Journal of Nutrition. 2002;132(11 Suppl):3508S-12S. [pmid: 12421878].
112 Haumann B F. Nutritional aspects of n-3 fatty acids. INFORM -International-News-on-Fats,-Oils-and-Related-Materials. 1997;8(5):428-47.
113 Hazra A, Tripathi S K, Ghosh A. Pharmacology and therapeutic potential of the n-3 polyunsaturated fatty acids, eicosapentaenoic acid (EPA) and docosahexaenoic acid (DHA) in fish oils. Indian Journal of Pharmacology. 1999;31(4):247-64.
114 Heller A, Koch T, Schmeck J, Van Ackern C. Lipid mediators in inflammatory disorders. Drugs. 1998;55(4):487-96. [pmid: 9561339].
115 Henderson M M. Role of intervention trials in research on nutrition and cancer. Cancer Research. 1992;52(7 Suppl):2030s-4s. [pmid: 1544137].
116 Heslin M J, Brennan M F. Advances in perioperative nutrition: cancer. [Review] [72 refs]. World Journal of Surgery. 2000;24(12):1477-85. [pmid: 11193711].
117 Heyden S. Polyunsaturated fatty acids, serum cholesterol and cancer. The end of the hypotheses. Munchener-Medizinische-Wochenschrift. 1990;132(3132):476-9. 21 ref.
118 Heyland D K, Cook D J, Guyatt G H. Does the formulation of enteral feeding products influence infectious morbidity and mortality rates in the critically ill patient? A critical review of the evidence. Critical Care Medicine. 1994;22(7):1192-202. [pmid: 8026212].
119 Heys S D, Gough D B, Khan L, Eremin O. Nutritional pharmacology and malignant disease: a therapeutic modality in patients with cancer. [Review]. British Journal of Surgery. 1996;83(5):608-19. [pmid: 8689201].
120 Hill H A, Austin H. Nutrition and endometrial cancer. [Review] [64 refs]. Cancer Causes & Control. 1996;7(1):19-32. [pmid: 8850432].
121 Hill M J. Mechanisms of diet and colon carcinogenesis. [Review] [33 refs]. European Journal of Cancer Prevention. 1999;8(Suppl 1):S95-8. Dec. [pmid: 10772423].
122 Hjartaker A. Fish consumption and risk of breast, colorectal and prostate cancer: A critical evaluation of epidemiological studies. Scandinavian Journal of Nutrition/Naringsforskning. 2003;47(3):111-22.
123 Holder H. Nursing management of nutrition in cancer and palliative care. [Review][30 refs]. British Journal of Nursing 670; 12(11):667–8.
124 Horrocks L, Keo Y. Health benefits of docosahexaenoic acid (DHA). Pharmacological Research. 1999;40(3):211-25. [pmid: 10479465].
125 Howe G R, Aronson K J, Benito E, et al. The relationship between dietary fat intake and risk of colorectal cancer: evidence from the combined analysis of 13 case-control studies. Cancer Causes & Control. 1997;8(2):215-28. [pmid: 9134246].
126 Hsing A W. Essential fatty acids and prostate cancer: an emerging hypothesis?[comment]. Cancer Epidemiology, Biomarkers & Prevention. 1996;5(11):859-60.
127 Hunter D J, Spiegelman D, Adami H O, et al. Cohort studies of fat intake and the risk of breast cancer--a pooled analysis. [comment]. New England Journal of Medicine. 1996;334(6):356-61. [pmid: 8538706].
128 Imoberdorf R. Immuno-nutrition: Designer diets in cancer. Supportive Care in Cancer. 1997;5(5):381-6. [pmid: 9322350].
129 Inoue K, Takano H, Yoshikawa T. Fatty fish supplementation and risk of prostate cancer. [comment]. Lancet. 2001;358(9290):1367. [pmid: 11684247].
130 Jackson M J, Jackson M J, McArdle F, et al. Effects of micronutrient supplements on u.v.-induced skin damage. [Review] [15 refs]. Proceedings of the Nutrition Society. 2002;61(2):187-9. [pmid: 12133200].
131 Jacobson J S, Workman S B, Kronenberg F. Research on complementary/alternative medicine for patients with breast cancer: A review of the biomedical literature. Journal of Clinical Oncology. 2000;18(3):668-83. [pmid: 10653883].
132 Jankevicius F, Miller S M, Ackermann R. Nutrition and risk of prostate cancer. Urologia Internationalis. 2002;68(2):69-80. [pmid: 11834894].
133 Jatoi A, Loprinzi C L. Nutritional determinants of survival among patients with breast cancer. [Review] [60 refs]. Surgical Clinics of North America. 1999;79(5):1145-56. [pmid: 10572555].
134 Jatoi AJ, Loprinzi CL. Current management of cancer-associated anorexia and weight loss. [Review][44 refs]. Oncology (Huntington) 508-2001; 15(4):497–502.
135 Kamat A M, Lamm D L. Chemoprevention of bladder cancer. [Review] [75 refs]. Urologic Clinics of North America. 2002;29(1):157-68. [pmid: 12109342].
136 Karmali R. n-3 fatty acids: biochemical actions in cancer. [Review][24 refs]. Journal of Nutritional Science & Vitaminology. Spec No:148–52, 1992.
137 Karmali R A. Historical perspective and potential use of n-3 fatty acids in therapy of cancer cachexia. Nutrition. 1996;12(1 Suppl):S2-4. [pmid: 8850210].
138 Karmali RA. n-3 fatty acids and cancer. [Review][30 refs]. Journal of Internal Medicine. Supplement 1989; 225(731):197–200.
139 Kennedy A R. The evidence for soybean products as cancer preventive agents.[comment]. [Review] [92 refs]. Journal of Nutrition. 1995;125(3 Suppl):733S-43S. [pmid: 7884559].
140 Key T J, Fraser G E, Thorogood M, et al. Mortality in vegetarians and nonvegetarians: detailed findings from a collaborative analysis of 5 prospective studies. Am. 1999;70(3 Suppl):516S-24S.
141 Kim Y I, Mason J B. Nutrition chemoprevention of gastrointestinal cancers: A critical review. Nutrition Reviews. 1996;54(9):259-79. [pmid: 9009668].
142 Knittweis J. Weight loss in cancer and Alzheimer's disease is mediated by a similar pathway. [Review] [40 refs]. Medical Hypotheses. 1999;53(2):172-4. [pmid: 10532714].
143 Kohlmeier L. Biomarkers of fatty acid exposure and breast cancer risk. [Review] [87 refs]. American Journal of Clinical Nutrition. 1997;66(6 Suppl):1548S-56S. [pmid: 9394714].
144 Kohlmeier L, Mendez M. Controversies surrounding diet and breast cancer. Proceedings-of-the-Nutrition-Society. 1997;56(1B):369-82. 4 pp. of ref. [pmid: 9168546].
145 Kris-Etherton P M, Hecker K D, Bonanome A, et al. Bioactive compounds in foods: their role in the prevention of cardiovascular disease and cancer. [Review] [196 refs]. American Journal of Medicine. 2002;113(Suppl 9B):71S-88S. Dec 30. [pmid: 12566142].
146 Kromhout D. The importance of N-6 and N-3 fatty acids in carcinogenesis. [Review] [17 refs]. Medical Oncology & Tumor Pharmacotherapy. 1990;7(23):173-6. [pmid: 2232934].
147 Kucuk O. Chemoprevention of prostate cancer. Cancer & Metastasis Reviews. 2002;21(2):111-24. [pmid: 12465750].
148 Kune G A. Eating fish protects against some cancers: epidemiological and experimental evidence for a hypothesis. Journal-of-Nutritional-Medicine. 1990;1(2):139-44. 36 ref.
149 Kurzer M S. Phytoestrogen supplement use by women. [Review] [70 refs]. Journal of Nutrition. 2003;133(6):1983S-6S. [pmid: 12771350].
150 Kushi L H, Lenart E B, Willett W C. Health implications of Mediterranean diets in light of contemporary knowledge. 2. Meat, wine, fats, and oils. [Review] [155 refs]. American Journal of Clinical Nutrition. 1995;61(6 Suppl):1416S-27S. [pmid: 7754997].
151 La Vecchia C, Chatenoud L, Altieri A, Tavani A. Nutrition and health: epidemiology of diet, cancer and cardiovascular disease in Italy. Nutrition Metabolism & Cardiovascular Diseases. 2001;11(4 Suppl):10-5.
152 Lands W E, Hamazaki T, Yamazaki K, et al. Changing dietary patterns. Am. 1990;51(6):991-3.
153 Laviano A, Meguid M M. Nutritional issues in cancer management. Nutrition. 1996;12(5):358-71. [pmid: 8875522].
154 Law M. Dietary fat and adult diseases and the implications for childhood nutrition: an epidemiologic approach. [Review] [42 refs]. American Journal of Clinical Nutrition. 2000;72(5 Suppl):1291S-6S. [pmid: 11063471].
155 Lee M M, Lin S S. Dietary fat and breast cancer. [Review] [113 refs]. Annual Review of Nutrition. 2000;20:221-48. [pmid: 10940333].
156 Levy J, Turkish A. Protective nutrients. Current Opinion in Gastroenterology. 2002;18(6):717-22. [pmid: 17033354].
157 Lewis CJ, Yetley EA, Byers T (ed.), Dickson JH. Health claims and observational human data: relation between dietary fat and cancer. The Role of Epidemiology in Determining When Evidence Is Sufficient to Support Nutrition Recommendations 1999; 69(6):1357S–64S; 20 ref.
158 Lewis N M, Seburg S, Flanagan N L. Enriched eggs as a source of N-3 polyunsaturated fatty acids for humans. [Review] [21 refs]. Poultry Science. 2000;79(7):971-4. [pmid: 10901195].
159 Li D. Omega-3 fatty acids and non-communicable diseases. Chinese Medical Journal. 2003;116(3):453-8. [pmid: 12781058].
160 Lipworth L, Martinez M E, Angell J, Hsieh C C, Trichopoulos D. Olive oil and human cancer: an assessment of the evidence. Preventive Medicine. 1997;26(2):181-90. [pmid: 9085386].
161 Macrae F A. Fat and calories in colon and breast cancer: from animal studies to controlled clinical trials. [Review] [47 refs]. Preventive Medicine. 1993;22(5):750-66. [pmid: 8234215].
162 Magalova T. Nutrition and female breast tumors [Review]. Bratislavske Lekarske Listy. 1999;100(9):503-14. [pmid: 10645042].
163 Mantovani G, Maccio A, Madeddu C, Massa E. Cancer-related cachexia and oxidative stress: Beyond current therapeutic options. Expert Review of Anticancer Therapy. 2003;3(3):381-92. [pmid: 12820780].
164 Martinez M E, Giovannucci E. Diet and the prevention of cancer. Cancer & Metastasis Reviews. 1997;16(34):357-76. [pmid: 9433645].
165 Mason J B. Diet, folate, and colon cancer. Current Opinion in Gastroenterology. 2002;18(2):229-34. [pmid: 17033292].
166 Mason J B, Kim Y. Nutritional strategies in the prevention of colorectal cancer. [Review] [91 refs]. Current Gastroenterology Reports. 1999;1(4):341-53. [pmid: 10980971].
167 Mason JB, Choi SW, Bronner F. Nutritional assessment and management of the cancer patient. Nutritional-Aspects-and-Clinical-Management-of-Chronic-Disorders-and-Diseases. 2002, 197–224; 125 Ref.
168 Mattox T W. Use of glutamine, arginine, and omega-3 fatty acids in patients with malignancy. Cancer Control. 1995;2(4):334-41. [pmid: 10862175].
169 Mera S L. Diet and disease. British Journal of Biomedical Science. 1994;51(3):189-206. [pmid: 7881318].
170 Messina M. Modern applications for an ancient bean: soybeans and the prevention and treatment of chronic disease. [Review] [16 refs]. Journal of Nutrition. 1995;125(3 Suppl):567S-9S. [pmid: 7884533].
171 Messina M, Bennink M. Soyfoods, isoflavones and risk of colonic cancer: a review of the in vitro and in vivo data. [Review] [109 refs]. Baillieres Clinical Endocrinology & Metabolism. 1998;12(4):707-28.
172 Messina M, Messina V. Increasing use of soyfoods and their potential role in cancer prevention. [Review] [56 refs]. Journal of the American Dietetic Association. 1991;91(7):836-40. [pmid: 2071799].
173 Messina M J. Emerging evidence on the role of soy in reducing prostate cancer risk. [Review] [83 refs]. Nutrition Reviews. 2003;61(4):117-31. [pmid: 12795445].
174 Messina M J, Loprinzi C L. Soy for breast cancer survivors: a critical review of the literature. [Review]. Journal of Nutrition. 2001;131(11 Suppl):3095S-108S. [pmid: 11694655].
175 Messina M J, Persky V, Setchell K D, Barnes S. Soy intake and cancer risk: a review of the in vitro and in vivo data. [Review]. Nutrition & Cancer. 1994;21(2):113-31. [pmid: 8058523].
176 Messina M. Legumes and soybeans: overview of their nutritional profiles and health effects. American Journal of Clinical Nutrition. 1999;70(3):450S.
177 Messina M. Soy foods and soybean isoflavones and menopausal health. Nutrition in Clinical Care. 2002;5(6):272-82. [pmid: 12557810].
178 Meydani S N, Lichtenstein A H, White P J, et al. Food use and health effects of soybean and sunflower oils. [Review] [222 refs]. Journal of the American College of Nutrition. 1991;10(5):406-28. [pmid: 1955619].
179 Meydani S. Effect of (n-3) polyunsaturated fatty acids on cytokine production and their biologic function. Nutrition. 1996;12(1 supp):S8-S14. [pmid: 8850212].
180 Meyer J P, Gillatt D A. Can diet affect prostate cancer?. BJU International. 2002;89(3):250-4. [pmid: 11856105].
181 Moyad M A. Dietary fat reduction to reduce prostate cancer risk: Controlled enthusiasm, learning a lesson from breast or other cancers, and the big picture. Urology. 2002;59(4 SUPPL. 1):51-62. [pmid: 11937436].
182 Moyad M A. Fat reduction to prevent prostate cancer: waiting for more evidence?. [Review] [64 refs]. Current Opinion in Urology. 2001;11(5):457-61. [pmid: 11493765].
183 Moyad M A. The use of complementary/preventive medicine to prevent prostate cancer recurrence/progression following definitive therapy. Part II--rapid review of dietary supplements. Current Opinion in Urology. 2003;13(2):147-51. [pmid: 12584475].
184 Muriana F J G. Omega-3 fatty acids and health. Nutricion Clinica: Dietetica Hospitalaria. 2003;23(1):46-9.
185 Narisawa T. An overview on chemoprevention of colorectal cancer. [Review] [23 refs] [Japanese]. Nippon Geka Gakkai Zasshi. Journal of Japan Surgical Society. 1998;99(6):362-7. [pmid: 9695073].
186 Nestle I, Bal D G, Birt D F, et al. Guidelines on diet, nutrition, and cancer prevention: Reducing the risk of cancer with healthy food choices and physical activity. Ca-A Cancer Journal for Clinicians. 1996;46(6):(Pp 325-341). [pmid: 8917019].
187 Newmark H, Lipkin M. Omega-3 fatty acids and rectal epithelial cell proliferation. [comment]. Gastroenterology. 1994;107(6):1892-4. [pmid: 7958709].
188 Newton I S. Polyunsaturated fatty acids in diet and health. Chemistry-and-Industry-London. 1997;No. 8:302-305. 42 Ref.
189 Nixon D W. Diet and chemoprevention of colon polyps and colorectal cancer. [Review] [34 refs]. Seminars in Surgical Oncology. 1995;11(6):411-5. [pmid: 8607010].
190 Nkondjock A, Shatenstein B, Maisonneuve P, Ghadirian P. Specific fatty acids and human colorectal cancer: an overview. [Review] [64 refs]. Cancer Detection & Prevention. 2003;27(1):55-66. [pmid: 12600418].
191 Noguchi M, Rose D P, Earashi M, Miyazaki I. The role of fatty acids and eicosanoid synthesis inhibitors in breast carcinoma. Oncology. 1995;52(4):265-71. [pmid: 7777237].
192 Noguchi M, Rose D P, Miyazaki I. Breast cancer chemoprevention: Clinical trials and research. Oncology. 1996;53(3):175-81. [pmid: 8643218].
193 Nordoy A. Is there a rational use for n-3 fatty acids (fish oils) in clinical medicine?. Drugs. 1991;42(3):331-42. [pmid: 1720377].
194 O'Keefe S J D. Nutrition and gastrointestinal disease. Scandinavian Journal of Gastroenterology - Supplement. 1996;31(220):52-9. [pmid: 8898436].
195 Ochoa M C, Lamas O, Martinez J A, Marti A. Role of dietary fat on immune function. Anales De La Real Academia De Farmacia; Instituto De Espana. 2001;67(3):473-87.
196 Okuyama H, Kobayashi T, Watanabe S. Dietary fatty acids - the N-6/N-3 balance and chronic elderly diseases. Excess linoleic acid and relative N-3 deficiency syndrome seen in Japan. Progress in Lipid Research. 1996;35(4):409-57. [pmid: 9246358].
197 Osborne R H, Sinclair A J. Red blood cell polyunsaturated fatty acid n-6 to n-3 ratios correlate with anxiety and depression in women with breast cancer. Proceedings-of-the-Nutrition-Society-of-Australia. 1995;19:53. 8 ref.
198 Pandian S S, Eremin O E, McClinton S, Wahle K W J, Heys S D. Fatty acids and prostate cancer: Current status and future challenges. Journal of the Royal College of Surgeons of Edinburgh. 1999;44(6):(Pp 352-361). [pmid: 10612956].
199 Papoutsakis Tsarouhas C, Wolinsky I, Matalas AL (ed.), Zampelas A (ed.), Stavrinos V (ed.), Wolinsky I. Cancer and the Mediterranean Diet. The-Mediterranean-Diet:-Constituents-and-Health-Promotion. 2001, 293–340; 272 Ref.
200 Pascaud M, Brouard C. Essential polyenoic fatty acids of the omega3 and omega6 series. Dietary requirements. Food balance. Cahiers-De-Nutrition-Et-De-Dietetique. 1991;26(3):185-90. 38 ref.
201 Pathak S K, Sharma R A, Mellon J K. Chemoprevention of prostate cancer by diet-derived antioxidant agents and hormonal manipulation (Review). [Review] [95 refs]. International Journal of Oncology. 2003;22(1):5-13. [pmid: 12469179].
202 Pepping J. Omega-3 essential fatty acids. Am J Healht-Syst Pharm. 1999;56(8):719-24.
203 Pratt S, Greenway HT, Naugle C, Watson RR. Nutrition and skin cancer risk prevention. Functional-Foods-and-Nutraceuticals-in-Cancer-Prevention. 2003, 105–120; Many Ref.
204 Purasiri P, Heys S D, Eremin O. Essential fatty acids and malignant disease. [Review] [39 refs]. European Journal of Surgical Oncology. 1994;20(5):603-6. [pmid: 7926070].
205 Rao A V, Sung M K. Saponins as anticarcinogens. [Review] [52 refs]. Journal of Nutrition. 1995;125(3 Suppl):717S-24S. [pmid: 7884557].
206 Reddy B S. Chemoprevention of colon cancer by dietary fatty acids. Cancer & Metastasis Reviews. 1994;13(34):285-302. [pmid: 7712591].
207 Reddy B S. Types and amount of dietary fat and colon cancer risk: Prevention by omega-3 fatty acid-rich diets. Environmental Health & Preventive Medicine. 2002;7(3):95-102.
208 Reddy BS, Nelson GJ. Omega-3 fatty acids as anticancer agents. Health Effects of Dietary Fatty Acids. 1991, 157–166; 44 Ref.
209 Riaz M N. Soybeans as functional foods. Cereal-Foods-World. 1999;44(2):88-92. 39 ref.
210 Riboli E, Kaaks R, Esteve J. Nutrition and laryngeal cancer. [Review] [28 refs]. Cancer Causes & Control. 1996;7(1):147-56. [pmid: 8850442].
211 Ritenbaugh C. Diet and prevention of colorectal cancer. [Review] [52 refs]. Current Oncology Reports. 2000;2(3):225-33. [pmid: 11122847].
212 Romieu I, Trenga C. Role of nutrition in environmental lung disease. Seminars in Respiratory & Critical Care Medicine. 1999;20(6):581-90.
213 Rose D P. Dietary fatty acids and cancer. American Journal of Clinical Nutrition. 1997;66(4 SUPPL.):998S-1003S. [pmid: 9322580].
214 Rose D P. Dietary fatty acids and prevention of hormone-responsive cancer. [Review]. Proceedings of the Society for Experimental Biology & Medicine. 1997;216(2):224-33. [pmid: 9349691].
215 Rose D P, Connolly J M. Dietary fat, fatty acids and prostate cancer. Lipids. 1992;27(10):798-803. [pmid: 1435098].
216 Rose D P, Connolly J M. Omega-3 fatty acids as cancer chemopreventive agents. [Review]. Pharmacology & Therapeutics. 1999;83(3):217-44. [pmid: 10576293].
217 Rose D P, Hatala M A. Dietary fatty acids and breast cancer invasion and metastasis. [Review] [82 refs]. Nutrition & Cancer. 1994;21(2):103-11. [pmid: 8058522].
218 Rose D P. The mechanistic rationale in support of dietary cancer prevention. Preventive-Medicine. 1996;25(1):34-7. 36 ref. [pmid: 8778758].
219 Ross J A, Potter J D, Severson R K. Platelet-derived growth factor and risk factors for colorectal cancer. [Review] [157 refs]. European Journal of Cancer Prevention. 1993;2(3):197-210. [pmid: 8490537].
220 Rudman D, Cohan M E. Polyunsaturated fatty acids and the health of the elderly. [Review] [79 refs]. World Review of Nutrition & Dietetics. 1991;66:143-60. [pmid: 2053334].
221 Sarkkinen E , Uusitupa M. The role of fish oil in the prevention and treatment of diseases. Duodecim 1996; (19):1755–63.
222 Schmitz Drager B J, Eichholzer M, Beiche B, Ebert T. Nutrition and prostate cancer. Urologia-Internationalis. 2001;67(1):1-11. 107 ref. [pmid: 11464107].
223 Schulman C C, Ekane S, Zlotta A R. Nutrition and prostate cancer: evidence or suspicion?. Urology. 2001;58(3):318-34. 71 ref. [pmid: 11549473].
224 Shirai T, Asamoto M, Takahashi S, Imaida K. Diet and prostate cancer. Toxicology. 2002, 181–182: 89–94.
225 Siguel E N. Cancerostatic effect of vegetarian diets. Nutrition & Cancer. 1983;4(4):285-91. [pmid: 6878049].
226 Siguel E N. Re: Dietary modulation of omega-3/omega-6 polyunsaturated fatty acid ratios in patients with breast cancer. [comment]. Journal of the National Cancer Institute. 1998;90(8):629-31. [pmid: 9554449].
227 Simopoulos A P. Evolutionary aspects of omega-3 fatty acids in the food supply. [Review] [54 refs]. Prostaglandins Leukotrienes & Essential Fatty Acids. 1999;60(56):421-9.
228 Simopoulos A P. The Mediterranean diets: What is so special about the diet of Greece? The scientific evidence. [Review]. Journal of Nutrition. 2001;131(11 Suppl):3065S-73S. [pmid: 11694649].
229 Simopoulos A P. Nutritional cancer risks derived from energy and fat. [Review] [51 refs]. Medical Oncology & Tumor Pharmacotherapy. 1987;4(34):227-39. [pmid: 3326985].
230 Simopoulos A P. Omega-3 fatty acids in health and disease. Journal of Nutrition Growth & Cancer. 1986;3(2):69-81.
231 Simopoulos A. The importance of the ratio of omega-6/omega-3 essential fatty acids. Biomedicine & Pharmacotherapy. 2002;56(8):365-79.
232 Simopoulos A. Omega-3 fatty acids in health and disease and in growth and development. American Journal of Clinical Nutrition. 1991;54(3):438-63. [pmid: 1908631].
233 Sinclair A J, Attar Bashi N M, Li Duo, Li D. What is the role of alpha-linolenic acid for mammals?. Lipids. 2002;37(12):1113-23. 145 ref. [pmid: 12617463].
234 Sinclair H M. Essential fatty acids in perspective. Human Nutrition - Clinical Nutrition. 1984;38(4):245-60. [pmid: 6469703].
235 Sirtori C R. Risks and benefits of soy phytoestrogens in cardiovascular diseases, cancer, climacteric symptoms and osteoporosis. [Review]. Drug Safety. 2001;24(9):665-82. [pmid: 11522120].
236 Smith-Warner S A, Spiegelman D, Adami H O, et al. Types of dietary fat and breast cancer: a pooled analysis of cohort studies. International Journal of Cancer. 2001;92(5):767-74.
237 Stangl G I. The action of dietary fat in cancerogenesis. Ernahrungs-Umschau. 1999;46(1):4-9. 80 ref.
238 Steiner A, Greminger P, Vetter W. [Review] [56 refs] [German]. Schweizerische Rundschau Fur Medizin Praxis. 1989;78(41):1126-31. [pmid: 2678376].
239 Stoll B A. Association between breast and colorectal cancers.[comment]. [Review] [82 refs]. British Journal of Surgery. 1998;85(11):1468-72. [pmid: 9823904].
240 Stoll B A. Breast cancer and the western diet: role of fatty acids and antioxidant vitamins. [Review] [81 refs]. European Journal of Cancer. 1998;34(12):1852-6. [pmid: 10023305].
241 Stoll B A. Eating to beat breast cancer: potential role for soy supplements. Annals of Oncology. 1997;8(3):223-5. [pmid: 9137789].
242 Stoll B A. N-3 fatty acids and lipid peroxidation in breast cancer inhibition. [Review] [63 refs]. British Journal of Nutrition. 2002;87(3):193-8. [pmid: 12064327].
243 Stoll B A. Western nutrition and the insulin resistance syndrome: a link to breast cancer. [Review] [52 refs]. European Journal of Clinical Nutrition. 1999;53(2):83-7. [pmid: 10099938].
244 Tagliaferri M, Cohen I, Tripathy D. Complementary and alternative medicine in early-stage breast cancer. Seminars in Oncology. 2001;28(1):121-34. [pmid: 11254871].
245 Tapiero H, Nguyen Ba G, Couvreur P, Tew K D. Polyunsaturated fatty acids (PUFA) and eicosanoids in human health and pathologies. Biomedicine & Pharmacotherapy. 2002;56(5):215-22.
246 Teas J. The consumption of seaweed as a protective factor in the etiology of breast cancer. Medical Hypotheses. 1981;7(5):601-13. [pmid: 7278725].
247 Terry P D, Rohan T E, Wolk A. Intakes of fish and marine fatty acids and the risks of cancers of the breast and prostate and of other hormone-related cancers: a review of the epidemiologic evidence. [Review]. American Journal of Clinical Nutrition. 2003;77(3):532-43. [pmid: 12600840].
248 Tessier C, Corda B, Marty J. Denutrition and postoperative infection in cancer patients. Pathologie Et Biologie. 2000;48(8):725-32. [pmid: 11244601].
249 Tisdale M J. Biology of cachexia.[comment]. [Review]. Journal of the National Cancer Institute. 1997;89(23):1763-73. [pmid: 9392617].
250 Tisdale M J. Cancer anorexia and cachexia. [Review] [80 refs]. Nutrition. 2001;17(5):438-42. [pmid: 11377146].
251 Tisdale M J. The ‘cancer cachectic factor’. Supportive Care in Cancer. 2003;11(2):73-8. [pmid: 12560934].
252 Tisdale M J. Lipolytic and proteolytic factors in cancer cachexia. Nutrition Clinique Et Metabolisme. 2001;15(4):266-72.
253 Tisdale M J. Metabolic abnormalities in cachexia and anorexia. [Review] [34 refs]. Nutrition. 2000;16(10):1013-4. [pmid: 11054609].
254 Tokudome S, Imaeda N, Tokudome Y, et al. No association between fat and fatty acids intake and risk of colorectal cancer [1] (multiple letters). Cancer Epidemiology, Biomarkers & Prevention. 2002;11(2):217-8.
255 Tokudome S, Kuriki K, Moore M A. Seaweed and cancer prevention. Japanese Journal of Cancer Research. 2001;92(9):1008-9. [pmid: 11831193].
256 Troyer D, Fernandes G. Nutrition and apoptosis. Nutrition Research. 1996;16(1112):1959-87.
257 Turini M E, Basu T K, Clandinin M T. Prostaglandins - diet - cancer: A review. Nutrition Research. 1990;10(7):819-27.
258 Vitello J M. Nutritional assessment and the role of preoperative parenteral nutrition in the colon cancer patient. [Review] [105 refs]. Seminars in Surgical Oncology. 1994;10(3):183-94. [pmid: 8085095].
259 Von Hoff D D, Bearss D. New drugs for patients with pancreatic cancer. [Review] [54 refs]. Current Opinion in Oncology. 2002;14(6):621-7. [pmid: 12409652].
260 von Meyenfeldt MF. Nutritional support during treatment of biliopancreatic malignancy. [Review][82 refs]. Annals of Oncology. 10 Suppl 4:273–7, 1999.
261 Wahle K W J, Heys S D. Comments on the role of fish-oil fatty acids in the prevention of cancer cachexia. Clinical Science. 2000;98(4):365. [pmid: 10731468].
262 Wallace J M. Nutritional and botanical modulation of the inflammatory cascade - Eicosanoids, cyclooxygenases, and lipoxygenases - As an adjunct in cancer therapy. Integrative Cancer Therapies. 2002;1(1):7-37. [pmid: 14664746].
263 Ward J F, Blute M L. Chemoprevention of prostate cancer. Expert Review of Anticancer Therapy. 2003;3(2):203-14. [pmid: 12722880].
264 Wargovich M J. Fish oil and colon cancer. [comment]. Gastroenterology. 1992;103(3):1096-8. [pmid: 1386824].
265 Watkins B, Li Y, Lippman H, Seifert M. Omega-3 polyunsaturated fatty acids and skeletal health. Experimental Biology & Medicine. 2001;226(6):485-97. [pmid: 11395919].
266 Weisburger E K. Chemoprevention of cancer: A brief review. In Vivo. 2000;14(5):699-701. [pmid: 11125552].
267 Weisburger J H. Approaches for chronic disease prevention based on current understanding of underlying mechanisms. [Review] [30 refs]. American Journal of Clinical Nutrition. 2000;71(6 Suppl):1710S-4S. discussion 1715S–9S. [pmid: 10837325].
268 Weisburger J H. Dietary fat and risk of chronic disease: mechanistic insights from experimental studies. [Review] [66 refs]. Journal of the American Dietetic Association. 1997;97(7 Suppl):S16-23. [pmid: 9216563].
269 Whelan J. Antagonistic effects of dietary arachidonic acid and n-3 polyunsaturated fatty acids. [Review] [35 refs]. Journal of Nutrition. 1996;126(4 Suppl):1086S-91S. [pmid: 8642438].
270 Wilkinson S, Chodak G W. Critical review of complementary therapies for prostate cancer. [Review] Journal of Clinical Oncology. 2003;21(11):2199-210. [pmid: 12775747].
271 Willett W C. Diet and breast cancer. Journal of Internal Medicine. 2001;249(5):395-411. [pmid: 11350564].
272 Willett W C. Dietary fat and breast cancer. [Review] Toxicological Sciences. 1999;52(2 Suppl):127-46. [pmid: 10630601].
273 Willett W C. Specific fatty acids and risks of breast and prostate cancer: dietary intake. [Review] [63 refs]. American Journal of Clinical Nutrition. 1997;66(6 Suppl):1557S-63S. [pmid: 9394715].
274 Woo J. Relationships among diet, physical activity and other lifestyle factors and debilitating diseases in the elderly. [Review] [67 refs]. European Journal of Clinical Nutrition. 2000;54(Suppl 3):S143-7. Jun. [pmid: 11041086].
275 Wu A, Ziegler R, Nomura A, et al. Soy intake and risk of breast cancer in Asians and Asian Americans. Am J Cin Nutr. 1998;68(supp):1437S-43S.
276 Wynder E L, Fujita Y, Harris R E, Hirayama T, Hiyama T. Comparative epidemiology of cancer between the United States and Japan. A second look. Cancer. 1991;67(3):746-63. [pmid: 1985768].
277 Wynder E L, Morabia A, Rose D P, Cohen L A. Clinical trials of dietary interventions to enhance cancer survival. [Review] [55 refs]. Progress in Clinical & Biological Research. 1990;346:217-29. [pmid: 2165262].
278 Wynder E L, Rose D P, Cohen L A. Diet and breast cancer in causation and therapy. Cancer. 1986;58(8 Suppl):1804-13. [pmid: 3756804].
279 Wynder E L, Rose D P, Cohen L A. Nutrition and prostate cancer: a proposal for dietary intervention. [Review] [82 refs]. Nutrition & Cancer. 1994;22(1):1-10. [pmid: 11304906].
280 Yip I, Heber D, Aronson W. Nutrition and prostate cancer. Urologic Clinics of North America. 1999;26(2):403-11. [pmid: 10361562].
281 Yoon H, Benamouzig R, Little J, Francois-Collange M, Tome D. Systematic review of epidemiological studies on meat, dairy products and egg consumption and risk of colorectal adenomas. European Journal of Cancer Prevention. 2000;9(3):151-64. [pmid: 10954254].
282 Yun T K. Update from Asia. Asian studies on cancer chemoprevention. [Review] Annals of the New York Academy of Sciences. 1999;889:157-92. [pmid: 10668493].
283 Zhou J R, Blackburn G L. Bridging animal and human studies: what are the missing segments in dietary fat and prostate cancer?. [Review] [73 refs]. American Journal of Clinical Nutrition. 1997;66(6 Suppl):1572S-80S. [pmid: 9394717].

### Rejected Inappropriate Study Design (n = 89)

1 Agudo A, Beguiristain J M, Rodriguez M, et al. Patterns and sources of fat and specific fatty acids intake in the participants of the European Prospective Study of Cancer and Nutrition (EPIC) in Spain. Medicina-Clinica-Barcelona. 1999;112(4):125-32. 37 ref.
2 Akedo I, Ishikawa H, Nakamura T, et al. Three cases with familial adenomatous polyposis diagnosed as having malignant lesions in the course of a long-term trial using docosahexanoic acid (DHA)-concentrated fish oil capsules. Japanese Journal of Clinical Oncology. 1998;28(12):762-5. [pmid: 9879296].
3 Almendingen K, Trygg K, Hofstad B, Veierod M B, Vatn M H. Results from two repeated 5 day dietary records with a 1 y interval among patients with colorectal polyps. European Journal of Clinical Nutrition. 2001;55(5):374-9. [pmid: 11378811].
4 Aronson W J, Glaspy J A, Reddy S T, Reese D, Heber D, Bagga D. Modulation of omega-3/omega-6 polyunsaturated ratios with dietary fish oils in men with prostate cancer. Urology. 2001;58(2):283-8. [pmid: 11489728].
5 Bagga D, Capone S, Wang H J, et al. Dietary modulation of omega-3/omega-6 polyunsaturated fatty acid ratios in patients with breast cancer. [comment]. Journal of the National Cancer Institute. 1997;89(15):1123-31. [pmid: 9262250].
6 Baghurst K I, Record S J, Baghurst P A, Syrette J A, Crawford D, Worsley A. Sociodemographic determinants in Australia of the intake of food and nutrients implicated in cancer aetiology. Medical Journal of Australia. 1990;153(8):444-52. [pmid: 2215334].
7 Baghurst P A, Carman J A, Syrette J A, Baghurst K I, Crocker J M. Diet, prolactin, and breast cancer. American Journal of Clinical Nutrition. 1992;56(5):943-9. [pmid: 1415014].
8 Bairati I, Meyer F, Fradet Y, Moore L. Dietary fat and advanced prostate cancer. Journal-of-Urology. 1998;159(4):1271-5. 37 ref. [pmid: 9507851].
9 Bakker N, Van't Veer P, Zock P L. Adipose fatty acids and cancers of the breast, prostate and colon: an ecological study. EURAMIC Study Group. International Journal of Cancer. 1997;72(4):587-91.
10 Barber M D, Fearon K C. Tolerance and incorporation of a high-dose eicosapentaenoic acid diester emulsion by patients with pancreatic cancer cachexia. Lipids. 2001;36(4):347-51. [pmid: 11383684].
11 Barber M D, Fearon K C, Tisdale M J, McMillan D C, Ross J A. Effect of a fish oil-enriched nutritional supplement on metabolic mediators in patients with pancreatic cancer cachexia. Nutrition & Cancer. 2001;40(2):118-24. [pmid: 11962246].
12 Barber M D, McMillan D C, Preston T, Ross J A, Fearon K C. Metabolic response to feeding in weight-losing pancreatic cancer patients and its modulation by a fish-oil-enriched nutritional supplement. [comment]. Clinical Science. 2000;98(4):389-99. [pmid: 10731472].
13 Barber M D, Ross J A, Voss A C, Tisdale M J, Fearon K C. The effect of an oral nutritional supplement enriched with fish oil on weight-loss in patients with pancreatic cancer. British Journal of Cancer. 1999;81(1):80-6. [pmid: 10487616].
14 Barnes S, Urban D, Grizzle W, et al. A double-blind, clinical trial of the effects of soy protein on risk parameters for prostate cancer. Am J Clin Nutr. 1998;68(supp):1529S.
15 Bourrain J L, Califano C, Richard M, Amblard P, Beani J C. Effect of dietary supplementation with omega-3 fatty acids on MED. Nouvelles Dermatologiques. 1996;15(5):369-71.
16 Boutron M C, Faivre J, Bornet B, et al. Methodology of diet studies. Experience of the Digestive Cancers Registry of Burgundy (France). Cahiers-De-Nutrition-Et-De-Dietetique. 1991;25(4):249-55. 11 ref.
17 Bryhn M. Omega-3 and preventing skin damage in the sun. Agro-Food-Industry-Hi-Tech. 2002;13(4):50-1. 6 ref.
18 Burns C P, Halabi S, Clamon G H, et al. Phase I clinical study of fish oil fatty acid capsules for patients with cancer cachexia: cancer and leukemia group B study 9473. Clinical Cancer Research. 1999;5(12):3942-7. [pmid: 10632323].
19 Caderni G, Palli D, Lancioni L, et al. Dietary determinants of colorectal proliferation in the normal mucosa of subjects with previous colon adenomas. Cancer Epidemiology, Biomarkers & Prevention. 1999;8(3):219-25.
20 Caperle M, Maiani G, Azzini E, et al. Dietary profiles and anti-oxidants in a rural population of central Italy with a low frequency of cancer. European Journal of Cancer Prevention. 1996;5(3):197-206. [pmid: 8818609].
21 Caygill C P J, Charlett A, Hill M J. Fat, fish, fish oil and cancer. British Journal of Cancer. 1996;74(1):159-64. [pmid: 8679451].
22 Caygill C P J, Hill M J. Fish, n-3 fatty acids and human colorectal and breast cancer mortality. European Journal of Cancer Prevention. 1995;4(4):329-32. [pmid: 7549825].
23 Chajes V, Niyongabo T, Lanson M, Fignon A, Couet C, Bougnoux P. Fatty-acid composition of breast and iliac adipose tissue in breast-cancer patients. International Journal of Cancer. 1992;50(3):405-8.
24 Chuntrasakul C, Siltharm S, Sarasombath S, et al. Metabolic and immune effects of dietary arginine, glutamine and omega-3 fatty acids supplementation in immunocompromised patients. Journal of the Medical Association of Thailand. 1998;81(5):334-43. [pmid: 9623033].
25 Corella D, Cortina P, Guillen M, Gonzalez J I. Dietary habits and geographic variation in stomach cancer mortality in Spain. European-Journal-of-Cancer-Prevention. 1996;5(4):249-57. 37 ref. [pmid: 8894562].
26 Dalberg J, Jacobsen O, Nielsen N H, Steig B A, Storm H H. Colorectal cancer in the Faroe Islands--a setting for the study of the role of diet. Journal of Epidemiology & Biostatistics. 1999;4(1):31-6. [pmid: 10613714].
27 Demark-Wahnefried W, Price D T, Polascik T J, et al. Pilot study of dietary fat restriction and flaxseed supplementation in men with prostate cancer before surgery: exploring the effects on hormonal levels, prostate-specific antigen, and histopathologic features. Urology. 2001;58(1):47-52. [pmid: 11445478].
28 Dewailly E, Mulvad G, Sloth Pedersen H, Hansen J C, Behrendt N, Hart Hansen J P. Inuit are protected against prostate cancer. Cancer Epidemiology, Biomarkers & Prevention. 2003;12(9):926-7.
29 Filiberti R, Kubik A, Reissigova J, Merlo F, Bonassi S. Cancer, cardiovascular mortality, and diet in Italy and the Czech Republic. Neoplasma. 1995;42(5):275-83. [pmid: 8552209].
30 Frich L, Akslen L A, Glattre E. [Norwegian]. Tidsskrift for Den Norske Laegeforening. 1998;118(27):4202-5. [pmid: 9857802].
31 Furberg A S, Sandanger T, Thune I, Burkow I C, Lun E. Fish consumption and plasma levels of organochlorines in a female population in Northern Norway. Journal of Environmental Monitoring. 2002;4(1):175-81. [pmid: 11871702].
32 Garritson B K, Nikaein A, Peters G N, Gorman M A, King C C, Lipa G U. Effect of major dietary modifications on immune system in patients with breast cancer. A pilot study. Cancer Practice. 1995;3(4):239-46. [pmid: 7620489].
33 Giacosa A, Filiberti R, Visconti P, Puntoni R. Mediterranean diet and digestive precancerous lesions. European-Journal-of-Cancer-Prevention. 1993;2(SUP 2):17-26. 37 ref. [pmid: 8364367].
34 Gramaglia A, Loi G F, Mongioj V, Baronzio G F. Increased survival in brain metastatic patients treated with stereotactic radiotherapy, omega three fatty acids and bioflavonoids. Anticancer Research. 1999;19(6C):5583-6. [pmid: 10697622].
35 Grant W B. An ecologic study of dietary and solar ultraviolet-B links to breast carcinoma mortality rates. Cancer. 2002;94(1):272-81. [pmid: 11815987].
36 Hanai T, Hashimoto T, Nishiwaki K, et al. Comparison of prostanoids and their precursor fatty acids in human hepatocellular carcinoma and noncancerous reference tissues. Journal of Surgical Research. 1993;54(1):57-60. [pmid: 8094103].
37 Hebert J R, Hurley T G, Olendzki B C, et al. Nutritional and socioeconomic factors in relation to prostate cancer mortality: a cross-national study. Journal-of-the-National-Cancer-Institute. 1998;90(21):1637-47. 66 ref. [pmid: 9811313].
38 Henderson MM, Nelson GJ. Correlations between fatty acid intake and cancer incidence. Health Effects of Dietary Fatty Acids. 1991, 136–149; 27 Ref.
39 Hill C. Overview of available data on diet and cancer mortality in France. Tumori. 1990;76(4):299-305. 14 ref. [pmid: 2399559].
40 Hirayama T. Epidemiology of prostate cancer with special reference to the role of diet. Natl 1979; (53):149–55.
41 Hirayama T, Hill MJ (ed.), Giacosa A (ed.), Caygill CPJ. Japanese studies on diet and cancer. Epidemiology-of-Diet-and-Cancer. 1994, 17–64; 13 Ref.
42 Holmes M D, Stampfer M J, Colditz G A, Rosner B, Hunter D J, Willett W C. Dietary factors and the survival of women with breast carcinoma. Cancer. 1999;86(5):826-35. [pmid: 10463982].
43 Hursting S D, Thornquist M, Henderson M M. Types of dietary fat and the incidence of cancer at five sites. Preventive Medicine. 1990;19(3):242-53. [pmid: 2377587].
44 Jakes R W, Alexander L, Duffy S W, Leong J, Chen L H, Lee W H. Dietary intake of soybean protein and menstrual cycle length in pre-menopausal Singapore Chinese women. Public Health Nutrition. 2001;4(2):191-6. [pmid: 11299091].
45 Joossens JV, Kesteloot H. Fish consumption and health status. Bibliotheca Nutritio Et Dieta 1990; (46):37–44.
46 Kaizer L, Boyd N F, Kriukov V, Tritchler D. Fish consumption and breast cancer risk: an ecological study. Nutrition & Cancer. 1989;12(1):61-8. [pmid: 2710648].
47 Khuroo M S, Zargar S A, Mahajan R, Banday M A. High incidence of oesophageal and gastric cancer in Kashmir in a population with special personal and dietary habits. Gut. 1992;33(1):11-5. 21 ref. [pmid: 1740265]. [pmcid: 1373857].
48 Kobayashi M, Sasaki S, Hamada G S, Tsugane S. Serum n-3 fatty acids, fish consumption and cancer mortality in six Japanese populations in Japan and Brazil. Japanese Journal of Cancer Research. 1999;90(9):914-21. [pmid: 10551318].
49 Kolonel L N, Hankin J H, Lee J, Chu S Y, Nomura A M Y, Hinds M W. Nutrient intakes in relation to cancer incidence in Hawaii. British-Journal-of-Cancer. 1981;44(3):332-9. 32 ref. [pmid: 7284230].
50 Kolonel L N, Nomura A M Y, Hirohata T, Hankin J H, Hinds M W. Association of diet and place of birth with stomach cancer incidence in Hawaii Japanese and Caucasians. American-Journal-of-Clinical-Nutrition. 1981;34(11):2478-85. 43 ref. [pmid: 7304487].
51 Koo L C, Mang O W K, Ho J H C. An ecological study of trends in cancer incidence and dietary changes in Hong Kong. Nutrition-and-Cancer. 1997;28(3):289-301. 13 ref. [pmid: 9343839].
52 Li W, Zhu M, Chen P, Lu W. Study on dietary pattern and nutrients intakes of residents in areas of high and low incidence of esophageal cancer. [Chinese]. Wei Sheng Yen Chiu/Journal of Hygiene Research. 1997;26(5):351-5.
53 Linseisen J, Bergstrom E, Gafa L, et al. Consumption of added fats and oils in the European Prospective Investigation into Cancer and Nutrition (EPIC) centres across 10 European countries as assessed by 24-hour dietary recalls. Public Health Nutrition. 2002;5(6B):1227-42. [pmid: 12639229].
54 Linseisen J, Schulze M B, Saadatian-Elahi M, Kroke A, Miller A B, Boeing H. Quantity and quality of dietary fat, carbohydrate, and fiber intake in the German EPIC cohorts. Annals of Nutrition & Metabolism. 2003;47(1):37-46. [pmid: 12624486].
55 Lockwood K, Moesgaard S, Hanioka T, Folkers K. Apparent partial remission of breast cancer in ‘high risk’ patients supplemented with nutritional antioxidants, essential fatty acids and coenzyme Q10. Molecular Aspects of Medicine. 1994;15(Suppl):S231-40. [pmid: 7752835].
56 Lu L J, Anderson K E, Grady J J, Nagamani M. Effects of soya consumption for one month on steroid hormones in premenopausal women: implications for breast cancer risk reduction. Cancer Epidemiology, Biomarkers & Prevention. 1996;5(1):63-70.
57 Lu L J, Grady J J, Marshall M V, Ramanujam V M, Anderson K E. Altered time course of urinary daidzein and genistein excretion during chronic soya diet in healthy male subjects. Nutrition & Cancer. 1995;24(3):311-23. [pmid: 8610050].
58 Lu L J, Lin S N, Grady J J, Nagamani M, Anderson K E. Altered kinetics and extent of urinary daidzein and genistein excretion in women during chronic soya exposure. Nutrition & Cancer. 1996;26(3):289-302. [pmid: 8910911].
59 Mamalakis G, Kafatos A, Kalogeropoulos N, Andrikopoulos N, Daskalopulos G, Kranidis A. Prostate cancer vs hyperplasia: relationships with prostatic and adipose tissue fatty acid composition. Prostaglandins Leukotrienes & Essential Fatty Acids. 2002;66(56):467-77.
60 Maskarinec G, Singh S, Meng L, Franke A A. Dietary soy intake and urinary isoflavone excretion among women from a multiethnic population. Cancer Epidemiology, Biomarkers & Prevention. 1998;7(7):613-9.
61 Meydani M, Natiello F, Goldin B, et al. Effect of long-term fish oil supplementation on vitamin E status and lipid peroxidation in women. J Nutr. 1991;121(4):484-91. [pmid: 1826131].
62 Nagai M, Hashimoto T, Yanagawa H, Yokoyama H, Minowa M. Relationship of diet to the incidence of esophageal and stomach cancer in Japan. Nutrition & Cancer. 1982;3(4):257-68. [pmid: 6890672].
63 Newman V, Rock C L, Faerber S, Flatt S W, Wright F A, Pierce J P. Dietary supplement use by women at risk for breast cancer recurrence. The Women's Healthy Eating and Living Study Group. Journal of the American Dietetic Association. 1998;98(3):285-92. [pmid: 9508010].
64 Nomura A, Yamakawa H, Ishidate T, et al. Intestinal metaplasia in Japan: association with diet. Journal of the National Cancer Institute. 1982;68(3):401-5. [pmid: 6950167].
65 Normen A L, Brants H A, Voorrips L E, Andersson H A, van den Brandt P A, Goldbohm R A. Plant sterol intakes and colorectal cancer risk in the Netherlands Cohort Study on Diet and Cancer. [comment]. American Journal of Clinical Nutrition. 2001;74(1):141-8. [pmid: 11451730].
66 Palli D, Decarli A, Cipriani F, et al. Plasma pepsinogens, nutrients, and diet in areas of Italy at varying gastric cancer risk. Cancer-Epidemiology,-Biomarkers-and-Prevention. 1991;1(1):45-50. 31 ref.
67 Palli D, Vineis P, Russo A, et al. Diet, metabolic polymorphisms and DNA adducts: the EPIC-Italy cross-sectional study. International-Journal-of-Cancer. 2000;87(3):444-51. 35 ref.
68 Prieto Ramos F, Serra Majem L, Vecchia C la, Ramon JM, Tresserras R, Salleras L. Mortality trends and past and current dietary factors of breast cancer in Spain. European-Journal-of-Epidemiology 1996; 12(2):141–8; 50 ref.
69 Rhodes L E, O'Farrell S, Jackson M J, Friedmann P S. Dietary fish-oil supplementation in humans reduces UVB-erythemal sensitivity but increases epidermal lipid peroxidation. J. 1994;103(2):151-4.
70 Riemersma RA (ed.), Armstrong R (ed.), Kelly RW (ed.), Wilson R. Essential fatty acids and eicosanoids: invited papers from the Fourth International Congress, Edinburgh, Scotland, UK, July 20–24, 1997. 1998, Xvi + 432 Pp.; Many Ref.
71 Sasaki S, Horacsek M, Kesteloot H. An ecological study of the relationship between dietary fat intake and breast cancer mortality. Preventive Medicine. 1993;22(2):187-202. [pmid: 8483858].
72 Sharp D S, Rodriguez B L, Shahar E, Hwang L J, Burchfiel C M. Fish consumption may limit the damage of smoking on the lung. American Journal of Respiratory & Critical Care Medicine. 1994;150(4):983-7. [pmid: 7921474].
73 Siari S, Scali J, Richard A et al. Subregional variations of dietary consumption and incidences of cancers in southern Europe. Nutrition-and-Lifestyle:-Opportunities-for-Cancer-Prevention.-European-Conference-on-Nutrition-and-Cancer-Held-in-Lyon,-France-on-21–24-June,-2003. 2002, 127–129; 2 Ref.
74 Silver S. EPA halts cancer-induced weight loss. Lancet Oncology. 2002;3(1):7.
75 Stoneham M, Goldacre M, Seagroatt V, Gill L. Olive oil, diet and colorectal cancer: an ecological study and a hypothesis. [comment]. Journal of Epidemiology & Community Health. 2000;54(10):756-60. [pmid: 10990479].
76 Sudzhian A V, Saltanov A I, Abbasov F E, Breusenko EIa. [Russian]. Voprosy Onkologii. 1990;36(9):1058-63. [pmid: 2238546].
77 Thomson C A, Flatt S W, Rock C L, Ritenbaugh C, Newman V, Pierce J P. Increased fruit, vegetable and fiber intake and lower fat intake reported among women previously treated for invasive breast cancer. Journal of the American Dietetic Association. 2002;102(6):801-8. [pmid: 12067045].
78 Tsutsumi M, Suzuki K, Shiga Y, Ishikawa S, Ishikawa Y. A low-fat and high soybean protein diet for patients with elevated serum PSA level: alteration of QOL and serum PSA level after the dietary intervention. [Japanese]. Hinyokika Kiyo - Acta Urologica Japonica. 2002;48(4):207-11. [pmid: 12048932].
79 Vachon C M, Kushi L H, Cerhan J R, Kuni C C, Sellers T A. Association of diet and mammographic breast density in the Minnesota breast cancer family cohort. Cancer-Epidemiology,-Biomarkers-and-Prevention. 2000;9(2):151-60. 47 ref.
80 Veierod M B, Thelle D S, Laake P. Diet and risk of cutaneous malignant melanoma: a prospective study of 50,757 Norwegian men and women. International Journal of Cancer. 1997;71(4):600-4.
81 Voss AC, Jensen J. Application of evidence based practice: omega-3 fatty acids in cancer cachexia. Proceedings of the Conference of New Zealand Dietetic Association Inc., Auckland, New Zealand, September 1999, No. 4. 1999, 11–14; 19 Ref.
82 Welch A A, Lund E, Amiano P, et al. Variability of fish consumption within the 10 European countries participating in the European Investigation into Cancer and Nutrition (EPIC) study. Public Health Nutrition. 2002;5(6B):1273-85. [pmid: 12639232].
83 Wigmore S J, Barber M D, Ross J A, Tisdale M J, Fearon K C. Effect of oral eicosapentaenoic acid on weight loss in patients with pancreatic cancer. Nutrition & Cancer. 2000;36(2):177-84. [pmid: 10890028].
84 Wigmore S J, Fearon K C H, Maingay J P, Ross J A. Down-regulation of the acute-phase response in patients with pancreatic cancer cachexia receiving oral eicosapentaenoic acid is mediated via suppression of interleukin-6. Clinical Science. 1997;92(2):215-21. [pmid: 9059324].
85 Wigmore S J, Ross J A, Falconer J S, et al. The effect of polyunsaturated fatty acids on the progress of cachexia in patients with pancreatic cancer. Nutrition. 1996;12(1 SUPPL.):S27-S30. [pmid: 8850216].
86 Zhang J, Temme E H, Kesteloot H. Fish consumption is inversely associated with male lung cancer mortality in countries with high levels of cigarette smoking or animal fat consumption. International Journal of Epidemiology. 2000;29(4):615-21. [pmid: 10922336].
87 Zhuo X G, Watanabe S. Factor analysis of digestive cancer mortality and food consumption in 65 Chinese counties. Journal of Epidemiology. 1999;9(4):275-84. [pmid: 10510586].
88 Zuijdgeest-van Leeuwen S, Dagnelie P, Rietveld T, et al. Inhibition of lipolysis by eicosapentaenoic acid in weight-losing cancer patients and healthy volunteers [abstract]. Clinical Nutrition. 1998;17(sup 1):13.
89 Zuijdgeest-van Leeuwen S, Dagnelie P, Rietveld T, et al. Eicosapentaenoic acid inhibits lipolysis in weightlosing cancer patients as well as in healthy volunteers[abstract]. European Journal of Gastroenterology & Hepatology. 1998;10(supp 12):A67.

### Rejected No Outcomes of Interest/Effect of Omega-3 on Outcome Not Described (n = 14)

1 Baronzio G, Freitas I, Griffini P, et al. Omega-3 fatty acids can improve radioresponse modifying tumor interstitial pressure, blood rheology and membrane peroxidability. Anticancer Res. 1994;14(3A):1145-54. [pmid: 8074465].
2 Bennett F C, Ingram D M. Diet and female sex hormone concentrations: an intervention study for the type of fat consumed. Am. 1990;52(5):808-12.
3 Bertolini G, Iapichino G, Radrizzani D, et al. Early enteral immunonutrition in patients with severe sepsis: results of an interim analysis of a randomized multicentre clinical trial. Intensive Care Med. 2003;29(5):834-40. [pmid: 12684745].
4 Bougnoux P, Koscielny S, Chajes V, Descamps P, Couet C, Calais G. alpha-Linolenic acid content of adipose breast tissue: a host determinant of the risk of early metastasis in breast cancer. British Journal of Cancer. 1994;70(2):330-4. [pmid: 7914425].
5 Colas S, Paon L, Denis F, et al. Enhanced radiosensitivity of rat autochthonous mammary tumors by dietary docosahexaenoic acid. Int J Cancer. 2004;109(3):449-54. [pmid: 14961586].
6 Fearon K, von Meyenfeldt M, Moses A et al. Effect of an energy and protein dense high n-3 fatty acid oral supplement on tumor response in patients with cancer cachexia. International Journal of Cancer 2002; supp 13:245.
7 Huang X E, Tajima K, Hamajima N, et al. Effects of dietary, drinking, and smoking habits on the prognosis of gastric cancer. Nutr. 2000;38(1):30-6.
8 Jatoi A, Rowland K, Loprinzi C L, et al. An eicosapentaenoic acid supplement versus megestrol acetate versus both for patients with cancer-associated wasting: a North Central Cancer Treatment Group and National Cancer Institute of Canada collaborative effort. J Clin Oncol. 2004;22(12):2469-76. [pmid: 15197210].
9 Johnson I T. Anticarcinogenic effects of diet-related apoptosis in the colorectal mucosa. Food Chem Toxicol. 2002;40(8):1171-8. [pmid: 12067580].
10 Moses A W, Slater C, Preston T, Barber M D, Fearon K C. Reduced total energy expenditure and physical activity in cachectic patients with pancreatic cancer can be modulated by an energy and protein dense oral supplement enriched with n-3 fatty acids. Br J Cancer. 2004;90(5):996-1002. [pmid: 14997196].
11 Palozza P, Calviello G, Luberto C, et al. Effects of n-3 PUFA on cell proliferation and vitamin E content in human subjects at high risk for colon cancer. Acta Medica Romana. 1994;32(4):623-32.
12 Roynette C E, Calder P C, Dupertuis Y M, Pichard C. n-3 polyunsaturated fatty acids and colon cancer prevention. Clin Nutr. 2004;23(2):139-51. [pmid: 15030953].
13 Takatsuka H, Takemoto Y, Iwata N, et al. Oral eicosapentaenoic acid for complications of bone marrow transplantation. Bone Marrow Transplant. 2001;28(8):769-74. [pmid: 11781629].
14 Trichopoulou A, Costacou T, Bamia C, Trichopoulos D. Adherence to a Mediterranean diet and survival in a Greek population. New England Journal of Medicine. 2003;Vol 348(26):(Pp 2599-2608). 26 JUN 2003. [pmid: 12826634].

### Rejected Unable to Find Translator (n = 2)

1 Hagve TA. [Correlation between dietary fat and cancer]. [Norwegian]. Tidsskrift for Den Norske Laegeforening 2934; 107(33):2951–4.
2 Trushina E N, Mustafina O K, Volgarev M N. [Review] [Russian]. Voprosy Pitaniia. 2003;72(3):35-40. [pmid: 12872662].

### Rejected Not Able to Compare Omega-3 Effect Across Study Arms (n = 39)

1 Appleby P N, Thorogood M, Mann J I, Key T J. The Oxford Vegetarian Study: an overview. American Journal of Clinical Nutrition. 1999;70(3 Suppl):525S-31S. [pmid: 10479226].
2 Barrett-Connor E, Friedlander N J. Dietary fat, calories, and the risk of breast cancer in postmenopausal women: a prospective population-based study. Journal of the American College of Nutrition. 1993;12(4):390-9. [pmid: 8409101].
3 Berrino F, Secreto G, Camerini E, et al. A randomized trial to prevent hormonal patterns at high risk for breast cancer: the DIANA (diet and androgens) project. Am J Clin Nutr. 1998;68(supp):1529S.
4 Bougnoux P, Germain E, Chajes V, et al. Cytotoxic drugs efficacy correlates with adipose tissue docosahexaenoic acid level in locally advanced breast carcinoma. British Journal of Cancer. 1999;79(1112):1765-9. [pmid: 10206290].
5 Braga M, Gianotti L, Vignali A, Di Carlo V. Immunonutrition in gastric cancer surgical patients. [comment]. Nutrition. 1998;14(1112):831-5. [pmid: 9834924].
6 Breslow R A, Graubard B I, Sinha R, Subar A F. Diet and lung cancer mortality: A 1987 National Health Interview Survey cohort study. Cancer Causes & Control. 2000;11(5):419-31. [pmid: 10877335].
7 Buzzard I M, Asp E H, Chlebowski R T, et al. Diet intervention methods to reduce fat intake: nutrient and food group composition of self-selected low-fat diets. Journal of the American Dietetic Association. 1990;90(1):42-50. [pmid: 2404049].
8 Castagnetta L, Granata O M, Cusimano R, et al. The Mediet Project. Annals of the New York Academy of Sciences. 2002;963:282-9. Jun. [pmid: 12095953].
9 Darmadi I, Horie Y, Wahlqvist M L, et al. Food and nutrient intakes and overall survival of elderly Japanese. Asia-Pacific-Journal-of-Clinical-Nutrition. 2000;9(1):7-11.
10 De Lorgeril M, Salen P, Martin J L, Monjaud I, Boucher P, Mamelle N. Mediterranean dietary pattern in a randomized trial: Prolonged survival and possible reduced cancer rate. Archives of Internal Medicine. 1998;158(11):1181-7. [pmid: 9625397].
11 Djuric Z, Depper J B, Uhley V, et al. Oxidative DNA damage levels in blood from women at high risk for breast cancer are associated with dietary intakes of meats, vegetables, and fruits. Journal-of-the-American-Dietetic-Association. 1998;98(5):524-8. 33 ref. [pmid: 9597024].
12 Dolecek T A. Epidemiological evidence of relationships between dietary polyunsaturated fatty acids and mortality in the Multiple Risk Factor Intervention Trial. Proceedings of the Society for Experimental Biology and Medicine. 1992;Vol 200(2):(Pp 177-182). [pmid: 1579579].
13 Dolecek TA, Grandits G. Dietary polyunsaturated fatty acids and mortality in the Multiple Risk Factor Intervention Trial (MRFIT). In: Simopoulos AP, Kifer RR, Martin RE, Barlow SM, eds. Health effects of omega-3 polyunsaturated fatty acids in seafoods. Vol. 66. Basel, Karger: World Rev Nutr Diet, 1991: 205–16.
14 Fidanza F, Zappia V (ed.), Salvatore M (ed.), Ragione FD. Nutrition and cancer: general considerations. Advances-in-Nutrition-and-Cancer. 1993, 65–67; 6 Ref.
15 Henderson M M, Kushi L H, Thompson D J, et al. Feasibility of a randomized trial of a low-fat diet for the prevention of breast cancer: dietary compliance in the Women's Health Trial Vanguard Study. Preventive Medicine. 1990;19(2):115-33. [pmid: 2193306].
16 Horn-Ross P L, Barnes S, Lee M, et al. Assessing phytoestrogen exposure in epidemiologic studies: development of a database (United States). Cancer. 2000;11(4):289-98.
17 Ikeda M, Yoshimoto K, Yoshimura T, et al. A cohort study on the possible association between broiled fish intake and cancer. Gann, The Japanese Journal of Cancer Research. 1983;Vol 74(5):(Pp 640-648).
18 Jenkins D J, Kendall C W, Connelly P W, et al. Effects of high- and low-isoflavone (phytoestrogen) soy foods on inflammatory biomarkers and proinflammatory cytokines in middle-aged men and women. Metabolism: Clinical & Experimental. 2002;51(7):919-24. [pmid: 12077742].
19 Knekt P, Albanes D, Seppanen R, et al. Dietary fat and risk of breast cancer. American Journal of Clinical Nutrition. 1990;52(5):903-8. [pmid: 2239766].
20 Knekt P, Seppanen R, Jarvinen R, et al. Dietary cholesterol, fatty acids, and the risk of lung cancer among men. Nutrition-and-Cancer. 1991;16(34):267-75. 29 ref. [pmid: 1775388].
21 Kristal A R, White E, Shattuck A L, et al. Long-term maintenance of a low-fat diet: durability of fat-related dietary habits in the Women's Health Trial. Journal of the American Dietetic Association. 1992;92(5):553-9. [pmid: 1573135].
22 Lanza E, Schatzkin A, Ballard-Barbash R et al. The polyp prevention trial II: dietary intervention program and participant baseline dietary characteristics. [erratum appears in Cancer Epidemiol Biomarkers Prev 1996 Jul;5(7):584 Note: Clifford DC[corrected to Clifford C]]. Cancer Epidemiology, Biomarkers & Prevention 1996; 5(5):385–92.
23 Lund E, Bonaa K H. Reduced breast cancer mortality among fishermen's wives in Norway. Cancer Causes & Control. 1993;4(3):283-7. [pmid: 8318644].
24 Man-Fan Wan J, Kanders B S, Kowalchuk M, et al. Omega 3 fatty acids and cancer metastasis in humans. [Review] [36 refs]. World Review of Nutrition & Dietetics. 1991;66:477-87. [pmid: 2053364].
25 Michaud D S, Augustsson K, Rimm E B, Stampfer M J, Willet W C, Giovannucci E. A prospective study on intake of animal products and risk of prostate cancer. Cancer Causes & Control. 2001;12(6):557-67. [pmid: 11519764].
26 Michels K B, Wolk A. A prospective study of variety of healthy foods and mortality in women. International Journal of Epidemiology. 2002;31(4):847-54. [pmid: 12177033].
27 Mills P K, Beeson W L, Phillips R L, Fraser G E. Bladder cancer in a low risk population: results from the Adventist health study. American-Journal-of-Epidemiology. 1991;133(3):230-9. [pmid: 2000840].
28 Multiple risk factor intervention trial research group. Multiple risk factor intervention trial: Risk factor changes and mortality results. JAMA. 1982;248(12):1465-77. [pmid: 7050440].
29 Nordevang E, Azavedo E, Svane G, Nilsson B, Holm L E. Dietary habits and mammographic patterns in patients with breast cancer. Breast Cancer Research & Treatment. 1993;26(3):207-15. [pmid: 8251646].
30 Osborne M P, Karmali R A, Herschcopf R J, et al. Omega-3 fatty acids: Modulation of estrogen metabolism and potential for breast cancer prevention. Cancer Investigation. 1988;6(5):629-31.
31 Pearce M L, Dayton S. Incidence of cancer in men on a diet high in polyunsaturated fat. Lancet. 1971;1(7697):464-7. [pmid: 4100347].
32 Pfeiffer R, McShane L, Wargovich M, et al. The effect of a low-fat, high fiber, fruit and vegetable intervention on rectal mucosal proliferation. Cancer. 2003;98(6):1161-8. [pmid: 12973839].
33 Rylander L, Hagmar L. Mortality and cancer incidence among women with a high consumption of fatty fish contaminated with persistent organochlorine compounds. Scandinavian Journal of Work, Environment & Health. 1995;21(6):419-26. [pmid: 8824747].
34 Schatzkin A, Lanza E, Corle D, et al. Lack of effect of a low-fat, high-fiber diet on the recurrence of colorectal adenomas. New-England-Journal-of-Medicine. 2000;342(16):1149-55. 37 ref. [pmid: 10770979].
35 Sieri S, Krogh V, Muti P, et al. Fat and protein intake and subsequent breast cancer risk in postmenopausal women. Nutrition & Cancer. 2002;42(1):10-7. [pmid: 12235640].
36 Svensson B G, Mikoczy Z, Stromberg U, Hagmar L. Mortality and cancer incidence among Swedish fishermen with a high dietary intake of persistent organochlorine compounds. Scandinavian Journal of Work, Environment & Health. 1995;21(2):106-15. [pmid: 7618056].
37 Terry P, Suzuki R, Hu F B, Wolk A. A prospective study of major dietary patterns and the risk of breast cancer. Cancer Epidemiology, Biomarkers & Prevention. 2001;10(12):1281-5.
38 Veierod M B, Laake P, Thelle D S. Dietary fat intake and risk of prostate cancer: a prospective study of 25,708 Norwegian men. International Journal of Cancer. 1997;73(5):634-8.
39 Wu Y, Zheng W, Sellers T A, Kushi L H, Bostick R M, Potter J D. Dietary cholesterol, fat, and lung cancer incidence among older women: the Iowa Women's Health Study (United States). Cancer Causes & Control. 1994;5(5):395-400. [pmid: 7999960].

### Rejected Study Design: Case Control/Case Series (n = 224)

1 Agheli N, Kurkure A, Doctor V, Therwath A. A comparative study on the role of diet in breast cancer in a high-risk ethnic group. Journal-of-Clinical-Biochemistry-and-Nutrition. 1996;20(1):71-81. 29 ref.
2 Ahn Jiyoung, Park InSuh, Lee KyongSik, et al. Fatty acid patterns in gastric mucosa of stomach cancer patients. Yonsei-Medical-Journal. 2001;42(2):220-6. 23 ref. [pmid: 11371111].
3 Alavanja M C R, Brown C C, Swanson C, Brownson R C, Kolonel L N. Saturated fat intake and lung cancer risk among nonsmoking women in Missouri. Journal-of-the-National-Cancer-Institute. 1993;85(23):1906-16. [pmid: 8230280].
4 Almendingen K, Hofstad B, Trygg K, Hoff G, Hussain A, Vatn M H. Current diet and colorectal adenomas: A case-control study including different sets of traditionally chosen control groups. European Journal of Cancer Prevention. 2001;10(5):395-406. [pmid: 11711754].
5 Amadori D, Nanni O, Ricci M, et al. Hospital versus population controls in a retrospective study on diet and stomach cancer. European-Journal-of-Public-Health. 1995;5(3):209-14. 23 ref.
6 Amaral T, Almeida MDV de, Barros H et al. Diet and colorectal cancer in Portugal. Nutrition-and-Lifestyle:-Opportunities-for-Cancer-Prevention.-European-Conference-on-Nutrition-and-Cancer-Held-in-Lyon,-France-on-21–24-June,-2003. 2002, 549–552; 5 Ref.
7 Armstrong R W, Armstrong M J, Yu M C, Henderson B E. Salted fish and inhalants as risk factors for nasopharyngeal carcinoma in Malaysian Chinese. Cancer Research. 1983;43(6):2967-70. [pmid: 6850606].
8 Armstrong R W, Eng A C. Salted fish and nasopharyngeal carcinoma in Malaysia. Social Science & Medicine. 1983;17(20):1559-67. [pmid: 6635717].
9 Armstrong R W, Imrey P B, Lye M S, Armstrong M J, Yu M C, Sani S. Nasopharyngeal carcinoma in Malaysian Chinese: salted fish and other dietary exposures. International Journal of Cancer. 1998;77(2):228-35.
10 Bagga D, Anders K H, Wang H J, Glaspy J A. Long-chain n-3-to-n-6 polyunsaturated fatty acid ratios in breast adipose tissue from women with and without breast cancer. Nutrition & Cancer. 2002;42(2):180-5. [pmid: 12416257].
11 Bain C, Green A, Siskind V, Alexander J, Harvey P. Diet and melanoma. An exploratory case-control study. Annals of Epidemiology. 1993;3(3):235-8. [pmid: 8275194].
12 Barber M D, Ross J A, Preston T, Shenkin A, Fearon K C. Fish oil-enriched nutritional supplement attenuates progression of the acute-phase response in weight-losing patients with advanced pancreatic cancer. Journal of Nutrition. 1999;129(6):1120-5. [pmid: 10356075].
13 Barber MDRJMDPTSAaFK. A fish oil-enriched nutritional supplement modulates changes in the acute phase protein response in weight-losing pancreatic cancer patients [abstract]. Clinical Nutrition. Vol.17 Suppl 1, Pp.41, 1998.
14 Baro L, Hermoso J C, Nunez M C, Jimenez-Rios J A, Gil A. Abnormalities in plasma and red blood cell fatty acid profiles of patients with colorectal cancer. British Journal of Cancer. 1998;77(11):1978-83. [pmid: 9667678].
15 Bennink M, Mayle J, Bourquin L, Thiagarajan D. Evaluation of soy protein in risk reduction for colon cancer and cardiovascualr disease: preliminary results. Am J Clin Nutr. 1998;68(supp):1529S.
16 Berg JP, Glattre E, Haldorsen T et al. Longchain serum fatty acids and risk of thyroid cancer: a population-based case-control study in Norway. [erratum appears in Cancer Causes Control 1995 Mar;6(2):182]. Cancer Causes & Control 1994; 5(5):433–9.
17 Boeing H, Schlehofer B, Blettner M, Wahrendorf J. Dietary carcinogens and the risk for glioma and meningioma in Germany. International Journal of Cancer. 1993;53(4):561-5.
18 Bosetti C, La Vecchia C, Talamin R, et al. Energy, macronutrients and laryngeal cancer risk. Annals of Oncology. 2003;Vol 14(6):(Pp 907-912). 01 JUN 2003. [pmid: 12796029].
19 Bosetti C, Negri E, Franceschi S, et al. Diet and ovarian cancer risk: a case-control study in Italy. International-Journal-of-Cancer. 2001;93(6):911-5. 39 ref.
20 Bosetti C, Negri E, Franceschi S, et al. Olive oil, seed oils and other added fats in relation to ovarian cancer (Italy). Cancer-Causes-and-Control. 2002;13(5):465-70. [pmid: 12146851].
21 Bosetti C, Vecchia C la, Talamini R et al. Food groups and laryngeal cancer risk: a case-control study from Italy and Switzerland. International-Journal-of-Cancer 2002; 100(3):355–60; 34 ref.
22 Bosetti C, Vecchia C la, Talamini R et al. Food groups and risk of squamous cell esophageal cancer in northern Italy. International-Journal-of-Cancer 2000; 87(2):289–94; 21 ref.
23 Bougnoux P, Maillard V, Ferrari P, Jourdan M L, Chajes V. n-3 fatty acids and breast cancer. [Review] [26 refs]. IARC Scientific Publications. 2002;156:337-41. [pmid: 12484201].
24 Boutron Ruault M C, Senesse P, Faivre J, Chatelain N, Belghiti C, Meance S. Foods as risk factors for colorectal cancer: a case - control study in Burgundy (France). European-Journal-of-Cancer-Prevention. 1999;8(3):229-35. 24 ref. [pmid: 10443952].
25 Braga C, La Vecchia C, Franceschi S, et al. Olive oil, other seasoning fats, and the risk of colorectal carcinoma. Cancer. 1998;82(3):448-53. [pmid: 9452260].
26 Braga C, La Vecchia C, Negri E, Franceschi S, Parpinel M. Intake of selected foods and nutrients and breast cancer risk: an age- and menopause-specific analysis. Nutrition & Cancer. 1997;28(3):258-63. [pmid: 9343834].
27 Brown L M, Gridley G, Pottern L M, et al. Diet and nutrition as risk factors for multiple myeloma among blacks and whites in the United States. Cancer-Causes-and-Control. 2001;12(2):117-25. 35 ref. [pmid: 11246840].
28 Bueno de Mesquita H B, Maisonneuve P, Runia S, Moerman C J. Intake of foods and nutrients and cancer of the exocrine pancreas: a population-based case-control study in the Netherlands. International-Journal-of-Cancer. 1991;48(4):540-9. 48 ref.
29 Busstra M C, Siezen C L, Grubben M J, van Kranen H J, Nagengast F M, van't Veer P. Tissue levels of fish fatty acids and risk of colorectal adenomas: a case-control study (Netherlands). Cancer Causes & Control. 2003;14(3):269-76. [pmid: 12814206].
30 Calza S, Ferraroni M, Vecchia C la, Franceschi S, Decarli A, la Vecchia C. Low-risk diet for colorectal cancer in Italy. European-Journal-of-Cancer-Prevention 2001; 10(6):515–21; 27 ref.
31 Carley K W, Raghunath Puttaiah, Alvarez J O, Heimburger D C, Anantha N, Puttaiah R. Diet and oral premalignancy in female South Indian tobacco and betel chewers: a case-control study. Nutrition-and-Cancer. 1994;22(1):73-84. 45 ref. [pmid: 11304912].
32 Caughey G E, Mantzioris E, Gibson R A, Cleland L G, James M J. The effect on human tumor necrosis factor alpha and interleukin 1 beta production of diets enriched in n-3 fatty acids from vegetable oil or fish oil. American Journal of Clinical Nutrition. 1996;63(1):116-22. [pmid: 8604658].
33 Centonze S, Boeing H, Leoci C, Guerra V, Misciagna G. Dietary habits and colorectal cancer in a low-risk area. Results from a population-based case-control study in southern Italy. Nutrition & Cancer. 1994;21(3):233-46. [pmid: 8072877].
34 Chajes V, Cognault S, Maillard V, et al. alpha-Linoleic acid, antioxidants and mammary tumour growth. Body Fat, Nutrition and Health, Topical Questions Bordeaux; Pessac, France, 25 and 26 November 1999. OCL -Oleagineux,-Corps-Gras,-Lipides. 2000;7(1):64-7. 28 ref.
35 Chajes V, Hulten K, Kappel AL van et al. Fatty-acid composition in serum phospholipids and risk of breast cancer: an incident case-control study in Sweden. International-Journal-of-Cancer 1999; 83(5):585–90; 29 ref.
36 Chajes V, Hulten K, Van Kappel A L, et al. Fatty acid composition in serum phospholipids and risk of breast cancer: A prospective cohort study in northern Sweden. Lipids. 1999;34(6 SUPPL.):S113. [pmid: 10419113].
37 Chajes V, Lanson M, Fetissof F, Lhuillery C, Bougnoux P. Membrane fatty acids of breast carcinoma: Contribution of host fatty acids and tumor properties. International Journal of Cancer. 1995;63(2):169-75.
38 Challier B, Perarnau J M, Viel J F. Garlic, onion and cereal fibre as protective factors for breast cancer: a French case-control study. European Journal of Epidemiology. 1998;14(8):737-47. [pmid: 9928867].
39 Chaudry A, McClinton S, Moffat L E F, Wahle K W J. Essential fatty acid distribution in the plasma and tissue phospholipids of patients with benign and malignant prostatic disease. British Journal of Cancer. 1991;64(6):1157-60. [pmid: 1764380].
40 Chen H L, Ward M H, Graubard B I, et al. Dietary patterns and adenocarcinoma of the esophagus and distal stomach. American-Journal-of-Clinical-Nutrition. 2002;75(1):137-43. 49 ref. [pmid: 11756071].
41 Chie. 20th Annual San Antonio Breast Cancer Symposium. San Antonio, Texas, USA. December 3–6, 1997. Abstracts. Breast. 1997;46(1):23-113.
42 Crosignani P, Russo A, Tagliabue G, Berrino F. Tobacco and diet as determinants of survival in male laryngeal cancer patients. International Journal of Cancer. 1996;65(3):308-13.
43 Dai Q, Shu X O, Jin F, Gao Y T, Ruan Z X, Zheng W. Consumption of animal foods, cooking methods, and risk of breast cancer. Cancer Epidemiology, Biomarkers & Prevention. 2002;11(9):801-8.
44 Darby S, Whitley E, Doll R, Key T, Silcocks P. Diet, smoking and lung cancer: a case-control study of 1000 cases and 1500 controls in South-West England. British Journal of Cancer. 2001;84(5):728-35. [pmid: 11237398].
45 Davies T W, Treasure F P, Welch A A, Day N E. Diet and basal cell skin cancer: results from the EPIC-Norfolk cohort. British Journal of Dermatology. 2002;146(6):1017-22. [pmid: 12072070].
46 De Stefani E, Deneo-Pellegrini H, Boffetta P, Ronco A, Mendilaharsu M. Alpha-linolenic acid and risk of prostate cancer: a case-control study in Uruguay. Cancer Epidemiology, Biomarkers & Prevention. 2000;9(3):335-8.
47 De Stefani E, Deneo Pellegrini H, Mendilaharsu M, Ronco A, de Stefani E. Essential fatty acids and breast cancer: a case-control study in Uruguay. International-Journal-of-Cancer. 1998;76(4):491-4. 38 ref.
48 Deneo Pellegrini H, Stefani E, Ronco A, Mendilaharsu M, de Stefani E. Foods, nutrients and prostate cancer: a case-control study in Uruguay. British-Journal-of-Cancer. 1999;80(34):591-7. 29 ref. [pmid: 10408871].
49 Diergaarde B, Geloof WL van, Muijen GNP van et al. Dietary factors and the occurrence of truncating APC mutations in sporadic colon carcinomas: a Dutch population-based study. Carcinogenesis 2003; 24(2):283–90; 46 ref.
50 Dos Santos Silva I, Mangtani P, McCormack V, Bhakta D, Sevak L, McMichael A J. Lifelong vegetarianism and risk of breast cancer: a population-based case-control study among South Asian migrant women living in England. International Journal of Cancer. 2002;99(2):238-44.
51 Drukker M, Bueno de Mesquita H B. Risk-increasing factors in the diet and cancer of the pancreas. Voeding. 1993;54(1112):10-4. 5 ref.
52 Eid A, Berry E M. The relationship between dietary fat, adipose tissue composition, and neoplasms of the breast. Nutrition-and-Cancer. 1988;11(3):173-7. 27 ref. [pmid: 3405869].
53 Esteve J, Riboli E, Pequignot G, et al. Diet and cancers of the larynx and hypopharynx: the IARC multi-center study in southwestern Europe. Cancer Causes & Control. 1996;7(2):240-52. [pmid: 8740737].
54 Ewings P, Bowie C. A case-control study of cancer of the prostate in Somerset and east Devon. British Journal of Cancer. 1996;74(4):661-6. [pmid: 8761387].
55 Fang J L, Vaca C E, Valsta L M, Mutanen M. Determination of DNA adducts of malonaldehyde in humans: effects of dietary fatty acid composition. Carcinogenesis. 1996;17(5):1035-40. [pmid: 8640909].
56 Farrow D C, Davis S. Diet and the risk of pancreatic cancer in men. American Journal of Epidemiology. 1990;132(3):423-31. [pmid: 2389747].
57 Favero A, Parpinel M, Franceschi S. Diet and risk of breast cancer: major findings from an Italian case-control study. Biomedicine-and-Pharmacotherapy. 1998;52(3):109-15. 32 ref.
58 Fernandez-Banares F, Esteve M, Navarro E, et al. Changes of the mucosal n3 and n6 fatty acid status occur early in the colorectal adenoma-carcinoma sequence. [comment]. Gut. 1996;38(2):254-9. [pmid: 8801207]. [pmcid: 1383033].
59 Fernandez E, Chatenoud L, La Vecchia C, Negri E, Franceschi S. Fish consumption and cancer risk. [comment]. American Journal of Clinical Nutrition. 1999;70(1):85-90. [pmid: 10393143].
60 Fortes C, Forastiere F, Farchi S, et al. The protective effect of the Mediterranean diet on lung cancer. Nutrition & Cancer. 2003;46(1):30-7. [pmid: 12925301].
61 Franceschi S. Nutrients and food groups and large bowel cancer in Europe. European Journal of Cancer Prevention. 1999;8(Suppl 1):S49-52. Dec. [pmid: 10772418].
62 Franceschi S, Fassina A, Talamini R, et al. Risk factors for thyroid cancer in northern Italy. International Journal of Epidemiology. 1989;18(3):578-84. [pmid: 2807659].
63 Franceschi S, Favero A. The role of energy and fat in cancers of the breast and colon-rectum in a southern European population. Annals of Oncology. 1999;10(Suppl 6):61-3. [pmid: 10676554].
64 Franceschi S, Favero A, Conti E, et al. Food groups, oils and butter, and cancer of the oral cavity and pharynx. British-Journal-of-Cancer. 1999;80(34):614-20. 37 ref. [pmid: 10408875].
65 Franceschi S, Favero A, Decarli A, et al. Intake of macronutrients and risk of breast cancer. Lancet. 1996;347(9012):1351-6. [pmid: 8637339].
66 Franceschi S, Favero A, Parpinel M, Giacosa A, Vecchia C la, La Vecchia C. Italian study on colorectal cancer with emphasis on influence of cereals. Cereals, Fibre and Colorectal and Breast Cancers Proceedings of a European Cancer Prevention Organisation consensus meeting; Santa Margherita, Italy, 2–5 October, 1997. European-Journal-of-Cancer-Prevention. 1998, 7(Supplement2):S19–S23; 24 ref.
67 Franceschi S, Favero A, Vecchia C la et al. Influence of food groups and food diversity on breast cancer risk in Italy. International-Journal-of-Cancer 1995; 63(6):785–9; 20 ref.
68 Franceschi S, La Vecchia C, Russo A, Negri E, Favero A, Decarli A. Low-risk diet for breast cancer in Italy. Cancer Epidemiology, Biomarkers & Prevention. 1997;6(11):875-9.
69 Freeman V L, Meydani M, Yong S, et al. Prostatic levels of fatty acids and the histopathology of localized prostate cancer. Journal of Urology. 2000;164(6):2168-72. [pmid: 11061949].
70 Gann P H, Hennekens C H, Sacks F M, Grodstein F, Giovannucci E L, Stampfer M J. Prospective study of plasma fatty acids and risk of prostate cancer. Journal of the National Cancer Institute. 1994;Vol 86(4):(Pp 281-286). [pmid: 8158682].
71 Gerber M, Richardson S, Crastes de Paulet P, Pujol H, Crastes de Paulet A. Relationship between vitamin E and polyunsaturated fatty acids in breast cancer: nutritional and metabolic aspects. Cancer. 1989;64(11):2347-52. 40 ref. [pmid: 2804926].
72 Glattre E, Haldorsen T, Berg J P, Stensvold I, Solvoll K. Norwegian case-control study testing the hypothesis that seafood increases the risk of thyroid cancer. Cancer Causes & Control. 1993;4(1):11-6. [pmid: 8431525].
73 Godley P A, Campbell M K, Gallagher P, Martinson F E A, Mohler J L, Sandler R S. Biomarkers of essential fatty acid consumption and risk of prostatic carcinoma. Cancer Epidemiology, Biomarkers & Prevention. 1996;5(11):889-95.
74 Godley P A, Campbell M K, Miller C, et al. Correlation between biomarkers of omega-3 fatty acid consumption and questionnaire data in African American and Caucasian United States males with and without prostatic carcinoma. Cancer Epidemiology, Biomarkers & Prevention. 1996;5(2):115-9.
75 Gogos C A, Ginopoulos P, Zoumbos N C, Apostolidou E, Kalfarentzos F. The effect of dietary omega-3 polyunsaturated fatty acids on T-lymphocyte subsets of patients with solid tumors. Cancer Detection & Prevention. 1995;19(5):415-7. [pmid: 7585727].
76 Gonzalez C A, Sanz J M, Marcos G, et al. Dietary factors and stomach cancer in Spain: a multi-centre case-control study. International-Journal-of-Cancer. 1991;49(4):513-9. 36 ref.
77 Goodman M T, Nomura A M, Wilkens L R, Hankin J. The association of diet, obesity, and breast cancer in Hawaii. Cancer Epidemiology, Biomarkers & Prevention. 1992;1(4):269-75.
78 Goodman M T, Wilkens L R, Hankin J H, Lyu L C, Wu A H, Kolonel L N. Association of soy and fiber consumption with the risk of endometrial cancer. American Journal of Epidemiology. 1997;146(4):294-306. [pmid: 9270408].
79 Goodstine S L, Zheng T, Holford T R, et al. Dietary (n-3)/(n-6) fatty acid ratio: possible relationship to premenopausal but not postmenopausal breast cancer risk in U.S. women. Journal of Nutrition. 2003;133(5):1409-14. [pmid: 12730430].
80 Hagmar L, Linden K, Nilsson A, et al. Cancer incidence and mortality among Swedish Baltic Sea fishermen. Scandinavian Journal of Work, Environment & Health. 1992;18(4):217-24. [pmid: 1411363].
81 Hakim I A, Harris R B, Ritenbaugh C. Fat intake and risk of squamous cell carcinoma of the skin. Nutrition & Cancer. 2000;36(2):155-62. [pmid: 10890025].
82 Harvei S, Bjerve K S, Tretli S, Jellum E, Robsahm T E, Vatten L. Prediagnostic level of fatty acids in serum phospholipids: omega-3 and omega-6 fatty acids and the risk of prostate cancer. International Journal of Cancer. 1997;71(4):545-51.
83 Hayes R B, Ziegler R G, Gridley G, et al. Dietary factors and risks for prostate cancer among blacks and whites in the United States. Cancer Epidemiology, Biomarkers & Prevention. 1999;8(1):25-34.
84 Hirose K, Tajima K, Hamajima N, et al. A large-scale, hospital-based case-control study of risk factors of breast cancer according to menopausal status. Jpn J Cancer Res. 1995;86(2):146-54. [pmid: 7730137].
85 Hirose K, Takezaki T, Hamajima N, Miura S, Tajima K. Dietary factors protective against breast cancer in Japanese premenopausal and postmenopausal women. International Journal of Cancer. 2003;107(2):276-82.
86 Horn-Ross P L, Barnes S, Lee M, et al. Assessing phytoestrogen exposure in epidemiologic studies: development of a database (United States). Cancer. 2000;11(4):289-98.
87 Hoshiyama Y, Sasaba T. A case-control study of single and multiple stomach cancers in Saitama Prefecture, Japan. Japanese Journal of Cancer Research. 1992;83(9):937-43. [pmid: 1429203].
88 Hoshiyama Y, Sekine T, Sasaba T. A case-control study of colorectal cancer and its relation to diet, cigarettes, and alcohol consumption in Saitama Prefecture, Japan. Tohoku Journal of Experimental Medicine. 1993;171(2):153-65. [pmid: 8128484].
89 Hu JinFu, Vecchia C la, Negri E et al. Diet and brain cancer in adults: a case-control study in northeast China. International-Journal-of-Cancer 1999; 81(1):20–3; 24 ref.
90 Hyun Ja Kim, Woong Ki C, Mi Kyung Kim, Sang Sun Lee, Bo Youl C. Dietary factors and gastric cancer in Korea: A case-control study. International Journal of Cancer. 2002;Vol 97(4):(Pp 531-535). 01 FEB 2002.
91 Ilow R, Regulska Ilow B, Hudziec P, Cieslinska A. Comparison of nutritional habits of women with breast or ovarian carcinoma and of those of healthy women. 1. Nutritional habits and frequency of consumption of food products. Zywienie-Czlowieka-i-Metabolizm. 1995;22(4):335-50. 23 ref.
92 Ingram D M, Nottage E, Roberts T. The role of diet in the development of breast cancer: a case-control study of patients with breast cancer, benign epithelial hyperplasia and fibrocystic disease of the breast. British-Journal-of-Cancer. 1991;64(1):187-91. 9 ref. [pmid: 1854621].
93 Ito L S, Inoue M, Tajima K, et al. Dietary factors and the risk of gastric cancer among Japanese women: a comparison between the differentiated and non-differentiated subtypes. Annals of Epidemiology. 2003;13(1):24-31. [pmid: 12547482].
94 Ji B T, Chow W H, Yang G, et al. Dietary habits and stomach cancer in Shanghai, China. International Journal of Cancer. 1998;76(5):659-64.
95 Kaaks R, Tuyns A J, Haelterman M, Riboli E. Nutrient intake patterns and gastric cancer risk: a case-control study in Belgium. International-Journal-of-Cancer. 1998;78(4):415-20. 41 ref.
96 Kato K, Akai S, Tominaga S, Kato I. A case-control study of biliary tract cancer in Niigata Prefecture, Japan. Japanese Journal of Cancer Research. 1989;80(10):932-8. [pmid: 2515177].
97 Key T J A, Silcocks P B, Davey G K, Appleby P N, Bishop D T. A case-control study of diet and prostate cancer. British-Journal-of-Cancer. 1997;76(5):678-87. 43 ref. [pmid: 9303371].
98 Kim H J, Chang W K, Kim M K, Lee S S, Choi B Y. Dietary factors and gastric cancer in Korea: a case-control study. International Journal of Cancer. 2002;97(4):531-5.
99 Klein V, Chajes V, Germain E, et al. Low alpha-linolenic acid content of adipose breast tissue is associated with an increased risk of breast cancer. European Journal of Cancer. 2000;36(3):335-40. [pmid: 10708934].
100 Kokoglu E, Tuter Y, Yazici Z, et al. Profiles of the fatty acids in the plasma membrane of human brain tumors. Cancer Biochemistry Biophysics. 1998;16(4):301-12. [pmid: 9925279].
101 Kolonel L N, Hankin J H, Wilkens L R, Fukunaga F H, Hinds M W. An epidemiologic study of thyroid cancer in Hawaii. Cancer Causes & Control. 1990;1(3):223-34. [pmid: 2102295].
102 Kolonel LN, Nomura AMY, Hinds MW, Hirohata T, Hankin JH, Lee J. Role of diet in cancer incidence in Hawaii. Cancer-Research 1983; 43(5):Suppl., 2397s–402s; 55 ref.
103 Koo L C. Dietary habits and lung cancer risk among Chinese females in Hong Kong who never smoked. Nutrition-and-Cancer. 1988;11(3):155-72. 33 ref. [pmid: 2841651].
104 Kotake K, Koyama Y, Nasu J, Fukutomi T, Yamaguchi N. Relation of family history of cancer and environmental factors to the risk of colorectal cancer: a case-control study. Japanese Journal of Clinical Oncology. 1995;25(5):195-202. [pmid: 7474407].
105 Kristal A R, Cohen J H, Qu P, Stanford J L. Associations of energy, fat, calcium, and vitamin D with prostate cancer risk. Cancer Epidemiology, Biomarkers & Prevention. 2002;11(8):719-25.
106 Kune G A, Bannerman S, Field B, et al. Diet, alcohol, smoking, serum beta-carotene, and vitamin A in male nonmelanocytic skin cancer patients and controls. Nutrition-and-Cancer. 1992;18(3):237-44. 19 ref. [pmid: 1296197].
107 Kyogoku S, Hirohata T, Nomura Y, Shigematsu T, Takeshita S, Hirohata I. Diet and prognosis of breast cancer. Nutrition-and-Cancer. 1992;17(3):271-7. 27 ref. [pmid: 1437645].
108 La Vecchia C, Decarli A, Negri E, et al. Dietary factors and the risk of epithelial ovarian cancer. Journal-of-the-National-Cancer-Institute. 1987;79(4):663-9. 19 ref. [pmid: 3116309].
109 la Vecchia C, Negri E, Franceschi S, Decarli A, Giacosa A, Lipworth L. Olive oil, other dietary fats, and the risk of breast cancer (Italy). Cancer Causes & Control. 1995;6(6):545-50. [pmid: 8580304].
110 Landa M C, Frago N, Tres A. Diet and the risk of breast cancer in Spain. European-Journal-of-Cancer-Prevention. 1994;3(4):313-20. 38 ref. [pmid: 7950885].
111 Launoy G, Milan C, Day N E, Pienkowski M P, Gignoux M, Faivre J. Diet and squamous-cell cancer of the oesophagus: a French multicentre case-control study. International Journal of Cancer. 1998;76(1):7-12.
112 Lawson N, Husband D, McGuigan J, Watson D C, Collins F J, Pandov H I. Increased levels of vaccenic acid in bronchogenic carcinoma tissue. Annals of Clinical Biochemistry. 1989;26(Pt 2):125-31. [pmid: 2729855].
113 Lee H P, Gourley L, Duffy S W, Esteve J, Lee J, Day N E. Risk factors for breast cancer by age and menopausal status: a case-control study in Singapore. Cancer Causes Control. 1992;3(4):313-22. [pmid: 1617118].
114 Lee H P, Gourley L, Duffy S W, Esteve J, Lee J, Day N E. Dietary effects on breast-cancer risk in Singapore. Lancet-British-Edition. 1991;337(8751):1197-200. 20 ref.
115 Lee J K, Park B J, Yoo K Y, Ahn Y O. Dietary factors and stomach cancer: a case-control study in Korea. International Journal of Epidemiology. 1995;24(1):33-41. [pmid: 7797354].
116 Lee M M, Wang R T, Hsing A W, Gu F L, Wang T, Spitz M. Case-control study of diet and prostate cancer in China. [comment]. Cancer Causes & Control. 1998;9(6):545-52. [pmid: 10189039].
117 Lee S A, Kang D, Shim K N, Choe J W, Hong W S, Choi H. Effect of diet and Helicobacter pylori infection to the risk of early gastric cancer. Journal of Epidemiology. 2003;13(3):162-8. [pmid: 12749604].
118 Levi F, Pasche C, Vecchia C la et al. Food groups and risk of oral and pharyngeal cancer. International-Journal-of-Cancer 1998; 77(5):705–9; 27 ref.
119 Lissner L, Kroon U B, Bjorntorp P, Blosk S, Wilhelmsen L, Silverstolpe G. Adipose tissue fatty acids and dietary fat sources in relation to endometrial cancer: a retrospective study of cases in remission, and population-based controls. Acta-Obstetricia-Et-Gynecologica-Scandinavica. 1993;72(6):481-7. 31 ref. [pmid: 8394629].
120 Littman A J, Beresford S A A, White E. The association of dietary fat and plant foods with endometrial cancer (United States). Cancer-Causes-and-Control. 2001;12(8):691-702. [pmid: 11562109].
121 London S J, Sacks F M, Stampfer M J, et al. Fatty acid composition of the subcutaneous adipose tissue and risk of proliferative benign breast disease and breast cancer. [comment]. Journal of the National Cancer Institute. 1993;85(10):785-93. [pmid: 8487323].
122 Louw L, Engelbrecht A M, Cloete F. Comparison of the fatty acid compositions in intraepithelial and infiltrating lesions of the cervix: part III, saturated and unsaturated fatty acid profiles. Prostaglandins Leukotrienes & Essential Fatty Acids. 1998;59(4):259-64.
123 Lu L J, Anderson K E, Grady J J, Kohen F, Nagamani M. Decreased ovarian hormones during a soya diet: implications for breast cancer prevention. Cancer Research. 2000;60(15):4112-21. [pmid: 10945618].
124 Lu L J, Anderson K E, Grady J J, Nagamani M. Effects of an isoflavone-free soy diet on ovarian hormones in premenopausal women. Journal of Clinical Endocrinology & Metabolism. 2001;86(7):3045-52. [pmid: 11443166].
125 Lu Q, Yao S, Huang C, et al. [A cohort study on the relationship between vegetable intake and risks of lung cancer in the Tin Corporation (YTC) miners in Yunnan]. Chung-Hua Liu Hsing Ping Hsueh Tsa Chih Chinese Journal of Epidemiology. 2000;21(3):205-7.
126 Mack W J, Preston-Martin S, Bernstein L, Qian D. Lifestyle and other risk factors for thyroid cancer in Los Angeles County females. Annals of Epidemiology. 2002;12(6):395-401. [pmid: 12160598].
127 Maillard V, Bougnoux P, Ferrari P, et al. n-3 and n-6 Fatty acids in breast adipose tissue and relative risk of breast cancer in a case-control study in Tours, France. International-Journal-of-Cancer. 2002;98(1):78-83. 50 ref.
128 Malik I A, Sharif S, Malik F, Hakimali A, Khan W A, Badruddin S H. Nutritional aspects of mammary carcinogenesis: a case-control study. JPMA - Journal of the Pakistan Medical Association. 1993;43(6):118-20.
129 Mannisto S, Pietinen P, Virtanen M, Kataja V, Uusitupa M. Diet and the risk of breast cancer in a case-control study: does the threat of disease have an influence on recall bias?. Journal of Clinical Epidemiology. 1999;52(5):429-39. [pmid: 10360338].
130 Markaki I, Linos D, Linos A. The influence of dietary patterns on the development of thyroid cancer. European Journal of Cancer. 2003;39(13):1912-9. [pmid: 12932671].
131 Martin D D, Robbins M E, Spector A A, Wen B C, Hussey D H. The fatty acid composition of human gliomas differs from that found in nonmalignant brain tissue. Lipids. 1996;31(12):1283-8. [pmid: 8972462].
132 Martin-Moreno J M, Willett W C, Gorgojo L, et al. Dietary fat, olive oil intake and breast cancer risk. International Journal of Cancer. 1994;58(6):774-80.
133 Matsuo K, Hamajima N, Hirose K, et al. Alcohol, smoking, and dietary status and susceptibility to malignant lymphoma in Japan: results of a hospital-based case-control study at Aichi Cancer Center. Japanese-Journal-of-Cancer-Research. 2001;92(10):1011-7. [pmid: 11676850].
134 McClinton S, Moffat L E F, Horrobin D F, Manku M S. Abnormalities of essential fatty acid distribution in the plasma phospholipids of patients with bladder cancer. British Journal of Cancer. 1991;63(2):314-6. [pmid: 1997113].
135 Memon A, Varghese A, Suresh A. Benign thyroid disease and dietary factors in thyroid cancer: a case-control study in Kuwait. British-Journal-of-Cancer. 2002;86(11):1745-50. 29 ref. [pmid: 12087461].
136 Meyer F, Bairati I, Fradet Y, Moore L. Dietary energy and nutrients in relation to preclinical prostate cancer. Nutrition & Cancer. 1997;29(2):120-6. [pmid: 9427974].
137 Mishina T, Watanabe H, Araki H, Nakao M. Epidemiological study of prostatic cancer by matched-pair analysis. Prostate. 1985;6(4):423-36. [pmid: 4088954].
138 Mohr D L, Blot W J, Tousey P M, Van Doren M L, Wolfe K W. Southern cooking and lung cancer. Nutrition & Cancer. 1999;35(1):34-43. [pmid: 10624704].
139 Mori M, Harabuchi I, Miyake H, Casagrande J T, Henderson B E, Ross R K. Reproductive, genetic, and dietary risk factors for ovarian cancer. American Journal of Epidemiology. 1988;128(4):771-7. [pmid: 3421242].
140 Munoz N, Plummer M, Vivas J, et al. A case-control study of gastric cancer in Venezuela. International-Journal-of-Cancer. 2001;93(3):417-23. 33 ref.
141 Nakachi K, Imai K, Hoshiyama Y, Sasaba T. The joint effects of two factors in the aetiology of oesophageal cancer in Japan. Journal of Epidemiology & Community Health. 1988;42(4):355-64. [pmid: 3256578].
142 Navarro A, Diaz M P, Munoz S E, Lantieri M J, Eynard A R. Characterization of meat consumption and risk of colorectal cancer in Cordoba, Argentina. Nutrition. 2003;19(1):7-10. 32 ref. [pmid: 12507631].
143 Neoptolemos J P, Husband D, Imray C, Rowley S, Lawson N. Arachidonic acid and docosahexaenoic acid are increased in human colorectal cancer. Gut. 1991;32(3):278-81. [pmid: 1826490]. [pmcid: 1378834].
144 Neugut A I, Garbowski G C, Won Chul Lee, et al. Dietary risk factors for the incidence and recurrence of colorectal adenomatous polyps: A case-control study. Annals of Internal Medicine. 1992;118(2):91-5. [pmid: 8416323].
145 Newcomer L M, King I B, Wicklund K G, Stanford J L. The association of fatty acids with prostate cancer risk. Prostate. 2001;47(4):262-8. [pmid: 11398173].
146 Nkondjock A, Shatenstein B, Maisonneuve P, Ghadirian P. Assessment of risk associated with specific fatty acids and colorectal cancer among French-Canadians in Montreal: A case-control study. International Journal of Epidemiology. 2003;32(2):200-9. [pmid: 12714537].
147 Norrish A E, Jackson R T, Sharpe S J, Skeaff C M. Men who consume vegetable oils rich in monounsaturated fat: their dietary patterns and risk of prostate cancer (New Zealand). Cancer Causes & Control. 2000;11(7):609-15. [pmid: 10977105].
148 Norrish A E, Skeaff C M, Arribas G L, Sharpe S J, Jackson R T. Prostate cancer risk and consumption of fish oils: a dietary biomarker-based case-control study. British Journal of Cancer. 1999;81(7):1238-42. [pmid: 10584888].
149 Nyberg F, Agrenius V, Svartengren K, Svensson C, Pershagen G. Dietary factors and risk of lung cancer in never-smokers. International-Journal-of-Cancer. 1998;78(4):430-6. 29 ref.
150 Oreggia F, Stefani E, Boffetta P, et al. Meat, fat and risk of laryngeal cancer: a case-control study in Uruguay. Oral-Oncology. 2001;37(2):141-5. 22 ref. [pmid: 11167140].
151 Palli D, Russo A, Decarli A. Dietary patterns, nutrient intake and gastric cancer in a high-risk area of Italy. Cancer-Causes-and-Control. 2001;12(2):163-72. 35 ref. [pmid: 11246845].
152 Pandey M, Khatri A K, Dubey S S, Gautam A, Shukla V K. Erythrocyte membrane fatty acid profile in patients with primary carcinoma of the gallbladder. Journal of Surgical Oncology. 1995;59(1):31-4. [pmid: 7745974].
153 Pawlega J, Rachtan J, Dyba T. Diet, alcohol, tobacco and prostate cancer. Zywienie-Czlowieka-i-Metabolizm. 1993;20(1):16-22. 24 ref.
154 Pawlega J, Rachtan J, Dyba T. Dietary factors and risk of prostate cancer in Poland. Results of case-control study. Neoplasma. 1996;43(1):61-3. 22 ref. [pmid: 8843963].
155 Petrek J A, Hudgins L C, Ho M, Bajorunas D R, Hirsch J. Fatty acid composition of adipose tissue, an indication of dietary fatty acids, and breast cancer prognosis. Journal of Clinical Oncology. 1997;15(4):1377-84. [pmid: 9193329].
156 Petridou E, Kedikoglou S, Koukoulomatis P, Dessypris N, Trichopoulos D. Diet in relation to endometrial cancer risk: a case-control study in Greece. Nutrition-and-Cancer. 2002;44(1):16-22. [pmid: 12672637].
157 Petridou E, Zavras A I, Lefatzis D, et al. The role of diet and specific micronutrients in the etiology of oral carcinoma. Cancer. 2002;94(11):2981-8. [pmid: 12115387].
158 Pierce R J, Kune G A, Kune S, et al. Dietary and alcohol intake, smoking pattern, occupational risk, and family history in lung cancer patients: results of a case-control study in males. Nutrition & Cancer. 1989;12(3):237-48. [pmid: 2771801].
159 Ping Y, Ogushi Y, Okada Y, Haruki Y, Okazaki I, Ogawa T. Lifestyle and colorectal cancer: A case-control study. Environmental Health & Preventive Medicine. 1998;3(3):146-51.
160 Potischman N, Weiss H A, Swanson C A, et al. Diet during adolescence and risk of breast cancer among young women. Journal of the National Cancer Institute. 1998;90(3):226-33. [pmid: 9462680].
161 Prisco D, Paniccia R, Coppo M, et al. Platelet activation and platelet lipid composition in pulmonary cancer. Prostaglandins Leukotrienes & Essential Fatty Acids. 1995;53(1):65-8.
162 Purasiri P, Ashby J, Heys S D, Eremin O. Effect of essential fatty acids on circulating T cell subsets in patients with colorectal cancer. Cancer Immunology & Immunotherapy. 1994;39(4):217-22. [pmid: 7954523].
163 Purasiri P, Ashby J, Heys S D, Eremin O. Effect of essential fatty acids on natural cytotoxicity in patients with colorectal cancer. European Journal of Surgical Oncology. 1995;21(3):254-60. [pmid: 7781792].
164 Purasiri P, Murray A, Richardson S, Heys S D, Horrobin D, Eremin O. Modulation of cytokine production in vivo by dietary essential fatty acids in patients with colorectal cancer. Clinical Science. 1994;87(6):711-7. [pmid: 7874864].
165 Quevedo Coli S, Crespi C, Benito E, Palou A, Roca P. Alterations in circulating fatty acids and the compartmentation of selected metabolites in women with breast cancer. Biochemistry-and-Molecular-Biology-International. 1997;41(1):1-10. 26 ref. [pmid: 9043629].
166 Rajkumar T, Sridhar H, Balaram P, et al. Oral cancer in Southern India: the influence of body size, diet, infections and sexual practices. European-Journal-of-Cancer-Prevention. 2003;12(2):135-43. 34 ref. [pmid: 12671537].
167 Ramon J M, Bou R, Romea S, et al. Dietary fat intake and prostate cancer risk: a case-control study in Spain. [comment]. Cancer Causes & Control. 2000;11(8):679-85. [pmid: 11065004].
168 Rao D N, Balasubramaniam Ganesh, Dinshaw K A, Mohandas K M, Ganesh B. A case-control study of stomach cancer in Mumbai, India. International-Journal-of-Cancer. 2002;99(5):727-31. 38 ref.
169 Riboli E, Gonzalez C A, Lopez-Abente G, et al. Diet and bladder cancer in Spain: a multi-centre case-control study. International Journal of Cancer. 1991;49(2):214-9.
170 Richardson S, Gerber M, Hill MJ (ed.), Giacosa A (ed.), Caygill CPJ. Nutritional factors and breast cancer in a French Mediterranean region. Epidemiology-of-Diet-and-Cancer. 1994, 353–377; 55 Ref.
171 Risch H A, Jain M, Choi N W, et al. Dietary factors and the incidence of cancer of the stomach. American Journal of Epidemiology. 1985;122(6):947-59. [pmid: 2998182].
172 Ronco AL, Stefani E de, Fabra A, de Stefani E. White meat intake and the risk of breast cancer: a case-control study in Montevideo, Uruguay. Nutrition-Research 2003; 23(2): 151–62; 55 ref.
173 Rosenblatt K A, Thomas D B, Jimenez L M, et al. The relationship between diet and breast cancer in men (United States). Cancer Causes & Control. 1999;10(2):107-13. [pmid: 10231158].
174 Saadatian-Elahi M, Toniolo P, Ferrari P, et al. Serum fatty acids and risk of breast cancer in a nested case-control study of the New York University Women's Health Study. IARC Scientific Publications. 2002;156:227-30. [pmid: 12484174].
175 Saadatian-Elahi MTPFPGJAAZ-JARE. Serum fatty acids and risk of breast cancer in a nested case-control study of the New York University Women's Health Study. Cancer Epidemiology, Biomarkers & Prevention. 11(11):1353–60, 2002 Nov.
176 Sakai K, Okuyama H, Yura J, et al. Composition and turnover of phospholipids and neutral lipids in human breast cancer and reference tissues. Carcinogenesis. 1992;13(4):579-84. [pmid: 1576710].
177 Sala E, Warren R, Duffy S, Welch A, Luben R, Day N. High risk mammographic parenchymal patterns and diet: a case-control study. British Journal of Cancer. 2000;83(1):121-6. [pmid: 10883679].
178 Schloss I, Kidd M S G, Tichelaar H Y, Young G O, O'Keefe S J D. Dietary factors associated with a low risk of colon cancer in coloured West Coast fishermen. South African Medical Journal. 1997;87(2):152-8. [pmid: 9107220].
179 Shu X O, Jin F, Dai Q, et al. Soyfood intake during adolescence and subsequent risk of breast cancer among Chinese women. Cancer. 2001;10(5):483-8.
180 Shu X O, Zheng W, Potischman N, et al. A population-based case-control study of dietary factors and endometrial cancer in Shanghai, People's Republic of China. American-Journal-of-Epidemiology. 1993;137(2):155-65. 32 ref. [pmid: 8452119].
181 Simard A, Vobecky J, Vobecky J S. Nutrition and lifestyle factors in fibrocystic disease and cancer of the breast. Cancer-Detection-and-Prevention. 1990;14(5):567-72. 14 ref. [pmid: 2224921].
182 Simon J A, Fong J, Bernert J T Jr, Browner W S. USA Multiple Risk Factor Intervention Trial Study Group. Serum fatty acids and the risk of fatal cancer. American-Journal-of-Epidemiology. 1998;148(9):854-8. 18 ref. [pmid: 9801015].
183 Simonsen N, van't Veer P, Strain J J, et al. Adipose tissue omega-3 and omega-6 fatty acid content and breast cancer in the EURAMIC study. European Community Multicenter Study on Antioxidants, Myocardial Infarction, and Breast Cancer. Am J Epidemiol. 1998;147(4):342-52. [pmid: 9508101].
184 Skorepa J, Sindelkova E, Zadak Z. [Essential fatty acids in carcinoma]. [Czech]. Vnitrni Lekarstvi. 1991;37(1):37-40. [pmid: 2058095].
185 Slattery M L, Potter J D, Duncan D M, Berry T D. Dietary fats and colon cancer: assessment of risk associated with specific fatty acids. International Journal of Cancer. 1997;73(5):670-7.
186 Slattery M L, Schumacher M C, West D W, Robison L M, French T K. Food-consumption trends between adolescent and adult years and subsequent risk of prostate cancer. American-Journal-of-Clinical-Nutrition. 1990;52(4):752-7. 15 ref. [pmid: 2403069].
187 Soler M, Chatenoud L, Vecchia C la, Franceschi S, Negri E, la Vecchia C. Diet, alcohol, coffee and pancreatic cancer: final results from an Italian study. European-Journal-of-Cancer-Prevention. 1998;7(6):455-60. 41 ref. [pmid: 9926293].
188 Sotnikova E N, Drakina L V, Isaev V A, et al. Role of nutrition in the prevention and correction of precancerous conditions in groups at risk. Voprosy-Pitaniya. 1993;4:41-44. 5 Ref.
189 Sriamporn S, Vatanasapt V, Pisani P, Yongchaiyudha S, Rungpitarangsri V. Environmental risk factors for nasopharyngeal carcinoma: a case-control study in northeastern Thailand. Cancer Epidemiology, Biomarkers & Prevention. 1992;1(5):345-8.
190 Takezaki T, Hirose K, Inoue M, et al. Dietary factors and lung cancer risk in Japanese: with special reference to fish consumption and adenocarcinomas. British Journal of Cancer. 2001;84(9):1199-206. [pmid: 11336471].
191 Tashiro T, Yamamori H, Takagi K, Hayashi N, Furukawa K, Nakajima N. n-3 versus n-6 polyunsaturated fatty acids in critical illness. Nutrition. 1998;14(6):551-3. [pmid: 9646301].
192 Tavani A, Pelucchi C, Parpinel M, et al. n-3 polyunsaturated fatty acid intake and cancer risk in Italy and Switzerland. International Journal of Cancer. 2003;105(1):113-6.
193 Terry P, Rohan T E, Wolk A, Maehle-Schmidt M, Magnusson C. Fish consumption and breast cancer risk. Nutrition & Cancer. 2002;44(1):1-6. [pmid: 12672635].
194 Terry P, Wolk A, Vainio H, Weiderpass E. Fatty fish consumption lowers the risk of endometrial cancer: a nationwide case-control study in Sweden. Cancer Epidemiology, Biomarkers & Prevention. 2002;11(1):143-5.
195 Tolkacheva N V, Kulakova S N, Lysenko I N, Akhmed B A, Stogova E V. [Changes in the fatty acid composition of serum albumin in patients with lung and breast neoplasms]. [Russian]. Voprosy Meditsinskoi Khimii. 1997;43(4):261-6. [pmid: 9312942].
196 Toniolo P, Riboli E, Protta F, Charrel M, Cappa A P M. Calorie-providing nutrients and risk of breast cancer. Journal of the National Cancer Institute. 1989;Vol 81(4):(Pp 278-286). [pmid: 2913325].
197 Toniolo P, Riboli E, Shore R E, Pasternack B S. Consumption of meat, animal products, protein, and fat and risk of breast cancer: a prospective cohort study in New York. [comment]. Epidemiology. 1994;5(4):391-7. [pmid: 7918807].
198 Trichopoulou A, Katsouyanni K, Stuver S, et al. Consumption of olive oil and specific food groups in relation to breast cancer risk in Greece. [comment]. Journal of the National Cancer Institute. 1995;87(2):110-6. [pmid: 7503842].
199 Tuyns A J, Kaaks R, Haelterman M. Colorectal cancer and the consumption of foods: a case-control study in Belgium. Nutrition & Cancer. 1988;11(3):189-204. [pmid: 3405870].
200 Tzonou A, Lipworth L, Garidou A, et al. Diet and risk of esophageal cancer by histologic type in a low-risk population. International-Journal-of-Cancer. 1996;68(3):300-4. 26 ref.
201 Tzonou A, Lipworth L, Kalandidi A, et al. Dietary factors and the risk of endometrial cancer: a case-control study in Greece. British-Journal-of-Cancer. 1996;73(10):1284-90. 32 ref. [pmid: 8630294].
202 Tzonou A, Signorello L B, Lagiou P, Wuu J, Trichopoulos D, Trichopoulou A. Diet and cancer of the prostate: a case-control study in Greece. International Journal of Cancer. 1999;80(5):704-8.
203 Vatten L J, Bjerve K S, Andersen A, Jellum E. Polyunsaturated fatty acids in serum phospholipids and risk of breast cancer: a case-control study from the Janus serum bank in Norway. European Journal of Cancer. 1993;29A(4):532-8. [pmid: 8435206].
204 Wakai K, Ohno Y, Genka K, et al. Risk modification in lung cancer by a dietary intake of preserved foods and soyfoods: findings from a case-control study in Okinawa, Japan. Lung Cancer. 1999;25(3):147-59. [pmid: 10512125].
205 Wang Y P, Han X Y, Su W, et al. Esophageal cancer in Shanxi Province, People's Republic of China: a case-control study in high and moderate risk areas. Cancer Causes & Control. 1992;3(2):107-13. [pmid: 1562700].
206 Ward M H, Pan WenHarn, Cheng YuJuen, et al. Dietary exposure to nitrite and nitrosamines and risk of nasopharyngeal carcinoma in Taiwan. International-Journal-of-Cancer. 2000;86(5):603-9. 37 ref.
207 Winn D M, Ziegler R G, Pickle L W, et al. Diet in the etiology of oral and pharyngeal cancer among women from the southern United States. Cancer Research. 1984;44(3):1216-22. [pmid: 6692405].
208 Wirfalt E, Mattisson I, Gullberg B, Johansson U, Olsson H, Berglund G. Postmenopausal breast cancer is associated with high intakes of omega6 fatty acids (Sweden). Cancer-Causes-and-Control. 2002;13(10):883-93. [pmid: 12588084].
209 Witte J S, Longnecker M P, Bird C L, Lee E R, Frankl H D, Haile R W. Relation of vegetable, fruit, and grain consumption to colorectal adenomatous polyps. [comment]. American Journal of Epidemiology. 1996;144(11):1015-25. [pmid: 8942431].
210 Wu A H, Ziegler R G, Horn-Ross P L, et al. Tofu and risk of breast cancer in Asian-Americans. Cancer Epidemiol Biomarkers Prev. 1996;5(11):901-6. [pmid: 8922298].
211 Wu A H, Yu M C, Mack T M. Smoking, alcohol use, dietary factors and risk of small intestinal adenocarcinoma. International-Journal-of-Cancer. 1997;70(5):512-7. 26 ref.
212 Yang C X, Takezaki T, Hirose K, Inoue M, Huang X E, Tajima K. Fish consumption and colorectal cancer: a case-reference study in Japan. European Journal of Cancer Prevention. 2003;12(2):109-15. [pmid: 12671534].
213 Yang Y J, Lee S H, Hong S J, Chung B C. Comparison of fatty acid profiles in the serum of patients with prostate cancer and benign prostatic hyperplasia. Clinical Biochemistry. 1999;32(6):405-9. [pmid: 10667474].
214 Ye W, Yi Y, Luo R. A case-control study on diet and gastric cancer. [Chinese]. Chung-Hua Yu Fang i Hsueh Tsa Chih [Chinese Journal of Preventive Medicine]. 1998;32(2):100-2.
215 Yoon Jung Y, Seon Hwa Lee, Sung Joon H, Bong Chul C. Comparison of fatty acid profiles in the serum of patients with prostate cancer and benign prostatic hyperplasia. Clinical Biochemistry. 1999;32(6):405-9. [pmid: 10667474].
216 Yuan J M, Wang Q S, Ross R K, Henderson B E, Yu M C. Diet and breast cancer in Shanghai and Tianjin, China. British-Journal-of-Cancer. 1995;71(6):1353-8. 18 ref. [pmid: 7779738].
217 Zhang Z F, Kurtz R C, Yu G P, et al. Adenocarcinomas of the esophagus and gastric cardia: The role of diet. Nutrition & Cancer. 1997;27(3):298-309. [pmid: 9101561].
218 Zhao Y, Shi Z, Liu L. Matched case-control study for detecting risk factors of breast cancer in women living in Chengdu. [Chinese]. Chung-Hua Liu Hsing Ping Hsueh Tsa Chih Chinese Journal of Epidemiology. 1999;20(2):91-4.
219 Zheng W, Blot W J, Shu X O, et al. Risk factors for oral and pharyngeal cancer in Shanghai, with emphasis on diet. Cancer-Epidemiology,-Biomarkers-and-Prevention. 1992;1(6):441.
220 Zheng W, Blot W J, Shu X O, et al. Diet and other risk factors for laryngeal cancer in Shanghai, China. American-Journal-of-Epidemiology. 1992;136(2):178-91. 45 ref. [pmid: 1415140].
221 Zhu Z R, Agren J, Mannisto S, et al. Fatty acid composition of breast adipose tissue in breast cancer patients and in patients with benign breast disease. Nutrition & Cancer. 1995;24(2):151-60. [pmid: 8584451].
222 Ziegler R G, Morris L E, Blot W J, Pottern L M, Hoover R, Fraumeni J F J. Esophageal cancer among black men in Washington, D.C. II. Role of nutrition. Journal of the National Cancer Institute. 1981;67(6):1199-206. [pmid: 6947105].
223 Zou J, Sun Q, Akiba S, et al. A case-control study of nasopharyngeal carcinoma in the high background radiation areas of Yangjiang, China. Journal of Radiation Research. 2000;41(Suppl):53-62. Oct. [pmid: 11142212].
224 Zuijdgeest van Leeuwen SD, Heijden MS van der, Rietveld T et al. Fatty acid composition of plasma lipids on patients with pancreatic, lung and oesophageal cancer in comparison with healthy subjects. Clinical-Nutrition 2002; 21(3):225–30; 34 ref.

### Rejected No Outcomes of Interest and/or Not Able to Compare Omega-3 Effect Across Study Arms (n = 41)

1 Anti M, Armelao F, Marra G, et al. Effects of different doses of fish oil on rectal cell proliferation in patients with sporadic colonic adenomas. Gastroenterology. 1994;107(6):1709-18. 50 ref. [pmid: 7958682].
2 Anti M, Marra G, Armelao F, et al. Effect of omega-3 fatty acids on rectal mucosal cell proliferation in subjects at risk for colon cancer. [comment]. Gastroenterology. 1992;103(3):883-91. [pmid: 1386825].
3 Anti M, Marra G, Armelao F, Percesepe A, Gentinoli N. Modulating effect of omega-3 fatty acids on the proliferative pattern of human colorectal mucosa. Advances in Experimental Medicine & Biology. 1997;Vol 400 B:(Pp 605-610).
4 Bartoli G M, Palozza P, Marra G, et al. n-3 PUFA and alpha-tocopherol control of tumor cell proliferation. Molecular Aspects of Medicine. 1993;14(3):247-52. [pmid: 8264339].
5 Bartram H P, Gostner A, Kelber E, Dusel G, Scheppach W, Kasper H. Effect of dietary fish oil on fecal bile acid and neutral sterol excretion in healthy volunteers. Zeitschrift Fur Ernahrungswissenschaft. 1998;37(Suppl 1):139-41. [pmid: 9558749].
6 Bartram H P, Gostner A, Kelber E, et al. Effects of fish oil on fecal bacterial enzymes and steroid excretion in healthy volunteers: implications for colon cancer prevention. Nutrition & Cancer. 1996;25(1):71-8. [pmid: 8837863].
7 Bartram H P, Gostner A, Reddy B S, et al. Missing anti-proliferative effect of fish oil on rectal epithelium in healthy volunteers consuming a high-fat diet: potential role of the n-3:n-6 fatty acid ratio. European Journal of Cancer Prevention. 1995;4(3):231-7. [pmid: 7647691].
8 Bartram H P, Gostner A, Scheppach W, et al. Effects of fish oil on rectal cell proliferation, mucosal fatty acids, and prostaglandin E2 release in healthy subjects. Gastroenterology. 1993;105(5):1317-22. [pmid: 8224635].
9 Brown B D, Thomas W, Hutchins A, Martini M C, Slavin J L. Types of dietary fat and soy minimally affect hormones and biomarkers associated with breast cancer risk in premenopausal women. Nutrition & Cancer. 2002;43(1):22-30. [pmid: 12467131].
10 Bruera E, Strasser F, Palmer J L, et al. Effect of fish oil on appetite and other symptoms in patients with advanced cancer and anorexia/cachexia: a double-blind, placebo-controlled study. [comment]. Journal of Clinical Oncology. 2003;21(1):129-34. [pmid: 12506181].
11 Bye A, Ose T, Kaasa S. Food choice and nutrient intake among patients on a low-fat, low-lactose diet: Experience from a prospective randomized study. Journal of Human Nutrition & Dietetics. 1999;12(4):273-85.
12 Bye A, Ose T, Kaasa S. Quality of life during pelvic radiotherapy. Acta Obstetricia Et Gynecologica Scandinavica. 1995;74(2):147-52. [pmid: 7900512].
13 Cheng J, Ogawa K, Kuriki K, et al. Increased intake of n-3 polyunsaturated fatty acids elevates the level of apoptosis in the normal sigmoid colon of patients polypectomized for adenomas/tumors. Cancer Letters. 2003;193(1):17-24. [pmid: 12691819].
14 Fearon KCHvMMMAvGRRAGDGAvGATM. An energy and protein dense, high n-3 fatty acid oral supplement promotes weight gain in cancer cachexia. European Journal of Cancer. 37(Suppl 6):27 Abs. 90, 2001.
15 Fidanza F. Food patterns and health problems: Conclusions of the chairman. Ann Nutr Metab. 1991;35(supp 1):78-80. [pmid: 1888131].
16 Furukawa K, Tashiro T, Yamamori H, et al. Effects of soybean oil emulsion and eicosapentaenoic acid on stress response and immune function after a severely stressful operation. Annals of Surgery. 1999;229(2):255-61. [pmid: 10024108]. [pmcid: 1191639].
17 Gee J M, Watson M, Matthew J A, et al. Consumption of fish oil leads to prompt incorporation of eicosapentaenoic acid into colonic mucosa of patients prior to surgery for colorectal cancer, but has no detectable effect on epithelial cytokinetics. Journal of Nutrition. 1999;129(10):1862-5. [pmid: 10498759].
18 Gianotti L, Braga M, Nespoli L, Radaelli G, Beneduce A, Di Carlo V. A randomized controlled trial of preoperative oral supplementation with a specialized diet in patients with gastrointestinal cancer. Gastroenterology. 2002;122(7):1763-70. [pmid: 12055582].
19 Gogos C A, Ginopoulos P, Salsa B, Apostolidou E, Zoumbos N C, Kalfarentzos F. Dietary omega-3 polyunsaturated fatty acids plus vitamin E restore immunodeficiency and prolong survival for severely ill patients with generalized malignancy: a randomized control trial. Cancer. 1998;82(2):395-402. [pmid: 9445198].
20 Heslin M J, Latkany L, Leung D, et al. A prospective, randomized trial of early enteral feeding after resection of upper gastrointestinal malignancy. Annals of Surgery. 1997;226(4):567-80. [pmid: 9351723]. [pmcid: 1191079].
21 Hirayama T. Relationship of soybean paste soup intake to gastric cancer risk. Nutrition & Cancer. 1982;3(4):223-33. [pmid: 6890671].
22 Holm L E, Nordevang E, Ikkala E, Hallstrom L, Callmer E. Dietary intervention as adjuvant therapy in breast cancer patients--a feasibility study. Breast Cancer Research & Treatment. 1990;16(2):103-9. [pmid: 2265258].
23 Homann HHKMSMBANHaZV. Influence of arginine, RNA and omega-3-fatty acid supplemented enteral nutrition on postoperative humoral immunity in cancer patients undergoing major upper gastrointestinal surgery [abstract]. Clinical Nutrition. Vol.11 Spec Suppl, Pp.30–1, 1992.
24 Huang Y C, Jessup J M, Forse R A, et al. n-3 fatty acids decrease colonic epithelial cell proliferation in high-risk bowel mucosa. Lipids. 1996;31(Suppl):S313-7. Mar. [pmid: 8729142].
25 Jatoi A, Rowland K, Loprinzi C L, et al. An eicosapentaenoic acid supplement versus megestrol acetate versus both for patients with cancer-associated wasting: a North Central Cancer Treatment Group and National Cancer Institute of Canada collaborative effort. J Clin Oncol. 2004;22(12):2469-76. [pmid: 15197210].
26 Jenkins D J, Kendall C W, Vidgen E, et al. Health aspects of partially defatted flaxseed, including effects on serum lipids, oxidative measures, and ex vivo androgen and progestin activity: a controlled crossover trial. American Journal of Clinical Nutrition. 1999;69(3):395-402. [pmid: 10075322].
27 Kemen M, Senkal M, Homann H H, et al. Early postoperative enteral nutrition with arginine-omega-3 fatty acids and ribonucleic acid-supplemented diet versus placebo in cancer patients: an immunologic evaluation of Impact. Critical Care Medicine. 1995;23(4):652-9. [pmid: 7536138].
28 Leitzmann M F, Stampfer M J, Michaud D S, et al. Dietary intake of n-3 and n-6 fatty acids and the risk of prostate cancer. Am J Clin Nutr. 2004;80(1):204-16. [pmid: 15213050].
29 McMichael-Phillips D, Harding C, Morton M, et al. Effects of soy-protein supplementation on epithelial proliferation in the histologically normal human breast. Am J Clin Nutr. 1998;68(supp):1431S-6S. [pmid: 9848512].
30 Moses A W, Slater C, Preston T, Barber M D, Fearon K C. Reduced total energy expenditure and physical activity in cachectic patients with pancreatic cancer can be modulated by an energy and protein dense oral supplement enriched with n-3 fatty acids. Br J Cancer. 2004;90(5):996-1002. [pmid: 14997196].
31 Nagata C, Takatsuka N, Shimizu H. Soy and fish oil intake and mortality in a Japanese community. American Journal of Epidemiology. 2002;156(9):824-31. [pmid: 12397000].
32 Neumann HAKMaBJ. Influence of an Arginine, RNA and omega-3 fatty acids supplemented enteral diet on postoperative immune parameters in tumor patients. Onkologie. 16(Suppl 1):16–7, 1993.
33 Nordevang E, Ikkala E, Callmer E, Hallstrom L, Holm L E. Dietary intervention in breast cancer patients: effects on dietary habits and nutrient intake. European Journal of Clinical Nutrition. 1990;44(9):681-7. [pmid: 2261900].
34 Orengo I F, Black H S, Wolf J E J. Influence of fish oil supplementation on the minimal erythema dose in humans. Arch. 1992;284(4):219-21.
35 Pratt V C, Watanabe S, Bruera E, et al. Plasma and neutrophil fatty acid composition in advanced cancer patients and response to fish oil supplementation. British Journal of Cancer. 2002;87(12):1370-8. [pmid: 12454764].
36 Rhodes L E, Shahbakhti H, Azurdia R M, et al. Effect of eicosapentaenoic acid, an omega-3 polyunsaturated fatty acid, on UVR-related cancer risk in humans. An assessment of early genotoxic markers. Carcinogenesis. 2003;24(5):919-25. [pmid: 12771037].
37 Schauder P, Rohn U, Schafer G, Korff G, Schenk H D. Impact of fish oil enriched total parenteral nutrition on DNA synthesis, cytokine release and receptor expression by lymphocytes in the postoperative period. British Journal of Nutrition. 2002;87(Suppl 1):S103-10. Jan. [pmid: 11895146].
38 Schuurman A G, van den Brandt P A, Dorant E, Brants H A, Goldbohm R A. Association of energy and fat intake with prostate carcinoma risk: results from The Netherlands Cohort Study. Cancer. 1999;86(6):1019-27. [pmid: 10491529].
39 Senkal M, Kemen M, Homann H H, Eickhoff U, Baier J, Zumtobel V. Modulation of postoperative immune response by enteral nutrition with a diet enriched with arginine, RNA, and omega-3 fatty acids in patients with upper gastrointestinal cancer. European Journal of Surgery. 1995;161(2):115-22. [pmid: 7539633].
40 Wu G H, Zhang Y W, Wu Z H. Modulation of postoperative immune and inflammatory response by immune-enhancing enteral diet in gastrointestinal cancer patients. World Journal of Gastroenterology. 2001;7(3):357-62. [pmid: 11819790].
41 Zuijdgeest-Van Leeuwen S D, Dagnelie P C, Wattimena J L, et al. Eicosapentaenoic acid ethyl ester supplementation in cachectic cancer patients and healthy subjects: effects on lipolysis and lipid oxidation. Clinical Nutrition. 2000;19(6):417-23. [pmid: 11104593].

### Listing of Excluded Studies: Tumor Behavior

### Rejected Not Omega-3 Fatty Acids (n = 7)

1 Adlercruetz H. Phytoestrogens: Epidemiology and a possible role in cancer protection. SO - Environmental Health Perspectives. 1995;103(SUPPL. 7):103-112.
2 Carroll K K, Khor H T. Dietary fat in relation to tumorigenesis. Prog Biochem Pharmacol. 1975;10:308-53. [pmid: 165553].
3 Eynard A R. Is the risk of urinary tract tumorigenesis enhanced by a marginal chronic essential fatty acid deficiency (EFAD)?. Nutrition. 1998;14(2):211-6. [pmid: 9530649].
4 Fournier D B, Erdman John W Jr, Gordon G B. Soy, its components, and cancer prevention: A review of the in vitro, animal, and human data. SO - Cancer Epidemiology, Biomarkers & Prevention. Nov. 1998;7(11):1055-1065.
5 Messina MJ, Persky V, Setchell KDR, Barnes S. Soy intake and cancer risk: A review of the in vitro and in vivo data.
6 Messina M J, Loprinzi C L. Soy for breast cancer survivors: A critical review of the literature. Journal of Nutrition. 2001;131:3095S-108S. [pmid: 11694655].
7 Tang D G, La E, Kern J, Kehrer J P. Fatty acid oxidation and signaling in apoptosis. Biological Chemistry. 2002;383(34):425-42. [pmid: 12033433].

### Rejected Not EFA Supplementation (n = 1)

1 Eynard A R. Does chronic essential fatty acid deficiency constitute a pro-tumorigenic condition?. SO - Medical Hypotheses. 1997;48(1):55-62.

### Rejected Other Mechanisms (n = 2)

1 Carroll K K. Biological effects of fish oils in relation to chronic diseases. Lipids. 1986;21(12):731-2. [pmid: 3821385].
2 Cave W T Jr. Dietary n-3 (omega-3) polyunsaturated fatty acid effects on animal tumorigenesis. FASEB Journal. 1991;5(8):2160-6. [pmid: 1673664].

### Rejected Not a Review (n = 1)

1 Colas S, Paon L, Denis F, et al. Enhanced radiosensitivity of rat autochthonous mammary tumors by dietary docosahexaenoic acid. Int J Cancer. 2004;109(3):449-54. [pmid: 14961586].

### Rejected Not Cancer Development (n = 1)

1 Baronzio G, Freitas I, Griffini P, et al. Omega-3 fatty acids can improve radioresponse modifying tumor interstitial pressure, blood rheology and membrane peroxidizability. SO - Anticancer Research. 1994;14(3A):1145-1154.