# References and Included Studies

1 Jones P, Papamandjaris A. Lipids and cellular metabolism. Present knowledge in nutrition. 8th edition. Vol. Chapter 10. Washington, DC: International Life Sciences Institute, 2003.
2 James M, Gibson R, Cleland L. Dietary polyunsaturated fatty acids and inflammatory mediator production. Am J Clin Nut. 2000;71(1):343S-8S.
3 Fallon and Enig. The Price-Pottenger nutrition foundation. Tripping lightly down the prostaglandin pathways [Web Page]. Available at www.price-pottenger.org/articles/prostaglandin.htm2001.
4 Marcheselli V L, Hong S, Lukiw W J, et al. Novel docosanoids inhibit brain ischemia-reperfusion-mediated leukocyte infiltration and pro-inflammatory gene expression. J Biol Chem. 2003;278(44):43807-17. [pmid: 12923200].
5 Serhan C N, Hong S, Gronert K, et al. Resolvins: a family of bioactive products of omega-3 fatty acid transformation circuits initiated by aspirin treatment that counter proinflammation signals. J Exp Med. 2002;196(8):1025-37. [pmid: 12391014].
6 Hong S, Gronert K, Devchand P R, Moussignac R L, Serhan C N. Novel docosatrienes and 17S-resolvins generated from docosahexaenoic acid in murine brain, human blood, and glial cells. Autacoids in anti-inflammation. J Biol Chem. 2003;278(17):14677-87. [pmid: 12590139].
7 Niu S L, Mitchell D C, Lim S Y, et al. Reduced G protein-coupled signaling efficiency in retinal rod outer segments in response to n-3 fatty acid deficiency. J Biol Chem. 2004;279(30):31098-104. [pmid: 15145938].
8 Simopoulos A. The importance of the ratio of omega-6/omega-3 essential fatty acids. Biomedicine & Pharmacotherapy. 2002;56(8):365-79.
9 Richardson A J. The importance of omega-3 fatty acids for behaviour, cognition and mood. Scandinavian Journal of Nutrition/Naringsforskning. 2003;47(2):92-8.
10 Institute of Medicine (IOM). Dietary Reference Intakes: Energy, Carbohydrates, Fiber, Fat, Fatty Acids, Cholesterol, Protein, and Amino Acids. Washington, DC: National Academy Press, 2002.
11 Schulz K, Chalmers I, Hayes R, et al. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273(5):408-41. [pmid: 7823387].
12 Jadad A, Moore A, Carrol D, et al. Assessing the quality of reports of randomized clinical trials: Is blinding necessary?. Control Clin Trials. 1996;17:1-12. [pmid: 8721797].
13 Moher D, Pham B, Jones A, et al. Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352:609-13. [pmid: 9746022].
14 Khan K, Daya S, Jadad A. The importance of quality of primary studies in producing unbiased systematic reviews. Arch Intern Med. 1996;156:661-6. [pmid: 8629879].
15 Downs S, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. 1998;52:377-84. [pmid: 9764259].
16 Saunders L, Soomro G, Buckingham J, Jamtvedt G, Raina P. Assessing the methodological quality of nonrandomized intervention studies. Western Journal of Nursing Research. 2003;25:223-37. [pmid: 12666645].
17 Prentice R L. Aspects of the science of cancer prevention trials: lessons from the conduct and planning of clinical trials of a low-fat diet intervention among women. Preventive Medicine. 1991;20(1):147-57. [pmid: 2008423].
18 Saxe G A, Rock C L, Wicha M S, Schottenfeld D. Diet and risk for breast cancer recurrence and survival. Breast Cancer Research & Treatment. 1999;53(3):241-53. [pmid: 10369070].
19 Slattery M L, Potter J D, Duncan D M, Berry T D. Dietary fats and colon cancer: assessment of risk associated with specific fatty acids. International Journal of Cancer. 1997;73(5):670-7.
20 Purasiri P, Murray A, Richardson S, Heys S D, Horrobin D, Eremin O. Modulation of cytokine production in vivo by dietary essential fatty acids in patients with colorectal cancer. Clinical Science. 1994;87(6):711-7. [pmid: 7874864].
21 Thomson C A, Flatt S W, Rock C L, Ritenbaugh C, Newman V, Pierce J P. Increased fruit, vegetable and fiber intake and lower fat intake reported among women previously treated for invasive breast cancer. Journal of the American Dietetic Association. 2002;102(6):801-8. [pmid: 12067045].
22 Simon M S, Heilbrun L K, Boomer A, et al. A randomized trial of a low-fat dietary intervention in women at high risk for breast cancer. Nutrition & Cancer. 1997;27(2):136-42. [pmid: 9121940].
23 Rohan T E, Howe G R, Burch J D, Jain M. Dietary factors and risk of prostate cancer: a case-control study in Ontario, Canada. Cancer Causes & Control. 1995;6(2):145-54. [pmid: 7749054].
24 Takezaki T, Inoue M, Kataoka H, et al. Diet and lung cancer risk from a 14-year population-based prospective study in Japan: With special reference to fish consumption. Nutrition & Cancer. 2003;45(2):160-7. [pmid: 12881009].
25 Stolzenberg-Solomon R Z, Pietinen P, Taylor P R, Virtamo J, Albanes D. Prospective study of diet and pancreatic cancer in male smokers. [comment]. American Journal of Epidemiology. 2002;155(9):783-92. [pmid: 11978580].
26 Ngoan L T, Mizoue T, Fujino Y, Tokui N, Yoshimura T. Dietary factors and stomach cancer mortality. British-Journal-of-Cancer. 2002;87(1):37-42. many ref. [pmid: 12085253].
27 Le Marchand L, Kolonel L N, Wilkens L R, Myers B C, Hirohata T. Animal fat consumption and prostate cancer: a prospective study in Hawaii. [comment]. Epidemiology. 1994;5(3):276-82. [pmid: 8038241].
28 Augustsson K, Michaud D S, Rimm E B, et al. A prospective study of intake of fish and marine fatty acids and prostate cancer. Cancer Epidemiology, Biomarkers & Prevention. 2003;12(1):64-7.
29 Giovannucci E, Rimm E B, Colditz G A, et al. A prospective study of dietary fat and risk of prostate cancer. [comment]. Journal of the National Cancer Institute. 1993;85(19):1571-9. [pmid: 8105097].
30 Giovannucci E, Rimm E B, Stampfer M J, Colditz G A, Ascherio A, Willett W C. Intake of fat, meat, and fiber in relation to risk of colon cancer in men. Cancer Research. 1994;54(9):2390-7. [pmid: 8162586].
31 van Dam R M, Huang Z, Giovannucci E, et al. Diet and basal cell carcinoma of the skin in a prospective cohort of men. [comment]. American Journal of Clinical Nutrition. 2000;71(1):135-41. [pmid: 10617958].
32 Chyou P H, Nomura A M Y, Stemmermann G N. Diet, alcohol, smoking and cancer of the upper aerodigestive tract: A prospective study among Hawaii Japanese men. International Journal of Cancer. 1995;60(5):616-21.
33 Chyou P H, Nomura A M Y, Stemmermann G N. A prospective study of diet, smoking, and lower urinary tract cancer. Annals of Epidemiology. 1993;3(3):211-6. [pmid: 8275191].
34 Bostick R M, Potter J D, Kushi L H, et al. Sugar, meat, and fat intake, and non-dietary risk factors for colon cancer incidence in Iowa women (United States). Cancer Causes & Control. 1994;5(1):38-52. [pmid: 8123778].
35 Chiu B C, Cerhan J R, Folsom A R, et al. Diet and risk of non-Hodgkin lymphoma in older women. JAMA. 1996;275(17):1315-21. [pmid: 8614116].
36 Ozasa K, Watanabe Y, Ito Y, et al. Dietary habits and risk of lung cancer death in a large-scale cohort study (JACC Study) in Japan by sex and smoking habit. Jpn J Cancer Res. 2001;92(12):1259-69. [pmid: 11749690].
37 Voorrips L E, Brants H A, Kardinaal A F, Hiddink G J, van den Brandt P A, Goldbohm R A. Intake of conjugated linoleic acid, fat, and other fatty acids in relation to postmenopausal breast cancer: the Netherlands Cohort Study on Diet and Cancer. American Journal of Clinical Nutrition. 2002;76(4):873-82. [pmid: 12324303].
38 Goldbohm R A, van den Brandt P A, van't Veer P, et al. A prospective cohort study on the relation between meat consumption and the risk of colon cancer. Cancer Research. 1994;54(3):718-23. [pmid: 8306333].
39 Schuurman A G, van den Brandt P A, Dorant E, Brants H A, Goldbohm R A. Association of energy and fat intake with prostate carcinoma risk: results from The Netherlands Cohort Study. Cancer. 1999;86(6):1019-27. [pmid: 10491529].
40 Kato I, Akhmedkhanov A, Koenig K, Toniolo P G, Shore R E, Riboli E. Prospective study of diet and female colorectal cancer: the New York University Women's Health Study. Nutrition & Cancer. 1997;28(3):276-81. [pmid: 9343837].
41 Vatten L J, Solvoll K, Loken E B. Frequency of meat and fish intake and risk of breast cancer in a prospective study of 14,500 Norwegian women. International Journal of Cancer. 1990;46(1):12-5.
42 Veierod M B, Laake P, Thelle D S. Dietary fat intake and risk of lung cancer: a prospective study of 51,452 Norwegian men and women. European Journal of Cancer Prevention. 1997;6(6):540-9. [pmid: 9496456].
43 Holmes M D, Colditz G A, Hunter D J, et al. Meat, fish and egg intake and risk of breast cancer. International-Journal-of-Cancer. 2003;104(2):221-7. 36 ref.
44 Holmes M D, Hunter D J, Colditz G A, et al. Association of dietary intake of fat and fatty acids with risk of breast cancer. [comment]. JAMA. 1999;281(10):914-20. [pmid: 10078488].
45 Gertig D M, Hankinson S E, Hough H, et al. N-acetyl transferase 2 genotypes, meat intake and breast cancer risk. Int J Cancer. 1999;80(1):13-7. [pmid: 9935222].
46 Willett W C, Stampfer M J, Colditz G A, Rosner B A, Speizer F E. Relation of meat, fat, and fiber intake to the risk of colon cancer in a prospective study among women. [comment]. New England Journal of Medicine. 1990;323(24):1664-72. [pmid: 2172820].
47 Zhang S, Hunter D J, Rosner B A, et al. Dietary fat and protein in relation to risk of non-Hodgkin's lymphoma among women. Journal of the National Cancer Institute. 1999;91(20):1751-8. [pmid: 10528026].
48 Bertone E R, Rosner B A, Hunter D J, et al. Dietary fat intake and ovarian cancer in a cohort of US women. American Journal of Epidemiology. 2002;156(1):22-31. [pmid: 12076885].
49 Michaud D S, Giovannucci E, Willett W C, Colditz G A, Fuchs C S. Dietary meat, dairy products, fat, and cholesterol and pancreatic cancer risk in a prospective study. American Journal of Epidemiology. 2003;157(12):1115-25. [pmid: 12796048].
50 Mills P K, Beeson W L, Phillips R L, Fraser G E. Cohort study of diet, lifestyle, and prostate cancer in Adventist men. Cancer. 1989;64(3):598-604. [pmid: 2743254].
51 Gago-Dominguez M, Yuan J M, Sun C L, Lee H P, Yu M C. Opposing effects of dietary n-3 and n-6 fatty acids on mammary carcinogenesis: The Singapore Chinese Health Study. British Journal of Cancer. 2003;89(9):1686-92. [pmid: 14583770].
52 Key T J, Sharp G B, Appleby P N, et al. Soya foods and breast cancer risk: a prospective study in Hiroshima and Nagasaki, Japan. Br. 1999;81(7):1248-56.
53 Terry P, Lichtenstein P, Feychting M, Ahlbom A, Wolk A. Fatty fish consumption and risk of prostate cancer. [comment]. Lancet. 2001;357(9270):1764-6. [pmid: 11403817].
54 Terry P, Bergkvist L, Holmberg L, Wolk A. No association between fat and fatty acids intake and risk of colorectal cancer. Cancer Epidemiology, Biomarkers & Prevention. 2001;10(8):913-4.
55 Stripp C, Overvad K, Christensen J, et al. Fish intake is positively associated with breast cancer incidence rate. J Nutr. 2003;133(11):3664-9. [pmid: 14608091].
56 Kvale G, Bjelke E, Gart J J. Dietary habits and lung cancer risk. Int J Cancer. 1983;31(4):397-405. [pmid: 6832851].
57 Leitzmann M F, Stampfer M J, Michaud D S, et al. Dietary intake of n-3 and n-6 fatty acids and the risk of prostate cancer. Am J Clin Nutr. 2004;80(1):204-16. [pmid: 15213050].
58 Seventh-day Adventist Church. Available at www.adventist.org.
59 Seventh-day Adventist Church. Available at www.religioustolerance.org/sda.htm.
60 Denson K W. Re: Multicenter case-control study of exposure to environmental tobacco smoke and lung cancer in Europe. [comment]. Journal of the National Cancer Institute. 1999;91(9):803-4. [pmid: 10328113].
61 Kenler A S, Swails W S, Driscoll D F, et al. Early enteral feeding in postsurgical cancer patients. Fish oil structured lipid-based polymeric formula versus a standard polymeric formula. Annals of Surgery. 1996;223(3):316-33. [pmid: 8604913]. [pmcid: 1235121].
62 McCarter M D, Gentilini O D, Gomez M E, Daly J M. Preoperative oral supplement with immunonutrients in cancer patients. Jpen: Journal of Parenteral & Enteral Nutrition. 1998;22(4):206-11. [pmid: 9661120].
63 Swails W S, Kenler A S, Driscoll D F, et al. Effect of a fish oil structured lipid-based diet on prostaglandin release from mononuclear cells in cancer patients after surgery. Journal of Parenteral & Enteral Nutrition. 1997;21(5):266-74. [pmid: 9323688].
64 Braga M, Gianotti L, Vignali A, Carlo V D. Preoperative oral arginine and n-3 fatty acid supplementation improves the immunometabolic host response and outcome after colorectal resection for cancer. Surgery. 2002;132(5):805-14. [pmid: 12464864].
65 Braga M, Gianotti L, Nespoli L, Radaelli G, Di Carlo V. Nutritional approach in malnourished surgical patients: a prospective randomized study. Archives of Surgery. 2002;137(2):174-80. [pmid: 11822956].
66 Braga M, Vignali A, Gianotti L, Cestari A, Profili M, Di Carlo V. Benefits of early postoperative enteral feeding in cancer patients. Infusionstherapie Und Transfusionsmedizin. 1995;22(5):280-4. [pmid: 8924741].
67 Braga M, Gianotti L, Radaelli G, et al. Perioperative immunonutrition in patients undergoing cancer surgery: Results of a randomized double-blind phase 3 trial. Archives of Surgery. 1999;134(4):428-33. [pmid: 10199318].
68 Daly J M, Lieberman M D, Goldfine J, et al. Enteral nutrition with supplemental arginine, RNA, and omega-3 fatty acids in patients after operation: immunologic, metabolic, and clinical outcome. Surgery. 1992;112(1):56-67. [pmid: 1377838].
69 Daly J M, Weintraub F N, Shou J, Rosato E F, Lucia M. Enteral nutrition during multimodality therapy in upper gastrointestinal cancer patients. Annals of Surgery. 1995;221(4):327-38. [pmid: 7726669]. [pmcid: 1234581].
70 Di Carlo V, Gianotti L, Balzano G, Zerbi A, Braga M. Complications of pancreatic surgery and the role of perioperative nutrition. Digestive Surgery. 1999;16(4):320-6. [pmid: 10449977].
71 Gianotti L, Braga M, Vignali A, et al. Effect of route of delivery and formulation of postoperative nutritional support in patients undergoing major operations for malignant neoplasms. Archives of Surgery. 1997;132(11):1222-30. [pmid: 9366716].
72 Schilling J, Vranjes N, Fierz W, et al. Clinical outcome and immunology of postoperative arginine, omega-3 fatty acids, and nucleotide-enriched enteral feeding: a randomized prospective comparison with standard enteral and low calorie/low fat i.v solutions. Nutrition. 1996;12(6):423-9. [pmid: 8875537].
73 Senkal M, Zumtobel V, Bauer K H, et al. Outcome and cost-effectiveness of perioperative enteral immunonutrition in patients undergoing elective upper gastrointestinal tract surgery: a prospective randomized study. Archives of Surgery. 1999;134(12):1309-16. [pmid: 10593328].
74 Senkal M, Mumme A, Eickhoff U, et al. Early postoperative enteral immunonutrition: Clinical outcome and cost- comparison analysis in surgical patients. Critical Care Medicine. 1997;25(9):1489-96. [pmid: 9295822].
75 Heller A R, Rossel T, Gottschlich B, et al. Omega-3 fatty acids improve liver and pancreas function in postoperative cancer patients. Int J Cancer. 2004;111(4):611-6. [pmid: 15239141].
76 Fearon K C, Von Meyenfeldt M F, Moses A G, et al. Effect of a protein and energy dense N-3 fatty acid enriched oral supplement on loss of weight and lean tissue in cancer cachexia: a randomised double blind trial. Gut. 2003;52(10):1479-86. [pmid: 12970142]. [pmcid: 1773823].
77 Gianotti L, Braga M, Fortis C, et al. A prospective, randomized clinical trial on perioperative feeding with an arginine-, omega-3 fatty acid-, and RNA-enriched enteral diet: effect on host response and nutritional status. [comment]. Jpen: Journal of Parenteral & Enteral Nutrition. 1999;23(6):314-20. [pmid: 10574478].
78 Vignali A, Braga M, Gianotti L, Cestari A, Profili M, Di Carlo T. Impact of an enriched enteral formula on immune function and nutritional status in cancer patients following surgery. Rivista Italiana Di Nutrizione Parenterale Ed Enterale. 1995;13(1):25-31.
79 Preshaw R M, Attisha R P, Hollingsworth W J. Randomized sequential trial of parenteral nutrition in healing of colonic anastomoses in man. Canadian Journal of Surgery. 1979;22(5):437-9.
80 Fay M P, Freedman L S, Clifford C K, Midthune D N. Effect of different types and amounts of fat on the development of mammary tumors in rodents: A review. SO - Cancer Research. 1997;57(18):3979-88.
81 Kolonel L N, Nomura A M Y, Cooney R V. Dietary fat and prostate cancer: Current status. SO - Journal of the National Cancer Institute (Bethesda). March 3. 1999;91(5):414-428.
82 Cave W T Jr. Omega 3 fatty acid diet effects on tumorigenesis in experimental animals. World Review of Nutrition & Dietetics. 1991;66:462-76. [pmid: 2053363].
83 Zhao L P, Kushi L H, Klein R D, Prentice R L. Quantitative review of studies of dietary fat and rat colon carcinoma. Nutrition & Cancer. 1991;15(34):169-77. [pmid: 1866311].
84 Corpet D, Tache' S. Most effective colon cancer chemopreventive agents in rats: A systematic review of aberrant crypt foci and tumor data, ranked by potency. Nutrition and Cancer. 2002;43(1):1-21. [pmid: 12467130].
85 Reddy B S. Dietary fat and colon cancer: animal model studies. Lipids. 1992;27(10):807-13. [pmid: 1435100].
86 Baronzio G, Freitas I, Griffini P, et al. Omega-3 fatty acids can improve radioresponse modifying tumor interstitial pressure, blood rheology and membrane peroxidizability. SO - Anticancer Research. 1994;14(3A):1145-1154.
87 Avula C P R, Lawrence R A, Jolly C A, Fernandes G. Role of n-3 polyunsaturated fatty acids (PUFA) in autoimmunity, inflammation, carcinogenesis, and apoptosis. Recent-Research-Developments-in-Lipids. 2000;4(2):303-19. 216 ref.
88 Stoll B A. Linkage between retinoid and fatty acid receptors: implications for breast cancer prevention. European Journal of Cancer Prevention. 2002;11(4):319-25. [pmid: 12195157].
89 Troyer D, Fernandes G. Nutrition and apoptosis. SO - Nutrition Research. 1996;16(1112):1959-87.
90 Johnson I T. Anticarcinogenic effects of diet-related apoptosis in the colorectal mucosa. Food Chem Toxicol. 2002;40(8):1171-8. [pmid: 12067580].
91 Cave W T Jr. Omega-3 polyunsaturated fatty acids in rodent models of breast cancer. Breast Cancer Research & Treatment. 1997;46(23):239-46. [pmid: 9478278].
92 Corpet DE, Pierre F. Point: From animal models to prevention of colon cancer. Systematic review of chemoprevention in min mice and choice of the model system. 2003.
93 Ma Q, Hoper M, Halliday I, Rowlands B J. Diet and experimental colorectal cancer. SO - Nutrition Research. 1996;16(3):413-26.
94 Klurfeld D. Fat effects in experimental tumorigenesis. SO - Journal of Nutritional Biochemistry. 1995;6(4):201-5.
95 Blok W L, Katan M B, Van DMJWM. Modulation of inflammation and cytokine production by dietary (n-3) fatty acids. SO - Journal of Nutrition. 1996;126(6):1515-1533.
96 Calder P C. N-3 Polyunsaturated fatty acids and cytokine production in health and disease. SO - Annals of Nutrition & Metabolism. 1997;41(4):203-234.
97 Rose D P, Connolly J M. Regulation of tumor angiogenesis by dietary fatty acids and eicosanoids. Nutrition & Cancer. 2000;37(2):119-27. [pmid: 11142082].
98 Rose D P. Dietary fatty acids and prevention of hormone-responsive cancer. SO - Proceedings of the Society for Experimental Biology & Medicine. 1997;216(2):224-233.
99 Larsson S, Kumlin M, Ingelman-Sundberg M, Wolk A. Dietary long-chain n-3 fatty acids for the prevention of cancer: a review of potential mechanisms. Am J Clin Nutr. 2004;79:935-45. [pmid: 15159222].
100 Cantrill R C, Huang Y S. Fatty acids and cancer. [comment]. Nutrition. 1998;14(2):235-7. [pmid: 9530654].
101 Peet M, Edwards R W. Lipids, depression and physical diseases. Current Opinion in Psychiatry. 1997;10(6):477-80.
102 Fernandes G, Venkatraman J T. Modulation of breast cancer growth in nude mice by omega 3 lipids. World Review of Nutrition & Dietetics. 1991;66:488-503. [pmid: 2053366].
103 Noguchi M, Rose D P, Earashi M, Miyazaki I. The role of fatty acids and eicosanoid synthesis inhibitors in breast carcinoma. SO - Oncology (Basel). 1995;52(4):265-271.
104 Gonzalez M J. Fish oil, lipid peroxidation and mammary tumor growth. Journal of the American College of Nutrition. 1995;14(4):325-35. [pmid: 8568108].
105 Stoll B. Breast cancer and the Western diet: Role of fatty acids and antioxidant vitamins. SO - European Journal of Cancer. 1998;34(12):1852-6.
106 Stoll B. Essential fatty acids, insulin resistance and breast cancer risk. SO - Nutrition & Cancer. 1998;31(1):72-7.
107 Sinclair A J, Attar-Bashi N M, Lib D. What is the role of at-linolenic acid for mammals?. Lipids. 2002;37(12):1113-23. [pmid: 12617463].
108 Burns C P, Spector A A. Biochemical effects of lipids on cancer therapy. SO - Journal of Nutritional Biochemistry. 1994;5(3):114-23.
109 Das UN. Essential fatty acids, lipid peroxidation and apoptosis.