# Acknowledgments

We thank Herbert D. Woolf, of BASF Corporation for providing us with unpublished data on omega-3 fatty acids. We thank Di Valentine, for providing translation of Italian studies, Matthias Schonlau, for providing translation of German studies, and Grazyna Besser, for providing translation of Polish studies.

Chapter 1 was written in collaboration with the New England Medical Center Evidence-based Practice Center.