# Discussion

## Overview

To summarize existing data about the effects of omega-3 fatty acids on cancer incidence, cancer treatment and tumor behavior, we screened over 5,000 titles, from which we reviewed 1,270 full text articles. Among these, 79 articles met our inclusion criteria including 19 randomized controlled trials, 33 prospective cohort studies and 27 reviews. These articles underwent detailed review; our main findings are summarized below.

## Main Findings

### Cancer Incidence

We identified 19 different cohorts for which the association between omega-3 fatty acid consumption and the incidence of one or more types of cancer had been assessed; these data were reported in 33 different publications. Omega-3 consumption was estimated based on dietary questionnaires that were typically completed once at study entry, although a few of the cohorts updated dietary intake. Omega-3 consumption was expressed as total omega-3 fatty acids, fish/marine omega-3 fatty acids or as the specific omega-3 fatty acids ALA, EPA and/or DHA. Fish consumption, which serves as a proxy for EPA and DHA consumption, was also reported in many of the studies. Across these cohorts, cancer incidence was assessed during the 3 to 24 years after dietary information was obtained and was typically ascertained using population cancer registries.

The association between omega-3 fatty acid consumption and cancer incidence was described for the following types of cancer in one or more studies: aerodigestive, bladder, breast, colorectal, lung, lymphoma, ovarian, pancreatic, prostate, skin (basal-cell) and stomach. For most of these cancers the association between omega-3 consumption and incidence was described in one study. However, associations were described in multiple studies for the following cancers: breast (7), colorectal (6), lung (4), pancreatic (2) and prostate (7).

Across the 19 cohorts for 11 different types of cancer and using up to 5 different ways to categorize omega-3 fatty acid consumption, 43 estimates of the association between omega-3 fatty acid consumption were reported. Among these, only six were statistically significant. Significant associations between omega-3 consumption and cancer risk were reported for breast cancer in two studies; for lung cancer in two; for prostate cancer in one; and for skin cancer in one. For breast cancer, one significant estimate was for increased risk, and one was for decreased risk; five other estimates did not show a significant association. For lung cancer one of the significant associations was for increased cancer risk, the other was for decreased risk and four other estimates were not significant. Only one study assessed skin cancer risk.

Considering these data together, there is no overall trend across many different cohorts and categories of omega-3 fatty acid consumption to suggest that omega-3 fatty acids reduce overall cancer risk, i.e. omega-3 fatty acids appear not to affect a mechanism of cancer development that is common across the different types of cancers evaluated in this report. Although significant associations between omega-3 fatty acids and cancer incidence were observed for several specific types of cancer, for all but one of these types of cancers and for which there were no other studies, there were many other estimates of association that were not significant. Hence, we did not identify any specific types of cancer for which the composite evidence suggests an association between omega-3 fatty acids and cancer incidence. However, for most types of cancer, the data are not sufficient to exclude with confidence an association between omega-3 fatty acid consumption and cancer incidence.

### Cancer Treatment

We identified 19 studies from which the effect of omega-3 fatty acids on clinical outcomes after cancer therapy could be ascertained, all of which pertained to patients who had undergone cancer surgery for upper gastrointestinal malignancies. We did not identify any studies that assessed the effects of omega-3 fatty acids on clinical outcomes after chemotherapy or radiation treatment. Among the identified studies, the effect of omega-3 fatty acids alone could be ascertained from six studies; the effect of omega-3 fatty acids given in combination with arginine and RNA could be ascertained from 13. Effects on post-operative complications were described in 14, on hospital length of stay in 13, on mortality in ten, on nutritional parameters in 11, and on weight in three. In pooled analyses, omega-3 fatty acids had no effect compared to placebo on post-operative complications, hospital length of stay, nutritional parameters, or mortality.

Relative to a standard enteral diet, omega-3 fatty acids in combination with arginine and RNA were associated with a reduced risk of postoperative complications (RR 0.51, 95%CI 0.40, 0.64) and reduced length of hospital stay (pooled mean difference -3.33 days, 95%CI -4.29, -2.38). Among nine studies that assessed the effect on nutritional parameters omega-3 plus arginine and RNA, prealbumin was significantly higher in the omega-3 + arginine + RNA group in three studies, but not different in three others; mean nitrogen intake was significantly higher in one study but not in another. No significant differences were found for mean caloric intake, mean albumin, or mean transferrin.

Although the combination of omega-3 fatty acids, arginine, and RNA are associated with a reduced risk of post-operative complications and reduced length of hospital stay, it is not possible to ascertain whether these effects are due to omega-3 fatty acids, arginine, RNA, or a combination of these.

### Tumor Behavior

We evaluated 27 reviews of studies on animals or cell culture models that described the effects of tumor growth, differentiation or apoptosis. Although much of the evidence favored a role for n-3 dietary enrichment in the inhibition or prevention of tumor growth, at least in some animal models, the quality of the reviews is not sufficient to permit strong conclusions to be drawn.

A 1995 nonsystematic review^100^ and 1997 meta-analysis^101^ commented on the validity of various methods of dietary fat manipulation - isocaloric substitution of omega-3 FAs or omega-6 FAs for fat nutrients, isocaloric substitution for a combination of nutrients, simple addition to a complete diet, fat restriction, or energy restriction. Ideally, the total caloric intake and fat intake should be the same across all experimental groups. The authors concluded that some effects attributed to low-fat diets or to omega-3 FAs added to a calorie-controlled diet might in fact be the result of energy restriction; some nutrition researchers have theorized that ad lib-feeding of rodents actually produces a model of obesity rather than a model of a normal weight animal subject to some dietary manipulation. In some studies, fat and energy parity were maintained by varying the ratio of omega-3 FAs to some other fat (e.g., omega-6 FAs) , whereas omega-3 FA intake was varied in other studies by substituting it for a non-fat nutrient or simply adding it to an ad lib-fed diet, thus altering the proportion of dietary fat and other nutrients and potentially altering total caloric intake. If the ability of omega-3 FAs to exert an effect depends on their ratio to omega-6 FAs in the diet, differential effectiveness would be expected from different means of supplementation.

The 1995 review^100^ also commented on the variation in times of introduction and duration of n-3 supplementation relative to age and age at exposure to carcinogen. As described above, crossover studies have been used to test hypotheses regarding the stage of tumor development at which dietary fats might exert their effects; however, conclusions derived from such studies are suspect for a number of reasons. In the laboratory situation, the time of exposure to the carcinogen is known precisely. In contrast, because the causes of most human cancers are not known, the exposure time and time to onset can never be pinpointed, although it is believed that the time of onset may be many years. Thus, any substance that served to mitigate initial exposure or the events following exposure would need to be taken as a preventive and for as long as possible. None of the reviews appeared to include studies in which n-3 supplementation was initiated early in development or even much before exposure to the carcinogen.

Finally, at least one review noted that tumors induced by different carcinogens responded differently to dietary n-3 supplementation. This finding further limits the comparability and applicability of animal studies.

## Limitations

The result in this report should be interpreted in the context of its limitations. The sections on cancer incidence, cancer treatment and tumor behavior have specific limitations which we detail below. Additionally, the results we report in each of these sections could be affected by publication bias or incomplete data. With regard to publication bias, for observational studies, publication bias occurs as the result of preferential publication of studies with outcomes that achieve statistical significance, with no regard for whether such outcomes were secondary in nature. Given that the results for the observational studies included in this report were all essentially negative, publication bias does not appear to be present. For the RCTs, included in this report, we found no evidence of publication bias on funnel plot analyses.

Regarding incomplete data, it is possible that additional information that would change our conclusions is available in reports that we were unable to locate or for which we were unable to find a translator. For the section on tumor behavior we were unable to obtain 22 out of 82 articles that were of potential relevance to the report. For the sections on cancer incidence and treatment, this is unlikely that our data were incomplete given that our screening strategy was broad and that among over 1,200 articles that were of possible relevance to the report, only 28 could not be located.

Additional limitations specific to each of the sections of this report follow.

### Cancer Incidence

Interpretation of the data we report are limited by differences in the characteristics of the populations that were studied in the different cohorts and by differences in the methods used to ascertain exposure to omega-3 fatty acids and tumor incidence. With regard to differences in population characteristics, differences in measured and unmeasured characteristics across cohorts could affect the estimates of effect of omega-3 fatty acids in studies relative to one another. Of particular note is the fact that omega-3 consumption varied a great deal across study cohorts. However, given that basically no effect was found in any of the cohorts, this could be regarded as evidence that omega-3 fatty acids have no effect regardless of intake amount. With regard to differences in the methods used to ascertain omega-3 fatty acid exposure, with the exception of the Health Professionals Follow-up Study and the Nurses' Health Study, all other studies assessed omega-3 exposure at a single time point. For these studies it is not know whether omega-3 fatty acid consumption remained constant over the observation period for ascertainment of cancer incidence, which ranged from 6 to 27 years. Since for these studies it is not known whether omega-3 fatty acid consumption was constant over time, the reported estimates of effect for these studies should be interpreted with caution.

### Cancer Treatment

Interpretation of the results of the RCTs that assessed the effects of omega-3 fatty acids on clinical outcomes after cancer surgery is limited by the fact that the populations enrolled in these studies were highly selected and hence the results may not be generalizable to other patient populations.

### Tumor Behavior

In addition to the limitations imposed on our summary of the evidence by the quality of the reviews and the quality and heterogeneity of the original research, our summary may have been further affected by several other factors. First, a paucity of the reviews included cell and tissue culture models. Second, only the 2004 review included findings that really addressed the role of genes involved in n-3 transport and metabolism, and little evidence was presented in that review regarding transport. A review of original animal and cell/tissue culture studies for the years 1999 to 2004 might provide more complete answers to that question and point the way toward possible applications to human disease prevention and treatment.

## Conclusions

In a large body of literature spanning numerous cohorts from many countries and with different demographic characteristics, the evidence does not suggest a significant association between omega-3 fatty acids and cancer incidence. In a small body of literature, there is no significant association between omega-3 fatty acids and clinical outcomes after surgery for upper GI malignancy. Although a large, but heterogeneous, body of literature suggests that omega-3 dietary enrichment may play a favorable role in the inhibition or prevention of tumor growth in some animal models, the quality of the reviews is not sufficient to permit strong conclusions to be drawn.

## Future Research

We offer the following observations and recommendations regarding future research on the effects of omega-3 fatty acids on cancer.

Given the large body of evidence that suggests no association between omega-3 fatty acid consumption and cancer incidence, future research in this general area is unlikely to reveal significant associations. However, for specific cancer sites for which few studies have been published, and for which animal models suggest an association between omega-3 fatty acids and cancer, systematic pooling of data across existing cohorts to might be worthwhile. Likewise, should new evidence suggest a role for omega-3 fatty acids in the growth or development of a particular type of cancer, studies to assess the effect of omega-3 fatty acids on the incidence of that particular type of cancer might be warranted.

Although existing studies do not demonstrate an effect of omega-3 fatty acids on mortality, post-operative complications or nutrition after cancer surgery, the body of literature is small and does not support strong conclusions. Given a plausible model for an omega-3 effect on outcomes after cancer therapy, future directed trials might be warranted.

Although the body of literature that describes the effects of omega-3 fatty acids on tumor behavior in animal and cell culture models is large, it is heterogeneous in terms of the models used, the carcinogens used and the dose, timing and duration of exposure to omega-3 fatty acids. The development and dissemination of a consensus statement about goals and standards of research in this area might lead to more efficient and fruitful research in this area.