# Results

## Results of Literature Search

### Tumor Incidence and Outcomes After Cancer Treatment

Figure 3.1 displays the flow of the literature review to assess the effects of omega-3 FA on tumor incidence and treatment.

Figure 3.1 Literature flow to assess the effects of omega-3 FA on tumor incidence and treatment

To assess the effects of omega-3 FA on tumor incidence and treatment, the University of Ottawa EPC e-mailed us a total of 4,729 citations as a result of their computerized library searches; our reviewers found 93 additional citations after reference mining; a request for unpublished data yielded one citation; peer reviewers of a draft of this report identified 11 more citations. In total we reviewed 4,834 citations. Our reviewers considered 1,238 of these article titles to be relevant to our research topics. We were able to retrieve 1,210 (98%) of these articles.

Of the articles retrieved, 356 were accepted for further review because they reported on results from randomized clinical trials, controlled clinical trials, or prospective cohort studies of omega-3 FA in the treatment of cancer. We rejected 854 at this stage: 283 were reviews and meta-analyses, 328 reported on a topic other than omega-3 FA, 112 did not report on a population of interest, 26 had descriptive study designs, 89 had other inappropriate study designs, 14 either reported on a condition other than those of interest or did not describe the effect of omega-3 FA on these outcomes, and two were written in foreign languages for which we did not have translators.

Of the 356 articles that went to further review, a total of 263 were rejected. Among those rejected, we were unable to compare the effect of omega-3 FA across study arms in 39. The remaining 224 were rejected for study design (i.e., case control/case series). Thus, a total of 93 articles were tentatively accepted for supplementary analysis. However, on further inspection, 41 of these articles did not report on outcomes of interest and/or we were not able to compare the effects of omega-3 FA across study arms, leaving 52 articles for the final analysis. Of these 52, 33 reported on cancer incidence and 19 reported on cancer treatment. Of the 19 articles that reported on cancer treatment, all reported on cancer surgery; none reported on chemotherapy or radiation therapy. Some articles assessed more than one cancer surgery outcome: 14 assessed post-operative complications, 13 assessed length of stay, 10 assessed mortality, 11 assessed nutrition, and three assessed body weight.

As noted above, an additional 11 articles not identified in our initial search were recommended by external reviewers who reviewed a first draft of this report. Among those studies, 3 met our inclusion criteria and were added to the report.

### Tumor Behavior

Figure 3.2 displays the flow of the literature reviews to assess the effects of omega-3 FA on tumor growth, differentiation, and apoptosis.

Figure 3.2 Literature flow to assess the effects of omega-3 FA on tumor behavior

To assess the effects of omega-3 FA on tumor growth differentiation and apoptosis, the University of Ottawa EPC e-mailed us a total of 366 citations as a result of their computerized library searches, and our reviewers found three citations after reference mining, for a total of 369 citations. Our reviewers considered 82 of these article titles to be relevant to our research topics. We were able to retrieve 60 (73%) of these articles.

Of the 60 articles retrieved, 27 were accepted for further review, because they appeared to report on the effects of omega-3 FA (added to the diet or to cell cultures) on cancer development, apoptosis, or cell differentiation in laboratory animals or cell culture systems. The other 37 articles were rejected because they did not report on a topic of interest (26), were not about omega-3 FA (7), were not about supplementation (1), were about other mechanisms (2), were reviews (1), or were not about cancer development (1).

Summaries of the 27 accepted articles can be found in Appendix C. Table C.3.1 summarizes the findings for the systematic reviews and meta-analyses, and Table C.3.2 summarizes the findings for the nonsystematic reviews of tumor growth. Table C.3.3 summarizes the findings relevant to differentiation. Table C.3.4 summarizes the findings regarding apoptosis. Table C.3.5 summarizes the evidence related to a role for n-3 transport and metabolic enzyme genes. These findings are described qualitatively below as responses to the questions posed.

## Tumor Incidence

We identified 33^24–56^ reports that described the effect of omega-3 FA on the incidence of eleven different types of cancer among subjects enrolled in nineteen different cohorts (Table 3.1). Over half of these reports described the effect of omega-3 FA on one of three types of cancer: breast,^37,^ ^41,^ ^43,^ ^44,^ ^51,^ ^52,^ ^55^ colorectal,^30,^ ^34,^ ^38,^ ^40,^ ^46,^ ^54^ and prostate.^27,^ ^28,^ ^29,^ ^39,^ ^50,^ ^53,^ ^57^ The remaining publications described the effects of omega-3 FA on the incidence of eight different types of cancer with only one or two publications describing the effects on each of these types of cancer.

Table 3.1 Prospective observational studies of cancer incidence by cancer type and cohort

Cohort | Cancer Type
| Aerodigestive, upper | Bladder | Breast | Colorectal | Lung | Lymphoma, Non-hodgkin's | Ovarian | Pancreatic | Prostate | Skin, BCC | Stomach
Aichi Prefecture Cohort, Japan | | | | | Takezaki, 2003^24^
Alpha-tocopherol, Beta-Carotene Cancer Prevention Study | | | | | | | | Stolzenberg-Solomon, 2002^25^
Diet, Cancer and Health Study | | | Stripp, 2003^55^
Fukuoka Prefecture Cohort, Japan | | | | | | | | | | | Ngoan, 2002^26^
Hawaii Health Surveillance Program | | | | | | | | | LeMarchand, 1994^27^
Health Professionals Follow-up Study | | | | Giovannucci, 1994^30^ | | | | | Giovannucci, 1993^29^; | Van Dam, 2000^31^
| | | | | | | | | Augustsson, 2003;^28^
| | | | | | | | | Leitzman, 2004^57^
Honolulu Heart Program | Chyou, 1995^32^ | Chyou, 1993^33^
Iowa Women's Health Study | | | | Bostick, 1994^34^ | | Chiu, 1996^35^
Japan Collaborative Cohort | | | | | Ozasa, 2001^36^
Life Span Study | | | Key, 1999^52^
Netherlands Cohort Study | | | Voorips, 2002^37^ | Goldbohm, 1994^38^ | | | | | Schuurman, 1999^39^
New York University Women's Health Study | | | | Kato, 1997^40^
Norwegian National Health Screening Service Cohort | | | Vatten, 1990^41^ | | Veierod, 1997^42^
Norwegian Cohorts | | | | | Kvale, 1983^56^
Nurses' Health Study | | | Holmes 1999^44^; | Willett, 1990^46^ | | Zhang, 1999^47^ | Bertone, 2002^48^ | Michaud, 2003^49^
| | | Holmes, 2003^43^
Seventh-day Adventist | | | | | | | | | Mills, 1989^50^
Singapore Chinese Health Study | | | Gago-Dominguez, 2003^51^
Swedish Twin Registry | | | | | | | | | Terry, 2001^53^
Swedish Women in Mammography Screening Program | | | | Terry, 2001^54^

## Cohort Characteristics

The characteristics of the nineteen cohorts in which cancer incidence was studied are summarized in Table 3.2. These cohorts ranged in size from 6,000 to 121,000, with from 9,000 to 1.5 million person-years of observation; together, these cohorts include over 700,000 subjects and 3 million person-years of observation. The observation periods in these cohorts ranged from 3 to 30 years.

Table 3.2 Characteristics of cohorts that have described the effects of omega-3 FA on cancer incidence

Cohort | Author, year | Cancer type | # subjects in cohort* | Birth years | Enrollment period | Observation period, exposure to omega-3 | Ascertainment of omega-3 exposure | Observation period, cancer | Ascertainment of cancer | Base-population | Predominant race/ethnicity | Gender(s) in cohort
Aichi Prefecture Cohort, Japan | Takezaki, 2003^24^ | Lung | 9,753 | 1917-1972 | 1986-1989 | Enrollment | Food frequency questionnaire | ND | ND | Population of Aichi Prefecture | Japanese
Alpha-tocopherol, Beta-Carotene Cancer Prevention Study | Stolzenberg-Solomon, 2002^25^ | Pancreatic | 27,111 | 1916-1938 | 1985-1988 | Enrollment | Food frequency questionnaire about 1-year prior to enrollment | 1985-1997 | Tumor registry with medical records verification | Male smokers | Caucasian | Male
Diet, Cancer and Health Study | Stripp, 2003^55^ | Breast | 29,875 | 1929-1947 | 1993-1997 | Enrollment | Food frequency questionnaire | 1993-2000 | Cancer registry | Population of greater Copenhagen and Aarhus | Caucasian | Male and Female
| | | | | | | | | | | | Female for substudy reported here
Fukuoka Prefecture Cohort, Japan | Ngoan, 2002 ^26^ | Stomach | 13,250 | 1880-1974 | 1986-1989 | Enrollment | Dietary questionnaire | Not stated | Not explicitly stated; infer death certificates from text. | Population of Fukuoka Prefecture | Japanese | Male and Female
Hawaii Health Surveillance Program | LeMarchand, 1994^27^ | Prostate | 8,881 | ND | 1975-1980 | 1975-1980 | Lifestyle questionnaire | 1975-1989 | Hawaii tumor registry | Hawaiians of Japanese, Caucasian, Filipino, Hawaiian or Chinese ancestry | Caucasian, Asian, Pacific Islander | Male
Health Professionals Follow-up Study | Augustsson, 2003^28^ | Prostate | 51,529 | 1911-1946 | 1986 | 1986, 1990, 1994 | Food frequency questionnaire | 1986-1998 | self-report or vital records confirmed by medical records review | Male dentists, optometrist, osteopaths, podiatrists, pharmacists, and veterinarians that responded to a postal questionnaire | Caucasian | Male
| Giovannucci, 1993^29^ | Prostate
| Giovannucci, 1994^30^ | Colorectal
| Leitzmann, 2004^57^ | Prostate
| VanDam, 2000^31^ | Skin, basal cell carcinoma
Honolulu Heart Program | Chyou, 1995 ^32^ | Upper Aero-digestive | 8,006 | 1900-1919 | 1965-1968 | 1965-1968 | Food frequency questionnaire and 24-hr diet recall history | 1965-1993 | Oahu hospitalizations for cancer and Hawaii Tumor Registry† | Institutionalized American men of Japanese ancestry residing on Oahu. | Hawaiians of Japanese ancestry | Male
| Chyou, 1993 ^33^ | Bladder
Iowa Women's Health Study | Bostick, 1994^34^ | Colorectal | 41,837 | 1917-1931 | 1986 | 1986 | Food frequency questionnaire re: prior 1-year | 1986-1992 | State Health Registry of Iowa | Women with valid Iowa driver's license | Caucasian | Female
| Chiu, 1996^35^ | Non-Hodgkin's lymphoma
Japan Collaborative Cohort | Ozasa, 2001^36^ | Lung | 110,792 | 1909-1950 | 1988-1990 | At enrollment | Food frequency questionnaire | 1988-1997 | Death certificates | Population of 19 prefectures in Japan | Japanese | Male and Female
Life Span Study | Key, 1999^52^ | Breast | Approx. 120,000 | NR | 1969-1970 | 1969-1970, 1979 | Food frequency questionnaire | 1969-1993, 1981-1983 | Hiroshima and Nagasaki cancer Registries | Survivors of atomic bomb in Hiroshima or Nagasaki, Japan that were alive on September 1, 1969 | Asian | Male and Female
Netherlands Cohort Study | Voorrips, 2002^37^ | Breast | 62,573 | 1917-1931 | 1986 | 1986 | Food frequency questionnaire | 1986-1992 | Regional cancer registries | Population | Caucasian/Dutch | Male and female
| Goldbohm, 1994^38^ | Colorectal
| Schuurman, 1999^39^ | Prostate
New York University Women's Health Study | Kato, 1997^40^ | Colorectal | 14,727 | 1920-1957 | 1985-1991 | At enrollment | Dietary questionnaire | 1985-1992 | Self report confirmed by medical records review supplemented by review of state cancer registries and National Death index | Women treated at the Guttman Breast Diagnostic Institute in New York City or at the Strax Breast Cancer Institute in Florida | Caucasian, Black, Hispanic | Female
Norwegian Cohorts | Kvale, 1983^56^ | Lung | 16,713 | NR | 1964 | One- time questionnaire between 1967 and 1969 | Dietary questionnaire | From questionnaire until 1978 | Cancer registry | Population | Caucasian | Male and Female
Norwegian National Health Screening Service Cohort | Vatten, 1990^41^ | Breast | 14,729 | 1925-1942 | 1974-1977 | At enrollment | Food frequency questionnaire and 24-hr diet recall history | 11–14 years f/u, mean = 12 | National Cancer Registry | Population of Norway | Caucasian | Male and Female
| Veierod, 1997^42^ | Lung
| Holmes, 2003^43^ | Breast
| Holmes, 1999^44^ | Breast
Nurses' Health Study | Willett, 1990^46^ | Colorectal | 121,700 | 1921-1946 | 1976 | 1980, 1984, 1986, 1990, 1994 | Food frequency questionnaire re: prior 1-year | 1980-1994 | Self-report or vital records confirmed by medical records review | US female registered nurses | Caucasian | Female
| Zhang, 1999 ^47^ | Non-Hodgkin's lymphoma
| Bertone, 2002^48^ | Ovarian
| Michaud, 2003^49^ | Pancreatic
Seventh-day Adventist | Mills, 1989^50^ | Prostate | ND | ND | 1976 | 1976 | Lifestyle questionnaire | 1976-1982 | Self-report confirmed by medical records review and Cancer registry | Seventh-day Adventist households in California | ND | Male and Female
Singapore Chinese Health Study | Gago-Dominguez, 2003^51^ | Breast | 63,257 | 1919-1953 | 1993-1998 | 1-year prior to enrollment | Food frequency questionnaire | Enrollment -2000 | Singapore Cancer registry | Permanent residents or citizens of Singapore living in government housing estates† speaking Hokkien or Cantonese | Asian | Male and Female
Swedish Twin Registry | Terry, 2001^53^ | Prostate | 6272 | 1886-1925 | 1961 | 1967 | Lifestyle questionnaire | 1967-1997 | National Cancer and death registries | Male twin pairs residing in Sweden in 1961 | Caucasian | Male
Swedish women in mammography-screening program | Terry, 2001^54^ | Colorectal | 61,463 | 1925-1939 | 1987-1990 | 6-months prior to enrollment | Food intake questionnaire | Enrollment-1998 | Regional cancer registries | Participants of population-based mammography screening program | Caucasian | Female

* Total number of subjects enrolled in cohort, number may differ from number of subjects in analyses of specific diseases;

† 86% of population lived in this type of housing at the time the cohort was formed.

Demographic characteristics differ greatly across these cohorts. Among the cohorts, eleven comprise subjects who live in countries outside the US, and seven comprise US residents. Among both foreign and US cohorts, seven are population-based (Table 3.2), although from populations that are racially and culturally distinct. For example, while the Aichi Prefecture Cohort^24^ and the Netherlands Cohort^37,^ ^38^ are both population-based samples, the former comprises Asians from rural Japan, the latter Caucasians from Northern Europe. None of the US cohorts are derived from a population-based sample. The remaining eleven cohorts were drawn from base populations with specific geographic, professional, religious and/or other socioeconomic characteristics. For example, the Health Professionals Follow-up study cohort comprises US male dentists, optometrists, osteopaths, podiatrists, pharmacists, and veterinarians - professionals who are highly educated and generally of high income. Subjects in the Seventh-day Adventist Cohort study cohort are, as the name suggests, members of the Seventh-day Adventist Church, which advocates a healthy lifestyle^58^ that includes abstinence from alcohol, coffee, tea, and tobacco; many are vegetarians who supplement their diet with eggs and milk.^59^ These and other unique measured and unmeasured characteristics of the cohorts could differentially affect the risk estimates presented by each study. However, reproduction of findings across these diverse cohorts would strengthen their validity.

Particularly relevant to this report, the range of omega-3 consumption varies among the different cohorts. Figures 3.3 to 3.7 display the population intake of different categories of omega-3 fatty acid consumption for the cohorts that are described in this report. Each figure describes a different category of omega-3 fatty acid consumption and includes a series of stacked bars for each cohort that signify the amount consumed for quintiles, quartiles, or tertiles of intake. Each bar bounds the range of intake for a quintile, quartile, or tertile. In order to demonstrate how omega-3 consumption in the cohorts identified for this report compare to US population norms, Figures 3.5 to 3.7 additionally indicate the mean US consumption of ALA, EPA, and DHA, respectively, as reported by NHANES III and CSFII.

Figure 3.4 Distribution of omega-3 consumption by cohort relative to US intake reported in CSFII and NHANES III.*

Figure 3.3 Distribution of fish consumption by cohort relative to US intake reported in CSFII and NHANES III.*

Figure 3.5 Distribution of ALA consumption by cohort relative to US intake reported in CSFII and NHANES III.*

Figure 3.7 Distribution of DHA consumption by cohort relative to US intake reported in CSFII and NHANES III.*

Because the types of omega-3 fatty acid assessed varied across the cohorts, it is not possible to determine which cohort had the highest or lowest omega-3 fatty acid consumption. However, among cohorts for which fish intake was reported, the highest population intake was reported for the Lifespan Study cohort, for which the median intake of fish in the lowest and highest tertiles were less than one serving per week and greater than 5 servings per week, respectively. The lowest intake was reported in the Seventh Day Adventist cohort, for which the median intake of fish is estimated to be 1 serving per week. In general, omega-3 fatty acid intake in the US cohorts was not very different than for Asian and European cohorts (Figures 3.3 to3.7). Among US cohorts, the Health Professionals Follow-up Study reported a median ALA intake similar to that reported by NHANES III and CSF II; intake in the Nurses Health Study Cohort was a bit lower than that reported but CSF II, but similar to that reported by NHANES II (Figure 3.5). Among foreign cohorts, median ALA intake in the Netherlands Cohort study was similar to that reported by NHANES III and CSF II; intake was lower in the Swedish Mammography cohort (Figure 3.5). Median intake of EPA and DHA were much higher in the Netherlands and Swedish Women Mammography cohorts than that reported by NHANES III and CSFII (Figures 3.6 and 3.7). The amount of omega-3 fatty acid in the diet of different populations could differentially affect risk estimates, depending on the mechanism of action and/or dose-response of the effects of omega-3 FA on cancer. If omega-3 FA have no effect on cancer, then the amount of omega-3 FA in the diets of various populations should not affect risk estimates. If omega-3 FA do affect cancer risk, then the amount of omega-3 FA in the diets of different populations could have several effects on risk estimates. Assuming a linear dose-response to omega-3 FA, then a dose effect over different levels of intake should be seen for all cohorts regardless of the mean consumption of the population. Assuming a threshold effect at a low dose, an effect might not be observed for cohorts in which most subjects consume at least the threshold dose. Conversely, assuming a threshold effect at a high dose, an effect might not be observed for cohorts in which most subjects do not consume at least the threshold dose.

Figure 3.6 Distribution of EPA consumption by cohort relative to US intake reported in CSFII and NHANES III.*

Other factors that should be considered when interpreting the data from the different cohorts include the year of birth for the members of the cohort and when the exposure to omega-3 FA was assessed. Many of the cohorts comprise individuals born between 1915 and 1935, a few comprise individuals born before 1925, and a few include a broad range of birth years ranging roughly from 1910 to 1960 (Table 3.2). It is possible that secular trends, including changes in diet, could differentially affect risk estimates for different birth cohorts. It is likely that the diets of individuals in the 1915 to 1935 birth cohorts, particularly those from Europe and Japan, were affected for a period of time by World War II. For all but two of the cohorts, exposure to omega-3 FA was assessed at one time point. In most studies, dietary habits during a finite preceding time period of up to one year were assessed at the time of enrollment. In contrast, the Health Professionals Follow-up Study and the Nurses' Health Study assessed dietary habits at multiple time points.

Summaries of all evaluated studies can be found in Appendix C.1. The following sections describe the reported effects of omega-3 FA and the incidence of specific types of tumors.

## Overall Effect of Omega-3 FA on Tumor Incidence

The risk ratios for developing cancer for the highest consumption group (quartile, quintile, dose group, etc) relative to the lowest consumption group for fish consumption, total omega-3 FA consumption, ALA consumption, DHA consumption, and EPA consumption are displayed in Figures 3.8 through 3.12. Among 44 estimates of association calculated across 19 different cohorts for 11 different types of cancer and 5 different ways to assess omega-3 FA consumption, only six are statistically significant. Significant associations between omega-3 FA consumption and cancer risk were reported for lung cancer in two studies; for breast cancer in two; for prostate cancer in one; and for skin cancer in one. However, for lung cancer, one of the significant associations was for increased cancer risk and the other was for decreased risk; four other risk ratios were not significant. Likewise for breast cancer, one of the statistically significant risk ratios was for increased risk and one was for decreased risk; five other risk ratios did not show a significant association. Only one study assessed skin cancer risk. Hence, no trend was found across many different cohorts and many different categories of omega-3 FA consumption to suggest that omega-3 FA reduce overall cancer risk.

Figure 3.9 Risk of developing cancer for subjects with the highest grouping of omega-3 intake relative to subjects with the lowest grouping of intake by cancer type

Figure 3.10 Risk of developing cancer for subjects with the highest grouping of ALA intake relative to subjects with the lowest grouping of intake by cancer type

Figure 3.11 Risk of developing cancer for subjects with the highest grouping of EPA intake relative to subjects with the lowest grouping of intake by cancer type

Figure 3.8 Risk of developing cancer for subjects with the highest grouping of fish intake relative to subjects with the lowest grouping of intake by cancer type

Figure 3.12 Risk of developing cancer for subjects with the highest grouping of DHA intake relative to subjects with the lowest grouping of intake by cancer type

### Aerodigestive Tract Cancer

Overall effect. We identified one study^32^ that evaluated the effect of fish consumption on the incidence of upper aerodigestive tract cancer, which was defined as squamous cell carcinoma of the oral cavity/pharynx, esophagus, or larynx. In this study, fish consumption had no significant effect on the incidence of aerodigestive tract cancer. Using fish consumption 1 time per week or less as the referent group, the relative risks of developing aerodigestive tract cancer were 1.02 (0.65–1.61) and 1.37 (0.70–2.69) for men consuming fish 2 to 4 times per week and ≥ 5 times per week or more, respectively (Table 3.3).

Table 3.3 Risk of upper aerodigestive cancer for different categories of consumption of omega-3 FA, by category.*

Cohort | Study arm (quartile, quintile or dose group) | n† | Median intake | Estimates of effect
Author, Year | | | | Age adjusted RR (95% CI) | Multivariate RR (95% CI) | | Multivariate Adjustors
FISH
Honolulu Heart Program | 1 | NR | < 1 g/week | NR | 1 | | Age, alcohol, number of cigarettes/day, number of years smoked.
Chyou, 1995^32^ | 2 | NR | 2–4 g/week | NR | 1.02 | (0.65, 1.61)
| 3 | NR | ≥ 5 g/week | NR | 1.37 | (0.70, 2.69)
| Total 7,995 | | p = 0.473‡

* NR = Not Reported;

† = Number of people included in analysis;

‡ = test for trend.

Sub-populations. The subjects in this one study were from a distinct population, institutionalized American men of Japanese ancestry who resided on the Hawaiian island of Oahu. Analyses of subpopulations were not performed.

Covariates. The effects of covariates on the effect of fish were not assessed.

Effects of dose, source, and exposure duration. Omega-3 dose was not defined in this study. Rather, the amount of fish consumed was described. As noted above, comparisons between different levels of fish consumption and a referent value did not reveal any statistically significant effects. Additionally, with testing across all exposure levels, the p-value for trend was 0.473. Duration of exposure was not defined in this study, and the effects of different durations of exposure were not tested; usual fish intake at baseline between 1965 and 1968 was determined but not assessed subsequently.

Sustainment of Effect. Sustainment of effect was not assessed.

Quality and Applicability. See Table 3.4.

Table 3.4 Relationship between methodologic quality and applicability for estimates of effect of omega-3 fatty acid consumption on risk of upper aerodigestive cancer.*

Cohort | Applicability | Quality Parameters
Author, Year | | Adjustment for confounders | Blinding | Valid ascertainment, cases | Valid ascertainment, exposure | Withdrawals and dropouts described
Honolulu Heart Program | III | Yes | NR | Yes | Yes | Yes
Chyou, 1995^32^

* NR = Not Reported

### Bladder Cancer

Overall effect. We identified one study^33^ that evaluated the effect of fish consumption on the incidence of urinary bladder cancer. In this study, fish consumption had no significant effect on the incidence of bladder cancer. Using fish consumption 1 time per week or less as the referent group, the relative risks of developing bladder cancer were 0.90 (0.59–1.39) and 0.67 (0.26–1.67) for men consuming fish 2 to 4 times per week and 5 times per week or more, respectively (Table 3.5).

Table 3.5 Risk of bladder cancer for different categories of consumption of omega-3 FA, by category.*

Cohort | Study arm (quartile, quintile or dose group) | n† | Median intake | Estimates of effect
Author, Year | | | | Age adjusted RR (95% CI) | Multivariate RR (95% CI) | | Multivariate Adjustors
FISH
Honolulu Heart Program | 1 | NR | ≤ 1 times/week | NR | 1 | | Age, smoking.
Chyou, 1993^33^ | 2 | NR | 2–4 times/week | NR | 0.90 | (0.59, 1.39)
| 3 | NR | ≥ 5 times/week | NR | 0.67 | (0.26, 1.67)
| Total 7,995 | | p = 0.377‡

* NR = Not Reported;

† = Number of people included in analysis;

‡ = test for trend.

Sub-populations. The subjects in this one study were from a distinct population, institutionalized American men of Japanese ancestry who resided on the Hawaiian island of Oahu. Analyses of subpopulations were not performed.

Covariates. The effects of covariates on the effect of fish were not assessed.

Effects of dose, source, and exposure duration. Omega-3 dose was not defined in this study. Rather, the amount of fish consumed was described. As noted above, comparisons between different levels of fish consumption and a referent value did not reveal any statistically significant effects. Additionally, with testing across all exposure levels, the p-value for trend was 0.38. Duration of exposure was not defined in this study, and the effects of different durations of exposure were not tested; usual fish intake at baseline between 1965 and 1968 was determined, but not assessed subsequently.

Sustainment of effect. Sustainment of effect was not assessed.

Quality and applicability. See Table 3.6

Table 3.6 Relationship between methodologic quality and applicability for estimates of effect of omega-3 fatty acid consumption on risk of bladder cancer.*

Cohort | Applicability | Quality Parameters
Author, Year | | Adjustment for confounders | Blinding | Valid ascertainment, cases | Valid ascertainment, exposure | Withdrawals and dropouts described
Honolulu Heart Program | III | Yes | NR | Yes | Yes | Yes
Chyou, 1993^33^

* NR = Not Reported.

### Breast Cancer

Overall effect. We identified seven studies^37,^ ^41,^ ^43,^ ^44,^ ^51,^ ^52,^ ^55^ from six different cohorts that evaluated the effect of omega-3 FA on the incidence of breast cancer. Breast cancer incidence relative to fish consumption was reported in four studies,^41,^ ^43,^ ^52,^ ^55^ incidence relative to total and marine omega-3 fatty acid consumption was reported in one,^51^ and incidence relative to each of the specific omega-3 FA, DHA, EPA and ALA was reported in one.^37^ No significant overall association with the incidence of breast cancer was found with fish, total omega-3 FA, DHA, or EPA consumption (Table 3.7). In one study,^55^ women in the highest quartile of fish intake had an increased risk of breast cancer relative to women in the lowest quartile of fish intake (IRR 1.47; 95% CI 1.10, 1.98). Omega-3 FA consumption from marine sources and ALA consumption were associated with a reduced risk of developing breast cancer. Women in the highest quartile of consumption of marine omega-3 FA had a lower incidence of breast cancer than women in the lowest quartile of consumption (RR 0.72, 95% CI 0.53, 0.98). Women in the highest quintile of ALA consumption had a significantly lower incidence of breast cancer than women in the lowest quintile of consumption. This observation held true with adjustment for both age (RR 0.68; 95% CI 0.51, 0.91) and multiple variables (RR 0.70; 95% CI 0.51, 0.97). Associations between ALA consumption and breast cancer incidence were not significant for comparisons between the other quintiles and the lowest quintiles.

Table 3.7 Risk of breast cancer for different categories of consumption of omega-3 FA, by category.*

Cohort | | Study arm (quartile, quintile or dose group) | n† | Median intake | Estimates of effect
Author, Year | | | | | Age adjusted RR (95% CI) | | Multivariate RR | | Multivariate Adjustors (95% CI)
FISH
Diet, Cancer and Health Study | | 1 | NR | 0–26 g/day | 1 | | 1 | | Age, parity, number of births, age at first birth, BMI, benign breast tumor, years of school, use of HRT, duration of HRT use, alcohol.
Stripp, 2003^55^ | | 2 | NR | 27–39 g/day | 1.01 | (0.77. 1.32) | .99 | (0.76, 1.30)
| | 3 | NR | 40–58 g/day | 1.17 | (0.89, 1.53) | 1.12 | (0.85, 1.47)
| | 4 | NR | > 58 g/day | 1.54 | (1.18, 2.02) | 1.47 | (1.10, 1.98)
| | Total 23,693
Nurses' Health Study | | 1 | NR | ≤ 0.13 servings/day | NR | | 1 | | Age, 2yr time period, total energy, alcohol intake, parity and age at first birth, BMI at age 18, weight change since 18, height in inches, family history of breast cancer, history of benign breast disease, age at menarche in years, menopausal status, age at menopausal and HRT use, duration of menopausal.
Holmes, 2003^43^ | | 2 | NR | 0.14–0.2 servings/day | NR | | .98 | (0.89, 1.08)
| | 3 | NR | 0.21–0.27 servings/day | NR | | .97 | (0.87, 1.08)
| | 4 | NR | 0.28–0.39 servings/day | NR | | .99 | (0.90, 1.09)
| | 5 | NR | ≥ 0.4 servings/day | NR | | 1.04 | (0.93, 1.14)
| | Total 88,647 | | | | | | p = 0.55‡
Life Span Study | Fish, not dry | 1 | NR | ≤ 1 times/week | NR | | 1 | | Attained age, calendar period, city, age at time of bombing, and radiation dose.
Key, 1999^52^ | | 2 | NR | 2–4 times/week | NR | | 1.08 | (0.84, 1.39)
| | 3 | NR | ≥ 5 times/week | NR | | 1.17 | (0.90, 1.54)
| | 4 | NR | Unknown | NR | | 0.92 | (0.66, 1.29)
| | Total 34,759 | | | | | | p = 0.21‡
| Fish, dry | 1 | NR | ≤ 1 times/week | NR | | 1
| | 2 | NR | 2–4 times/week | NR | | 0.85 | (0.64, 1.12)
| | 3 | NR | ≥ 5 times/week | NR | | 0.49 | (0.24, 1.02)
| | 4 | NR | Unknown | NR | | 0.77 | (0.60, 0.98)
| | Total 34,759 | | | | | | p = 0.03‡
Norwegian National Health Screening Service Cohort | | 1 | NR | ≤ 2 g/week | 1§ | | NR | | NR
Vatten, 1990^41^ | | 2 | NR | ≥ 2 g/week | 1.2§ | (0.8, 1.7) | NR
| | Total 14,500 | | | | p = 0.24‡
OMEGA-3
Singapore Chinese Health Study | | 1 | NR | NR | NR | | 1 | | Age at baseline interview, year of recruitment, dialect group, education, daily alcohol drinker, family history of breast cancer, age when period became regular, number of live births.
Gago-Dominguez, 2003^51^ | | 2 | NR | NR | NR | | 0.82 | (0.60, 1.1)
| | 3 | NR | NR | NR | | 0.84 | (0.62, 1.15)
| | 4 | NR | NR | NR | | 0.87 | (0.64, 1.18)
| | Total 35,298 | | | | | | p = 0.40‡
ALA
Netherlands Cohort Study | | 1 | NR | 0.6 | 1 | | 1 | | Age, history of benign breast cancer, breast cancer in one or more sisters, age at menarche, age at menopause, oral contraceptive use, parity, age at first childbirth, Quetelet index, education, alcohol use, current cigarette smoking, total energy intake, total energy-adjusted fat intake.
Voorips, 2002^37^ | | 2 | NR | 0.8 | 0.76 | (0.58, 1.00) | 0.78 | (0.57, 1.05)
| | 3 | NR | 1.0 | 0.92 | (0.71, 1.20) | 1.03 | (0.76, 1.39)
| | 4 | NR | 1.3 | 0.69 | (0.52, 0.91) | 0.74 | (0.54, 1.00)
| | 5 | NR | 1.7 | 0.68 | (0.51, 0.91) | 0.70 | (0.51, 0.97)
| | Total 62,573 | | | | p = 0.001‡ | | p = 0.006‡
EPA
Netherlands Cohort Study | | 1 | NR | 0 g/d | 1 | | 1 | | Age, history of benign breast cancer, breast cancer in one or more sisters, age at menarche, age at menopause, oral contraceptive use, parity, age at first childbirth, Quetelet index, education, alcohol use, current cigarette smoking, total energy intake, total energy-adjusted fat intake.
Voorips, 2002^37^ | | 2 | NR | 0.01 g/d | 1.18 | (0.88, 1.56) | 1.15 | (0.84, 1.58)
| | 3 | NR | 0.02 g/d | 1.14 | (0.87, 1.50) | 1.10 | (0.82, 1.49)
| | 4 | NR | 0.04 g/d | 1.23 | (0.93, 1.62) | 1.22 | (0.90, 1.65)
| | 5 | NR | 0.08 g/d | 1.03 | (0.78, 1.37) | 0.98 | (0.72, 1.35)
| | Total 62,573 | | | | p = 0.63‡ | | p = 0.87‡
DHA
Netherlands Cohort Study | | 1 | NR | 0.01 | 1 | | 1 | | Age, history of benign breast cancer, breast cancer in one or more sisters, age at menarche, age at menopause, oral contraceptive use, parity, age at first childbirth, Quetelet index, education, alcohol use, current cigarette smoking, total energy intake, total energy-adjusted fat intake.
Voorips, 2002^37^ | | 2 | NR | 0.03 | 1.11 | (0.83, 1.47) | 1.10 | (0.81, 1.51)
| | 3 | NR | 0.05 | 1.04 | (0.78, 1.37) | 1.03 | (0.76, 1.40)
| | 4 | NR | 0.08 | 1.20 | (0.91, 1.58) | 1.21 | (0.90, 1.64)
| | 5 | NR | 0.14 | 1.02 | (0.77, 1.36) | 1.00 | (0.72, 1.37)
| | Total 62,573 | | | | p = 0.62‡ | | p = 0.70‡

* NR = Not Reported;

† = Number of people included in analysis;

‡ = test for trend;

§ = incidence rate ratio.

Sub-populations. All analyses were restricted to women of racial groups that were homogeneous within, but that differed across, the studies. The four studies that assessed the association between fish consumption and breast cancer incidence used cohorts from the US (Nurses Health Study), Denmark (Diet Cancer and Health Study), and Norway (Norwegian National Health Cohort). The study that assessed the association between the specific omega-3 FA ALA, DHA and EPA used a cohort of women residing in the Netherlands (Netherlands Cohort Study). The study that assessed the association between total omega-3 FA consumption and breast cancer risk used a cohort of Chinese women residing in Singapore (Singapore Chinese Health Study). In this last study, subgroup analyses revealed that the reduced incidence of breast cancer associated with marine omega-3 FA consumption was confined to postmenopausal women and to women with advanced stage disease (stage II or greater). The Nurses Health Study also compared the effect of marine omega-3 FA on premenopausal and postmenopausal women.^44^ In this study, a small increased risk of breast cancer was seen among postmenopausal women (RR 1.09; 95% CI 1.02, 1.17), but no significant association was seen overall or for premenopausal women (Table 3.7).

Covariates. The effects of covariates on the effect of omega-3 FA on incidence of breast cancer were assessed in four of the studies. In one study, the risk of developing breast cancer associated with fish intake was not affected by family history of breast cancer, multivitamin use, or glycemic load in separate analyses.^43^ In another study, occupational status and BMI did not affect the reported association between fish consumption and breast cancer incidence.^41^

One study examined the relationship between breast cancer incidence, marine omega-3 FA intake, and omega-6 FA intake.^51^ In this study, among subjects in the lowest quartile of marine omega-3 FA consumption, breast cancer risk increased significantly with increasing levels of omega-6 FA consumption (p for trend = 0.08). Relative to women in the lowest quartile of both omega-6 and marine omega-3 consumption, the relative risk of developing breast cancer for women in both the lowest quartile of omega-3 consumption and the highest quartile of omega-6 consumption was 1.87 (95% CI, 1.06, 3.27).

One study examined the relationship between fish intake, estrogen receptor (ER) positivity, and cancer incidence.^55^ In this study, the incidence rate ratio (IRR) for breast cancer per mean intake of 25 g/d of fish was 1.14 (955 CI 1.03, 1.26) for ER-positive women and 1.00 (95% CI 0.81, 1.24) for ER-negative women.

#### Effects of dose, source, and exposure duration

Dose: Each of the studies assessed the effects of dose. No dose effect was observed for fish, total omega-3, DHA, or EPA consumption (Table 3.7). However, dose effects were demonstrated for marine omega-3 FA^51^ and ALA^37^ (p for trend < 0.05).

Source: No effects were observed for fish in two studies.^41,^ ^43^ One study demonstrated a reduced risk for marine omega-3 but not for total omega-3 FA.^51^ One study demonstrated reduced risk for ALA but not EPA or DHA.^37^ (Table 3.7).

Exposure duration: Three of the studies identified assessed exposure at baseline only; the follow-up period in these studies ranged from 2 to 12 years.^37,^ ^41,^ ^51^ These studies did not assess the effect of exposure duration. Two cohorts assessed exposure at multiple time points. The Life Span Study^52^ and Nurses Health Study^43,^ ^44^ collected dietary data at two and four time points, respectively. The Life Span Study found no difference in cancer risk associated with soy products (no association) using dietary data from either dietary survey; this study did not report the effect of exposure duration for fish on the risk of breast cancer. The Nurses Health Study assessed the associations of diet with breast cancer when the diet was assessed only at baseline and also when diet was updated over time without cumulatively averaging in prior intake;^43^ results did not change with these analyses.

Sustainment of effect. None of the studies specifically assessed sustainment of effect.

Quality and applicability. See Table 3.8

Table 3.8 Relationship between methodologic quality and applicability for estimates of effect of omega-3 fatty acid consumption on risk of breast cancer.*

Cohort | Applicability | Quality Parameters
Author, Year | | Adjustment for confounders | Blinding | Valid ascertainment, cases | Valid ascertainment, exposure | Withdrawals and dropouts described
Diet, Cancer and Health Study | II | Yes | NR | Yes | Yes | Yes
Stripp^55^
Life Span Study | III | Yes | NR | Yes | Yes | Yes
Key, 1999^52^
Netherlands Cohort Study | II | Yes | Yes | Yes | Yes | Yes
Voorips, 2002^37^
Norwegian National Health Screening Service Cohort | II | Yes | NR | Yes | Yes | Yes
Vatten, 1990^41^
Nurses' Health Study | II | Yes | Yes | Yes | Yes | Yes
Holmes, 2003^43^
Singapore Chinese Health Study | II | Yes | NR | Yes | Yes | No
Gago-Dominguez, 2003^51^

* NR = Not Reported.

### Colorectal Cancer

Overall effect. We identified six studies^30,^ ^34,^ ^38,^ ^40,^ ^46,^ ^54^ from six different cohorts that evaluated the effect of omega-3 FA on the incidence of colorectal cancer. Colorectal cancer incidence relative to fish consumption was reported in four studies,^30,^ ^38,^ ^40,^ ^46^ incidence relative to total omega-3 fatty acid consumption was reported in one,^34^ and incidence relative to each of the specific omega-3 FA, DHA, EPA and ALA was reported in one.^54^ Among the studies that measured fish consumption, three found no association with the incidence of colorectal cancer;^30,^ ^38,^ ^46^ one study^40^ demonstrated a reduced risk among subjects in the highest quartile of fish intake relative to subjects in the lowest quartile of fish intake (RR 0.49, 95% CI 0.27, 0.89). The one study that measured total omega-3 FA consumption^34^ demonstrated a trend for reducing the risk of colorectal cancer with higher consumption of omega-3 FA when adjusting only for age. However, with adjustment for multiple variables no significant association was observed between omega-3 fatty acid consumption and the incidence of colorectal cancer. No significant association with the incidence of colorectal cancer was found with ALA, DHA, or EPA consumption^54^ (Table 3.9).

Table 3.9 Risk of colorectal cancer for different categories of consumption of omega-3 FA, by category.*

Cohort | | Study arm (quartile, quintile or dose group) | n† | Median intake | Estimates of effect
Author, Year | | | | | Age adjusted RR (95% CI) | | Multivariate RR (95% CI) | | Multivariate Adjustors
FISH
Health Professionals Follow-up Study | | 1 | NR | 8.4 g/d | 1 | | NR | | NR
Giovannucci, 1994^30^ | | 2 | NR | 20.9 g/d | 0.85 | (0.54, 1.33) | NR
| | 3 | NR | 31.0 g/d | 1.05 | (0.68, 1.61) | NR
| | 4 | NR | 47.8 g/d | 0.80 | (0.51, 1.26) | NR
| | 5 | NR | 83.4 g/d | 1.06 | (0.70, 1.60) | NR
| | Total 47,949 | | | | p = 0.79‡
Netherlands Cohort Study | | 1 | NR | 0 g/d | NR | | 1 | | Age and energy.
Goldbohm, 1994^38^ | | 2 | NR | 0–10 g/d | NR | | 1 | (0.68, 1.47)
| | 3 | NR | 10–20 g/d | NR | | 0.74 | (0.48, 1.15)
| | 4 | NR | > 20 g/d | NR | | 0.81 | (0.56, 1.17)
| | Total 3,111 | | | | | | p = 0.14‡
Nurses' Health Study | | 1 | NR | < 1 g/month | 1 | | NR | | NR
Willett, 1990^46^ | | 2 | NR | 1–3 g/month | 1.29 | (0.70, 2.40) | NR
| | 3 | NR | 1 g/week | 0.92 | (0.49, 1.72) | NR
| | 4 | NR | 2–4 g/week | 0.75 | (0.35, 1.58) | NR
| | 5 | NR | 4 g/week | 1.06 | (0.36, 3.12) | NR
| | Total 88,751 | | | | p = 0.09‡
New York University Women's Health Study | | 1 | NR | NR | NR | | 1 | | Age, total calorie, place at enrollment and highest level of education.
Kato, 1997^40^ | | 2 | NR | NR | NR | | 1.01 | (0.62, 1.67)
| | 3 | NR | NR | NR | | 0.65 | (0.37, 1.13)
| | 4 | NR | NR | NR | | 0.49 | (0.27, 0.89)
| | Total 14,727 | | | | | | p = 0.007‡
Omega-3
Iowa Women's Health Study | | 1 | NR | < 0.03 g/day | 1 | | 1 | | Age, total energy intake, height, parity, total vitamin E, a total vitamin E by age interaction term, vitamin A supplement intake.
Bostick, 1994^34^ | | 2 | NR | 0.03–0.05 g/day | 0.67 | NR | 0.82 | (0.55, 1.24)
| | 3 | NR | 0.06–0.10 g/day | 0.61 | NR | 0.77 | (0.50, 1.17)
| | 4 | NR | 0.11–0.18 g/day | 0.72 | NR | 0.96 | (0.64, 1.43)
| | 5 | NR | > 0.18 g/day | 0.60 | NR | 0.70 | (0.45, 1.09)
| | Total 35,215 | | | p = 0.04‡ | | | p = 0.26‡
ALA
Swedish women in mammography-screening program | Colorectal | 1 | NR | 0.45 g/d | NR | | 1 | | Age, BMI, education level, energy intake, intakes of red meat and alcohol, energy, dietary fiber, calcium, vitamin C, folic acid, Vitamin D, saturated fat, monounsaturated fat, polyunsaturated fat.
Terry, 2001^54^ | | 2 | NR | 0.50 g/d | NR | | 0.96 | (0.73, 1.27)
| | 3 | NR | 0.54 g/d | NR | | 0.96 | (0.72, 1.28)
| | 4 | NR | 0.70 g/d | NR | | 0.99 | (0.75, 1.32)
| | Total 61,463 | | | | | | p = 0.99‡
| Colon | 1 | NR | 0.45 g/d | NR | | 1
| | 2 | NR | 0.50 g/d | NR | | 0.96 | (0.68, 1.35)
| | 3 | NR | 0.54 g/d | NR | | 0.96 | (0.67, 1.3)
| | 4 | NR | 0.70 g/d | NR | | 0.90 | (0.63, 1.28)
| | Total 61,463 | | | | | | p = 0.57‡
| Rectal | 1 | NR | 0.45 g/d | NR | | 1
| | 2 | NR | 0.50 g/d | NR | | 0.95 | (0.60, 1.52)
| | 3 | NR | 0.54 g/d | NR | | 0.92 | (0.56, 1.49)
| | 4 | NR | 0.70 g/d | NR | | 1.11 | (0.70, 1.78)
| | Total 61,463
EPA
Swedish women in mammography-screening program | Colorectal | 1 | NR | 0.03 g/d | NR | | 1 | | Age, BMI, education level, energy intake, intakes of red meat and alcohol, energy, dietary fiber, calcium, vitamin C, folic acid, Vitamin D, saturated fat, monounsaturated fat, polyunsaturated fat.
Terry, 2001^54^ | | 2 | NR | 0.05 g/d | NR | | 0.80 | (0.68, 1.15)
| | 3 | NR | 0.07 g/d | NR | | 0.96 | (0.73, 1.26)
| | 4 | NR | 0.09 g/d | NR | | 0.96 | (0.72, 1.28)
| | Total 61,463 | | | | | | p = 0.91‡
| Colon | 1 | NR | 0.03 g/d | NR | | 1
| | 2 | NR | 0.05 g/d | NR | | 0.76 | (0.54, 1.06)
| | 3 | NR | 0.07 g/d | NR | | 0.81 | (0.58, 1.15)
| | 4 | NR | 0.09 g/d | NR | | 0.85 | (0.60, 1.21)
| | Total 61,463 | | | | | | p = 0.46‡
| Rectal | 1 | NR | 0.03 g/d | NR | | 1
| | 2 | NR | 0.05 g/d | NR | | 1.17 | (0.75, 1.83)
| | 3 | NR | 0.07 g/d | NR | | 1.29 | (0.80, 2.06)
| | 4 | NR | 0.09 g/d | NR | | 1.25 | (0.75, 2.06)
| | Total 61,463 | | | | | | p = 0.35‡
DHA
Swedish women in mammography-screening program | Colorectal | 1 | NR | 0.08 g/d | NR | | 1 | | Age, BMI, education level, energy intake, intakes of red meat and alcohol, energy, dietary fiber, calcium, vitamin C, folic acid, Vitamin D, saturated fat, monounsaturated fat, polyunsaturated fat.
Terry, 2001^54^ | | 2 | NR | 0.11 g/d | NR | | 0.88 | (0.67, 1.15)
| | 3 | NR | 0.13 g/d | NR | | 0.87 | (0.66, 1.15)
| | 4 | NR | 0.18 g/d | NR | | 0.90 | (0.67, 1.20)
| | Total 61,463 | | | | | | p = 0.52‡
| Colon | 1 | NR | 0.08 g/d | NR | | 1
| | 2 | NR | 0.11 g/d | NR | | 0.84 | (0.60, 1.17)
| | 3 | NR | 0.13 g/d | NR | | 0.74 | (0.51, 1.06)
| | 4 | NR | 0.18 g/d | NR | | 0.88 | (0.61, 1.26)
| | Total 61,463 | | | | | | p = 0.41‡
| Rectal | 1 | NR | 0.08 g/d | NR | | 1
| | 2 | NR | 0.11 g/d | NR | | 1.03 | (0.66, 1.61)
| | 3 | NR | 0.13 g/d | NR | | 1.16 | (0.73, 1.8)
| | 4 | NR | 0.18 g/d | NR | | 1.03 | (0.62, 1.71)
| | Total 61,463 | | | | | | P=0.79‡

* NR = Not Reported;

† Number of people included in analysis;

‡ = test for trend.

Sub-populations. Three of the studies were among cohorts of women,^34,^ ^40,^ ^46^ one among a cohort of men,^30^ and two among cohorts that included both men and women.^38,^ ^54^ Among the latter, one study performed subgroup analyses among men and women and found no association between fish consumption and colon cancer for men or women.^38^ The one study that demonstrated a favorable association between a source of omega-3 FA and incidence of colorectal cancer after adjustment for multiple variables was performed in a cohort of women.^40^

Three of the studies assessed the incidence of colon cancer only^34,^ ^38,^ ^46^ and three assessed the incidence of colorectal cancer including cancers of the colon or rectum.^30,^ ^40,^ ^54^ In the one study that assessed the incidence of colon cancer, rectal cancer, and colorectal cancer,^54^ there was no difference in the association between ALA, EPA, or DHA intake and the incidence of any of these types of cancer, i.e., there was no association in any case. The one study that demonstrated a favorable association between a source of omega-3 FA and incidence of colorectal cancer after adjustment for multiple variables included both cancers of the colon and rectum to define colorectal cancer.^40^

Covariates. Although each of the studies performed multivariable analyses, the effects of specific covariates were not reported.

#### Effects of dose, source, and exposure duration

Dose: Each of the studies assessed the effects of dose. The one study^40^ that demonstrated a reduced risk of colorectal cancer among subjects in the highest quartile of fish intake relative to subjects in the lowest quartile of fish intake also reported a significant test for trend across all quartiles (p = 0.007). However, comparisons of cancer incidence between the first quartile and each of the second and third quartiles of fish intake did not yield significant results. One additional study^34^ demonstrated a trend for reducing the risk of colorectal cancer with higher consumption of omega-3 FA, when adjusting only for age. However, there was no significant dose effect with adjustment for multiple variables. None of the other studies demonstrated a dose effect.^30,^ ^38,^ ^46,^ ^54^

Source: One study demonstrated a reduced risk for fish;^40^ three did not.^30,^ ^38,^ ^46^ One study demonstrated a reduced risk for omega-3 FA consumption that was not significant after adjustment for multiple variables.^34^ One study assessed the effects of different types of omega-3 FA on the incidence of colorectal cancer and found no association with ALA, DHA, or EPA consumption.^54^

Exposure duration: Four of the studies assessed exposure at baseline only,^34,^ ^38,^ ^40,^ ^54^ and two assessed exposure at multiple time points. However, none specifically assessed the effect of exposure duration on the incidence of colorectal cancer.

Sustainment of Effect. None of the studies specifically assessed sustainment of effect.

Quality and applicability. See Table 3.10

Table 3.10 Relationship between methodologic quality and applicability for estimates of effect of omega-3 fatty acid consumption on risk of colorectal cancer.*

Cohort | Applicability | Quality Parameters
Author, Year | | Adjustment for confounders | Blinding | Valid ascertainment, cases | Valid ascertainment, exposure | Withdrawals and dropouts described
Health Professionals Follow-up Study | II | Yes | Yes | Yes | Yes | Yes
Giovannucci, 1994^30^
Netherlands Cohort Study | II | Yes | NR | Yes | Yes | No
Goldbohm, 1994^38^
Nurses' Health Study | II | Yes | Yes | Yes | Yes | Yes
Willett, 1990^46^
New York University Women's Health Study | III | Yes | NR | Yes | Yes | Yes
Kato, 1997^40^
Iowa Women's Health Study | II | Yes | NR | Yes | Yes | Yes
Bostick, 1994^34^
Swedish women in mammography-screening program | II | Yes | No | Yes | Yes | NR
Terry, 2001^54^

* NR = Not Reported.

### Lung Cancer

Overall effect. We identified three studies^24,^ ^42,^ ^56^ from three different cohorts that evaluated the effect of omega-3 FA on the incidence of lung cancer and one that evaluated the effect of omega-3 FA intake on death from lung cancer.^36^ All of these studies assessed lung cancer incidence relative to fish consumption (Table 3.11). In one study,^24^ fish consumption was associated with a reduced risk of lung cancer (RR 0.32, 95% CI 0.13, 0.76). In the other studies, no significant association was found between fish intake and lung cancer incidence^42,^ ^56^ or death from lung cancer.^36^

Table 3.11 Risk of lung cancer for different categories of consumption of omega-3 FA, by category.*

Cohort | | Study arm (quartile, quintile or dose group) | n† | Median intake | Estimates of effect
Author, Year | | | | | Age adjusted RR (95% CI) | Multivariate RR (95% CI) | | Multivariate Adjustors
FISH
Aichi Prefecture Cohort, Japan | | 1 | 174 | < 1 times/week | NR | 1 | | Age, sex, smoke, occupation.
Takezaki, 2003^24^ | | 2 | 1,264 | 1–2 times/week | NR | 0.99 | (0.48, 2.03)
| | 3 | 1,360 | ≥ 3 times/week | NR | 0.32 | (0.13, 0.76)
| | Total 5,885 | | | | | p = 0.003‡
Japan Collaborative Cohort | Men | 1 | NR | ≤ 1–2 times/week | NR | 1§ | | Age, parent's history of lung cancer, smoking status, smoking index and time since quitting smoking.
Ozasa, 2001^36^ | | 2 | NR | 3–4 times/week | NR | 1.12§ | (0.87, 1.43)
| | 3 | NR | almost every day | NR | 1.03§ | (0.79, 1.34)
| | Total 42,940 | | | | | p = 0.72‡
| Women | 1 | NR | ≤ 1–2 times/week | NR | 1
| | 2 | NR | 3–4 times/week | NR | 0.73 | (0.45, 1.21)
| | 3 | NR | almost every day | NR | 0.88 | (0.52, 1.49)
| | Total 55,308 | | | | | | p = 0.50‡
Norwegian Cohorts | Histologic verification | 1 | NR | < 10 times/month | NR | 1 | | Age, cigarette smoking, region and urban/rural place of residence.
Kvale, 1983^56^ | | 2 | NR | 10–14 times/month | NR | NR
| | 3 | NR | 15–19 times/month | NR | NR
| | 4 | NR | ≥ 20 times/month | NR | 0.82 | NR
| | Total 13785 | | | | | | p = 0.63‡
| Squamous and small-cell carcinomas | 1 | NR | < 10 times/month | NR | 1
| | 2 | NR | 10–14 times/month | NR | NR
| | 3 | NR | 15–19 times/month | NR | NR
| | 4 | NR | ≥ 20 times/month | NR | 0.98 | NR
| | Total 13785 | | | | | | p = 0.99‡
Norwegian National Health Screening Service Cohort | | 1 | NR | <1 times/week | | 1§ | | Smoking status, gender, age at inclusion, attained age.
Veierod, 1997^42^ | | 2 | NR | 1–2 times/week | | 1.1\|\| | (0.6, 2.2)
| | 3 | NR | 3–4 times/week | | 1.0\|\| | (0.5, 2.1)
| | 4 | NR | ≥ 5 times/week | | 3.0\|\| | (1.2, 7.3)
| | Total 51,452 | | | | | | p = 0.2‡

* NR = Not Reported;

† Number of people included in analysis;

‡ = test for trend;

§ Hazard Ratio;

|| Incidence Rate Ratio.

Sub-populations. Each of the cohorts was population-based and included men and women. The base population comprised residents of a single rural prefecture in Japan in one study,^24^ 19 Japanese prefectures in another study,^36^ and people residing in Norway in the other two.^42,^ ^56^ One study reported the risk of dying from lung cancer stratified by gender.^36^ This study found no significant association between fish consumption and death from lung cancer for either men or women (Table 3.11).

Covariates. The effects of different methods of cooking fish on the incidence of lung cancer were assessed in one study.^24^ Consumption of fish that had been broiled or boiled was associated with reduced risk for lung cancer (p values for trend < 0.02). No significant reduction in risk of lung cancer was found for consumption of fish that was raw or deep-fried.

#### Effects of dose, source, and exposure duration

Dose: Three of the studies assessed the effects of dose.^24,^ ^36,^ ^42^ The study that reported a reduced risk of lung cancer with fish consumption, also reported a dose effect.^24^ Subjects in each the middle and high consumption categories had a lower risk relative to subjects in the lowest category of consumption and the risk decreased with higher consumption (p for trend = 0.003). No overall or dose effect was observed in the other studies.^24,^ ^42^

Source: The source of omega-3 fatty acid was fish in each of the studies.

Exposure duration: Each of the studies assessed fish consumption at baseline only; the follow-up period in these studies ranged from 8 to 14 years. None of the studies assessed the effect of exposure duration.

Sustainment of effect. Neither of the studies specifically assessed sustainment of effect.

Quality and applicability. See Table 3.12.

Table 3.12 Relationship between methodologic quality and applicability for estimates of omega-3 fatty acid consumption on risk of lung cancer.*

Cohort | Applicability | Quality Parameters
Author, Year | | Adjustment for confounders | Blinding | Valid ascertainment, cases | Valid ascertainment, exposure | Withdrawals and dropouts described
Aichi Prefecture Cohort, Japan | II | Yes | NR | Yes | Yes | NR
Takezaki, 2003^24^
Japan Collaborative Cohort | II | Yes | NR | Yes | Yes | Yes
Ozasa, 2001^36^
Norwegian Cohorts | II | Yes | NR | Yes | Yes | Yes
Kvale, 1983^56^
Norwegian National Health Screening Service Cohort | II | Yes | NR | Yes | Yes | Yes
Veierod, 1997^42^

* NR = Not Reported.

### Lymphoma

Overall effect. We identified two studies from two different cohorts that evaluated the effect of omega-3 FA on the incidence of non-Hodgkin's lymphoma.^35,^ ^47^ One study assessed incidence relative to fish consumption, the other relative to marine omega-3 fat consumption. Neither study found a significant association between fish intake and the incidence of non-Hodgkin's lymphoma (Table 3.13).

Table 3.13 Risk of non-hodgkin's lymphoma for different categories of consumption of omega-3 FA, by category.*

Cohort | Study arm (quartile, quintile or dose group) | n† | Median intake | Estimates of effect
Author, Year | | | | Age adjusted RR (95% CI) | | Multivariate RR (95% CI) | | Multivariate Adjustors
FISH
Iowa Women's Health Study | 1 | NR | < 4 servings/ month | NR | | 1 | | Age and energy.
Chiu, 1996^35^ | 2 | NR | 4–6 servings/ month | NR | | 0.94 | (0.59, 1.49)
| 3 | NR | > 6 servings/month | NR | | 0.81 | (0.49, 1.35
| Total 35,136 | | | | | | p = 0.42‡
Omega-3
Nurses' Health Study | 1 | NR | 0.02 % of energy intake | 1 | | 1 | | Age, total energy, length of follow-up, geographic region, cigarette smoke, height in inches, saturated and trans unsaturated fats, fruit, vegetable intake.
Zhang, 1999^47^ | 2 | NR | 0.03 % of energy intake | 1.2 | NR | 1.2 | NR
| 3 | NR | 0.04% of energy intake | 1.3 | NR | 1.4 | NR
| 4 | NR | 0.05% of energy intake | 1.1 | NR | 1.2 | NR
| 5 | NR | 0.10% of energy intake | 1.1 | (0.7, 1.7) | 1.4 | (0.8, 2.2)
| Total 88,410 | | | | p = 0.90‡ | | Testing NR

* NR = Not Reported;

† Number of people included in analysis;

‡ = test for trend.

Sub-populations. Both cohorts were restricted to women. The Nurses Health Study cohort includes U.S. female registered nurses who responded to a mailed questionnaire.^47^ The Iowa Women's Health Study cohort includes women who had valid Iowa driver's licenses at the time of recruitment. Analyses on subpopulations were not reported in either study.

Covariates. The effects of covariates on risk associated with omega-3 FA were not reported.

#### Effects of dose, source, and exposure duration

Dose: Both studies assessed the risk of developing non-Hodgkin's lymphoma given different levels of fish or omega-3 fat consumption and found no dose effect (p for trend > 0.40 for all comparisons).

Source: The source of omega-3 fatty acid was fish in one study^35^ and marine omega-3 FA in the other.^47^

Exposure duration: Each of the studies assessed fish consumption at baseline only; the follow-up period in these studies ranged from 6 to 14 years. Neither study assessed the effect of exposure duration to omega-3 FA on risk of non-Hodgkin's lymphoma.

Sustainment of effect. Neither of the studies specifically assessed sustainment of effect.

Quality and applicability. See Table 3.14.

Table 3.14 Relationship between methodologic quality and applicability for estimates of effect of omega-3 fatty acid consumption on risk of non-Hodgkin's lymphoma.*

Cohort | Applicability | Quality Parameters
Author, Year | | Adjustment for confounders | Blinding | Valid ascertainment, cases | Valid ascertainment, exposure | Withdrawals and dropouts described
Iowa Women's Health Study | II | Yes | NR | Yes | Yes | Yes
Chiu, 1996^35^
Nurses' Health Study | II | Yes | Yes | Yes | Yes | Yes
Zhang, 1999^47^

* NR = Not Reported.

### Ovarian Cancer

Overall Effect. We identified one report^48^ that evaluated the effect of different kinds of fat, including the omega-3 FA DHA, EPA, and ALA, on the incidence of ovarian cancer among women enrolled in the Nurses Health Study. This study found no evidence of an association between intake of any type of fat, including DHA, EPA, and ALA, and the incidence of ovarian cancer (Table 3.15). Secondary analyses showed that total fat intake (i.e., different levels of total fat intake) had no effect on the development of specific subtypes of ovarian cancer (serous, mucinous, and endometrial tumors). However, these analyses were not conducted for omega-3 FA specifically.

Table 3.15 Risk of ovarian cancer for different categories of consumption of omega-3 FA, by category.*

Cohort | Study arm (quartile, quintile or dose group) | n† | Median intake | Estimates of effect
Author, Year | | | | Age adjusted RR (95% CI) | | Multivariate RR (95% CI) | | Multivariate Adjustors
ALA
Nurses' Health Study | 1 | NR | NR | 1.0 | | 1.0 | | Age, parity, age at menarche, oral contraceptive use and duration, menopausal status/postmenopausal hormone use, smoking status.
Bertone, 2002^48^ | 2 | NR | NR | 0.74 | NR | 0.95 | (0.68, 1.33)
| 3 | NR | NR | 0.62 | NR | 0.8 | (0.56, 1.14)
| 4 | NR | NR | 0.86 | NR | 0.82 | (0.58, 1.15)
| 5 | NR | NR | 0.98 | NR | 0.88 | (0.62, 1.24)
| Total 80,258 | | | | | | p = 0.27‡
EPA
Nurses' Health Study | 1 | NR | NR | 1 | | 1 | | Age, parity, age at menarche, oral contraceptive use and duration, menopausal status/postmenopausal hormone use, smoking status.
Bertone, 2002^48^ | 2 | NR | NR | 1.01 | NR | 1.04 | (0.68, 1.59)
| 3 | NR | NR | 0.73 | NR | 0.75 | (0.47, 1.17)
| 4 | NR | NR | 0.96 | NR | 1.00 | (0.66, 1.52)
| 5 | NR | NR | 0.96 | NR | 0.97 | (0.64, 1.48)
| Total 80,258 | | | | | | p = 0.80‡
DHA
Nurses' Health Study | 1 | NR | NR | 1 | | 1 | | Age, parity, age at menarche, oral contraceptive use and duration, menopausal status/postmenopausal hormone use, smoking status.
Bertone, 2002^48^ | 2 | NR | NR | 1.06 | NR | 1.06 | (0.70, 1.61)
| 3 | NR | NR | 0.67 | NR | 0.67 | (0.42, 1.08)
| 4 | NR | NR | 1.05 | NR | 1.07 | (0.71, 1.63)
| 5 | NR | NR | 0.88 | NR | 0.86 | (0.55, 1.33)
| Total 80,258 | | | | | | p = 0.52‡

* NR = Not Reported;

† Number of people included in analysis;

‡ = test for trend.

Sub-populations. The subjects in this study were all female registered nurses in the US. The effect of total fat intake, but not omega-3 FA intake was assessed for several different subpopulations. The relation between fat intake and ovarian cancer risk (i.e., no association) did not differ substantially by age or menopausal status.

Covariates. The effects of several covariates on the effect of total fat intake but not omega-3 fat were assessed. Neither body mass index, oral contraceptive use, smoking status, nor physical activity level had an effect on the relation between fat intake and ovarian cancer.

#### Effects of dose, source, and exposure duration

Dose: No dose effect was observed for ALA, DHA, or EPA consumption (Table 3.15).

Source: The effects of source were not specifically assessed.

Exposure duration: This study assessed dietary intake at four time points. Analyses that excluded cases diagnoses during the first 2 and 4 years of follow-up did not differ in their findings from analyses including all cases.

Sustainment of effect. Sustainment of effect was not assessed.

Quality and applicability. See Table 3.16.

Table 3.16 Relationship between methodologic quality and applicability for estimates of effect of omega-3 fatty acid consumption on risk of ovarian cancer

Cohort Author, Year | Applicability | Quality Parameters
| | Adjustment for confounders | Blinding | Valid ascertainment, cases | Valid ascertainment, exposure | Withdrawals and dropouts described
Nurses' Health Study | II | Yes | Yes | Yes | Yes | Yes
Bertone, 2002^48^

### Pancreatic Cancer

Overall Effect. We identified two studies^25,^ ^49^ from two different cohorts that evaluated the effect of omega-3 FA on the incidence of pancreatic cancer. One study assessed incidence relative to fish, omega-3 FA, and ALA consumption;^25^ the other assessed incidence relative to ALA consumption.^49^ There was no significant association between fish intake and any of these measures of omega-3 FA in either study (Table 3.17).

Table 3.17 Risk of pancreatic cancer for different categories of consumption of omega-3 FA, by category.*

Cohort | Study arm (quartile, quintile or dose group) | n† | Median intake | Estimates of effect
Author, Year | | | | Age adjusted RR (95% CI) | Multivariate RR (95% CI) | | Multivariate Adjustors
Fish
Alpha-tocopherol, Beta-Carotene Cancer Prevention Study | 1 | NR | NR | NR | 1 | | Energy intake by the residual method, age, and years of smoking, energy-adjusted saturated fat intake.
Stolzenberg-Solomon, 2002^25^ | 2 | NR | NR | NR | 1.22 | (0.75, 1.97)
| 3 | NR | NR | NR | 1.14 | (0.70, 1.86)
| 4 | NR | NR | NR | 1.07 | (0.65, 1.76)
| 5 | NR | NR | NR | 0.91 | (0.54, 1.52)
| Total 27,111 | | | | | p = 0.59‡
Omega-3
Alpha-tocopherol, Beta-Carotene Cancer Prevention Study | 1 | NR | NR | NR | 1 | | Energy intake by the residual method, age, and years of smoking.
Stolzenberg-Solomon, 2002^25^ | 2 | NR | NR | NR | 0.97 | (0.60, 1.60)
| 3 | NR | NR | NR | 1.04 | (0.64, 1.69)
| 4 | NR | NR | NR | 1.16 | (0.72, 1.86)
| 5 | NR | NR | NR | 0.96 | (0.58, 1.58)
| Total 27,111 | | | | | p = 0.90‡
ALA
Nurses' Health Study | 1 | NR | 0.7 g/d | 1 | 1 | | Pack-years of smoking, BMI, history of diabetes mellitus, caloric intake, height, physical activity, menopausal status, glycemic load intake.
Michaud, 2003^49^ | 2 | NR | 0.8 g/d | 1.03 | 1.08 | (0.70, 1.67)
| 3 | NR | 0.9 g/d | 1 | 1.03 | (0.66, 1.61)
| 4 | NR | 1.0 g/d | 0.75 | 0.80 | (0.49, 1.30)
| 5 | NR | 1.1 g/d | 0.76 | 0.77 | (0.47, 1.26)
| Total 88,802 | | | p = 0.12‡ | | p = 0.16‡
Alpha-tocopherol, Beta-Carotene Cancer Prevention Study | 1 | NR | NR | NR | 1 | | Energy intake by the residual method, age, and years of smoking, energy-adjusted saturated fat intake.
Stolzenberg-Solomon, 2002^25^ | 2 | NR | NR | NR | 1.09 | (0.69, 1.73)
| 3 | NR | NR | NR | 1.10 | (0.68, 1.79)
| 4 | NR | NR | NR | 1.04 | (0.61, 1.77)
| 5 | NR | NR | NR | 1.11 | (0.65, 1.91)
| Total 27,111 | | | | | p = 0.77‡

* NR = Not Reported;

† Number of people included in analysis;

‡ = test for trend.

Sub-populations. One cohort comprised women, the other men. The Nurses Health Study cohort includes U.S. female registered nurses who responded to a mailed questionnaire.^49^ The Alpha-tocopherol, Beta-Carotene Cancer Prevention Study cohort includes male smokers. Analyses of the relationship between omega-3 FA and pancreatic cancer risk for subpopulations were not reported in either study.

Covariates. The effects of covariates on risk associated with omega-3 FA were not reported.

#### Effects of dose, source, and exposure duration

Dose: Both studies assessed the risk of developing pancreatic cancer given different levels of fish or omega-3 FA consumption and found no dose effect (p for trend > 0.10 for all comparisons).

Source: One study assessed incidence relative to fish, omega-3 FA and ALA consumption;^25^ the other assessed incidence relative to ALA consumption.^49^

Exposure duration: One study assessed fish consumption at baseline only.^25^ The other study^49^ assessed dietary intake at four time points but did not report the effect of the duration of exposure to omega-3 FA and pancreatic cancer.

Sustainment of effect. Neither of the studies specifically assessed sustainment of effect.

Quality and applicability. See Table 3.18.

Table 3.18 Relationship between methodologic quality and applicability for estimates of effect of omega-3 fatty acid consumption on risk of pancreatic cancer.*

Cohort | Applicability | Quality Parameters
Author, Year | | Adjustment for confounders | Blinding | Valid ascertainment, cases | Valid ascertainment, exposure | Withdrawals and dropouts described
Alpha-tocopherol, Beta-Carotene Cancer Prevention Study | III | Yes | NR | Yes | Yes | Yes
Stolzenberg-Solomon, 2002^25^
Nurses' Health Study | II | Yes | Yes | Yes | Yes | Yes
Michaud, 2003^49^

* NR = Not Reported.

### Prostate Cancer

Overall effect. We identified seven studies^27–29,^ ^39,^ ^50,^ ^53,^ ^57^ from five different cohorts that evaluated the effect of omega-3 FA on the incidence of prostate cancer. Prostate cancer incidence relative to fish consumption was reported in four studies,^27,^ ^28,^ ^50,^ ^53^ relative to marine omega-3 fatty acid consumption in one,^29^ relative to the specific omega-3 FA DHA and EPA in two, ^39,^ ^57^ and relative to the specific omega-3 fatty acid ALA in three.^29,^ ^39,^ ^57^ Among the four studies that assessed risk relative to fish consumption, one demonstrated a favorable effect^53^ and one an unfavorable effect.^50^ For ALA, there was no association with overall prostate cancer risk in two studies.^29,^ ^39,^ ^57^ However, one of these studies demonstrated increased risk for advanced prostate cancer;^57^ the other did not.^39^ No significant association with the incidence of prostate cancer was found with marine omega-3 fats, DHA, or EPA consumption (Table 3.19).

Table 3.19 Risk of prostate cancer for different categories of consumption of omega-3 FA, by category.*

Cohort | Study arm (quartile, quintile or dose group) | n† | Median intake | Estimates of effect
Author, Year | | | | Age adjusted RR (95%CI) | | Multivariate RR (95% CI) | | Multivariate Adjustors
Fish
Hawaii Health Surveillance Program | 1 | NR | NR | NR | | 1 | | Age, race, income.
LeMarchand, 1994^27^ | 2 | NR | NR | NR | | 1.1 | (0.7, 1.7)
| 3 | NR | NR | NR | | 0.9 | (0.6, 1.3)
| 4 | NR | NR | NR | | 1.2 | (0.8, 1.8)
| Total 8,881 | | | | | | p = 0.55‡
Health Professionals Follow-up Study | 1 | NR | < 2 times/month | 1 | | 1 | | Age, calories, fatty acid, lycopene, retinol, vitamin D and physical activity.
Augustsson, 2003^28^ | 2 | NR | 2 times/month-1 time/week | 1.06 | (0.92, 1.22) | 1.05 | (0.91, 1.21)
| 3 | NR | 2–3 times/week | 1.06 | (0.94, 1.20) | 1.06 | (0.93, 1.20)
| 4 | NR | > 3 times/week | 0.91 | (0.79, 1.05) | 0.93 | (0.80, 1.08)
| Total 47,882
Seventh-day | 1 | NR | Never | 1 | | NR | | NR
Adventist Mills, 1989^50^ | 2 | NR | < 1 g/week | 1.68 | (1.16, 2.43) | NR
| 3 | NR | ≥ 1 g/week | 1.47 | (0.84, 2.60) | NR
| Total 14,000 | | | | p = 0.03‡
Swedish Twin | 1 | NR | Never/ seldom | 1.7 | (1.0, 3.0) | 2.3 | (1.2, 4.5) | Age, BMI, physical activity, smoking, consumption of alcohol, red meat, processed meat, fruit, vegetable and milk.
Registry Terry, 2001^53^ | 2 | NR | Small | 1.1 | (0.9, 1.3) | 1.2 | (1.0, 1.4)
| 3 | NR | Moderate | 1 | | 1
| 4 | NR | Large | 1.1 | (0.8, 1.5) | 1.0 | (0.7, 1.6)
| Total 6,272 | | | | p = 0.35‡ | | p = 0.05‡
Marine Omega-3
Health Professionals Follow-up Study | 1 | NR | 0.05 g/d | 1 | | NR | | NR
Giovannucci, 1993^29^ | 2 | NR | 0.12 g/d | 1.34 | (0.78, 2.30) | NR
| 3 | NR | 0.21 g/d | 1.05 | (0.59, 1.89) | NR
| 4 | NR | 0.30 g/d | 0.92 | (0.51, 1.65) | NR
| 5 | NR | 0.55 g/d | 0.90 | (0.51, 1.61) | NR
| Total 47,855 | | | | p = 0.30‡
ALA
Health Professionals Follow-up Study | 1 | NR | <0.37% of energy | 1.0 | | 1.0 | | Age, time period, major ancestry, family history of prostate cancer, BMI at age 21, height, type 2 diabetes, vasectomy, cigarettes in past decade, vigorous physical activity, intake of total energy, % energy from protein, % energy from monounsaturated fat, % energy from saturated fat, % energy from trans unsaturated fats, and intakes of calcium, supplemental vitamin E and lycopene.
Leitzmann, 2004§^57^ | 2 | NR | 0.37–0.43% of energy | 1.08 | NR | 1.04 | (0.89, 1.22)
Prostate cancer excluding stage A-1 | 3 | NR | 0.44–0.49% of energy | 1.12 | NR | 1.05 | (0.89, 1.25)
| 4 | NR | 0.50–0.58% of energy | 1.24 | NR | 1.16 | (0.97, 1.39)
| 5 | NR | >0.58% of energy | 1.11 | NR | 1.04 | (0.85, 1.27)
| Total 47,866 | | | p = 0.10† | | p = 0.10†
Health Professionals Follow-up Study | 1 | NR | <0.37% of energy | 1.0 | | 1.0
Leitzmann, 2004§^57^ | 2 | NR | 0.37–0.43% of energy | 1.33 | NR | 1.47 | (1.07, 2.01)
Advanced prostate cancer | 3 | NR | 0.44–0.49% of energy | 1.41 | NR | 1.57 | (1.12, 2.21)
| 4 | NR | 0.50–0.58% of energy | 1.53 | NR | 1.77 | (1.24, 2.53)
| 5 | NR | >0.58% of energy | 1.69 | NR | 1.98 | (1.34, 2.93)
| Total 47,866 | | | p = 0.0005‡ | | p = 0.0005†
Netherlands Cohort Study | 1 | NR | 0.7 g/d | 1 | | 1 | | Age, family history of prostate carcinoma, socioeconomic status, total energy intake, total energy-adjusted fat intake.
Schuurman, 1999^39^ | 2 | NR | 1.1 g/d | 0.80 | (0.59, 1..08) | 0.76 | (0.55, 1.05)
| 3 | NR | 1.3 g/d | 0.82 | (0.61, 1.11) | 0.82 | (0.60, 1.13)
| 4 | NR | 1.7 g/d | 0.80 | (0.59, 1.08) | 0.80 | (0.59, 1.10)
| 5 | NR | 2.1 g/d | 0.76 | (0.56, 1.03) | 0.76 | (0.66, 1.04)
| Total 58,279 | | | p = 0.04‡ | | | p = 0.09‡
EPA
Health Professionals Follow-up Study | 1 | NR | <0.014% of energy | 1.0 | | 1.0 | | Age, time period, major ancestry, family history of prostate cancer, BMI at age 21, height, type 2 diabetes, vasectomy, cigarettes in past decade, vigorous physical activity, intake of total energy, % energy from protein, % energy from monounsaturated fat, % energy from saturated fat, % energy from trans unsaturated fats, and intakes of calcium, supplemental vitamin E and lycopene.
Leitzmann, 2004^57^ | 2 | NR | 0.014–0.027% of energy | 1.14 | NR | 1.09 | (0.93, 1.28)
Prostate cancer excluding stage A-1 | 3 | NR | 0.028–0.042% of energy | 1.06 | NR | 1.02 | (0.87, 1.21)
| 4 | NR | 0.043–0.066% of energy | 1.03 | NR | 0.97 | (0.81, 1.15)
| 5 | NR | >0.066% of energy | 0.92 | NR | 0.87 | (0.72, 1.06)
| Total 47,866 | | | | p = 0.04† | | p = 0.03†
Health Professionals Follow-up Study | 1 | NR | <0.014% of energy | 1.0 | | 1.0
Leitzmann, 2004^57^ | 2 | NR | 0.014–0.027% of energy | 1.01 | NR | 1.05 | (0.75, 1.37)
Advanced prostate cancer | 3 | NR | 0.028–0.042% of energy | 1.03 | NR | 0.99 | (0.73, 1.35)
| 4 | NR | 0.043–0.066% of energy | 0.89 | NR | 0.87 | (0.63, 1.21)
| 5 | NR | >0.066% of energy | 0.82 | NR | 0.82 | (0.58, 1.17)
| Total 47,866 | | | | p = 0.08† | | p = 0.18†
Netherlands Cohort Study | 1 | NR | 0 g/d | 1 | | 1 | | Age, family history of prostate carcinoma, socioeconomic status, total energy intake, total energy-adjusted fat intake.
Schuurman, 1999^39^ | 2 | NR | 0.01 g/d | 0.69 | (0.50, 0.95) | 0.66 | (0.47, 0.91)
| 3 | NR | 0.03 g/d | 0.94 | (0.69, 1.28) | 0.92 | (0.67, 1.27)
| 4 | NR | 0.05 g/d | 1.06 | (0.79, 1.46) | 1.05 | (0.77, 1.44)
| 5 | NR | 0.10 g/d | 1.01 | (0.75, 1.37) | 1.00 | (0.73, 1.35)
| Total 58,279 | | | | p = 0.11‡ | | p = 0.10‡
DHA
Health Professionals Follow-up Study | 1 | NR | <0.032% of energy | 1.0 | | 1.0 | | Age, time period, major ancestry, family history of prostate cancer, BMI at age 21, height, type 2 diabetes, vasectomy, cigarettes in past decade, vigorous physical activity, intake of total energy, % energy from protein, % energy from monounsaturated fat, % energy from saturated fat, % energy from trans unsaturated fats, and intakes of calcium, supplemental vitamin E and lycopene.
Leitzmann, 2004^57^ | 2 | NR | 0.032–0.053% of energy | 1.16 | NR | 1.13 | (0.96, 1.33)
Prostate cancer excluding stage A-1 | 3 | NR | 0.054–0.079% of energy | 1.03 | NR | 0.99 | (0.83, 1.17)
| 4 | NR | 0.080–0.122% of energy | 1.03 | NR | 0.99 | (0.83, 1.19)
| 5 | NR | >0.122% of energy | 1.03 | NR | 1.02 | (0.84, 1.25)
| Total 47,866 | | | | p = 0.63† | | p = 0.77†
Health Professionals Follow-up Study | 1 | NR | <0.032% of energy | 1.0 | | 1.0
Leitzmann, 2004^57^ | 2 | NR | 0.032–0.053% of energy | 0.84 | NR | 0.79 | (0.58, 1.07)
Advanced prostate cancer | 3 | NR | 0.054–0.079% of energy | 0.91 | NR | 0.84 | (0.62, 1.15)
| 4 | NR | 0.080–0.122% of energy | 0.86 | NR | 0.82 | (0.59, 1.13)
| 5 | NR | >0.122% of energy | 0.73 | NR | 0.71 | (0.49, 1.08)
| Total 47,866 | | | | p = 0.06† | | p = 0.13†
Netherlands Cohort Study | 1 | NR | 0.01 g/d | 1 | | 1 | | Age, family history of prostate carcinoma, socioeconomic status, total energy intake, total energy-adjusted fat intake.
Schuurman, 1999^39^ | 2 | NR | 0.03 g/d | 0.82 | (0.60, 1.13) | 0.81 | (0.58, 1.11)
| 3 | NR | 0.06 g/d | 1.01 | (0.74, 1.38) | 1.00 | (0.73, 1.38)
| 4 | NR | 0.09 g/d | 1.07 | (0.79, 1.46) | 1.09 | (0.80, 1.49)
| 5 | NR | 0.18 g/d | 1.05 | (0.77, 1.42) | 1.03 | (0.75, 1.40)
| Total 58,279 | | | | p = 0.19‡ | | p = 0.19‡

* NR = Not Reported;

† Number of people included in analysis;

‡ = test for trend;

§ Update of data reported in Giovannucci.^29^

Sub-populations. All analyses were restricted to men of racial groups that were homogeneous within, but that differed across, the studies. These studies followed cohorts that are ethnically, geographically, and/or socio-economically distinct. The base populations for these studies comprised Hawaiian men of Japanese ancestry,^27^ Seventh Day Adventist men residing in California,^50^ US male health professionals,^28,^ ^60^ Swedish male twin pairs,^53^ and the Dutch population.^39^ These studies did not perform analyses of specific subpopulations.

Covariates. The effects of covariates on the effect of omega-3 on incidence of prostate cancer were not assessed in these studies.

#### Effects of dose, source, and exposure duration

Dose and source: Each of the studies assessed the effects of dose. Dose effects in opposite directions for fish consumption were reported for two studies;^50,^ ^53^ no dose effect for fish was found in two.^27,^ ^28^ Dose effects in opposite directions for ALA consumption were reported by two studies.^29,^ ^39^ One of these studies^29^ found an inverse dose effect for overall prostate cancer risk and proportionate dose effect for advanced prostate cancer, although the inverse dose effect for overall prostate cancer risk did not persist with multivariable adjustment. No dose effect was reported for marine omega-3 FA,^29^ DHA, or EPA^39^ (Table 3.19).

Exposure duration: Four of the cohorts identified assessed exposure at baseline only; the follow-up period in these studies ranged from 6 to30 years.^27,^ ^39,^ ^50,^ ^53^ These studies did not assess the effect of exposure duration. One cohort assessed exposure at multiple time points. The Health Professionals Follow-up Study^28,^ ^29,^ ^57^ collected dietary data at three time points but did not report the effect of exposure duration on the risk of prostate cancer.

Sustainment of effect. None of the studies specifically assessed sustainment of effect.

Quality and applicability. See Table 3.20.

Table 3.20 Relationship between methodologic quality and applicability for estimates of effect of omega-3 fatty acid consumption on risk of prostate cancer.*

Cohort | | Quality Parameters
Author, Year | Applicability | Adjustment for confounders | Blinding | Valid ascertainment, cases | Valid ascertainment, exposure | Withdrawals and dropouts described
Hawaii Health Surveillance Program | II | Yes | NR | Yes | Yes | Yes
LeMarchand, 1994^27^
Health Professionals Follow-up Study | II | Yes | Yes | Yes | Yes | Yes
Augustsson, 2003^28^
Giovannucci, 1993^29^
Leitzmann^57^
Seventh-day | III | Yes | NR | Yes | Yes | Yes
Adventist Mills, 1989^50^
Swedish Twin Registry | III | Yes | NR | Yes | Yes | Yes
Terry, 2001^53^
Netherlands Cohort Study | II | Yes | NR | Yes | Yes | Yes
Schuurman, 1999^39^

* NR = Not Reported.

### Skin Cancer (Basal Cell Carcinoma)

Overall effect. We identified one study^31^ that evaluated the effect of omega-3 FA on the incidence of skin cancer. This study assessed incidence of basal cell carcinoma relative to omega-3 FA consumption. Relative to subjects in the lowest quartile of omega-3 fat consumption, subjects in the highest quartile of consumption had a small but statistically significant increase in the risk of basal cell carcinoma (RR 1.13, 95% CI 1.01, 1.27) (Table 3.21).

Table 3.21 Risk of skin (BCC) cancer for different categories of consumption of omega-3 FA, by category.*

Cohort | Study arm (quartile, quintile or dose group) | n† | Median intake | Estimates of effect
Author, Year | | | | Age adjusted RR (95% CI) | | Multivariate RR (95% CI) | | Multivariate Adjustors
Omega-3
Health Professionals Follow-up Study | 1 | NR | 0.07 g/d | 1 | | 1 | | Age, 2-year follow-up period, major ancestry, energy intake, BMI, hair color, frequency of routine physical examinations, cigarette smoking, mean annual solar radiation in region of residence, fat.
VanDam, 2000^31^ | 2 | NR | 0.15 g/d | 0.98 | NR | 0.97 | (0.86, 1.09)
| 3 | NR | 0.24 g/d | 1.07 | NR | 1.04 | (0.93, 1.17)
| 4 | NR | 0.34 g/d | 1.07 | NR | 1.05 | (0.93, 1.18)
| 5 | NR | 0.58 g/d | 1.14 | NR | 1.13 | (1.01, 1.27)
| Total 43,217 | | | p = 0.003‡ | | | P = 0.008‡

* NR = Not Reported;

† Number of people included in analysis;

‡ = test for trend.

Sub-populations. The study cohort comprises men enrolled in the Health Professionals Follow-up Study. Analyses of the relationship between omega-3 FA and basal cell carcinoma risk for subpopulations were not reported.

Covariates. The effects of covariates on risk associated with omega-3 FA was not reported.

#### Effects of dose, source, and exposure duration

Dose: This study assessed the risk of developing basal cell carcinoma given different levels of omega-3 fat consumption and found increased risk with increased dose (p for trend = 0.008).

Source: Consumption of omega-3 fat from all food sources was assessed.

Exposure duration: This study assessed dietary intake at four time points but did not report the effect of the duration of exposure to omega-3 FA and basal cell carcinoma.

Sustainment of effect. Sustainment of effect was not assessed.

Quality and applicability. See Table 3.22.

Table 3.22 Relationship between methodologic quality and applicability for estimates of effect of omega-3 fatty acid consumption on risk of skin (BCC) cancer

Cohort | Applicability | Quality Parameters
Author, Year | | Adjustment for confounders | Blinding | Valid ascertainment, cases | Valid ascertainment, exposure | Withdrawals and dropouts described
Health Professionals Follow-up Study | II | Yes | Yes | Yes | Yes | Yes
VanDam, 2000^31^

### Stomach Cancer

Overall effect. We identified one study^26^ that evaluated the effect of omega-3 FA on the incidence of stomach cancer. This study assessed incidence relative to fish consumption and found no association with the incidence of stomach cancer (Table 3.23).

Table 3.23 Risk of stomach cancer for different categories of consumption of omega-3 FA, by category.*

Cohort | Study arm (quartile, quintile or dose group) | n† | Median intake | Estimates of effect
Author, Year | | | | Age adjusted RR (95% CI) | Multivariate RR (95% CI) | | Multivariate Adjustors
Fish
Ngoan, 2002^26^ | 1 | NR | Low | NR | 1 | | Age, sex, smoking, processed meat, liver, cooking or salad oil, suimono and pickled food.
Stomach cancer including first 3 years follow-up | 2 | NR | Medium | NR | 1.1 | (0.5, 2.3)
Fukuoka Prefecture Cohort, Japan | 3 | NR | High | NR | 1.0 | (0.4, 2.2)
| Total 13,000 | | | | | p = 0.05‡
Ngoan, 2002^26^ | 1 | NR | Low | NR | 1
Stomach cancer excluding first 3 years follow-up | 2 | NR | Medium | NR | 0.9 | (0.4, 2.2)
Fukuoka Prefecture Cohort, Japan | 3 | NR | High | NR | 0.9 | (0.3, 2.1)
| Total 13,000 | | | | | p = 0.05‡

* NR = Not Reported;

† Number of people included in analysis;

‡ = test for trend.

Sub-populations. This study performed stratified analyses for men and women and found no association between fish consumption and stomach cancer risk for either group.

Covariates. The effects of covariates on risk associated with omega-3 FA were not reported.

#### Effects of dose, source, and exposure duration

Dose: This study assessed the risk of developing stomach cancer, given different levels of fish consumption, and found no dose response.

Source: No association between consumption and stomach cancer incidence was found for fresh fish, processed fish, or cuttle fish.

Exposure duration: This study assessed dietary intake at baseline only.

Sustainment of effect. Sustainment of effect was not assessed.

Quality and applicability. See Table 3.24.

Table 3.24 Relationship between methodologic quality and applicability for estimates of effect of omega-3 fatty acid consumption on risk of stomach cancer.*

Cohort | Applicability | Quality Parameters
Author, Year | | Adjustment for confounders | Blinding | Valid ascertainment, cases | Valid ascertainment, exposure | Withdrawals and dropouts described
Fukuoka Prefecture Cohort, Japan | II | Yes | NR | NR | Yes | NR
Ngoan, 2002^26^

* NR = Not Reported.

## Modification of Effects of Omega-3 Fatty Acids on Tumor Incidence

None of the studies identified assessed antioxidants, the immune system, or genes for omega-3 transportation as modifiers of the effects of omega-3 FA.

## Effects on Clinical Outcomes After Cancer Treatment

In reviewing the literature for this section of the report, we identified some studies for which comparisons across study arms could be used to assess the effect of omega-3 FA alone and others for which the effect of omega-3 FA in combination with arginine and RNA were assessed. In the following subsections, we describe the pooled effects of omega-3 FA alone, the pooled effect of omega-3 FA in combination with arginine and RNA, and the effect of pooling all of the studies.

### Cancer Surgery: Post-operative Complications

Overall effect. The effect of omega-3 FA on post-operative complications (any outcome specifically described as a “post-operative complication”) was described in fourteen studies; three for omega-3 FA alone^61–63^ and 11 for omega-3 FA in combination with arginine and RNA.^64–74^ Each of these studies assessed the effect of supplementation with omega-3 FA on post-operative complications in patients who underwent surgery for the resection of an upper gastrointestinal tract malignancy. The pooled random effects estimate of the risk of post-operative complications for omega-3 FA relative to placebo was 1.19 (95% CI: 0.66–2.13) (Table 3.25). The pooled random effects estimate of the risk of post-operative complications for omega-3 FA in combination with arginine and RNA relative to placebo was 0.51 (95% CI: 0.40–0.64) (Table 3.26 ). Pooling the studies that assessed the effect of omega-3 alone with the studies that assessed the effect of omega-3 in combination with arginine and RNA, the random effects estimate was 0.57 (95% CI: 0.46–0.71) (Figure 3.13).

Table 3.25 Relative risk of postoperative complications after cancer surgery for subjects treated with omega-3 FA compared to placebo

| Intervention | | Control
Trial | Source | n | Source | n | Relative Risk (95% CI)
Kenler, 1996^61^ | Fish oil, Soybean oil, Canola oil | 17 | Soybean oil, Osmolite | 18 | 0.91 | (0.38, 2.16)
McCarter, 1998^62^ | Standard + Arginine + Omega-3 | 13 | Standard + Arginine | 14 | 1.35 | (0.46, 3.95)
Swails, 1997^63^ | Fish oil, Canola oil, Soybean oil | 8 | Corn oil, Soybean oil | 10 | 1.67 | (0.52, 5.39)
Pooled Random Estimate* | | | | | 1.19 | (0.66, 2.13)

* Chi-squared test of heterogeneity p-value = 0.69.

Table 3.26 Relative risk of postoperative complications after cancer surgery for subjects treated with omega-3 FA in combination with arginine and RNA compared to placebo

| Intervention | | Control
Trial | Source | n | Source | n | Relative Risk (95% CI)
Braga, 2002^64^ | Omega-3, arginine, RNA | 100 | Standard hospital diet or isoenergetic control diet | 100 | 0.35 | (0.19, 0.67)
Braga, 2002^65^ | Omega-3, arginine, RNA | 50 | Standard enteral diet | 100 | 0.54 | (0.27, 1.10)
Braga, 1995^66^ | Omega-3, arginine, RNA | 26 | Standard enteral diet | 24 | 0.46 | (0.09, 2.30)
Braga, 1999^67^ | Omega-3, arginine, RNA | 85 | Isoenergetic control diet | 86 | 0.43 | (0.21, 0.89)
Daly, 1992^68^ | Omega-3, arginine, RNA | 36 | Standard enteral diet | 41 | 0.38 | (0.13, 1.07)
Daly, 1995^69^ | Omega-3, arginine, RNA | 30 | Standard enteral diet | 30 | 0.23 | (0.07, 0.73)
Di Carlo, 1999^70^ | Omega-3, arginine, RNA | 33 | Standard enteral diet | 35 | 0.53 | (0.14, 1.95)
Gianotti, 1997^71^ | Omega-3, arginine, RNA | 87 | Standard enteral diet | 87 | 0.65 | (0.35, 1.22)
Schilling, 1996^72^ | Omega-3, arginine, RNA | 14 | Standard enteral diet | 14 | 0.50 | (0.15, 1.61)
Senkal, 1999^73^ | Omega-3, arginine, RNA | 78 | Standard enteral diet | 76 | 0.54 | (0.27, 1.10)
Senkal, 1997^74^ | Omega-3, arginine, RNA | 77 | Standard enteral diet | 77 | 0.71 | (0.41, 1.21)
Pooled Random Effects Estimate* | | | | | 0.51 | (0.40, 0.64)

* Chi-squared test of heterogeneity p = 0.84.

Figure 3.13 Relative risk of post-operative complications associated with omega-3 fatty acids supplementation (omega-3 alone or omega-3 in combination with arginine and RNA) among subjects Who underwent resection of malignant tumor.*

Sub-populations. The effects of omega-3 FA on subpopulations were not assessed in these studies.

Covariates. The effects of covariates were not assessed.

Effects of dose, source, and exposure duration. Different doses of omega-3 FA were not compared in the studies. In all cases, the source of omega-3 FA was an enteral supplement and the duration of therapy was under two weeks.

Sustainment of Effect. The studies assessed the effect of omega-3 FA from five to ten days after therapy. Sustainment of effect was not assessed.

Quality and applicability. Among studies that entered the meta-analysis, none had both an applicability rating of I (representative of general adult population with cancer), and a summary quality score of A (Jadad score = 5 with concealment of allocation) (Table 3.27). All of the studies had an applicability rating of II because the study samples consisted of a specific subgroup of cancer patients, i.e., patients with gastrointestinal cancer. Nearly half of the studies were of poor methodologic quality, with summary quality scores of C (Jadad score <=2, concealment of allocation not performed or reported) (Table 3.27).

Table 3.27 Relationship between methodologic quality and applicability for estimates of effect of omega-3 fatty acid consumption on post-operative complications among people with cancer

Methodological Quality
Applicability | | A | B | C
| I
| II | | Daly, 1992^68^ | Kenler, 1996^61^
| | | Daly, 1995^69^ | Braga, 1995^66^
| | | Braga, 2002^64^ | Gianotti, 1997^71^
| | | Braga, 2002^65^ | Di Carlo, 1999^70^
| | | Braga, 1999^67^ | Schilling, 1996^72^
| | | McCarter, 1998^62^ | Swails, 1997^63^
| | | Senkal, 1999^73^
| | | Senkal, 1997^74^
| III

### Cancer Surgery: Length of Stay

Overall Effect. The effect of omega-3 FA on length of stay was described in thirteen studies; three for omega-3 alone^61,^ ^62,^ ^75^ and ten for omega-3 in combination with arginine and RNA.^64–66,^ ^68–74^ Each of these studies assessed the effect of supplementation with omega-3 FA on length of stay in the hospital after surgery for the resection of an upper gastrointestinal tract malignancy. The pooled random effects estimate of the mean difference between omega-3 FA and placebo for length of hospital stay is 1.09 days (95% CI: -3.63, 5.81) (Table 3.28) The pooled random effects estimate of the mean difference between omega-3 FA in combination with arginine and RNA and placebo for length of hospital stay is -3.33 days (95% CI: -4.29, -2.38) (Table 3.29). Pooling the studies that assessed the effect of omega-3 FA alone with the studies that assessed the effect of omega-3 FA in combination with arginine and RNA, the random effects estimate was -3.17 days (95% CI: -4.11, -2.26) (Figure 3.14).

Table 3.28 Mean difference of length of stay for subjects treated with omega-3 FA compared to placebo

| Intervention | | Control | | Length of stay in days
Trial | Source | n | Source | n | Mean difference (95% CI)
Heller, 2004^75^ | TPN with omega-3 | 24 | TPN | 20 | 0.3 | (-25.2, 25.8 )
Kenler, 1996^61^ | Fish oil, Soybean oil, Canola oil | 17 | Soybean oil, Osmolite | 18 | 0.7 | (-5.1, 6.5 )
McCarter, 1998^62^ | Standard + Arginine + Omega-3 | 13 | Standard + Arginine | 14 | 2.0 | (-6.5, 10.5 )
Pooled Random Effects Estimate* | | | | | 1 | (-3.6, 5.8 )

* Chi-squared test of heterogeneity p-value = 0.97.

Table 3.29 Mean difference of length of stay for subjects treated with omega-3 FA in combination with arginine and RNA compared to placebo

| Intervention | | Control | | Length of stay in days
Trial | Source | n | Source | n | Mean difference (95% CI)
Braga, 1995^66^ | Omega-3, arginine, RNA | 100 | Standard hospital diet or isoenergetic control diet | 100 | -1.70 | (-4.47, 1.07)
Braga, 2002^64^ | Omega-3, arginine, RNA | 50 | Standard enteral diet | 100 | -2.45 | (-3.46, -1.44)
Braga, 2002^65^ | Omega-3, arginine, RNA | 26 | Standard enteral diet | 24 | -2.70 | (-3.99, -1.41)
Daly, 1995^69^ | Omega-3, arginine, RNA | 36 | Standard enteral diet | 41 | -6.00 | (-7.09, -4.91)
Daly, 1992^68^ | Omega-3, arginine, RNA | 30 | Standard enteral diet | 30 | -4.40 | (-7.85, -0.95)
Di Carlo, 1999^70^ | Omega-3, arginine, RNA | 33 | Standard enteral diet | 35 | -1.50 | (-4.62, 1.62)
Gianotti, 1997^71^ | Omega-3, arginine, RNA | 87 | Standard enteral diet | 87 | -3.10 | (-5.21, -0.99)
Schilling, 1996^72^ | Omega-3, arginine, RNA | 14 | Standard enteral diet | 14 | 0.50 | (-7.50, 8.50)
Senkal, 1999^73^ | Omega-3, arginine, RNA | 78 | Standard enteral diet | 76 | -3.60 | (-4.85, -2.35)
Senkal, 1997^74^ | Omega-3, arginine, RNA | 77 | Standard enteral diet | 77 | -3.60 | (-4.46, -2.74)
Pooled Random Effects Estimate* | | | | | -3.33 | (-4.29, -2.38)

* Chi-squared test of heterogeneity p-value = 0.001.

Figure 3.14 Mean difference in hospital length of stay after malignant tumor resection surgery for subjects treated with omega-3 fatty acids supplementation (omega-3 alone or omega-3 in combination with arginine and RNA) compared to subjects not treated with supplementation.*

Sub-populations. The effects of omega-3 FA on subpopulations were not assessed in these studies.

Covariates. The effects of covariates were not assessed.

Effects of dose, source, and exposure duration. Different doses of omega-3 FA were not compared in the studies. In all cases, the source of omega-3 fatty acid was an enteral supplement and the duration of therapy was under two weeks.

Sustainment of effect. The studies assessed the effect of omega-3 FA from seven to ten days after therapy. Sustainment of effect was not assessed.

Quality and applicability. Among studies that entered the meta-analysis, none had both an applicability rating of I (representative of general adult population with cancer), and a summary quality score of A (Jadad score = 5 with concealment of allocation) (Table 3.30). All of the studies had an applicability rating of II because the study samples consisted of a specific subgroup of cancer patients, i.e., patients with gastrointestinal cancer. One study was of the highest methodologic quality, with a Jadad score of 5 and reporting of concealment of allocation. Nearly half of the studies were of poor methodologic quality, with summary quality scores of C (Jadad score <=2, concealment of allocation not performed or reported) (Table 3.30).

Table 3.30 Relationship between methodologic quality and applicability for estimates of effect of omega-3 fatty acid consumption on length of stay among people with cancer

Methodological Quality
Applicability | | A | B | C
| I | | Heller, 2004^75^
| II | | Daly, 1992^68^ | Kenler, 1996^61^
| | | Daly, 1995^69^ | Braga, 1995^66^
| | | Braga, 2002^64^ | Gianotti, 1997^71^
| | | Braga, 2002^65^ | Di Carlo, 1999^70^
| | | McCarter, 1998^62^ | Schilling, 1996^72^
| | | Senkal, 1999^73^
| | | Senkal, 1997^74^
| III

### Cancer Surgery: Mortality

Overall effect. The effect of omega-3 FA on mortality was described in ten studies; four for omega-3 FA alone^61–63,^ ^76^ and six for omega-3 in combination with arginine and RNA.^64,^ ^65,^ ^68,^ ^70,^ ^71,^ ^74^ Each of these studies assessed the effect of supplementation with omega-3 FA on mortality after surgery for the resection of an upper gastrointestinal tract malignancy. The pooled random effects estimate for the risk of death for subjects treated with omega-3 FA relative to placebo is 1.42 (95% CI: 0.63, 3.38) (Table 3.31). The pooled random effects estimate for the risk of death for subjects treated with omega-3 FA in combination with arginine and RNA relative to placebo is 1.01 (95% CI: 0.31, 3.35) (Table 3.32). Combining all studies, the pooled random effects estimate for the risk of death is 1.25 (95% CI: 0.64, 2.48; chi-squared test of heterogeneity p = 0.43). The follow-up period ranged from seven days to eight weeks.

Table 3.31 Odds ratio of mortality for subjects treated with omega-3 FA compared to placebo

| Intervention | | Control | | Deaths
Trial | Source | n | Source | n | Intervention | Control | Odds Ratio (95% CI)
Fearon, 2003^76^ | N3 FA | 95 | Isoenergetic control diet | 105 | 16 | 11 | -
Kenler, 1996^61^ | Fish oil, Soybean oil, Canola oil | 17 | Soybean oil, Osmolite | 18 | 0 | 1 | -
McCarter, 1998^62^ | Enteral standard diet, Arginine, Omega-3 | 13 | Enteral standard diet, Arginine | 14 | 0 | 1 | -
Swails, 1997^63^ | Fish oil, Canola oil, Soybean oil | 8 | Corn oil, Soybean oil | 10 | 0 | 0 | -
Pooled Random Effects Estimate* | | | | | | | 1.67 (0.71, 4.04)

* Chi-squared test of heterogeneity p = 0.17.

Table 3.32 Odds ratio of mortality for subjects treated with omega-3 FA in combination with arginine and RNA compared to placebo

| Intervention | | Control | | Deaths
Trial | Source | n | Source | n | Intervention | Control | Odds Ratio (95% CI)
Braga, 2002^64^ | N3 FA, Arginine | 100 | Standard hospital diet, Isoenergetic control diet | 100 | 1 | 1 | -
Braga, 2002^65^ | Enteral standard diet, N3 FA | 100 | Enteral standard diet | 50 | 1 | 2 | -
Daly, 1992^68^ | EPA + DHA | 36 | Enteral standard diet | 41 | 1 | 0 | -
Di Carlo, 1999^70^ | N3 FA, Arginine | 33 | Standard enteral formula | 35 | 1 | 0 | -
Gianotti, 1997^71^ | N3 FA, Arginine | 87 | Enteral standard diet | 87 | 1 | 2 | -
Senkal, 1997^74^ | N3 FA, Arginine, Omega6 FA | 77 | Isoenergetic control diet, Omega6 FA | 77 | 3 | 2 | -
Pooled Random Effects Estimate* | | | | | | | 1.01 (0.31, 3.35)

* Chi-squared test of heterogeneity p = 0.54.

Sub-populations. Analyses of the effects of omega-3 FA on subpopulations were not assessed in these studies.

Covariates. The effects of covariates were not assessed in any of the studies.

Effects of dose, source, and exposure duration. Different doses of omega-3 FA were not compared in the studies. In all cases, the source of omega-3 fatty acid was an enteral supplement and the duration of therapy was under two weeks.

Sustainment of effect. The studies assessed the effect of omega-3 FA from seven days to eight weeks after therapy. Sustainment of effect was not assessed.

Quality and applicability. Among studies that entered the meta-analysis, none had both an applicability rating of I (representative of general adult population with cancer), and a summary quality score of A (Jadad score = 5 with concealment of allocation) (Table 3.33). All of the studies had an applicability rating of II because the study samples consisted of a specific subgroup of cancer patients, i.e., patients with gastrointestinal cancer. One study was of the highest methodologic quality, with a Jadad score of 5 and reporting of concealment of allocation. Nearly half of the studies were of poor methodologic quality, with summary quality scores of C (Jadad score <=2, concealment of allocation not performed or reported) (Table 3.33).

Table 3.33 Relationship between methodologic quality and applicability for estimates of effect of omega-3 fatty acid consumption on mortality among people with cancer

Methodological Quality
Applicability | | A | B | C
| I
| II | Fearon, 2003^76^ | Daly, 1992^68^ | Kenler, 1996^61^
| | | Braga, 2002^64^ | Gianotti, 1997^71^
| | | Braga, 2002^65^ | Di Carlo, 1999^70^
| | | McCarter, 1998^62^ | Swails, 1997^63^
| | | Senkal, 1997^74^
| III

### Cancer Surgery: Nutrition

Overall effect. The effect of omega-3 FA on nutrition was described in 11 studies; two for omega-3 alone^61,^ ^63^ and nine for omega-3 in combination with arginine and RNA.^66–72,^ ^77,^ ^78^ In each of these studies, subjects underwent surgery for the resection of an upper gastrointestinal tract malignancy. The nutritional parameters assessed included caloric intake, nitrogen intake, and serum albumin, transferrin, and prealbumin. In each of the studies, subjects were randomized to either receive or not receive supplementation with omega-3 FA in the peri-operative period. Treatment duration and follow-up ranged from 7 to 14 days. Values for the treatment and control groups for each of the nutritional parameters are detailed in Table 3.34. Six of the studies assessed caloric intake;^61,^ ^63,^ ^68–70,^ ^72^ statistically significant differences were not reported by any. Of two studies that reported nitrogen intake,^68,^ ^69^ one^68^ found a significant increase among subjects who received omega-3 supplementation; the other found no significant difference between groups.^69^ Among six studies that assessed albumin^66–69,^ ^77,^ ^78^ and three that assessed transferrin levels^67–69^ no significant differences between groups was found. Of six studies that assessed prealbumin,^66,^ ^67,^ ^69,^ ^71,^ ^77,^ ^78^ two found significant increases in the intervention groups.^67,^ ^77^

Table 3.34 Effects of omega-3 fatty acid supplementation on nutritional parameters of subjects who underwent cancer resection therapy, by nutritional supplement*

Author, year | Intervention | Follow-up | n | Nutritional parameters
| | | | Mean Caloric intake, kcal/d (S.D.) | Mean Nitrogen intake, g/d (S.D.) | Mean Albumin, g/dl (S.D.) | Mean Transferrin, mg/dl (S.D.) | Mean Prealbumin, mg/dl (S.D.)
Omega-3 FA
Kenler, 1996^61^ | Soybean oil, Osmolite | 7 days | 18 | 1049.6 (78) | NR | NR | NR | NR
| Fish oil, Soybean oil, Canola Oil | | 17 | 1102.9 (78.7) | NR | NR | NR | NR
| Testing between groups | | | p = 0.63
Swails, 1997^63^ | Corn oil, Soybean oil | 7 days | 10 | 1047 (92) | NR | NR | NR | NR
| Fish oil, Canola oil, Soybean oil | | 8 | 1010 (100) | NR | NR | NR | NR
| Testing between groups
Omega-3 FA in combination with arginine and RNA
Braga, 1995^66^ | Enteral standard diet | 8 days | 24 | NR | NR | 3.2 (5.6) | NR | 17.3 (5.1)
| Omega-3, arginine, RNA | | 26 | NR | NR | 3.4 (5.1) | NR | 20.3 (4.6)
| Difference between groups
Braga, 1999^67^ | Enteral standard diet | 7 days | 86 | NR | NR | 3.7 (3.8) | 218 (52) | 18 (4)
| Omega-3, arginine, RNA | | 85 | NR | NR | 3.7 (3.6) | 223 (48) | 23 (4)
| Difference between groups | | | | | | | p < 0.05
Daly, 1992^68^ | Enteral standard diet | 7 days | 41 | 1285 (399) | 9 (2.8) | 2.0 (1.3) | 152 (61) | NR
| Omega-3, arginine, RNA | | 36 | 1421 (252) | 15.6 (2.8) | 2.1 (1.3) | 161 (73) | NR
| Testing between groups | | | NS | p = 0.001 | NS | NS
Daly, 1995^69^ | Enteral standard diet | 14 days | 30 | 1232 (372)† | 10.1 (3.1)† | 3.1 (0.4) | 181 (53) | 17 (4)
| Omega-3, arginine, RNA | | 30 | 1067 (335)† | 11.9 (4.1)† | 3.1 (0.4) | 190 (60) | 16 (7)
| Difference between groups
Di Carlo, 1999^70^ | Enteral standard diet | 12 days | 35 | 1550 (350)
| Omega-3, arginine, RNA | | 33 | 1580 (330)
| Difference between groups | | | NR
Gianotti, 1999^77^ | Enteral standard diet | 8 days | 25 | | | 3.7 (3.9) | | 18 (6)
| Omega-3, arginine, RNA | | 25 | | | 3.7 (3.6) | | 26 (5)
| Difference between groups | | | | | NR | | p < 0.05
Gianotti, 1997^71^ | Enteral standard diet | 8 days | 87 | | | | | 18 (6)
| Omega-3, arginine, RNA | | 87 | | | | | 23 (5)
| Difference between groups | | | | | | | p < 0.01
Schilling, 1996^72^ | Enteral standard diet | 10 days | 14 | 30.4‡
| Omega-3, arginine, RNA | | 14 | 17.4‡
| Difference between groups | | | NR
Vignali, 1995^78^ | Enteral standard diet | 8 days | 16 | | | 3.2 (.6) | | 17.3 (.5)
| Omega-3, arginine, RNA | | 16 | | | 3.4 (.5) | | 20.3 (.5)
| Difference between groups | | | | | NR | | NR

* NR = Not Reported, NS = Not Significant;

† = 7 days after surgery;

‡ kcal/kg/day.

Sub-populations. Analyses of the effects of omega-3 FA on subpopulations were not assessed in these studies.

Covariates. Analyses of the effects of covariates on the effect of omega-3 FA on nutritional parameters were not reported in these studies.

Effects of dose, source, and exposure duration. Different doses of omega-3 FA were not compared in the studies. In all cases, the source of omega-3 FA was an enteral supplement, and the duration of therapy was under two weeks.

Sustainment of effect. The studies assessed the effect of omega-3 FA from seven to ten days after therapy. Sustainment of effect was not assessed.

Quality and applicability. Among studies that entered the meta-analysis, none had both an applicability rating of I (representative of general adult population with cancer), and a summary quality score of A (Jadad score = 5 with concealment of allocation) (Table 3.35). All but one of the studies had an applicability rating of II because the study samples consisted of a specific subgroup of cancer patients, i.e., patients with gastrointestinal cancer. One study had an applicability rating of III, which signifies a highly selected population. None of the studies had optimal methodological quality ratings (Table 3.35).

Table 3.35 Relationship between methodologic quality and applicability for estimates of effect of omega-3 fatty acid consumption on nutritional parameters among people with cancer

Methodological Quality
Applicability | | A | B | C
| I
| II | | Daly, 1992^68^ | Kenler, 1996^61^
| | | Daly, 1995^69^ | Braga, 1995^66^
| | | Gianotti, 1999^77^ | Gianotti, 1997^71^
| | | Schilling, 1996^72^ | Di Carlo, 1999^70^
| | | | Swails, 1997^63^
| | | | Braga, 1999^67^
| III | | | Vignali, 1995^78^

### Cancer Surgery: Weight

Overall effect. We identified three^75,^ ^76,^ ^79^ randomized controlled trials that evaluated the effect of omega-3 FA on weight among patients undergoing surgery for the treatment of cancer (Table 3.36). Subjects receiving omega-3 supplementation had less weight loss over eight weeks in one study,^76^ less weight loss during the hospital stay^75,^ ^79^ in another study, and more weight loss over 14 days in the third study.^79^ However, differences between the groups were not significant in any of the studies.

Table 3.36 Effect of omega-3 fatty acid supplementation on weight loss after cancer surgery

Author, year | Intervention | Follow-up | n | Mean Weight loss
Fearon, 2003^76^ | Isoenergetic control diet | 8 weeks | 105 | 0.37 kg/month
| N3 FA | | 95 | 0.25 kg/month
Heller, 2004^75^ | TPN without omega-3 FA | 5 days | 20 | 1.1 kg
| TPN with omega-3 FA | | 24 | 0.0 kg
Preshaw, 1979^79^ | IV fluids, Amino acids | 14 days | 23 | 2.5 kg
| IV fluids, Soybean oil, Amino acids | | 24 | 3.9 kg

Sub-populations. Analyses of the effects of omega-3 FA on subpopulations were not assessed in these studies.

Covariates. Analyses of the effects of covariates on the effect of omega-3 FA on nutritional parameters were not reported in these studies.

Effects of dose, source, and exposure duration. Different doses of omega-3 FA were not compared in the studies. In all cases, the source of omega-3 fatty acid was an enteral supplement, and the duration of therapy was under two weeks.

Sustainment of effect. The studies assessed the effect of omega-3 FA from seven to a mean of 19 days after therapy. Sustainment of effect was not assessed.

Quality and applicability. Among studies that entered the meta-analysis, none had an applicability rating of I (representative of general adult population with cancer); all of the studies had an applicability rating of II because the study samples consisted of a specific subgroup of cancer patients, i.e., patients with gastrointestinal cancer (Table 3.37). Two of the studies had optimal methodological quality ratings and a summary quality score of A (Jadad score = 5 with concealment of allocation); one had a poor quality rating (Table 3.37).

Table 3.37 Relationship between methodologic quality and applicability for estimates of effect of omega-3 fatty acid consumption on weight loss among people with cancer

Methodological Quality
Applicability | | A | B | C
| I | Heller, 2004^75^
| II | Fearon, 2003^76^ | | Preshaw, 1979^79^
| III

## Cancer Chemotherapy

No studies were identified that assessed the effects of omega-3 FA on clinical outcomes after chemotherapy for cancer.

## Cancer Radiation Therapy

No studies were identified that assessed the effects of omega-3 FA on clinical outcomes after radiation therapy for cancer.

## Modification of Effects of Omega-3 FA on Tumor Treatment

None of the studies identified assessed antioxidants or the immune system as modifiers of the effects of omega-3 FA.

## Tumor Behavior: Effects of n-3 Fatty Acids on Tumor Growth, Apoptosis, and Cell Differentiation in Animal and Cell Culture Models

The effects of omega-3 FA (n-3s) have been examined on four types of tumors in animal models: mammary (breast) tumors, colon tumors, prostate tumors, and pancreatic tumors (no review articles were found on cell culture models). Of these four types, meta-analysis has been performed only on findings regarding the growth and development of mammary tumors, and systematic analysis has been performed only on findings regarding the growth and development of colon and prostate tumors.

No meta-analyses or systematic reviews were identified that addressed the issues of differentiation or apoptosis.

The conclusions regarding growth and development will be summarized for each type of tumor, followed by the conclusions regarding differentiation and apoptosis.

### Growth

Mammary tumor growth. A meta-analysis of the literature on dietary FA and mammary tumor development in rats and mice found that omega-3 FA substituted isocalorically for a non-fat nutrient in the diet were associated with a small, nonsignificant decrease in the incidence of mammary tumors induced by a variety of agents^80^ (Table C.3.1, Appendix C). No studies were included on the transplantation of tumor cells into healthy animals. No conclusions could be drawn about other aspects of tumor growth such as time to onset, tumor size, or number of tumors.

Nine nonsystematic reviews assessed studies of the influence of omega-3 FAs on mammary tumor development (Table C.3.2, Appendix C). These studies used two types of models: 1) rodents that received a carcinogen to induce a cancerous tumor agent were fed diets containing defined levels of omega-3 FAs (the model described for the meta-analysis); 2) cultured tumor cells were injected or transplanted into one of a number of strains of immune-challenged mice that were fed diets containing defined levels of omega-3 FAs. Sources of omega-3 FAs included fish oil (no further definition), menhaden oil (also a type of fish oil), perilla oil (a plant source of omega-3 FAs containing only ALA), purified DHA, purified EPA, and purified ALA. None of these reviews provided quantitative data. Reviews of studies adhering to the first model generally showed that diets in which the primary source of fat was enriched in omega-3 FAs decreased the incidence and burden of chemically induced mammary tumors in rodents compared with diets in which the source of fat was corn oil, safflower oil, or some other source enriched with omega-6 FA. No negative findings were reported. Reviews of studies adhering to the second model found that the growth rates of transplanted tumors were lower in animals maintained on omega-3 FAs.

Prostate tumor growth. Few animal models of prostate cancer exist. One systematic review of four studies found that fish oils containing high levels of EPA and DHA generally suppress prostate tumor growth in vivo and in vitro;^81^ however, one of the studies found that EPA was inhibitory only at high concentrations. Thus, the authors concluded that fish oil might not decrease the risk for prostate cancer. Further, nothing is known about the possible mechanism(s) by which omega-3 FAs might alter prostate tumor development.

A nonsystematic review of two studies of the effects of omega-3 FAs (in the form of fish oil) on prostate tumor growth in nude mice found that omega-3 FAs might suppress tumor growth but only when the initial number of implanted cells was low.^82^

Colon tumor growth. Three systematic reviews were identified that reported on the effects of omega-3 FAs on colon tumor growth and development. A 1991 review considered the effects of dietary omega-3 FAs on the incidence and number of carcinogen-induced colon tumors in two strains of rats (Sprague-Dawley [S-D] and Fischer 344).^83^ Among the criteria for study inclusion were the use of isocaloric diets (i.e., omega-3 FAs were substituted isocalorically for another source of fat to rule out the effect of increased dietary fat or calories) and the use of standard feeding methods (to exclude the use of gavage to introduce the fats, which would bypass normal digestion and possibly absorption mechanisms). Fourteen studies were identified that met the inclusion criteria. The majority of studies demonstrated an effect of omega-3 FAs on reducing the incidence and number of colon tumors in both strains of rats. By comparison, omega-6 FA appeared to promote tumors, but only in Fischer rats. The method used to calculate the fat content of each of the diets may not have been entirely valid, in part because many of the studies omitted information required to calculate the true dietary fat intake.

A 2002 review also assessed the effect of omega-3 FAs (among a wide variety of agents) on carcinogen-induced colon tumors in Sprague-Dawley, Fischer, and Wistar rats.^84^ The review considered studies that used any of three sources of omega-3 FAs: perilla oil ( alone and in combination with beta-carotene), purified DHA, and fish oil (which contains DHA and EPA). Two outcomes were examined: induction of aberrant crypt foci (ACF) (an intermediate outcome) and tumor incidence. Perilla oil (12 percent by weight) in combination with beta-carotene was one of the most potent inhibitors of ACF induction (91 percent inhibition in Fischer rats), presumably because of the ability of beta-carotene, an antioxidant, to prevent peroxidative damage to the omega-3 FA. Perilla oil alone (12 percent by weight) and DHA (0.5 and 0.7 ml/day) also inhibited formation of ACF in Fischer rats. A diet of eight percent fish oil resulted in only a 50 percent inhibition of ACF in Wistar rats. Tumor incidence was reduced as much as 64 percent by fish oil and 52 percent by perilla oil in Fischer rats, and one study reported a reduction in tumor incidence in fish oil-fed S-D rats, but the actual incidences were not reported in the latter study. The effects of omega-3 FAs on tumor incidence were weak compared with those of many of the other agents tested, such as the COX-2 inhibitor, celecoxib; the NSAID, piroxicam; and polyethylene glycol (a detergent). What's more, the review excluded studies with only negative results.

A 2003 systematic review examined the effects of a number of putative cancer preventive agents, including omega-3 FAs, on tumor growth in the colon and small intestine in the min (multiple intestinal neoplasia) mouse model, a mutant that spontaneously develops multiple intestinal neoplasias secondary to a mutation in the Apc gene, similar to humans with familial adenomatous polyposis. Findings on the effects of omega-3 FAs were obtained from two studies. The results of one study showed that DHA reduced the incidence of small intestinal tumors in female mice but actually appeared to increase the incidence in male mice. The results of the other study showed that fish oil decreased tumor yield in the small intestine by 26 to 67 percent; however, no significant effect was observed on colon tumors.

Studies of the effects of omega-3 FAs on colon cancer were also reviewed in three non-systematic reviews. A 1991 review reported that omega-3 FAs (in the form of menhaden oil or EPA) suppressed tumor number or lowered the incidence of carcinogen-induced tumors in three strains of rats - Fischer, Sprague-Dawley (S-D), and Donryu - and in Balb/c (immune-compromised) mice injected with colon carcinoma cells.^82^ A 1992 review described an additional study that used a crossover design to assess the timeframe of the inhibitory effect of fish oil on colon tumor development in rats (see Timing).^85^

Pancreatic tumor growth. No systematic reviews assessed the results of studies on omega-3 FAs and pancreatic tumors. One nonsystematic review reported the results of a crossover study that compared the effects of isocaloric menhaden Oil and corn oil (CO) diets and examined the effects of varying ratios of omega-3 FAs and omega-6 FA on preneoplastic atypical acinar cell nodules, and assessed the timeframe of the effects on adenocarcinoma development in carcinogen-treated Wistar rats.^82^ A menhaden oil diet reduced the number and size of preneoplastic lesions relative to corn oil. The effect of varying ratios is reported in the Intake section. The crossover findings are reported in Timing.

### Differentiation

The process of cellular differentiation can be defined as the acquisition of traits or functions that are distinct from those of the original cells, a process that is usually associated with the cessation or slowing of cell division (as in terminal differentiation). Thus anything that stimulates or hastens differentiation would likely inhibit tumorigenesis.

One nonsystematic review considered the evidence that particular lipids might influence cellular differentiation by modifying the plasma membrane composition, in the context of a discussion of the potential role of lipids in cancer therapy.^86^ HL 60 and L1210 leukemia cells as well as a line of colon cancer cells showed increased rates of chemically mediated differentiation and decreased rates of growth when incubated in the presence of DHA (compared with oleic acid). Another nonsystematic review reported that EPA and DHA increased numbers of differentiating cells in a colon tumor model.^87^ Finally, omega-3 FAs were found to increase expression of peroxisome proliferator-activated receptor (PPAR)-γ expression in nuclei of many cell types.^88^ PPAR α, a member of the same family, was the first transcription factor found to be regulated by FA. Activation of PPAR-γ has been shown to increase differentiation of human breast cancer cells in culture.

### Apoptosis

Apoptosis is generally defined as a process of programmed cell death, in contrast to necrosis. Tumor production may be a result of the inhibition of apoptosis. Putative mechanisms for the promotion of tumor survival and growth by prostaglandins include the inhibition of apoptosis.

Three nonsystematic reviews considered the effects of omega-3 FAs on apoptosis and the possible association with tumor development. A review of the role of nutrition in apoptosis briefly speculated that omega-3 FAs might serve to maintain normal apoptosis because they increase formation of free-radical scavenging enzymes .^89^ The authors cited as two examples the stimulation of apoptosis by EPA in HL-60 cells, a line of cells cultured from a human tumor, and suppression of expression of the oncogene h-ras by fish oil in cells derived from a carcinogen-induced rat mammary tumor. The h-ras oncogene disrupts cellular processes that control apoptosis.

A second review - of the role of omega-3 FAs in autoimmunity, inflammation, carcinogenesis, and apoptosis - provided several possible models supporting the possibility that omega-3 FAs might inhibit tumorigenesis by promoting apoptosis.^87^ The susceptibility of omega-3 FAs to oxidative stress (peroxidation) might be responsible for the apoptosis observed in a variety of cell culture systems. As is well known, high omega-3 FA diets increase the levels of omega-3 FAs in membrane lipids of laboratory animals as well as the requirement for antioxidants to prevent peroxidation of these lipids. This oxidative stress can induce apoptosis. Likewise, expression of the bcl-2 oncogene, an antioxidant involved in controlling apoptosis, is inhibited by omega-3 FAs in transgenic and normal mice and in vitro (HL-60 and K-562 cells), which could be the mechanism by which omega-3 FAs suppress tumor growth (via promoting apoptosis). Another gene product that regulates apoptosis, in lymphocytes, is Fas/Apo-1, a receptor that is a member of the Tumor Necrosis Factor family. Fas-L, a ligand, mediates apoptosis by cross-linking the Fas receptor. Fas-L gene expression is increased by omega-3 FAs in splenocytes, and increasing evidence suggests that tumor progression can be controlled by altering cancer cell sensitivity to Fas-mediated apoptosis in this way.

A third review assessed the evidence that diet-mediated apoptosis protects the intestinal epithelium from carcinogenic stimuli.^90^ The surface of the intestinal mucosa is characterized by rapidly proliferating cells organized into structures called crypts. The proliferating cells undergo an organized process of differentiation, migration, senescence, and exfoliation. Such rapid proliferation (as well as constant exposure to food borne toxins) increases susceptibility to neoplastic mutation, yet the small intestine is among the tissue least likely to be transformed. This observation has generated considerable interest in identifying the mechanisms responsible for inhibiting such mutations. The review cites evidence from an in vitro model - a human colorectal carcinoma cell line - showing that EPA leads to cellular detachment, which in turn results in apoptosis. Evidence is also presented from an in vivo model: rats fed corn oil prior to exposure to a chemical carcinogen and then immediately switched to fish oil showed an enhancement of apoptosis and a significant decrease in the frequency of abnormal crypt foci. In both models, the effects were enhanced by glutathione depletion and inhibited by antioxidants, suggesting a role for membrane lipid peroxidation in the regulation of apoptosis.

### Intake

An assessment of the relationship between n-3 intake and suppression of tumor production requires that multiple groups of subjects be fed diets with varying amounts of omega-3 FAs. Dietary n-3 intake can be manipulated in several ways: 1) maintaining the caloric and fat content of the diet by substituting omega-3 FAs for another source of fat; 2) maintaining the caloric content but not the fat content of the diet by substituting omega-3 FAs for some other nutrient(s); 3) simply supplementing the regular diet with varying amounts of a source of omega-3 FAs.

Mammary Tumors. Neither the systematic nor the nonsystematic reviews of the findings on omega-3 FAs and mammary tumor growth explicitly assessed the effects of increasing n-3 intake. However, two reviews by Cave each cited a study showing an increase in mammary tumor latency (onset) and a decrease in burden and incidence with increasing dietary n-3 content (fish oil and menhaden oil) in both carcinogen-challenged rats and mice transplanted with tumor cells.^82,^ ^91^

Prostate Tumors. The systematic review of the findings on dietary fats and prostate cancer reported the findings of a 1996 study that showed that EPA inhibited tumor growth only at high doses and that at low doses, it promoted tumor growth; however, too few details were included in the review to ascertain whether low-dose EPA diets were in fact high-dose omega-6 diets, which would account for the tumor promoting effect. None of the nonsystematic reviews provided sufficient information to determine whether dose-response was assessed in any of the studies, although one review reported that in a study of Balb/c nude mice that received transplanted prostate tumor cells in one of two doses, fish oil retarded tumor progression only in the mice that received the lower dose of cells, which may suggest a dose effect.^82^

Colon Tumors. The systematic review of findings on omega-3 FAs and colon cancer in the min mouse model found no dose-response effect for omega-3 FAs.^92^ The data reported in the systematic review of findings on numerous agents by the same group precluded determination of the existence of a dose-response effect on tumor reduction in rats, because only the largest reported effect was included for each study.^84^

The 1991 nonsystematic review by Cave included several studies that assessed dose effects on tumor incidence and number in carcinogen-challenged Fischer rats and tumor size in Balb/c mice injected with colon carcinoma cells.^82^ This review presented findings suggestive of a possible dose effect for omega-3 FAs, but the data were insufficient to distinguish a dose-response effect from a threshold effect for high doses. A 1996 nonsystematic review reported that an omega-3 to omega-6 ratio of one prevented tumor proliferation and decreased incidence in carcinogen-challenged mice, a finding that argues for a more complex relationship between dietary omega-3 content and tumor growth.^93^ However, descriptions of study details were incomplete.

Pancreatic Tumors. A nonsystematic review of dietary fats and pancreatic cancer identified a study that found that increasing the ratio of omega-3 FAs to omega-6 FAs resulted in a decrease in development of preneoplastic atypical acinar cell nodules.^82^ These findings further support the idea that it is the relative intake of omega-3 FAs that is important, rather than the absolute dietary levels.

Timing. The real question regarding a temporal relationship is whether diet exerts modulating effects during initiation or promotion of tumor development. None of the systematic reviews addressed the issue of whether the timing of dietary n-3 enrichment affected outcomes. Although the review of the effects of multiple agents on colon cancer reported the timing of diet relative to induction, no one study appeared to compare the effects of administering the agents prior to, during, and post induction. Thus, the findings that address the question of a temporal relationship are drawn from nonsystematic reviews.

Mammary Tumors. Studies that attempted to assess the timing of omega-3 FA enrichment were usually carried out with a crossover design. One crossover study reported in the 1991 Cave review found that in a mouse tumor transplant model, dietary enrichment with fish oil prior to transplantation was more effective than enrichment post-transplantation.^82^ A study included in the 1997 Cave review that did not use a crossover design reported that menhaden oil lengthened the latency period for mammary tumor development both in carcinogen-challenged rats and transplanted mice, suggesting a possible temporal relationship.^91^

A 1995 review by Klurfeld related the findings of a study that suggested that studies might be more likely to report effects of mediators on promotion rather than on initiation because initiation is presumably a short period compared to promotion.^94^ However, the findings reported in the Cave reviews suggest the effects of omega-3 FAs may preferentially be exerted during or even prior to initiation.

Prostate Tumors. No studies assessed the role of timing of omega-3 FA enrichment.

Colon Tumors. A 1992 review of studies on dietary fats and colon tumors included a crossover study in which rats were fed diets low or high in corn oil, or high in fish oil for nine weeks; during the last two weeks of the experimental diet, they received two weekly injections of a carcinogen.^85^ Three days after the second injection, the rats were switched to a different diet or kept on the same diet for 42 additional weeks. The animals fed the fish oil diet during or after the induction phase showed a decrease in the incidence of colon tumors.

Studies in which the outcome is a precancerous condition or marker may also help address the possibility of a temporal relationship between n-3 dietary enrichment and effects on tumor development. A 1996 review included a study showing that rats that received supplemental DHA by intragastric gavage prior to carcinogenic challenge had a smaller number of and reduced development of aberrant crypt foci.^93^

Pancreatic Tumors. A study included in the 1991 review by Cave^82^ compared the effects of menhaden oil- and corn oil-enriched diets initiated after carcinogenic challenge of Wistar rats on the incidence of pancreatic tumors and preneoplastic atypical acinar cell nodules. Rats that consumed high-corn oil diets for 4 months had the highest number of tumors and preneoplastic lesions, followed by those who consumed high-menhaden oil diets for two months and were then switched to high-corn oil diets. Rats that were switched to high-menhaden oil diets after two months and those that consumed high-menhaden oil diets for the full four months had the lowest number of tumors and preneoplastic lesions, suggesting a possible effect of diet at the time of and immediately after challenge.

### Effect Modification by Genes for Omega-3 Transport

The observed effects of omega-3 FAs on tumor incidence and growth have been attributed to their involvement in the expression of a variety of genes, including those for growth factors, nuclear receptors, and oncogenes. However the response to this question limits itself to the role of gene products involved in the transport or metabolism of the omega-3 FAs themselves.

The synthesis of eicosanoids begins with the cleavage of PUFAs from membrane phospholipids via phospholipases. The metabolic pathways by which omega-3 and omega-6 FAs are then converted to the eicosanoids are regulated by two families of fast-acting and fast-turnover enzymes: the cyclooxygenases (COX) and lipoxygenases (LO) as well as cytochrome P450 monooxygenases. COX-1 is constitutively expressed and considered to be a housekeeping gene, while COX-2 is not usually detectable in normal tissues, but is induced in processes like inflammation and carcinogenesis. COX-2 controls the rate-limiting step in the synthesis of prostaglandins and thromboxanes, whereas the LO enzymes are responsible for synthesis of the leukotrienes and other products. The omega-3 and omega-6 FAs compete for the same COX and LO enzymes. Likewise, the eicosanoids derived from omega-6 FAs compete with those derived from omega-3 FAs. Prostaglandin E_2_ (PGE_2_), the major COX-2 metabolite of arachidonic acid, plays an important role in controlling immune function, inhibiting T-cell function and interleukin-2 production. Putative mechanisms for observed effects of omega-3 FAs on tumorigenesis that involve the PUFA transport and metabolic enzymes are included in a number of nonsystematic reviews of animal and in vitro studies (Table C.3.5, Appendix C).

Omega-3 fatty acid transport. Three nonsystematic reviews discussed the potential roles of the phospholipases in the effects of omega-3 FAs. Two reviews of studies of the effects of omega-3 FAs on cytokine production suggested that the phospholipases play a role in determining the amounts and types of eicosanoids synthesized in rodent ex vivo models.^95,^ ^96^ Similarly, a 2000 review of studies of the role of omega-3 and omega-6 FAs in potentiating angiogenesis included mention of a putative role for phospholipases but did not present specific data.^97^ Angiogenesis - neovascularization - is believed to be necessary for tumor growth. Each of these reviews cited evidence that augmenting dietary omega-3 FAs resulted in replacement of phospholipid n-6s with omega-3 FAs, increasing the amount of omega-3 FAs available for action by lipases; however, no evidence was presented that omega-3 FAs are preferential substrates for phospholipases. No other reviews or reports of original research were found that dealt with the topic of omega-3 FA transport and tumor development.

Omega-3 fatty acid metabolism. Six nonsystematic reviews identified in the original literature search considered the role of n-3 metabolic enzymes in the effects of omega-3 FAs on tumorigenesis. To augment the evidence presented in these reviews, an additional brief search was conducted in Medline for the years 1999-2004 using the terms omega* AND metabolism AND cancer or tumor* and limiting the reports to reviews. A summary of one relevant 2004 review follows that of the findings of the six reviews from the original search (and summarized in Table C.3.5, Appendix C).

All six of the nonsystematic reviews from the original search that included discussion of n-3 metabolic enzymes presented evidence that dietary enrichment with omega-3 FAs inhibits the COX-2-mediated conversion of AA to PGE_2_, which might, in itself, account for the effects of omega-3 FAs on tumor growth inhibition.^87,^ ^93,^ ^95–98^ COX-2 inhibitors, such as aspirin and NSAIDS, are well known to exert a preventive effect on tumor development.^92^ Rose and Connolly^97^ reviewed the evidence that COX-2 is involved in the angiogenesis of tumor growth and that the DHA-mediated inhibition of angiogenesis observed in nude mice transplanted with breast cancer cells is similar to the inhibition observed after treatment with COX-2 inhibitors. They also reviewed a series of studies using a line of human colon carcinoma cells that over-express COX-2, resulting in the stimulation of vascular endothelial cell migration and formation of capillary-like structures in culture. A review of the role of apoptosis in omega-3-mediated inhibition of tumor growth provided evidence from a variety of in vitro and in vivo models that dietary enrichment with omega-3 FAs results in a modification of COX-2 activity and a state of oxidative stress, which stimulates apoptosis.^87^

Finally, a 2004 nonsystematic review of potential mechanisms by which dietary omega-3 FAs might prevent cancer summarized the evidence for a role in the inhibition of AA-derived eicosanoids and the specific role of COX-2.^99^ Omega-3 FAs inhibit synthesis of AA metabolites at three levels. First, as discussed above, high intakes of omega-3 FAs result in their incorporation into membrane phospholipids, substituting for AA and decreasing its availability for conversion to eicosanoids. Second, omega-3 FAs compete with omega-6 FAs for desaturases and elongases and have greater affinity for those enzymes than do omega-6 FAs, resulting in lower levels of AA biosynthesis. Third, omega-3 FAs themselves suppress COX-2 synthesis in chemically induced rat mammary tumors and rodent models of colon cancer and compete with omega-6 FAs for the enzyme. In addition, omega-3 FAs are a preferential substrate for COX-2. COX-2 expression has been shown to down-regulate apoptosis, and over-expression of COX-2 has been observed in models of breast, colon, and prostate cancer. Further evidence for an involvement of COX-2 includes its ability to catalyze the conversion of procarcinogens to carcinogens as well as to liberate mutagens in the metabolism of AA in in vitro systems.

### Quality of Literature

Review Quality. Of the 36 reviews identified, only one was a meta-analysis and four others were systematic reviews, but at least one of those four excluded reports of negative findings. What's more, only three of these five reviews limited themselves to studies on PUFAs and their role in tumor development, and the studies were quite heterogeneous. Thus, two of the reviews included only one or two reports on omega-3 FAs.

Study Quality and Heterogeneity. Overshadowing the questionable quality of the reviews themselves may be the quality and heterogeneity of the studies reviewed. In vivo carcinogen-challenge studies differed in animal species and strain, forms and amounts of supplemental omega-3 FAs, method of dietary supplementation, feeding regimens (ad lib vs. calorie control), method of measuring dietary intake, carcinogen used, time and duration of carcinogen exposure with respect to animal age and exposure to supplemental omega-3 FAs, and outcome measures. Additionally, publication may be a particular problem with animal studies in that some journals explicitly discourage publication of negative results.