# Methodology

## Objectives

The topic of this report was nominated by the National Institutes of Health (NIH) Office of Dietary Supplements (ODS). The three participating Evidence-Based Practice Centers (EPCs) were asked to examine the effects of omega-3 fatty acids, in general, and on the following conditions: Cardiovascular Disease, Transplantation, Immune-Mediated Diseases, Gastrointestinal/Renal Diseases, Cancer, Neurology, Asthma, Child/Maternal Health, Eye Health, and Mental Health. The Southern California EPC (SCEPC) was responsible for examining Immune-Mediated Diseases and Gastrointestinal/Renal Diseases in Year 1 of the project and Cancer and Neurology in Year 2 of the project. This report pertains to cancer.

## Scope of Work

The methodology that we used for this study included the following:

- Refining the preliminary questions provided by AHRQ,
- Convening a technical expert panel to advise the SCEPC on the study,
- Identifying sources of evidence in the scientific literature,
- Establishing inclusion/exclusion criteria for the articles identified in the scientific literature,
- Identifying potential evidence with attention to controlled clinical trials using omega-3 fatty acids,
- Evaluating potential evidence for methodological quality and relevance,
- Extracting data from studies meeting methodological and clinical criteria,
- Synthesizing the results,
- Performing further statistical analysis on selected studies,
- Performing pooled analyses where appropriate,
- Submitting the results to technical experts for peer review,
- Incorporating reviewers' comments into a final report for submission to AHRQ.

## Original Proposed Key Questions

Preliminary questions for the project were developed by ODS in collaboration with the following NIH Institutes: (a) National Cancer Institute (NCI); (b) National Eye Institute (NEI); (c) National Heart, Lung, and Blood Institute (NHLBI); (d) National Institute of Alcohol Abuse and Alcoholism (NIAAA); (e) National Institute of Allergy and Infectious Diseases (NIAID); (f) National Institute of Arthritis and Musculoskeletal and Skin Diseases (NIAMS); (g) National Institute of Child Health and Human Development (NICHD); (h) National Institute of Diabetes and Digestive and Kidney Diseases (NIDDK); (i) National Institute of Mental Health; and (j) National Institute of Neurological Disorders and Stroke (NINDS) The general and disease-specific questions that were originally proposed are detailed in Appendix A.1.

## Technical Expert Panel

Each AHRQ evidence report is guided by a Technical Expert Panel (TEP). The TEP advises the SCEPC on refining the preliminary questions, determining the proper inclusion/exclusion criteria for the study and the populations of interest, establishing the proper outcomes measures, and conducting the appropriate analyses.

We convened a TEP that focused specifically on cancer. The TEP was composed of distinguished basic scientists and clinicians, with established expertise in omega-3 fatty acids, human nutrition, dietary assessment methods, cancer biology, and oncology. In addition to the experts that we identified, AHRQ and the relevant NIH Institute(s) recommended a number of industry experts. The members of our technical expert panel and a summary of their key comments and recommendations are listed in Appendix A.2.

## Key Questions Addressed in this Report

Based on input from our TEP, the preliminary disease-specific questions were revised. The questions that are addressed in this report are as follows:

[underlined: Tumor Incidence]

- What is the evidence that omega-3 fatty acids reduce the incidence of tumors?

If omega-3 fatty acids influence the incidence tumors:

- For what type of tumors?
- Is there an inverse relationship with intake?
- Is there a temporal relationship with intake?
- What is the evidence that genes involved in omega-3 fatty acid transport or metabolism influence the magnitude or direction of the influence on tumor incidence?
- What is the evidence that the response to omega-3 fatty acids is dependent of the intake of antioxidants such as vitamin E or other bioactive food components?
- What is the evidence that the response is modified by the state of the immune system?

[underlined: Effects on Clinical Outcomes After Cancer Treatment]

- What is the evidence that omega-3 fatty acids alter the effects of cancer treatment on malignant tumors and clinical outcomes after cancer treatments?
- What is the evidence that the response to omega-3 fatty acids is dependent of the intake of antioxidants such as vitamin E or other bioactive food components?
- What is the evidence that the response is modified by the state of the immune system?

[underlined: Tumor Behavior]

- What is the evidence that omega-3 fatty acids alter the behavior of malignant tumors in terms of growth, differentiation, and apoptosis?

If omega-3 fatty acids influence the behavior of tumors:

- For what type of tumors?
- Is there an inverse relationship with intake?
- Is there a temporal relationship with intake?
- What is the evidence that genes involved in omega-3 fatty acid transport or metabolism influence the magnitude or direction of the influence on tumor behavior?

## Identification of Literature Sources

Potential evidence for our study came from three sources: on-line library databases, the reference lists of all relevant articles, and industry experts.

### Tumor Incidence and Outcomes After Cancer Treatment

Jessie McGowan, Senior Information Scientist, and Nancy Santesso, Knowledge Translation Specialist, at the University of Ottawa were responsible for developing a common search strategy for omega-3 fatty acids for the 3 participating EPCs. Nancy Santesso developed a core omega-3 search strategy in collaboration with project librarians, biochemists, nutritionists, and clinicians, who also provided biochemical names, abbreviations, food sources, and commercial product names for omega-3 fatty acids. The literature search was not restricted by language of publication or by study design, in order to increase sensitivity. When possible, the searches were limited to studies involving human subjects. The core search strategy is detailed in Appendix A. Table 4.1.

For the SCEPC, this core search strategy was incorporated into a specific search for cancer. The strategy for this search is detailed in Appendix A. Table 4.2. In consultation with our TEP and the Task Order Officer, it was decided that for the questions pertaining to tumor behavior, i.e. apoptosis, tumor growth, and differentiation we would conduct a separate search focusing on review articles and meta-analyses of animal studies and cell culture studies pertaining to both humans and animals. This search strategy is also outlined in Appendix A. Table 4.2. The following databases were searched: Medline (1966-October week 5, 2003), Premedline (Nov 7, 2003), Embase (1980-Week 44, 2003), Cochrane Central Register of Controlled Trials (3nd Quarter, 2003), CAB Health (1973-October 2003). All of these databases were searched using the Ovid interface, except CAB Health, which was searched through SilverPlatter. Any duplicate records were identified and removed within each search question using Reference Manager software. The citations obtained from these literature searches were sent to the SCEPC via e-mail.

In addition, we sent letters to industry experts recommended by the Office of Dietary Supplements to obtain any unpublished data (Table A.3.1 and Figure A.3.1).

### Tumor Behavior

We were unable to identify human studies that assessed the effects of omega-3 fatty acids on tumor behavior, i.e. cell growth, differentiation, and apoptosis. Hence, to evaluate the effects of omega-3 fatty acids on tumor behavior, we turned to the animal and cell culture literature. The initial intent was to summarize only meta-analyses and systematic reviews; however, because a total of only one meta-analysis and four systematic reviews were identified, the decision was made to summarize all relevant reviews. The search strategy is detailed in Appendix A.4. The following databases were searched: Medline, CabHealth, Embase, and Bio-abstracts. Any duplicate records were identified and removed within each search question using Reference Manager software. The citations obtained from these literature searches were sent to the SCEPC via e-mail.

## Evaluation of Evidence

### Tumor Incidence and Outcomes After Cancer Treatment

Two reviewers independently evaluated the citations and abstracts. Walter Mojica evaluated all of the citations and abstracts; Puja Khanna and Amalia Issa each evaluated a portion of the citations and abstracts.

The reviewers flagged article titles that focused on omega-3 fatty acids and cancer. Language was not a barrier to inclusion. Articles that either reviewer flagged were ordered, as well as those articles in which it was unclear from the title or abstract whether the article was relevant. The articles were ordered from the UCLA library or Infotrieve, a literature retrieval firm with contacts around the world. The literature was tracked using ProCite and Access software.

Two reviewers independently reviewed each article that was ordered to determine whether it should be accepted for further study using structured screening forms (shown in Figure B.1, Appendix B) that included defined sets of inclusion/exclusion criteria (Table A.5.1, Appendix A.5). Walter Mojica reviewed all of the articles; Puja Khanna, Yee-Wei Lim, and Amalia Issa each reviewed a portion of the articles. The reviewers resolved any disagreements by consensus.

Inclusion criteria included 1) description of effects of consumtion of omega-3 fatty acids on a) tumor incidence or b) clinical outcomes after cancer therapy; 2) study design of either a) prospective cohort or b) controlled clinical trial; 3) human study population; 4) description of effect of omega-3 relative to non-exposed people in cohort studies or relative to placebo in controlled clinical trials. There was no language restriction. Although parameters of methodologic quality were evaluated, they were not used as inclusion criteria. We excluded case-control studies because they are highly susceptible to methodologic bias, especially recall bias.

### Tumor Behavior

The reviews and meta-analyses on tumor behavior were reviewed by one reviewer, a medical editor and nutritional biochemist with an extensive research background that includes the use of animal and cell culture models.

## Extraction of Data

### Tumor Incidence and Outcomes After Cancer Treatment

For the articles that passed our screening criteria, two reviewers independently abstracted detailed data onto a specialized quality review form (QRF) (Figure B.2, Appendix B).

Walter Mojica reviewed all of the articles and Puja Khanna and Amalia Issa each reviewed a portion of the articles. We consulted with several outside scientists to complete QRFs for foreign-language articles. The reviewers resolved differences through consensus, and a senior physician researcher resolved any disagreements that could not be resolved through this method.

The QRF included questions about the trial design; the outcomes of interest; the quality of the trial; the number and characteristics of the patients; details on the intervention, such as the dose, frequency, and duration; the types of outcome measures; and the elapsed time between the intervention and outcome measurements.

### Tumor Behavior

Since we planned to conduct a qualitative rather than a quantitative review of the articles about tumor behavior, we did not complete any QRFs for these articles. Walter Mojica screened all of the articles for relevance to this topic, and Sydne Newberry reviewed and summarized the subset of relevant articles on tumor behavior.

## Grading Evidence

### Methodologic Quality of Randomized Controlled Trials

To evaluate the quality of the design and execution of trials that met our inclusion criteria, we collected information on the QRF about the study design, appropriateness of randomization, blinding, description of withdrawals and dropouts, and concealment of allocation.^11,^ ^12^ A score for quality was calculated for each trial using a system developed by Jadad (Appendix A.6, Figure A.6.1).^12^ The Jadad score rates studies on a scale of 0 to 5. Empirical evidence has shown that studies scoring 2 or less report exaggerated results compared with studies scoring 3 or more.^13,^ ^14^ Thus, studies with a Jadad score of 3 or more are referred to as “high quality,” and studies scoring 2 or less are referred to as “poor quality.” For our purposes, if a trial was associated with more than one study, its quality score was equal to the maximum score calculated across its associated studies. Additionally, a generic summary quality score (A, B, C) was assigned to each study based upon the combination of its Jadad score and reporting of concealment of allocation (Appendix A.6, Table A.6.1).

### Methodologic Quality of Observational Studies

To evaluate the quality of the design and execution of observational studies, we collected information about the validity of ascertainment of cases and exposure, description of withdrawals and dropouts, and adjustment for confounders and blinded assessment of exposure and case status when ascertaining case and exposure status, respectively.^15,^ ^16^ A score for quality was not calculated for observational studies, as there is no validated method to do so.

### Applicability

In this report, the focus is on the U.S. population. To capture the potential applicability of studies to the different populations of interest as defined in the scope of work (namely Americans with cancer), we categorized the populations in the studies we reviewed in terms of 1) applicability to the U.S. population and 2) health state (Appendix A.6, Table A.6.2). In the summary tables, each study receives a combined applicability grade consisting of the applicability and health state.

## Data Synthesis

We performed both a qualitative and quantitative synthesis of the evidence. We performed a meta-analysis for those studies that sufficiently assessed interventions, populations, and outcomes to justify pooling. Only randomized controlled trials with a placebo comparator group were considered for meta-analysis. For the remaining studies and for those pertaining to the apoptosis, tumor growth, and differentiation question, we performed a qualitative analysis. For the cohort studies that assessed the effects of omega-3 fatty acids on tumor incidence we constructed summary tables for each type of cancer that detailed the age- and multivariate-adjusted risk ratios that were reported for each study arm. These tables are stratified by the specific categories of omega-3 fatty acids for which the risk ratios were reported, i.e. total omega-3, marine omega-3, ALA, EPA or DHA. Also included in these tables are strata for total fish intake which can reasonably be used as a surrogate for omega-3 consumption given the high omega-3 content of fish. Included in these tables is the median intake of the relevant omega-3 fatty acid for each study arm if it was reported. The categories of omega-3 fatty acids that we report are those that were reported in the included studies and were not identical across the different studies. These studies all calculated the intake of different categories of omega-3 fatty acids by comparing the food frequency diaries of study subjects to validated standard tables of nutritional components including omega-3 fatty acids. Total omega-3 intake includes all types of omega-3 fatty acids (ALA, EPA, DHA) that can be obtained from food. Fish intake describes the amount of fish consumed whereas marine omega-3 fatty acids describe the amount of ALA, EPA and DHA derived from marine sources.

## Meta-Analysis

### Selection of Trials for Descriptive Analysis or Meta-Analysis

First, we identified a set of relevant outcomes, based on input from our TEP. Randomized controlled trials were considered for further analysis if they contained information on a chosen outcome collected within a follow-up interval for which measures were considered clinically comparable.

For some trials, several publications presented the same outcome data. In these cases, we picked the most informative of the duplicates; for example, if one publication was a conference abstract with preliminary data and the second was a full journal article, we chose the latter. The publications dropped for duplicate data do not appear in the evidence table but are noted in the results text. We note that multiple citations of the same article were removed at the title screening stage of the project.

In order for a trial to be included in further analysis, the associated publication(s) had to report on the outcome, and contain sufficient statistical information for the calculation of a summary statistic.

## Trial Summary Statistics

Each trial contained one control or placebo group. Some trials contained more than one treatment (omega-3) group. In order not to double-count patients, we chose the most clinically relevant treatment group to enter our analysis, or in some cases combined treatment groups.

For those outcomes that were dichotomous, the summary statistic was a risk ratio, that is, the risk of the outcome in the treatment (omega-3) group divided by the risk of the outcome in the control or placebo group. A risk ratio greater than one indicates that the risk of the outcome in the treatment group is larger than that in the control or usual care arm. For example, if the risk ratio is 1.10, then patients in the treatment group are 1.10 times as likely to have the outcome as those in the control or placebo group.

For each study, we estimated the log risk ratio and its standard deviation. We conducted the analysis on the logarithmic scale for variance-stabilization reasons.^17^ We then back-transformed to the risk ratio scale for interpretability.

For those outcomes that were continuous, we extracted the follow-up means and standard deviations for the treatment and control or placebo groups, respectively. If a study did not report a follow-up mean, or a follow-up mean could not be calculated from the given data, the study was excluded from analysis. For studies that did not report a standard deviation or for which a standard deviation could not be calculated from the given data, we imputed the standard deviation by using those studies and groups that did report a standard deviation and weighting all groups equally, or we assumed that the standard deviation was 0.25 of the theoretical range for the specific measure in the study. For example, if a study measured pain on a 0–100 scale, we assumed the standard deviation was 25.

If all studies measured the outcome on the same scale or the measures could all be converted to the same scale, e.g., the summary statistic was the mean difference (MD) between the treatment group follow-up mean and the control or placebo group follow-up mean:

Mean difference = treatment follow-up mean - control follow-up mean

We estimated the standard deviation for that mean difference.^18^ If the studies used different measurements of the same outcome and we could not convert them all to the same scale, the summary statistic was an effect size. The effect size is the mean difference at follow-up divided by the pooled standard deviation. This summary statistic is unitless and indicates the number of standard deviations by which the treatment and control or placebo group means differ. We estimated an unbiased estimate^19^ of Hedges' g effect size^20^ and its standard deviation. A negative mean difference or effect size indicates that the treatment is associated with a decrease in the outcome at follow-up as compared with the control or usual care group.

## Performance of Meta-Analysis

In some cases, the trials were judged too clinically heterogeneous to combine. Furthermore, for each outcome, condition, and trial stratum combination, we required that at least three trials be available for pooling. In heterogeneous settings and those with insufficient data, we conduct only a descriptive analysis and present the study-level summary statistics but do not estimate a pooled effect.

For those conditions for which trials were determined to be clinically comparable and for which there were at least three trials, we estimated a pooled random-effects estimate^21^ by combining summary statistics across trials. We also report the chi-squared test of heterogeneity p-value.^19^

Forest plots were constructed for each setting. Each individual trial summary statistic is shown as a box whose area is inversely proportional to the estimated variance of the summary statistic in that trial. The trial's confidence interval is shown as a horizontal line through the box. The pooled estimate and its confidence interval are shown as a diamond at the bottom of the plot with a dotted vertical line indicating the pooled estimate value. A vertical solid line at one for dichotomous outcomes or at zero for continuous outcomes indicates no treatment effect.

All analyses and drawings of graphs were conducted in the statistical package Stata (Stata Statistical Software: Release 7.0 2001). The only exception was for the analysis of death. Given that deaths were rare, we used exact conditional inference to perform the pooling rather than applying the usual asymptotic methods that assume normality. Asymptotic methods require corrections if zero events are observed, and generally, half an event is added to all cells in the outcome-by-treatment (two-by-two) table in order to allow estimation, because these methods are based on assuming continuity. Such corrections can have a major impact on the results when the outcome event is rare. Exact methods do not require such corrections. We conducted the meta-analysis using the statistical software package StatXact (StatXact 4 for Windows 2000).

## Sensitivity Analyses

We conducted post hoc sensitivity analysis for meta-analyses that exhibited significant (p<0.05) heterogeneity based on the chi-squared test of heterogeneity. In these sensitivity analyses, we removed the most outlying study chosen based on a visual inspection of the forest plot of the original meta-analysis, and estimated a new pooled estimate. We compared this pooled estimate to the original result as well as observed whether significant heterogeneity still remained.

## Publication Bias

We assessed the possibility of publication bias by evaluating a funnel plot of summary statistics for asymmetry, which can result from the nonpublication of small trials with negative results. These funnel plots include a horizontal line at the fixed-effects pooled estimate and pseudo-95% confidence limits.^22^ If bias due to nonpublication exists, the distribution is asymmetric or skewed. Because graphical evaluation can be subjective, we also conducted an adjusted rank correlation test^23^ and a regression asymmetry test^22^ as formal statistical tests for publication bias. The correlation approach tests whether the correlation between the effect sizes and their variances is significant, and the regression approach tests whether the intercept of a regression of the effects sizes on their precision differs from zero; that is, both formally test for asymmetry in the funnel plot. We acknowledge that other factors, such as differences in trial quality or true study heterogeneity, could produce asymmetry in funnel plots.

## Interpretation of the Results

The mean difference pooled results are readily interpretable as they are measured in a clinically interpretable metric. To aid in interpreting the pooled effect size and risk ratio, whenever possible we back-transformed each pooled estimate to a specific metric. In order to do this, we multiplied each pooled effect size estimate by the average standard deviation of the most clinically relevant outcome measured across the trials, e.g., included in the pooled estimate.

## Peer Review

This draft report was sent for review to a select group of experts in omega-3 fatty acids, epidemiology, nutrition, and cancer. The names, expertise, and affiliations of the peer reviewers are listed in Table A.7.1, Appendix A. Additionally, this draft report was sent to the members of the TEP for review. Service as a peer reviewer or as a technical expert panelist does not imply agreement or endorsement of the findings of this report.