# Appendix C. Evidence Tables

Evidence Table C.1.1 . Evidence table of the effects of omega-3 fatty acids on the risk of developing cancer in cohort studies, by cancer type.*

Cohort | Study Characteristics | Duration: | Eligibility criteria | Type of cancer: | Applicability
First Author, Year | | | | Ascertainment: | Funding source
| | | | | Quality
Aerodigestive Cancer
Honolulu Heart Program | Sample size† (people/person-years): 8,002/NR py | Duration: 24 years | Inclusion: Institutionalized American men of Japanese ancestry residing on Oahu. | Type: oral cavity and pharynx, other gastrointestinal | Applicability: III
Chyou, 1995^32^ | Age (mean/range): NR/45–68 | | Exclusion: Prevalent aerodigestive cancer at enrollment. | Ascertainment: Oahu hospitalizations for cancer and Hawaii Tumor Registry (part of NCI SEER Program) | Funding source: Government
| Race: Asian | | | | Quality:
| % male: 100 | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: NR
| Location: Hawaii | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Bladder Cancer
Honolulu Heart Program | Sample size† people/person-years): 7,995/NR | Duration: 22 years | Inclusion: Institutionalized American men of Japanese ancestry residing on Oahu. | Type: Bladder | Applicability: III
Chyou, 1993^33^ | Age (mean/range): NR/45–68 | | Exclusion: Prevalent bladder cancer at enrollment. | Ascertainment: Oahu hospitalizations for cancer and Hawaii Tumor Registry (part of NCI SEER Program) | Funding source: Government
| Race: Asian | | | | Quality:
| % male: 100 | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: NR
| Location: Hawaii | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Breast Cancer
Diet, Cancer and Health Study | Sample size: 23, 693 people | Duration: 5 years | Inclusion: Age 50–60/Born in Denmark | Type: Breast | Applicability: II
Stripp, 2003^55^ | Age (mean/range): NR/50–65 | | Exclusion: Cancer diagnosis as per Danish Cancer Registry | Ascertainment: Danish Cancer Registry; Danish Breast Cancer Co-operative Group | Funding source: Private Non-Industry
| Race: NR | | | | Quality:
| % male: 0 | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: NR
| Location: Denmark | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Life Span Study | Sample size† people/person-years): 34,759/488,989 py | Duration: 12 years | Inclusion: Survivors of atomic bomb in Hiroshima or Nagasaki, Japan that were alive on September 1, 1969. | Type: breast | Applicability: III
Key, 1999^52^ | Age (mean/range): NR/NR | | Exclusion: Prevalent breast cancer at baseline. | Ascertainment: Hiroshima and Nagasaki cancer Registries | Funding source: Government
| Race: NR | | | | Quality:
| % male: NR | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: NR
| Location: Japan | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Netherlands Cohort Study | Sample size† people/person-years): 1,598/NR | Duration: 6 years | Inclusion: Population born between 1917 and 1931. | Type: breast | Applicability: II
Voorrips, 2002^37^ | Age (mean/range): NR/55–69 | | Exclusion: Prevalent cancer at baseline, incomplete dietary data. | Ascertainment: Regional cancer registries | Funding source: Government
| Race: NR | | | | Quality:
| % male: NR | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: Y
| Location: Netherlands | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Norwegian National Health Screening Service Cohort | Sample size† people/person-years): 14,500/161,013 py | Duration: 14 years | Inclusion: Population of Norway born between 1925 and 1942. | Type: breast | Applicability: II
Vatten, 1990^41^ | Age (mean/range): NR/35–51 | | Exclusion: Prevalent cancer, including breast cancer, at baseline, incomplete questionnaires. | Ascertainment: National Cancer Registry | Funding source: NR
| Race: NR | | | | Quality:
| % male: NR | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: NR
| Location: Norway | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Nurses' Health Study | Sample size† people/person-years): 88,795/1,172,028 py (1980-1994) | Duration: 18 years | Inclusion: US female nurses born between 1921 and 1946. | Type: breast | Applicability: II
Holmes, 2003^43^ | 88,647/NR py (1980-1998) | | Exclusion: Prevalent breast cancer at baseline. | Ascertainment: self-report or vital records confirmed by medical records review | Funding source: Government
Holmes, 1999^44^ | Age (mean/range): 47/30–55 | | | | Quality:
| Race: NR | | | | Adjustment for confounders: Y
| % male: NR | | | | Blinded to exposure/outcome: Y
| # sites: 1 | | | | Valid ascertainment of outcome: Y
| Location: US | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Singapore Chinese Health Study | Sample size† people/person-years): 34,734/NR py | Duration: 7 years | Inclusion: Permanent residents or citizens of Singapore living in government housing estates‡ speaking Hokkien or Cantonese born between 1919 and 1953. | Type: breast | Applicability: II
Gago-Dominguez, 2003^51^ | Age (mean/range): NR/45–74 | | Exclusion: Previous cancer history. | Ascertainment: Singapore Cancer registry | Funding source: NR
| Race: NR | | | | Quality:
| % male: NR | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: NR
| Location: Singapore | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: N
Colorectal Cancer
HealthProfessionals Follow-up Study | Sample size† people/person-years): 47,949/264,680 py | Duration: 6 years | Inclusion: Male dentists, optometrists, osteopaths, podiatrists, pharmacists, and veterinarians born between 1911 and 1946 that responded to a postal questionnaire. | Type: colorectal | Applicability: II
Giovannucci, 1994^30^ | Age (mean/range): NR/40–75 | | Exclusion: Cancer (other than non-melanoma skin cancer)/Incomplete food frequency questionnaire. | Ascertainment: self-report or vital records confirmed by medical records review | Funding source: Government and private (non-industry)
| Race: Caucasian, Black, Asian | | | | Quality:
| % male: 100 | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: Y
| Location: US | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Iowa Women's Health Study | Sample size† people/person-years): 35,215/167,447 py | Duration: 5 years | Inclusion: Women with valid Iowa driver's license born between 1917 and 1931. | Type: colorectal | Applicability: II
Bostick, 1994^34^ | Age (mean/range): 62/55–69 | | Exclusion: Cancer (other than non-melanoma skin cancer)/Incomplete food frequency questionnaire/Dietary questionnaire with implausible total energy intake. | Ascertainment: State Health Registry of Iowa | Funding source: Government
| Race: Caucasian | | | | Quality:
| % male: NR | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: NR
| Location: US | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Netherlands Cohort Study | Sample size† people/person-years): 3,123/NR | Duration: 3.3 years | Inclusion: Population born between 1917 and 1931. | Type: colorectal | Applicability: II
Goldbohm, 1994^38^ | Age (mean/range): NR/59–69 | | Exclusion: Prevalent colon cancer at baseline; incomplete dietary questionnaire. | Ascertainment: Regional cancer registries | Funding source: Unclear
| Race: NR | | | | Quality:
| % male: 49 | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: NR
| Location: Netherlands | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: N
New York University Women's Health Study | Sample size† people/person-years): 14,727/105,044 py | Duration: 7.1 years | Inclusion: Women treated at the Guttman Breast Diagnostic Institute in New York City or at the Strax Breast Cancer Institute in Florida. | Type: colorectal | Applicability: III
Kato, 1997^40^ | Age (mean/range): NR/34–65 | | Exclusion: Pregnancy/Hormonal medications use. | Ascertainment: Self report confirmed by medical records review supplemented by review of state cancer registries and National Death index | Funding source: Government
| Race: Caucasian, Black, Hispanic | | | | Quality:
| % male: NR | | | | Adjustment for confounders: Y
| # sites: 2 | | | | Blinded to exposure/outcome: NR
| Location: US | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Nurses' Health Study | Sample size† people/person-years): 88,751/510,332 py | Duration: 6 years | Inclusion: US female registered nurses born between 1921 and 1946. | Type: colorectal | Applicability: II
Willett, 1990^46^ | Age (mean/range): NR/30–55 | | Exclusion: Cancer (other than non-melanoma skin cancer)/Dietary questionnaire with implausible total energy intake/Incomplete food frequency questionnaire. | Ascertainment: self-report or vital records confirmed by medical records review | Funding source: Government
| Race: NR | | | | Quality:
| % male: NR | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: Y
| Location: US | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Swedish women in mammography-screening program | Sample size† people/person-years): 61,463/NR | Duration: 11 years | Inclusion: Population-based mammography screening program participants who returned a questionnaire and were free of cancer. | Type: colorectal | Applicability: II
Terry, 2001^54^ | Age (mean/range): NR/NR | | Exclusion: NR | Ascertainment: Regional cancer registries | Funding source: Government
| Race: NR | | | | Quality:
| % male: NR | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: NR
| Location: Sweden | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: NR
Lung Cancer
Aichi Prefecture Cohort, Japan | Sample size† people/person-years): 5,885/76,928 py | Duration: 14 years | Inclusion: Inhabitants in a rural area of Aichi Prefecture, Japan, born between 1917 and 1972. | Type: lung and bronchus | Applicability: II
Takezaki, 2003^24^ | Age (mean/range): 57/40–79 | | Exclusion: Incomplete questionnaires | Ascertainment: Cancer registry | Funding source: Unclear
| Race: NR | | | | Quality:
| % male: 48 | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: NR
| Location: Japan | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Japan Collaborative Cohort | Sample size† people/person-years): 98,248/ 796,074py | Duration: 9 years | Inclusion: Population of 19 prefectures in Japan born between 1909 and 1950. | Type: lung | Applicability: II
Ozasa, 2001^36^ | Age (mean/range): NR/NR | | Exclusion: Lung cancer at baseline; non-response to survey questions about smoking. | Ascertainment: Death certificates | Funding source: Government
| Race: Asian | | | | Quality:
| % male: 42 | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: NR
| Location: Japan | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Norwegian Cohorts | Sample size† people/person-years): 16,713/NR | Duration: 11 years | Inclusion: Probability sample of Norway population. Male siblings living in Norway of migrants to the US; Family members, friends of subjects in case-control study of gastric cancer; "usable' dietary questionnaire. | Type: lung | Applicability: II
Kvale, 1983^56^ | Age (mean/range): NR/NR | | Exclusion: NR | Ascertainment: Cancer registry | Funding source: Government
| Race: Caucasian | | | | Quality:
| % male: 82 | | | | Adjustment for confounders: Y
| # sites: NR | | | | Blinded to exposure/outcome: NR
| Location: Norway | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Norwegian National Health Screening Service Cohort | Sample size† people/person-years): 51,452/578,047 py | Duration: 15 years | Inclusion: Residents of three Norwegian counties (Finnmark, Sogn og Fjordane, and Oppland) born between 1925 and 1942. | Type: lung and bronchus | Applicability: II
Veierod, 1997^42^ | Age (mean/range): NR/16–56 | | Exclusion: Cancer. | Ascertainment: National Cancer Registry | Funding source: Government and private (non-industry)
| Race: NR | | | | Quality:
| % male: 52 | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: NR
| Location: Norway | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Lymphoma, non-Hodgkin's
Iowa Women's Health Study | Sample size† people/person-years): 35,156/233,262 py | Duration: 6 years | Inclusion: Women with valid Iowa driver's license born between 1917 and 1931. | Type: lymphoma | Applicability: II
Chiu, 1996^35^ | Age (mean/range): NR/55–69 | | Exclusion: Prior history of cancer at any site except skin, prior use of cancer chemotherapy, incomplete questionnaire. | Ascertainment: State Health Registry of Iowa | Funding source: Government
| Race: NR | | | | Quality:
| % male: NR | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: NR
| Location: US | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Nurses' Health Study | Sample size† people/person-years): 88,410/1,169,326 py | Duration: 14 years | Inclusion: US female registered nurses born between 1921 and 1946. | Type: lymphoma | Applicability: II
Zhang, 1999^47^ | Age (mean/range): 47/34–60 | | Exclusion: Cancer (other than non-melanoma skin cancer)/Incomplete food frequency questionnaire/Dietary questionnaire with implausible total energy intake/Missing patient characteristics information. | Ascertainment: self-report or vital records confirmed by medical records review | Funding source: Government
| Race: Caucasian, Black, Hispanic, Asian, Pacific Islander | | | | Quality:
| % male: NR | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: Y
| Location: US | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Ovarian Cancer
Nurses' Health Study | Sample size† people/person-years): 80,258/NR | Duration: 15 years | Inclusion: US female registered nurses born between 1921 and 1946. | Type: genital | Applicability: II
Bertone, 2002^48^ | Age (mean/range): 46/30–55 | | Exclusion: Cancer (other than non-melanoma skin cancer)/Incomplete food frequency questionnaire/Dietary questionnaire with implausible total energy intake/Missing patient characteristics information. | Ascertainment: self-report or vital records confirmed by medical records review | Funding source: Government
| Race: NR | | | | Quality:
| % male: NR | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: Y
| Location: US | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Pancreatic Cancer
Alpha-tocopherol, Beta-Carotene Cancer Prevention Study | Sample size† people/person-years): 27,111/260,006 py | Duration: 12 years | Inclusion: Males who smoked at least 5 cigarettes per day and that participated in a RCT of the effects of alpha-tocopherol, beta-carotene, both or placebo. | Type: other gastrointestinal | Applicability: III
Stolzenberg-Solomon, 2002^25^ | Age (mean/range): NR/50–69 | | Exclusion: Cancer (other than nonmelanoma skin cancer)/Angina upon exertion/Renal disease/Alcoholism/Anticoagulant use/Medical problems which limit participation/Vitamins use. | Ascertainment: Tumor registry with medical records verification | Funding source: Government
| Race: NR | | | | Quality:
| % male: 100 | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: NR
| Location: Finland | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Nurses' Health Study | Sample size† people/person-years): 88,802/1,545,069 py | Duration: 18 years | Inclusion: US female registered nurses born between 1921 and 1946. | Type: other gastrointestinal | Applicability: II
Michaud, 2003^49^ | Age (mean/range): 47/30–55 | | Exclusion: Cancer (other than non-melanoma skin cancer)/Incomplete food frequency questionnaire/Dietary questionnaire with implausible total energy intake/Missing patient characteristics information. | Ascertainment: self-report or vital records confirmed by medical records review | Funding source: Government
| Race: Caucasian, Black, Hispanic, Asian, Pacific Islander | | | | Quality:
| % male: NR | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: Y
| Location: US | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Prostate Cancer
Hawaii Health Surveillance Program | Sample size† people/person-years): 8,881/NR | Duration: 14 years | Inclusion: Permanent residents of Hawaii. | Type: prostate | Applicability: II
LeMarchand, 1994^27^ | Age (mean/range): NR/NR | | Exclusion: Previous cancer history, prostate cancer within 5 years prior to interview, missing or unreliable survey data. | Ascertainment: Hawaii tumor registry | Funding source: Government
| Race: Caucasian, Asian, Pacific Islander | | | | Quality:
| % male: 100 | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: NR
| Location: US | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Health Professionals Follow-up Study | Sample size† people/person-years): 47,855/166,923 py | Duration: 5 years | Inclusion: Male dentists, optomotrists, oseopaths, podiatrists, pharmacists, and veterinarians that responded to a postal questionnaire born between 1911 and 1946. | Type: prostate | Applicability: II
Giovannucci, 1993^29^ | Age (mean/range): NR/40–75 | | Exclusion: Cancer (other than nonmelanoma skin cancer)/Incomplete food frequency questionnaire. | Ascertainment: self-report or vital records confirmed by medical records review | Funding source: Government and private (non-industry)
| Race: Caucasian, Black, Asian | | | | Quality:
| % male: 100 | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: Y
| Location: US | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
HealthProfessionals Follow-up Study | Sample size† people/person-years): 47,882/515,445 py | Duration: 12 years | Inclusion: Male dentists, optomotrists, oseopaths, podiatrists, pharmacists, and veterinarians that responded to a postal questionnaire born between 1911 and 1946. | Type: prostate | Applicability: II
Augustsson, 2003^28^ | Age (mean/range): NR/40–75 | | Exclusion: Cancer (other than nonmelanoma skin cancer)/Incomplete food frequency questionnaire. | Ascertainment: self-report or vital records confirmed by medical records review | Funding source: Government and private (non-industry)
| Race: NR | | | | Quality:
| % male: 100 | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: Y
| Location: US | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Netherlands Cohort Study | Sample size† people/person-years): 58,279/9,123 py | Duration: 6.3 years | Inclusion: Population born between 1917 and 1931. | Type: prostate | Applicability: II
Schuurman, 1999^39^ | Age (mean/range): 63/55–69 | | Exclusion: Prevalent cancer at baseline; incomplete or inconsistent dietary data. | Ascertainment: Regional cancer registries | Funding source: Government
| Race: NR | | | | Quality:
| % male: 100 | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: NR
| Location: Netherlands | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Seventh-day Adventist | Sample size† people/person-years): 14,000/66,926 py | Duration: 6 years | Inclusion: Seventh Day Adventist/Age 25 or older. | Type: prostate | Applicability: III
Mills, 1989^50^ | Age (mean/range): NR/NR | | Exclusion: Prostate cancer at baseline. | Ascertainment: Review of all hospital records, population based tumor registries | Funding source: Government
| Race: Caucasian | | | | Quality:
| % male: 100 | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: NR
| Location: US | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Swedish Twin Registry | Sample size† people/person-years): 6,272/133,839 py | Duration: 30 years | Inclusion: Twins living in Sweden in 1961 born between 1886 and 1925. | Type: prostate | Applicability: III
Terry, 2001^53^ | Age (mean/range): 56/43–82 | | Exclusion: Previous cancer history; death prior to assessment. | Ascertainment: Cancer registry | Funding source: Government
| Race: NR | | | | Quality:
| % male: 100 | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: NR
| Location: Sweden | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Skin Cancer
HealthProfessionals Follow-up Study | Sample size† people/person-years): 43,217/308,070 py | Duration: 8 years | Inclusion: Male dentists, optomotrists, oseopaths, podiatrists, pharmacists, and veterinarians that responded to a postal questionnaire born between 1911 and 1946. | Type: skin | Applicability: II
VanDam, 2000^31^ | Age (mean/range): NR/40–75 | | Exclusion: Cancer (other than non-melanoma skin cancer)/Incomplete food frequency questionnaire. | Ascertainment: self-report or vital records confirmed by medical records review | Funding source: Government and private (non-industry)
| Race: Caucasian, Black, Asian | | | | Quality:
| % male: 100 | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: Y
| Location: US | | | | Valid ascertainment of outcome: Y
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: Y
Stomach Cancer
Fukuoka Prefecture Cohort, Japan | Sample size† people/person-years): 13,000/139,390 py | Duration: 14 years | Inclusion: NR | Type: other gastrointestinal | Applicability: II
Ngoan, 2002^26^ | Age (mean/range): 59/15–96 | | Exclusion: Incomplete questionnaire | Ascertainment: | Funding source: Government
| Race: NR | | | | Quality:
| % male: 45 | | | | Adjustment for confounders: Y
| # sites: 1 | | | | Blinded to exposure/outcome: NR
| Location: Japan | | | | Valid ascertainment of outcome: NR
| | | | | Valid ascertainment of exposure: Y
| | | | | Description of withdrawals and dropouts: NR

* NR = not reported; Y = yes; N = no; py = person years;

† Number of people in cohort who met inclusion criteria for analysis of specified type of cancer;

‡ 86% of population lived in this type of housing at the time the cohort was formed.

Evidence Table C.1.2. Evidence table of the effects of fish consumption on the risk of developing cancer in cohort studies, by cancer type.*

Cohort | | Study arm (quartile, quintile or dose group) | Median dose | Cases | Exposure (person-years) | Estimates of effect
First Author, Year | | | | | | Age adjusted RR (95% CI) | | Multivariate RR (95% CI) | | Multivariate Adjustors
Aerodigestive Cancer
Honolulu Heart Program | | 1 | < 1 g/week | 46 | 4,335 | NR | | 1 | | Age, alcohol, # of cig./d, # of yrs smoke.
Chyou, 1995^32^ | | 2 | 2–4 g/week | 35 | 2,992 | NR | | 1.02 | (0.65, 1.61)
| | 3 | ≥ 5 g/week | 11 | 575 | NR | | 1.37 | (0.70, 2.69)
| | | | | | | | | p = 0.473†
Bladder Cancer
Honolulu Heart Program | | 1 | ≤ 1 times/week | 53 | NR | NR | | 1 | | Age, smoking.
Chyou, 1993^33^ | | 2 | 2–4 times/week | 36 | NR | NR | | 0.9 | (0.59, 1.39)
| | 3 | ≥ 5 times/week | 7 | NR | NR | | 0.67 | (0.26, 1.67)
| | | | | | | | | p = 0.377†
Breast Cancer
Diet, Cancer and Health Study | | 1 | 0–26 g/day | NR | NR | 1 | | 1 | | Age, parity, number of births, age at first birth, BMI, benign breast tumor, years of school, use of HRT, duration of HRT use, alcohol.
Stripp, 2003^55^ | | 2 | 27–39 g/day | NR | NR | 1.01 | (0.77. 1.32) | 0.99 | (0.76, 1.30)
| | 3 | 40–58 g/day | NR | NR | 1.17 | (0.89, 1.53) | 1.12 | (0.85, 1.47)
| | 4 | > 58 g/day | NR | NR | 1.54 | (1.18, 2.02) | 1.47 | (1.10, 1.98)
| | Total 23,693
Nurses' Health Study | | 1 | ≤ 0.13 servings/day | NR | NR | NR | | 1 | | Age, 2yr time period, total energy, alcohol intake, parity and age at first birth, BMI at age 18, weight change since 18, height in inches, family history of breast cancer, history of benign breast disease, age at menarche in years, menopausal status, age at menopausal and HRT use, duration of menopausal.
Holmes, 2003^43^ | | 2 | 0.14–0.20 servings/day | NR | NR | NR | | 0.98 | (0.89, 1.08)
| | 3 | 0.21–0.27 servings/day | NR | NR | NR | | 0.97 | (0.87, 1.08)
| | 4 | 0.28–0.39 servings/day | NR | NR | NR | | 0.99 | (0.90, 1.09)
| | 5 | ≤ 0.4 servings/day | NR | NR | NR | | 1.04 | (0.93, 1.14)
| | | | | | | | | p = 0.55†
Life Span Study | Fish (not dried) | 1 | ≤ 1 time/week | 99 | 125,089 | NR | | 1 | | Attained age, calendar period, city, age at time of bombing and radiation dose.
Key, 1999^52^ | | 2 | 2–4 times/week | 159 | 185,031 | NR | | 1.08 | (0.84, 1.39)
| | 3 | ≥ 5 times/week | 118 | 112,564 | NR | | 1.17 | (0.90, 1.54)
| | 4 | unknown | 51 | 66,305 | NR | | 0.92 | (0.66, 1.29)
| | | | | | | | | p = 0.21†
| Dried fish | 1 | ≤ 1 times/week | 259 | 256,264 | NR | | 1
| | 2 | 2–4 times/week | 64 | 81,898 | NR | | 0.85 | (0.64, 1.12)
| | 3 | ≥ 5 times/week | 7 | 16,264 | NR | | 0.49 | (0.24, 1.02)
| | 4 | unknown | 97 | 134,563 | NR | | 0.77 | (0.60, 0.98)
| | | | | | | | | p = 0.03†
Norwegian National Health Screening Service Cohort | | 1 | ≤ 2 times/week | 103 | 115,470 | 1 | | NR | | NR
Vatten, 1990^41^ | | 2 | > 2 times/week | 49 | 45,543 | 1.2 | (0.8, 1.7) | NR | NR
| | | | | | | p = 0.24†
Colorectal Cancer
HealthProfessionals Follow-up Study | | 1 | 8.4 g/d | 41 | 52,817 | 1 | | NR | | NR
Giovannucci, 1994^30^ | | 2 | 20.9 g/d | 35 | 53,071 | 0.85 | (0.54, 1.33) | NR
| | 3 | 31.0 g/d | 43 | 52,789 | 1.05 | (0.68, 1.61) | NR
| | 4 | 47.8 g/d | 35 | 52,788 | 0.80 | (0.51, 1.26) | NR
| | 5 | 83.4 g/d | 51 | 53,215 | 1.06 | (0.70, 1.60) | NR
| | | | | | | p = 0.79†
Netherlands Cohort Study | | 1 | 0 g/d | 70 | NR | NR | | 1 | | Age and energy.
Goldbohm, 1994^38^ | | 2 | 0–10 g/d | 53 | NR | NR | | 1 | (0.68, 1.47)
| | 3 | 10–20 g/d | 33 | NR | NR | | 0.74 | (0.48, 1.15)
| | 4 | > 20 g/d | 59 | NR | NR | | 0.81 | (0.56, 1.17)
| | | | | | | | | p = 0.14†
Nurses' Health Study | | 1 | < 1 g/month | 12 | 43,948 | 1 | | NR | | NR
Willett, 1990^46^ | | 2 | 1–3 g/month | 59 | 173,019 | 1.29 | (0.70, 2.40) | NR
| | 3 | 1 g/week | 54 | 200,732 | 0.92 | (0.49, 1.72) | NR
| | 4 | 2–4 g/week | 19 | 77,277 | 0.75 | (0.35, 1.58) | NR
| | 5 | 4 g/week | 5 | 15,356 | 1.06 | (0.36, 3.12) | NR
| | | | | | | p = 0.09†
New York University Women's Health Study | | 1 | NR | NR | NR | NR | | 1 | | Age, total calorie, place at enrollment and highest level of education.
Kato, 1997^40^ | | 2 | NR | NR | NR | NR | | 1.01 | (0.62, 1.67)
| | 3 | NR | NR | NR | NR | | 0.65 | (0.37, 1.13)
| | 4 | NR | NR | NR | NR | | 0.49 | (0.27, 0.89)
| | | | | | | | | p = 0.007†
Lung Cancer
Japan Collaborative Cohort | Men | 1 | ≤ 1–2 times/week | 184 | 150,457 | NR | | 1‡ | | Age, parent's history of lung cancer, smoking status, smoking index, time since quitting smoking.
Ozasa, 2001^36^ | | 2 | 3–4 times/week | 112 | 85,300 | NR | | 1.12 | (0.87, 1.43)
| | 3 | Almost every day | 91 | 69,552 | NR | | 1.03 | (0.79, 1.34)
| | | | | | | | | p = 0.72†
| Women | 1 | ≤ 1–2 times/week | 59 | 187,845 | NR | | 1‡
| | 2 | 3–4 times/week | 24 | 119,381 | NR | | 0.73 | (0.45, 1.21)
| | 3 | Almost every day | 22 | 95,004 | NR | | 0.88 | (0.52, 1.49)
| | | | | | | | | p = 0.50†
Aichi Prefecture Cohort, Japan | | 1 | < 1 times/week | 10 | 10,237 | NR | | 1 | | Age, sex, smoke, occupation.
Takezaki, 2003^24^ | | 2 | 1–2 times/week | 31 | 33,138 | NR | | 0.99 | (0.48, 2.03)
| | 3 | ≥ 3 times/week | 10 | 33,551 | NR | | 0.32 | (0.13, 0.76)
| | | | | | | | | p = 0.003†
Norwegian National Health Screening Service Cohort | | 1 | < 1 times/week | 9 | 37,979 | NR | | 1‡ | | Smoking status, gender, age at inclusion, attained age.
Veierod, 1997^42^ | | 2 | 1–2 times/week | 84 | 334,322 | NR | | 1.1 | (0.6, 2.2)
| | 3 | 3–4 times/week | 47 | 190,637 | NR | | 1.0 | (0.5, 2.1)
| | 4 | ≥ 5 times/week | 11 | 11,971 | NR | | 3.0 | (1.2, 7.3)
| | | | | | | | | p = 0.2†
Lymphoma, non-Hodgkin's
Iowa Women's Health Study | | 1 | < 4 servings/month | 32 | 67,337 | NR | | 1 | | Age and energy.
Chiu, 1996^35^ | | 2 | 4–6 servings/month | 42 | 91,914 | NR | | 0.94 | (0.59, 1.49)
| | 3 | > 6 servings/month | 30 | 74,011 | NR | | 0.81 | (0.49, 1.35)
| | | | | | | | | p = 0.42†
Pancreatic Cancer
Alpha-tocopherol, Beta-Carotene Cancer Prevention Study | | 1 | NR | NR | NR | NR | | 1 | | Energy intake by the residual method, age, and years of smoking, energy-adjusted saturated fat intake.
Stolzenberg-Solomon, 2002^25^ | | 2 | NR | NR | NR | NR | | 1.22 | (0.75, 1.97)
| | 3 | NR | NR | NR | NR | | 1.14 | (0.70, 1.86)
| | 4 | NR | NR | NR | NR | | 1.07 | (0.65, 1.76)
| | 5 | NR | NR | NR | NR | | 0.91 | (0.54, 1.52)
| | | | | | | | | p = 0.59†
Prostate Cancer
Health Professionals Follow-up Study | | 1 | < 2 g/month | 320 | 73,601 | 1 | | 1 | | Age, calories, fatty acid, lycopene, retinol, vitamin D and physical activity.
Augustsson, 2003^28^ | | 2 | 2 g/month-1 g/week | 487 | 99,162 | 1.06 | (0.92, 1.22) | 1.05 | (0.91, 1.21)
| | 3 | 2–3 g/week | 1,181 | 232,606 | 1.06 | (0.94, 1.20) | 1.06 | (0.93, 1.20)
| | 4 | > 3 g/week | 494 | 110,076 | 0.91 | (0.79, 1.05) | 0.93 | (0.80, 1.08)
Hawaii Health Surveillance Program | | 1 | NR | NR | NR | NR | | 1 | | Age, race, income.
LeMarchand, 1994^27^ | | 2 | NR | NR | NR | NR | | 1.1 | (0.7, 1.7)
| | 3 | NR | NR | NR | NR | | 0.9 | (0.6, 1.3)
| | 4 | NR | NR | NR | NR | | 1.2 | (0.8, 1.8)
| | | | | | | | | p = 0.55†
Seventh-day Adventist | | 1 | Never | 43 | 24,916 | 1 | | NR | | NR
Mills, 1989^50^ | | 2 | < 1 g/week | 86 | 34,413 | 1.68 | (1.16, 2.43) | NR
| | 3 | ≥ 1 g/week | 17 | 7,597 | 1.47 | (0.84, 2.60) | NR
| | | | | | | p = 0.03†
Swedish Twin Registry | | 1 | Never/seldom | 14 | 2,406 | 1.7 | (1.0, 3.0) | 2.3 | (1.2, 4.5) | Age, BMI, physical activity, smoking, consumption of alcohol, red meat, processed meat, fruit, vegetable and milk.
Terry, 2001^53^ | | 2 | Small | 201 | 55,753 | 1.1 | (0.9, 1.3) | 1.2 | (1.0, 1.4)
| | 3 | Moderate | 209 | 64,458 | 1 | | 1
| | 4 | Large | 42 | 11,222 | 1.1 | (0.8, 1.5) | 1.0 | (0.7, 1.6)
| | | | | | | p = 0.35† | | p = 0.05†
Stomach Cancer
Fukuoka Prefecture Cohort, Japan | | 1 | Low | 19 | 2,366 | NR | | 1 | | Age, sex, smoking, processed meat, liver, cooking or salad oil, suimono and pickled food.
Ngoan, 2002^26^ | | 2 | Medium | 58 | 7,219 | NR | | 1.1 | (0.5, 2.3)
Stomach cancer including first 3 years follow-up | | 3 | High | 30 | 2,780 | NR | | 1.0 | (0.4, 2.2)
| | | | | | | | | p = 0.05†
Fukuoka Prefecture Cohort, Japan | | 1 | Low | 19 | 2,366 | NR | | 1
Ngoan, 2002^26^ | | 2 | Medium | 58 | 7,219 | NR | | 0.9 | (0.4, 2.2)
Stomach cancer excluding first 3 years follow-up | | 3 | High | 30 | 2,780 | NR | | 0.9 | (0.3, 2.1)
| | | | | | | | | p = 0.05†

* NR= not reported;

† = test for trend;

‡ = Hazard Ratio;

‡ = Incidence Rate Ratio.

Evidence Table C.1.3. Evidence table of the effects of omega-3 consumption on the risk of developing cancer in cohort studies, by cancer type.*

Cohort | Study arm (quartile, quintile or dose group) | Median dose | Cases | Exposure (person- years) | Estimates of effect
First Author, Year | | | | | Age adjusted RR (95% CI) | | Multivariate RR (95% CI) | | Multivariate Adjustors
Breast Cancer
Singapore Chinese Health Study | 1 | NR | 88 | NR | NR | | 1 | | Age at baseline interview, year of recruitment, dialect group, education, daily alcohol drinker, family history of breast cancer, age when period became regular, number of live births.
Gago-Dominguez, 2003^51^ | 2 | NR | 73 | NR | NR | | 0.82 | (0.60, 1.12)
| 3 | NR | 74 | NR | NR | | 0.84 | (0.62, 1.15)
| 4 | NR | 79 | NR | NR | | 0.87 | (0.64, 1.18)
| | | | | | | | p = 0.40†
Colorectal Cancer
Iowa Women's Health Study | 1 | < 0.03 g/d | 62 | NR | 1 | | 1 | | Age, total energy intake, height, parity, total vitamin E, a total vitamin E by age interaction term, vitamin A supplement intake.
Bostick, 1994^34^ | 2 | 0.03–0.05 g/d | 46 | NR | 0.67 | NR | 0.82 | (0.55, 1.24)
| 3 | 0.06–0.10 g/d | 28 | NR | 0.61 | NR | 0.77 | (0.50, 1.17)
| 4 | 0.11–0.18 g/d | 44 | NR | 0.72 | NR | 0.96 | (0.64, 1.43)
| 5 | > 0.18 g/d | 32 | NR | 0.60 | NR | 0.70 | (0.45, 1.09)
| | | | | p = 0.04† | | | p = 0.26†
Lymphoma, non-Hodgkin's
Nurses' Health Study | 1 | 0.02 % of energy intake | 33 | NR | 1 | | 1 | | Age, total energy, length of follow-up, geographic region, cigarette smoke, height in inches, saturated and trans unsaturated fats, fruit, vegetable intake.
Zhang, 1999^47^ | 2 | 0.03 % of energy intake | 40 | NR | 1.2 | NR | 1.2 | NR
| 3 | 0.04 % of energy intake | 46 | NR | 1.3 | NR | 1.4 | NR
| 4 | 0.05 % of energy intake | 39 | NR | 1.1 | NR | 1.2 | NR
| 5 | 0.10 % of energy intake | 41 | NR | 1.1 | (0.7, 1.7) | 1.4 | (0.8, 2.2)
| | | | | | p = 0.90† | | NR
Pancreatic Cancer
Alpha-tocopherol, Beta-Carotene Cancer Prevention Study | 1 | NR | NR | NR | NR | | 1 | | Energy intake by the residual method, age, and years of smoking.
Stolzenberg-Solomon, 2002^25^ | 2 | NR | NR | NR | NR | | 0.97 | (0.60, 1.60)
| 3 | NR | NR | NR | NR | | 1.04 | (0.64, 1.69)
| 4 | NR | NR | NR | NR | | 1.16 | (0.72, 1.86)
| 5 | NR | NR | NR | NR | | 0.96 | (0.58, 1.58)
| | | | | | | | p = 0.90†
Prostate Cancer
HealthProfessionals Follow-up Study | 1 | 0.05 g/d | 22 | 32,290 | 1 | | NR | | NR
Giovannucci, 1993^29^ | 2 | 0.12 g/d | 32 | 35,643 | 1.34 | (0.78, 2.30) | NR
| 3 | 0.21 g/d | 24 | 30,807 | 1.05 | (0.59, 1.89) | NR
| 4 | 0.30 g/d | 24 | 35,639 | 0.92 | (0.51, 1.65) | NR
| 5 | 0.55 g/d | 24 | 32,787 | 0.90 | (0.51, 1.61) | NR
| | | | | | p = 0.30†
Skin, BCC
HealthProfessionals Follow-up Study | 1 | 0.07 g/d | 604 | 63,581 | 1 | | 1 | | Age, 2-year follow-up period, major ancestry, energy intake, BMI, hair color, frequency of routine physical examinations, cigarette smoking, mean annual solar radiation in region of residence, fat.
VanDam, 2000^31^ | 2 | 0.15 g/d | 590 | 62,641 | 0.98 | NR | 0.97 | (0.86, 1.09)
| 3 | 0.24 g/d | 644 | 61,641 | 1.07 | NR | 1.04 | (0.93, 1.17)
| 4 | 0.34 g/d | 642 | 60,495 | 1.07 | NR | 1.05 | (0.93, 1.18)
| 5 | 0.58 g/d | 710 | 59,712 | 1.14 | NR | 1.13 | (1.01, 1.27)
| | | | | p = 0.003† | | | p = 0.008†

* NR = not reported;

† = test for trend.

Evidence Table C.1.4. Evidence table of the effects of alpha-linolenic acid consumption on the risk of developing cancer in cohort studies, by cancer type.*

Cohort | Study arm (quartile, quintile, or dose group) | Median dose | Cases | Exposure (person- years) | Estimates of effect
First Author, Year | | | | | Age adjusted RR (95% CI) | | Multivariate RR (95% CI) | | Multivariate Adjustors
Breast Cancer
Netherlands Cohort Study | 1 | 0.6 g/d | 194 | NR | 1 | | 1 | | Age, history of benign breast cancer, breast cancer in one or more sisters, age at menarche, age at menopause, oral contraceptive use, parity, age at first childbirth, Quetelet index, education, alcohol use, current cigarette smoking, total energy intake, total energy-adjusted fat intake.
Voorips, 2002^37^ | 2 | 0.8 g/d | 145 | NR | 0.76 | (0.58, 1.00) | 0.78 | (0.57, 1.05)
| 3 | 1.0 g/d | 187 | NR | 0.92 | (0.71, 1.20) | 1.03 | (0.76, 1.39)
| 4 | 1.3 g/d | 133 | NR | 0.69 | (0.52, 0.91) | 0.74 | (0.54, 1.00)
| 5 | 1.7 g/d | 124 | NR | 0.68 | (0.51, 0.91) | 0.70 | (0.51, 0.97)
| | | | | | p = 0.001† | | p = 0.006†
Colorectal Cancer
Swedish women in mammography-screening program | 1 | 0.45 g/d | NR | NR | NR | | 1 | | Age, BMI, education level, energy intake, intakes of red meat and alcohol, energy, dietary fiber, calcium, vitamin C, folic acid, Vitamin D, saturated fat, monounsaturated fat, polyunsaturated fat.
Terry, 2001^54^ | 2 | 0.50 g/d | NR | NR | NR | | 0.96 | (0.68, 1.35)
| 3 | 0.54 g/d | NR | NR | NR | | 0.96 | (0.67, 1.37)
| 4 | 0.70 g/d | NR | NR | NR | | 0.90 | (0.63, 1.28)
| | | | | | | | p = 0.57†
| 1 | 0.45 g/d | NR | NR | NR | | 1
| 2 | 0.50 g/d | NR | NR | NR | | 0.96 | (0.73, 1.27)
| 3 | 0.54 g/d | NR | NR | NR | | 0.96 | (0.72, 1.28)
| 4 | 0.70 g/d | NR | NR | NR | | 0.99 | (0.75, 1.32)
| | | | | | | | p = 0.99†
| 1 | 0.45 g/d | NR | NR | NR | | 1
| 2 | 0.50 g/d | NR | NR | NR | | 0.95 | (0.60, 1.52)
| 3 | 0.54 g/d | NR | NR | NR | | 0.92 | (0.56, 1.49)
| 4 | 0.70 g/d | NR | NR | NR | | 1.11 | (0.70, 1.78)
Ovarian Cancer
Nurses' Health Study | 1 | NR | 71 | NR | 1.0 | | 1.0 | | Age, parity, age at menarche, oral contraceptive use and duration, menopausal status/postmenopausal hormone use, smoking status.
Bertone, 2002^48^ | 2 | NR | 52 | NR | 0.74 | NR | 0.95 | (0.68, 1.33)
| 3 | NR | 45 | NR | 0.62 | NR | 0.80 | (0.56, 1.14)
| 4 | NR | 62 | NR | 0.86 | NR | 0.82 | (0.58, 1.15)
| 5 | NR | 71 | NR | 0.98 | NR | 0.88 | (0.62, 1.24)
| | | | | | | | p = 0.27†
Pancreatic Cancer
Nurses' Health Study | 1 | 0.7 g/d | 42 | 303,896 | 1 | | 1 | | Pack-years of smoking, BMI, history of diabetes mellitus, caloric intake, height, physical activity, menopausal status, glycemic load intake.
Michaud, 2003^49^ | 2 | 0.8 g/d | 40 | 304,791 | 1.03 | NR | 1.08 | (0.70, 1.67)
| 3 | 0.9 g/d | 39 | 315,822 | 1 | NR | 1.03 | (0.66, 1.61)
| 4 | 1.0 g/d | 29 | 318,512 | 0.75 | NR | 0.80 | (0.49, 1.30)
| 5 | 1.1 g/d | 28 | 302,048 | 0.76 | NR | 0.77 | (0.47, 1.26)
| | | | | p = 0.12† | | | p = 0.16†
Alpha-tocopherol, Beta-Carotene Cancer Prevention Study | 1 | NR | NR | NR | NR | | 1 | | Energy intake by the residual method, age, and years of smoking, energy-adjusted saturated fat intake.
Stolzenberg-Solomon, 2002^25^ | 2 | NR | NR | NR | NR | | 1.09 | (0.69, 1.73)
| 3 | NR | NR | NR | NR | | 1.10 | (0.68, 1.79)
| 4 | NR | NR | NR | NR | | 1.04 | (0.61, 1.77)
| 5 | NR | NR | NR | NR | | 1.11 | (0.65, 1.91)
| | | | | | | | p = 0.77†
Prostate Cancer
Health Professionals Follow-up Study | 1 | <0.37% of energy | 300 | NR | 1.0 | | 1.0 | | Age, time period, major ancestry, family history of prostate cancer, BMI at age 21, height, type 2 diabetes, vasectomy, cigarettes in past decade, vigorous physical activity, intake of total energy, % energy from protein, % energy from monounsaturated fat, % energy from saturated fat, % energy from trans unsaturated fats, and intakes of calcium, supplemental vitamin E and lycopene.
Leitzmann, 2004^57^ | 2 | 0.37–0.43% of energy | 349 | NR | 1.08 | NR | 1.04 | (0.89, 1.22)
Prostate cancer excluding stage A-1 | 3 | 0.44–0.49% of energy | 354 | NR | 1.12 | NR | 1.05 | (0.89, 1.25)
| 4 | 0.50–0.58% of energy | 379 | NR | 1.24 | NR | 1.16 | (0.97, 1.39)
| 5 | >0.58% of energy | 297 | NR | 1.11 | NR | 1.04 | (0.85, 1.27)
| | | | | p = 0.10† | | | p = 0.54†
Health Professionals Follow-up Study | 1 | <0.37% of energy | 82 | NR | 1.0 | | 1.0
Leitzmann, 2004^57^ | 2 | 0.37–0.43% of energy | 89 | NR | 1.33 | NR | 1.47 | (1.07, 2.01)
Advanced prostate cancer | 3 | 0.44–0.49% of energy | 87 | NR | 1.41 | NR | 1.57 | (1.12, 2.21)
| 4 | 0.50–0.58% of energy | 90 | NR | 1.53 | NR | 1.77 | (1.24, 2.53)
| 5 | >0.58% of energy | 100 | NR | 1.69 | NR | 1.98 | (1.34, 2.93)
| | | | | p = 0.0005† | | | p = 0.001†
Netherlands Cohort Study | 1 | 0.7 g/d | 154 | 1,802 | 1 | | 1 | | Age, family history of prostate carcinoma, socioeconomic status, total energy intake, total energy-adjusted fat intake.
Schuurman, 1999^39^ | 2 | 1.1 g/d | 126 | 1,820 | 0.80 | (0.59, 1..08) | 0.76 | (0.55, 1.05)
| 3 | 1.3 g/d | 125 | 1,808 | 0.82 | (0.61, 1.11) | 0.82 | (0.60, 1.13)
| 4 | 1.7 g/d | 123 | 1,838 | 0.80 | (0.59, 1.08) | 0.80 | (0.59, 1.10)
| 5 | 2.1 g/d | 114 | 1,855 | 0.76 | (0.56, 1.03) | 0.76 | (0.66, 1.04)
| | | | | p = 0.04 | | | p = 0.09

* NR = not reported;

† = test for trend.

Evidence Table C.1.5. Evidence table of the effects of EPA consumption on the risk of developing cancer in cohort studies, by cancer type.*

Cohort | Study arm (quartile, quintile or dose group) | Median dose | Cases | Exposure (person-years) | Estimates of effect
First Author, Year | | | | | Age adjusted RR (95% CI) | | Multivariate RR (95% CI) | | Multivariate Adjustors
Breast Cancer
Netherlands Cohort Study | 1 | 0 g/d | 152 | NR | 1 | | 1 | | Age, history of benign breast cancer, breast cancer in one or more sisters, age at menarche, age at menopause, oral contraceptive use, parity, age at first childbirth, Quetelet index, education, alcohol use, current cigarette smoking, total energy intake, total energy-adjusted fat intake.
Voorips, 2002^37^ | 2 | 0.01 g/d | 145 | NR | 1.18 | (0.88, 1.56) | 1.15 | (0.84, 1.58)
| 3 | 0.02 g/d | 170 | NR | 1.14 | (0.87, 1.50) | 1.10 | (0.82, 1.49)
| 4 | 0.04 g/d | 172 | NR | 1.23 | (0.93, 1.62) | 1.22 | (0.90, 1.65)
| 5 | 0.08 g/d | 144 | NR | 1.03 | (0.78, 1.37) | 0.98 | (0.72, 1.35)
| | | | | | p = 0.63† | | p = 0.87†
Colorectal Cancer
Swedish women in mammography-screening program | 1 | 0.03 g/d | NR | NR | NR | | 1 | | Age, BMI, education level, energy intake, intakes of red meat and alcohol, energy, dietary fiber, calcium, vitamin C, folic acid, Vitamin D, saturated fat, monounsaturated fat, polyunsaturated fat.
Terry, 2001^54^ | 2 | 0.05 g/d | NR | NR | NR | | 0.76 | (0.54, 1.06)
| 3 | 0.07 g/d | NR | NR | NR | | 0.81 | (0.58, 1.15)
| 4 | 0.09 g/d | NR | NR | NR | | 0.85 | (0.60, 1.21)
| | | | | | | | p = 0.46†
| 1 | 0.03 g/d | NR | NR | NR | | 1
| 2 | 0.05 g/d | NR | NR | NR | | 0.80 | (0.68, 1.15)
| 3 | 0.07 g/d | NR | NR | NR | | 0.96 | (0.73, 1.26)
| 4 | 0.09 g/d | NR | NR | NR | | 0.96 | (0.72, 1.28)
| | | | | | | | p = 0.91†
| 1 | 0.03 g/d | NR | NR | NR | | 1
| 2 | 0.05 g/d | NR | NR | NR | | 1.17 | (0.75, 1.83)
| 3 | 0.07 g/d | NR | NR | NR | | 1.29 | (0.80, 2.06)
| 4 | 0.09 g/d | NR | NR | NR | | 1.25 | (0.75, 2.06)
| | | | | | | | p = 0.35†
Ovarian Cancer
Nurses' Health Study | 1 | NR | 45 | NR | 1 | | 1 | | Age, parity, age at menarche, oral contraceptive use and duration, menopausal status/postmenopausal hormone use, smoking status.
Bertone, 2002^48^ | 2 | NR | 40 | NR | 1.01 | NR | 1.04 | (0.68, 1.59)
| 3 | NR | 32 | NR | 0.73 | NR | 0.75 | (0.47, 1.17)
| 4 | NR | 43 | NR | 0.96 | NR | 1.00 | (0.66, 1.52)
| 5 | NR | 43 | NR | 0.96 | NR | 0.97 | (0.64, 1.48)
| | | | | | | | p = 0.80†
Prostate Cancer
Health Professionals Follow-up Study | 1 | <0.014% of energy | 282 | NR | 1.0 | | 1.0 | | Age, time period, major ancestry, family history of prostate cancer, BMI at age 21, height, type 2 diabetes, vasectomy, cigarettes in past decade, vigorous physical activity, intake of total energy, % energy from protein, % energy from monounsaturated fat, % energy from saturated fat, % energy from trans unsaturated fats, and intakes of calcium, supplemental vitamin E and lycopene.
Leitzmann, 2004^57^ | 2 | 0.014–0.027% of energy | 353 | NR | 1.14 | NR | 1.09 | (0.93, 1.28)
Prostate cancer excluding stage A-1 | 3 | 0.028–0.042% of energy | 347 | NR | 1.06 | NR | 1.02 | (0.87, 1.21)
| 4 | 0.043–0.066% of energy | 343 | NR | 1.03 | NR | 0.97 | (0.81, 1.15)
| 5 | >0.066% of energy | 354 | NR | 0.92 | NR | 0.87 | (0.72, 1.06)
| | | | | p = 0.04† | | | p = 0.03†
Health Professionals Follow-up Study | 1 | <0.014% of energy | 87 | NR | 1.0 | | 1.0
Leitzmann, 2004^57^ | 2 | 0.014–0.027% of energy | 92 | NR | 1.01 | NR | 1.05 | (0.75, 1.37)
Advanced prostate cancer | 3 | 0.028–0.042% of energy | 94 | NR | 1.03 | NR | 0.99 | (0.73, 1.35)
| 4 | 0.043–0.066% of energy | 86 | NR | 0.89 | NR | 0.87 | (0.63, 1.21)
| 5 | >0.066% of energy | 89 | NR | 0.82 | NR | 0.82 | (0.58, 1.17)
| | | | | p = 0.08† | | | p = 0.18†
Netherlands Cohort Study | 1 | 0 g/d | 135 | 1,918 | 1 | | 1 | | Age, family history of prostate carcinoma, socioeconomic status, total energy intake, total energy-adjusted fat intake.
Schuurman, 1999^39^ | 2 | 0.01 g/d | 102 | 1,853 | 0.69 | (0.50, 0.95) | 0.66 | (0.47, 0.91)
| 3 | 0.03 g/d | 125 | 1,790 | 0.94 | (0.69, 1.28) | 0.92 | (0.67, 1.27)
| 4 | 0.05 g/d | 138 | 1,771 | 1.06 | (0.79, 1.46) | 1.05 | (0.77, 1.44)
| 5 | 0.10 g/d | 142 | 1,790 | 1.01 | (0.75, 1.37) | 1.00 | (0.73, 1.35)
| | | | | | p = 0.11† | | p = 0.10†

* NR = not reported;

† = test for trend.

Evidence Table C.1.6. Evidence table of the effects of DHA consumption on the risk of developing cancer in cohort studies, by cancer type.*

Cohort | Study arm (quartile, quintile or dose group) | Median dose | Cases | Exposure (person-years) | Estimates of effect
First Author, Year | | | | | Age adjusted RR (95% CI) | | Multivariate RR (95% CI) | | Multivariate Adjustors
Breast Cancer
Netherlands Cohort Study | 1 | 0.01 g/d | 147 | NR | 1 | | 1 | | Age, history of benign breast cancer, breast cancer in one or more sisters, age at menarche, age at menopause, oral contraceptive use, parity, age at first childbirth, Quetelet index, education, alcohol use, current cigarette smoking, total energy intake, total energy-adjusted fat intake.
Voorips, 2002^37^ | 2 | 0.03 g/d | 156 | NR | 1.11 | (0.83, 1.47) | 1.10 | (0.81, 1.51)
| 3 | 0.05 g/d | 158 | NR | 1.04 | (0.78, 1.37) | 1.03 | (0.76, 1.40)
| 4 | 0.08 g/d | 176 | NR | 1.20 | (0.91, 1.58) | 1.21 | (0.90, 1.64)
| 5 | 0.14 g/d | 146 | NR | 1.02 | (0.77, 1.36) | 1.00 | (0.72, 1.37)
| | | | | | p = 0.62† | | p = 0.70†
Colorectal Cancer
Swedish women in mammography-screening program | 1 | 0.08 g/d | NR | NR | NR | | 1 | | Age, BMI, education level, energy intake, intakes of red meat and alcohol, energy, dietary fiber, calcium, vitamin C, folic acid, Vitamin D, saturated fat, monounsaturated fat, polyunsaturated fat.
Terry, 2001^54^ | 2 | 0.11 g/d | NR | NR | NR | | 0.84 | (0.60, 1.17)
| 3 | 0.13 g/d | NR | NR | NR | | 0.74 | (0.51, 1.06)
| 4 | 0.18 g/d | NR | NR | NR | | 0.88 | (0.61, 1.26)
| | | | | | | | p = 0.41†
| 1 | 0.08 g/d | NR | NR | NR | | 1
| 2 | 0.11 g/d | NR | NR | NR | | 0.88 | (0.67, 1.15)
| 3 | 0.13 g/d | NR | NR | NR | | 0.87 | (0.66, 1.15)
| 4 | 0.18 g/d | NR | NR | NR | | 0.90 | (0.67, 1.20)
| | | | | | | | p = 0.49†
| 1 | 0.08 g/d | NR | NR | NR | | 1
| 2 | 0.11 g/d | NR | NR | NR | | 1.03 | (0.66, 1.61)
| 3 | 0.13 g/d | NR | NR | NR | | 1.16 | (0.73, 1.84)
| 4 | 0.18 g/d | NR | NR | NR | | 1.03 | (0.62, 1.71)
| | | | | | | | p = 0.79†
Ovarian Cancer
Nurses' Health Study | 1 | NR | 43 | NR | 1 | | 1 | | Age, parity, age at menarche, oral contraceptive use and duration, menopausal status/postmenopausal hormone use, smoking status.
Bertone, 2002^48^ | 2 | NR | 46 | NR | 1.06 | NR | 1.06 | (0.70, 1.61)
| 3 | NR | 28 | NR | 0.67 | NR | 0.67 | (0.42, 1.08)
| 4 | NR | 47 | NR | 1.05 | NR | 1.07 | (0.71, 1.63)
| 5 | NR | 39 | NR | 0.88 | NR | 0.86 | (0.55, 1.33)
| | | | | | | | p = 0.52†
Prostate Cancer
Health Professionals Follow-up Study | 1 | <0.032% of energy | 273 | NR | 1.0 | | 1.0 | | Age, time period, major ancestry, family history of prostate cancer, BMI at age 21, height, type 2 diabetes, vasectomy, cigarettes in past decade, vigorous physical activity, intake of total energy, % energy from protein, % energy from monounsaturated fat, % energy from saturated fat, % energy from trans unsaturated fats, and intakes of calcium, supplemental vitamin E and lycopene.
Leitzmann, 2004^57^ | 2 | 0.032–0.053% of energy | 349 | NR | 1.16 | NR | 1.13 | (0.96, 1.33)
Prostate cancer excluding stage A-1 | 3 | 0.054–0.079% of energy | 333 | NR | 1.03 | NR | 0.99 | (0.83, 1.17)
| 4 | 0.080–0.122% of energy | 350 | NR | 1.03 | NR | 0.99 | (0.83, 1.19)
| 5 | >0.122% of energy | 374 | NR | 1.03 | NR | 1.02 | (0.84, 1.25)
| | | | | p = 0.63† | | | p = 0.77†
Health Professionals Follow-up Study | 1 | <0.032% of energy | 94 | NR | 1.0 | | 1.0
Leitzmann, 2004^57^ | 2 | 0.032–0.053% of energy | 82 | NR | 0.84 | NR | 0.79 | (0.58, 1.07)
Advanced prostate cancer | 3 | 0.054–0.079% of energy | 94 | NR | 0.91 | NR | 0.84 | (0.62, 1.15)
| 4 | 0.080–0.122% of energy | 89 | NR | 0.86 | NR | 0.82 | (0.59, 1.13)
| 5 | >0.122% of energy | 89 | NR | 0.73 | NR | 0.71 | (0.49, 1.08)
| | | | | p = 0.06† | | | p = 0.13†
Netherlands Cohort Study | 1 | 0.01 g/d | 124 | 1,846 | 1 | | 1 | | Age, family history of prostate carcinoma, socioeconomic status, total energy intake, total energy-adjusted fat intake.
Schuurman, 1999^39^ | 2 | 0.03 g/d | 111 | 1,834 | 0.82 | (0.60, 1.13) | 0.81 | (0.58, 1.11)
| 3 | 0.06 g/d | 128 | 1,811 | 1.01 | (0.74, 1.38) | 1.00 | (0.73, 1.38)
| 4 | 0.09 g/d | 139 | 1,836 | 1.07 | (0.79, 1.46) | 1.09 | (0.80, 1.49)
| 5 | 0.18 g/d | 140 | 1,796 | 1.05 | (0.77, 1.42) | 1.03 | (0.75, 1.40)
| | | | | | p = 0.19† | | p = 0.19†

* NR = not reported;

† = test for trend.

Evidence Table C.2.1. Evidence table of clinical trials of the clinical effects of omega-3 fatty acids on clinical outcomes after cancer treatment.*

First Author, Year | Study Characteristics | Study Design Duration | Eligibility criteria | Cancer treatment | Arm | Interventions Dosage/Duration
Braga, 2002^64^ | Sample size: 200 | Design: RCT | Inclusion: Histologically proven GI neoplasm/Undergoing abdominal surgery/Age=18 | Surgery | 1 | Standard hospital diet 1.0 liter/variable days
| Age (mean/range): 62/18–99 | Duration: 8 days | Exclusion: Evidence of infection/Renal disease/Impaired liver function/Pulmonary dysfunction/Vegetarianism/Pregnancy | | 2 | Isoenergetic control diet 1.0 liter/variable days
| Race: NR | | | | 3 | N3 fatty acids, Arginine 1.0 liter/variable days
| % male: 59 | | | | 4 | N3 fatty acids, Arginine 1.0 liter/variable days
| # sites: 1
| Location: Italy
Braga, 2002^65^ | Sample size: 150 | Design: RCT | Inclusion: Undergoing abdominal surgery/Weight loss/Histologically proven GI neoplasm | Surgery | 1 | Enteral standard diet Standard hospital diet plus N6 polyunsaturated fat
| Age(mean/range): 65/NR | Duration: Variable | Exclusion: Evidence of infection/Pregnancy/Impaired liver function/Pulmonary dysfunction/Karnofsky score<60/Cardiacdysfunction/Immunedisorders | | 2 | Enteral standard diet plus N6 polyunsaturated fat
| Race: NR | | | | 3 | Enteral standard diet N3 fatty acids plus N6 polyunsaturated fat
| % male: 56
| # sites: 1
| Location: Italy
Braga, 1995^66^ | Sample size: 77 | Design: RCT | Inclusion: Upper gastro intestinal malignancies/Undergoing abdominal surgery | Surgery | 1 | Isocaloric TPN variable dose
| Age (mean/range): 6/NR | Duration: 11 days | Exclusion: NR | | 2 | Omega6 fatty acids variable dose
| Race:NR | | | | 3 | N3 fatty acids, Arginine variable dose
| % male: NR
| # sites: 1
| Location: Italy
Braga, 1999^67^ | Sample size: 171 | Design: RCT | Inclusion: Undergoing abdominal surgery/Colorectal cancer/Upper gastrointestinal malignancies | Surgery | 1 | Isoenergetic control diet 1.0 Liter/day
| Age (mean/range):61/18–75 | Duration: 7 days | Exclusion: Impaired liver function/Pulmonary dysfunction/Cardiac dysfunction/Renal disease/Immunosuppressive medications use/Radiation therapy/Immune disorders/Evidence of infection | | 2 | Fish oil, Arginine 1.0 Liter/day
| Race: NR
| % male: 62
| # sites: 1
| Location: Italy
Daly, 1992^68^ | Sample size: 85 | Design: RCT | Inclusion: Upper gastrointestinal malignancies/Undergoing abdominal surgery/Normal renal function/Normal hepatic function | Surgery | 1 | Enteral standard diet variable dose plus Linoleic acid
| Age (mean/range): 63/NR | Duration: 7 days | Exclusion: History benign intestinal disease/Previous abdominal or pelvic radio therapy/Evidence of infection/Steroids use | | 2 | EPA+DHA variable dose plus Linoleic acid
| Race: NR
| % male: 64
| # sites: 1
| Location: US
Daly, 1995^69^ | Sample size: 60 | Design: RCT | Inclusion: Upper gastrointestinal malignancies/Undergoing abdominal surgery/Normal renal function/Normal hepatic function | Surgery, chemotherapy, and radiation | 1 | Enteral standard diet variable dose
| Age (mean/range): 61/NR | Duration: Variable | Exclusion: History benign intestinal disease/Previous abdominal or pelvicradio therapy/Evidence of infection/Steroids use | | 2 | Enteral standard diet variable dose
| Race: NR | | | | 3 | EPA+DHA variable dose plus Linoleic acid
| % male: 68 | | | | 4 | EPA+DHA variable dose plus Linoleic acid
| # sites: 1
| Location: US
Di Carlo, 1999^70^ | Sample size: 100 | Design: RCT | Inclusion: Undergoing abdominal surgery | Surgery | 1 | Standard enteral formula variable dose
| Age (mean/range): 62/NR | Duration: Variable | Exclusion: NR | | 2 | Standard TPN variable dose
| Race: NR | | | | 3 | N3 fatty acids, Arginine variable dose
| % male: 62
| # sites: 1
| Location: Italy
Fearon, 2003^76^ | Sample size: 110 | Design: RCT | Inclusion: Upper gastrointestinal malignancies/Weight-losing cancer patients/Histologically proven GI neoplasm | Surgery | 1 | Isoenergetic control diet 474.0 ml/day
| Age (mean/range): 68/NR | Duration: 8 weeks | Exclusion: Karnofsky score<60/Chemotherapeutic treatment/Radiation therapy/Elective surgery/Renal disease/Diabetes mellitus/HIV/AIDS/Systemic medication or supplement use | | 2 | N3 fatty acids 474.0ml/day plus Vitamin E, Vitamin C, Selenium
| Race: NR
| % male: 55
| # sites: 12
| Location: Australia, Italy, Netherlands, UK, Canada, and Belgium
Gianotti, 1999^77^ | Sample size: 50 | Design: RCT | Inclusion: Upper gastrointestinal malignancies/Undergoing abdominal surgery/Colorectal cancer | Surgery | 1 | Enteral standard diet 1.0 Liter/DY X 14.0 DY plus N6 polyunsaturated fat
| Age (mean/range): 62/NR | Duration: 14 days | Exclusion: Immunosuppressive medications use/Evidence of infection/Chemotherapeutic treatment/Previous abdominal or pelvic radiotherapy/Renal disease/Impaired liver function/Cardiac dysfunction/Need for emergency | | 2 | 'N3 fatty acids 1.0 Liter/DY X 14.0 DY plus N6 polyunsaturated fat
| Race: NR
| % male: 60
| # sites: 1
| Location: Italy
Gianotti, 1997^71^ | Sample size: 260 | Design: RCT | Inclusion: Upper gastrointestinal malignancies/Undergoing abdominal surgery | Surgery | 1 | Enteral standard diet variable dose
| Age (mean/range): 64/NR | Duration: 7 days | Exclusion: Renal disease/Impaired liver function/Pulmonary dysfunction/Cardiac dysfunction/Evidence of infection/Immune disorders | | 2 | Standard TPN variable dose
| Race: NR | | | | 3 | N3 fatty acids variable dose
| % male: 56
| # sites: 1
| Location: Italy
Heller, 2004^75^ | Sample size: 44 | Design: RCT | Inclusion: Carcinoma of the gastrointestinal tract or pancreas/Undergoing abdominal surgery | Surgery | 1 | TPN
| Age (mean/range): 61/NR | Duration: 5 days | Exclusion: Age<18or>80 years, ASA status>3, BMI<16or>30, hypertiglyceridemia, pregnancy, hyperthyroidism, chronic liver disease, pancreatitis, HIV infection, hepatitis, severe cardiac or renal disease or medication with insulin, corticosteroids, cytostatics or cycoloxygenase inhibitors. | | 2 | TPN containing omega-3 fatty acids
| Race: NR
| % male: 73
| # sites: 1
| Location: Germany
Kenler, 1996^61^ | Sample size: 35 | Design: RCT | Inclusion: Upper gastrointestinal malignancies/Undergoing abdominal surgery | Surgery | 1 | Soybean oil, Osmolite dosage NR plus Vitamin E, Vitamin C
| Age (mean/range): 64/18–80 | Duration: 7 days | Exclusion: Evidence of infection/Steroids use/Renal disease/Cardiac dysfunction/HIV/AIDS | | 2 | Fish oil, Soybean oil, Canola oil dosage variable plus Vitamin E, Vitamin C
| Race: NR
| % male: 74
| # sites: 1
| Location: US
McCarter, 1998^62^ | Sample size: 38 | Design: RCT | Inclusion: Upper gastrointestinal malignancies/Undergoing abdominal surgery/Age=18 | Surgery | 1 | Standard nutritional supplement, Soybean oil dosage NR plus Vitamin C, Retinol, Carotene, Vitamin E
| Age (mean/range): 64/NR | Duration: 30 days | Exclusion: Evidence of infection/Immunosuppressive medications use/Impaired liver function/Serum creatinine>2 mg/dl/Radiation therapy/HIV/AIDS/Diabetes mellitus/Pregnancy | | 2 | Standard nutritional supplement, Arginine, Soybean oil dosage NR plus Vitamin C, Retinol, Carotene, Vitamin E
| Race: NR | | | | 3 | Fish, Standard nutritional supplement, Arginine, Soybean oil dosage NR plus Vitamin C, Retinol, Carotene, Vitamin E
| % male: 55
| # sites: 1
| Location: US
Preshaw, 1979^79^ | Sample size: 47 | Design: CCT | Inclusion: Upper gastrointestinal malignancies/Undergoing abdominal surgery/Age=75 | Surgery | 1 | IV fluids, Amino acids dosage variable
| Age (mean/range): 68/NR | Duration: 6 days | Exclusion: Cardiac dysfunction | | 2 | IV fluids, Soybean oil, Amino acids dosage variable
| Race: NR
| % male: NR
| # sites: 1
| Location: Canada
Schilling, 1996^72^ | Sample size: 41 | Design: RCT | Inclusion: Upper gastrointestinal malignancies/Undergoing abdominal surgery | Surgery | 1 | Enteral standard diet dosage NR
| Age (mean/range): 59/NR | Duration: 10 days | Exclusion: Renal disease/Food allergy history/Pregnancy/Evidence of infection/Steroids use/Immunosuppressive medications use/Radiation therapy/Diabetes mellitus | | 2 | IV fluids dosage NR
| Race: NR | | | | 3 | N3 fatty acids, Arganine, omega-6 fatty acids dosage NR plus Selenium
| % male: 54
| # sites: 1
| Location: Switzerland
Senkal, 1997^74^ | Sample size: 154 | Design: RCT | Inclusion: Upper gastrointestinal malignancies/Undergoing abdominal surgery/Minimum uptake of 3000 of study diet preoperatively | Surgery | 1 | Isoenergetic control diet, omega-6 fatty acids variable dosage plus n-6 poly unsaturated fat, Vitamin C, Retinol, Tocopherols, Selenium, Molybdenum
| Age (mean/range): 66/18–80 | Duration: 31 days | Exclusion: Immunosuppressive medications use/Radiation therapy/Chemotherapeutic treatment/Immune disorders/Diabetes mellitus/Pregnancy | | 2 | N3 fatty acids, Arginine, omega-6 fatty acids variable dosage plus n-6 polyunsaturated fat, Vitamin C, Retinol, Tocopherols, Selenium, Molybdenum
| Race: NR
| % male: NR
| # sites: 3
| Location: Germany
Senkal, 1999^73^ | Sample size: 154 | Design: RCT | Inclusion: Upper GI surgery/Histologically proven GI neoplasm/Minimum uptake of 3000 of study diet preoperatively | Surgery | 1 | Isoenergetic control diet, Standard hospital diet dosage NR plus Linoleic Acid, N6 polyunsaturated fat, Vitamin E, Carotene, Vitamin C, Retinol
| Age (mean/range): 66/18–80 | Duration: 10 days | Exclusion: Immunosuppressive medications use/Chemotherapeutic treatment/Cardiac dysfunction/Radiation therapy/Renal disease/Impaired liver function/Chronic disease history/Endocrine disease | | 2 | N3 fatty acids, Standard hospital diet 1.0 G/DY X 10.0DY plus Linoleic Acid, N6 polyunsaturated fat, Vitamin E, Carotene, Vitamin C, Retinol
| Race: NR
| % male: 56
| # sites: NR
| Location: Germany
Swails, 1997^63^ | Sample size: 18 | Design: RCT | Inclusion: Upper gastrointestinal malignancies/Undergoing abdominal surgery | Surgery | 1 | Cornoil, Soybean oil variable dosage plus Linoleic Acid, Vitamin E , Vitamin C
| Age (mean/range): 68/18–80 | Duration: 7 days | Exclusion: Renal disease/Cardiac dys function/Evidence of infection/HIV/AIDS/Steroids us | | 2 | Fish oil, Canola oil , Soybean oil variable dosage plus Selenium, Manganese, Linoleic Acid
| Race: NR
| % male: 61
| # sites: 1
| Location: US
Vignali, 1995^78^ | Sample size: 43 | Design: RCT | Inclusion: Gastric cancer, Pancreatic cancer, Surgery for tumor | Surgery | 1 | Enteral standard diet, Arginine, RNA, omega-3 fatty acids
| Age (mean/range): 60.3/NR | Duration: 8 days | Exclusion: NR | | 2 | Enteral standard diet
| Race: Caucasian | | | | 3 | Olive oil
| % male: 63
| # sites: 1
| Location: Italy

* NR = Not Reported.

Evidence Table C.2.2. Evidence table of clinical trials of the clinical effects of omega-3 fatty acids on clinical outcomes after cancer treatment

First Author, Year | Outcomes | | | | | | Applicability
| Results | | | | | | Funding Source
| | | | | | | Quality
Braga, 2002^64^ | Postoperative complications: | | | | | | Applicability: IIB
| RR: 0.35 (95% CI 0.19, 0.67) | | | | | | Funding source: NR
| Length of stay: | | | | | | Jadad: 3
| Mean difference: -2.5 days (95% CI -3.5, -3.5) | | | | | | Concealment of allocation: NR
| Mortality:
| Placebo: 1/10
| O-3: 1/100
| Nutrition: NR
| Mean weight loss: NR
Braga, 2002^65^ | Postoperative complications: | | | | | | Applicability: IIB
| RR: 0.54 (95% CI 0.27, 1.13) | | | | | | Funding source: NR
| Length of stay: | | | | | | Jadad: 3
| Mean difference: -2.7 days (95% CI -4.0, -1.4) | | | | | | Concealment of allocation: NR
| Mortality:
| Placebo: 1/10
| O-3: 2/50
| Nutrition: NR
| Mean weight loss: NR
Braga, 1995^66^ | Postoperative complications: | | | | | | Applicability: IIB
| RR: 0.46 (95% CI 0.09, 2.30) | | | | | | Funding source: NR
| Length of stay: | | | | | | Jadad: 2
| Mean difference: -1.7 days (95% CI -4.5, -1.0) | | | | | | Concealment of allocation: NR
| Mortality: NR
| Nutrition: NR
| Mean weight loss: NR
Braga, 1999^67^ | Postoperative complications: | | | | | | Applicability: IIB
| RR: 0.43 (95% CI 0.21, 0.89) | | | | | | Funding source: NR
| Length of stay: NR | | | | | | Jadad: 4
| Mortality: NR | | | | | | Concealment of allocation: NR
| Nutrition:
| | Caloric intake kcal/day | Nitrogen intake g/day | Albumin md/dl | Transferrin mg/dl | Prealbumin mg/dl
| Placebo | NR | NR | 3.7 | 218 | 18
| O-3 | NR | NR | 3.7 | 223 | 23
| Reported Testing | NR | NR | NR | NR | P<0.05
| Mean weight loss: NR
Daly, 1992^68^ | Postoperative complications: | | | | | | Applicability: IIB
| RR: 0.38 (95% CI 0.13, 1.07) | | | | | | Funding source: Government, private, industry
| Length of stay: | | | | | | Jadad: 1
| Mean difference: -6.0 days (95% CI -7.09, -4.91) | | | | | | Concealment of allocation: Y
| Mortality:
| Placebo: 0/41
| O-3: 1/36
| Nutrition:
| | Caloric intake kcal/day | Nitrogen intake g/day | Albumin mg/dl | Transferrin mg/dl | Prealbumin mg/dl
| Placebo | 1285 | 9 | 2.0 | 152 | NR
| O-3 | 1421 | 15.6 | 2.1 | 161 | NR
| Reported Testing | NR | p=0.001 | NR | NR | NR
| Mean weight loss: NR
Daly, 1995^69^ | Postoperative complications: | | | | | | Applicability: IIB
| RR: 0.23 (95% CI 0.07, 0.73) | | | | | | Funding source: NR
| Length of stay: | | | | | | Jadad: 1
| Mean difference: -4.4 days (95% CI -7.85, -0.95) | | | | | | Concealment of allocation: Y
| Mortality: NR
| Nutrition:
| | Caloric intake kcal/day | Nitrogen intake g/day | Albumin mg/dl | Transferrin mg/dl | Prealbumin mg/dl
| Placebo | 1232 | 10.1 | 3.1 | 181 | 17
| O-3 | 1067 | 11.9 | 3.1 | 190 | 16
| Reported Testing | NR | NR | NR | NR | NR
| Mean weight loss: NR
Di Carlo, 1999^70^ | Postoperative complications: | | | | | | Applicability: IIB
| RR: 0.53 (95% CI 0.14, 1.95) | | | | | | Funding source: NR
| Length of stay: | | | | | | Jadad: 1
| Mean difference: -1.5 days (95% CI -4.6, -1.6) | | | | | | Concealment of allocation: NR
| Mortality:
| Placebo: 1/33
| O-3: 0/35
| Nutrition:
| | Caloric intake kcal/day | Nitrogen intake g/day | Albumin mg/dl | Transferrin mg/dl | Prealbumin mg/dl
| Placebo | 1550 | NR | NR | NR | NR
| O-3 | 1580 | NR | NR | NR | NR
| Reported Testing | NR | NR | NR | NR | NR
| Mean weight loss: NR
Fearon, 2003^76^ | Postoperative complications: NR | | | | | | Applicability: IIB
| Length of stay: NR | | | | | | Funding source: Industry
| Mortality: | | | | | | Jadad: 5
| Placebo: 11/105 | | | | | | Concealment of allocation: Y
| O-3: 16/95
| Nutrition: NR
| Mean weight loss:
| Placebo: 0.37 kg/month
| O-3: 0.25 kg/month
Gianotti, 1999^77^ | Postoperative complications: NR | | | | | | Applicability: IIB
| Length of stay: NR | | | | | | Funding source: NR
| Mortality: NR | | | | | | Jadad: 4
| Nutrition: | | | | | | Concealment of allocation: NR
| | Caloric intake kcal/day | Nitrogen intake g/day | Albumin mg/dl | Transferrin mg/dl | Prealbumin mg/dl
| Placebo | NR | NR | 3.7 | NR | 18
| O-3 | NR | NR | 3.7 | NR | 26
| Reported Testing | NR | NR | NR | NR | <0.05
| Mean weight loss: NR
Gianotti, 1997^71^ | Postoperative complications: | | | | | | Applicability: IIB
| RR: 0.2365(95% CI 0.35, 1.22) | | | | | | Funding source: NR
| Length of stay: | | | | | | Jadad: 2
| Mean difference: -3.5 days (95% CI -5.2, -1.0) | | | | | | Concealment of allocation: NR
| Mortality:
| Placebo: 2/77
| O-3: 3/77
| Nutrition:
| | Caloric intake kcal/day | Nitrogen intake g/day | Albumin mg/dl | Transferrin mg/dl | Prealbumin mg/dl
| Placebo | NR | NR | NR | NR | 18
| O-3 | NR | NR | NR | NR | 23
| Reported Testing | NR | NR | NR | NR | p<0.01
| Mean weight loss: NR
Heller, 2004^75^ | Postoperative complications: NR | | | | | | Applicability: IIB
| Length of stay: | | | | | | Funding source:
| Mean difference: 0 days (95% CI -25, 25) | | | | | | Industry
| Mortality: NR | | | | | | Jadad: 5
| Nutrition: NR | | | | | | Concealment of allocation: Yes
| Mean weight loss:
| Placebo: 1.1 ± 2.2 kg over length of hospital stay
| O-3: 0.0 ± 2.9 kg over length of hospital stay
| No significant difference between groups
Kenler, 1996^61^ | Postoperative complications: | | | | | | Applicability: IIB
| RR: 0.91 (95% CI 0.38, 2.16) | | | | | | Funding source: Industry
| Length of stay: | | | | | | Jadad: 1
| Mean difference: 0.7 days (95% CI -2.80, 4.20) | | | | | | Concealment of allocation: NR
| Mortality:
| Placebo: 1/18
| O-3: 1/17
| Nutrition:
| | Caloric intak kcal/day | Nitrogen intake g/day | Albumin mg/dl | Transferrin mg/dl | Prealbumin mg/dl
| Placebo | 1050 | NR | NR | NR | NR
| O-3 | 1102 | NR | NR | NR | NR
| Reported Testing | p = 0.63 | NR | NR | NR | NR
| Mean weight loss: NR
McCarter, 1998^62^ | Postoperative complications: NR | | | | | | Applicability: IIB
| Length of stay: | | | | | | Funding source: Industry
| Mean difference: 2.0 days (95% CI -7.45, 11.45) | | | | | | Jadad: 4
| Mortality: NR | | | | | | Concealment of allocation: NR
| Nutrition: NR
| Mean weight loss: NR
Preshaw, 1979^79^ | Postoperative complications: NR | | | | | | Applicability: NR
| Length of stay: NR | | | | | | Funding source: RN
| Mortality: NR | | | | | | Jadad: 0
| Nutrition: NR | | | | | | Concealment of allocation: NR
| Mean weight loss:
| Placebo: 2.5 kg over 2 weeks
| O-3: 3.9 kg over 2 weeks
Schilling, 1996^72^ | Postoperative complications: | | | | | | Applicability: IIB
| RR: 0.50 (95% CI 0.15, 1.61) | | | | | | Funding source: Industry
| Length of stay: | | | | | | Jadad: 2
| Mean difference: 0.5 days (95% CI -7.5, 8.5) | | | | | | Concealment of allocation: NR
| Mortality: NR
| Nutrition:
| | Caloric intake kcal/kg/day | Nitrogen intake g/day | Albumin mg/dl | Transferrin mg/dl | Prealbumin mg/dl
| Placebo | 30.4 | NR | NR | NR | NR
| O-3 | 17.4 | NR | NR | NR | NR
| Reported Testing | NR | NR | NR | NR | NR
| Mean weight loss: NR
Senkal, 1997^74^ | Postoperative complications: | | | | | | Applicability: IIB
| RR: 0.71 (95% CI 0.41, 1.21) | | | | | | Funding source: NR
| Length of stay: | | | | | | Jadad: 3
| Mean difference: -3.6 days (95% CI -4.5, -2.7) | | | | | | Concealment of allocation: NR
| Mortality: NR
| Nutrition: NR
| Mean weight loss: NR
Senkal, 1999^73^ | Postoperative complications: | | | | | | Applicability: IIB
| RR: 0.54 (95% CI 0.27, 1.10) | | | | | | Funding source: NR
| Length of stay: | | | | | | Jadad: 3
| Mean difference: -3.6 days (95% CI -4.9, -2.4) | | | | | | Concealment of allocation: NR
| Mortality: NR
| Nutrition: NR
| Mean weight loss: NR
Swails, 1997^63^ | Postoperative complications: | | | | | | Applicability: IIB
| RR: 1.67 (95% CI 0.52, 5.39) | | | | | | Funding source:
| Length of stay: NR | | | | | | Jadad: 2
| Mortality: | | | | | | Concealment of allocation: NR
| Placebo: 0/10
| O-3: 0/8
| Nutrition:
| | Caloric intake kcal/day | Nitrogen intake g/day | Albumin mg/dl | Transferrin mg/dl | Prealbumin mg/dl
| Placebo | 1047 | NR | NR | NR | NR
| O-3 | 1010 | NR | NR | NR | NR
| Reported Testing | NR | NR | NR | NR | NR
| Weight: NR
Vignali, 1995^78^ | Postoperative complications: NR | | | | | | Applicability: IIIB
| Length of stay: NR | | | | | | Funding source: NR
| Mortality: NR | | | | | | Jadad: 2
| Nutrition: | | | | | | Concealment of allocation: NR
| | Caloric intake kcal/day | Nitrogen intake g/day | Albumin mg/dl | Transferrin mg/dl | Prealbumin mg/dl
| Placebo | NR | NR | 3.2 | NR | 17
| O-3 | NR | NR | 3.4 | NR | 20
| Reported Testing | NR | NR | NR | NR | NR
| Weight: NR

* NR = not reported, O-3 = omega-3, g = gram, kcal = kilocalories, mg = milligrams, dl = deciliter, kg = kilograms;

† mean values.

Evidence Table C.3.1. Systematic Reviews of Tumor Development

Author, Year | Model(s) | Outcomes Assessed | Conclusions | Years included | Completeness of Search | Databases | Inclusion Criteria | Conclusions Follow from Data?
Mammary
Fay, 1997^80^ | Rats and mice | Effects of n-6 PUFA, n-3 PUFA, monounsaturated fatty acids, saturated fatty acids, and energy restriction on incidence of mammary tumors in rats and mice.* | Substitution of n-3s for nonfat calories appeared to have a small, non-significant (p=0.62) protective effect on incidence of tumor development. No conclusions about other aspects of tumor growth such as time to onset, size, number of tumors.† | 1966-1994 | Systematic | Medline used to update a database created in 1990 by author | Random assignment to treatment groups; study of sufficient duration to allow reporting of final tumor incidence; animals all of same species/strain; at least two treatment groups per study; all groups followed for same duration; semipurified diets; only dietary interventions; fat sources reported; animals in one study all receive same carcinogenic insult at same age; carcinogen is not from transplanted tumors and not dietary | Yes
Meta-analysis
Prostate
Kolonel, 1999^81^ | Multiple models of mouse tumor induction with chemicals, irradiation, and prolonged testosterone‡ | Effects of dietary fat on promotion, inhibition of tumor growth | Mixed effects observed for total dietary fat. Fish oils containing high levels of EPA and DHA generally suppress prostate tumor growth in vivo and in vitro; however, one study found that EPA was inhibitory only at high concentrations. Thus fish oil may not decrease risk and nothing is known about the possible mechanism(s) by which it alters tumor development.(based on 4 studies) | 1940-1998; 1986-1996 for n-3 studies | Systematic | Medline | English language articles only | Yes, although no real conclusions, only suggested research directions.
Colon
Zhao, 1991^83^ | Sprague Dawley (SD) and Fischer 344 rats, carcinogen-induction | Effect of fat intake on incidence of colon carcinoma and number of tumors, controlling for calories | 14 studies of rats identified. N-3s represented 0–6.9 percent of total body weight. N-3 fatty acids appeared to be negatively associated with colon carcinoma incidence for both types of rats combined. Non-n 3s (n 6s) appeared to promote tumors in Fischer 344s but not in SD rats. | 1969-1990 | Systematic | Medline | Inclusion of information on dietary composition, including fat content; inclusion of incidence data; random assignment to treatment groups feeding in usual manner (probably to exclude feeding by gavage, e.g.) | Yes, but not sure of validity or effect of method used to calculate fat intake (much info lacking from reports)
Corpet, 2003^92^ | Min mouse, a mutant that spontaneously develops multiple intestinal neoplasias secondary to a mutation in the Apc gene, similar to humans with familial adenomatous polyposis | Effect of a variety of putative dietary cancer preventive agents on tumor yield in the colon and small intestine. | All studies involving fish oil and min mouse come from one published report (Paulsen et al., 1997): 0.4, 1.25, and 2.5% of diet in males and females, 17 weeks duration from 1 wk of age. | 1990 (1997)-2002 | Systematic | ISI Current Contents, Medline, AACR Website 1990-2002 | Plausibility, inclusion of quantitative data | Yes, although limited
| | | Effects were consistent across the animal models. Decreased tumor yield in small intestine by 60–70 percent. Not dose dependent. Effect in colon not significant.
Corpet, 2002^84^ | Carcinogen-induced colon tumors in Fischer and Sprague-Dawley rats | Effect of a wide variety of agents on inhibition of Aberrant crypt foci (ACF); tumor number | AGF Inhibition: | 1989-2001 | Systematic but omitted studies with no or insignificant effect | Medline, CCLS, AACR website, Carcinogenesis and Cancer Letters journals | Plausibility, inclusion of quantitative data, no use toxic agents, only those reporting a significant protective effect (as the point of the review was to identify agents for clinical trial testing). Only most potent agent and dose included from each study | Yes
| | | Perilla oil: 74–91%
| | | DHA: 64–65%
| | | Fish oil: 50%
| | | Tumor Reduction:
| | | Fish oil: 31–64% (somewhat dose-dependent)
| | | Perilla oil: 52%
| | | Effects seen only in Fischer rats.
| | | N-3s not ranked among most potent agents overall.

* Several means used to introduce n-3 PUFA: substituting for nonfat calories, substituting for n-6 calories, use of menhaden oil, which is high in saturated and monounsaturated fat also. Sensitivity analysis done by separating data on S-D rats from rest of rats, separating rats and mice.

† Effect may be supported by studies involving transplanted tumors, but these studies not included in analysis.

‡ Animal models of prostate cancer are nearly non-existent. No record exists of spontaneous neoplasms in mice and very low incidence of cancerous lesions in rats (only 2 reports in rats since 1963). Also, rodent prostate differs anatomically from human. Transgenic mouse models for prostatic neoplasia offer some hope of being able to research effects of various environmental factors.

Evidence Table C.3.2. Non-systematic reviews of n-3 Fatty Acids and Tumor Growth and Development

Author, Year | Model(s) | Outcomes | Conclusions | Years
Mammary/Breast tumors
Cave, 1991^82^ | Carcinogen induction models: NMU-induced mammary tumors in Buffalo rats and transplanted mammary tumors DMBA mammary tumor model | Effects on Tumor incidence and latency of diets high in fish oil (FO) vs. corn oil | Increasing % dietary n-3s (FO 0.5–20%) progressively lengthened tumor latency period (in some studies) and decreased incidence and burden | 75-89
| Transplant models: R3230AC mammary AC to female Fischer 344 rats; BALB-c mammary AC to Balb/c mice | Same | F 344 model: reduced transplant growth Balb/C model: tumor growth inhibition; suppression of effect of corn oil; increased rate of tumor cell loss (apoptosis?)
| BN 472 mammary AC transplanted into BN/Bi mice; crossover | Crossover 25% FO and 25% cocoa butter diets | Tumor inhibitory effect of FO greater when diet begun before transplantation
| Human mammary CA MX-1 transplanted into heterozygous BALB/c nu/+ athymic nude mice | 10% FO vs. 10% corn oil diet | Growth rates of tumor cells depressed by fish oil; Transplants in FO-fed rats more responsive to chemotherapeutic drugs than those in CO-fed rats
Fernandes, 1991^102^ | Nude mice transplanted with MCF-7 (E_2_-receptor-positive) human breast cancer cells; MDA-MB231 (E_2_-receptor-negative) | Modulation of mammary tumor development by n-3s | Rate of tumor cell growth and volume significantly lower in fish-oil fed mice cf. corn-oil fed: No data | 75-90
Noguchi, 1995^103^ | Rat in vivo; mouse transplants; human cell culture; | Breast Carcinoma tumorigenesis, Proliferation: effects of n 6s and n 3s (DHA and EPA) | DHA and EPA suppress breast carcinoma tumorigenesis and cell proliferation. No data. | 75-94
Gonzalez, 1995^104^ | Multiple animal and in vitro models discussed | Tumor suppression by n-3s | Possibility that lipid peroxidation secondary to high fish oil ingestion may be responsible for inhibition or suppression of mammary tumor growth, poss. through formation of cytotoxic compounds | 56-92
Klurfeld, 1995^94^ | DMBA-induced rat mammary tumor model | Energy restriction vs. fat restriction | Ad lib, low fat diets produce more tumors than energy restricted higher fat diets, regardless of source of fat; also, use of n-3s as sole fat source may inhibit tumor growth because mammary tumors require some n-6 FA; small amount of n-6+FO leads to increased growth in mammary tumors but suppression in others | '47-'89
Cave, 1997^91^ | rodent mammary tumor models: transplanted tumors to nude, athymic mice, carcinogen-induced tumors, DES-induced tumors, and x-ray induced tumors | Tumor promotion by n-3s | Increasing % dietary n-3s (menhaden oil 0.5–20%) progressively lengthened tumor latency period and decreased incidence and burden; fish oil, purified EPA and DHA, high levels ALN also reduced growth in tumor transplant models; fish oil also enhanced effects of several types of chemotherapy in athymic mouse model | 42-95
Stoll, 1998^105^ | Human mammary cell culture; explants; chemically-induced carcinogenesis in rat | Inhibition of growth, metastasis; Protex against induced carcinogenesis by n-3 FAs and antioxidants | N-3s, increased ratio n-3s/n-6s inhibit growth, metastasis; protect against induced CA: No data. Role of antioxidants alone vs. with n-3s unclear | 75-97
Stoll, 1998^106^ | Human mammary cell culture; explants; chemically-induced mammary tumors | Protection against growth by n-3s | n-3s inhibit growth; incidental to main point of review: insulin resistance and BC risk (insulin resistance may be one means by which n-3s influence tumorigenesis) | 87-97
Rose, 2000^97^ | MDA-MB-231 breast cancer cells in nude mice (part of a review on dietary FA and angiogenesis) | Effect of DHA on tumor mass | DHA inhibited tumor mass increase by a combination of decreased cell proliferation, increased apoptosis, and reduced angiogenesis | 95-99
Sinclair, 2002^107^ | Rat mammary tumor (mostly human models cited) | Tumor growth effects of α-linolenic acid | α-linolenic acid plus high vitamin E promoted tumor growth of cf. α-linolenic acud without E (most of paper reviews mechanisms of α-linolenic acid's effects). Suggests peroxidative damage (toxic products) inhibits tumor growth, which may depend on dietary oxidative status. Role may not be solely as precursor to EPA, DHA. Conversion to EPA, DHA actually inefficient | 30-02
Prostate tumors
Cave, 1991^82^ | Athymic nude mice (nu/nu) implanted with DU-145 cultured human prostate cancer cells | Effect of corn oil vs. FO on tumor volume and weight | Few animal models. Nu/nu mice on high FO diets had signif lower tumor volumes and weights, altered chemistry
| Nude mice (Balb/c CD-1) transplanted with DU-145 cells at one of two doses | Diet initiated 3 weeks prior to transplant | FO diet retarded progression of transplanted cells but only at lower dose of cells (initial tumor burden)
Colon tumors
Cave, 1991^82^ | Male Fischer344 rats induced with AOM | 4%, 22.5% MO+1%CO vs. 5%, 23.5% CO, 34 wks. | MO and low CO diets resulted in significantly lower tumor number in large intestine cf. high CO. Possible mechanisms: 1) n-3s may inhibit 2° bile acids or 2) n-3s may alter colon eicosanoid metabolism. | 77-89
| (Reddy) | Adenocarcinoma incidence and number of tumors in large intestine (may want to mention timing of carcinogen vs diet?)
| Same model with 6 combinations of oils | 4% MO+1%CO; | No increase in tumor incidence or number in 1^st^, 2^nd^, 3^rd^, 4^th^, 5^th^ groups; 6^th^ group had significant increase in incidence. Total number of tumors was lower in animals in groups 1,4,5. Therefore, high fat intake is necessary but not sufficient: N-3/n-6 ratio important.
| (Reddy) | 5.9%MO+17.6%CO
| | 11.8%MO+11.8%CO
| | 17.6%MO+5.9%CO;
| | 5%CO; 23.5%CO 38wks
| Similar model with Donryu rats (Minoura) | n-3 (EPA) vs. n-6 (LA) diet | Lower tumor incidence assoc. w/n-3 diet also assoc. w/lower tumor levels of PGE_2_. May have direct or indirect effx.
| SD rats induced with DMH | 17%MO vs. 17%CO | Signif lower colorectal tumor number in MO-fed rats but no difference in plasma peroxide concentrations, which may or may not reflect colon peroxide levels.
| Balb/c ByJ mice injected with CT-26 colon carcinoma cells | 5% Safflower Oil(SO) | Tumor size largest in 24.7%SO followed by 5%SO. 5% and 24.7% MO lowest and not different (i.e. No dose dependence for MO). 24.7%SO had increased mortality rate and tumor number cf. other groups.
| | 24.7%SO | Proposed that n-3s compete with and inhibit the effx of n-6s on some process required for growth and survival.
| | 5%MO
| | 24.7%MO
| | Effect on tumor size, number, mortality rate
Klurfeld, 1995^94^ | DMH-induced rat colon tumor model | Energy restriction vs. fat restriction | Ad lib, low fat diets produce more tumors than energy restricted higher fat diets, regardless of source of fat DMBA and DMH tumors even more sensitive to effects of energy restriction than DMBA tumors. Ad lib fed rats may actually be obese; | '47-'89
| | | small amount of n-6+FO leads to decreased growth on colon tumors
Reddy, 1992^85^ | Same as first two Reddy studies above and Minoura | Same as reviewed by Cave plus a third study with crossover design (low corn oil, high corn oil, high fish oil for 9 weeks; during last two weeks, two weekly injections of AOM; three days after 2^nd^ injection, animals switched to difft. diet or kept on same diet for 42 weeks) to test effect of diets on AOM-induced tumor initiation | High fish oil diet decreased colon tumor incidence and number when fed during initiation or post-initiation. Possible mechanisms may involve decrease in secondary bile acids (which fn as tumor promoters in gut and induce ornithine decarboxylase) and modification of gut flora, which modifies formation of tumor promoting substances in gut. Alternatively, could be due to n-3-mediated alterations in (inhibition of) PG synthesis; finally, n-3s may increase the rate of detoxification of AOM | 78-91
Ma, 1996^93^ | Same models as Cave review plus those post '90, but poor description of models | | | 83-93
| AOM-treated mice
| (Deschner)
| | Various ratios of n-3/n-6 effx on adenomatous proliferative pattern, tumor incidence in colon | n-3/n-6 ratio of 1 prevented prolif. and tumor incidence
| DMH-induced rats (Takahashi, 93)
| DMH-induced SD rats (Kuratko and Pence, 92) | IG gavage of DHA effx on formation and growth of aberrant crypt foci | Suppressed formation and growth of aberrant foci
| | 19% MO vs 19% beef tallow vs. 20% CO effects on colon tumor metabolism | MO increased lipid peroxidation in DMH-induced tumors
| | | Conclusion: n-3s may inhibit tumor formation
Pancreatic tumors
Cave, 1991^82^ | AZA-treated Wistar rats to induce preneoplastic atypical acinar cell nodules (AACN) and adenocarcinomas (O'Connor) | 1) 20% MO vs. 20% CO | MO reduced number and size of preneoplastic lesions
| | 2) 9 dietary groups with n-3/n-6 ratios varying from 0.01 to 7. | As n-3/n-6 increased, preneoplastic development decreased significantly, along with levels of PGE_2_.
| | 3) Crossover study post tumor inductions. 2 months each 20% MO and 20% CO and the reverse (2 control groups were not switched). | Highest to lowest number of tumors: All CO diet, switching from MO to CO, switching from CO to MO and all MO. Concluded n-3/n-6 ratio significantly influences AACN development.
Other
Avula, 2000^87^* | Hepatocarcinoma 3924A cells | Dietary supplementation with EPA and DHA | Increased apoptosis and decreased proliferation
| Normal spleen cells in culture with and without mitogens | n-3s in culture media | Decreased proliferation
| Various cancerous as well as normal cell lines | n-3s in culture media | Decreased proliferation

Evidence Table C.3.3. Non-systematic reviews of n-3 Fatty Acids and Differentiation

Author, Year | Definition and Model(s) | Outcomes Measured | Conclusions | Years
Burns, 1994^108^ | No definition provided | | | 67-92
| HL-60 leukemia cells | Retinoic acid-mediated differentiation as measured by superoxide production and nitroblue tetrazolium reduction | Plasma membrane PUFA appear to mediate differentiation of HL-60 cells in vitro: enrichment with DHA increases rate of differentiation and decreases growth rate cf. enrichment with oleic acid
| Cultured colon cancer cells | Butyrate-induced differentiation | Differentiation facilitated by DHA
Avula, 2000^87^* | No definition provided | Proliferation, apoptosis, numbers of differentiating cells | EPA and DHA increase numbers of differentiating cells without modifying crypt morphology or cell number per crypt column
| Colon cancer cell
| EPA and DHA- mediated changes in proliferation
Stoll, 2002^88^ | No definition provided | Expression of PPAR-γ and differentiation | n-3s increase PPAR-γ expression in nuclei of many cell types. Such activation has been shown to increase differentiation of HBC cells
| PPAR-γ is a nuclear receptor activated by PUFAs, antidiabetic agents that inhibit growth of cancer cells;
| HBC cells in culture

Evidence Table C.3.4. Non-systematic reviews of n-3 Fatty Acids and Apoptosis

Author, Year | (Definition) and Model(s) | Outcomes | Conclusions | Years
Troyer, 1996^89^ | (Apoptosis is an energy-dependent physiological process of cellular self-elimination) | | | 14-95
| Proposes that n-3s could affect apoptosis and suggests several mechanisms:
| n-3s increase expression of free radical scavenging enzymes, which should maintain normal apoptosis.
| N-3 mediation of gene expression: | EPA effects on proliferation and apoptosis | EPA inhibits proliferation and stimulates apoptosis
| HL-60 cells | | FO suppresses H-ras expression
| DMBA induced breast cancer cells | Effect of fish oil on H-ras expression
Das, 1999^109^ | (no definition) | Effects of EFAs on apoptosis | In contrast to findings of others, both n-6s and n-3s appear to stimulate apoptosis | '84-'98
| Variety of tumor cell models and normal cell lines
Johnson, 2002^90^ | (Apoptosis is the selective destruction of individual cells dispersed throughout a tissue, characterized by, among other changes, shrinkage and convolution of the nucleus, chromatin aggregation, and loss of intercellular contact) | Effects of LCPUFAs on intestinal apoptosis and aberrant crypt foci | Findings suggest apoptosis mediates anticarcinogenic effects of fish oil in small intestine, which in turn my be mediated by lipid peroxidation and intracellular redox potential | '92-'01
| Proposes that rapidly proliferating cells such as those in the intestinal mucosa are protected from tumorigenic mutational events by n-3-mediated apoptosis, independent of COX-2 inhibition.
| Human colorectal adenocarcinoma cell line HT29 | EPA leads to cellular detachment and apoptosis; enhanced by glutathione depletion/ blocked by antioxidants
| Feeding rats fish oil followed by exposure to DMH | Fish oil feeding enhances apoptosis, decreases mitosis, and reduces ACF frequency in intestinal epithelial cells; enhanced by glutathione depletion
Avula, 2000^87^ | (Apoptosis is synonymous with “programmed cell death” occurring at a specific time during development. Appears to result from induction of active intracellular processes.) | | | '87-'99
| Models:
| 1) n-3s susceptible to oxidative stress/peroxidation: | n-3 effects on apoptosis | n-3s increase apoptosis
| a variety of cell culture systems Animals in feeding studies: fed high n-3 diets show increased n-3s in membrane lipids. Requires antioxidant supplementation to prevent peroxidation. However, high levels of antioxidants reduce peroxidation and increase tumor growth. | Membrane n-3 levels | Increased by n-3 feeding
| 2) Transgenic and normal mice, HL-60 and K-562 cells in vitro: Bcl-2 is a gene product that suppresses apoptosis, a mechanism that plays a role in pathogenesis of some cancers; could be mechanism by which n-3s suppress tumor growth, i.e. stimulating apoptosis. | Bcl-2 expression | Inhibited by n-3s in vivo and in vitro
| Thus highly unsaturated FA are susceptible to peroxidation and these peroxides can induce apoptosis. | Fas-L gene expression and apoptosis
| 3) Fas/Apo-1, a TNF-family receptor. Fas-L, a ligand, mediates apoptosis by x-linking the Fas receptor. Splenocytes. Increasing evidence suggests that tumor progression can be controlled by altering cancer cell sensitivity to Fas-mediated apoptosis (w/ n-3s). | | N-3s increase both Fas expression, apoptosis, and cell sensitivity to Fas-mediated apoptosis

Notes: HBC Human breast cancer; PPAR Peroxisome proliferator-activated receptor

Evidence Table C.3.5. Evidence for Role of Genes Involved in n-3 Metabolism and Transport

Author, Year | Gene Product | Model | Outcomes | Years Cited
Blok, 1994^95^ | Phospholipases, COX, and LO | Numerous rodent ex vivo models: role of n-3s in cytokine production | EPA rapidly incorporated into membrane phospholipids, replaces AA as substrate for COX etc., and is converted to less active PGE_3_ and LTB_5_; mimic effects of dual inhibition of COX and LO. Effects in mice opposite to those in humans, rats. Poss. due to different cell types studied. | '88-'94
Ma, 1996^93^* | COX-2 pathway | Unknown | n-3s inhibit oxidative metabolism of AA involved in PG synthesis and decreases PGE2 synthesis; indomethacin, a COX-2 inhibitor, inhibits colon carcinogenesis. MO increases lipid peroxidation in colon tumors
Rose, 1997^98^ | COX-2 and LO | Expt. mammary carcinogenesis; human breast cancer cell progression in nude mice | Suppressive effects of n-3s appear to be mediated by inhibition of conversion of AA to PGE2 and 12-HETE | '88, 95
Calder, 1997^96^ | Phospholipases A2, C | None: background info on role of n-3s in cytokine production | Precursor PUFAs released from membrane phospholipids by phospholipases: play role along with COX and LO in amounts and types of eicosanoids synthesized; EPA is substrate for COX and 5-LO | 82-97
| COX-2, LO
Rose, 2000^97^ | LO and COX Phospholipase A2 | Nude mouse/breast cancer cell lines model of sangiogenesis potentiation by n-3s and n-6s | n-6 LO and COX metabolites (12-HETE and PGE2, resp.) are angiogenic in in vitro assays. Stimulate VEGF. Angiogenesis assoc. with tumor progression and poor prognosis. Inhibited by DHA and COX-2 inhibitor similarly. | '81-'99
| | Human colon cancer cells that overexpress COX-2 | Result is stimulation of vascular endothelial cell migration and formation of capillary-like tubes in culture
Avula, 2000^87^* | Peroxidases (used here to include LO, COX) | Variety of cell culture systems; in vivo diet expt. in mice | PUFAs susceptible to lipid peroxidation. Oxidative stress induces apoptosis in cell culture; n-3 feeding associated with increased markers for generation of reactive oxygen species and increased apoptosis; supplementation with antioxidants inhibits this and increases tumor cell growth (as well as preserving immune cell fn). N-3s themselves stimulate antioxidant enzyme activities.

* COX Cyclooxygenase; HETE Hydroxyeicosatetraenoic acid; LO Lipoxygenase; LTB Leukotriene B; PGE Prostaglandin E; VEGF Vascular endothelial growth factor;

* Review included in Response to Question 1.3 on apoptosis.