# Appendix B. Coding/Data Abstraction Forms

## B.1 Literature Screener Form

[image]

[image]