# Appendix A. Methodologic Approach

## A.1 Preliminary Research Questions

Table A.1.1 Preliminary Research Questions

GENERAL QUESTIONS: Questions posed for all three participating EPCs, for years 1 and 2.
1. What is the evidence that variable clinical effects may reflect differences in:
• Serving size (fish vs. dietary supplement);
• Source (fish, food, plant) vs. dietary supplement (fish oil, plant oil);
• Specific type(s) of omega-3 fatty acids (docosahexaenoic acid (DHA), eicosapentaenoic acid (EPA), docosapentaenoic acid (DPA), and alpha-linolenic acid (ALA), fish, fish oil), or the ratio of omega-6/omega-3 fatty acids used;
• Manufacturer (different purity, presence of other potentially active agents)?
2. What is the evidence for adverse events, side effects, or counter-indications associated with omega-3 fatty acids (DHA, EPA, DPA, ALA, fish oil, fish)?
3. What is the evidence that omega-3 fatty acids are associated with adverse events in specific subpopulations such as diabetics?
4. What are the mean and median intakes of DHA, EPA, DPA, ALA, fish, fish oil, omega-6, omega-6/omega-3 ratio in the US population?
5. What is the evidence that omega-3 fatty acids influence overall energy balance?
6. What is the evidence that accurate interpretation of the results of clinical studies is dependent on knowing the absolute fatty acid content of the baseline data, the relative fatty acid content of the baseline diet, or the tissue ratios of fatty acids (omega-6/omega-3) during the investigative period?
DISEASE-SPECIFIC QUESTIONS: Questions posed to the SCEPC for year 2 of the project.
Cancer:
A. Tumor Incidence:
A.1 What is the evidence that omega-3 fatty acids reduce the incidence of tumors?
If omega-3 fatty acids influence the incidence tumors:
A.2 For what type of tumors?
A.3 Is there an inverse relationship with intake?
A.4 Is there a temporal relationship with intake?
B. Tumor Behavior:
B.1 What is the evidence that omega-3 fatty acids alter the behavior of malignant tumors in terms of growth, differentiation and apoptosis?
If omega-3 fatty acids influence the behavior of tumors:
B.2 For what type of tumors?
B.3 Is there an inverse relationship with intake?
B.4 Is there a temporal relationship with intake?
C. Modification of Omega-3 Effects:
C.1 What is the evidence that the response to omega-3 fatty acids is dependent of the intake of antioxidants such as vitamin E or other bioactive food components?
C.2 What is the evidence that the response is modified by the state of the immune system?
C.3 What is the evidence that genes involved in omega-3 fatty acid transport or metabolism influence the magnitude or direction of the influence on tumor incidence/behavior?
D. Omega-3 Fatty Acids as Effect Modifiers:
D.1 What is the evidence that omega-3 fatty acids alter the effects of chemotherapy on malignant tumors?
E. Other:
E.1 What is the evidence that drugs influencing the cyclooxygenase activity influence tumor incidence/behavior?

## A.2 Technical Expert Panel

The members of our technical expert panels are listed in Table A.2.1. We conducted our TEP meetings via teleconference on January 8, 2004. Dr. Beth Collins-Sharp, the Task Order Officer, and Dr. Kenneth Fink, Director of the Evidence-Based Practice Center Program, represented AHRQ on these calls; Dr. Anne Thurn, Director of the Evidence-Based Review Program, represented ODS; and Dr. Catherine MacLean, the Task Order Director, Sally Morton, Co-Director of the SCEPC, and Rena Hasenfeld, the Project Manager, represented the SCEPC. The key comments and recommendations of the TEP are summarized in Table A.2.2. The TEP continued to advise the SCEPC throughout the project via mail, fax, e-mail, and phone calls.

Table A.2.1 Technical experts panel members

Cancer
Name | Area of Expertise | Institution
William S. Harris, PhD | Omega-3 Fatty Acids | University of Missouri-Kansas City School of Medicine
Jennifer Malin, MD | Oncology | University of California, Los Angeles
Cindy Davis, PhD | Cancer | National Cancer Institute
Ralph W. Moss, PhD | Cancer | Cancer Communications, Inc.
Walter Willett, MD, MPH, Dr PH | Omega-3 Fatty Acids | Harvard Medical School

Table A.2.2 Key TEP comments and recommendations

Cancer
[underlined: Cancer Question A: Tumor Incidence]
A.1 What is the evidence that omega-3 fatty acids reduce the incidence of tumors?
If omega-3 fatty acids influence the incidence tumors:
A.2 For what type of tumors?
A.3 Is there an inverse relationship with intake?
A.4 Is there a temporal relationship with intake?
• Address with large cohort studies.
• All types of cancers and malignant tumors
• Focus on pre-cancerous and malignant tumors.
• Examine the effects of omega-3 fatty acids on individual types of cancer in order to capture differential effects.
[underlined: Cancer Question B: Tumor Behavior]
B.1 What is the evidence that omega-3 fatty acids alter the behavior of malignant tumors in terms of growth, differentiation, and apoptosis?
If omega-3 fatty acids influence the behavior of tumors:
B.2 For what type of tumors?
B.3 Is there an inverse relationship with intake?
B.4 Is there a temporal relationship with intake?
• Studies in humans are very limited; most studies have been performed using animals and tissue lines.
• The focus of these questions differs substantially from the others addressed in the task order; the SCEPC and AHRQ will decide whether these questions are outside of the scope and resources of the task order..
[underlined: Cancer Question C: Modification of Omega-3 Effects]
C.1 What is the evidence that the response to omega-3 fatty acids is dependent of the intake of antioxidants such as vitamin E or other bioactive food components?
C.2 What is the evidence that the response is modified by the state of the immune system?
C.3 What is the evidence that genes involved in omega-3 fatty acid transport or metabolism influence the magnitude or direction of the influence on tumor incidence/behavior?
• There is no standard definition of “bioactive food components.”
• There is no standard definition of “state of the immune system.”
• These questions would be based on human evidence.
[underlined: Cancer Question D: Omega-3 Fatty Acids as Effect Modifiers]
D.1 What is the evidence that omega-3 fatty acids alter the effects of chemotherapy on malignant tumors?
• The question should be broadened to read: What is the evidence that omega-3 fatty acids alter the effects of cancer treatment on malignant tumors and clinical outcomes after cancer treatments?
Cancer Question E: Other
E.1 What is the evidence that drugs influencing the cyclooxygenase activity influence tumor incidence/behavior?
• This question seems to be off of the primary target of this task order.
• The TEP recommended adding a paragraph about the effects of cyclooxygenase inhibition on cancer to the background or introduction of the report.
1. What is the evidence that variable clinical effects may reflect differences in:
- Serving size (fish vs. dietary supplement)
- Source (fish, food, plant) vs. dietary supplement (fish oil, plant oil)
- Specific type of omega-3 fatty acid (DHA, EPA, DPA, ALA)
- Ratio of omega-6/omega-3
- Manufacturer (different purity, presence of other potentially active agents)?
• The effects of flaxseed and flaxseed oil should be specifically assessed. Even if there are no data, this should be stated in the report.
• It is important to look at ALA and long-chain fatty acids.
• It is important to look at the relative percent of fatty acids or percent of energy.
• To assess compliance with omega-3 fatty acids, tissue levels of omega-3 fatty acids can be used: there should be a 50% or double level of fatty acids among the intervention group, although this may vary by the type of tissue and baseline diet.
• If looking at tissue samples, the effect of the intervention is dependent on the baseline level of omega-3 fatty acids. The content of omega-3 fatty acids in the diet should be assessed.

## A.3 Industry Experts

Table A.3.1 Industry experts that were contacted for data about efficacy of omega-3 fatty acids

Name | Affiliation
Ian Newton | Roche Vitamins
Herb Woolf, PhD | BASF Corporation
Annette Dickinson | Council for Responsible Nutrition

## Figure A.3.1 Letter sent to industry experts

[image]

## A.4 Search Strategies

Table A.4.1 Core search strategy

1. exp fatty acids, omega-3/
2. fatty acids, essential/
3. Dietary Fats, Unsaturated/
4. linolenic acids/
5. exp fish oils/
6. (n 3 fatty acid$ or omega 3).tw.
7. docosahexa?noic.tw,hw,rw.
8. eicosapenta?noic.tw,hw,rw.
9. alpha linolenic.tw,hw,rw.
10. (linolenate or cervonic or timnodonic).tw,hw,rw.
11. menhaden oil$.tw,hw,rw.
12. (mediterranean adj diet$).tw.
13. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.
14. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.
15. (fish adj2 oil$).tw.
16. (cod liver oil$ or marine oil$ or marine fat$).tw.
17. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.
18. (fish consumption or fish intake or (fish adj2 diet$)).tw.
19. diet$ fatty acid$.tw.
20. or/1–19
21. dietary fats/
22. (randomized controlled trial or clinical trial or controlled clinical trial or evaluation studies or multicenter study).pt.
23. random$.tw.
24. exp clinical trials/ or evaluation studies/
25. follow-up studies/ or prospective studies/
26. or/22–25
27. 21 and 26
28. (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega).tw.
29. (omega 3 or n 3).mp.
30. (polyunsaturated fat$ or pufa or dha or epa or long chain or longchain or lc$).mp.
31. 29 and 30
32. 20 or 27 or 28 or 31

Table A.4.2 Literature searches by topic

Tumor incidence and outcomes after cancer treatment
1. exp fatty acids, omega-3/
2. fatty acids, essential/
3. Dietary Fats, Unsaturated/
4. linolenic acids/
5. exp fish oils/
6. (n 3 fatty acid$ or omega 3).tw.
7. docosahexa?noic.tw,hw,rw.
8. eicosapenta?noic.tw,hw,rw.
10. (linolenate or cervonic or timnodonic).tw,hw,rw.
11. menhaden oil$.tw,hw,rw.
12. (mediterranean adj diet$).tw.
13. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.
14. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.
15. (fish adj2 oil$).tw.
16. (cod liver oil$ or marine oil$ or marine fat$).tw.
17. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.
18. (fish consumption or fish intake or (fish adj2 diet$)).tw.
19. diet$ fatty acid$.tw.
20. or/1–19
21. dietary fats/
22. (randomized controlled trial or clinical trial or controlled clinical trial or evaluation studies or multicenter study).pt.
23. random$.tw.
24. exp clinical trials/ or evaluation studies/
25. follow-up studies/ or prospective studies/
26. or/22–25
27. 21 and 26
28. (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega).tw.
29. (omega 3 or n 3).mp.
30. (polyunsaturated fat$ or pufa or dha or epa or long chain or longchain or lc$).mp.
31. 29 and 30
32. 20 or 27 or 28 or 31
33. exp neoplasms/
34. (neoplasm$ or cancer$ or tumour$ or tumor$ or carcinoma$ or malignanc$).tw.
35. 33 or 34
36. 32 and 35
Tumor Behavior
1. (EICOSAPENTAENOIC ACID or DOCOSAHEXAENOIC ACID).sh. or “Nutrition/Lipids (1972- ) [13222]”.cc. or “Metabolism/Lipids [13006]”.cc. or “Biochemical Studies/Lipids [10066]”.cc.
2. dietary fat.sh.
3. plant oils.sh.
4. exp fatty acids, omega-3/
5. fatty acids, essential/
6. Dietary Fats, Unsaturated/
7. linolenic acids/
8. exp fish oils/
9. (n 3 fatty acid$ or omega 3).tw.
10. docosahexa?noic.tw,hw,rw.
11. eicosapenta?noic.tw,hw,rw.
12. alpha linolenic.tw,hw,rw.
13. (linolenate or cervonic or timnodonic).tw,hw,rw.
14. menhaden oil$.tw,hw,rw.
15. (mediterranean adj diet$).tw.
16. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.
17. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.
18. (fish adj2 oil$).tw.
19. (cod liver oil$ or marine oil$ or marine fat$).tw.
20. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.
21. (fish consumption or fish intake or (fish adj2 diet$)).tw.
22. diet$ fatty acid$.tw.
23. dietary fats/
24. (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega).tw.
25. (omega 3 or n 3).mp.
26. Gamma-linolenic acid/
27. (n 6 fatty acid$ or omega 6).tw.
28. octadecadienoic.tw,hw,rw.
29. linoleic.tw,hw,rw.
30. linoleate.tw,hw,rw.
31. ((olive or safflower or cottonseed or sesame or sesame seed or corn or borage or primrose or black currant or vegetable) adj2 oil$).tw.
32. arachidonic.tw,hw,rw.
33. or/1–32
34. neoplasm.sh.
35. neoplastic disease.sh.
36. (neoplasm$ or cancer$ or tumour$ or tumor$ or carcinoma$ or malignanc$).tw.
37. or/34–36
38. 33 and 37
39. limit 38 to animal
40. limit 39 to review

## A.5 Inclusion/Exclusion Criteria

Table A.5.1 Inclusion/Exclusion Criteria at Screening Stage for Cancer.*

Assessed the effect of omega-3 fatty acids on cancer
Presented research on human subjects; presented research on human subjects and animals for apoptosis, tumor growth, and differentiation questions only.
Reported the results of randomized or controlled clinical trials or prospective cohort studies;† reported the results of review articles and meta-analyses of animal studies and cell culture studies for apoptosis, tumor growth, and differentiation questions only.‡

* Language was not a barrier to inclusion;

† We defined a randomized controlled trial (RCT) as one in which the participants were assigned to one of two (or more) study groups using a process of random allocation (e.g., random number generation, coin flips); we defined a controlled clinical trial (CCT) as one in which participants were either: (1) assigned to one of two (or more) study groups using a quasi-random allocation method (e.g., alternation, date of birth, patient identifier), or (2) possibly assigned to one of two (or more) study groups using a process of random or quasi-random allocation;

‡ We defined a review article as one that summarizes a number of different studies and may draw conclusions about a particular intervention. The methods used to identify, select and appraise the studies are not systematic or necessarily reproducible. (Any review article that is not clearly a systematic review or a meta-analysis is a “review.”) The summary in a review is generally narrative; We defined a systematic review as a review of a clearly formulated question that uses systematic and explicit methods to identify, select, and critically appraise relevant research, and to collect and analyze data from the studies that are included in the review. Statistical methods are not used to analyze and summarize the results of the included studies; We defined a meta-analysis as a systematic review that uses statistical methods to integrate the results of the individual studies. A meta-analysis contains at least one estimate formed by pooling results across individual studies, i.e., an overall odds ratio.

## A.6 Evidence Grading System

Table A.6.1 Summary Score for Methodologic Quality

Summary Score | Jadad Score | Concealment of Allocation
A | 5 | Performed
B | 5 | Not performed, or Not reported
| 3 or 4 | Performed, Not performed, or Not reported
| 0, 1, or 2 | Performed
C | 0, 1, or 2 | Not performed or not reported

Even though a study may focus on a specific target population, limited study size, eligibility criteria and patient recruitment process may result in a narrow population sample that is of limited applicability, even to the target population. To capture this parameter, we categorize studies into the applicability scale described in Table A.6.1.

Table A.6.2 Applicability ratings

Applicability | | Health state
I | Sample is representative of the U.S. population. | A General population. Typical healthy people similar to Americans without known cardiovascular diseases.
II | Sample is representative of a relevant sub-group of the target population, but not the entire population. For example, a study that is restricted to women or a fish oil study in Japan where the background diet is very different from that of the US would fall into this category. | B Diseased population. Subjects with cancer.
III | Sample is representative of a narrow subgroup of subjects only, and not well applicable to other subgroups. For example, a study of oldest old men or a study of a population on highly controlled diet.

## Figure A.6.1 Jadad score of methodologic quality.*

## A.7 External Peer Reviewers

Table A.7.1 Peer Reviewers

Peer Reviewer | Area of Expertise | Affiliation
Judith Ashley, Ph.D., M.S.P.H., R.D. | Nutrition | University of Nevada, Reno
Bruce Bistrian, M.D., Ph.D. | Cancer | Harvard
Manuela Gago, M.D., Ph.D. | Cancer | University of Southern California
Heinz-Josef Lenz, M.D | Cancer | University of Southern California