# Listing of Excluded Studies

Codesheet for Episiotomy SER ProCite Database

[underlined: Field in ProCite] | [underlined: Code] | [underlined: Meaning of Code] | [underlined: Description & Comments]
Field Number: 11 | I | Abstract included | Article was pulled for review
Original field name: Title | E | Abstract excluded | Article was NOT pulled for review
Labeled as: Abstract Inclusion/Exclusion | B | Background | Article was excluded from the review but pulled for background
(From the Abstract Review Form)
[underlined: Field in ProCite] | [underlined: Code*] | [underlined: Meaning of Code] | [underlined: Description & Comments]
Field number: 12 | I | Full text included | “Full text INCLUDED” is checked at the end of the form
Original field name: Reprint Status | B | Background | “Full text EXCLUDED but used for BACKGROUND CITATION” is checked at the end of the form; these articles, because they are excluded, will also have an exclusion code(s) in this field
Labeled as: Full Text Inclusion/Exclusion | U | Unavailable | The article was to be pulled for review but was not retrievable by the libraries
(From the Full Text Inclusion/Exclusion form) | E | Full text excluded-Unclassified | These articles are obvious excludes but the reviewers did not agree on the reason…this may be settled in the future
*Please note: An article could be excluded for more than one reason if the reasons are E3-E6 | | | SETTLED 11/12/04
| E1 | Full text excluded - Not original research | #1 is “No”
| E2 | Full text excluded - Wrong population | #2 is “No”
| E3 | Full text excluded - N<40 | #3 is ”No”
| E4 | Full text excluded - Wrong outcome and/or study design | #4 is “No”
| E5 | Full text excluded - Foreign language | #5 is “No”
| E6 | Full text excluded - Wrong time period | #6 is “No”

* More than one code can be entered into this field. Separate codes with a comma

[underlined: Field in ProCite] | [underlined: Code*] | [underlined: Meaning of Code] | [underlined: Description & Comments]
Field number: 13 | 1 | Addresses KQ1 | Enter if box is checked under “Outcomes and Key Questions”
Original field name: Place of Meeting | 2 | Addresses KQ2 | Enter if box is checked under “Outcomes and Key Questions”
Labeled as: Key Questions Addressed | 3 | Addresses KQ3 | Enter if box is checked under “Outcomes and Key Questions”
(From the Full Text Inclusion/Exclusion form) | 4 | Addresses KQ4 | Enter if box is checked under “Outcomes and Key Questions”
| 5 | Addresses KQ5 | Enter if box is checked under “Outcomes and Key Questions”

* More than one code can be entered into this field. Separate codes with a comma

[underlined: Field in ProCite] | [underlined: Code] | [underlined: Meaning of Code] | [underlined: Description & Comments*]
Field Number: 14 | Y | Yes | The reference list of this background article was hand-searched for additional references
Original field name: Medium Designator | N | No | The reference list of this background article was not hand-searched for additional references
Labeled as: Background-Hand Searched

* These articles have a “B” in field number 11 or field number 12. This field will be blank for all other articles.

[underlined: Field in ProCite] | [underlined: Code] | [underlined: Meaning of Code] | [underlined: Description & Comments]
Field Number: 15 | RCT | RCT | This study was a randomized-controlled trial
Original field name: Edition
Labeled as: Study Design | COHORT | Prospective Cohort | This study was a prospective cohort