# Evidence Table References

Adoni A, Anteby E. The use of Histoacryl for episiotomy repair. Br J Obstet Gynaecol. 1991;98(5):476-8. [pmid: 2059595].
Argentine Episiotomy Trial Collaborative Group. Routine vs selective episiotomy: A randomised controlled trial. Lancet. 1993;342(88868887):1517-8. [pmid: 7902901].
Beard R, Boyd I, Sims C. A trial of polyglycolic acid and chromic catgut sutures in episiotomy repair. Br J Clin Pract. 1974;28(12):409-10. [pmid: 4617592].
Bowen M L, Selinger M. Episiotomy closure comparing enbucrilate tissue adhesive with conventional sutures. Int J Gynaecol Obstet. 2002;78(3):201-5. [pmid: 12384264].
Buchan P C, Nicholls J A. Pain after episiotomy--a comparison of two methods of repair. J R Coll Gen Pract. 1980;30(214):297-300. [pmid: 7003131]. [pmcid: 2159530].
Coats P M, Chan K K, Wilkins M, et al. A comparison between midline and mediolateral episiotomies. Br J Obstet Gynaecol. 1980;87(5):408-12. [pmid: 7387941].
Dannecker C, Hillemanns P, Strauss A, et al. Episiotomy and perineal tears presumed to be imminent: Randomized controlled trial. Acta Obstet Gynecol Scand. 2004;83:364-8. [pmid: 15005784].
Doyle P M, Johanson R, Geetha T, et al. A prospective randomised controlled trial of perineal repair after childbirth, comparing interrupted chromic catgut to subcuticular prolene for skin closure. Br J Obstet Gynaecol. 1993;100(1):93-4. [pmid: 8427847].
Eason E, Labrecque M, Marcoux S, et al. Anal incontinence after childbirth. CMAJ. 2002;166(3):326-30. [pmid: 11868640]. [pmcid: 99311].
Eason E, Labrecque M, Marcoux S, et al. Effects of carrying a pregnancy and of method of delivery on urinary incontinence: A prospective cohort study. BMC Pregnancy Childbirth. 2004;4(1):4. [pmid: 15053837]. [pmcid: 375532].
Eltorkey M M, Nuaim M A. Episiotomy, elective or selective: A report of a random allocation trial. J Obstet Gynaecol. 1994;14(5):317-20.
Fleming N, Newton E R, Roberts J. Changes in postpartum perineal muscle function in women with and without episiotomies. J Midwifery Womens Health. 2003;48(1):53-9. [pmid: 12589305].
Gordon B, Mackrodt C, Fern E, et al. The Ipswich Childbirth Study: 1 A randomised evaluation of two stage postpartum perineal repair leaving the skin unsutured. Br J Obstet Gynaecol. 1998;105(4):435-40. [pmid: 9609272].
Gordon H, Logue M. Perineal muscle function after childbirth. Lancet. 1985;2(8447):123-5. [pmid: 2862319].
Grant A, Gordon B, Mackrodat C, et al. The Ipswich childbirth study: One year follow up of alternative methods used in perineal repair. BJOG. 2001;108(1):34-40. [pmid: 11213002].
Grant A, Sleep J, Ashurst H, et al. Dyspareunia associated with the use of glycerol-impregnated catgut to repair perineal trauma. Report of a 3-year follow-up study. Br J Obstet Gynaecol. 1989;96(6):741-3. [pmid: 2803998].
House M J, Cario G, Jones M H. Episiotomy and the perineum: A random controlled trial. J Obstet Gynaecol. 1986;7(2):107-10.
Isager-Sally L, Legarth J, Jacobsen B, et al. Episiotomy repair--immediate and long-term sequelae. A prospective randomized study of three different methods of repair. Br J Obstet Gynaecol. 1986;93(5):420-5. [pmid: 3011061].
Karacam Z, Eroglu K. Effects of episiotomy on bonding and mothers' health. J Adv Nurs. 2003;43(4):384-94. [pmid: 12887357].
Kettle C, Hills R K, Jones P, et al. Continuous versus interrupted perineal repair with standard or rapidly absorbed sutures after spontaneous vaginal birth: A randomised controlled trial. Lancet. 2002;359(9325):2217-23. [pmid: 12103284].
Klein MC, Gauthier RJ, Jorgensen SH, et al. Does episiotomy prevent perineal trauma and pelvic floor relaxation? Online J Curr Clin Trials 1992; Doc No 10.
Klein M C, Gauthier R J, Robbins J M, et al. Relationship of episiotomy to perineal trauma and morbidity, sexual dysfunction, and pelvic floor relaxation. Am J Obstet Gynecol. 1994;171(3):591-8. [pmid: 8092203].
Larsson P G, Platz-Christensen J J, Bergman B, et al. Advantage or disadvantage of episiotomy compared with spontaneous perineal laceration. Gynecol Obstet Invest. 1991;31(4):213-6. [pmid: 1885090].
Livingstone E, Simpson D, Naismith W C. A comparison between catgut and polyglycolic acid sutures in episiotomy repair. J Obstet Gynaecol Br Commonw. 1974;81(3):245-7. [pmid: 4595298].
MacArthur C, Bick D E, Keighley M R. Faecal incontinence after childbirth. Br J Obstet Gynaecol. 1997;104(1):46-50. [pmid: 8988696].
Mackrodt C, Gordon B, Fern E, et al. The Ipswich Childbirth Study: 2 A randomised comparison of polyglactin 910 with chromic catgut for postpartum perineal repair. Br J Obstet Gynaecol. 1998;105(4):441-5. [pmid: 9609273].
Mahomed K, Grant A, Ashurst H, et al. The Southmead perineal suture study. A randomized comparison of suture materials and suturing techniques for repair of perineal trauma. Br J Obstet Gynaecol. 1989;96(11):1272-80. [pmid: 2558705].
McElhinney B R, Glenn D R, Dornan G, et al. Episiotomy repair: Vicryl versus Vicryl rapide. Ulster Med J. 2000;69(1):27-9. [pmid: 10881642].
Oboro V O, Tabowei T O, Loto O M, et al. A multicentre evaluation of the two-layered repair of postpartum perineal trauma. J Obstet Gynaecol. 2003;23(1):5-8. [pmid: 12623472].
Olah K S. Episiotomy repair-suture material and short term morbidity. J Obstet Gynaecol. 1990;10:503-5.
Ping W W, Kee T S. Episiotomy repair: A comparison of catgut and polyglycolic acid sutures. Med J Malaysia. 1975;30(2):135-8. [pmid: 1228379].
Rockner G. Urinary incontinence after perineal trauma at childbirth. Scand J Caring Sci. 1990;4(4):169-72. [pmid: 2293286].
Rockner G, Henningsson A, Wahlberg V, et al. Evaluation of episiotomy and spontaneous tears of perineum during childbirth. Scand J Caring Sci. 1988;2(1):19-24. [pmid: 3420336].
Rockner G, Jonasson A, Olund A. The effect of mediolateral episiotomy at delivery on pelvic floor muscle strength evaluated with vaginal cones. Acta Obstet Gynecol Scand. 1991;70(1):51-4. [pmid: 1858497].
Rogers R E. Evaluation of post-episiorrhaphy pain: Polyglycolic acid vs catgut sutures. Mil Med. 1974;139(2):102-4. [pmid: 4204803].
Sartore A, De Seta F, Maso G, et al. The effects of mediolateral episiotomy on pelvic floor function after vaginal delivery. Obstet Gynecol. 2004;103(4):669-73. [pmid: 15051557].
Signorello L B, Harlow B L, Chekos A K, et al. Postpartum sexual functioning and its relationship to perineal trauma: A retrospective cohort study of primiparous women. Am J Obstet Gynecol. 2001;184(5):881-8. ; discussion 888–90. [pmid: 11303195].
Sleep J, Grant A. West Berkshire perineal management trial: Three year follow up. Br Med J (Clin Res Ed). 1987;295(6601):749-51. [pmid: 3119022].
Sleep J, Grant A, Garcia J, et al. West Berkshire perineal management trial. Br Med J (Clin Res Ed). 1984;289(6445):587-90. [pmid: 6432201].
Spencer J A, Grant A, Elbourne D, et al. A randomized comparison of glycerol-impregnated chromic catgut with untreated chromic catgut for the repair of perineal trauma. Br J Obstet Gynaecol. 1986;93(5):426-30. [pmid: 3518787].
Upton A, Roberts C L, Ryan M, et al. A randomised trial, conducted by midwives, of perineal repairs comparing a polyglycolic suture material and chromic catgut. Midwifery. 2002;18(3):223-9. [pmid: 12381426].
Viktrup L, Lose G. The risk of stress incontinence 5 years after first delivery. Am J Obstet Gynecol. 2001;185(1):82-7. [pmid: 11483909].
Viktrup L, Lose G, Rolff M, et al. The symptom of stress incontinence caused by pregnancy or delivery in primiparas. Obstet Gynecol. 1992;79(6):945-9. [pmid: 1579319].
Walsh C J, Mooney E F, Upton G J, et al. Incidence of third-degree perineal tears in labour and outcome after primary repair. Br J Surg. 1996;83(2):218-21. [pmid: 8689168].