# Listing of excluded studies

Episiotomy no longer routine procedure. Health News 2000-2001; 17(6):3. Full text inclusion/exclusion: E1
Nonclinical factors may influence use of episiotomies. Research Activities 1996; (196):5-6. Full text inclusion/exclusion: E1
Solutions, techniques and pressure for wound cleansing. Best Practice 2003; 7(1):1–6. Full text inclusion/exclusion: E1
Albers L, Garcia J, Renfrew M, et al. Distribution of genital tract trauma in childbirth and related postnatal pain. Birth. 1999;26(1):11-5. Full text inclusion/exclusion: E4. [pmid: 10352050].
Albers L L, Anderson D, Cragin L, et al. Factors related to perineal trauma in childbirth. J Nurse Midwifery. 1996;41(4):269-76. Full text inclusion/exclusion: B, E4. [pmid: 8828312].
Althabe F, Belizan J M, Bergel E. Episiotomy rates in primiparous women in Latin America: hospital based descriptive study. Br Med J. 2002;324(7343):945-6. Full text inclusion/exclusion: E4. [pmid: 11964339]. [pmcid: 102327].
Anderson R, Greener D. A descriptive analysis of home births attended by CNMs in two nurse-midwifery services. J Nurse Midwifery. 1991;36(2):95-103. Full text inclusion/exclusion: E4. [pmid: 2037879].
Angioli R, Gomez-Marin O, Cantuaria G, et al. Severe perineal lacerations during vaginal delivery: the University of Miami experience. Am J Obstet Gynecol. 2000;182(5):1083-5. Full text inclusion/exclusion: E3. [pmid: 10819834].
Anthony S, Buitendijk S E, Zondervan K T, et al. Episiotomies and the occurrence of severe perineal lacerations. Br J Obstet Gynaecol. 1994;101(12):1064-7. Full text inclusion/exclusion: E4. [pmid: 7826959].
Arthure H G. Repair of the perineum. Lancet. 1970;1(7661):1405. Full text inclusion/exclusion: E1. [pmid: 4195078].
Atia W A, Tidbury P J. Persistent episiotomy granulation polyps; a polysymptomatic clinical entity. Acta Obstet Gynecol Scand. 1995;74(5):361-6. Full text inclusion/exclusion: E3,E4. [pmid: 7778429].
Aziz S A. Urinary fistulae from obstetrical trauma. J Obstet Gynaecol Br Commonw. 1965;72(5):765-8. Full text inclusion/exclusion: E1. [pmid: 5891593].
Bansal R K, Tan W M, Ecker J L, et al. Is there a benefit to episiotomy at spontaneous vaginal delivery? A natural experiment. Am J Obstet Gynecol. 1996;175(4 Pt 1):897-901. Full text inclusion/exclusion: B, E4. [pmid: 8885744].
Baruffi G, Dellinger W S J, Strobino D M, et al. Patterns of obstetric procedures use in maternity care. Obstet Gynecol. 1984;64(4):493-8. Full text inclusion/exclusion: E2. [pmid: 6483297].
Beischer N A. The anatomical and functional results of mediolateral episiotomy. Med J Aust. 1967;2(5):189-95. Full text inclusion/exclusion: B, E4. [pmid: 6057891].
Bergquist J R. The relief of postpartum pain with Fiorinal. Curr Ther Res Clin Exp. 1972;14(5):264-9. Full text inclusion/exclusion: E4. [pmid: 4623978].
Berry F N, Miller J M, Levin H M, et al. Relief of severe pain with acetaminophen in a new dose formulation versus propoxyphene hydrochloride 65 mg and placebo: a comparative double-blind study. Curr Ther Res Clin Exp. 1975;17(4):361-8. Full text inclusion/exclusion: E4. [pmid: 804383].
Bex P J, Hofmeyr G J. Perineal management during childbirth and subsequent dyspareunia. Clin Exp Obstet Gynecol. 1987;14(2):97-100. Full text inclusion/exclusion: E4. [pmid: 3568401].
Beynon C L. Midline episiotomy as a routine procedure. J Obstet Gynaecol Br Commonw. 1974;81(2):126-30. Full text inclusion/exclusion: E4. [pmid: 4816022].
Bloomfield S S, Barden T P, Hille R. Clinical evaluation of flufenisal, a long-acting analgesic. Clin Pharmacol Ther. 1970;11(5):747-54. Full text inclusion/exclusion: E4. [pmid: 4917093].
Bodner-Adler B, Bodner K, Kaider A, et al. Risk factors for third-degree perineal tears in vaginal delivery, with an analysis of episiotomy types. J Reprod Med. 2001;46(8):752-6. Full text inclusion/exclusion: E3. [pmid: 11547651].
Bodner K, Bodner-Adler B, Wagenbichler P, et al. Perineal lacerations during spontaneous vaginal delivery. Wien Klin Wochenschr. 2001;113(19):743-6. Full text inclusion/exclusion: E3. [pmid: 11715753].
Borgatta L, Piening S L, Cohen W R. Association of episiotomy and delivery position with deep perineal laceration during spontaneous delivery in nulliparous women. Am J Obstet Gynecol. 1989;160(2):294-7. Full text inclusion/exclusion: E3. [pmid: 2916609].
Bourne A. Perineal laceration. Med World. 1954;80(3):249-55. Full text inclusion/exclusion: E1. [pmid: 13153599].
Brendsel C, Peterson G, Mehl L E. Routine episiotomy and pelvic symptomatology. Women & Health. 1980;5:49-60. Full text inclusion/exclusion: E3.
Buchhave P, Flatow L, Rydhstroem H, et al. Risk factors for rupture of the anal sphincter. Eur J Obstet Gynecol Reprod Biol. 1999;87(2):129-32. Full text inclusion/exclusion: E3. [pmid: 10597960].
Buekens P, Lagasse R, Dramaix M, et al. Episiotomy and third-degree tears. Br J Obstet Gynaecol. 1985;92(8):820-3. Full text inclusion/exclusion: B, E4. [pmid: 4027204].
Burrett J. Episiorrhaphy - a challenge to be accepted!. Midwives Chron. 1983;96(1146):234. Full text inclusion/exclusion: E1. [pmid: 6353180].
Cain J J, Shirar E. A new method for teaching the repair of perineal trauma of birth. Fam Med. 1996;28(2):107-10. Full text inclusion/exclusion: E1. [pmid: 8932490].
Carley M E, Carley J M, Vasdev G, et al. Factors that are associated with clinically overt postpartum urinary retention after vaginal delivery. Am J Obstet Gynecol. 2002;187(2):430-3. Full text inclusion/exclusion: E3. [pmid: 12193938].
Carroli G, Belizan J. Episiotomy for vaginal birth. The Cochrane Library 2004; (1). Full text inclusion/exclusion: B, E1
Carroll T G, Engelken M, Mosier M C, et al. Epidural analgesia and severe perineal laceration in a community-based obstetric practice. J Am Board Fam Pract. 2003;16(1):1-6. Full text inclusion/exclusion: E1. [pmid: 12583644].
Cater L. Nursing Mirror midwifery forum. A little knowledge severity and duration of perineal pain following delivery. Nurs Mirror. 1984;159(11):i-viii. Full text inclusion/exclusion: B, E4. [pmid: 6567164].
Chaliha C, Sultan A H. Midline episiotomy and anal incontinence. Training is needed in the recognition and repair of perineal trauma. Br Med J. 2000;320(7249):1601. Full text inclusion/exclusion: E1.
Chalmers I. Evaluating the quality of new procedures. Arch Gynecol Obstet. 1987;241(Suppl):S101-6. Full text inclusion/exclusion: B, E1. [pmid: 3322200].
Chambliss L R, Daly C, Medearis A L, et al. The role of selection bias in comparing cesarean birth rates between physician and midwifery management. Obstet Gynecol. 1992;80(2):161-5. Full text inclusion/exclusion: E1. [pmid: 1635724].
Ching-Chung L, Shuenn-Dhy C, Ling-Hong T, et al. Postpartum urinary retention: assessment of contributing factors and long-term clinical impact. Aust N Z J Obstet Gynaecol. 2002;42(4):365-8. Full text inclusion/exclusion: E1. [pmid: 12403282].
Chowdhury M N, Desilva S K. Episiotomy wound infection due to Gardnerella vaginalis. Eur J Clin Microbiol. 1986;5(2):164-5. Full text inclusion/exclusion: E1. [pmid: 3487451].
Christianson L M, Bovbjerg V E, McDavitt E C, et al. Risk factors for perineal injury during delivery. Am J Obstet Gynecol. 2003;189(1):255-60. Full text inclusion/exclusion: E3. [pmid: 12861171].
Cloutier D, Regoli D. Double-blind study on the efficacy of benzydamine in episiotomy. Int Z Klin Pharmakol Ther Toxikol. 1971;5(3):297-300. Full text inclusion/exclusion: E1. [pmid: 4948238].
Coburn W A, Rutherford R N, Banks A L. Short-term use of oxyphenbutazone in the postpartum period. Obstet Gynecol. 1966;28(4):484-90. Full text inclusion/exclusion: E4. [pmid: 5925033].
Cochrane S. Perineal trauma. Nurs Times. 1992;88(21):64. Full text inclusion/exclusion: E1. [pmid: 1608764].
Cogan J E, Harris J W. Rectal complications after perineorrhaphy and episiotomy. Arch Surg. 1966;93(4):634-7. Full text inclusion/exclusion: E3. [pmid: 5331996].
Cogan R, Edmunds E P. The unkindest cut?. J Nurse Midwifery. 1978;23:17-23. Full text inclusion/exclusion: B, E1. [pmid: 357688].
Combs C A, Robertson P A, Laros R K J. Risk factors for third-degree and fourth-degree perineal lacerations in forceps and vacuum deliveries. Am J Obstet Gynecol. 1990;163(Pt 1):100-4. Full text inclusion/exclusion: E1. [pmid: 2375331].
Cox J, Cotzias C S, Siakpere O, et al. Does an inflatable obstetric belt facilitate spontaneous vaginal delivery in nulliparae with epidural analgesia?. Br J Obstet Gynaecol. 1999;106(12):1280-6. Full text inclusion/exclusion: E1. [pmid: 10609722].
Crawford L A, Quint E H, Pearl M L, et al. Incontinence following rupture of the anal sphincter during delivery. Obstet Gynecol. 1993;82(4 Pt 1):527-31. Full text inclusion/exclusion: E4. [pmid: 8377977].
Cronk M. Midwives' Journal. Perineal suturing. Nurs Times. 1987;83(7):62. Full text inclusion/exclusion: E1. [pmid: 3550716].
David M P, Boiman O, Avni A. Anti-inflammatory effect of oxyphenbutazone on episiotomy healing. Int Surg. 1976;61(20):555-6. Full text inclusion/exclusion: E4. [pmid: 789279].
Davidson K, Jacoby S, Brown M S. Prenatal perineal massage: preventing lacerations during delivery. J Obstet Gynecol Neonatal Nurs. 2000;29(5):474-9. Full text inclusion/exclusion: E1. [pmid: 11012126].
de Leeuw J W, Struijk P C, Vierhout M E, et al. Risk factors for third degree perineal ruptures during delivery. Br J Obstet Gynaecol. 2001;108(4):383-7. Full text inclusion/exclusion: E4.
De Leeuw J W, Vierhout M E, Struijk P C, et al. Anal sphincter damage after vaginal delivery: functional outcome and risk factors for fecal incontinence. Acta Obstet Gynecol Scand. 2001;80(9):830-4. Full text inclusion/exclusion: E3. [pmid: 11531634].
De Leeuw N K, Lowenstein L, Tucker E C, et al. Correlation of red cell loss at delivery with changes in red cell mass. Am J Obstet Gynecol. 1968;100(8):1092-101. Full text inclusion/exclusion: E1. [pmid: 5643188].
Deen K I, Kumar D, Williams J G, et al. The prevalence of anal sphincter defects in faecal incontinence: a prospective endosonic study. Gut. 1993;34(5):685-8. Full text inclusion/exclusion: E1. [pmid: 8504972]. [pmcid: 1374190].
Donkor E S. Continuous quality improvement initiative in health care: episiotomy management. West Afr J Nurs. 2001;12(1):12-21. Full text inclusion/exclusion: B, E1.
Dunn H P. Soft tissue dystocia and episiotomy. N Z Med J. 1965;64(397):496-9. Full text inclusion/exclusion: E1. [pmid: 5319853].
Dunn H P. Timing in obstetrics. N Z Med J. 1967;66(424):801-4. Full text inclusion/exclusion: E1. [pmid: 5236249].
Dunne K. Characteristics associated with perineal condition in an alternative birth center. J Nurse Midwifery. 1984;29(1):29-33. Full text inclusion/exclusion: E3. [pmid: 6559858].
Duthie S J, Ven D, Yung G L, et al. Discrepancy between laboratory determination and visual estimation of blood loss during normal delivery. Eur J Obstet Gynecol Reprod Biol. 1991;38(2):119-24. Full text inclusion/exclusion: E1. [pmid: 1995380].
Eason E, Labrecque M, Wells G, et al. Preventing perineal trauma during childbirth: a systematic review. Obstet Gynecol. 2000;95(3):464-71. Full text inclusion/exclusion: B, E1. [pmid: 10711565].
Eberhard J, Geissbuhler V. Influence of alternative birth methods on traditional birth management. Fetal Diagn Ther. 2000;15(5):283-90. Full text inclusion/exclusion: E1. [pmid: 10971082].
Ecker J L, Tan W M, Bansal R K, et al. Is there a benefit to episiotomy at operative vaginal delivery? Observations over ten years in a stable population. Am J Obstet Gynecol. 1997;176(2):411-4. Full text inclusion/exclusion: E1. [pmid: 9065190].
Enkin M W, Hunter D J, Snell L. Episiotomy: effects of a research protocol on clinical practice. Birth. 1984;11(3):145-6. Full text inclusion/exclusion: E1. [pmid: 6566573].
Essed G G, Martin C B, Crevels A J, et al. The influence of long term beta-mimetic drug administration during pregnancy on blood loss postpartum. Eur J Obstet Gynecol Reprod Biol. 1982;13(3):159-68. Full text inclusion/exclusion: B, E4. [pmid: 6980151].
Ezenagu L C, Kakaria R, Bofill J A. Sequential use of instruments at operative vaginal delivery: is it safe?. Am J Obstet Gynecol. 1999;180(6 Pt 1):1446-9. Full text inclusion/exclusion: E1. [pmid: 10368486].
Faut-Callahan M, Paice J. Postoperative pain control for the parturient. J Perinat Neonat Nursing. 1990;4(1):27-40. Full text inclusion/exclusion: E1.
Fedrick J, Yudkin P. Obstetric practice in the Oxford Record Linkage Study Area 1965-72. Br Med J. 1976;1(6012):738-40. Full text inclusion/exclusion: E1. [pmid: 944067]. [pmcid: 1639238].
Fenner D E, Genberg B, Brahma P, et al. Fecal and urinary incontinence after vaginal delivery with anal sphincter disruption in an obstetrics unit in the United States. Am J Obstet Gynecol. 2003;189(6):1543-9. discussion 1549-50. Full text inclusion/exclusion: E4. [pmid: 14710059].
Fernando B, Leeves L, Greenacre J, et al. Audit of the relationship between episiotomy and risk of major perineal laceration during childbirth. Br J Clin Pract. 1995;49(1):40-1. Full text inclusion/exclusion: E3. [pmid: 7742185].
Fernando R J, Sultan A H, Radley S, et al. Management of obstetric anal sphincter injury: a systematic review & national practice survey. BMC Health Serv Res. 2002;2(1):9. Full text inclusion/exclusion: E4. [pmid: 12006105]. [pmcid: 116576].
Fischer S R. Factors associated with the occurrence of perineal lacerations. J Nurse Midwifery. 1979;24(1):18-26. Full text inclusion/exclusion: E3. [pmid: 252538].
Fish S A. Complete perineal laceration. West J Surg Obstet Gynecol. 1954;62(11):577-81. Full text inclusion/exclusion: E1. [pmid: 13217253].
Fitzpatrick M, Behan M, O'Connell P R, et al. Randomised clinical trial to assess anal sphincter function following forceps or vacuum assisted vaginal delivery. Br J Obstet Gynaecol. 2003;110(4):424-9. Full text inclusion/exclusion: E1.
Fitzpatrick M, Harkin R, McQuillan K, et al. A randomised clinical trial comparing the effects of delayed versus immediate pushing with epidural analgesia on mode of delivery and faecal continence. Br J Obstet Gynaecol. 2002;109(12):1359-65. Full text inclusion/exclusion: E4.
Fleissig A. Prevalence of procedures in childbirth. Br Med J. 1993;306(6876):494-5. Full text inclusion/exclusion: E4. [pmid: 8448462]. [pmcid: 1676791].
Fleshman J W, Peters W R, Shemesh E I, et al. Anal sphincter reconstruction: anterior overlapping muscle repair. Dis Colon Rectum. 1991;34(9):739-43. Full text inclusion/exclusion: E1. [pmid: 1914735].
Flynn P, Franiek J, Janssen P, et al. How can second-stage management prevent perineal trauma? Critical review. Can Fam Physician. 1997;43:73-84. Full text inclusion/exclusion: B, E1. [pmid: 9626426]. [pmcid: 2255173].
Foldspang A, Mommsen S, Djurhuus J C. Prevalent urinary incontinence as a correlate of pregnancy, vaginal childbirth, and obstetric techniques. Am J Public Health. 1999;89(2):209-12. Full text inclusion/exclusion: E3. [pmid: 9949751]. [pmcid: 1508519].
Formato L S. Routine prophylactic episiotomy. Is it always necessary. J Nurse Midwifery. 1985;30(3):144-8. Full text inclusion/exclusion: E1. [pmid: 3847472].
Forna F, Jamieson D J, Sanders D, et al. Pregnancy outcomes in foreign-born and US-born women. Int J Gynaecol Obstet. 2003;83(3):257-65. Full text inclusion/exclusion: E1. [pmid: 14643035].
Fox J S. Episiotomy. Midwives Chron. 1979;92(1101):337-40. Full text inclusion/exclusion: E1. [pmid: 390323].
Frank R. Treatment of the perineum by pulsed electro magnetic therapy. Midwives Chron. 1985;98(1174):297-8. Full text inclusion/exclusion: E1. [pmid: 3854447].
French L. Are birth position and type of birth attendant associated with differences in rate of intact perineum?. Evidence-Based Practice. 2002;5(6):7-8. 2p. Full text inclusion/exclusion: E1.
French L. Does episiotomy lead to longer laceration in women undergoing their first vaginal delivery?. Evidence-Based Practice. 2001;4(12):1. 2p. Full text inclusion/exclusion: E1.
Frye A. Can we really use Super Glue instead of suture?. Midwifery Today Childbirth Educ. 1996;(38):13-4. Full text inclusion/exclusion: E1. [pmid: 8826377].
Fynes M. Childbirth and faecal incontinence. Aust Cont J 2001; 7(1):2–4, 6. Full text inclusion/exclusion: E1
Gass M S, Dunn C, Stys S J. Effect of episiotomy on the frequency of vaginal outlet lacerations. J Reprod Med. 1986;31(4):240-4. Full text inclusion/exclusion: E3. [pmid: 3712363].
Geissbuhler V, Eberhard J. Waterbirths: a comparative study. A prospective study on more than 2,000 waterbirths. Fetal Diagn Ther. 2000;15(5):291-300. Full text inclusion/exclusion: E1. [pmid: 10971083].
Gerrits D D, Brand R, Gravenhorst J B. The use of an episiotomy in relation to the professional education of the delivery attendant. Eur J Obstet Gynecol Reprod Biol. 1994;56(2):103-6. Full text inclusion/exclusion: E2. [pmid: 7805959].
Given F T J. Rectovaginal fistula. A review of 20 years' experience in a community hospital. Am J Obstet Gynecol. 1970;108(1):41-6. Full text inclusion/exclusion: E1. [pmid: 4916866].
Glossop C. Perineal care after childbirth. Health Visit. 1996;69(3):96-9. Full text inclusion/exclusion: E1.
Goldberg J, Holtz D, Hyslop T, et al. Has the use of routine episiotomy decreased? Examination of episiotomy rates from 1983 to 2000. Obstet Gynecol. 2002;99(3):395-400. Full text inclusion/exclusion: E4. [pmid: 11864665].
Graham I D, Graham D F. Episiotomy counts: trends and prevalence in Canada, 1981/1982 to 1993/1994. Birth. 1997;24(3):141-7. Full text inclusion/exclusion: E4. [pmid: 9355272].
Green J R, Soohoo S L. Factors associated with rectal injury in spontaneous deliveries. Obstet Gynecol. 1989;73(5 Pt 1):732-8. Full text inclusion/exclusion: B, E4. [pmid: 2704499].
Grudzinskas J G, Atkinson L. Sexual function during the puerperium. Arch Sex Behav. 1984;13(1):85-91. Full text inclusion/exclusion: E3. [pmid: 6712464].
Gurel H, Gurel S A. Pelvic relaxation and associated risk factors: the results of logistic regression analysis. Acta Obstet Gynecol Scand. 1999;78(4):290-3. Full text inclusion/exclusion: E4. [pmid: 10203294].
Gurel H, Gurel S A, Atilla M K. Urethral syndrome and associated risk factors related to obstetrics and gynecology. Eur J Obstet Gynecol Reprod Biol. 1999;83(1):5-7. Full text inclusion/exclusion: E3, E4. [pmid: 10221602].
Hall W, McCracken K, Osterweil P, et al. Frequency and predictors for postpartum fecal incontinence. Am J Obstet Gynecol. 2003;188(5):1205-7. Full text inclusion/exclusion: E3. [pmid: 12748479].
Harris R E. An evaluation of the median episiotomy. Am J Obstet Gynecol. 1970;106(5):660-5. Full text inclusion/exclusion: E4. [pmid: 5413985].
Harvo-Noponen M, Seppala M. Double blind study of oral chymotrypsin in patients with episiotomy. Ann Chir Gynaecol Fenn. 1968;57(4):444-6. Full text inclusion/exclusion: E4. [pmid: 4893746].
Helwig J T, Thorp J M J, Bowes W A J. Does midline episiotomy increase the risk of third- and fourth-degree lacerations in operative vaginal deliveries?. Obstet Gynecol. 1993;82(2):276-9. Full text inclusion/exclusion: E4. [pmid: 8336877].
Henriksen T B, Bek K M, Hedegaard M, et al. Episiotomy and perineal lesions in spontaneous vaginal deliveries. Br J Obstet Gynaecol. 1992;99(12):950-4. Full text inclusion/exclusion: E3. [pmid: 1477014].
Henriksen T B, Bek K M, Hedegaard M, et al. Methods and consequences of changes in use of episiotomy. Br Med J. 1994;309(6964):1255-8. Full text inclusion/exclusion: E4. [pmid: 7888844].
Hojberg K E, Salvig J D, Winslow N A, et al. Urinary incontinence: prevalence and risk factors at 16 weeks of gestation. Br J Obstet Gynaecol. 1999;106(8):842-50. Full text inclusion/exclusion: E1. [pmid: 10453836].
Howard D, Davies P S, DeLancey J O, et al. Differences in perineal lacerations in black and white primiparas. Obstet Gynecol. 2000;96(4):622-4. Full text inclusion/exclusion: E4. [pmid: 11004370]. [pmcid: 1226415].
Howat R C, Lewis G D. The effect of bromelain therapy on episiotomy wounds--a double blind controlled clinical trial. J Obstet Gynaecol Br Commonw. 1972;79(10):951-3. Full text inclusion/exclusion: E4. [pmid: 4563795].
Hueston W J. Factors associated with the use of episiotomy during vaginal delivery. Obstet Gynecol. 1996;87(6):1001-5. Full text inclusion/exclusion: B, E4. [pmid: 8649679].
Hueston W J, Applegate J A, Mansfield C J, et al. Practice variations between family physicians and obstetricians in the management of low-risk pregnancies. J Fam Pract. 1995;40(4):345-51. Full text inclusion/exclusion: E2. [pmid: 7699347].
Huffman J W. Dyspareunia of vulvo-vaginal origin. Causes and management. Postgrad Med. 1983;73(2):287-96. Full text inclusion/exclusion: E1. [pmid: 6823460].
Hvidman L, Foldspang A, Mommsen S, et al. Postpartum urinary incontinence. Acta Obstet Gynecol Scand. 2003;82(6):556-63. Full text inclusion/exclusion: E4. [pmid: 12780427].
Imoh-Ita F, Fowler A. Are delayed and misdirected episiotomies predisposing factors for pelvic floor muscle dysfunction and third-degree tears?. Medscape Womens Health. 2002;7(4):11. Full text inclusion/exclusion: E1. [pmid: 12466743].
Jackson S. Episiotomy: does it have to hurt so much afterwards?. Prof Care Mother Child. 1994;4(4):100-4. Full text inclusion/exclusion: B, E1. [pmid: 8680164].
Kabiru W N, Jamieson D, Graves W, et al. Trends in operative vaginal delivery rates and associated maternal complication rates in an inner-city hospital. Am J Obstet Gynecol. 2001;184(6):1112-4. Full text inclusion/exclusion: E1. [pmid: 11349172].
Kaufman K, McDonald H. A retrospective evaluation of a model of midwifery care. Birth. 1988;15(2):95-9. Full text inclusion/exclusion: E4. [pmid: 3390279].
Ketcham K R, Pastorek J G 2, Letellier R L. Episiotomy repair: chromic versus polyglycolic acid suture. South Med J. 1994;87(4):514-7. Full text inclusion/exclusion: E4. [pmid: 8153782].
Klein M C, Janssen P A, MacWilliam L, et al. Determinants of vaginal-perineal integrity and pelvic floor functioning in childbirth. Am J Obstet Gynecol. 1997;176(2):403-10. Full text inclusion/exclusion: E1. [pmid: 9065189].
Klopfer F J, Cogan R, Henneborn W J. Second stage medical intervention and pain during childbirth. J Psychosom Res. 1975;19(4):289-93. Full text inclusion/exclusion: E4. [pmid: 1202214].
Knauth D G, Haloburdo E P. Effect of pushing techniques in birthing chair on length of second stage of labor. Nurs Res. 1986;35(1):49-51. Full text inclusion/exclusion: E1. [pmid: 3632848].
Labrecque M, Baillargeon L, Dallaire M, et al. Association between median episiotomy and severe perineal lacerations in primiparous women. Can Med Assoc J. 1997;156(6):797-802. Full text inclusion/exclusion: E4. [pmid: 9084384]. [pmcid: 1227042].
Legino L J, Woods M P, Rayburn W F, et al. Third- and fourth-degree perineal tears. 50 year's experience at a university hospital. J Reprod Med. 1988;33(5):423-6. Full text inclusion/exclusion: E1. [pmid: 3385696].
Levett D. Episiotomy - an over-used procedure?. Nurs Mirror Midwives J. 1974;139(16):89. Full text inclusion/exclusion: E1. [pmid: 4497204].
Levin H M, Bare W W, Berry F N, et al. Acetaminophen with codeine for the relief of severe pain in postpartum patients. Curr Ther Res Clin Exp. 1974;16(9):921-7. Full text inclusion/exclusion: E1. [pmid: 4214667].
Lewis L. “Are you sitting comfortably?” perineal management up to 13 months postnatally. Midwives Chron. 1994;107(1277):226-7. Full text inclusion/exclusion: E1. [pmid: 8028528].
Limb D G, Thelwall-Jones H. Perineal repair. Midwives Chron. 1975;88(1047):116. Full text inclusion/exclusion: E1. [pmid: 1091821].
Lind B. Obstetrical analgesia in Norway. Acta Obstet Gynecol Scand. 1970;49(3):231-4. Full text inclusion/exclusion: E1. [pmid: 5519496].
Liston W A. Episiotomy repair--immediate and long term sequela. A randomised study of three different methods of repair. Br J Obstet Gynaecol. 1987;94(3):282-3. Full text inclusion/exclusion: E1. [pmid: 3552027].
Lopez-Escobar G, Fortney JA, Riano-Gamboa G, et al. Maternity record: initial report on a national experience (Colombia). Int J Gynaecol Obstet 1978-1979; 17(1):40-6. Full text inclusion/exclusion: E1
Low L K, Seng J S, Murtland T L, et al. Clinician-specific episiotomy rates: Impact on perineal outcomes. J Midwifery Womens Health. 2000;45(2):87-93. Full text inclusion/exclusion: B, E4. [pmid: 10812853].
Lowe N K. Parity and pain during parturition. J Obstet Gynecol Neonatal Nurs. 1987;16(5):340-6. Full text inclusion/exclusion: E1. [pmid: 3316548].
Lydon-Rochelle M T, Albers L, Teaf D. Perineal outcomes and nurse-midwifery management. J Nurse Midwifery. 1995;40(1):13-8. Full text inclusion/exclusion: E3. [pmid: 7869144].
MacLennan A H. Perineal pain after childbirth. Med J Aust. 1990;152(1):1-2. Full text inclusion/exclusion: E1. [pmid: 2136762].
Mahony R, Behan M, O'Herlihy C, et al. Randomized, clinical trial of bowel confinement vs laxative use after primary repair of a third-degree obstetric anal sphincter tear. Dis Colon Rectum. 2004;47(1):12-7. Full text inclusion/exclusion: E4. [pmid: 14719145].
Maimbolwa M C, Ransjo-Arvidson A, Ng'andu N, et al. Routine care of women experiencing normal deliveries in Zambian maternity wards: a pilot study. Midwifery. 1997;13(3):125-31. Full text inclusion/exclusion: E1. [pmid: 9362852].
Marai W. A two years retrospective review of episiotomy at Jimma Teaching Hospital, southwestern Ethiopia. Ethiop Med J. 2002;40(2):141-8. Full text inclusion/exclusion: E4. [pmid: 12240575].
Maresh M. Management of the second stage of labour. Midwife Health Visit Community Nurse 1987; 23(11):498, 502–6. Full text inclusion/exclusion: E1
Martin S, Labrecque M, Marcoux S, et al. The association between perineal trauma and spontaneous perineal tears. J Fam Pract. 2001;50(4):333-7. Full text inclusion/exclusion: E1. [pmid: 11300986].
May J L. Modified median episiotomy minimizes the risk of third-degree tears. Obstet Gynecol. 1994;83(1):156-7. Full text inclusion/exclusion: E1. [pmid: 8272298].
Mazier W P, Senagore A J, Schiesel E C. Operative repair of anovaginal and rectovaginal fistulas. Dis Colon Rectum. 1995;38(1):4-6. Full text inclusion/exclusion: E1. [pmid: 7813343].
Mazuji M K, McGivney J Q. Etiology of anterior anal ulcer in the female. Va Med Mon (1918). 1968;95(9):523-4. Full text inclusion/exclusion: E1. [pmid: 5679316].
McCandlish R. Routine perineal suturing: is it time to stop?. Midwifery Digest. 2001;11(3):296-300. Full text inclusion/exclusion: E1.
McCandlish R, Bowler U, van Asten H, et al. A randomised controlled trial of care of the perineum during second stage of normal labour. Br J Obstet Gynaecol. 1998;105(12):1262-72. Full text inclusion/exclusion: E4. [pmid: 9883917].
McCullough A M. Episiotomy. J R Army Med Corps. 1984;130(1):60-3. Full text inclusion/exclusion: E1. [pmid: 6716359].
McCullough A M. Salt baths. J R Army Med Corps. 1992;138(2):101. Full text inclusion/exclusion: E1. [pmid: 1640409].
McGuinness M, Norr K, Nacion K. Comparison between different perineal outcomes on tissue healing. J Nurse Midwifery. 1991;36(3):192-8. Full text inclusion/exclusion: E3. [pmid: 1856765].
McIntyre D, Knox W A, Gumley S. Born before arrival--mother nature accoucheur. Aust Coll Midwives Inc J. 1993;6(3):7-10. Full text inclusion/exclusion: E1. [pmid: 8285875].
McLeod N L, Gilmour D T, Joseph K S, et al. Trends in major risk factors for anal sphincter lacerations: A 10-year study. J Obstet Gynaecol Can. 2003;25(7):586-93. Full text inclusion/exclusion: E4. [pmid: 12851671].
Mengert W F, Fish S A. Anterior rectal wall advancement; technic for repair of complete perineal laceration and recto-vaginal fistula. Obstet Gynecol. 1955;5(3):262-7. Full text inclusion/exclusion: E1. [pmid: 14356585].
Metcalfe A, Tohill S, Williams A, et al. A pragmatic tool for the measurement of perineal tears. Br J Midwifery. 2002;10(7):412-7. Full text inclusion/exclusion: E1.
Minassian V A, Jazayeri A, Prien S D, et al. Randomized trial of lidocaine ointment versus placebo for the treatment of postpartum perineal pain. Obstet Gynecol. 2002;100(6):1239-43. Full text inclusion/exclusion: E3. [pmid: 12468168].
Moir D D, Wallace G. Blood loss at forceps delivery. J Obstet Gynaecol Br Commonw. 1967;74(3):424-9. Full text inclusion/exclusion: E1. [pmid: 5298024].
Moore F A. Anal incontinence: a reappraisal. Obstet Gynecol. 1973;41(4):483-93. Full text inclusion/exclusion: E1. [pmid: 4696963].
Morrel B, Flu P K, Straub M J, et al. Isolated rectal lesions during parturition. Acta Obstet Gynecol Scand. 1996;75(5):495-7. Full text inclusion/exclusion: E1. [pmid: 8677778].
Murphy P A, Feinland J B. Perineal outcomes in a home birth setting. Birth. 1998;25(4):226-34. Full text inclusion/exclusion: E4. [pmid: 9892890].
Myerscough P R. Genital prolapse. Practitioner. 1972;208(246):470-4. Full text inclusion/exclusion: E1. [pmid: 4113159].
Nager C W, Helliwell J P. Episiotomy increases perineal laceration length in primiparous women. Am J Obstet Gynecol. 2001;185(2):444-50. Full text inclusion/exclusion: B, E4. [pmid: 11518907].
Nazir M, Carlsen E, Jacobsen A F, et al. Is there any correlation between objective anal testing, rupture grade, and bowel symptoms after primary repair of obstetric anal sphincter rupture?: an observational cohort study. Dis Colon Rectum. 2002;45(10):1325-31. Full text inclusion/exclusion: E4. [pmid: 12394430].
Nazir M, Stien R, Carlsen E, et al. Early evaluation of bowel symptoms after primary repair of obstetric perineal rupture is misleading: an observational cohort study. Dis Colon Rectum. 2003;46(9):1245-50. Full text inclusion/exclusion: E4. [pmid: 12972970].
Needham D, Sheriff J. A survey on tears and episiotomies of the perineum. Midwives Chron. 1983;96(1146):232-3. Full text inclusion/exclusion: E3. [pmid: 6555565].
Nelson M K. Client responses to a discrepancy between the care they want and the care they receive. Women Health. 1981;6(34):135-52. Full text inclusion/exclusion: B, E1. [pmid: 7052989].
Neri A, Joel-Cohen S J, Ovadia J. Anal stretching after obstetrical and gynecological surgery. Isr J Med Sci. 1981;17(8):709-10. Full text inclusion/exclusion: E1. [pmid: 7287413].
Newman M G, Lindsay M K, Graves W. The effect of epidural analgesia on rates of episiotomy use and episiotomy extension in an inner-city hospital. J Matern Fetal Med. 2001;10(2):97-101. Full text inclusion/exclusion: B, E4. [pmid: 11392600].
Nodine P M, Roberts J. Factors associated with perineal outcome during childbirth. J Nurse Midwifery. 1987;32(3):123-30. Full text inclusion/exclusion: E3. [pmid: 3647118].
Nygaard I E, Rao S S, Dawson J D. Anal incontinence after anal sphincter disruption: a 30-year retrospective cohort study. Obstet Gynecol. 1997;89(6):896-901. Full text inclusion/exclusion: B, E4. [pmid: 9170461].
Oakley D, Murray M E, Murtland T, et al. Comparisons of outcomes of maternity care by obstetricians and certified nurse-midwives. Obstet Gynecol. 1996;88(5):823-9. Full text inclusion/exclusion: E1. [pmid: 8885921].
Otoide V O, Ogbonmwan S M, Okonofua F E. Episiotomy in Nigeria. Int J Gynaecol Obstet. 2000;68(1):13-7. Full text inclusion/exclusion: E4. [pmid: 10687831].
Parnell C, Langhoff-Roos J, Moller H. Conduct of labor and rupture of the sphincter ani. Acta Obstet Gynecol Scand. 2001;80(3):256-61. Full text inclusion/exclusion: E4. [pmid: 11207492].
Paull T, Tedeschi L G. Perineal endometriosis at the site of episiotomy scar. Obstet Gynecol. 1972;40(1):28-34. Full text inclusion/exclusion: E3. [pmid: 4537891].
Payne T N, Carey J C, Rayburn W F. Prior third- or fourth-degree perineal tears and recurrence risks. Int J Gynaecol Obstet. 1999;64(1):55-7. Full text inclusion/exclusion: E4. [pmid: 10190670].
Pearl M L, Roberts J M, Laros R K, et al. Vaginal delivery from the persistent occiput posterior position. Influence on maternal and neonatal morbidity. J Reprod Med. 1993;38(12):955-61. Full text inclusion/exclusion: E1. [pmid: 8120853].
Peleg D, Kennedy C M, Merrill D, et al. Risk of repetition of a severe perineal laceration. Obstet Gynecol. 1999;93(6):1021-4. Full text inclusion/exclusion: E4. [pmid: 10362174].
Perry R E, Blatchford G J, Christensen M A, et al. Manometric diagnosis of anal sphincter injuries. Am J Surg. 1990;159(1):112-6. discussion 116-7. Full text inclusion/exclusion: E1. [pmid: 2294787].
Peschers U M, Sultan A H, Jundt K, et al. Urinary and anal incontinence after vacuum delivery. Eur J Obstet Gynecol Reprod Biol. 2003;110(1):39-42. Full text inclusion/exclusion: E4. [pmid: 12932869].
Petrou S, Gordon B, Mackrodt C, et al. Research How cost-effective is it to leave perineal skin unsutured?. Br J Midwifery. 2001;9(4):209-14. Full text inclusion/exclusion: E4.
Philpott R H. Foetal quality preserved in cephalopelvic disproportion in the primigravida. S Afr Med J. 1973;47(42):2021-5. Full text inclusion/exclusion: E1. [pmid: 4755014].
Pinta T M, Kylanpaa M L, Salmi T K, et al. Primary sphincter repair: are the results of the operation good enough?. Dis Colon Rectum. 2004;47(1):18-23. Full text inclusion/exclusion: E3. [pmid: 14719146].
Poen A C, Felt-Bersma R J, Dekker G A, et al. Third degree obstetric perineal tears: risk factors and the preventive role of mediolateral episiotomy. Br J Obstet Gynaecol. 1997;104(5):563-6. Full text inclusion/exclusion: E3. [pmid: 9166198].
Poen A C, Felt-Bersma R J, Strijers R L, et al. Third-degree obstetric perineal tear: long-term clinical and functional results after primary repair. Br J Surg. 1998;85(10):1433-8. Full text inclusion/exclusion: E4. [pmid: 9782032].
Rahman M S, Al-Suleiman S A, El-Yahia A R, et al. Surgical treatment of rectovaginal fistula of obstetric origin: a review of 15 years' experience in a teaching hospital. J Obstet Gynaecol. 2003;23(6):607-10. Full text inclusion/exclusion: E4. [pmid: 14617459].
Reading A E. A comparison of the McGill Pain Questionnaire in chronic and acute pain. Pain. 1982;13(2):185-92. Full text inclusion/exclusion: B, E1. [pmid: 6889722].
Reading A E, Sledmere C M, Cox D N, et al. How women view postepisiotomy pain. Br Med J (Clin Res Ed). 1982;284(6311):243-6. Full text inclusion/exclusion: E4. [pmid: 6799123].
Reynolds J L, Yudkin P L. Changes in the management of labour: 2. Perineal management. Can Med Assoc J. 1987;136(10):1045-9. Full text inclusion/exclusion: E4. [pmid: 3567764]. [pmcid: 1492550].
Rieger N, Perera S, Stephens J, et al. Anal sphincter function and integrity after primary repair of third-degree tear: uncontrolled prospective analysis. Aust N Z J Surg. 2004;74(3):122-4. Full text inclusion/exclusion: E4.
Riskin-Mashiah S, O'Brian Smith E, Wilkins I A. Risk factors for severe perineal tear: Can we do better?. Am J Perinatol. 2002;19(5):225-34. Full text inclusion/exclusion: E3. [pmid: 12152139].
Roberts J E, Kriz D M. Delivery positions and perineal outcome. J Nurse Midwifery. 1984;29(3):186-90. Full text inclusion/exclusion: E4. [pmid: 6563071].
Robinson J N, Norwitz E R, Cohen A P, et al. Episiotomy, operative vaginal delivery, and significant perinatal trauma in nulliparous women. Am J Obstet Gynecol. 1999;181(5 Pt 1):1180-4. Full text inclusion/exclusion: E1. [pmid: 10561641].
Rockner G, Wahlberg V, Olund A. Episiotomy and perineal trauma during childbirth. J Adv Nurs. 1989;14(4):264-8. Full text inclusion/exclusion: E4. [pmid: 2786892].
Rooks J P, Weatherby N L, Ernst E K M. The National Birth Center Study -- intrapartum and immediate postpartum and neonatal care part 2. J Nurse Midwifery. 1992;37(5):301-30. Full text inclusion/exclusion: B, E4. [pmid: 1403177].
Roopnarinesingh S. Combined vaginal-abdominal delivery of twins. West Indian Med J. 1987;36(1):17-8. Full text inclusion/exclusion: E1. [pmid: 3590743].
Rosser J. Cochrane made simple Women's position in second stage. Pract Midwife. 2000;3(8):10-1. Full text inclusion/exclusion: E1.
Rosser J. Fools rush in how little we know about normal birth. Pract Midwife. 1998;1(9):4-5. Full text inclusion/exclusion: E1.
Rosser J. Women's position in second stage. Pract Midwife. 2000;3(8):10-1. Full text inclusion/exclusion: E1.
Sa'adah S. Perineal massage to prevent perineal trauma during pregnancy. J Fam Pract. 1999;48(7):494-5. Full text inclusion/exclusion: E1. [pmid: 10428240].
Sachs D, Levin P S, Dooley K. Marginal eyelid laceration at birth. Am J Ophthalmol. 1986;102(4):539. Full text inclusion/exclusion: E1. [pmid: 3766675].
Sagen N, Haram K. Diazepam (Valium) as an anaesthetic for operative vaginal delivery. Acta Obstet Gynecol Scand. 1973;52(2):153-6. Full text inclusion/exclusion: E1. [pmid: 4689225].
Salamalekis E, Vasiliadis T X, Kairi P, et al. Perineal endometriosis. Int J Gynaecol Obstet. 1990;31(1):75-80. Full text inclusion/exclusion: E3, E4. [pmid: 1968023].
Samples J T, Dougherty M C, Abrams R M, et al. The dynamic characteristics of the circumvaginal muscles. J Obstet Gynecol Neonatal Nurs. 1988;17(3):194-201. Full text inclusion/exclusion: E3. [pmid: 3392622].
Sampselle C M, Brink C A, Wells T J. Digital measurement of pelvic muscle strength in childbearing women. Nurs Res. 1989;38(3):134-8. Full text inclusion/exclusion: E1. [pmid: 2717436].
Sampselle C M, Hines S. Spontaneous pushing during birth. Relationship to perineal outcomes. J Nurse Midwifery. 1999;44(1):36-9. Full text inclusion/exclusion: E3. [pmid: 10063223].
Sanders J, Campbell R, Peters T J. Effectiveness of pain relief during perineal suturing. Br J Obstet Gynaecol. 2002;109(9):1066-8. Full text inclusion/exclusion: E1.
Sandridge D A, Thorp J M J, Roddenberry P, et al. Vaginal delivery is associated with occult disruption of the anal sphincter mechanism. Am J Perinatol. 1997;14(9):527-33. Full text inclusion/exclusion: E3. [pmid: 9394161].
Schachtel B P, Thoden W R, Baybutt R I. Ibuprofen and acetaminophen in the relief of postpartum episiotomy pain. J Clin Pharmacol. 1989;29(6):550-3. Full text inclusion/exclusion: E4. [pmid: 2666455].
Seckin B, Avsar F, Parlakyigit E, et al. Effects of indomethacin suppository and lidocaine pomade for the relief of post-episiotomy pain. Int J Gynaecol Obstet. 2002;78(2):159-61. Full text inclusion/exclusion: E4. [pmid: 12175719].
Shihadeh A S, Nawafleh A N. Third degree tears and episiotomy. Saudi Med J. 2001;22(3):272-5. Full text inclusion/exclusion: E4. [pmid: 11307117].
Shiono P, Klebanoff M A, Carey J C. Midline episiotomies: More harm than good?. Obstet Gynecol. 1990;75(5):765-70. Full text inclusion/exclusion: E4. [pmid: 2183106].
Shorten A, Shorten B. Women's choice? The impact of private health insurance on episiotomy rates in Australian hospitals. Midwifery. 2000;16(3):204-12. Full text inclusion/exclusion: E4. [pmid: 10970754].
Shy K K, Eschenbach D A. Fatal perineal cellulitis from an episiotomy site. Obstet Gynecol. 1979;54(3):292-8. Full text inclusion/exclusion: E1. [pmid: 471368].
Signorello L B, Harlow B L, Chekos A K, et al. Midline episiotomy and anal incontinence: retrospective cohort study. Br Med J. 2000;320(7227):86-90. Full text inclusion/exclusion: B, E4. [pmid: 10625261]. [pmcid: 27253].
Simpson D. Examining the episiotomy argument. Midwife Health Visit Community Nurse. 1988;24(1):6-14. Full text inclusion/exclusion: E1. [pmid: 3357431].
Skoner M M, Thompson W D, Caron V A. Factors associated with risk of stress urinary incontinence in women. Nurs Res. 1994;43(5):301-6. Full text inclusion/exclusion: E3. [pmid: 7937177].
Skovlund E, Fyllingen G, Landre H, et al. Comparison of postpartum pain treatments using a sequential trial design. I Paracetamol versus placebo. Eur J Clin Pharmacol. 1991;40(4):343-7. Full text inclusion/exclusion: E3,E4. [pmid: 2050168].
Skovlund E, Fyllingen G, Landre H, et al. Comparison of postpartum pain treatments using a sequential trial design: II. Naproxen versus paracetamol. Eur J Clin Pharmacol. 1991;40(6):539-42. Full text inclusion/exclusion: E1. [pmid: 1884732].
Skovsted P, Hudson H E, Marshall B E. Some factors influencing early puerperal pulmonary function. Am J Obstet Gynecol. 1969;103(1):128-30. Full text inclusion/exclusion: E1. [pmid: 5812459].
Sleep J. Episiotomy in normal delivery. Nursing (Lond). 1984;2(21):614. Full text inclusion/exclusion: E1. [pmid: 6560301].
Sleep J. Episiotomy in normal delivery. One. Nurs Times. 1984;80(47):28-30. Full text inclusion/exclusion: E1.
Sleep J. Episiotomy in normal delivery. Two Management of the perineum. Nurs Times. 1984;80(48):51-4. Full text inclusion/exclusion: E1. [pmid: 6569498].
Smith M T, Levin H M, Bare W W, et al. Acetaminophen extra strength capsules versus propoxphene compound-65 versus placebo: a double-blind study of effectiveness and safety. Curr Ther Res Clin Exp. 1975;17(5):452-9. Full text inclusion/exclusion: E4. [pmid: 805029].
Snooks S J, Swash M, Henry M M, et al. Risk factors in childbirth causing damage to the pelvic floor innervation. Int J Colorectal Dis. 1986;1(1):20-4. Full text inclusion/exclusion: E4. [pmid: 3598309].
Snyder R R, Hammond T L, Hankins G D. Human papillomavirus associated with poor healing of episiotomy repairs. Obstet Gynecol. 1990;76(4):664-7. Full text inclusion/exclusion: E4. [pmid: 2170886].
Spellacy C E. Urinary incontinence in pregnancy and the puerperium. J Obstet Gynecol Neonat Nursing. 2001;30(6):634-41. Full text inclusion/exclusion: E3.
Steen M, Cooper K. A new device for the treatment of perineal wounds. J Wound Care. 1999;8(2):87-90. Full text inclusion/exclusion: E1. [pmid: 10232204].
Stiles D. Techniques for reducing the need for an episiotomy. Issues Health Care Women. 1980;2(34):105-11. Full text inclusion/exclusion: E1. [pmid: 6912864].
Stone I K, von Fraunhofer J A, Masterson B J. A comparative study of suture materials: chromic gut and chromic gut treated with glycerin. Am J Obstet Gynecol. 1985;151(8):1087-93. Full text inclusion/exclusion: E1. [pmid: 3885745].
Sullivan H. Midwives' Journal. Repairing the tear. Nurs Times. 1991;87(35):60-1. Full text inclusion/exclusion: E1.
Sultan A H, Johanson R B, Carter J E. Occult anal sphincter trauma following randomized forceps and vacuum delivery. Int J Gynaecol Obstet. 1998;61(2):113-9. Full text inclusion/exclusion: E4. [pmid: 9639214].
Sultan A H, Kamm M A. Faecal incontinence after childbirth. Br J Obstet Gynaecol. 1997;104(9):979-82. Full text inclusion/exclusion: E1. [pmid: 9307520].
Sultan A H, Kamm M A, Hudson C N, et al. Anal-sphincter disruption during vaginal delivery. N Engl J Med. 1993;329(26):1905-11. Full text inclusion/exclusion: E1. [pmid: 8247054].
Tay S K, Soong S L, Choo B M. Is routine procaine spirit application necessary in the care of episiotomy wound?. Singapore Med J. 1999;40(9):581-3. Full text inclusion/exclusion: E4. [pmid: 10628247].
Thorp J M J, Bowes W A J, Brame R G, et al. Selected use of midline episiotomy: Effect on perineal trauma. Obstet Gynecol. 1987;70(2):260-2. Full text inclusion/exclusion: E4. [pmid: 3601289].
Thranov I, Kringelbach A M, Melchior E, et al. Postpartum symptoms. Episiotomy or tear at vaginal delivery. Acta Obstet Gynecol Scand. 1990;69(1):11-5. Full text inclusion/exclusion: E4. [pmid: 2346076].
Timonen S, Widholm O, Vara P. Puerperal infections. Ann Chir Gynaecol Fenn. 1967;56(1):75-83. Full text inclusion/exclusion: E1. [pmid: 6030226].
Tincello D G, Williams A, Fowler G E, et al. Differences in episiotomy technique between midwives and doctors. Br J Obstet Gynaecol. 2003;110(12):1041-4. Full text inclusion/exclusion: E4.
Tjandra J J, Han W R, Goh J, et al. Direct repair vs overlapping sphincter repair: a randomized, controlled trial. Dis Colon Rectum. 2003;46(7):937-42. discussion 942-3. Full text inclusion/exclusion: E4. [pmid: 12847369].
Tompkins M G, Lea R H. The use of polyglycolic acid sutures in obstetrics and gynecology. Can Med Assoc J. 1972;106(6):675 p. assim. Full text inclusion/exclusion: E4. [pmid: 5012232]. [pmcid: 1940509].
Van Dam P A, Irvine L. Carcinoma in episiotomy scars. Gynecol Oncol. 1992;44(1):96-100. Full text inclusion/exclusion: E1. [pmid: 1730433].
Varma A, Gunn J, Gardiner A, et al. Obstetric anal sphincter injury: prospective evaluation of incidence. Dis Colon Rectum. 1999;42(12):1537-43. Full text inclusion/exclusion: E4. [pmid: 10613471].
Venkatesh K S, Ramanujam P. Surgical treatment of traumatic cloaca. Dis Colon Rectum. 1996;39(7):811-6. Full text inclusion/exclusion: E1. [pmid: 8674376].
Venkatesh K S, Ramanujam P S, Larson D M, et al. Anorectal complications of vaginal delivery. Dis Colon Rectum. 1989;32(12):1039-41. Full text inclusion/exclusion: E3. [pmid: 2591278].
Vintzileos A M, Campbell W A, Dreiss R J, et al. Intrapartum fetal heart rate monitoring of the extremely premature fetus. Am J Obstet Gynecol. 1985;151(6):744-5. Full text inclusion/exclusion: E1. [pmid: 3976783].
Virtanen H, Hirvonen T, Makinen J, et al. Outcome of thirty patients who underwent repair of posthysterectomy prolapse of the vaginal vault with abdominal sacral colpopexy. J Am Coll Surg. 1994;178(3):283-7. Full text inclusion/exclusion: E1. [pmid: 8149022].
Virtanen H S, Makinen J I. Retrospective analysis of 711 patients operated on for pelvic relaxation in 1983-1989. Int J Gynaecol Obstet. 1993;42(2):109-15. Full text inclusion/exclusion: E1. [pmid: 7901057].
Vlasis G. Treatment of Bartholin cysts. Am Fam Physician. 1971;3(6):85-6. Full text inclusion/exclusion: E1. [pmid: 4931738].
Wadhawan S, Wacha D S. A review of urinary fistulae in a university teaching hospital. Int J Gynaecol Obstet. 1983;21(5):381-5. Full text inclusion/exclusion: E1. [pmid: 6141096].
Wagner R K, Nielsen P E, Gonik B. Shoulder dystocia. Obstet Gynecol Clin North Am. 1999;26(2):371-83. Full text inclusion/exclusion: E1. [pmid: 10399767].
Wahman A J, Finan M A, Emerson S C. Striae gravidarum as a predictor of vaginal lacerations at delivery. South Med J. 2000;93(9):873-6. Full text inclusion/exclusion: E4. [pmid: 11005345].
Waldenstrom U, Borg I, Olsson B, et al. The childbirth experience: a study of 295 new mothers. Birth. 1996;23(3):144-53. Full text inclusion/exclusion: B, E4. [pmid: 8924100].
Waldenstrom U, Gottvall K. A randomized trial of birthing stool or conventional semirecumbent position for second-stage labor. Birth. 1991;18(1):5-10. Full text inclusion/exclusion: E1. [pmid: 2006963].
Walker J. Edgware Birth Centre: what is the significance of this model of care?. MIDIRS Midwifery Digest. 2001;11(1):8-12. Full text inclusion/exclusion: E1.
Walker J L. Complete perineal incision for delivery. South Med J. 1974;67(3):265-8. Full text inclusion/exclusion: E4. [pmid: 4592182].
Walker M P, Farine D, Rolbin S H, et al. Epidural anesthesia, episiotomy, and obstetric laceration. Obstet Gynecol. 1991;77(5):668-71. Full text inclusion/exclusion: E3. [pmid: 2014077].
Walker P. Episiotomy: issues for practice. Nursing (Lond). 1990;4(15):18-22. Full text inclusion/exclusion: E1. [pmid: 2402346].
Wallace G. Blood loss in obstetrics using a haemoglobin dilution technique. J Obstet Gynaecol Br Commonw. 1967;74(1):64-7. Full text inclusion/exclusion: E1. [pmid: 6018099].
Walsh D. Evidence-based care Part eight: perineal care should be a feminist issue. Br J Midwifery. 2000;8(12):731-2. 734-7. Full text inclusion/exclusion: B, E1.
Walsworth D T, French L. Minimizing trauma to the genital tract in childbirth. J Fam Pract. 1998;47(6):411-2. Full text inclusion/exclusion: B, E1. [pmid: 9866655].
Walters B N, Smith V A, de Swiet M, et al. Pain relief after episiotomy--a comparative study of suprofen and dihydrocodeine. Br J Obstet Gynaecol. 1985;92(11):1160-3. Full text inclusion/exclusion: E4. [pmid: 3904819].
Walters R. Midwifery: episiotomy. Nurs Times 1981; 77 Suppl(38):14. Full text inclusion/exclusion: E1
Wandstrat T L. On the pharm Episiotomy spray on a newborn's painful diaper rash?. Mother Baby J. 1996;1(2):42-3. Full text inclusion/exclusion: E1.
Warren C. Making sense of episiotomy. Nurs Times. 1989;85(44):60-1. Full text inclusion/exclusion: E1. [pmid: 2594511].
Warshaw J S. Obstetric anal sphincter injury: incidence, risk factors, and repair. Seminars in Colon & Rectal Surgery. 2001;12(2):90-7. Full text inclusion/exclusion: E1.
Waterhouse C. Square peg, round hole. Pract Midwife. 1998;1(6):46. Full text inclusion/exclusion: E1.
Wear A. Problems in labor. Nursing (Lond). 1986;3(2):46-51. Full text inclusion/exclusion: E1. [pmid: 3485779].
Webb D A, Culhane J. Time of day variation in rates of obstetric intervention to assist in vaginal delivery. J Epidemiol Community Health. 2002;56(8):577-8. Full text inclusion/exclusion: B, E2. [pmid: 12118047].
Webb J C, Gilson G, Gordon L. Late second stage rupture of the uterus and bladder with vaginal birth after cesarean section: a case report and review of the literature. J Matern Fetal Med. 2000;9(6):362-5. Full text inclusion/exclusion: E1. [pmid: 11243296].
Weerasekera D S, Premaratne S. A randomised prospective trial of the obstetric forceps versus vacuum extraction using defined criteria. J Obstet Gynaecol. 2002;22(4):344-5. Full text inclusion/exclusion: E1. [pmid: 12521450].
Welch R A, Bottoms S F. Reconsideration of head compression and intraventricular hemorrhage in the vertex very-low-birth-weight fetus. Obstet Gynecol. 1986;68(1):29-34. Full text inclusion/exclusion: E1. [pmid: 3725256].
Wen S W, Liu S, Kramer M S, et al. Comparison of maternal and infant outcomes between vacuum extraction and forceps deliveries. Am J Epidemiol. 2001;153(2):103-7. Full text inclusion/exclusion: E1. [pmid: 11159152].
Whalen T V J, Kovalcik P J, Wilson G G. Traumatic perineal laceration. Am Surg. 1982;48(4):145-8. Full text inclusion/exclusion: E1. [pmid: 7081824].
Wheeler D G. Intrapartum bleeding. NAACOG's Clinical Issues in Perinatal and Women's Health Nursing. 1991;2(3):381-4. Full text inclusion/exclusion: E1. [pmid: 1931385].
Whelton J. Pain control in labour. Nursing (Lond). 1990;4(2):14-8. Full text inclusion/exclusion: E1. [pmid: 2320321].
White C A, Koontz F P. Emolytic streptococcus infections in postpartum patients. Obstet Gynecol. 1973;41(1):27-32. Full text inclusion/exclusion: E1. [pmid: 4539406].
Widmark C, Tishelman C, Ahlberg B M. A study of Swedish midwives' encounters with infibulated African women in Sweden. Midwifery. 2002;18(2):113-25. Full text inclusion/exclusion: E1. [pmid: 12139909].
Wiklund I, Matthiesen A, Klang B, et al. A comparative study in Stockholm, Sweden of labour outcome and women's perceptions of being referred in labour. Midwifery. 2002;18(3):193-9. Full text inclusion/exclusion: E1. [pmid: 12381423].
Wilcox L S, Strobino D M, Baruffi G, et al. Episiotomy and its role in the incidence of perineal lacerations in a maternity center and a tertiary hospital obstetric service. Am J Obstet Gynecol. 1989;160(5 Pt 1):1047-52. Full text inclusion/exclusion: E4. [pmid: 2729380].
Wilkerson V A. The use of episiotomy in normal delivery. Midwives Chron. 1984;97(1155):106-10. Full text inclusion/exclusion: E4. [pmid: 6562371].
Williams A. Third-degree perineal tears: risk factors and outcome after primary repair. J Obstet Gynaecol. 2003;23(6):611-4. Full text inclusion/exclusion: E4. [pmid: 14617460].
Williams B. Care and repair of the perineum. Nurs Times. 1974;70(9):301-2. Full text inclusion/exclusion: E1. [pmid: 4594910].
Williams F L, du V F C, Mires G J, et al. Episiotomy and perineal tears in low-risk UK primigravidae. J Public Health Med. 1998;20(4):422-7. Full text inclusion/exclusion: E4. [pmid: 9923949].
Williams F L, Florey C V, Ogston S A, et al. UK study of intrapartum care for low risk primigravidas: a survey of interventions. J Epidemiol Community Health. 1998;52(8):494-500. Full text inclusion/exclusion: E4. [pmid: 9876360].
Williams JL, Cohen-Dodge K. Unveiling ritual mutilation. Midwifery Today Childbirth Educ 1993; (25):17-9, 41. Full text inclusion/exclusion: E1
Williams M C, Knuppel R A, O'Brien W F, et al. A randomized comparison of assisted vaginal delivery by obstetric forceps and polyethylene vacuum cup. Obstet Gynecol. 1991;78(5 Pt 1):789-94. Full text inclusion/exclusion: E1. [pmid: 1923198].
Willmott J. Community nursing: no need to flaw the pelvic floor. Nurs Mirror. 1979;148(13):31. Full text inclusion/exclusion: E1. [pmid: 254203].
Willmott J. Too many episiotomies. Midwives Chron. 1980;93(1105):46-8. Full text inclusion/exclusion: E1. [pmid: 6898278].
Wilson B L. Delivery outcomes of low risk births: comparison of certified nurse midwives and obstetricians. J Am Acad Nurs Pract. 1989;1(1):9-13. Full text inclusion/exclusion: E4.
Wilson E. The unusual anal fistula. Dis Colon Rectum. 1968;11(5):348-55. Full text inclusion/exclusion: E1. [pmid: 5683627].
Wittich A C. Endometriosis in an episiotomy scar: review of the literature and report of case. J Am Osteopath Assoc. 1982;82(1):22-3. Full text inclusion/exclusion: E1. [pmid: 7174384].
Wood C, Ng K H, Hounslow D, et al. Proceedings: A control trial demonstrates that speeding birth favourably affects cord blood pH. J Reprod Fertil. 1974;36(2):472-3. Full text inclusion/exclusion: E3,E4. [pmid: 4406173].
Wood C, Ng K H, Hounslow D, et al. Time--an important variable in normal delivery. J Obstet Gynaecol Br Commonw. 1973;80(4):295-300. Full text inclusion/exclusion: E3, E4. [pmid: 4704674].
Wood J, Amos L, Rieger N. Third degree anal sphincter tears: risk factors and outcome. Aust N Z J Obstet Gynaecol. 1998;38(4):414-7. Full text inclusion/exclusion: B, E4. [pmid: 9890222].
Woodman P J, Graney D O. Anatomy and physiology of the female perineal body with relevance to obstetrical injury and repair. Clin Anat. 2002;15(5):321-34. Full text inclusion/exclusion: B, E1. [pmid: 12203375].
Worth A M, Dougherty M C, McKey P L. Development and testing of the Circumvaginal Muscles Rating Scale. Nurs Res. 1986;35(3):166-8. Full text inclusion/exclusion: E1. [pmid: 3635052].
Wray J. ‘Being hard’ Reflections on making it to be a midwife. Pract Midwife. 2001;4(7):23. Full text inclusion/exclusion: E1. [pmid: 12026629].
Yackovich F H, Bender G N, Tsuchida A M. Case report: peri-anal episiotomy scar endometrioma imaged by CT and sector endoluminal ultrasound. Clin Radiol. 1994;49(8):578-9. Full text inclusion/exclusion: E1. [pmid: 7955876].
Yeo S, Fetters M, Maeda Y. Japanese couples' childbirth experiences in Michigan: implications for care. Birth. 2000;27(3):191-8. Full text inclusion/exclusion: E1. [pmid: 11251502].