# References and Included Studies

1 Weber A M, Meyn L. Episiotomy use in the United States, 1979-1997. Obstet Gynecol. 2002;100(6):1177-82. [pmid: 12468160].
2 Popovic JR. 1999 National Hospital Discharge Survey: Annual summary with detailed diagnosis and procedure data. Vital Health Stat 13 2001; (151):i–v, 1–206.
3 Martin J A, Hamilton B E, Ventura S J, et al. Births: Final data for 2000. Natl Vital Stat Rep. 2002;50(5):1-101. [pmid: 11876093].
4 Hall MJ, DeFrances CJ. 2001 National hospital discharge survey. Advance data from Vital and Health Statistics [serial online]. [Web Page]. 9 April 2003; Available at http://www.cdc.gov/nchs/data/ad/ad332.pdf.
5 Parrish K M, Holt V L, Connell F A, et al. Variations in the accuracy of obstetric procedures and diagnoses on birth records in Washington State, 1989. Am J Epidemiol. 1993;138(2):119-27. [pmid: 8342530].
6 Declercq ED, Sakala C, Corry MP, Applebaum S, Risher P, et al. Listening to Mothers: Report of the First National U.S. Survey of Women's Childbearing Experiences. New York: Maternity Center Association, 2002.
7 Hueston W J. Factors associated with the use of episiotomy during vaginal delivery. Obstet Gynecol. 1996;87(6):1001-5. [pmid: 8649679].
8 Webb D A, Culhane J. Hospital variation in episiotomy use and the risk of perineal trauma during childbirth. Birth. 2002;29(2):132-6. [pmid: 12000414].
9 Banta D, Thacker S B. The risks and benefits of episiotomy: A review. Birth. 1982;9(1):25-30. [pmid: 6751345].
10 Longo LD. Rigidity of soft parts. Delivery effected by incision in the perineum. by R.M.Taliaferro. The stethoscopie and Virginia Medical Gazette, vol. 2, pp. 383–385, 1852. Am J Obstet Gynecol 1976; 125(1):115.
11 Leavitt JW. Brought to bed: Childbearing in America 1750 to 1950. New York: Oxford University Press, 1986: 179–86.
12 Edwards M, Waldorf M. Reclaiming birth: History and heroines of American childbirth reform. The Crossing Press, 1984.
13 Bland BP, Montgomery TL. Practical Obstetrics. 3rd revised edition. Philadelphia: F.A. Davis Company, 1939.
14 Curtis AH, ed. Obstetrics and Gynecology. Philadelphia: W.B. Saunders Co., 1933.
15 Thacker S B, Banta H D. Benefits and risks of episiotomy: An interpretative review of the English language literature, 1860-1980. Obstet Gynecol Surv. 1983;38(6):322-38. [pmid: 6346168].
16 Banta H D, Thacker S B. The case for reassessment of health care technology. Once is not enough. JAMA. 1990;264(2):235-40. [pmid: 2355445].
17 Weeks J D, Kozak L J. Trends in the use of episiotomy in the United States: 1980-1998. Birth. 2001;28(3):152-60. [pmid: 11552962].
18 Draper J, Newell R. A discussion of some of the literature relating to history, repair and consequences of perineal trauma. Midwifery. 1996;12(3):140-5. [pmid: 8938094].
19 Low L K, Seng J S, Murtland T L, et al. Clinician-specific episiotomy rates: Impact on perineal outcomes. J Midwifery Womens Health. 2000;45(2):87-93. [pmid: 10812853].
20 Webb D A, Culhane J. Time of day variation in rates of obstetric intervention to assist in vaginal delivery. J Epidemiol Community Health. 2002;56(8):577-8. [pmid: 12118047].
21 Kaczorowski J, Levitt C, Hanvey L, et al. A national survey of use of obstetric procedures and technologies in Canadian hospitals: Routine or based on existing evidence?. Birth. 1998;25(1):11-8. [pmid: 9534500].
22 Harrison R F, Brennan M, North P M, et al. Is routine episiotomy necessary?. Br Med J (Clin Res Ed). 1984;288(6435):1971-5. [pmid: 6428627].
23 Sleep J, Grant A, Garcia J, et al. West Berkshire perineal management trial. Br Med J (Clin Res Ed). 1984;289(6445):587-90. [pmid: 6432201].
24 Klein M C, Kaczorowski J, Robbins J M, et al. Physicians' beliefs and behaviour during a randomized controlled trial of episiotomy: Consequences for women in their care. CMAJ. 1995;153(6):769-79. [pmid: 7664230]. [pmcid: 1487268].
25 Anonymous. Episiotomy Lancet 1968; 1(7533):75–6.
26 West SL, King V, Carey TS et al. Systems to rate the strength of scientific evidence. Evidence Report, Technology Assessment No. 47. Rockville, Md.: Agency for Healthcare Research and Quality. AHRQ Publication No. 02-E016, 2002.
27 Berkman ND, DeWalt DA, Pignone MP et al. Literacy and health outcomes. Evidence Report/Technology Assessment No. 87 (Prepared by RTI International-University of North Carolina Evidence-based Practice Center under Contract No. 290-02-0016). AHRQ Publication No. 04-E007-2. Rockville, MD: Agency for Healthcare Research and Quality, 2004.
28 House M J, Cario G, Jones M H. Episiotomy and the perineum: A random controlled trial. J Obstet Gynaecol. 1986;7(2):107-10.
29 Klein MC, Gauthier RJ, Jorgensen SH, et al. Does episiotomy prevent perineal trauma and pelvic floor relaxation? Online J Curr Clin Trials 1992; Doc No 10.
30 Argentine Episiotomy Trial Collaborative Group. Routine vs selective episiotomy: A randomised controlled trial. Lancet. 1993;342(88868887):1517-8. [pmid: 7902901].
31 Eltorkey M M, Nuaim M A. Episiotomy, elective or selective: A report of a random allocation trial. J Obstet Gynaecol. 1994;14(5):317-20.
32 Dannecker C, Hillemanns P, Strauss A, et al. Episiotomy and perineal tears presumed to be imminent: Randomized controlled trial. Acta Obstet Gynecol Scand. 2004;83:364-8. [pmid: 15005784].
33 Sleep J, Grant A. West Berkshire perineal management trial: Three year follow up. Br Med J (Clin Res Ed). 1987;295(6601):749-51. [pmid: 3119022].
34 Klein M C, Gauthier R J, Robbins J M, et al. Relationship of episiotomy to perineal trauma and morbidity, sexual dysfunction, and pelvic floor relaxation. Am J Obstet Gynecol. 1994;171(3):591-8. [pmid: 8092203].
35 Lede R L, Belizan J M, Carroli G. Is routine use of episiotomy justified?. Am J Obstet Gynecol. 1996;174(5):1399-402. [pmid: 9065102].
36 Coats P M, Chan K K, Wilkins M, et al. A comparison between midline and mediolateral episiotomies. Br J Obstet Gynaecol. 1980;87(5):408-12. [pmid: 7387941].
37 Helwig J T, Thorp J M J, Bowes W A J. Does midline episiotomy increase the risk of third- and fourth-degree lacerations in operative vaginal deliveries?. Obstet Gynecol. 1993;82(2):276-9. [pmid: 8336877].
38 Signorello L B, Harlow B L, Chekos A K, et al. Postpartum sexual functioning and its relationship to perineal trauma: A retrospective cohort study of primiparous women. Am J Obstet Gynecol. 2001;184(5):881-8. discussion 888–90. [pmid: 11303195].
39 Combs C A, Robertson P A, Laros R K J. Risk factors for third-degree and fourth-degree perineal lacerations in forceps and vacuum deliveries. Am J Obstet Gynecol. 1990;163(Pt 1):100-4. [pmid: 2375331].
40 Shiono P, Klebanoff M A, Carey J C. Midline episiotomies: More harm than good?. Obstet Gynecol. 1990;75(5):765-70. [pmid: 2183106].
41 Riskin-Mashiah S, O'Brian Smith E, Wilkins I A. Risk factors for severe perineal tear: Can we do better?. Am J Perinatol. 2002;19(5):225-34. [pmid: 12152139].
42 Bodner-Adler B, Bodner K, Kaider A, et al. Risk factors for third-degree perineal tears in vaginal delivery, with an analysis of episiotomy types. J Reprod Med. 2001;46(8):752-6. [pmid: 11547651].
43 Bodner-Adler B, Bodner K, Kimberger O, et al. Management of the perineum during forceps delivery. Association of episiotomy with the frequency and severity of perineal trauma in women undergoing forceps delivery. J Reprod Med. 2003;48(4):239-42. [pmid: 12746986].
44 Fenner D E, Genberg B, Brahma P, et al. Fecal and urinary incontinence after vaginal delivery with anal sphincter disruption in an obstetrics unit in the United States. Am J Obstet Gynecol. 2003;189(6):1543-9. discussion 1549–50. [pmid: 14710059].
45 McLeod N L, Gilmour D T, Joseph K S, et al. Trends in major risk factors for anal sphincter lacerations: A 10-year study. J Obstet Gynaecol Can. 2003;25(7):586-93. [pmid: 12851671].
46 Signorello L B, Harlow B L, Chekos A K, et al. Midline episiotomy and anal incontinence: retrospective cohort study. BMJ. 2000;320(7227):86-90. [pmid: 10625261]. [pmcid: 27253].
47 Adoni A, Anteby E. The use of Histoacryl for episiotomy repair. Br J Obstet Gynaecol. 1991;98(5):476-8. [pmid: 2059595].
48 Kettle C, Hills R K, Jones P, et al. Continuous versus interrupted perineal repair with standard or rapidly absorbed sutures after spontaneous vaginal birth: A randomised controlled trial. Lancet. 2002;359(9325):2217-23. [pmid: 12103284].
49 Doyle P M, Johanson R, Geetha T, et al. A prospective randomised controlled trial of perineal repair after childbirth, comparing interrupted chromic catgut to subcuticular prolene for skin closure. Br J Obstet Gynaecol. 1993;100(1):93-4. [pmid: 8427847].
50 Beard R, Boyd I, Sims C. A trial of polyglycolic acid and chromic catgut sutures in episiotomy repair. Br J Clin Pract. 1974;28(12):409-10. [pmid: 4617592].
51 Livingstone E, Simpson D, Naismith W C. A comparison between catgut and polyglycolic acid sutures in episiotomy repair. J Obstet Gynaecol Br Commonw. 1974;81(3):245-7. [pmid: 4595298].
52 Rogers R E. Evaluation of post-episiorrhaphy pain: Polyglycolic acid vs catgut sutures. Mil Med. 1974;139(2):102-4. [pmid: 4204803].
53 Ping W W, Kee T S. Episiotomy repair: A comparison of catgut and polyglycolic acid sutures. Med J Malaysia. 1975;30(2):135-8. [pmid: 1228379].
54 Buchan P C, Nicholls J A. Pain after episiotomy--a comparison of two methods of repair. J R Coll Gen Pract. 1980;30(214):297-300. [pmid: 7003131]. [pmcid: 2159530].
55 Isager-Sally L, Legarth J, Jacobsen B, et al. Episiotomy repair--immediate and long-term sequelae. A prospective randomized study of three different methods of repair. Br J Obstet Gynaecol. 1986;93(5):420-5. [pmid: 3011061].
56 Spencer J A, Grant A, Elbourne D, et al. A randomized comparison of glycerol-impregnated chromic catgut with untreated chromic catgut for the repair of perineal trauma. Br J Obstet Gynaecol. 1986;93(5):426-30. [pmid: 3518787].
57 Grant A, Sleep J, Ashurst H, et al. Dyspareunia associated with the use of glycerol-impregnated catgut to repair perineal trauma. Report of a 3-year follow-up study. Br J Obstet Gynaecol. 1989;96(6):741-3. [pmid: 2803998].
58 Mahomed K, Grant A, Ashurst H, et al. The Southmead perineal suture study. A randomized comparison of suture materials and suturing techniques for repair of perineal trauma. Br J Obstet Gynaecol. 1989;96(11):1272-80. [pmid: 2558705].
59 Olah K S. Episiotomy repair-suture material and short term morbidity. J Obstet Gynaecol. 1990;10:503-5.
60 Gordon B, Mackrodt C, Fern E, et al. The Ipswich Childbirth Study: 1. A randomised evaluation of two stage postpartum perineal repair leaving the skin unsutured. Br J Obstet Gynaecol. 1998;105(4):435-40. [pmid: 9609272].
61 Mackrodt C, Gordon B, Fern E, et al. The Ipswich Childbirth Study: 2. A randomised evaluation of two stage postpartum perineal repair leaving the skin unsutured. Br J Obstet Gynaecol. 1998;105(4):441-5. [pmid: 9609273].
62 McElhinney B R, Glenn D R, Dornan G, et al. Episiotomy repair: Vicryl versus Vicryl rapide. Ulster Med J. 2000;69(1):27-9. [pmid: 10881642].
63 Grant A, Gordon B, Mackrodat C, et al. The Ipswich childbirth study: One year follow up of alternative methods used in perineal repair. Br J Obstet Gynaecol. 2001;108(1):34-40.
64 Bowen M L, Selinger M. Episiotomy closure comparing enbucrilate tissue adhesive with conventional sutures. Int J Gynaecol Obstet. 2002;78(3):201-5. [pmid: 12384264].
65 Upton A, Roberts C L, Ryan M, et al. A randomised trial, conducted by midwives, of perineal repairs comparing a polyglycolic suture material and chromic catgut. Midwifery. 2002;18(3):223-9. [pmid: 12381426].
66 Oboro V O, Tabowei T O, Loto O M, et al. A multicentre evaluation of the two-layered repair of postpartum perineal trauma. J Obstet Gynaecol. 2003;23(1):5-8. [pmid: 12623472].
67 Kettle C. Perineal care. Clin Evid. 2002;(7):1284-95. [pmid: 12230747].
68 Gordon H, Logue M. Perineal muscle function after childbirth. Lancet. 1985;2(8447):123-5. [pmid: 2862319].
69 Viktrup L, Lose G. The risk of stress incontinence 5 years after first delivery. Am J Obstet Gynecol. 2001;185(1):82-7. [pmid: 11483909].
70 Viktrup L, Lose G, Rolff M, et al. The symptom of stress incontinence caused by pregnancy or delivery in primiparas. Obstet Gynecol. 1992;79(6):945-9. [pmid: 1579319].
71 Sartore A, De Seta F, Maso G, et al. The effects of mediolateral episiotomy on pelvic floor function after vaginal delivery. Obstet Gynecol. 2004;103(4):669-73. [pmid: 15051557].
72 Karacam Z, Eroglu K. Effects of episiotomy on bonding and mothers' health. J Adv Nurs. 2003;43(4):384-94. [pmid: 12887357].
73 Fleming N, Newton E R, Roberts J. Changes in postpartum perineal muscle function in women with and without episiotomies. J Midwifery Womens Health. 2003;48(1):53-9. [pmid: 12589305].
74 Rockner G. Urinary incontinence after perineal trauma at childbirth. Scand J Caring Sci. 1990;4(4):169-72. [pmid: 2293286].
75 Eason E, Labrecque M, Marcoux S, et al. Anal incontinence after childbirth. CMAJ. 2002;166(3):326-30. [pmid: 11868640]. [pmcid: 99311].
76 Eason E, Labrecque M, Marcoux S, et al. Effects of carrying a pregnancy and of method of delivery on urinary incontinence: A prospective cohort study. BMC Pregnancy Childbirth. 2004;4(1):4. [pmid: 15053837]. [pmcid: 375532].
77 Walsh C J, Mooney E F, Upton G J, et al. Incidence of third-degree perineal tears in labour and outcome after primary repair. Br J Surg. 1996;83(2):218-21. [pmid: 8689168].
78 Rockner G, Jonasson A, Olund A. The effect of mediolateral episiotomy at delivery on pelvic floor muscle strength evaluated with vaginal cones. Acta Obstet Gynecol Scand. 1991;70(1):51-4. [pmid: 1858497].
79 MacArthur C, Bick D E, Keighley M R. Faecal incontinence after childbirth. Br J Obstet Gynaecol. 1997;104(1):46-50. [pmid: 8988696].
80 Rockner G, Henningsson A, Wahlberg V, et al. Evaluation of episiotomy and spontaneous tears of perineum during childbirth. Scand J Caring Sci. 1988;2(1):19-24. [pmid: 3420336].
81 Larsson P G, Platz-Christensen J J, Bergman B, et al. Advantage or disadvantage of episiotomy compared with spontaneous perineal laceration. Gynecol Obstet Invest. 1991;31(4):213-6. [pmid: 1885090].
82 Kettle C, Johanson RB. Absorbable synthetic versus catgut suture material for perineal repair. Cochrane Database Syst Rev 2000; (2):CD000006 .
83 Thorp J M J, Bowes W A J, Brame R G, et al. Selected use of midline episiotomy: Effect on perineal trauma. Obstet Gynecol. 1987;70(2):260-2. [pmid: 3601289].
84 Gurewitsch E D, Donithan M, Stallings S P, et al. Episiotomy versus fetal manipulation in managing severe shoulder dystocia: A comparison of outcomes. Am J Obstet Gynecol. 2004;191(3):911-6. [pmid: 15467564].