# Discussion

The RTI International-University of North Carolina Evidence-based Practice Center (RTI-UNC EPC) identified a modest body of literature addressing the relationship between episiotomy and maternal outcomes. This chapter presents the conclusions from each of our key questions and discusses these conclusions in the context of our ratings of the strength of the body of evidence that we reviewed in detail in Chapter 3. Additionally, we discuss limitations of the review and this literature in general. Finally, we summarize needs for future research.

The focus of this systematic review is on maternal outcomes of “routine” episiotomy, with specific emphasis on five key questions:

KQ 1. Does the practice of liberal or routine episiotomy, compared to more selective use of episiotomy, influence maternal postpartum outcomes?

KQ 2. Does episiotomy incision type (i.e., midline or mediolateral) influence maternal postpartum outcomes?

KQ 3. Does the repair of the perineal defect (suture type and repair approach) influence maternal postpartum outcomes?

KQ 4. Does episiotomy have a long-term influence on urinary incontinence, fecal incontinence, or pelvic floor defects?

KQ 5. Does episiotomy or incision type, or both, influence future sexual function?

We have not assessed literature on maternal or fetal outcomes at the time of use in response to a maternal or fetal emergency or concurrent with use of vacuum or forceps. Moreover, much of the literature we did review to answer these key questions did not examine a full range of maternal outcomes.

Several elements of our review and approach to documentation warrant emphasis. First, conceptualizing “routine use” is a challenge because many studies describe the category by negatives such as “not for fetal distress” and “not for dystocia.” Thus, we provide the operational definitions of “routine” (sometimes denoted as “liberal”) and “restricted” use that authors of included publications used; in this way, readers may apply this information as a filter through which to view study findings. Second, readers need to appreciate that the majority of the included studies reflect outcomes of mediolateral episiotomy, rather than midline; the latter is the predominant approach used in the United States. For that reason, we specifically note the type of episiotomy used in individual studies in the text and tables throughout this report. Finally, we have developed detailed evidence tables (Appendix C *) that include these details as well as numerous other specifics of study design, measurement methods, and outcomes.

* Appendixes are provided electronically at http://www.ahrq.gov/clinic/tp/epistp.htm

This systematic evidence review assessed 7 randomized controlled trials of routine versus restricted use of episiotomy and identifies the sole trial of midline versus median episiotomy. We present evidence from 17 randomized controlled trials (RCTs) that is relevant to choosing among options for repair methods. We have also extended prior reviews to encompass longer-term maternal outcomes. Specifically, we have systematically assessed the evidence from 3 trials and 12 prospective cohorts related to the influence of episiotomy on measures of pelvic floor relaxation and urinary and fecal continence and the evidence from 4 trials and 6 prospective cohorts that provide information about sexual function and satisfaction.

As described in Chapter 3 and documented in our evidence tables, we gave close attention to grading the quality of individual studies. To complete the picture of the strength of evidence, we used that information and the collective picture of relevant work on each key question to arrive at a systematic rating of the overall strength of the evidence. To accomplish this, we created four ratings, based largely on past methods for this step from previous evidence reports of the RTI-UNC EPC, including systematic reviews performed for the U.S. Preventive Services Task Force. This approach employs four categories to describe the strength of evidence, as defined below:

- I. The evidence is from studies of strong design; results are both clinically important and consistent with minor exceptions at most; results are free from serious doubts about generalizability, bias, or flaws in research design. Studies with negative results have sufficiently large samples to have adequate statistical power.
- II. The evidence is from studies of strong design, but some uncertainty remains because of inconsistencies or concern about generalizability, bias, research design flaws, or adequate sample size. Alternatively, the evidence is consistent but derives from studies of weaker design.
- III. The evidence is from a limited number of studies of weaker design. Studies with strong design either have not been done or are inconclusive. No published literature.

Table 11 uses these four categories to document our assessment of the strength of evidence for our main key questions (or subquestions). No key question reflected Grade I evidence (the best possible). The strength of evidence was Grade II for KQ 1 and one part of KQ 3. The evidence was poorer - Grade III - for KQ 2, most of KQ 3, KQ 4, and KQ 5. All key questions had some degree of evidence, so Grade IV was not relevant.

Table 11. Overall strength of the evidence for this body of literature

Key Question | Grade (I–IV Scale)*
1. Episiotomy and maternal postpartum outcomes | II
2. Episiotomy incision type and maternal morbidity | III
3. Repair of perineal defect and maternal morbidity
Methods: 2-layer vs. 3-layer repair | III
Methods: Continuous vs. interrupted sutures | III
Materials: Absorbable vs. tissue adhesive | III
Materials: Absorbable sutures — standard vs. rapidly absorbed | III
Materials: Untreated catgut vs. treated catgut | III
Materials: Nonabsorbable vs. absorbable | III
Materials: Polyglycolic acid vs. chromic catgut | II
Combined methods and materials | III
4. Episiotomy and urinary incontinence, fecal incontinence, and pelvic floor defects | II
5. Episiotomy and future sexual function | II

## Principal Findings

### Key Question 1: Episiotomy and Maternal Postpartum Outcomes

This literature, spanning two decades from the mid-1980s to the present, has high internal consistency with respect to the postpartum effects of routine (or liberal) versus restrictive strategies for episiotomy use.^22,^ ^23,^ ^28–32^ We found few if any meaningful discrepancies in findings, and overall we regarded this body of evidence as Grade II.

Across studies, women in the restrictive-use groups had less severe posterior perineal trauma, more frequent but not severe anterior vaginal trauma, less overall need for suturing, and higher probability of having an intact perineum when compared to routine- or liberal-use policies. These differences in perineal trauma were associated with less pain in the short term among those in restrictive-use groups, with fairly prompt resolution of pain regardless of trial arm. Women in restrictive use arms had no greater or lesser risk of wound healing complications and were more likely to resume intercourse earlier. Overall loss to followup was pronounced during the weeks after birth; remarkably little is known about recovery trajectory or complications thereafter.

Although these trials are of fair to poor quality overall, we base our conclusion that this evidence does not support routine use of episiotomy on the notable consistency of findings. Routine episiotomy does not achieve any of the short-term goals it has been hypothesized to achieve. Indeed, routine use is harmful to the extent that it creates a surgical incision of greater extent than many women might have experienced had episiotomy not been performed.

### Key Question 2: Episiotomy Incision Type and Maternal Morbidity

On the question of midline vs. mediolateral episiotomy, only a single study found that women who had a midline episiotomy had a significantly greater rate of anal sphincter injuries than women in the mediolateral episiotomy group.^36^ Treatment groups did not report differences in pain or satisfaction with intercourse at 3 months after the intervention.

Because of considerable methodological flaws in this trial (poor internal validity), any conclusions must be drawn cautiously, and we rate this “body” of evidence as Grade III. However, because differences in sphincter injury rates are clinically important, we consider the finding of increased risk of severe injury with midline episiotomy compared to mediolateral to be relevant observational evidence.

### Key Question 3: Repair of Perineal Defect and Maternal Morbidity

Methods. Because of the heterogeneity of methods used for repair of episiotomies and perineal lacerations, overall conclusions are applicable only to the repair method under study. Generally, we rate the strength of evidence for these issues as Grade III except in one instance, mentioned below.

Two trials^60,^ ^63,^ ^66^ studied a two-layer approach, in which the perineal skin is left unsutured, against a three-layer approach, in which the skin is sutured closed. Two trials^48,^ ^58^ investigated the differences between a continuous (or subcuticular) method and an interrupted (or transcutaneous) method. Specific limitations of the trials and conclusions can be found below, grouped by the particular method comparison under study. Overall limitations in this body of evidence and suggestions for future research are presented later in this chapter.

Two-layer vs. three-layer repair. Both trials provided consistent evidence that favored the two-layer approach, although statistically significant differences between the two approaches were not always found. The Ipswich Childbirth study had an overall good quality with adequate definitions and measurement of outcomes, reported masking of the outcome assessors and patients, and less than 15 percent loss to followup at 1 year.^60,^ ^63^ Definitions and measurement of the outcomes were only fair in the other trial,^66^ making it harder to compare to other trials. The latter trial also reported outcomes only on women who had completed all followup assessments; it did not report on possible differences between completers and the women who missed one or more followup assessments.

Because the two-layer approach involves less suturing, it also means less inflammation and bruising; this in turn could result in less pain and perineal morbidity. Another explanation for the differences may lie with suture type. In the first trial, which produced fewer significant differences between the approaches, the investigators balanced polyglycolic acid and chromic catgut sutures.^60,^ ^63^In the other trial, a portion of the significant differences between the groups may be explained by an imbalance in suture type used. Chromic catgut was predominantly used and is hypothesized to be associated with increased pain, edema, and inflammation.^66^

Even with the limitations discussed above, the pool of evidence from both trials suggests that less overall perineal morbidity is associated with the two-layer repair approach, which leaves the perineal skin unsutured, than with the three-layer approach. The reduction in pain, need for analgesia, wound healing problems, and sexual morbidity, as well as a decrease in the time and cost required for initial suturing of the perineal skin, removal, and possible resuturing, may make the two-layer approach more beneficial than the traditional three-layer approach.

Continuous vs. interrupted sutures. Although the evidence is unclear, it suggests that a continuous method of repair, though it may be technically more difficult, may be superior to the interrupted method. Two good-quality trials produced inconsistent evidence that the continuous method of repair has less perineal morbidity and more patient satisfaction associated with it than the interrupted method of repair.^48,^ ^58^

Both trials, through a factorial design of randomization, also randomized women to different suture material groups. Both trials achieved valance with respect to suture type; authors represented results for methods of repair regardless of suture type. Both trials defined and measured outcomes well and achieved good followup. In both trials, the authors describe greater familiarity with the interrupted method of repair, which is said to be technically easier to perform than the continuous method. One clinical group (for the trials conducted in Southmead, United Kingdom) even suggests that their inconsistencies with other trials might have be attributable to the lack of practice with the method and subsequent unpopularity with the operators that performed the repair.^58^ Whether such differences in outcome arise for clinicians and women outside the United Kingdom, where methods of repair and training of those performing the repair could be different compared to other countries, remains to be seen.

Materials. Because this review includes trials dating back to 1974, the materials used differ over time. Two trials^47,^ ^64^ compared absorbable sutures with tissue adhesive; two trials^48,^ ^62^ compared absorbable sutures with their rapidly absorbed versions; one trial^56^ compared untreated with treated catgut; two trials^54,^ ^58^ compared nonabsorbable sutures with absorbable sutures; and eight trials^50–53,^ ^58,^ ^59,^ ^61,^ ^63,^ ^65^ compared polyglycolic acid with chromic catgut. Because of this heterogeneity, specific limitations of the trials and conclusions can be found below, grouped by the particular material comparison under study. Overall limitations in this body of evidence and suggestions for future research can be found later in this chapter.

Absorbable vs. tissue adhesive. Both trials^47,^ ^64^ were of poor quality because the method of randomization was inadequate or broken. However, even though sample size was small (n < 65 in both trials), both groups did define and measure perineal pain well and achieved good followup. These trials contribute possible evidence that repair with tissue adhesive may decrease perineal pain experienced in different situations in the immediate postpartum. This conclusion must be weighed in light of the inadequate randomization of these studies. Our review suggests that this question merits further study in a well-randomized trial.

Absorbable sutures: standard vs. rapidly absorbed. The mixed results from the good trial^48^ and lack of significant differences between groups in the poor trial^62^ suggest that evidence is insufficient about any difference in perineal pain between standard and rapidly absorbed sutures. We saw stronger evidence that women who had rapidly absorbed sutures required less removal of the material, presumably because it had been absorbed more quickly in the postpartum period. We had difficulty assessing the effect of type of absorbable suture on other healing outcomes because the poor trial grouped all outcomes together. Although the two trials evaluated sexual functioning at different time points, evidence suggests that rapidly absorbed sutures may decrease the amount of dyspareunia and the severity thereof in the puerperium. One item to note in the good-quality trial was the masking of the suture material. The trial acquired undyed sutures direct from the manufacturer, thereby achieving a very high level of internal validity and decreasing the amount of bias in assessment of the outcomes.

Untreated catgut vs. treated catgut. Only one trial addressed treated and untreated catgut.^56^ This trial achieved fair randomization and was able to blind the assessors and the patients. Loss to followup at 10 days and 3 months was minimal, but at 3 years, loss to followup was only fair (70 percent). A small amount of crossover to the other suture material group occurred, but the investigations did perform an intent-to-treat analysis.

This trial produced no evidence that “softgut” (i.e., treated catgut) is superior to untreated catgut with regard to perineal morbidity. In fact, the trial may indicate that softgut may be associated with higher morbidity, as there appeared to be more perineal pain in the immediate postpartum period and more painful sexual intercourse in the longer-term period. Though untreated catgut sutures needed to be removed more often, the authors attributed the difference to the tendency for the sutures to dry out. However, they speculated that such drying out could not completely explain the differences in perineal pain.

The women were repaired using different techniques, but the randomized groups were balanced in that respect. Investigators used the interrupted method approximately 60 percent of the time in both groups. Stratifying by technique of repair showed more marked dyspareunia and need for suture removal in women who were repaired using interrupted sutures, a finding that is consistent with other trials investigating method of repair

Nonabsorbable vs. absorbable. Because of the study design of the fair-quality trial^54^ and lack of control for possible confounding by method of repair, we cannot draw conclusions about the role of silk sutures in perineal morbidity from this trial. The authors present data by suture material and then do not mention differences in the methods until the conclusions section of their article. They concluded that the subcuticular method lent itself to short-term advantages, but they did not present the data to support their conclusion. Thus, although this trial may contribute to a body of evidence that looks at combinations of materials and methods, it does not contribute to the overall understanding of the role of suture materials in perineal morbidity, separate from methods of repair. The Mahomed et al. trial^58^ found no differences between the two groups in the short-term postpartum period, but did find differences at 3 months, indicating a possible delayed effect of the suture material.

Polyglycolic acid vs. chromic catgut. In 2004, the Cochrane Library published a systematic review and meta-analysis of information on polyglycolic acid versus catgut suture material for repair of perineal trauma.^82^ In it, they report that polyglycolic acid sutures were associated with less pain in the short-term postpartum period (Odds ratio [OR] = 0.62; 95% confidence interval [CI], 0.54–0.71) and with less need for analgesia (OR = 0.63; 95% CI, 0.52–0.77). No differences were found in long-term pain outcomes or in reports of dyspareunia.

Our systematic evidence review includes six of the eight trials that were included in the Cochrane review and an additional two trials. Overall, the evidence is from a combination of poor, fair, and good trials, but we considered the strength of evidence as Grade II; moreover, it is consistent with the previous Cochrane review. Basically, evidence indicates that polyglycolic acid sutures are associated with less perineal pain, a lesser need for analgesia use, and fewer healing problems in the short-term postpartum. For long-term outcomes, the evidence is consistent that outcomes of the use of polyglycolic acid sutures and chromic catgut do not differ substantially. One trial not in the Cochrane review^65^ did report more perineal pain and dyspareunia in the polyglycolic-acid group at 6 months, an outcome the authors attributed to the slower absorption rate of polyglycolic-acid sutures; however, these results were neither statistically significant nor precise. Overall, the body of evidence for the comparison of polyglycolic-acid sutures versus chromic-catgut sutures suggests that using polyglycolic-acid sutures for perineal repair offers many short-term advantages.

Combined Methods and Materials. Instead of investigating methods and materials separately, two trials^49,^ ^55^ compared entire approaches, combining both materials and methods in a single randomization design. The poor trial^49^ found no differences between the groups; the fair-quality trial^55^ found that women repaired with polyglycolic-acid sutures using a continuous, subcuticular approach suffered less perineal morbidity. This result is consistent with other trials that investigated subcuticular suturing and polyglycolic-acid sutures separately, perhaps reinforcing the notion that this method and suture type are superior to other options available to obstetric clinicians. Overall limitations in this body of evidence and suggestions for future research are provided later in this chapter.

Summary. The heterogeneity of methods and materials used for repair of episiotomy and perineal laceration arises in part from the passage of time and differences in practice across continents. Another set of issues to consider in studying the repair of episiotomy are the economic and geographic differences among clinical practices across the world. The choice of suture material might be restricted in resource-poor settings. If a clinic cannot afford or does not have access to polyglycolic acid, which, as reported in one of the studies,^66^ is more expensive than other absorbable sutures, then the clinic may have to make do with available sutures but perhaps supplement them with a method of repair that can decrease perineal morbidity.

During the time period that this review encompasses, investigators studied three major classes of suture material (nonabsorbable, absorbable, and tissue adhesive) and two subtypes of sutures (treated versus untreated and standard versus rapidly absorbed). These materials were all studied in the presence of different approaches to the method of suturing; therefore, individual effects of the materials themselves cannot be examined. Likewise, the methods of repair were examined in the context of different materials among the studies and within them for different stages of repair. For these reasons, truly determining the effects of a certain method of repair is impossible, because we are unable to tell whether the outcomes are confounded or modified by suture material.

### Key Question 4: Episiotomy and Urinary Incontinence, Fecal Incontinence, and Pelvic Floor Defects

The literature that provides evidence about routine episiotomy, continence, and pelvic floor defects and function is limited in several domains. All but two of the cohorts^34,^ ^75^ report outcomes for use of mediolateral episiotomy rather than midline episiotomy. The length and incompleteness of followup limits the usefulness of the data. We aimed to identify publications with followup ranging from years to decades after births to women with known episotomy histories. However, at completion, only five of 16 publications provide data with followup at 1 year or longer;^33,^ ^68–70,^ ^74^the longest interval was 5 years.^69^ Followup conducted within 6 months of birth, as in 10 percent of the 16 studies, does not reflect full recovery of the pelvic floor from vaginal birth. For that reason, we considered 6 months followup as an intermediate point of comparison rather than an evaluation of final pelvic floor and continence status.

All measures for followup at or beyond a year were self-reported by interview or questionnaire except a single study with perineometry conducted at 12 months.^68^ Neither self-report for many urinary and rectal continence symptoms nor perineometry and physiologic measures have been adequately validated. These measures do not relate directly to physical examination findings or individual functional status. Indeed, urodynamic testing and physical examination have very limited documentation of their ability to predict or classify continence status. These limitations must be kept in mind. The greatest clinical relevance would be to assess continence and pelvic floor deficits among women with known episiotomy histories beginning in their 40s and proceeding through their lifetimes. None of the identified studies provided such data.

Given these limitations of timing and methods of followup, these prospective studies did not identify improvements in continence for urine or stool or in pelvic floor muscle function among women who had had episiotomy compared to those who had not. This finding includes comparison to women who had spontaneous lacerations of similar severity. Several authors reported decrements in pelvic floor function among women who had episiotomy. Only a single study, using multivariable models, found that episiotomy was an independent predictor of urinary continence.^69^ In the majority of other studies using multivariate models, adjusting for factors such as parity, neonatal weight, and length of second-stage labor revealed that episiotomy was not an independent risk factor for incontinence. Taken in total, this literature, predominantly of fair to poor quality, does not support use of episiotomy for the purpose of preventing pelvic floor defects, urinary incontinence, or incontinence of stool or flatus. Table 11 shows this as graded strength of evidence Grade III.

In summary, these prospective studies are limited because they do not follow women long enough to detect disease occurrence. At present, the assumption that intermediate variables such as pelvic muscle strength measured by perineometry, urodynamic test results, or early reports of symptoms can predict later disease has not been validated. Prospective evaluation only during the months after birth when the pelvic floor is still in a recovery and stabilization period may be misleading. Conclusions about whether episiotomy prevents or increases risk for incontinence and prolapse later in adult life cannot be reached from currently available randomized and cohort studies.

### Key Question 5: Episiotomy and Future Sexual Function

The studies addressing this question need to be considered in three groups: the six studies that virtually exclusively evaluate effects of mediolateral incision,^23,^ ^33,^ ^71,^ ^72,^ ^80,^ ^81^ three that evaluate midline (median) incision,^29,^ ^34,^ ^38^ and one that compared the two incision types.^36^ From just the clinical trials of episiotomy strategy—liberal versus restrictive—one trial addresses each type of incision, and one directly compares the two incision types. None finds substantive differences in sexual function. Overall, this body of literature supports a conclusion that perineal trauma is associated with probability of pain with intercourse in a dose-response fashion such that greater perineal injury is associated with greater probability of pain.

The quality of the evidence (to which we assigned Grade III) to assess this question is limited for reflecting on the consequences of episiotomy. Both the clinical trials and the prospective cohorts assess overly simplified measures of sexual function. Definitions and specification of approaches to measurement are insufficient in many studies to assure accurate interpretation of findings. Validated instruments intended to assess nuances of sexual function such as type of pain, location of pain, severity of pain, orgasm, lubrication, and libido have not been deployed in the published research to assess prospectively the influence of perineal trauma in childbirth on future sexual function. More complex measures would need to be used to understand properly relationships between perineal trauma and future sexual function. Specific factors such as prior sexual function and current libido, in addition to factors such as duration of second-stage labor, size of infant, and lactation status need to be incorporated into multivariable models to generate more-informative and less-biased estimates of the long-term effects of episiotomy in this area. With these caveats, the evidence does not suggest that episotomy results in improved sexual function outcomes.

## Limitations of This Review and the Literature

### Deficiencies in The Literature

Our systematic review should be interpreted in the context of several limitations. First, as with all systematic reviews, its findings depend on the predefined approach to searching the literature and on the quality of the published literature identified. The limitations of the available studies (see Chapter 3) include the following:

- age of the data (trials from the 1980s and early 1990s were conducted in an era when background rate of episiotomy was higher);
- insufficient size of most trials for assessing clinically relevant endpoints (third- and fourth-degree lacerations, long-term incontinence);
- inadequate specification of a priori primary and secondary outcomes with few references to power calculations to determine required study size;
- infrequent use of multivariate modeling to account for shortcomings of randomization or need for stratification within RCTs or potential confounders in prospective cohort studies;
- infrequent use of masking of the assessor for outcomes;
- use of a wide variety of measures and timepoints for maternal postpartum outcomes, making comparisons among studies difficult;
- rare use of validated outcome measures;
- limited reporting of precise definitions of self-reported outcomes, particularly for pain, sexual function, and incontinence; and
- inconsistent reporting of appropriate statistical measures (i.e., use of P values without measures of magnitude or confidence intervals), making it difficult to determine if null findings represent lack of effect or limitations in power.

An additional limitation of the literature on KQ 1 results from the nature of the intervention. In essence, KQ 1 reviews studies of clinician behavior when asked to implement different policies for episitomy use. Differences in episiotomy rates observed in groups assigned to routine (i.e., liberal) use vary from a low of 23 percent^29^ to a high of 52 percent,^30^ suggesting that clinician behavior is not easily modified, even in the context of an RCT. Inconsistencies in the way that clinicians define and interpret routine use and restricted use of episiotomy within and across trials may temper differences between protocol groups. Additionally, violations of protocol can invalidate initial power calculations and lead to results that cannot be interpreted.

### Limitations to Our Review Procedures

Our review process also had some limitations. Because of time and resource constraints, we did not conduct dual, independent, blinded review of articles for inclusion or abstraction of information into evidence tables. Instead, one reviewer performed the initial review, and a second reviewer examined that input and recommended changes. Differences were reconciled between the two reviewers. We used dual review for grading the quality of individual articles, allowing us to evaluate rigorously systematic bias in these assessments.

## Future Research

Studies comparing restrictive to liberal use of episiotomy report that, even under a restrictive approach, episiotomy rates vary between 8 percent and 52 percent.^22,^ ^23,^ ^28–32^ This disparity suggests that episiotomy is considered to be clinically indicated for a substantial number of women even at the lowest levels recorded by our review. Currently, the evidence suggests that the putative benefits of episiotomy do not outweigh the harms in the general population. Instead, outcomes from episiotomy are worse because some proportion of women who would have had lesser injury instead had a surgical incision.

The majority of these studies to assess outcomes of routine episiotomy used mediolateral episiotomy. We do not, however, conclude that additional study of outcomes of routine use versus liberal use of midline episiotomy is warranted. Observational studies other than RCTs clearly and consistently relate midline episiotomy to higher rates of anal sphincter and rectal injury than those observed with mediolateral episiotomy.^9,^ ^40,^ ^42,^ ^83^ Thus, we would expect trials of routine use of midline episiotomy to have more numerous unfavorable outcomes than those observed in these studies, an effort not worth replicating given the lack of benefit of episiotomy supported by existing evidence.

If episiotomy were restricted to indicated use, an important question remains for women and their care providers: Which, if any, of the prevailing indications for episiotomy are supported by an adequate research base? A two-stage research agenda could address this need. First, a systematic review may clarify current knowledge about outcomes of episiotomy for the leading presumed indications. Second, primary data collection may be needed to fill in research gaps identified by such a review and to improve understanding of whether these are indeed indications for episiotomy. Work relating to the latter element of such a research agenda is under way on several topics including recent publication of a retrospective cohort study that suggests that use of episiotomy conferred no benefit in averting neonatal injury at the time of births complicated by shoulder dystocia.^84^ Additional evidence will be required to fully investigate what circumstances should be considered indications for episiotomy.

Establishing an evidence base for indications would lead to a health services research agenda focused on variations in rates and outcomes. Several issues are paramount: What safe and conservative rates of episiotomy are attainable? Should measures of quality of childbirth care include episiotomy rates? What approaches are most successful in reducing unnecessary use of episiotomy?

Furthermore, if the professional community accepts that routine episiotomy is not an effective means to reduce perineal injury, that attitude should enable them to redouble efforts to understand fully various (other) approaches to attending the second stage of labor that can promote maternal and infant safety, minimize perineal trauma, and maximize maternal comfort. The failure of one intervention-oriented method such as episiotomy to deliver such results does not reduce the likelihood that other approaches, or combinations of approaches, may be useful. These approaches include giving attention to maternal position, avoiding fundal pressure, reducing coached pushing, providing perineal support, and employing “hands poised” versus hands on techniques to support the perineum, and the role for lubrication and types of lubrication for use during crowning of the infant head. Any or all of these techniques may help women and their care providers reach desired outcomes more frequently and deserve to be subjected to rigorous study.

Researchers must also continue to investigate the relationship between self-care practices such as Kegel pelvic floor exercises, general physical fitness, and nutrition, and the risk for pelvic floor defects including incontinence and prolaspes. To the degree that pelvic floor recovery can be facilitated or “rehabilitation” achieved by nonsurgical means, numerous women would benefit from such research. To understand pelvic floor defects and childbirth experiences properly, including history of episiotomy, studies need to be designed to identify populations of women who have a known episiotomy history to evaluate their continence and pelvic organ prolapse status in the age groups between 40 and 70 years.

Understanding the relationship of pelvic floor morbidity to childbirth experiences will require increasingly sophisticated analysis methods and study designs. Evaluation and incorporation of confounders and modifiers of the effect of exposure must become the norm for prospective data analysis. Factors such as maternal race and ethnicity, body mass index, infant birth weight, duration of second-stage labor, duration of strenuous pushing, and elements of reproductive history such as outcomes of prior births require attention. Cohorts of women who participated in perinatal research in the 1980s will soon enter the timeframe in which meaningful followup of pelvic floor status can be obtained.

Future research on sexual function and sexuality after childbirth is needed. Very limited data are available even to describe what women should expect as normal. Research will need to take into account breastfeeding status, episiotomy and laceration history, repair methods, and contraceptive type. Greater attention is needed to distinguish dyspareunia and characteristics that help describe dypareunia (an anatomic symptom), from “satisfaction” with its components of relationship quality, sexual aptitude, and cerebral contribution, and from ability to achieve and consistency of achieving orgasm. Sexual function outcomes need to be regarded as appropriate primary research aims so that these concerns do not remain secondary measures with insufficient attention to reach meaningful answers.

Our review of the literature on the repair of perineal defects points to another avenue for further research. Clinical judgment suggests that the perineal outcome of repair is a function of both materials and methods. Consistencies in the evidence from the studies of repair (e.g., polyglycolic-acid sutures are better than chromic catgut; continuous suturing is better than interrupted suturing) can be used to inform future studies in more creative randomization designs or multivariate analyses. More sophisticated designs might allow a trial to compare complete approaches to repair rather than individual components, such as the studies performed by Doyle et al.^49^ and Isager-Sally et al.^55^

One clinically relevant study might compare combinations of the materials and methods that seem to decrease morbidity (e.g., subcuticular polyglycolic-acid sutures) with new materials such as tissue adhesive that enter the market with (unproven) claims of reduced perineal morbidity. Unless multivariate models are used to tease out mixed-effects of methods and materials or future research begins randomizing groups to entire approaches to repair, results can be informative and applicable to a population only to a certain point. The gap in information may mean that, in the future, women who are receiving appropriate episiotomies may still not receive a thorough repair. Some observers, however, may regard mounting such a trial as questionable. Thus, a useful first step might be to develop sample-size estimates based on a range of important outcomes and, in this way, to determine whether such a trial is even feasible to attempt.

## Conclusion

Our systematic review finds no health benefits from episiotomy. We found fair to good evidence suggesting that the immediate outcomes for routine (liberal-use policies) episiotomy are no better than those for indicated use of episiotomy under more restrictive-use policies. Indeed, routine use is harmful to the extent that it creates a surgical incision of greater extent than many women might have experienced had episiotomy not been performed. Weak trial evidence, consistent with observational data, suggests that the harms of midline episiotomy are greater than the harms of mediolateral episiotomy.

For outcomes of repairing an episiotomy, fair to good evidence, albeit across different comparisons of methods and materials, suggests that leaving the perineal skin unsutured may confer some benefit; if suturing is indicated, then a continuous, subcuticular method is better than an interrupted, transcutaneous method. Regarding suture material, the evidence is consistent and clear that absorbable sutures are preferred and that polyglycolic-acid sutures have significantly less perineal morbidity associated with them. Newer materials, such as tissue adhesive, may offer further benefits, but the data are at present wholly inadequate to inform care practices.

The level of evidence for long-term sequelae, specifically fecal and urinary incontinence, pelvic floor function, and future sexual function is fair to poor. Nonetheless, it is consistent in demonstrating the lack of benefit of the procedure in a comparatively early timeframe. For women in later adult life, when morbidity is most likely to occur in the form of severe and persistent incontinence or pelvic organ prolapse, the expected results of routine episiotomy are unknown.