# Results

This chapter presents results of our literature search and findings for each key question (KQ) introduced in Chapter 1. KQ 1 examines postpartum maternal outcomes related to liberal or restrictive use of episiotomy. KQ 2 compares postpartum outcomes of midline and mediolateral episiotomy. KQ 3 examines outcomes of methods for repair of perineal defects. KQ 4 summarizes longer term outcomes of episiotomy related to fecal and urinary incontinence and pelvic floor integrity and function, and KQ 5 examines longer-term sexual function.

We report results in five main sections of this chapter corresponding to the core issues that this systematic review addressed. In each section, we report first on specific details about the yields of the literature searches, population, outcomes, and quality of the studies, and then on the findings for each key question. Summary tables present selected information on each study. Detailed evidence tables are in Appendix C *.

* Appendixes are provided electronically at http://www.ahrq.gov/clinic/tp/epistp.htm

Overall, our literature search yielded 992 articles (Figure 2). Of these, we excluded 662 articles after reviewing the abstracts and obtained 326 articles for complete review (4 were unavailable for full article review). Of the 326 articles retained for full article review, we included 45 articles in this evidence report, some of which address multiple key questions. Of the 45 articles, seven address KQ 1, one addresses KQ 2, 20 address KQ 3, 15 address KQ 4, and 10 address KQ 5.

## Key Question 1: Episiotomy and Maternal Postpartum Outcomes

### Literature Search and Included Studies

Overview of the Evidence. We identified seven primary publications of randomized controlled trials (RCTs) of liberal versus restrictive use of episiotomy.^22,^ ^23,^ ^28–32^ Evidence Table 1 in Appendix C provides details on each study. Three of these studies were conducted in the United Kingdom;^22,^ ^23,^ ^28^ one at a British military hospital in Saudi Arabia;^31^ one in Germany;^32^ one in Argentina;^30^ and one in Canada.^29^ The first trial was performed in the United Kingdom and published in 1984;^23^ the most recent, in Germany in 2004.^32^ The studies are not evenly distributed over time: three trials were conducted in the early to mid-1980s in the United Kingdom, three in the first half of the 1990s, and a decade passed before the publication by Danneker and colleagues in Germany in 2004. We also identified two secondary reports from randomized clinical trials.^33,^ ^34^ One publication reports on 3-year followup of a trial cohort;^33^ the other is a re-analysis of 3-month followup data grouped by degree of perineal trauma after the birth, rather than by allocated trial group.^34^ Discussion of these publications is included in the results for Key Questions 4 and 5 because they focus on continence and sexual function outcomes.

Each trial that we identified, compared two study arms or groups: (1) one in which the intention was to restrict routine use of episiotomy and (2) one group in which a liberal--use policy endorsed routine use. Defining the distinctions between such groups in a manner that can be uniformly achieved is the central challenge for these trials.

The strictest definition of “restrictive” was to avoid episiotomy unless indicated for fetal well-being.^23,^ ^32^ Other definitions pivoted on instructions to “avoid episiotomy,” use only when “medically necessary,” or not perform episiotomy for the sole purpose of avoiding a laceration.^22,^ ^28,^ ^29,^ ^31^ The largest trial defined restrictive use as only for fetal indications and/or to avoid severe lacerations.^30^

Liberal-use arms were defined in terms such as “routinely conducted,” “routine,” “usual care,” and “elective.”^22,^ ^28–31^ Two studies describeed the liberal-use policy as encouraging routine use of episiotomy when “a tear is imminent”^32^ and “to prevent a tear.”^23^

Regardless of how the randomization groups were defined for study implementation, neither definition may align with the usual practice of individual clinicians, especially with respect to how they would describe the goal they are trying to achieve when performing an episiotomy. Variation in norms and usual practice patterns are demonstrable in the variation of episiotomy use observed in these trials. Use of episiotomy in the restrictive groups ranged from lows of 7.6 percent^22^ and 10.2 percent^23^ to highs of 44 percent^29^ and 53 percent.^31^ We observed up to a seven-fold difference in the use of episiotomy within the restrictive groups across these trials. The routine--use/liberal-use arms had episiotomy use rates from a low of 44.9 percent^22^ to a high of 83 percent.^30,^ ^31^ Wide variation in patterns of use across trials introduces substantial heterogeneity in the “exposures” under study. A large degree of built-in “cross-over” occurred in the setting of higher rates of use in the restrictive groups. In synthesizing these data, we emphasize that these trials compare policies of episiotomy use, not episiotomy versus no episiotomy.

An additional factor that influences generalizability of findings for practice in the United States is that six of the seven studies used mediolateral episiotomy. The only North American study, conducted in Canada, was also the only study in which median (midline) episiotomy was used. Because midline episiotomy is the most common technique used in the United States,^9,^ ^35^ this means that the majority of the literature reflects outcomes that would be expected with a distinctively different episiotomy approach with respect to anatomic location of the defect and potential complications. Key Question 2, focused on incision type, identified only one poor- quality RCT directly comparing median and mediolateral episiotomy.^36^ We review this study- in detail in the next section; briefly, the study -suggests increased risk of rectal injury and complicated or extended incision with midline episiotomy. This finding is comparable to those of observational studies that report that midline incisions are more likely to result in extensions that injure the anal sphincter and/or rectal mucosa.^37,^ ^38^

Study Populations. Six studies restricted participation to term births;^22,^ ^23,^ ^28–31^ the seventh, to births at longer than 34 weeks' gestation.^32^ Five studies specified that they enrolled only singleton gestations. The two studies that did not specify singleton gestations were conducted in the 1980s before routine use of ultrasound; in that period, -providers were unlikely to miss a multiple gestation clinically, -excluding twin gestations before enrollment- in a trial might have been difficult to do with complete confidence.^22,^ ^23^ Two studies required vertex presentations.^28,^ ^31^ Regardless of stated inclusion criteria, multiple gestations and breech presentations do not seem to be represented in these trials. To this extent the studies do represent episiotomy use in uncomplicated vaginal deliveries.

Three studies enrolled only women having their first births.^22,^ ^31,^ ^32^ This approach eliminates any influence of prior perineal trauma and healing on the trial outcomes. The combined study populations of these three studies was 409 participants; this is smaller than the entire cohort of each of the other studies. Four studies enrolled multiparous women. In these studies, the proportion of women who were primiparous ranged from 40 percent to 68 percent, generally with good balance across study groups.^23,^ ^28–30^ The exception occurred in the publication by House and colleagues in which it appears that multiparous women were more likely to have been randomized to the restricted-use group.^28^ Within the studies that achieved balanced allocation by parity, analyses that stratify outcomes by parity help inform how outcomes may differ based on prior childbirth experiences. No trial data were identified that allow consideration of whether outcomes vary by race and ethnicity.

Each study focused on normal spontaneous vaginal births. To reduce the number of women who subsequently had operative vaginal deliveries or cesarean births, the majority of studies allocated women to study groups as close to the anticipated time of birth as feasible. The proportion of assisted vaginal births (both forceps and vacuum) in these trials was 2 percent,^30^ 3 percent,^29^ 4 percent to 5 percent,^31^ 11 percent to 14 percent,^28^ or not specifically reported; . The absence of reporting on instrumental and cesarean births raises the potential of unreported post-randomization exclusions. In two cases, authors noted the number of cesarean births and that those cases are described as part of the trial population and excluded from analyses.^29,^ ^32^ Both of these studies enrolled women during prenatal care, an approach that improved representativeness of the study population and explains the increased numbers of women with cesarean births who were logically excluded later.

Outcomes. The most common primary outcome was perineal status after the birth. All seven studies reported incidence of episiotomy and of third- or fourth-degree lacerations or extensions. Five studies reported prevalence of intact perineum;^22,^ ^23,^ ^29,^ ^31,^ ^32^ one reported prevalence of intact perineum combined with first-degree lacerations.^28^ One trial did not report data about intact perineum or minor lacerations, but the proportion can be inferred because first-degree or intact should be the converse of the data they do report about “any perineal suturing” required.^30^

A single study incorporated masked assessment of perineal trauma; Sleep and colleagues arranged to have a clinician who did not assist the delivery and was masked to the study group asesss perineal status and perform the repair.^23^ Although this design approach does not mask the obvious appearance of an episiotomy compared to a spontaneous tear or intact perineum, it prevents any bias in uniformly recording the extent and location of any perineal trauma. The other studies are at risk of this type of bias.

The most common secondary outcome was pain in the days immediately after the birth. Five of the seven trials assessed pain. Two groups used visual analog scores and classified responses into categories of mild, moderate, or severe.^28,^ ^32^ One study used an unspecified “standardized questionnaire” and also reported pain severity as mild, moderate, or severe. ^23^ Another used the McGill Pain Questionnaire and reported the composite score of the 10-item scale.^29^ The largest study, conducted in Argentina, did not define how they collected data about “perineal pain.”^30^ Additional measures include use of pain medications and reports of pain with specific physical activities.

Three publications did not report masking of the assessors to study group.^22,^ ^31,^ ^32^ The remainder of the studies reported that the individual conducting the pain assessment was unaware of allocation of the participants. Two studies clearly noted that women were not aware of the group to which they were allocated.^23,^ ^28^

Additional outcomes assessed include resumption of sexual activity, estimated blood loss, and wound- healing appearance and complications, including infection, healing by secondary intention, and persistent granulation tissue. Few of these outcomes were measured uniformly in more than one study.

### Results

Perineal Trauma Outcomes. Table 4 summarizes key elements of study design and the perineal outcomes observed in each of the RCTs. The table provides a summary and does not include all outcomes such as anterior tears. Based on quality of the conduct of the trials, the strongest of these studies (rated good quality) was the first RCT conducted; like the majority of these trials, it evaluated the use of mediolateral episiotomy. This first study, conducted in the early 1980s, enrolled 1,000 women, featured an appropriate randomization approach that achieved good balance, and had masked assessment of outcomes with clear definitions.^23^ The investigators did not make any post-randomization exclusions and specifically reported conducting an intention-to-treat analysis. The study methods achieved a wide gradient of episiotomy use between the liberal and restrictive groups—a 41 percentage point difference: 51.4 percent in the liberal-use group and 10.2 percent in the restrictive- use group. Women in the restrictive group were more likely to have an intact perineum; 24.3 percent of those in the liberal group had intact perinea compared to 33.9 percent in the restrictive group. Third- and fourth-degree lacerations were rare (0.2 percent in the trial cohort) and did not differ by group. The effects of liberal versus restricted use with respect to any need for suturing were less marked among multiparous women who had similar outcomes: 69 percent of multiparous women in the liberal group and 66 percent in the restrictive group. required any suturing for repair. Among nulliparous women, the difference in need for suturing was more pronounced (89 percent in the liberal-use group and 74 percent in the restrictive group). Sleep and colleagues concluded that restricting use of episiotomy neither increased nor decreased maternal morbidity.^23^

Table 4. Results of randomized controlled trials of liberal versus restrictive use of episiotomy: Perineal trauma

Citation | Inclusion Parity | Groups | Outcome(s) | Outcome among Liberal-Use Group | Outcome among Restrictive-Use Group | Authors' Conclusions
Country | | Episiotomy Use
Episiotomy Type
Number
Sleep et al., 1984^23^ | Term, singleton pregnancy | G1: Liberal = “try to prevent a tear” | Intact | 24.30% | 33.90% | Restricting use of episiotomy neither increased nor decreased problems experienced by mothers.
United Kingdom | Anticipated NSVD | G2: Restrictive = “try to avoid episiotomy and restrict to fetal indications” | Third or fourth degree | n = 1 | n = 4
Mediolateral | 40%–46% primiparous | G1: 51.4% | Any suturing
N = 1,000 | | G2: 10.2% | | Primip: 89% | Primip: 74%
| | | | Multip: 69% | Multip: 66%
Harrison et al., 1984^22^ | Term, primigravid, anticipated vaginal birth | G1: Mediolateral episiotomy routinely conducted | Intact | Not reported | 21% | Primigravid patients allocated to not undergo episiotomy generally fared better than they would have done with normal hospital practices. Forty-six percent had no or only first-degree tears.
Ireland | | G2: No episiotomy unless “medically necessary” | Third or fourth degree | 6% | None
Mediolateral | | G1: 44.9%
N = 181 | | G2: 7.6%
House et al., 1986^28^ | Term, vertex, anticipated NSVD | G1: Standard current management | Intact or first degree | Primip: 4% | Primip: 32% | Restrictive policy resulted in a significant increase in the incidence of patients with intact perineum or only a first-degree tear.
United Kingdom | 53%–68% primiparous | G2: Episiotomy not performed to prevent laceration | Second degree = | Multip: 26% | Multip: 54%
Mediolateral | | G1: 69% | Episiotomy or second degree | Primip: 96% | Primip: 68%
N = 165 | | G2: 18% | Third degree | Multip: 70% | Multip: 45%
| | | | Primip: 4% | Primip: None
| | | | Multip: 4% | Multip: None
Klein et al., 1992^29^ | Term, singleton; anticipated NSVD | G1: Liberal = avoid tear | Intact (no suturing) | Primip: 6.6% | Primip: 7.5% | No evidence that liberal use prevents perineal trauma; restriction of episiotomy use among multiparous women results in significantly more intact perineums and less suturing.
Canada | 50%–52% primiparous | G2: Restrictive = attempt to avoid episiotomy | Episiotomy alone | Multip: 19.3% | Multip: 30.7%
Midline | | G1: | Third or fourth degree | Primip: 67.2% | Primip: 42.2%
N = 730 | | Primip: 81% | | Multip: 45.2% | Multip: 29.0%
| | Multip: 52% | | Primip: 7.9% | Primip: 13.9%
| | G2: | | Multip: 0% | Multip: 0%
| | Primip: 47%
| | Multip: 31%
Argentine Episiotomy Trial Collaborative Group, 1993^30^ | Term, singleton first or second vaginal birth; no prior cesarean or severe perineal trauma | G1: Routine | Perineal suturing | 88.1% | 63.1% | No evidence that routine use of episiotomy reduces risk of severe perineal trauma.
Argentina | 40%–41% primiparous | G2: Selective | Third or fourth degree | Primip: 1.8% | Primip: 1.4%
Mediolateral | | G1: 82.6% | | Multip: 0.9% | Multip: 0.8%
N = 2,606 | | G2: 30.1%
Eltorkey and Nuaim, 1994^31^ | Term, singleton, vertex, primiparous; anticipated NSVD | G1: Elective | Intact | 7% | 28% | Selective group more likely to have an intact perineum. No indication that episiotomy offers clear benefit in terms of decreased numbers of lacerations.
Saudi Arabia | | G2: Selective = essential | Second degree or episiotomy without extension | 71%* | 49%*
(British staff) | | G1: 83%* | Third degree or episiotomy with extension | None | None
Mediolateral | | G2: 53%*
N = 200
Dannecker et al., 2004^32^ | >34 weeks, singleton, primiparous; anticipated NSVD | G1: Liberal = if tear imminent and/or fetal indications | Intact | 10% | 29% | Restrictive use resulted in three-fold increase in the rates of intact perinea. No difference with regard to third-degree tears.
Germany | | G2: Restrictive = fetal indications only | Third degree | 8% | 4%
Mediolateral | | G1: 77%
N = 109 | | G2: 41%

G, group; primip, primiparous; multip, multiparous; NSVD, normal spontaneous vaginal delivery.

* Text and tables in this publication are not concordant; overall incidence from text; second degree and episiotomy totals from table.

The largest trial conducted was a multisite study in Argentina that enrolled 2,606 women and was of fair quality (see evidence tables in Appendix C for details).^30^ This study found a 2.4-fold increase in risk of anterior tears among women in the restrictive- use arm (95% confidence interval [CI], 1.9–2.9), and decreased risk of posterior perineal surgical repair (relative risk [RR] = 0.72; 95% CI, 0.68–0.75) when comparing restrictive to liberal use. Eighty-eight percent of women in the liberal group had a surgical repair, as did 63 percent in the restrictive group. Pain, healing complications, and dehiscence were all less frequent in the restrictive-use group. The authors concluded that episiotomy confers no apparent benefit and that high rates of use cannot be justified.

These two studies, which are also the two largest trials, yield results compatible with the findings of the other trials with respect to perineal outcomes (see Table 4 for summary). Intact perineum was uniformly more common in the restrictive groups.^28,^ ^29,^ ^31,^ ^32^ With two exceptions,^29,^ ^32^ studies reported more third- and fourth-degree lacerations among women in the liberal-use group. However, each of these studies was underpowered to distinguish differences in risk across the groups because third- and fourth-degree lacerations were rare. In fact, one study of 200 women had no severe lacerations among participants in either arm.^31^ Anterior lacerations, including anterior labial lacerations, were reported to be more common in three studies^23,^ ^30,^ ^32^ and equivalent in one study.^32^ Anterior lacerations did not contribute to overall higher use of suturing, suggesting that these tears were less severe than posterior tears.

The findings of these studies are fully compatible. None of the authors concluded that episiotomy provides any benefits with respect to perineal trauma. The majority concluded that intact or minimal perineal trauma is more common when episiotomy use is restricted. This synthesis of the data is compatible with the findings of prior systematic evidence reviews that are updated with this report. Although the authors of these research publication appear loath to ascribe harm to the use of episiotomy, in our judgement-concluding from their data that routine use is harmful is accurate, at least to the extent that it creates a surgical incision of greater extent than a woman might have experienced had the episiotomy not been performed.

Pain Outcomes. Five studies assessed pain outcomes (Table 5).^23,^ ^28–30,^ ^32^ The two largest trials collected pain outcome data.^23,^ ^30^ Sleep and colleagues used midwives masked to study group to assess pain at 10 days postpartum. Participants were asked to assess pain severity in the prior 24 hours. Pain severity groupings were virtually identical by study group. Among those in the liberal-use group, 14.6 percent had mild pain; 7.8 percent, moderate; and 0.2 percent, severe; the comparable proportions for the restricted-use group were 14.1 percent, 7.5 percent, and 0.9 percent, respectively. Use of oral analgesics by postpartum day 10 was rare in both groups—2 percent and 3 percent, respectively—and not different by group. The Argentine study did not adequately define how they measured pain; pain is reported as “pain on the day of discharge”; the liberal-use group is reported as 42.5 percent with pain, and the restricted-use group as 30.7 percent with pain.

Table 5. Results of randomized controlled trials of liberal versus restrictive use of episiotomy: Pain outcomes

Citation | Inclusion Parity | Groups | Outcome(s) | Outcome among Liberal-Use Group | Outcome among Restrictive-Use Group | Authors' Conclusions
Country | | Episiotomy Use | How Measured?
Episiotomy Type | | | When?
Number
Sleep, 1984^23^ | Term, singleton pregnancy, anticipated NSVD* | G1: Liberal = “try to prevent a tear” | Pain severity in prior 24 hours; questionnaire administered by midwife; 10 days postpartum | 10 days | 10 days | No significant differences between the two groups in maternal pain at 10 days and 3 months postpartum.
United Kingdom | 40%–46% primiparous | G2: Restrictive = “try to avoid episiotomy and restrict to fetal indications” | Worst pain in past week; postal questionnaire; 3 months postpartum | Mild: 14.6% | Mild: 14.1%
Mediolateral | | G1: 51.4% | | Mod: 7.8% | Mod: 7.5%
N =1000 | | G2: 10.2% | | Severe: 0.2% | Severe: 0.9%
| | | | 3 months | 3 months
| | | | Mild: 5.7% | Mild: 4.6%
| | | | Mod: 1.8% | Mod: 2.5%
| | | | Severe: 0.2% | Severe: 0.5%
House et al., 1986^28^ | Term, vertex, anticipated NSVD* | G1: Standard current management | Pain severity; interview by one of authors using VAS scale 1 to 10 with 1–3 grouped as minimal; 4–6 moderate; 7–10 severe; | 3 days | 3 days | Pain symptoms on the third day postpartum were on average reduced in the patients in whom the use of episiotomy was restricted and equivalent thereafter.
United Kingdom | 53%–68% primiparous. | G2: Episiotomy not performed to prevent laceration | 3 days; 6 weeks; 3 months | Mild: 55% | Mild: 68%
Mediolateral | | G1: 69% | | Mod: 34% | Mod: 22%
N = 165 | | G2: 18% | | Severe: 11% | Severe: 10%
| | | | No differences at 6 weeks and 3 months | No women in either group with more than minimal pain at 3 months
Klein et al., 1992^29^ | Term, singleton; anticipated NSVD | G1: Liberal = avoid tear | Perineal pain measured by 10 individually scored items using the McGill Pain Questionnaire at 1, 2, and 10 days postpartum | First day | First day | No significant differences in perineal pain and pain with urination at 1, 2, and 10 days postpartum for individual pain scale items or composite score
Canada | 50%–52% primiparous | G2: Restrictive = attempt to avoid episiotomy | | Primip: 1.8± 0.8 | Primip: 1.7± 0.8
Midline | | G1: | | Multip:1.3± 0.8 | Multip:1.3± 0.9
N = 730 | | Primip: 81% | | Second day | Second day
| | Multip: 52% | | Primip: 1.3± 0.7 | Primip: 1.4±0.8
| | G2: | | Multip:0.9± 0.7 | Multip: 0.9± 0.8
| | Primip: 47% | | Tenth day | Tenth day
| | Multip: 31% | | Primip:0.5±0.5 | Primip: 0.5± 0.5
| | | | Multip: 0.3±0.4 | Multip: 0.3± 0.5
Argentine Episiotomy Trial Collaborative Group, 1993^30^ | Term, singleton first or second vaginal birth; no prior cesarean or severe perineal trauma | G1: Routine = do according to hospital's policy before trial | Perineal pain (not clearly defined), assessment method not clearly delineated, physician masked to allocation evaluated on day of discharge | 42.5% | 30.7% | Perineal pain was less common in the restrictive use group.
Argentina | 40%–41% primiparous | G2: Selective = try to avoid, do only for fetal indications or if severe tear is imminent
Mediolateral | | G1: 82.6%
N = 2,606 | | G2: 30.1%
Dannecker et al., 2004^32^ | >34 weeks, singleton, primiparous; anticipated NSVD | G1: Liberal = if tear imminent and/or fetal indications | Perineal pain in postpartum period (days 1 to 5) on 100 mm visual analog scale anchored at “not at all” and “very much” for a range of activities; approach to measurement not clearly specified | Bedrest: 39± 28 | Bedrest: 22±21 | Women in the restrictive group had considerably lower perineal pain scores in all activities assessed during the first 5 days postpartum.
Germany | | G2: Restrictive = fetal indications only | | Sitting: 69±23 | Sitting: 51±25
Mediolateral | | G1: 77% | | Walking: 56±24 | Walking: 37±24
N = 109 | | G2: 41% | | Defecation: 36±30 | Defecation: 21±21

G, group; primip, primiparous; mod, moderate; multip, multiparous; NSVD, normal spontaneous vaginal delivery

The most recent study, although small, provided the most nuanced approach to pain assessment. The investigators used a visual analog scale to assess pain with four activities: bedrest, sitting, walking, and defecation. Scores were reported in millimeters of the 100 mm-pain scale for each activity. Those in the liberal-use group had the following mean scores (± standard deviation): 39 ± 28 mm with bedrest; 69 ± 23 mm with sitting; 56 ± 24 mm with walking; and 36 ± 30 mm with defecation. The comparable scores in the restrictive group were 22 ± 21 mm; 51 ± 25 mm; 37 ± 24 mm; and 21 ± 21 mm. These differences indicate that the restrictive-use group experienced significantly lower perineal pain during all activities, at levels that are likely clinically significant. These findings could indicate a real difference in pain outcomes or some bias in assessment. The publication does not report masking of the assessors or how the assessments were conducted.

House and colleagues report that pain was more severe on postpartum day 3 among those in the liberal-use group. They also assessed pain outcomes by visual analog scale during an interview conducted by an author; masking of the assessors is not specifically noted. On day 3 in the liberal-use group, 55 percent of women had mild pain' 34 percent, moderate pain; and 11 percent, severe; the comparable categories for those in the restrictive-use group were 68 percent, 22 percent, and 10 percent. They also report tenderness at the time of examination on postpartum day 3. The restricted use group had less tenderness on examination: 79 percent had mild or minimal pain; 18 percent, moderate; 3 percent, severe; compared to 51 percent, 39 percent, and 10 percent in the liberal-use group. . These differences were statistically significant and likely to be clinically relevant.^28^ These differences in pain by group had resolved by 6 weeks and 3 months respectively.

Klein and colleagues, who conducted the only North American trial and the only trial using midline episiotomy, found no difference in McGill pain scores on days 1, 2, and 10 after the birth for either perineal pain or pain with urination.^29^ They reported that they conducted analyses both with individual pain-scale items and composite scores. Across each of the five studies, no study found a pain measure that was improved by routine liberal use of episiotomy.

Healing Outcomes. Two studies assessed healing outcomes by physical examination. The Argentine trial reported no difference in rates of the following adverse outcomes that were adequately defined: hematoma prior to discharge; - and infection, healing complications, and dehiscence as assessed on day 7 postpartum. At discharge, they assessed 92 percent and 93 percent of participants in the restricted use and liberal-use groups respectively; this dropped to 43 percent of both groups by the evaluation on day 7 postpartum. ^30^ House and colleagues examined participants on day 3 postpartum and at 6 weeks. Risk of infection was assessed for all participants on day 3; poor wound apposition and granulation tissue indicating secondary healing were assessed at the later visit at which 53 percent of the trial participants were assessed. Each adverse outcome was equivalent across groups.^28^

Other Outcomes. Two trials, both reflecting use of mediolateral episiotomy, reported on timing of resumption of intercourse. One study documented that women in the restricted episiotomy-use group resumed intercourse an average of a week earlier (5.5 ± 3.0 weeks compared to 6.5 ± 3.0 weeks).^28^ The other study found that 37 percent of the women in the liberal-use group (P < 0.01) .^23^ Longer-term influences on sexual function - those assessed at 3 months or later - are reviewed in the section on KQ 5.

Two studies, also of mediolateral episiotomy use, assessed estimated maternal blood loss. One found no difference in the amount that maternal hemoglobin measures fell.^32^ The other found that estimated blood loss (method not defined) was 58 cc greater in the liberal-use group, a statistically significant but likely not clinically relevant mean difference.^23^

## Key Question 2: Episiotomy Incision Type and Maternal Morbidity

### Literature Search and Included Studies

We found only one RCT comparing outcomes of midline episiotomy to those of mediolateral episiotomy.^36^ Evidence Table 2 in Appendix C provides details. An additional focused literature search did not reveal any prospective cohort studies pertaining to this key question.

Study Participants. The study included primigravidas who were admitted to the delivery unit of a university hospital in London. The mean age at delivery was 26 years; the mean gestational age was 40 weeks.

Episiotomy Type. Midline episiotomy—“incisions divided 2 to 3 cm of the perineal tissue in the midline.” Mediolateral incisions “were made from the midline and were carried to the right of the anal sphincter for about 3 to 4 cm.”^36^ Method of repair was identical for both study groups. Standard repair technique for both types of incisions included subcuticular skin closure with polygycolic acid suture.

Outcomes. Outcome measures included the proportion of extended or complicated incisions, recommencement of sexual intercourse, pain, pain during intercourse, satisfaction from intercourse, and the cosmetic appearance of the scar. Investigators did not report methods of outcomes assessment or the use of objective scales for pain and sexual satisfaction. An exam was conducted and pain was queried before hospital discharge and again at a 3-month followup visit that included the sexual function data collection. The study did not assess differences in fecal incontinence.

Quality. This study had serious methodological flaws; we gave it a poor rating for internal validity. In particular, we viewed an inadequate randomization method, lack of allocation concealment, and failure to blind the outcome assessors as potential sources of severe biases and as a rationale for a poor-quality rating. Consequently, the evidence is insufficient to draw any firm conclusions on differences in adverse outcomes of midline compared to mediolateral episiotomy.

### Results

The trial included 407 primigravidas who were randomly assigned to midline or mediolateral episiotomy. Results revealed a significantly higher rate of complicated or extended incisions for the midline group than for the mediolateral group (P < 0.001). A total of 23.9 percent of women in the midline group experienced an extension of the episiotomy into or through the sphincter, compared to 9 percent of women in the mediolateral group. The midline group had significantly less bruising of the perineum than the mediolateral group (P < 0.001). The investigators did not note any differences in pain in the postpartum timeframe. Of all enrolled women, 76 percent attended a 3-month followup. Women in the midline group began sexual intercourse significantly earlier (P < 0.01) and had a significantly better cosmetic appearance of the scar (P < 0.02) than women in the mediolateral group. No significant differences in pain or satisfaction from sexual intercourse were detected.

On the question of midline versus mediolateral episiotomy, the only study in our review that met our inclusion criteria found that women receiving midline episiotomy had a significantly greater probability of anal sphincter injuries than women in the mediolateral episiotomy group.^36^ This study did not assess fecal incontinence as a long-term health outcome. Because of considerable methodologic flaws, any conclusions must be made cautiously.

Differences in sphincter injury rates are clinically important. As an RCT, this study's internal validity is poor. Nevertheless, considering that this is the only trial pertaining to this key question, the findings regarding sphincter injuries could be viewed as relevant observational evidence. Multiple retrospective cohort studies that did not meet eligibility criteria for this key question support findings regarding high sphincter injury rates and midline episiotomy.^39–45^ These studies provide consistent evidence that midline episiotomy leads to significantly higher rates of third- and fourth-degree tears than mediolateral episiotomy. In another study, women with midline episiotomy had a significantly higher rate of fecal incontinence than did women with spontaneous second-degree tears.^46^

## Key Question 3: Repair of Perineal Defect and Maternal Morbidity

### Literature Search and Included Studies

Overview. We included 17 randomized controlled trials (RCTs) examining various methods and materials for repairing perineal defects.^47,^ ^48,^ ^48–66^ As shown in the three main sections of Table 6, four trials investigated techniques of repair;^48,^ ^58,^ ^60,^ ^63,^ ^66^ 14 trials investigated materials for repair;^50,^ ^47,^ ^48,^ ^51–54,^ ^56–59,^ ^61–65^and two trials combined comparison of both techniques and materials in their design.^49,^ ^55^ Details on all 17 studies are provided in Evidence Tables 3–10 in Appendix C.

Table 6. Description of trials of episiotomy repair relating to methods, materials, or both

Trial | Trial Groups | Setting | Trial Size | Percentage Primiparous | Percentage Instrumental Delivery | Overall Quality Rating
Type of Repair
Oboro et al., 2003^66^ | 2 layer vs. 3 layer | Nigeria | N =1,077 | 53% | 23% | Fair
Ipswich Childbirth Study, Gordon et al., 1998,^60^ Grant et al., 2001^63^ | 2 layer vs. 3 layer | United Kingdom | N =1,780* | 61% | 17% | Good
Kettle, 2002^67^ | Continuous vs. interrupted | United Kingdom | N =1,542 | 56% | 0% | Good
Mahomed et al., 1989^58^ | Continuous vs. interrupted | United Kingdom | N =1,574† | 51% | 23% | Good
Materials for Repair
Bowen and Selinger, 2002^64^ | Absorbable vs. adhesive | United Kingdom | N = 62 | 100% | NR | Poor
Adoni and Anteby, 1991^47^ | Absorbable vs. adhesive | Israel | N = 60 | NR | NR | Poor
Kettle, 2002^67^ | Absorbable vs. rapidly absorbable | United Kingdom | N = 1,542 | 56% | 0% | Good
McElhinney et al., 2000^62^ | Absorbable vs. rapidly absorbable | Ireland | N = 153 | 55% | NR | Poor
Spencer et al., 1986,^56^ Grant et al., 1989^57^ | Untreated vs. treated CC | United Kingdom | N = 737 | 47% | 0% | Fair
Buchan and Nicholls, 1980^54^ | Nonabsorbable vs. absorbable | United Kingdom | N = 140 | 100% | 0% | Fair
Mahomed et al., 1989^58^ | a. Absorbable vs. absorbable vs. nonabsorbable b. PGA vs. CC | United Kingdom | N = 1,574 | 52% | 23% | Good
Upton et al., 2002^65^ | PGA vs. CC | Australia | N = 391 | 47% | 0% | Fair
Ipswich Childbirth Study, Mackrodt et al., 1998,^61^ Grant et al., 2001^63^ | PGA vs. CC | United Kingdom | N = 1,780* | 61% | 17% | Good
Olah, 1990^59^ | PGA vs. CC | United Kingdom | N = 120 | 46% | 100% | Fair
Ping and Kee, 1975^53^ | PGA vs. CC | Malaysia | N = 122 | 61% | 38% | Fair
Rogers, 1974^52^ | PGA vs. CC | United States | N = 600 | NR | NR | Poor
Livingstone et al., 1974^51^ | PGA vs. CC | Scotland | N = 100 | 100% | 62% | Poor
Beard et al., 1974^50^ | PGA vs. CC | United Kingdom | N = 200 | 51% | NR | Fair
Repair Techniques and Materials
Doyle et al., 1993^49^ | Absorbable sutures (plain catgut, PGA) and combination of methods | United Kingdom | N = 199 | 72% | NR | Poor
Isager-Sally et al., 1986^55^ | Combination of absorbable and nonabsorbable sutures and combination of methods | Denmark | N = 900‡ | 61% | NR | Fair

Note: CC, chromic catgut; NR, not reported; PGA, polyglycolic acid.

* The Ipswich Childbirth Study^61,^ ^63^ reported a 1-year followup of results^63^ that included a subset (n= 793) of the original trial's population. Percentages shown reflect baseline population.

† The trial used a 2×3×2 factorial design to investigate both methods and materials for repair. The methods for the repair arm of the trial investigated continuous and interrupted methods for absorbable sutures, a subset (N= 1,057) of the entire population (N = 1,574). Percentages of primiparous and instrumental deliveries were calculated with a denominator of 1,057.

‡ 900 women were randomized but 98 were excluded because they transferred to another hospital or left the hospital before the fifth day after delivery. Three groups did not differ in age, parity, or frequency of previous episiotomy.

Of the four trials investigating techniques of repair, two compared a two-layer approach (leaving the perineal skin unsutured) with a three-layer approach (suturing the perineal skin) and two trials compared a continuous (subcutaneous) technique with an interrupted (transcutaneous) technique.

Of the 14 trials investigating repair materials, eight compared polyglycolic-acid sutures with chromic-catgut sutures, both absorbable. Two trials compared absorbable sutures (one polyglycolic acid and one chromic catgut) with an enbucrilate tissue adhesive (Histoacryl^®^). Two trials compared standard absorbable suture material with its rapidly absorbed counterpart, and one trial compared untreated chromic-catgut with a glycerol-treated “softgut” chromic catgut. In addition, two trials compared nonabsorbable and absorbable sutures: one compared silk sutures with polyglycolic-acid sutures and one compared silk sutures with both polyglycolic-acid and chromic-catgut sutures.

Most of these trials randomly allocated participants to one of two groups. Three trials, however, incorporated a factorial design of randomization. Using a 2×2 design, both the Ipswich Childbirth Study^60,^ ^61,^ ^63^ and the Kettle et al. trial^67^ randomized to methods of repair and type of sutures. The Mahomed et al. perineal suture study used a 2×3×2 design and randomized to suture type for deep tissue repair (two groups), suture type for the perineal skin (three groups), and method of repair (two groups).^58^ These studies contributed to more than one section of the results below.

Country. Approximately 65 percent of the RCTs in this report were conducted in the United Kingdom, including Ireland and Scotland. Australia, Denmark, Israel, Malaysia, Nigeria, and the United States each contributed one trial to this report.

Episiotomy Type. These trials included women who had an episiotomy at the time of vaginal childbirth, regardless of the number of previous pregnancies or births. The vast majority of episiotomies repaired in these studies were mediolateral. This reflects the fact that most of the studies were conducted in European countries, the majority contributed by the United Kingdom. Practitioners in North America generally perform midline episiotomy, whereas mediolateral is the rule elsewhere.

Because this question addresses outcomes of repair, we reviewed trials that included women who had forcep- or vacuum-assisted births with an episiotomy. The rationale for inclusion is that the technique of repair and materials can be evaluated with respect to postpartum perineal healing and maternal morbidity, regardless of the mechanisms that led to the perineal trauma. Of these 17 trials, seven explicitly excluded women who had instrumental deliveries; four did not report whether instrumental deliveries were included; one trial included instrumental deliveries but did not report the proportion of women who had them; and five trials reported proportions of participants who had instrumental deliveries (see Table 6). The proportion of participants who had instrumental deliveries ranged from17 percent to 64 percent.

Outcomes. Perineal pain and need for analgesia were assessed during the short-term postpartum period in a majority of the trials and during the long-term postpartum period for some of the trials. Investigators used self-report through interviews administered by midwives or study staff and questionnaires to measure subjective levels of pain and use of analgesia. Trials also reported on specific aspects of healing and wound breakdown including inflammation, bruising, infection, wound gaping, need for removal of sutures, and need for resuturing. In each case, a clinician involved in the trial assessed these outcomes, often without masking to study allocation. Longer-term outcomes related to sexual function, such as dyspareunia, recommencement of sexual intercourse, and timing of resumption of intercourse, were typically measured at 3 months postpartum and up to 3 years by interview or questionnaire. Incontinence and other pelvic-floor-related outcomes were investigated by one trial.^55^ Few trials collected data on comfort with daily activities or satisfaction with repair.

Quality. Of the 17 trials, we rated three as good quality, eight as fair quality, and six as poor quality; for the last group, four trials were rated poor because of inadequate randomization techniques and were most likely not truly randomized. We rated trials as fair or poor quality on the basis of inadequate randomization approach and implementation, failure to mask the outcome assessors, and high loss to followup. Specific limitations of the trials are discussed elsewhere in this report.

### Results for Methods of Repair

Two-layer vs. Three-layer Repair. One trial of good quality^60,^ ^63^ and one trial of fair quality^66^ compared a two-layer suturing approach with a three-layer suturing approach (Evidence Table 3, Appendix C). Both trials described the standard technique as three-layered, suturing the perineal skin closed after repair of the vagina and deeper tissues with interrupted transcutaneous or continuous subcuticular sutures. The two-layer approach leaves the perineal skin unsutured, a technique that is hypothesized to decrease perineal morbidity.

Pain and analgesia use. Consistent evidence from these two trials suggests that the two-layer suturing technique decreases perineal pain in both the short- and long-term postpartum periods and requires less analgesia use. When the evidence is limited to the trial of good quality, however, these differences were not statistically significant.

Although both trials reported less perineal pain in the two-layer groups, only one trial^66^ found significant differences in the short-term postpartum period (0 to 3 months) and the long-term postpartum period (≥ 3 months). At 48 hours postpartum, fewer participants in the two-layer approach reported perineal pain than those in the three-layer approach (RR = 0.87; 95% CI, 0.78–0.97). Over time, the differences persisted: two-layer was superior at 14 days (RR = 0.77; 95% CI, 0.61–0.98), at 6 weeks (RR = 0.64; 95% CI, 0.44–0.93), and at 3 months postpartum (RR = 0.19; 95% CI, 0.06–0.54). The Ipswich Childbirth Study^60,^ ^63^ did not note differences between the two groups in self-report of any, mild, moderate, or severe perineal pain at 24 to 48 hours, 10 days, 3 months, or 1 year. At each followup period, however, fewer women in the two-layer group reported perineal pain.

Similar findings extended to analgesia use in the two groups but only in the short-term postpartum period. Participants in the two-layer group of the Oboro et al. trial reported significantly less use of analgesics at 48 hours (RR = 0.71; 95% CI, 0.60–0.83) and at 14 days (RR = 0.54; 95% CI, 0.32–0.90) but not at 6 weeks (RR = 0.56; 95% CI, 0.16–0.1.89) or at 3 months postpartum (RR = 0.16; 95% CI, 0.02–1.34). The Ipswich trial found no differences in analgesia use at followup.^60,^ ^63^

Healing and wound breakdown. Despite inconsistent definition and measurement of healing outcomes, the evidence suggesting that the two-layer approach decreases healing complications and that wound gaping associated with leaving the perineal skin unsutured resolves shortly after repair.

Significantly fewer participants in the two-layer group needed sutures removed for pain or infection in both trials at any time. Healing outcomes were assessed at 14 days, 6 weeks, and 3 months in one trial^66^ and were generally significant ; these outcomes were also significant at 1 year in the other trial (RR = 0.61, 95% CI, 0.45–0.83, P = 0.002).^60,^ ^63^

Oboro et al. found that fewer women in the two-layer group reported “tight stitches” than in the three-layer group.^66^ Neither trial found a difference in the need for resuturing.

In the Ipswich trials, more women in the two-layer group than the three-layer group had wound gaping, defined in one of the trials as having edges greater than 0.5 cm apart, in the 24- to 48-hour postpartum period.^60^ Observing such a separation may be an artifact of the technique used to examine the incision, because only incisions without suture approximation of the skin can appear to “gape” when tension is applied to the posterior perineum to allow visual inspection. Only one trial looked at outcomes at 1 year postpartum; the authors reported that fewer women in the two-layer group reported that the area that had been cut or torn felt different (RR = 0.75; 95% CI, 0.61–0.91; P < 0.01).^63^

Incontinence and pelvic floor function. Neither trial investigated outcomes related to incontinence and pelvic floor function in terms of the difference in suturing methods.

Sexual function. These two trials did not investigate the same sexual functioning outcomes. The trend in healing outcomes suggests that the two-layer approach to suturing is associated with less morbidity.

Women in the two-layer repair group were significantly less likely in the Oboro et al. trial to have superficial dyspareunia than women in the three-layer repair group at both 6 weeks and 3 months (RR = 0.60; 95% CI, 0.42–0.85 and RR = 0.52; 95% CI, 0.33–0.81, respectively).^66^ These results did not extend to deep dyspareunia, which was comparable between the two groups. At 6 weeks, more women in the two-layer group had resumed pain-free intercourse (26 percent vs. 10 percent, RR = 2.54; 95% CI, 1.82–3.55);^66^ in the Ipswich trial,^60,^ ^63^ this difference was noted but not statistically significant.

Continuous vs. Interrupted Sutures. Two trials, both of good quality, investigated perineal outcomes in women whose repairs were made with a continuous, subcutaneous suturing method compared to an interrupted, transcutaneous method^48,^ ^58^ (Evidence Table 4, Appendix C).

Pain and analgesia use. The evidence is inconsistent as to whether the continuous subcutaneous method of suturing decreases perineal pain and need for oral analgesia following repair. In the Mahomed et al. trial,^58^ the groups did not differ across the categories of any, mild, moderate, or severe perineal pain at day 2, day 10, and 3 months postpartum. By contrast, the trial by Kettle and colleagues documented significant differences.^48^ In this latter trial, at the same time points, women in the continuous-suture group reported less pain than women in the interrupted-suture group. On day 2, 69 percent of the continuous group and 79 percent of the interrupted group reported pain (P < 0.0001). The difference in pain outcomes continued at day 10 (26.5 percent vs. 44 percent; P < 0.0001), 3 months (9 percent vs. 13 percent; P = 0.03) and 1 year (4 percent vs. 7 percent; P = 0.05). At day 10, significant differences were also seen in perineal pain reported during walking, sitting, urination, and defecation; the difference in favor of less pain among those with subcutaneous repair ranged from 7 percent to 16 percent.

The former study also did not find significant differences between the two groups in their need for oral analgesia at day 2 (52% vs. 48%) or day 10 (7% vs. 9%). By contrast, the latter trial found that women in the continuous group needed less analgesia at 10 days postpartum (8.5% vs. 13.5%; P = 0.002).

Healing and wound breakdown. Evidence was inconsistent with respect to healing and wound breakdown. The Mahomed et al. trial found no significant differences in edema, bruising, or inflammation between the groups on day 2. The trial by Kettle and colleagues reported less morbidity in the continuous suture group on day 2 for uncomfortable stitches (OR = 0.78; 95% CI, 0.64–0.96) and tight stitches (OR = 0.40; 95% CI, 0.22–0.74), but they did not find a difference in wound gaping. They reported significant differences on day 10 for wound gaping (OR = 0.46; 95% CI, 0.29–0.74), uncomfortable stitches (OR = 0.58; 95% CI, 0.46–0.74), and tight stitches (OR = 0.43; 95% CI, 0.27–0.69). The need to remove sutures was significantly lower in the continuous method group on day 10 (OR = 0.17; 95% CI, 0.10–0.28). The Mahomed trial measured this variable only at 3 months; they reported a significant difference in favor of continuous subcutaneous closure (26% vs. 37%; P < 0.001).

Incontinence and pelvic floor function. Neither trial investigated the difference in suturing methods regarding outcomes related to incontinence and pelvic floor function.

Sexual function. Neither trial found significant differences between the groups regarding dyspareunia at 3 months postpartum. The trial that measured dyspareunia at 1 year also found equivalent outcomes across the groups.

Other outcomes. Kettle et al. collected information from the women about their overall satisfaction with the repair.^48^ Significantly more women in the continuous method group reported being satisfied with the repair at both 3 months and 12 months postpartum (OR = 1.64; 95% CI, 1.28–2.11 and OR = 1.68; 95% CI, 1.27–2.21, respectively).

### Results for Materials for Repair

Absorbable Suture vs. Tissue Adhesive. Two trials examined use of tissue adhesive in the repair of episiotomy as compared to polyglycolic-acid^64^or chromic-catgut sutures^47^ (Evidence Table 5, Appendix C) Both trials were poor quality because randomization methods were either broken^64^ or inadequate (odd and even registration numbers).^47^ As such, conclusions about perineal morbidity related to the use of tissue adhesive are speculative at best.

Perineal pain and analgesia use. Both trials report less pain during several activities and at rest in women whose episiotomies were repaired with tissue adhesive. Bowen and colleagues^64^ used a 10-point visual analog scale (VAS) and Adoni and colleagues^47^ used a Likert pain scale of 1 (minimum) to 5 (maximum). Because of the differences in the pain scales, the results are not directly comparable, but the overall differences do contribute to the consistent evidence in these two trials that adhesive may lead to less perineal pain in the immediate postpartum. Both trials reported less pain while walking (1.6 vs. 2.6, P < 0.001^47^ and 2.7 vs. 4.0, P = 0.0015)^64^ on day 2. One trial^47^ reported significantly less pain on day 3 (2.0 vs. 2.9, P = 0.029). Both trials reported less pain during micturition: in the Adoni and Anteby trial^47^ on days 1 and 3 (4.5 vs. 6.3, P = 0.025 and 3.0 vs. 4.0, P = 0.025, respectively) and, in the Bowen and Selinger trial,^64^ on day 2 (1.0 vs. 1.7, P < 0.031). Bowen and Selinger^64^ reported less pain in the adhesive group on day 2 (1.95 vs. 3.3, P < 0.001), both while sitting (1.75 vs. 3.6, P < 0.0001) and while lying down (1.0 vs. 2.35, P < 0.001). Adoni and colleagues reported less pain in the adhesive group during defecation on days 3 and 4 (2.2 vs. 4.3, P = 0.003 and 2.1 vs. 3.7, P = 0.015, respectively). Nonsignificant differences were reported on other days. Neither trial compared need for analgesia between the two repair groups.

Healing and wound breakdown. Neither trial investigated differences in these outcomes by type of repair materials. One trial^64^ did report that they identified no cases of wound infection or dehiscence.

Sexual function. Only one trial reported on sexual functioning postpartum.^64^ The group repaired with adhesive, in this case Enbucrilate^®^ tissue adhesive, had a 35 percent reduction in the onset of pain-free sexual intercourse (P = 0.0009). Neither trial reported any other outcomes related to sexual functioning.

Absorbable Sutures: Standard vs. Rapidly Absorbed. Two studies compared standard absorbable to rapidly absorbed sutures (Evidence Table 6, Appendix C). McElhinney and colleagues, in a poor-quality trial,^62^ compared standard absorbable sutures with rapidly absorbable suture material (Vicryl® polyglycolic acid). Kettle and colleagues, in a trial of good quality,^48^ also addressed the continuous versus interrupted methods of suturing in its 2×2 factorial design while comparing standard polyglactin 910 with its rapidly absorbed counterpart.

Perineal pain and analgesia use. The poor-quality trial, although it used good measurements of pain (VAS and Likert scale), found no significant differences in perineal pain between the two groups at 24 hours and 3 days. Analgesic use before discharge also did not differ by group. The good-quality Kettle trial reported mixed results for perineal pain during specific activities and the need for analgesia at 10 days postpartum. Women in the rapidly absorbed suture groups reported less pain while walking, sitting, passing urine, and defecating. Only the differences in pain with walking were statistically significant (OR = 0.74; 95% CI, 0.56–0.97; P = 0.004). Women in the rapidly absorbed group also reported less need for analgesia (8% versus 14%, P = 0.0002). This trial randomized women to suture method (continuous versus interrupted), so the investigator was able to complete stratified analyses; they showed nonsignificant results by both method of suturing and degree of trauma. In other words, improvement in pain was independent of method of closure or size of defect.

Healing and wound breakdown. The poor-quality trial combined all healing outcomes, such as infection, gaping wound, or residual material requiring removal, into one group and found that at 6 weeks, 30 percent of women whose episiotomies were repaired with standard material and 1.7 percent of women whose episiotomies were repaired with the rapidly absorbed material reported problems. The good-quality trial examined different healing outcomes separately and did not find significant differences between the two groups with respect to wound gaping, uncomfortable sutures, or tight stitches at 2 or 10 days postpartum. However, groups had meaningful differences in need for removal of sutures between 10 days and 3 months. Women whose episiotomies were repaired with the rapidly absorbed material required removal less often than women who received the standard suture at 10 days, between 10 days and 3 months, and at any point before 3 months postpartum (OR = 0.38, 95% CI, 0.23–0.64; OR = 0.19, 95% CI, 0.13–0.30; and OR = 0.26, 95% CI, 0.18–0.37, respectively).

Sexual function. Both trials measured dyspareunia, although at different time points in the short- and long-term periods of followup. The good-quality trial found no statistically significant differences at 3 months or 12 months postpartum. The poor-quality trial found that women with repairs using rapidly absorbed material had significantly lower dyspareunia scores than women who received standard sutures. This finding extended to 3 months (mean scores 0.05 versus 0.27 in women who had dyspareunia, P < 0.05) but the authors noted that the scores were very low in both groups.

Untreated Catgut vs. Treated Catgut. Only one fair-quality trial^56^ investigated the use of treated, glycerol-impregnated “softgut” compared to chromic catgut. A followup to the original trial occurred at 3 years^57^ (Evidence Table 7, Appendix C).

Perineal pain and analgesia use. Women in the softgut group reported significantly greater perineal pain (P = 0.015) at 10 days postpartum. Women in the softgut group were also significantly more likely to have used a perineal salt bath to relieve pain (42% versus 34%, P = 0.03) and to use more doses of oral analgesia (P = 0.18), though this difference was not statistically significant. At 3 months postpartum, self-report of perineal pain did not differ by type of catgut used.

Healing and wound breakdown. Sutures were removed more often in the chromic-catgut group both by 10 days (2.4% versus 11.5%, P < 0.001) and 3 months (6.9% versus 16.4%, P < 0.0001). Removals were described as being for maternal discomfort. Based on assessment by a midwife at 10 days, risk of perineal breakdown and healing by secondary intention did not differ by group.

Sexual function. Sexual function was assessed at 3 months postpartum and 3 years. More women in the chromic-catgut group reported pain-free sexual intercourse than women in the softgut group (50.7% versus 38.0%, P < 0.025). This difference was significant for both transient and persistent pain. At 3 years, more women in the softgut group still reported painful intercourse (OR = 1.17; 95% CI, 1.1–2.6; P < 0.02); a majority with pain described the pain as “soreness.”

Nonabsorbable vs. Absorbable. One good-quality trial, the Southmead suture study by Mahomed and colleagues,^58^ and one fair trial by Buchan and Nicholls^54^compare absorbable sutures for repair of the perineal skin with nonabsorbable, silk sutures (Evidence Table 8, Appendix C). The good-quality trial randomized using a 2×3×2 factorial design and randomized women to one of three material groups for suturing of the perineal skin; polyglycolic-acid, chromic-catgut, or silk sutures. Balance was obtained between use of polyglycolic acid and chromic catgut for repair of the deeper tissue and between continuous and interrupted methods of suturing. The fair-quality trial randomized women to either silk sutures or polyglycolic-acid sutures for repair of the perineal skin and chromic catgut was used in both groups for repair of the deeper tissues. In this study, method of repair of the perineal skin has potential to confound outcomes because the silk-suture group was repaired using an interrupted method and the polyglycolic-acid suture group was repaired using a subcuticular method. The trial is included under this heading because the authors frame the primary goal of the trial as a comparison of silk suture and polyglycolic-acid suture.

Perineal pain and analgesia use. The Mahomed et al. study reported no statistically significant differences among the material groups with respect to perineal pain or use of analgesia at 2 and 10 days postpartum or at 3 months. The Buchan and Nicholls trial did report differences between the groups, but the results were inconsistent by the day 6 postpartum. The investigators used the mean number of analgesic tablets used by the women to make inferences about the level of perineal pain experienced by the women. Women with repairs made with silk sutures used more analgesia than women whose episiotomies were repaired with polyglycolic-acid suture, but the results were only significant for days 3 through 5 (P < 0.001).

Healing and wound breakdown. The Mahomed et al. study reported no significant differences among the groups with regard to bruising, edema, or healing, outcomes that were clinically assessed at 2 days postpartum. In the long-term postpartum period, the silk suture group needed the absorbable suture materials removed from perineal tissue significantly less than the polyglycolic-acid or chromic-catgut groups (7 percent versus 39 percent versus 23 percent, P < 0.001).^58^ No other results were reported and the fair-quality trial did not contribute to this outcome assessment.

Sexual function. In the good-quality trial, more women in the silk-suture group had not resumed intercourse by 3 months postpartum (15 percent versus 9 percent and 11 percent, P < 0.05). Among women who had resumed intercourse, dyspareunia risk was comparable. Conflicting evidence was reported by the fair-quality trial: at 4 months postpartum, more women in the silk-suture group reported no pain at all during intercourse (21 percent versus 11 percent, P < 0.001).

Polyglycolic Acid vs. Chromic Catgut. Eight RCTs compared polyglycolic-acid sutures with chromic-catgut sutures, both absorbable materials (Evidence Table 9, Appendix C). Information on these trials, ordered from the most recent to the oldest, appears in Table 7. Check marks indicate whether one type of sutures had better outcomes than the other; “ND” indicates no difference.

Table 7. Trial results for polyglycolic-acid and chromic-catgut sutures

Trial Information | Description of Pain Outcome | Superior Material for Pain | | | Description of Healing Outcome | Superior Material for Healing | | | Author's Overall Conclusions
| | PGA | CC | ND | | PGA | CC | ND
Upton et al., 2002^65^* | Short-term perineal pain (any, moderate to severe) | | | ✓ | Short-term problems with sutures | | | ✓ | No statistically significant differences between groups but leaned in favor of polyglycolic acid
Australia
N = 391
Quality: Fair
Ipswich Childbirth Study, Mackrodt et al., 1998 and Grant et al., 2001^61,^ ^63^* | Short-term perineal pain (any, mild, moderate) | ✓ | | | Short-term healing problems (tight stitches, uncomfortable stitches, gaping perineum) | ✓ | | | Clear advantages of polyglycolic acid
United Kingdom | Long-term perineal pain (mild, moderate, or severe) | | | ✓ | Long-term need for resuturing | | | ✓
N = 1,780
Quality: Good
Olah, 1990^59^ | Short-term perineal pain (10 cm VAS) | | | ✓ | Short-term edema and bruising | | | ✓ | Does not substantiate previous trials that show a benefit to polyglycolic acid
United Kingdom
N=120
Quality: Fair
Mahomed et al., 1989^58^* | Short- and long-term perineal pain (none, mild, mod, severe) | | | ✓ | Short- and long-term edema, bruising and healing | | | ✓ | Not much evidence to support polyglycolic acid but the little they have is consistent with other trials
United Kingdom | Short-term use of analgesics | ✓ | | | Long-term need for removal of sutures | | | ✓
N = 1,574 | Long-term use of analgesics | | | ✓ | Long-term need for resuturing | | | ✓
Quality: Good
Ping and Kee, 1975^53^ | Short-term perineal pain (No pain, mild, moderate, severe) | ✓ | | | Not measured | --- | --- | --- | Polyglycolic-acid sutures have considerable advantage over chromic-catgut sutures in episiotomy repair
Malaysia
N = 122
Quality: Fair
Beard et al., 1974^50^ | Short-term perineal pain (none, mild, moderate, severe) | ✓ | | | Short-term wound breakdown and inflammation | | | ✓ | Polyglycolic-acid sutures should be used
United Kingdom
N = 200
Quality: Fair
Livingstone et al., 1974^51^ | Short-term perineal pain (none, uncomfortable, painful, very painful, unbearably painful) | ✓ | | | Short-term edema | ✓ | | | Significant reduction in pain and edema with polyglycolic acid, no evident disadvantage in the use of polyglycolic acid
Scotland
N = 100
Quality: Poor
Rogers, 1974^52^ | Short-term perineal pain (none, degree of pain) | ✓ | | | Not measured | --- | --- | --- | Polyglycolic acid decreased the pain by half
United States
N = 600
Quality: Poor

Note: PGA, polyglycolic acid; CC, chromic catgut; ND, no difference.

* Three trials also investigated long-term sexual function outcomes with regards to polyglycolic-acid and chromic-catgut sutures. Two trials^58,^ ^65^ found no differences between the sutures and one trial^61,^ ^63^ found polyglycolic-acid sutures to be superior at 1 year postpartum regarding resumption of pain-free intercourse and dyspareunia.

Both the Mahomed et al.^58^ and the Mackrodt et al.^61,^ ^63^ trials were of good quality; they contributed to other sections of this key question because of their factorial design. Four trials were of fair quality.^50,^ ^53,^ ^59,^ ^65^ Finally, two trials were of poor quality;^51,^ ^52^ both used methods of randomization that are not considered to be truly randomized; thus, we considered them to have a fatal flaw.

Perineal pain and analgesia use. All eight trials investigated differences in perineal pain outcomes between the two groups. All but two provided consistent evidence that polyglycolic-acid sutures have an advantage over chromic catgut with regards to perineal pain. Two of the fair-quality trials^59,^ ^65^ found no significant differences between the groups; in one trial, the estimate of effect favored polyglycolic-acid suture for their pain measures on postpartum day 3 (OR = 0.70; 95% CI, 0.46–1.08). The same group of women who were in the polyglycolic-acid suture group, however, were more likely to have perineal pain at 6 months (OR = 1.77; 95% CI, 0.57–5.47), although the precision of that estimate is much less than that others in the study.

Two fair^50,^ ^53^ and two poor trials^51,^ ^52^ also reported less perineal pain and less need for analgesics in women who received polyglycolic-acid sutures in the short-term postpartum period. All four trials used Likert scales (mild, moderate, severe, or the equivalent) to measure pain; one trial^50^ counted the proportion of women requiring analgesia (tablets or injections). Although these trials offer only fair- or poor-quality evidence, they do contribute consistent evidence that polyglycolic-acid sutures may be associated with less short-term perineal pain.

The best evidence comes from the two good-quality trials.^58,^ ^61,^ ^63^ In the short-term postpartum period, both trials reported pain outcomes at 24 to 48 hours and 10 days. At 24 to 48 hours, more women in the chromic-catgut group in the Mahomed et al. trial required analgesia (54 percent versus 48 percent, P < 0.05;^58^ 47 percent versus 42 percent, P = 0.03^61,^ ^63^). This requirement for analgesia continued at 10 days postpartum in both trials and remained statistically significant in the Ipswich trial (10 percent versus 6 percent, P = 0.01). In the Ipswich trial,^61,^ ^63^ women in the chromic-catgut group reported more perineal pain and greater severity of pain at 24 to 48 hours (P for trend = 0.002) and at 10 days postpartum (P for trend = 0.05). The earlier trial had not identified significant differences for perineal pain at these two time points.^58^ Neither trial found significant differences between the groups regarding perineal pain at 3 months. In addition, the Ipswich trial found no differences at 1 year.

Healing and wound breakdown. Six of the eight trials examined healing and wound-breakdown outcomes between the two suture groups. Three fair trials^50,^ ^59,^ ^65^ and the Mahomed et al. study^58^ did not report statistically significant differences between the groups with respect to removal of sutures, resuturing, wound breakdown, inflammation, edema, bruising, or infection, most of which were measured before 3 months. One of the poor trials^51^ reported significantly more edema (P < 0.05 at the perineotomy site on day 3 postpartum) in the chromic-catgut group. The Ipswich trial results favored polyglycolic-acid suture at various followup time points and on various measures. At 24 to 48 hours and 10 days postpartum, more women in the chromic-catgut group reported uncomfortable stitches (40 percent versus 33 percent, P = 0.003, and 26 percent versus 19 percent, P = 0.001, respectively). The midwives reported more “wound gaping” in the chromic-catgut women at 10 days postpartum (26 percent versus 16 percent, P < 0.00001) but not at 24 to 48 hours. By 10 days, neither group was more likely to have sutures removed, but fewer women in the chromic-catgut group reported ever having any sutures removed by 3 months (7 percent versus 12 percent, P = 0.002). This finding is the only outcome representing a disadvantage among those who received polyglycolic-acid sutures in this trial.

Sexual function. Three trials, two of good quality^58,^ ^61,^ ^63^ and one of fair quality,^65^ investigated the effect of suture type on outcomes of sexual function. The fair-quality trial found no significant differences between the groups at 6 weeks, 3 months, or 6 months postpartum. The adjusted odds ratios (adjusted for parity) indicated a possible association between polyglycolic-acid sutures and less resumption of intercourse and more dyspareunia among women who had resumed intercourse. In one good-quality trial, women whose repairs were made with polyglactin 910, a polyglycolic acid-based suture, were less likely to suffer from dyspareunia at 1 year (RR = 0.59; 95% CI, 0.39–0.91; P = 0.002) and less likely to fail to resume pain-free intercourse (RR = 0.57; 95% CI, 0.38–0.87; P < 0.01).^61,^ ^63^ In both of the good-quality trials, all other comparisons yielded nonsignificant differences between the two suture groups at 3 months and 1 year.

### Results on Combined Approaches to Repair: Methods and Materials

Two additional trials investigated approaches to repair of perineal defects but did not distinguish between methods and materials^49^ (Evidence Table 10, Appendix C).^55^ Because of this, the trials are not directly comparable to other trials included in this review, and they do not contribute to the separate bodies of evidence for methods or materials. However, the results may be more applicable in the clinical setting where using a particular technique with a certain suture material, because of the properties of the materials themselves, may be more practical. We briefly describe these two trials and their results below.

One trial randomized women to one of two groups, both of which used the standard chromic-catgut approach to repair the deeper vaginal defect. In one group, the perineal skin was repaired with chromic catgut using an interrupted method of suturing; in the other, perineal skin was repaired with PROLENE™, a nonabsorbable suture material, using a subcuticular approach.^49^ A similar set of groups was seen in the Buchan and Nichols trial (included above in the “Nonabsorbable versus Absorbable” section).^54^ However, the Doyle trial, unlike the Buchan and Nicholls trial, was clear in its intent to investigate an entire approach to repair rather than a particular method or material.

The Doyle trial is of poor quality because it used a fair-quality randomization and implementation approach, had a small number of post-randomization exclusions, and had poor retention of subjects at followup, even in the short-term, immediate postpartum period.

As assessed by the midwife at 2 and 10 days, the groups did not differ with respect to perineal pain, need for analgesia, or bruising. The groups did not differ in pain or pain during sexual intercourse at 3 months.

Another trial randomly allocated women to one of three groups.^55^ The first group had the episiotomy repaired using chromic catgut for the deep tissues and perineal muscles and an interrupted method using nylon for the perineal skin. The second group received polyglycolic-acid sutures for the deep tissues and perineal muscles and an interrupted method using polyglycolic-acid sutures for the perineal skin. The third group is described more ambiguously and had a repair done with polyglycolic-acid sutures for the deep tissues and perineal muscles and a subcuticular method using polyglycolic-acid sutures for the perineal skin.

This trial is of fair quality because of fair definitions and measurements of the outcomes and post-randomization exclusion of 98 women whom the authors were unable to follow because of relocation. These exclusions were nondifferential across the three randomized groups.

More women who had a repair with subcuticular polyglycolic suturing had no discomfort at 5 days than did women who had repairs with interrupted nylon or interrupted polyglycolic-acid sutures (40%, 12%, and 18%, respectively, P < 0.001). The groups that had repairs with the interrupted method did not differ. The authors reported significant differences between women who had repairs with subcuticular polyglycolic-acid sutures and the interrupted method group including pain during sitting, walking, and bowel movements at 5 days. As assessed by the midwife at 5 days, the group repaired with subcuticular polyglycolic-acid sutures experienced less edema (11 percent versus 30 percent versus 23 percent, P < 0.005). No significant differences were found with respect to infection or hematoma.

At 3 months, the polyglycolic-acid suture groups differed significantly. Women whose episiotomies were repaired with the subcuticular approach were less likely to suffer from dyspareunia, discomfort with defecation, incontinence of flatus or discomfort when sitting (P < 0.025) than women whose episiotomies were repaired with the interrupted approach.

## Key Question 4: Episiotomy and Urinary Incontinence, Fecal Incontinence, and Pelvic Floor Defects

### Literature Search and Included Studies

Overview. We identified 16 publications that prospectively collected data about some aspect of continence or pelvic floor muscle function with good documentation of perineal status and episiotomy use at the time of the index birth. Outcomes of interest included physiologic measures of muscle strength, clinical urodynamic testing, or self report by interview or questionnaire. No studies directly compared type of incision and future pelvic floor function. The 16 publications include four reports from two randomized clinical trials (RCTs) of liberal versus restrictive use of episiotomy, 11 prospective studies of representative cohorts of women delivering at particular facilities or with a particular practice group (including two publications from a cohort of women who participated in an RCT of perineal massage versus none in the third trimester), and one cohort composed of all women in a region who had third-degree lacerations at the time of the index birth. The last study followed the cohort to assess risk of fecal incontinence at 3 months.

Two publications came from the same population in the United Kingdom: a primary analysis of the RCT outcomes at 3 months,^23^ and a secondary analysis after 3 years of followup.^33^ Two Canadian reports also present analyses of the same study population.^29,^ ^34^ In this case, both publications report 3-month followup data: one analysis by the initial trial groups of liberal versus restrictive use of episiotomy and the other an analysis based on classification of perineal trauma at the index birth. Of the remaining 12 prospective studies, three were conducted in the United Kingdom, two in Denmark (separate populations), two in Canada (separate populations), two in Sweden (separate populations), one in Italy, one in Turkey, and one in the United States. In total, the 16 publications represent 12 unduplicated study populations from seven countries.

Study Participants. All but the study of third-degree lacerations restricted study participants to those with term, singleton gestations at the time of the index birth. Four of 16 studies restricted their study populations to primiparous women;^68–71^ four studies restricted to spontaneous vaginal deliveries.^23,^ ^33,^ ^71,^ ^72^ To assess what component of change in pelvic floor muscle function could be attributed to pregnancy and what component was most influenced by vaginal births, two studies included a nonpregnant comparison group and a group of women who had cesarean birth in their physiologic measures.^68,^ ^73^ In each case the comparison groups were recruited contemporaneously to the women who had vaginal deliveries generally from the same practice.

Episiotomy Type. We did not identify any studies that compared the influence of mediolateral versus midline (also called median) episiotomy on pelvic floor function or continence. The remainder of the studies reflects the dominant practice patterns in the countries in which the studies were conducted. Mediolateral episiotomy was the rule (with very rare exceptions) in European and Turkish cohorts; midline episiotomy predominated in the United States and Canada. This implies that to some degree European and North American studies are investigating fundamentally different exposures. The anatomic location, involved tissue planes, extent of perineal body disruption, and risk for extension associated with mediolateral compared to midline episiotomy would be expected to be distinctly different.

A single randomized trial comparing the two methods has documented that the risk of extension into and/or through the rectal sphincter is more than 2.5 times more likely with midline episiotomy; sphincter involvement occurred in 24 percent of deliveries with midline episiotomy in their trial.^36^ They also noted that local extension, not involving the sphincter, was 1.8-fold more likely with midline episiotomy. These differential outcomes are believed to represent differences in the tissue planes involved. They may also represent differences in familiarity with midline episiotomy technique since reported risk of extension is lower in prospective cohorts in countries where midline episiotomy is routine. Because no trials or prospective studies directly compare the pelvic floor muscle function across type of episiotomy, the long-term differences in continence and pelvic floor muscle outcomes that would be anticipated secondary to differences in the type is unknown. These differences must be taken into consideration when synthesizing the findings relevant to this key question.

Outcomes Measured. This question was aimed at identifying research publications that undertook long-term followup, measured in years. However, we identified only five publications from four study populations with followup of a year or longer.^33,^ ^68–70^ ^74^ In response, we have included the entire literature that assesses continence and pelvic floor function at any time after the arbitrary 8-week window that can be used to define the postpartum period. Shorter-term continence and pelvic floor outcomes in the days and weeks around birth are described in the section on the outcomes of routine use of episiotomy.

To summarize outcomes, we grouped measures into four categories: those that assess urinary incontinence by self-report, those that assess continence of stool and flatus by self-report, those based on physical examination findings to describe anatomy, and those measures intended to document physiologic function, such as perioneometry. Seven studies assessed urinary incontinence by self-report; timeframes for self-report included 3 months,^23,^ ^29,^ ^34,^ ^70,^ ^71,^ ^75,^ ^76^ 12 months,^70^ 3 years,^33^ 4 years,^74^ and 5 years.^69^ Three studies assessed continence of stool and/or flatus by self-report at 3 months,^71,^ ^75,^ ^77^ and one study collected self-report data at an average of 10 months postpartum. Two studies described physical examination findings related to prolapse^71^and anal sphincter function and anorectal anatomy.^77^ Five studies used perineometry measures to document characteristics of muscle function such as maximum strength of contraction and maximum sustained contraction over 10 seconds.^29,^ ^34,^ ^68,^ ^71,^ ^73^ A single study reports findings from urodynamic testing that included observation of stress incontinence with strain and timing of interval required to stop urine flow;^71^ one study used weighted vaginal cones recording the heaviest weight that could be retained while standing or walking antepartum and 2 months postpartum. The highest-quality studies combined types of measures and reported data in standardized fashion that concurs with definitions of the International Continence Society.

Quality. Quality assessment is described in detail in Chapter 2 (Methods); key components of quality assessment and an overall quality score are provided in Evidence Table 11 (Appendix C). Four publications for this key question derive from the conduct of two RCTs that had good-quality ratings for assessing outcomes of liberal versus restrictive use of episiotomy. For this question, we also rated the breadth of measures used to characterize outcomes, the clarity of specification of the outcome measures (including documentation of how participants were asked self-reported measures), use of measures with documented validity and reliability, and loss to followup. For prospective cohort studies, we assessed these features and the representativeness of the participants to reflect a base population of women having births, as well as use of adjusted models to control for potential confounding factors.

Table 8 summarizes the methods and findings of the individual studies identified. Publications are listed in order from older to more recent reports. We then separately consider the findings from randomized trials of liberal versus restrictive use of episiotomy and prospective studies that employ episiotomy or perineal trauma categories as the primary exposure of interest. The findings are further grouped within study type by urinary incontinence outcomes, rectal continence outcomes, anatomic findings, and pelvic muscle function measures obtained using physiologic measurements.

Table 8. Episiotomy and urinary incontinence, fecal incontinence, and pelvic floor defects

Author, Year | Study Design | Timing of Outcome | Outcome(s) Assessed | Outcome among Those with Episiotomy | Outcome among Those without Episiotomy | Results of Multivariable Models
Country | N | Assessment after Birth Approach | Definitions Provided | | | Authors' Conclusions
Sleep et al., 1984^23^ | RCT | 3 months | Urinary incontinence | Incontinence: | Incontinence: | Incontinence was more common among multiparas than primiparas but did not differ significantly between the two trial groups when stratified by parity.
United Kingdom | N = 1,000 | Mailed questionnaire | “involuntary loss of urine” | 19% | 19% | There is no evidence that episiotomy prevents urinary incontinence.
| | | “Need to wear a pad” for loss of urine | Pad: 6% | Pad: 6%
Gordon and Logue, 1985^68^ | Prospective cohort | 12 months | Perineometry pressure readings | Maximum pressure epis: | Maximum pressure intact: | Not reported
United Kingdom | N = 70 | Physiologic testing in women with all perineal outcomes and cesarean | Methods summarized in text; average of five measures used | 11.7 mm water | 11.1 | No significant difference between the groups. Differences between postnatal exercise levels were highly significant with more exercise associated with greater perineal muscle strength.
| | | | Maximum pressure forceps and epis: | Maximum pressure
| | | | 9.4 mm water | second degree: 10.8
| | | | | Maximum pressure cesarean: 12.5
Sleep et al., 1987^33^ | RCT | 3 years | Urinary incontinence | Incontinence | Incontinence | Not reported
United Kingdom | N = 674 | Mailed questionnaire | “Lost urine when they did not mean to” | < once past wk: 22% | < once past wk: 25% | No difference in prevalence of urinary incontinence, even when severity and nature of the incontinence, and subsequent deliveries, were taken into account.
| | | “Severe enough to wear pad” | 1–2× past wk: 12% | 1–2× past wk: 11%
| | | “Loss when coughing, laughing, sneezing” | ≥ 3× past wk: 2% | ≥ 3× past wk: 2%
| | | “Loss with urgent desire to pass urine but no toilet nearby" | Pad sometimes: 8% | Pad sometimes: 7%
| | | | Pad daily: 2% | Pad daily: 1%
| | | | SUI: 33% | SUI: 31%
| | | | Urge incont.: 13% | Urge incont: 13%
Rockner, 1990^74^ | Prospective Cohort | 4 years | Urinary incontinence | Urinary incontinence: | Urinary incontinence: | Not reported.
Sweden | N = 185 | Mailed questionnaire | Frequency | Occas.: 37 (26%) | Occas.: 12 (28%) | Episiotomy and spontaneous tear groups had the same frequency of urinary incontinence symptoms, giving no support to the suggestion that episiotomy prevents long-term damage of the pelvic floor.
| | | Severity | 1×/week: 10 (7%) | 1×/week: 1 (2%)
| | | (data corresponds to definitions) | 2–3×/wk: 2 (1%) | 2–3×/wk: 1 (2%)
| | | | >3×/wk: 1 (1%) | >3×/wk: 1 (2%)
| | | | With cough/laugh/sneeze: | With cough/laugh/ sneeze
| | | | 48 (34%) | 13 (30%)
| | | | Sufficiently severe to wear pad | Sufficiently severe to wear pad
| | | | Sometimes: 13 (9%) | Sometimes: 6 (14%)
| | | | Always: 1 (1%) | Always: 0 (0%)
Rockner et al, 1991^78^ | Prospective cohort | 2 months | Pelvic floor muscle function measured using weighted vaginal cones at 36 wks gestation and postpartum | Mean decrease in muscle function (gms): 30.0 ± 11.8 | Mean decrease in muscle function (gms) | Not reported
Sweden | N = 92 | Physiologic measure | Details provided in text | | Intact: 19.2 ± 10.2 | Pelvic floor muscle function was most decreased in the episiotomy group. The results do not support the concept that episiotomy reduces damage to the pelvic floor muscles.
| | | | | Spontaneous tear: 18.9 ± 9.1
| | | | | (P < 0.001)
Klein et al., 1992^29^ | RCT | 3 months | Urinary incontinence | Incontinence | Incontinence | Not reported
Canada | N = 703 | In-person interview | Not defined - used 4-point scale, dichotomized as present/ absent | Primip: 14.5% | Primip: 21.1% | None of the differences in urinary incontinence were statistically significant after controlling for antepartum history of urinary incontinence.
| | Physiologic measure: Antepartum and 3 months postpartum | Subjective sense of “perineal bulging”; 4-point scale dichotomized as present/ absent | Multip: 21.5% | Multip: 12.9%
| | | Perineometry | Bulging | Bulging
| | | | Primip: 7.9% | Primip: 9.1%
| | | | Multip: 9.5% | Multip: 5.4%
| | | | EMG | EMG
| | | | Primip ante: 2.1 (1.8) | Primip ante: 2.0 (1.6)
| | | | Primip post: 2.3 (1.8) | Primip post: 2.3 (1.6)
| | | | Multip ante: 1.7 (1.5) | Multip ante: 1.9 (1.6)
| | | | Multip post: 2.1 (1.5) | Multip post: 2.1 (1.5)
Viktrup et al., 1992^70^ | Prospective cohort | 3 months | Telephone interview | Data not provided | Data not provided | Not reported
Denmark | N = 305 | 12 months | Questionnaire using International Continence Society definitions | | | Women who had an episiotomy developed stress incontinence significantly (P < 0.05) more frequently after delivery. However, episiotomy was performed more often in women with an increased length of second stage (P < 0.01). Differences in stress incontinence associated with episiotomy had resolved by 1 year.
| | | Urinary incontinence provoked by physical exertion; daily incontinence; incontinence as hygienic or social problem
Klein et al., 1994^34^ | Prospective cohort assembled from participants in liberal vs. restrictive episiotomy trial | 3 months | Self-reported urinary incontinence (4 point scale) | No difference | No difference | Not reported
Canada | N = 697 | In-person interview | Perineometry scores | (data not shown) | (data not shown) | Episiotomy fails to prevent the trauma or pelvic floor relaxation that it was designed to prevent.
| | Physiologic measures antepartum and postpartum | (electronic vaginal myography) | Epis, no exten. | In tact
| | | Methods described in text | Net change: Primip: 0.19 | Net change: Primip: 0.47
| | | | Multip: 0.05 | Multip: 0.57
| | | | Third/fourth degree | Spontaneous tear
| | | | Net change: Primip: 0.08 | Net change:
| | | | Multip: -0.07 | Primip: 0.29
| | | | | Multip: 0.39
Walsh et al., 1996^77^ | Prospective cohort of women with Third-degree tears | 3 months | Physical examination by colorectal surgeon | 100% of women with abnormal exam and fecal incontinence had episiotomy | No cases of fecal incontinence among women without episiotomy | Not reported
United Kingdom | N = 81 | | | 60% of women with abnormal exam and no incontinence had episiotomy | 40% of women with abnormal exam and no incontinence did not have episiotomy | Obstetric trauma causes significant anorectal dysfunction and patients with third-degree tears require assessment.
MacArthur et al., 1997^79^ | Prospective cohort | 10 months | Fecal incontinence | Primp.: 4.6% | Intact | In multivariable models: episiotomy not an independent predictor of fecal incontinence
United Kingdom | N = 906 | N = 906 | “Loss of bowel control with no warning needed to go”; | Multip.:8.8% | Primp.: 5.2%
| | In-person | “soiling or staining”; “felt need to go but couldn't hold on” | | Multip.:2.9%
| | Interview | One or more considered incontinence | | Second degree
| | | | | Primip: 5.2%
| | | | | Multip: 4.2%
Viktrup and Lose, 2001^69^ | Prospective cohort | 5 years | Telephone interview | Not provided by episiotomy status | | In multivariable modes, episiotomy at the first delivery was significantly associated with stress incontinence 5 years after delivery, even after adjustment for the few with coexistence of anal sphincter rupture.
Denmark | N = 305 | | Questionnaire using International Continence Society definitions; | Episiotomy contributed to prediction of risk of incontinence at 5 years when comparing women who had incontinence during their pregnancy to those without any incontinence associated with pregnancy or postpartum.
| | | urinary incontinence provoked by physical exertion; daily incontinence; incontinence as hygienic or social problem | Episiotomy not risk factor among women with only postpartum symptoms.
Eason et al., 2002^75^ | Prospective cohort assembled from participants in perineal massage RCT | 3 months | Incontinence of stool | Loss of stool: | Loss of stool: | Loss of stool/flatus:
Canada | N = 949 | Mailed questionnaire | Incontinence of flatus | RR: 5.4% | RR: 2.5% | No perineal injury: RR 1.0
| | | “Involuntary loss of stool or flatus” | Loss of flatus: | Loss of flatus: | First degree: 1.2 (0.8, 1.7)
| | | Frequency (never, less than 1 a week, 1 to 6 times a week, daily, or more than once a day) | RR: 30.2% | RR: 24.4% | Episiotomy without extension: 1.3 (0.9, 1.8)
| | | | | | Third/fourth degree: 2.1 (1.4, 3.1)
| | | | | | Anal incontinence is associated with sphincter laceration, which was more common among those with episiotomy.
Fleming et al., 2003^73^ | Prospective cohort | 6 months | Perineometry scores | Mean score (SD) | Mean score (SD) | Not reported
United States | N = 102 | Baseline perineometry during pregnancy; and at 6 wks | (electronic vaginal myography) | Peak: -1.7 (2.1) | Intact | No significant differences in absolute postpartum perineal muscle strength or endurance between episiotomy and laceration groups.
| | Physiologic testing in women with all perineal outcomes and cesarean | Methods detailed in text; average of three measures of each type of contraction used for analysis | Hold: -1.7 (2.1) | Peak: 2.7 (2.8) | Women who had episiotomy were only group with net loss of perineal muscle function after delivery.
| | | Difference in antepartum and postpartum scores | | Hold: 2.8 (3.5)
| | | | | Second- or third-degree laceration
| | | | | Peak: 0.8 (2.6)
| | | | | Hold: 0.8 (2.3)
Karacam and Eroglu, 2003^72^ | Prospective cohort | 3 months | Stress incontinence | 12/50 (24%) | 15/50 (30%) | No significant differences in stress incontinence before labor, or if after delivery of first child, or if after delivery of second child that was related to episiotomy.
Turkey | N = 100 | Telephone questionnaire | Not defined
Eason et al., 2004^76^ | Prospective cohort participants in perineal massage RCT | 3 months | Frequency of involuntary loss of urine when coughing, sneezing, laughing, running | Any stress urinary incontinence: 29% | Any stress urinary incontinence: 35% | OR: 0.68 (0.47, 1.01)
Canada | N = 949 | Mailed questionnaire | | | | No significant association between episiotomy and urinary incontinence.
Sartore et al., 2004^71^ | Prospective cohort | 3 months | Perineometry with highest/best single recording used for analysis | SUI: 12.9% | SUI: 12.1% | OR: 1.01 (0.61, 1.7)
Italy | N = 519 | Physical exam | Baden and Walker classification of urogenital prolapse | Anal incont: 2.8% | Anal incont: 1.9% | OR: 1.47 (0.46, 4.7)
| | Physiologic measures: | Urine stream interruption test | Ante prolapse: 41p.5% | Ante prolapse: 42.1 | OR: 0.97 (0.69, 1.4)
| | Perineometry | SVI - visible involuntary loss of urine by ICS standards | Post prolapse: 15.8% | Post prolapse: 14.6% | OR: 1.1 (0.68, 1.8)
| | Uroflowmeter | Self-reported urge and anal incontinence of stool or flatus, classified by frequency | Vaginal manometry: | Vaginal manometry: | P < 0.001
| | In-person interview | | 12.2 (5.1) | 13.8 (4.7) | P = 0.85
| | | | Urine stream interrupt: 3.9 (3.5) | Urine stream interrupt: 3.8 (2.9) | OR: 1.79 (1.2, 2.6)
| | | | Vaginal manometry percent abnormal: | Vaginal manometry: percent abnormal: | Mediolateral episiotomy does not protect against urinary and anal incontinence. Episiotomy is associated with lower pelvic floor muscle strength than spontaneous tears.
| | | | 40.60% | 27.7%

### Results

Randomized Clinical Trials. Both randomized clinical trials, Sleep and colleagues in the United Kingdom^23^ and Klein and colleagues in Canada,^29^ conducted trials that required providers to alter their use of episiotomy. These trials randomized women to receive “liberal use” versus “restricted use” of episiotomy, with the latter category intended to restrict use to circumstances such as fetal distress or maternal exhaustion with an “unyielding perineum.” Both trials enrolled singleton, vertex presentation pregnancies at term and randomized in the delivery suite close to the time of birth.

The United Kingdom trial had a 10.2 percent use of episiotomy in the restrictive group (2.6 percent for maternal indications; 6.6 percent for fetal distress), compared to 51.4 percent use of episiotomy in the liberal group. The Canadian trial had greater difficulty modifying provider behavior as background rates of episiotomy exceeded 80 percent. Restrictive use resulted in 57.2 percent of the women having an episiotomy compared to 81.4 percent in the liberal-use arm. Each of these research groups published an analysis as randomized for 3-month postpartum data. The sole violation of intention to treat was Klein's elimination of five women with cesarean section from analysis of pelvic floor outcomes. Both trials achieved good balance of baseline characteristics through randomization. Both trials assessed urinary incontinence outcomes; neither assessed continence of stool or flatus.

The Canadian trial also assessed self-reported sensation of perineal “bulging” and conducted perineometry. The Canadian team has published two analyses: an analysis as randomized and an analysis by perineal trauma sustained. The randomized analyses produced no meaningful differences in self-reported urinary incontinence, subjective sensation of perineal bulging, or perineometry readings, including when baseline antepartum readings and parity were incorporated. Likewise, the analysis by perineal status (intact, episiotomy, spontaneous tear, third- and fourth-degree tear) revealed no differences in self-reported incontinence or in perineometry scores. These analyses were stratified by parity and suggest some effect modification; however, the authors did not provide adjusted models or note any statistically significant results.

The research team from the United Kingdom has published two analyses as randomized: a 3-month and 3-year followup, both conducted by mailed questionnaire followup.^23,^ ^33^ The 3-month followup found no difference by group in risk of involuntary loss of urine (19 percent in both arms) or in need to wear a pad because of urine loss (6 percent in both arms). Their 3-year followup was more detailed and included involuntary loss of urine; use of a pad; loss of urine with coughing, sneezing, laughing; and loss with urgent need to void. No aspect of these symptoms or their severity varied by restrictive versus liberal episiotomy group. For the 3-year followup, this lack of difference across groups persisted when taking into account subsequent obstetric history. The 3-year followup was also marred by loss, although the authors were able to use 3-month data to demonstrate little evidence of response bias. Adjustment using multivariable models is alluded to but numeric data are not provided.

Neither trial collected data about continence of flatus or stool, descriptive data from physical examination, or urodynamic studies. Both research teams concluded that they did not observe any benefits associated with episiotomy. Klein and colleagues, based on perineometry measures, also concluded that episiotomy fails to prevent pelvic floor relaxation.

Prospective Studies. The Italian study by Sartore and colleagues provided the most global assessment of continence and pelvic floor function; they addressed each of our four categories of outcomes.^71^ They enrolled 519 primiparous women who had singleton, spontaneous vaginal births in lithotomy position. Women with pre-existing incontinence were excluded. Measures of outcomes at 3 months included in-person interviews, physical examination, perineometry, a test to provoke stress urinary incontinence, and a urine-stream-interruption test. The study team clearly described methods, used a standard scheme for classifying prolapse, and collected data about urinary and anal incontinence. Overall measures and implementation were good. For the entire panel of outcomes (stress urinary incontinence, anal incontinence, anterior prolapse, posterior prolapse, vaginal manometry, and urine-stream interruption), there was only one statistically significant difference in perineometry findings. Women who did not have an episiotomy (all mediolateral) had higher contraction strength on perineometry (13.8 compared to 12.2; P < 0.001); moreover, the proportion of women with abnormal manometry was higher among women with episiotomy (40.6 percent compared to 27.7 percent without episiotomy). The adjusted relative risk for abnormal manometry was 1.8 (95% CI, 1.2–2.6). The study team concluded that episiotomy is associated with lower pelvic floor muscle strength than spontaneous tears. All self-reported symptoms of urinary and anal incontinence and degree of prolapse on physical examination were equivalent across groups so the clinical significance of this finding is unclear. Overall interpretation must be that episiotomy does not protect against incontinence, prolapse, or decrements in pelvic floor muscle function by 3 months postpartum.

Studies focused on self-reported urinary continence. Excluding the clinical trial populations and the study by Sartore et al. described above, five studies (in four study populations) evaluated self-report of urinary continence.^69,^ ^70,^ ^72,^ ^74,^ ^76^ Two used a telephone interview,^70,^ ^72^ the other three mailed questionnaires.

Karacam and Eroglu provided the least-detailed information:^72^ no details about how stress incontinence was queried or defined for data analysis and no report of adjusting for factors that might influence outcomes by using stratified analyses or multivariable models. They reported, from bivariate data at 3 months (N = 100), that 24 percent of women with episiotomy and 30 percent of women without episiotomy had stress incontinence.

Eason and colleagues asked about occurrence and frequency of “involuntary loss of urine when coughing, sneezing, laughing, or running” in a cohort of 949 women also at 3 months.^76^ For analysis, they reported that any stress incontinence occurred in 29 percent of those with episiotomy and in 35 percent of those without. Multivariable models for stress urinary incontinence comparing episiotomy to no episiotomy yielded an odds ratio of 0.68 (95% CI, 0.47–1.01).

Viktrup and colleagues reported using a questionnaire to obtain all the facets of the International Continence Society definitions of incontinence from 305 women.^70^ They reported no differences but do not provide numeric data. In summary, they stated that although women with episiotomy had more incontinence postpartum, differences had resolved by 3 months and remained equivalent at 1 year. Their followup survey at 5 years revealed in multivariable models that episiotomy in a first birth was significantly associated with stress incontinence.^69^ An adjusted point estimate is not provided.

Rockner's followup of a cohort of 185 women with either episiotomy or spontaneous tear at 4 years after the index pregnancy asked women about symptoms before, during, and after all pregnancies; information about the index pregnancy focused on frequency and severity of urinary incontinence; need for pad; and loss of urine provoked by cough, laugh, or sneeze.^74^ Symptom profiles were very similar across groups; for instance, 34 percent of women who had an episiotomy and 30 percent without reported incontinence provoked by cough, laugh, or sneeze. No stratified or adjusted models are provided. The author concluded that episiotomy and spontaneous-tear groups had the same frequency of incontinence symptoms. Overall, each research team investigating self-reported urinary incontinence concluded that no evidence supported the view that episiotomy prevents pelvic floor defects.

Studies focused on self-reported incontinence of stool or flatus. Three cohort studies asked women about rectal incontinence symptoms.^75,^ ^77,^ ^79^ One study also conducted physical examinations.^77^

The earliest of these studies was conducted on a cohort constructed of 81 women who had third-or fourth-degree lacerations.^77^ The prevalence of episiotomy among women without third- or fourth-degree lacerations was known as well as their episiotomy history in the index pregnancy. They were followed up at 3 months when their symptoms were evaluated and they received a physical examination. All women who had fecal incontinence and abnormal rectal examination at three months had had an episiotomy. Of those with an abnormal exam and no incontinence 60 percent had had an episiotomy, meaning relative risk of abnormal exam was 50 percent greater among those with history of episiotomy. These authors focused on the high prevalence of anorectal dysfunction at 3 months with episiotomy as a key risk factor. None of the research teams that focused on incontinence of flatus or stool found episiotomy to be significantly associated with reduced risk.

MacArthur and colleagues sent questionnaires at 6 to 7 months and then followed up all women who had a variety of symptoms at 10-months with an in-person interview. ^79^ Their questionnaire and interview classified several types of fecal incontinence and staining (not including simple flatus); any one or more of the symptoms was considered evidence of incontinence. At 10 months, episiotomy was not an independent predictor of fecal incontinence in multivariable models. Because episiotomy was not a key focus of their analysis, they do not provide a point estimate.

Eason and colleagues inquired about involuntary loss of stool or flatus and the frequency at 3 months.^75^ Women with episiotomy reported higher prevalence of loss of stool (5.4 percent) and loss of flatus (30.2 percent) than did women without episiotomy (2.5 percent and 24.4 percent, respectively). Adjusted models revealed that episiotomy without extension was associated with a relative risk of 1.3 (95% CI, 0.9–1.8), and third- to fourth-degree lacerations (virtually all after episiotomy) were associated with 2.1-fold increased risk of anal incontinence (95% CI, 1.4–3.1). The study team concluded that anal incontinence was associated with severe lacerations that are most likely to result from episiotomy.

Studies focused on physiologic measures of pelvic floor function. In 1985, Gordon and Logue published the first use of perineometry to evaluate prospectively a group of 70 women.^68^ They included a nonpregnant and a cesarean comparison group to take into account changes associated with pregnancy and labor, respectively. They did not compare women with their own measures in pregnancy. No difference in maximum contraction strength was seen across groups. However, the researchers did note that postnatal exercise level was highly associated with perinatal muscle strength.

Fleming and colleagues refined the Gordon and Logue study design.^73^ They conducted perineometry antepartum, at 6 weeks, and again at 6 months among 102 women with singleton spontaneous vaginal births. Detailed measurement protocols are provided and their analysis focused on mean difference between antepartum scores and 6-month scores. No differences in perineal muscle strength or endurance were identified between laceration and episiotomy groups.

In another approach to measuring muscle strength, Rockner and colleagues conducted studies with weighted vaginal cones at 36 weeks gestation and again at 2 months postpartum. They calculated decrements in weight that could be retained while standing or walking: women with episiotomy had the greatest decrement in function (30 gm decrease in maximum weight held), compared to 19.2 gram decrease with intact perineum, and 18.9 gm decrease with spontaneous tears (P < 0.001).^78^

Overall, none of these research teams concluded that episiotomy had advantages, and one identified a decrease in functional muscle strength. These intermediate findings concur with the self-report and clinical examination findings of other studies that detected no evidence of benefit from episiotomy with respect to preserving continence or pelvic floor muscle function.

## Key Question 5: Episiotomy and Future Sexual Function

### Literature Search and Included Studies

Overview of the Evidence. Nine publications were identified that prospectively collected outcome data about sexual function among women who did or did not have a routine episiotomy. Evidence Table 12 in Appendix C provides details. One study compared incision type and assessed sexual function.^36^ These 10 publications include three randomized trials of restrictive versus liberal use of episiotomy;^23,^ ^29,^ ^33^ one trial of median versus midline episiotomy;^36^ and five prospective cohort studies.^34,^ ^71,^ ^72,^ ^80,^ ^81^ One study (the only study conducted in the United States), described by the authors as “retrospective,” included a single followup time point (6 months) for which the data collection about sexual function was prospective.^38^ Two publications reflect a primary analysis from a randomized clinical trial (RCT) with 3 months of followup^23^ and a secondary analysis after 3 years of followup^33^ in the same study population from the United Kingdom. Two publications by a Canadian research team are also analyses of the same study population.^29,^ ^34^ In this case, both publications report 3-month followup data: one analysis focused on randomization to liberal versus restrictive episiotomy groups, and the other took the perspective of exposure groups classified by perineal trauma at the time of delivery. Two of the prospective studies were conducted in Sweden (separate study populations), one in Italy, and one in Turkey. Thus, in total, this literature represents seven distinctive study populations from six countries.

Study Participants. In current practice in the United States, women who are giving birth for the first time are most likely to have a routine episiotomy. Several studies that evaluated sexual function restricted the study population to primiparous women. This approach assures that the influence of episiotomy, spontaneous laceration, or intact perineum reflects only the potential influences of the index birth, rather than both the index birth and any prior history of perineal trauma among women who have had prior births. Those studies that did not restrict their study of sexual function to primiparous patients adjusted for prior episiotomy in data analysis as a method to account for the influence of prior birth experiences. All studies restricted participation to singleton births; and some specifically included only women who had a spontaneous vaginal birth.

Episiotomy Type. Only one study directly compared mediolateral to median (midline) episiotomy.^36^ The remainder of the studies reflects the dominant practice patterns of the countries in which the studies were conducted. Mediolateral episiotomy is routine in the countries represented, with the exception of the United States and Canada, where median episiotomy is routine. Overall, when episiotomy was performed in the U.S. and Canadian studies, it was a median incision;^29,^ ^34,^ ^38^ this phenomenon stands in contrast to 98.9 percent mediolateral episiotomies in the European and Turkish studies.^72,^ ^33,^ ^71,^ ^80,^ ^80,^ ^81^

This factor introduces a fundamental difference in the “exposure” across studies. The anatomic location, involved tissues plains, extent of perineal disruption, and risk for extension associated with mediolateral as compared to median episiotomy are distinctly different. Once healed, the scar from each type of episiotomy and from spontaneous lacerations will be subject to different amounts and types of contact, pressure, and stretch depending on position of partners during sexual intercourse. Thus, the literature reflects two distinct types of procedures, the effects of which need to be addressed separately.

Outcome Measures. Of the 10 studies included for this key question, eight were not designed to address sexual function as the primary outcome. Only the Signorello et al. and Karacam and Eroglu studies reported that a primary objective of the study was to assess the relationship between perineal trauma (spontaneous versus episiotomy) and postpartum sexual function.^38,^ ^72^

The most consistently reported outcome was “dyspareunia.” In three of these 10 publications, the researchers provide no detail to document how they phrased a question or questions about pain with intercourse or how they recorded participant responses; no reports distinguished between pain on insertion, deep dyspareunia with thrusting, or residual pain (deep or perineal) after intercourse. Four studies used a written questionnaire to collect information about sexual function.^23,^ ^33,^ ^38,^ ^80^ One study conducted telephone interviews,^72^ and four conducted in-person interviews.^29,^ ^34,^ ^71,^ ^81^ In-person interview methods for assessing sexual function outcome tended to be more detailed than those obtained from written questionnaires. However, none of the publications distinguish between pain on insertion, deep dyspareunia with thrusting, or residual pain (deep or perineal) after intercourse.

Across all 10 studies, investigators used three approaches for summarizing when women experienced dyspareunia. The most common was to inquire about any dyspareunia since resuming intercourse. Other authors inquired about dyspareunia with episodes of intercourse near the time of the followup. To differentiate this approach from measures of any experience of dyspareunia, we have called inquiry about recent status “current dyspareunia” in this report. Less often, authors reported about pain at the time of the first episode of intercourse after the index birth.

In a related measure, four research teams also asked women to recall when they resumed having intercourse. This question allows the investigators to report both continuous and categorical data about the proportion of women who had resumed intercourse by particular points in time, for example, by 2 months postpartum.^23,^ ^29,^ ^34,^ ^80^ Few authors clearly explained if the prevalence of dyspareunia reported is appropriately calculated as a proportion (number of women with pain with intercourse divided by number of women who have resumed intercourse). The most common timeframe for assessment of outcomes was 3 months. One group assessed dyspareunia at postpartum exams between 2 and 3 months;^81^ one used a mailed questionnaire at 6 months;^38^ and the longest followup was conducted by questionnaire mailed at 3 years.^33^

The two publications by Klein and colleagues had the most elaborate approach to collecting several types of information. These authors reported greater detail about how participant responses were collected and analyzed. In interviews at 3 months postpartum, they asked women when they resumed intercourse and assessed recalled pain at the first postpartum episode of intercourse using the McGill Pain Scale. They inquired about sexual satisfaction using an unspecified number of items measured on a 4-point scale and reported a summary measure of “sexual satisfaction” in their tables.^29,^ ^34^ Two other groups classified degree of pain with intercourse using an approach that assigned levels: none, mild, moderate, and severe.^71,^ ^34^

Quality. None of the identified studies was designed exclusively to examine sexual function. We classified primary and secondary outcomes based on objectives provided in the introduction of the publication or used stated research questions to classify primary and secondary objectives.

None of the 10 studies met criteria that we consider necessary to be a good study of sexual function after episiotomy. Our criteria included (1) documentation of a representative sample of women who had spontaneous vaginal births, (2) use of outcomes that provide a well-rounded picture of sexual function, (3) clear specification of outcome measurement approach (including specification of items asked of participants on surveys or in interviews), (4) use of measures with documented validity and reliability, (5) use of adjusted models in prospective data to control for potential confounding factors, (6) minimal to modest loss to followup, and (7) use of intention-to-treat analysis in randomized clinical trials.

### Results

Table 9 summarizes the methods and findings of the individual studies identified. Publications are listed in order from older to more recent reports. We also separately consider the findings of controlled trials of liberal use versus restricted use of episiotomy and other prospective cohort studies of episiotomy that include sexual function outcomes (Table 10). The single study that compared type of episiotomy incision and included assessment of sexual function is reviewed on pages 30 and 31; no differences in pain with initiation of intercourse or with satisfaction with intercourse were noted by episiotomy type.

Table 9. Episiotomy and future sexual function

Citation | Study Design | Timing of Outcome Assessment after Birth; | Outcome Assessed | Outcome among Those with Episiotomy | Outcome among Those without Episiotomy | Results of Multivariable Models
Epis. Type | N | Approach | Definitions Provided | | | Authors' Conclusions
Country
Sleep et al., 1984^23^ | RCT | 3 months | Resumption of intercourse by 3 months (not defined) | 90% | 90% | Not reported
Mediolateral | N = 1000 | Mailed questionnaire | Current dyspareunia: “pain during sexual intercourse” | 22% | 18% | Only difference was tendency for women allocated to restrictive episiotomy to resume intercourse sooner.
UK | | | Any dyspareunia: “pain during sexual intercourse, at some time” in prior 3 months | 52% | 51%
Sleep and Grant, 1987^33^ | Prospective cohort that included RCT participants | 3 years | Any dyspareunia: | 16% | 13% | RR 1.21 (0.84, 1.75);
Mediolateral | N = 326 | Mailed questionnaire | “ever suffering painful sexual intercourse” | | | No significant difference
UK
Rockner et al., 1988^80^ | Prospective cohort | 3 months | Resumption of intercourse (Y/N) | 92% | 92% | Not reported
Mediolateral (88%) | N = 205 | Questionnaire (setting not specified) | Current dyspareunia | 20% | 20% | No significant difference
Sweden | | | (not defined) | 44% | 43%
| | | Any dypareunia in prior 3 months
| | | (not defined)
Larsson et al., 1991^81^ | Prospective cohort | 2 to 3 months | Dyspareunia (not defined) | 16% | 11% | Not reported
Mediolateral | N = 1889 | In-person interview with midwife | | | | None made regarding sexual function
Sweden
Klein et al., 1992^29^ | RCT: | 3 months | Resumption of intercourse (“weeks between birth and first intercourse”) | Primip: 5.8 (2.1) | Primip: 5.9 (2.5) | Time to resumption of intercourse similar; those with intact perineum began intercourse 1 week earlier than others. Pain with resumption, 3-month sexual satisfaction and proportion not resuming by 3 months similar across groups.
Midline | Liberal vs restrictive | In-person interview | Dyspareunia: “Pain at first postpartum intercourse” assessed using McGill Pain Scale | Multip: 5.8 (2.6) | Multip: 5.4 (2.3)
Canada | N = 703 | | Sexual satisfaction at 3 months × items using “4 point scale” - actual items not provided | Primip: 2.2 (1.3) | Primip: 2.2 (1.3)
| | | | Multip: 1.3 (1.1) | Multip: 1.2 (1.0)
| | | | Primip: 3.1 (0.7) | Primip: 3.0 (0.8)
| | | | Multip: 3.3 (0.7) | Multip: 3.3 (0.6)
Klein et al., 1994^34^ | Prospective cohort derived from RCT | 3 months | Resumption of intercourse by week 6 | Epis alone: 61.7% | Intact: 76.5% | Women with spontaneous perineal tears had less pain on first intercourse than those with episiotomy alone. Those with third- to fourth-degree episiotomy extensions had the most pain on resumption of intercourse.
Midline | N = 697 | In-person interview | Dyspareunia: “Pain at first postpartum intercourse: none, mild, discomforting, distressing-horrible” | Third-/fourth-degree: 55.4% | Spont. tear: 62.5%
Canada | | | Sexual satisfaction at 3 months; items using “4-point scale” - actual items not provided | Epis alone: | Intact:
| | | | Mild: 22.7% | Mild: 37.6%
| | | | Discomf: 34.1% | Discomf: 22.8%
| | | | Distress: 28.8% | Distress: 6.9%
| | | | Third-/fourth-degree: | Spont. tear:
| | | | Mild: 23.0% | Mild: 27.3%
| | | | Discomf: 39.3% | Discomf: 27.3%
| | | | Distress: 29.5% | Distress: 24.6%
| | | | Epis alone: | Intact:
| | | | Not satisfied: 16.3% | Not satisfied: 5%
| | | | Third/fourth degree: | Spont:
| | | | Not satisfied: 21.3% | Not satisfied: 15.8%
Signorello et al., 2001^38^ | Cohort with a single prospective window | 6 months | Current dyspareunia: “pain on sexual intercourse” at 6 months | Multivariate models for type of perineal trauma: | Degree of perineal trauma, not episiotomy per se associated with dyspareunia.
Midline | N = 921 | Mailed questionnaire | | None: Referent
United States | | | | Second degree:1.3 (0.8, 2.2)
| | | | Third/fourth degree: 1.5 (0.7, 3.5)
Karacam and Eroglu, 2003^72^ | Prospective cohort | 3 months | Any dyspareunia (not defined) | 64.58% | 54.17% | Not reported
Mediolateral | N = 100 | Telephone interview | | | | No significant differences between groups in rate of mothers' dyspareunia.
Turkey
Sartore et al., 2004^71^ | Prospective cohort | 3 months | Current dyspareunia (not defined); classified as “absent, mild, moderate, severe”; reported Y/N | 7.9% | 3.4% | Summary measure:
Mediolateral | N = 519 | In-person interview | | | | RR: 2.43 (1.05, 5.45)
Italy

Table 10. Episiotomy and dyspareunia

Citation | Study Design | Timing of Outcome Assessment after Birth | Outcome Assessed | Outcome among Those with Episiotomy* | Outcome among Those without Episiotomy* | Authors Conclusions
Country | Episiotomy Type | Approach | Definitions Provided
Dyspareunia at 3 Months
Rockner et al., 1988^80^ | Prospective cohort | 3 months | Current dyspareunia | 31/154 (20%) | 9/46 (20%) | No significant difference
Sweden | Mediolateral: 88% | Questionnaire (method not specified) | (not defined)
Larsson et al., 1991^81^ | Prospective cohort | 2 to 3 months | Dyspareunia | 66/410 (16%) | 69/627 (11%) | None made regarding sexual function
Sweden | Mediolateral: 98% | In-person interview with midwife | (not defined)
Sartore et al., 2004^71^ | Prospective cohort | 3 months | Current dyspareunia (not defined); classified as “absent, mild, moderate, severe”; reported Y/N | 20/254 (7.9%) | 9/265 (3.4%) | RR: 2.43 (1.08, 5.45)
Italy | Mediolateral: 100% | In-person interview
Dyspareunia within 3 Months
Rockner et al., 1988^80^ | Prospective cohort | 3 months | Any dyspareunia | 68/154 (44%) | 20/46 (43%) | No significant difference
Sweden | Mediolateral: | Questionnaire (method not specified) | (not defined)
| 88%
Karacam and Eroglu, 2003^72^ | Prospective cohort | 3 months | Any dyspareunia (not defined) | 31/48 (64.58%) | 26/48 (54.17%) | No significant differences between groups in rate of mothers' dyspareunia
Turkey | Mediolateral: | Telephone interview
| 100%

Note: RR, relative risk; Y, yes; N, no.

Randomized Controlled Trials. Two publications present results from RCTs of restrictive compared to liberal use of episiotomy; the investigators used an intention-to-treat analysis. These trials provide evidence about the long-term effects of a particular type of policy about episiotomy use on the sexual outcomes of populations of women. The earlier of the two trials was conducted in the United Kingdom in 1982.^23^ Perineal outcomes in the West Berkshire Perineal Management Trial differed clinically and statistically by group. Among women in the liberal-use group, 51.4 percent had had an episiotomy (all mediolateral), 6.0 percent had an episiotomy with extension to third- or fourth-degree laceration, 24.5 percent had a spontaneous perineal tear only, and 24.3 percent had no perineal trauma. In the restrictive-use group, 10.2 percent had an episiotomy, 1.2 percent had an episiotomy with extension, 55.8 percent had a spontaneous perineal tear only, and 33.9 percent had no trauma. By 1 month after delivery, 37 percent of the restrictive group and 27 percent in the liberal group had resumed sexual intercourse (P < 0.01). The proportion of women with resumption of intercourse by 3 months, current dyspareunia at 3 months, or any dyspareunia within the 3 months of followup did not differ significantly by group.^23^ By the third year of followup, the likelihood of “ever suffering painful intercourse” remained comparable across groups.^33^

The trial conducted by Klein and colleagues in Canada also found less episiotomy use in the restrictive group with higher rates of spontaneous lacerations.^29^ Among women in the liberal-use group, 67.2 percent had an episiotomy (midline), 14.2 percent had an episiotomy with extension to third- or fourth-degree laceration or sulcal tear high in the vaginal vault, 12 percent had a spontaneous perineal tear only, and 6.6 percent had no perineal trauma. In the restrictive-use group, 42 percent had an episiotomy, 15 percent had an episiotomy with extension, 35 percent had a spontaneous perineal tear only, and 7.5 percent had no perineal trauma. Women in the restrictive group resumed intercourse an average of 1 week earlier that those in the liberal group; however, all other measures of sexual function were equivalent by 3 months.^29^

These trials were designed primarily to assess rates of episiotomy and perineal trauma under different strategies to guide use of episiotomy. Restrictive use, as addressed in KQ 1, was hypothesized to result in less severe trauma among women with lacerations and in a higher proportion of women without perineal lacerations. If women experienced less perineal trauma, this improvement would be expected to be associated with less pain with future intercourse. Therefore, the Canadian trial team also undertook a separate analysis of the relationship between the degree of perineal trauma and sexual function. Using data from the 3-month interviews, they regrouped participants by perineal status that was systematically documented at the time of the index birth, creating a prospective cohort. In this cohort analysis, women with an intact perineum were most likely to have resumed intercourse by 6 weeks (76.5 percent), followed by those with spontaneous tears (62.5 percent), episiotomy alone (61.7 percent) and third- and fourth-degree lacerations (55.4 percent). Women with episiotomy had the slowest return to intercourse. Pain with the first intercourse followed a similar pattern.^34^

Prospective Cohorts. Signorello and colleagues were the sole research team from the United States to assess sexual function.^38^ They documented trauma at the time of childbirth by chart review and followed up women at 6 months. They reported that the degree of trauma, rather than whether it resulted from episiotomy or spontaneous tear, was the primary determinant of pain with intercourse at 6 months. In prospective 6-month data, the risk of pain with intercourse was higher among those with second-degree trauma compared to no trauma (RR 1.3, 95% CI, 0.8–2.2), and highest with third- and fourth-degree trauma (RR 1.5; 95% CI, 0.7–3.5), although not statistically significant.

These cohort studies do not find large or statistically significant differences in sexual function. Only one study identified lasting differences in dyspareunia at 3 months. Sartore and colleagues reported that women with episiotomy were more than twice as likely to have pain than those without episiotomy.^71^ An aggregate estimate for current dyspareunia at 3 months can be estimated from three of the cohort studies using 818 women with episiotomy and 938 women without episiotomy.^71,^ ^80,^ ^81^ We used meta-analysis techniques to calculate an aggregate risk ratio for the combined population of the prospective cohorts. In these studies, women with episiotomy were 54 percent more likely to have pain with intercourse 3 months after delivery (RR: 1.54, 95% CI: (I: 1.19, 2.00), with an absolute increase in risk of dyspareunia of 5 percent among women who had episiotomy: 14.3 percent versus 9.3 percent. Similar estimates for the two studies that assessed any dyspareunia during the 3 months after childbirth reveal no difference in the overall probability of having had painful intercourse. Among 50 women with episiotomy, 65 percent have had pain with intercourse and 50 women without episiotomy, 54 percent had had pain with intercourse but this was not statistically significant.^72^