# Methods

In this chapter, we document the procedures that the RTI International-University of North Carolina Evidence-based Practice Center (RTI-UNC EPC) used to develop this comprehensive evidence report on episiotomy. We first describe our strategy for identifying articles relevant to our key questions, our inclusion/exclusion criteria, and the process we used to abstract relevant information from the eligible articles and generate our evidence tables. We also discuss our criteria for grading the quality of individual articles and the strength of the evidence as a whole. Finally, we explain the peer-review process.

## Literature Review Methods

### Inclusion and Exclusion Criteria

Our inclusion and exclusion criteria, documented in Table 1, were relatively complex. The reason is largely that criteria for study design differed for each key question based on the sufficiency and quality of evidence. Key Questions 1 and 3 have been more commonly examined in randomized controlled trials (RCTs); thus, we elected to limit the searches to RCTs. Key Questions 2, 4, and 5 have been studied less extensively in trials; therefore, we searched for both RCTs and prospective cohort studies.

Table 1. Inclusion/exclusion criteria

Category | Criteria
Study population | Humans
Study settings and geography | Inpatient, outpatient, home; all geographical locations subject to publication language and study design criteria
Time period | 1950 through 2004
Publication languages | English only
Sample size | N greater than or equal to 40
Admissible evidence (study design and other criteria) | Original research studies that provide sufficient detail regarding methods and results to enable use and adjustment of the data and results
| [underlined: For studies on KQ 1 and KQ 3]
| RCTs: double-blinded and single-blinded designs
| [underlined: For studies on KQ 2, KQ 4 and KQ 5]
| RCTs: double-blinded and single-blinded designs
| Non-RCTs: prospective cohort studies
| Relevant outcomes must be able to be abstracted from data presented in the papers

We excluded studies that (1) did not report on women of reproductive age; (2) were published in languages other than English; (3) did not report information pertinent to the key clinical questions; (4) had fewer than 40 subjects; and (5) were not original studies (although we did include systematic reviews and meta-analysis in our discussion).

### Literature Search and Retrieval Process

Databases. We used multifaceted search strategies to include all the current valid research on the key questions. We used standard electronic databases: MEDLINE^®^, Cochrane Collaboration resources, and the Cumulative Index to Nursing and Allied Health Literature (CINAHL^®^). We also undertook hand-searches of the reference lists of relevant articles to make sure that we were not missing any relevant studies. We consulted with the Technical Expert Advisory Group (TEAG) about any studies or trials that are currently under way that may not be published yet.

Search Terms. Based on the inclusion/exclusion criteria above, we generated a list of Medical Subject Heading (MeSH) search terms (Tables 2 and 3, also Appendix A *). Our TEAG also reviewed these terms to ensure that we were not missing any critical areas, and this list represents our collective decisions as to the MeSH terms used for all searches. MEDLINE^®^ searches for “Episiotomy” articles are fairly straightforward because the concept is well established and the MeSH indexing is standard. In addition to searching on the MeSH term “Episiotomy,” we also searched for “Labor Stage, Second.”

* Appendixes are provided electronically at http://www.ahrq.gov/clinic/tp/epistp.htm

Table 2. Focused search terms and results from MEDLINE^®^

Search Terms | Results
“Episiotomy” [MeSH] Field: All Fields, Limits: English, Randomized Controlled Trial, Human | 75
“Episiotomy” [MeSH], English, Review, Human | 68
Labor Stage, Second [mh], English, Review, Human | 40
Labor Stage, Second [mh], English, Randomized Controlled Trial, Human | 58

Table 3. Additional search terms and results from MEDLINE^®^

Search Number | Search Terms | Results
#1 | “Episiotomy”[MeSH:NoExp] Field: All Fields, Limits: English, Human | 676
#2 | “Episiotomy” English, Editorial, Human | 14
#3 | “Episiotomy” English, Letter, Human | 58
#4 | “Episiotomy” English, Review, Human | 68
#5 | “Episiotomy” English, Meta-Analysis, Human | 3
#6 | “Episiotomy” English, Practice Guideline, Human | 0
#7 | #2 OR #3 OR #4 OR #5 OR #6 | 140
#8 | #1 NOT #7 | 536
#9 | Repair | 138,222
#10 | #1 AND #9 | 86
#11 | labor stage, second [mh] | 638
#12 | #9 AND #11 | 6
#13 | ((“Episiotomy” OR “pregnancy”) AND (“midline” AND “mediolateral”)) [MeSH:NoExp] Field: All Fields, Limits: English, Human | 11
#14 | ((“Episiotomy” OR “pregnancy”) AND (“sphincter”)) [MeSH:NoExp] Field: All Fields, Limits: English, Human | 3

Figure 2 presents the yield and results from our search. We conducted our initial search in late 2003 and updated it in November 2004. Beginning with a yield of 992 articles, we retained 45 articles that we determined were relevant to address our key questions and met our inclusion/exclusion criteria.

Figure 2. Episiotomy article disposition

Article Selection Process. Once we had identified articles through the electronic database search, review articles, and bibliographies, we examined abstracts of articles to determine whether studies did, in fact, meet our criteria. Two reviewers separately evaluated the abstracts for inclusion or exclusion, using an Abstract Review Form (see Appendix B). If one abstractor concluded that the article should be included in the review, we retained it. Abstracts initially excluded from the study by one reviewer received a second review. The group included three physician health-services researchers—Katherine Hartmann, MD, PhD (Scientific Director); John Thorp, Jr., MD (Co-Investigator); and Gerald Gartlehner, MD, MPH (Study Coordinator); one health-services researcher—Meera Viswanathan, PhD (Study Director); and one junior epidemiologist—Rachel Palmieri, B.S.

Approximately 325 articles required review of the full article because of missing or uninformative abstracts. For the full article review, one reviewer read each article and decided whether it met our inclusion criteria, using a Full Text Inclusion/Exclusion Form (see Appendix B *). A list of articles excluded at the full-article review stage is provided at the end of this report, along with the reasons for their exclusion.

* Appendixes are provided electronically at http://www.ahrq.gov/clinic/tp/epistp.htm

## Literature Synthesis

### Development of Evidence Tables and Data Abstraction Process

The five staff members who conducted this systematic review jointly developed the data abstraction tables (see Appendix B) and evidence tables (Appendix C). These tables were designed to provide sufficient information to enable readers to understand the studies and to determine their quality; we gave particular emphasis to essential information related to our key questions. The format of the evidence tables, which was based on successful designs used for prior systematic reviews, varies somewhat by key questions.

The abstractors trained themselves on entering data into the tables by abstracting several articles and then reconvening as a group to discuss the utility of the table design. The abstractors repeated this process through several iterations until they decided that the tables included the appropriate categories for gathering the information contained in the articles. The design was then reviewed by the TEAG through a teleconference.

All team members shared the task of initially entering information into the data abstraction forms. Another member of the team also reviewed the articles and edited all initial table entries for accuracy, completeness, and consistency. The two abstractors reconciled all disagreements concerning the information reported in the abstraction forms. The full research team met regularly during the article abstraction period and discussed global issues related to the data abstraction process.

We then entered the data from the abstraction forms into evidence tables and once again checked for consistency and accuracy.

The final evidence tables are presented in their entirety in Appendix C. Entries in the tables are listed by publication date. A list of abbreviations used in the tables appears at the beginning of that appendix.

### Quality and Strength of Evidence Evaluation

Rating the Quality of Individual Articles. The RTI-UNC EPC's approach to assessing the quality of individual articles was developed based on the domains and elements recommended in the evidence report by West and colleagues, Systems to Rate the Strength of Scientific Evidence. ^26^ We developed different rating schemes for RCTs and prospective cohort studies.

For RCTs, we rated studies on the following criteria (see Appendix B for the RCT Quality Rating Form).

- 1. Randomization Approach and Implementation: This item judged whether the approach described a valid method of randomization, whether allocation concealment was achieved, and whether balance was documented across study groups.
  Approach: Articles that assigned the groups in a manner inconsistent with true randomization methods automatically received a poor rating for this category and overall. Articles that merely stated that they “randomly assigned” the groups and had either no balance or did not report on balance received a poor rating. Articles with no documentation of concealment were rated poor. Those with potentially inadequate concealment methods were rated poor if the study had poor balance of allocation or if balance was not documented in the paper. Those with potentially poor concealment were rated fair if they documented good balance.
- 2. Masking: This item was relevant only to Key Question (KQ) 3. For KQ 1, masking of the birth attendant is not feasible and for KQ 2, masking the kind of episiotomy the women received was not possible.
  Approach: If the outcome assessors and participants were adequately masked within the possibilities of the study design, we rated the category as good. If there was a mix of masking among the outcomes, we rated the category as fair. If masking was not done at all and not attempted, we rated the category as poor. In the event that the article did not report on masking, we noted this point in the quality assessment table and counted it against the trial in the overall quality rating.
- 3. Operational Definitions and Measurements: This item judged the quality of the operational definitions of the outcomes (i.e., were they adequately described) and whether they were adequately collected (i.e., was the method sufficient and appropriate).
  Approach: If a primary outcome was identified, we gave it more weight in its contribution to this category's score. Otherwise, we rated this category on the basis of an average across all outcomes and the ability to define and measure them. Good definitions and measurement include the following: visual analog scale, detailed Likert scale, detailed time points in question, details about what was asked of the patient, medical chart abstractions, and clinical examination or assessment. If an article simply stated an outcome, such as “perineal pain,” and gave no further explanations about it, we rated the category in the fair-to-poor range, depending on how the study collected the information.
- 4. Post-Randomization Exclusions: This item captured how many post-randomization exclusions were explicitly stated.
  Approach: In typical randomized trials, intention to treat analysis is expected. Some investigators represented in this literature enrolled women during prenatal care rather than on labor and delivery in an effort to get a representative sample of prenatal patients. We note exclusions as appropriate when individual gave birth at a hospital not participating in the study, or when participants had outcomes that made them ineligible to participate in the trial such as preterm birth or cesarean birth. Any other exclusions after randomization were considered inappropriate.
- 5. Loss to Followup: This item collected percentages of followup at every time point in the study at which data were collected; we used it to determine if followup was adequate.
  Approach: An average of followup percentages for short-term and long-term followup contributed to this category. In general, we considered followup greater than or equal to 90 percent in the short term and 80 percent in the long term to be good.
- 6. Statistical analysis: This factor included whether the investigators conducted the study in an appropriate manner and took the effect of multiple comparisons into account. This item also reviewed the study's use of multivariate statistical techniques and/or participant restriction or stratification to control for confounding.
  Approach: This category is not included on the quality assessment form because of the nature of reporting in journals dating back to 1974. P-values were sufficient for reporting in the past, whereas point estimates, tests for homogeneity, stratification, and confidence intervals are more widely reported now. Although this category did not explicitly contribute to the overall quality rating, we used it for articles that were on the border between categories.

For RCTs, the two article abstractors independently rated each article on each of the first five categories as indicated by the quality assessment form (Appendix B *). A third reviewer flagged studies with differences in scoring on individual components. We reconciled these differences by consensus. We then created a composite rating. If a study had poor randomization approach or implementation with a fatal flaw (e.g., lottery cards), we rated it as poor. For all other scores, we gave each item equal weight. Specifically, studies that received good ratings on all categories were rated as good studies overall. If a study received one or two fair or poor ratings, or the equivalent of a deficiency, it was rated as an overall fair-quality study. Studies with three or more fair ratings or a poor randomization design or implementation with a fatal flaw were rated poor-quality studies.

* Appendixes are provided electronically at http://www.ahrq.gov/clinic/tp/epistp.htm

For classifying the quality of prospective cohort studies included for KQs4 and 5, we assessed the following factors:

- 1. Study population: We sought documentation in the publication of the degree to which the study population was representative of women with uncomplicated spontaneous vaginal births in the study facilities or broader population sampled.
- Approach: To receive a rating of good for this component of study design and conduct, we required a study to describe clearly (1) the base population from which cohort participants were sought, (2) the number of women in that base population (a denominator), (3) clear inclusion and exclusion criteria, and (4) the proportion of eligible women who were ultimately enrolled in the cohort.
- Studies lacking only items (2) and (4) were classified as fair, and studies lacking items (1) or (3) with any combination of other missing documentation were rated as poor with respect to documentation of the study population.
- 2. Measures: We sought documentation in the publication of four components of quality of measurements. The first was specification of whether the measure was a primary or secondary measure for the study as noted in any portion of the paper. The second was a clear description of the measures used that is sufficient to allow replication of the measure (e.g., visual analog scale, McGill Pain Score). We accepted references to methods described more fully in other publications as documentation if the reference in fact provided details. The third component was a clear description of how the measure was obtained and by whom if, applicable (e.g., telephone interview, face-to-face interview, mailed questionnaire). The fourth was a clear specification of the time interval in which the data were collected with respect to the index birth.
- Approach: We classified studies that achieved all four document requirements for the measurement of relevance to the key question as having good implementation of the measures component. We classified studies as fair for this component if item (1) was unclear or not noted and if this was the only limitation. If any other item was missing, we considered the quality of documentation of measures to be poor. Of note, a given study could be classified as good for one key question (e.g., the key question about sexual function), while getting a fair rating for another measure that related to a different key question.
- 3. Loss to followup: If data from more than one time interval were reported, we sought documentation of the these followup measures: (1) the number of participants in the sample at the time of followup, (2) analysis of how respondents differed from nonrespondents if loss exceeded 20 percent, and (3) absolute loss to followup by time interval.
- Approach: We rated a study as good quality if the research team accomplished each of the above measures and had ≤ 20 percent loss to followup at 3 months and beyond. A study was rated fair if the investigators accomplished items (1) and (2), had no apparent response bias as investigated by comparison of baseline characteristics, and had up to 30 percent loss to followup; or if they had between 20 percent and 25 percent loss to followup without documentation of comparability. We rated a study as poor for this component if it had more than 30 percent loss to followup or more than 25 percent loss without comparison for response bias.
- 4. Analysis: We sought four tiers of documentation: (1) thorough enumeration of the number of cohort participants, the characteristics of their birth experience and perineal status, and general descriptive characteristics such as parity and number of prior vaginal births in cohorts that included multiparous women; (2) assessment of confounding and modifying factors by bivariate analysis, stratified analysis, or multivariable modeling; (3) reporting of adjusted estimates for main effects that took into account identified confounding or modifying factors (stratified or separate analyses were acceptable for simple constructs); and (4) presentation of adjusted results with a measure of statistical precision such as a confidence interval or P-value.
- Approach: We rated a study as having a good analysis implementation if all of these elements were present. Missing or limited detail for item (1) resulted in a fair rating if this was the only deficit; similarly, we rated a study fair if it was missing or providing only limited detail for item (2) if subsequent multivariable modeling implied that the step had been completed and all other items were present. Missing items (3) or (4) or any other two or more items in combination resulted in a poor rating.

Grading the Strength of Available Evidence. Our scheme follows the criteria applied by Berkman et al.^27^ That system included three domains: quality of the research, quantity of studies (including number of studies and adequacy of the sample size), and consistency of findings. The four senior staff members assigned grades by consensus.

We graded the body of literature applicable to each of the four components of the two key questions separately and present our findings in Chapter 4. The possible grades in our scheme are as follows:

- I. The evidence is from studies of strong design; results are both clinically important and consistent with minor exceptions at most; results are free from serious doubts about generalizability, bias, or flaws in research design. Studies with negative results have sufficiently large samples to have adequate statistical power.
- II. The evidence is from studies of strong design, but some uncertainty remains because of inconsistencies or concern about generalizability, bias, research design flaws, or adequate sample size. Alternatively, the evidence is consistent but derives from studies of weaker design.
- III. The evidence is from a limited number of studies of weaker design. Studies with strong design either have not been done or are inconclusive.
- IV. No published literature.

## External Peer Review

As is customary for all evidence reports and systematic reviews done for the Agency for Healthcare Research and Quality (AHRQ), the RTI-UNC EPC requested review of this report from a wide array of outside experts in the field and from relevant professional societies and public organizations. AHRQ also requested review from its own staff and appropriate federal agencies. We received 18 responses; the 17 individuals listed in Appendix D * gave us permission to acknowledge them. We compiled all comments and addressed each one individually, revising the text as appropriate.

* Appendixes are provided electronically at http://www.ahrq.gov/clinic/tp/epistp.htm