# Appendix C Evidence Tables

## Glossary for Evidence Tables

AP | antepartum
BMI | body mass index
CC | chromic catgut
cm | centimeter
cont | continuous
deg | degree
diff | difference
ext | extension
G | group
g | grams
GA | gestational age
GP | General Practitioner
hrs | hours
instr | instrumental
interr | interrupted
int | interview
L&D/MU | Labor and Delivery Maternity Unit
LSCS | lower segment cesarean section
mL | millileter
mm | millimeter
mod | moderate
mos | months
N | number
NA | not applicable
NR | not reported
NS | not significant
OR | odds ratio
PFMS | pelvic floor muscles
PGA | polyglycolic acid
PNC | prenatal care
pt | point
quest | postal questionnaire, self-report questionnaire
RCT | randomized controlled trial
RR | relative risk/risk ratio
SD | standard deviation
sec | second (adjective)
SHO | senior house officer
sig diff | significant differences
spont | spontaneous
subcut | subcuticular
transcut | transcutaneous
UK | United Kingdom
VAS | Visual Analog Scale
wks | weeks
yr | year

Evidence Table 1. Key Question 2: Liberal versus restrictive use of episiotomy

Study Characteristics | Demographic Characteristics | Labor, Delivery, and Repair Characteristics | Perineal Trauma Outcomes | Pain Outcomes | Sexual Function Outcomes | Repair and Healing Outcomes | Incontinence and Pelvic Floor Outcomes | Other Outcomes | Quality and Comments
Author | Age (mean ± SD) | Delivery by | Third/fourth deg tear | [underlined: Short term: 10 days] | [underlined: Short term: 1 mo] | [underlined: Short term] | [underlined: Short term] | [underlined: Short term] | Overall quality
Sleep, 1984 | G1: 26yrs ± 5.3 | Student and midwife | (ext through anal sphincter or through to the rectal mucosa or to the upper third of vagina) | Mild pain | Recommencement of sexual intercourse | Required suturing | Involuntary loss of urine (3 mos) | NR | Good
Setting | G2: 26.6yrs ± 5.2 | G1: 35.9% | G1: 1 | G1: 14.6% | G1: 27% | G1: 78% | G1: 19% | [underlined: Long term] | Randomization approach and implementation
UK | Primiparous | G2: 35.2% | G2: 4 | G2: 14.1% | G2: 37% | G2: 69% | G2: 19% | NR | Good
Study design | G1: 46.3% | Midwife | Anterior labial tears | Mod pain | X^2^ = 8.67 | X^2^ = 9.99 | NS | | Masking
RCT | G2: 40.4% | G1: 32.1% | G1: 17.3% | G1: 7.8% | P < 0.01 | P = < 0.01 | [underlined: Long term] | | Good+
Inculsion criteria | | G2: 30.1% | G2: 26.3% | G2: 7.5% | [underlined: Long term: 3 mos] | [underlined: Long term] | NR | | Operator performing repair blind to allocation
• Live singleton fetus of at least 37 wks GA | | Obstetrician | X^2^= 11.29 | Severe pain | Resumed sexual intercourse | NR | | | Mother in most cases blind to allocation
• Presented cephalically | | G1: 1.8% | P < 0.00l | G1: 0.2% | 90% overall, similar within groups | | | | Operational definitions and measures
• Spont vaginal delivery expected at end of sec stage labor | | G2: 8% | RR = 1.52 | G2: 0.9% | Dyspareunia | | | | Good
Exclusion criteria | | Other (“sister”) | (1.19–1.94) | All levels: | G1: 18% | | | | Post-randomization exclusions
• Elected episiotomy | | G1: 31.3% | | G1: 22.6% | G2: 22% | | | | No
• No consent | | G2: 32.7% | | G2: 22.6% | Dyspareunia | | | | Retention of participants
• Private patient | | Estimated GA | | X^2 ^= 1.91 NS | “At some time” | | | | Good
• Precipitate delivery | | G1: 39.8wks ± 1.2 | | [underlined: Long term: 3 mos] | G1: 51% | | | | 10 days
Groups | | G2: 39.8wks ± 1.2 | | Mild pain | G2: 52% | | | | G1: 446 (89%)
G1: Liberal (instructed to “try to prevent a tear”) | | Birthweight (mean+ SD) | | G1: 5.7% | [underlined: Long term] | | | | G2: 439 (88%)
G2: Restrictive (instructed to “try to avoid episiotomy and restrict episiotomy to fetal indications”) | | G1: 3367g ± 438 | | G2: 4.6% | NR | | | | Total: 885 (89%)
N at enrollment | | G2: 3393g ± 4.48 | | Mod pain | | | | | 3 mos
G1: 502 | | Episiotomy rate (all mediolateral) | | G1: 1.8% | | | | | G1: 457 (91%)
G2: 498 | | G1: 51.4% | | G2: 2.5% | | | | | G2: 438 (88%)
Total: 1000 | | G2: 10.2% | | Severe pain | | | | | Total: 895 (90%)
Followup | | | | G1: 0.2%
10 days to 3 mos | | | | G2: 0.5%
| | | | All levels
| | | | G1: 7.7%
| | | | G2: 7.6%
| | | | X^2^=2.58 NS
Author | Age | Mode of delivery | Intact perineum | [underlined: Short term] | [underlined: Short term] | [underlined: Short term] | [underlined: Short term] | [underlined: Short term] | Overall quality
Harrison, 1984 | NR | G1: NR | G1: NR | NR | NR | NR | NR | NR | Poor: Not possible to see outcome as randomized analysis does not take advantage of having done a trial
Setting | Primiparous | G2: | G2: 21% | [underlined: Long term] | [underlined: Long term] | [underlined: Long term] | [underlined: Long term] | [underlined: Long term] | Randomization approach and implementation
Ireland | G1: 100% | • Spont: 92% | First deg tears | NR | NR | NR | NR | NR | Poor: No detail about method, allocation, concealment or balance
Study design | G2: 100% | • Vacuum: 2% | G1: 0 to 2% | Comment | | | | | Masking
RCT | | • Forceps: 3% | G2: 25% | *All analyses were completed on a subset of participants: 40 participants from G1 who had a spont vertex delivery and 37 participants from G2 who had sustained a sec deg tear during delivery (these participants had not undergone episiotomy). Outcomes analyzed do not address differences between routine and restrictive policies of episiotomy and are not reported here | | | | | NR
Inculsion criteria | | Birthweight (mean ± SD) | Sec deg tears | | | | | | Operational definitions and measures
• 16 yrs and older | | NR | G1: None | | | | | | Good
• ≥ 38 wks GA | | Episiotomy rate | G2: 47% | | | | | | Post-randomization exclusions
• Vaginal delivery | | G1: 44.9% (40/89) | Third deg tears | | | | | | Yes
• Primigravid | | G2: 7.6% (7/92) | G1: 6% | | | | | | Retention of participants
Exclusion criteria | | Suture method and type | G2: 0% | | | | | | Good
• Psychiatric or medical condition | | G1 andG2: Mattress sutures with CC | | | | | | | G1: NR
• Eclampsia | | | | | | | | | G2: NR
Groups | | | | | | | | | Total: NR
G1: Routine Defined as mediolateral episiotomy routinely conducted
G2: Restrictive Defined as no episiotomy except when medically necessary
N at randomization
G1: 89
G2: 92
Total: 181
Followup
1 to 5 days
Author | Age | Mode of delivery | Among primigravidae participants | [underlined: Short term: 3 days] | [underlined: Short term] | [underlined: Short term: 3 days] | [underlined: Short term] | [underlined: Short term] | Overall quality
House et al., 1986 | NR | G1: | Intact or first deg tear (exam) | Perineal pain (int) | NR | Tenderness (int) (10 pt VAS scale where 1 to 3 minimal, 4 to 6 mod, 7 to 10 severe) | NR | Blood loss | Poor
Setting | Primiparous | • Spont: 86% | G1: 4% | (10 pt VAS scale where 1 to 3 minimal, 4 to 6 mod, 7 to 10 severe) | [underlined: Long term] | G1: | [underlined: Long term] | G1: 214mL ± 162 | Randomization approach and implementation
UK | G1: 68% | • Forceps: 14% | G2: 32% | G1: | NR | •Minimal: 51% | NR | G2: 272mL ± 160 | Good
Study design | G2: 53% | G2: | P < 0.001 | • Mild: 55% | | • Mod: 39% | | P = 0.01 | Masking
RCT | | • Spont: 89% | Sec deg tear (exam) | • Mod: 34% | | • Severe: 10% | | [underlined: Long term: 3 mos] | NR
Inculsion criteria | | • Forceps: 11% | Defined: Laceration involving more than superficial mucosa requiring more than three sutures to repair | • Severe: 11% | | G2: | | Prolapse, details NR but NS | Operational definitions and measures
NR | | Duration of sec stage labor (mean ± SD) | G1: 17% | G2: | | • Minimal: 79% | | | Good
Exclusion criteria | | G1: 53min ± 41 | G2: 36% | • Mild: 68% | | • Mod: 18% | | | Post-randomization exclusions
• Labor at < 37 wks pregnant | | G2: 46min ± 40 | P < 0.05 | • Mod: 22% | | • Severe: 3% | | | Yes: loss of multigravidae participants from early discharge, loss to immediate postnatal follow-up by one of the authors. The method is adequate, describes concealment and reports balance in multiple factors except imbalance that resulted from Post-randomization exclusions
• Presentation other than vertex | | Birthweight (mean ± SD) | Third deg tear (exam) | • Severe: 10% | | P = 0.001 | | | Retention of participants
• Cesarean section | | G1: 3400g ± 429 | Defined: Involved anal sphincter | [underlined: Short term: 6 wks] | | Infection (exam) | | | [underlined: Short term: 3 days]
• Forceps delivery | | G2: 3282g ± 399 | G1: 0% | No diff, details NR | | G1: 4% | | | Good
Groups | | Episiotomy rate (all mediolateral) | G2: 0% | [underlined: Long term: 3 mos] | | G2: 5% | | | G1: 71 (100%)
G1: Liberal | | G1: 69% | NS | No diff, details NR | | Primary healing (exam) | | | G2: 94 (100%)
Defined: Received standard current management Episiotomy was performed if perineum appeared too rigid to permit delivery without laceration | | G2: 18% | Among multigravidae participants | | | Defined: Complete skin apposition | | | Total: 165 (100%)
G2: Restricted Defined: | | | Intact or first deg tear (exam) | | | G1: 92% | | | [underlined: Short term: 6 wks]
Episiotomy not performed specifically to prevent laceration | | | G1: 26% | | | G2: 88% | | | Good
N at enrollment | | | G2: 54% | | | Secondary healing (exam) | | | G1: NR
G1: 71 | | | P < 0.05 | | | Defined: Significant granulation | | | G2: NR
G2: 94 | | | Sec deg tear (exam) | | | G1: 8% | | | Total: 88 (53%)
Total: 165 | | | Defined: Laceration involving more than superficial mucosa requiring more than three sutures to repair | | | G2: 12% | | | [underlined: Long term: 3 mos]
Followup | | | G1: 22% | | | [underlined: Long term] | | | Poor
3 mos (no data in article) | | | G2: 43% | | | NR | | | G1: NR
| | | NS | | | | | | G2: NR
| | | Third deg tear (exam) | | | | | | Total: 88 (53%)
| | | Defined: Involved anal sphincter
| | | G1: 4%
| | | G2: 0%
| | | NS
Author | Age (mean ± SD) | Episiotomy rate (all median) | Intact perineum | [underlined: Short term: 1 day] | [underlined: Short term: 3 mos] | [underlined: Short term] | [underlined: Short term: 3 mos] | [underlined: Short term: 3 mos] | Overall quality
Klein et al., 1992 | G1a: 27.9yrs ± 3.9 | G1a: 81% | Measured at delivery | G1a: 1.8 ± 0.8 | Time to resumption of sexual intercourse | NR | Urinary incontinence | Pelvic floor function | Fair
Setting | G1b: 27.9yrs ± 4.4 | G1b: 52% | G1a: 12 (6.6%) | G1b: 1.7 ± 0.8 | NS | [underlined: Long term] | G1a: 26 (14.5%) | NS | Randomization approach and implementation
Canada | G2a: 31.0yrs ± 3.7 | G2a: 47% | G1b: 13 (7.5%) | G2a: 1.3 ± 0.8 | Mean degree of pain at resumption of sexual intercourse | NR | G1b: 35 (21.1%) | Perineal bulging | Good
Study design | G2b: 30.3yrs ± 9.1 | G2b: 31% | OR = 1.16 | G2b: 1.3 ± 0.9 | NS | | P = 0.11 | NS | Masking
RCT | Primiparous | Birthweight (mean +SD) | (0.48, 2.8) | [underlined: Short term: 2 days] | Female sexual satisfaction | | G2a: 34 (21.5) | [underlined: Long term] | Fair
Inculsion criteria | G1: 100% | G1a: 3325g ± 416 | G2a: 32 (19.3%) | G1a: 1.3 ± 0.7 | NS | | G2b: 22 (12.9) | NR | Operational definitions and measures
• 18 to 40 yrs old | G2: 100% | G1b: 3377g ± 432 | G2b: 54 (30.7%) | G1b: 1.4 ± 0.8 | [underlined: Long term] | | P = 0.04 | | Good for short term
• Parity of 0, 1, 2 | Previous episiotomy | G2a: 3496g ± 449 | OR = 1.85 | G2a: 0.9 ± 0.7 | NR | | [underlined: Long term] | | Poor for long term
• Single fetus | NS | G2b: 3467g ± 497 | (1.1, 3.2) | G2b: 0.9 ± 0.8 | | | NR | | Post-randomization exclusions
• Spoke English or French | Education (yrs) (sig diff NR) | GA | Sec degree tear measured at delivery | [underlined: Short term: 10 days] | | | | | Cesarean only
• Low medical and obstetrical risk | G1a: 15.4 | NS | G1a: 22 (12.6%) | G1a: 0.5 ± 0.5 | | | | | Retention of participants
Exclusion criteria | G1b: 15.0 | | G1b: 61 (35.3%) | G1b: 0.5 ± 0.5 | | | | | Fair
• Prematurity (gestation < 37 wks) | G2a: 15.4 | | OR = 3.99 | G2a: 0.3 ± 0.4
• Fetal distress | G2b: 15.0 | | (2.2, 7.1) | G2b: 0.3 ± 0.5
• Cesarean deliveries | Stable Relationship | | G2a: 56 (33.7%) | [underlined: Long term]
• Planned forceps | Diff NS | | G2b: 68 (38.6%) | NR
• Medical condition developed late in pregnancy | Employment
Groups | Diff NS
G1: Primiparous
G1a: Liberal (attempted to avoid a tear/separated by parity)
G1b: Restricted (attempted to avoid an episiotomy/ separated by parity)
G2: Multiparous
G2a: Liberal
G2b: Restricted
N at enrollment
G1a: 184
G1b: 175
G2a: 166
G2b: 178
Total: 703
Followup
1 day to 3 mos
Author | Age | Mode of delivery | Third deg tear (exam) | [underlined: Short term: Discharge] | [underlined: Short term] | [underlined: Short term: Discharge] | [underlined: Short term] | [underlined: Short term] | Overall quality
Argentine, 1993 | NR | G1: Operative: 3% | Defined: Vaginal middle and/or upper third tear | Perineal pain (int) | NR | Hematoma | NR | NR | Fair
Setting | Primiparous * | G2: Operative: 2% | G1: 2.2% | G1: 43% | [underlined: Long term] | (exam) | [underlined: Long term] | [underlined: Long term] | Randomization approach and implementation
Argentina | G1: 60% | Oxytocin at sec stage | G2: 2.9% | G2: 31% | NR | G1: 4% | NR | NR | Good+
Study design | G2: 59% | G1: 59% | RR = 1.38 | RR = 0.72 | | G2: 4% | | | Masking
RCT | Previous episiotomy | G2: 58% | (0.84, 2.21) | (0.65, 0.81) | | RR = 0.96 | | | Fair
Inculsion criteria | G1: 33% | Birthweight (mean ± SD) | NS | [underlined: Long term] | | (0.65, 1.42) | | | Operational definitions and measures
• Uncomplicated labor at 37 to 42 wks | G2: 34% | G1: 3244g ± 418.3 | Severe perineal trauma (exam) | NR | | NS | | | Fair
• Nulliparous or primiparous gestation | *Note: The article identifies the women, at the time of gestation, as nulliparous or primiparous. For our purposes, the nullips from the article are our primips (meaning this was their first birth). | G2: 3244g ± 427.3 | Defined: Ext through the anal sphincter and/or the anal or rectal mucosa; third deg and fourth deg lacerations | | | [underlined: Short term: 7 days] | | | Post-randomization exclusions
• Single fetus in cephalic presentation | | Cephalic perimeter | G1: 1.8% | | | Healing complications (exam) | | | No
• No history of cesarean delivery or severe perineal tears | | (mean ± SD) | G2: 1.4% | | | G1: 30% | | | Retention of participants
Exclusion criteria | | G1: 34.2cm ± 15.5 | RR = 0.78 | | | G2: 21% | | | Good
NR | | G2: 34.3cm ± 17.5 | (0.40, 1.54) | | | RR = 0.69 | | | At discharge
Groups | | Episiotomy rate (all mediolateral) | NS | | | (0.56, 0.85) | | | G1: NR (93%)
G1: Routine | | G1: 83% | Anterior perineal trauma (exam) | | | Local infection (exam) | | | G2: NR (93%)
Defined: Performed episiotomy according to hospital's policy prior to the trial | | G2: 30% | G1: 8% | | | G1: 2% | | | Total: NR (93%)
G2: Selective | | Suture type | G2: 19% | | | G2: 2% | | | 7 days
Defined: Tried to avoid episiotomy unless fetal distress or severe perineal trauma judged to be imminent | | NR | RR = 2.36 | | | RR = 0.91 | | | G1: NR (43%)
N at randomization | | Suture method | (1.89, 2.94) | | | (0.37, 2.21) | | | G2: NR (43%)
G1: 1298 | | NR | | | | NS | | | Total: NR (43%)
G2: 1308 | | | | | | Dehiscence
Total: 2606 | | | | | | (exam)
Followup | | | | | | G1: 9%
7 days | | | | | | G2: 5%
| | | | | | RR = 0.45
| | | | | | (0.30, 0.75)
| | | | | | [underlined: Long term]
| | | | | | NR
Author | Age (mean ± SD) | Mode of delivery | Intact perineum (exam) | [underlined: Short term] | [underlined: Short term] | [underlined: Short term] | [underlined: Short term] | [underlined: Short term] | Overall quality
Eltorkey and Nuaim, 1994 | G1: 21.0yrs ± 3.5 | G1: | G1: 7% | NR | NR | NR | NR | NR | Fair
Setting | G2: 21.2yrs ± 3.9 | • Spont: 95% | G2: 28% | [underlined: Long term] | [underlined: Long term] | [underlined: Long term] | [underlined: Long term] | [underlined: Long term] | Randomization approach and implementation
Saudi Arabia | Primiparous | • Forceps: 3% | OR = 5.17 | NR | NR | NR | NR | NR | Good
Study design | G1: 100% | • Vacuum: 2% | P < 0.001 | | | | | | Masking
RCT | G2: 100% | G2: | No posterior trauma (exam) | | | | | | NR
Inculsion criteria | | •Spont: 96% | G1: 25% | | | | | | Operational definitions and measures
• Live singleton fetus of at least 37 wks GA | | • Forceps: 2% | G2: 40% | | | | | | Good
• Presenting cephalically | | • Vacuum: 2% | P < 0.05 | | | | | | Post-randomization exclusions
• No important medical or psychiatric illness | | Anesthesia at delivery | No anterior trauma (exam) | | | | | | No
• Spont vaginal delivery expected toward the end of sec stage labor | | G1: | G1: 82% | | | | | | Retention of participants
Exclusion criteria | | •Epidural: 14% | G2: 88% | | | | | | Good
NR | | • Pethidine: 56% | NS | | | | | | 1 to 5 days
Groups | | • Gas and air: 30% | First deg tear | | | | | | G1: 100 (100%)
G1: Elective episiotomy | | G2: | Defined: Injury only to anterior of perineum and related posterior wall of vagina (exam) | | | | | | G2: 100 (100%)
Defined: Performed unless it was considered absolutely unnecessary | | • Epidural: 20% | G1: 3% | | | | | | Total: 100 (100%)
G2: Selective episiotomy | | • Pethidine: 47% | G2: 4%
Defined: Only to prevent extensive perineal laceration or to accelerate labor for fetal distress | | • Gas and air: 33% | NS
N at randomization | | Birthweight (mean ± SD) | Sec deg tear
G1: 100 | | G1: 3080g ± 399 | Defined: Tear up to but not including anal sphincter (exam)
G2: 100 | | G2: 3069g ± 438 | G1: 1%
Total: 200 | | Estimated GA | G2: 8%
Followup | | (mean ± SD) | P < 0.05
Immediate postpartum | | G1: 279days ± 8 | Episiotomy alone (exam)
| | G2: 280days ± 9 | G1: 64%
| | Episiotomy rate (all mediolateral) | G2: 41%
| | G1: 83% | P <0.01
| | G2: 53% | Ext of episiotomy (exam)
| | P < 0.001 | G1: 7%
| | Suture type | G2: 7%
| | G1 andG2: CC | NS
| | Suture method | Para-urethral laceration (exam)
| | G1 andG2: | G1: 4%
| | “Continuous suture was used to repair the vagina, interrupted sutures were used for the deeper tissues and interrupted or subcuticular sutures to repair the perineal skin.” | G2: 5%
| | | NS
| | | Lateral vaginal wall laceration (exam)
| | | G1: 14%
| | | G2: 7%
| | | NS
Author | Age (mean ± SD) | Mode of delivery | Intact perineum (exam) | [underlined: Short term 1 to 5 days] | [underlined: Short term] | [underlined: Short term] | [underlined: Short term] | [underlined: Short term] | Overall quality
Dannecker et al., 2004 | G1: 28.6yrs ± 4.5 | G1: Vacuum: 7% | G1: 10% | Perineal pain during bedrest (int) | NR | NR | NR | NR | Fair
Setting | G2: 28.3yrs ± 5.0 | G2: Vacuum: 18% | G2: 29% | mean ± SD from 100mm VAS | [underlined: Long term] | [underlined: Long term] | [underlined: Long term] | [underlined: Long term] | Randomization approach and implementation
Germany | Primiparous | Anesthesia at delivery | RR = 2.9 | G1: 39 ± 28 | NR | NR | NR | NR | Good
Study design | G1: 100% | G1: Epidural: 72% | (1.2, 6.9) | G2: 22 ± 21 | | | | | Masking
RCT | G2: 100% | G2: Epidural: 63% | P = 0.023 | Diff = 16 (2, 30) | | | | | NR
Inculsion criteria | | Birthweight (mean ± SD) | Minor perineal trauma (exam) | P = 0.025 | | | | | Operational definitions and measures
• Primiparous | | G1: 3535g ± 429 | Defined: First deg tear or intact perineum | Perineal pain during sitting (int) | | | | | Good
• > 34 wks of gestation | | G2: 3313g ± 455 | G1: 13% | mean ± SD from 100mm VAS | | | | | Post-randomization exclusions
• Uncomplicated pregnancy | | Cephalic perimeter | G2: 39% | G1: 69 ± 23 | | | | | Yes: but given enrollment during PNC appropriate. 37 participants did not receive allocated intervention due to cesarean section
• Live singleton fetus | | (mean ± SD) | RR = 2.9 | G2: 51 ± 25 | | | | | (n = 24), preterm labor (n = 4), delivery elsewhere (n = 8), and refusal (n = 1)
• Intention of vaginal delivery | | G1: 35.2cm ± 1.6 | (1.6, 10.5) | Diff = 18 (5, 31) | | | | | Retention of participants *
Exclusion criteria | | G2: 34.8cm ± 1.4 | P = 0.003 | P = 0.009 | | | | | [underlined: Short term: 1 to 5 days]
• Previous surgery at pelvic floor | | Episiotomy rate (all mediolateral) | Third deg tear (Severe perineal trauma) (exam) | Perineal pain during walking (int) | | | | | Good
• Neurological disorder | | G1: 77% | Defined: Ext through the anal sphincter or through rectal mucosa | mean ± SD from 100mm VAS G1: 56 ± 24 | | | | | G1: 31 (52%)
Groups | | G2: 41% | G1: 8% | G2: 37 ± 24 | | | | | G2: 22 (45%)
G1: Liberal | | RR = 0.47 | G2: 4% | Diff = 19 (6, 33) | | | | | Total: 53 (49%)
Defined: Tear imminent, fetal indications | | (0.3, 0.7) | RR = 0.43 | P = 0.005 | | | | | [underlined: Long term]
G2: Restrictive | | P < 0.001 | (0.1, 2.1) | Perineal pain during defecation (int) | | | | | Poor
Defined: Fetal indications only | | Suture type | P = 0.46 | mean ± SD from 100mm VAS | | | | | 48% in postpartum pain measures
N at randomization (randomized at outpatient clinic) | | NR | Anterior trauma (exam) | G1: 36 ± 30 | | | | | Comment
G1: 76 | | Suture method | Defined: Labial and vaginal tears | G2: 21 ± 21 | | | | | *Percentage of participants retained for follow-up in the 1 to 5 days postpartum period was calculated with a denominator of randomized participants who were not post-randomization exclusions.
G2: 70 | | G1 andG2: “ Continuous suture was used to repair the vagina, deeper perineal tissues, subcuticular and skin.” | G1: 42% | Diff = 15 (0, 30)
Total: 146 | | | G2: 55% | P = 0.048
N at delivery | | | RR = 1.1 | [underlined: Long term]
G1: 60 | | | (0.8, 1.8) | NR
G2: 49 | | | P = 0.25
Followup
1 to 5 days

Evidence Table 2. Key Question 2: Midline versus mediolateral episiotomy

Study Characteristics | Demographic Characteristics | Labor, Delivery, and Repair Characteristics | Perineal Trauma Outcomes | Pain Outcomes | Sexual Function Outcomes | Healing Outcomes | Incontinence and Pelvic Floor Outcomes | Other Outcomes | Quality and Comments
Author | Age (mean ± SD) | Mode of delivery | No ext of episiotomy | [underlined: Short term: At discharge] | Outcomes reported apply to KQ5 and are included in Evidence Table 5 | [underlined: Short term discharge] | Outcomes reported apply to KQ4 and are included in Evidence Table 4 | [underlined: Short term] | Overall quality
Coats et al., 1980 | G1: 26.38yrs ± 6.94 | G1 | G1: 54% | “The total pain experienced by the women from their episiotomies was similar.” | | Bruising | | NR | Poor
Setting | G2:26.58yrs ± 7.22 | •Spont: 75% | G2: 79% | “The numbers who required analgesics were also not significantly different.” | | G1 had significantly less bruising than G2 | | [underlined: Long term] | Randomization approach and implementation
UK | Primiparous | •Breech: 1% | Local ext of episiotomy | [underlined: Long term: 3 mos] | | P < 0.001 | | NR | Poor
Study design | G1: 100% | •Forceps: 21% | G1: 22% | “No difference was experienced in the pain felt from their episiotomies.” | | Texture of scar | | | Masking
RCT | G2: 100% | •Venthouse: 4% | G2: 12% | | | G1: | | | NR
Inclusion criteria | | G2 | Ext of episiotomy into sphincter | | | •Thick: 14% | | | Operational definitions and measures
•Primigravidae | | •Spont: 68% | G1: 12% | | | •Normal: 79% | | | Poor
•Admitted to delivery suite | | •Breech: 5% | G2: 7% | | | •Lax: 7% | | | Post-randomization exclusions
Exclusion criteria | | •Forceps: 23% | Ext of episiotomy through sphincter | | | G2: | | | Yes: If episiotomy performed was other than allocated, participant was removed from trial
NR | | •Venthouse: 3% | G1: 6% | | | •Thick: 19% | | | Retention of participants
Groups | | Anesthesia | | | | •Normal: 79% | | | Before discharge
G1: Midline episiotomy | | G1 | G2: 2% | | | •Lax: 2% | | | G1: 163 (100%)
G2: Mediolateral episiotomy | | •Local: 71% | Ext of episiotomy into rectal mucosa | | | NS | | | G2: 244 (100%)
N at randomization | | •Pudendal block: 15% | G1: 6% | | | Appearance of scar | | | Total: 407 (100%)
G1: 163 | | •Epidural: 14% | G2: 0.4% | | | G1: | | | 3 mos
G2: 244 | | •General: 1% | P < 0.001 across all groups | | | •Good: 43% | | | G1: NR
Total: 407 | | G2 | | | | •Fair: 44% | | | G2: NR
Note: Only women who were randomized and underwent episiotomy were reported. Total number randomized, including women who did not undergo episiotomy, was not reported. | | •Local: 65% | | | | •Poor: 13% | | | Total: 311 (76%)
Followup | | •Pudendal block: 14% | | | | G2:
3 mos | | •Epidural: 18% | | | | •Good: 27%
| | •General: 3% | | | | •Fair: 56%
| | GA (mean ± SD) | | | | •Poor: 18%
| | G1: 40.3wks ± 1.78 | | | | P < 0.02 across all groups
| | G2: 40.0wks ± 1.48 | | | | [underlined: Long term]
| | Birthweight (mean ± SD) | | | | NR
| | NR
| | Suture type and method
| | G1 and G2: Subcut skin closure with PGA suture
| | Sutured by G1
| | •SHO: 69%
| | •Registrar: 12%
| | •Student: 19%
| | G2
| | •SHO: 65%
| | •Registrar: 17%
| | •Student: 19%

Evidence Table 3. Key Question 3: Methods of repair - 2-layer versus 3-layer repair

Study Characteristics | Demographic Characteristics | Labor and Delivery Characteristics | Episiotomy and Repair Characteristics | Pain Outcomes | Sexual Function Outcomes | Healing Outcomes | Incontinence and Pelvic Floor Outcomes | Other Outcomes | Quality and Comments
Author | Age (mean ± SD) | Mode of delivery | Episiotomy rate vs. sec deg tear | [underlined: Short term: 48 hrs] | [underlined: Short term: 6 wks] | [underlined: Short term: 48 hrs] | [underlined: Short term] | [underlined: Short term] | Overall quality
Oboro et al., 2003 | G1: 26.3yrs ± 4.0 | G1: | G1: 38% vs. 62% | (int) | (int) | (exam) | NR | NR | Fair
Setting | G2: 26.2yrs ± 3.8 | •Spont: 76% | G2: 36% vs. 64% | Perineal pain | Superficial dyspareunia | Tight stitches | [underlined: Long term] | [underlined: Long term] | Randomization approach and implementation
Nigeria | Primiparous | •Vacuum/forceps: 24% | NS | G1: 57% | G1: 11% | G1: 25% | NR | NR | Good
Study design | G1: 54% | G2: | Duration of repairs (mean time ± SD) | G2: 65% | G2: 18% | G2: 38% | | | Masking
RCT | G2: 52% | •Spont: 77% | G1: 21min ± 11.3 | RR = 0.87 | RR = 0.60(0.42, 0.85) | RR = 0.67 | | | Assessor blind to allocation
Inclusion criteria | NS | •Vacuum/forceps: 23% | G2: 25min ± 12 | (0.78, 0.97) | Deep dyspareunia | (0.54, 0.82) | | | Good
Episiotomy or a sec deg tear during vaginal delivery | Previous perineal repair | Birthweight (mean ± SD) | P < 0.001 | Analgesia use | G1: 8% | Inflammation/ bruising | | | Operational definitions and measures
Exclusion criteria | G1: 31% | G1: 3184g ± 461 | Delivery attendant | G1: 34% | G2: 9% | G1: 7% | | | Fair
•First deg lacerations (rarely require suturing) | G2: 29% | G2: 3188g ± 459 | G1: | G2: 49% | RR = 0.89 | G2: 14% | | | Intention-to-treat analyses
•Third deg tears (need for specialist repair) | NS | NS | •Midwife: 71% | RR = 0.71 | (0.56, 1.41) | RR = 0.50 | | | No
Groups | | | •Medical officers/ consultants: 29% | (0.60, 0.83) | Resumed intercourse pain free | (0.33, 0.77) | | | Post-randomization exclusions
G1: 2-layered: perineal skin not sutured | | | G2: | [underlined: Short term: 14 days] | G1: 26% | Wound gaping (edges > 0.5 cm apart) | | | Yes
G2: 3-layered: skin repair with either subcut or interr number 00 CC or polyglycolic sutures | | | •Midwife: 68% | (int) | G2: 10% | G1: 26% | | | Retention of participants
N at randomization | | | •Medical officers/ consultants: 32% | Perineal pain | RR = 2.54 | G2: 5% | | | 48 hrs
Total: 1077 | | | | G1: 22% | (1.82, 3.55) | RR = 4.96 | | | Total: 1077 (100%)
N at 48 hrs | | | | G2: 29% | Tried but too painful | (3.17, 7.76) | | | 14 days
G1: 417 | | | | RR = 0.77 | G1: 10% | Primary healing (skin edges apposed) | | | Total: 823 (76%)
G2: 406 | | | | (0.61, 0.98) | G2: 22% | G1: 56% G2: 62% | | | 6 wks
Total: 823 | | | | Analgesia use | RR = 0.43 | RR = 0.91 | | | Total: 823 (76%)
Followup | | | | G1: 5% | (0.39, 0.99) | (0.81, 1.02) | | | 3 mos
6 wks | | | | G2: 9% | [underlined: Long term: 3 mos] | Secondary healing (skin edges not apposed but < 0.5 cm apart) | | | Total: 823 (76%)
3 mos | | | | RR = 0.54 | (quest) | G1: 53%
| | | | (0.32, 0.90) | Resumed intercourse < 2 mos | G2: 59%
| | | | [underlined: Short term: 6 wks] | G1: 59% | RR = 0.89
| | | | (int) | G2: 50% | (0.79, 1.01)
| | | | Perineal pain | RR = 1.16 | [underlined: Short term: 14 days]
| | | | G1: 10% | (1.03, 1.32) | (exam/int) | NR | NR
| | | | G2: 15% | Resume intercourse 2 to 3 mos | Suturing removed
| | | | RR = 0.64 | G1: 22% | G1: 5%
| | | | (0.44, 0.93) | G2: 16% | G2: 9%
| | | | Analgesia use | RR = 1.39 | RR = 0.58
| | | | G1: 1% | (1.05, 1.85) | (0.35, 0.96)
| | | | G2: 2% | [underlined: Long term: 3 mos] | Wound breakdown
| | | | RR = 0.56 | Superficial dyspareunia | G1: 3%
| | | | (0.16, 1.89) | G1: 6% | G2: 2%
| | | | [underlined: Long term: 3 mos] | G2: 12% | RR = 1.27
| | | | (quest) | RR = 0.52 | (0.56, 2.85)
| | | | Perineal pain | (0.33, 0.81) | Wound gaping (edges > 0.5 cm apart)
| | | | G1: 1% | Deep dyspareunia | G1: 21%
| | | | G2: 5% | G1: 4% | G2: 17%
| | | | RR = 0.19 | G2: 5% | RR = 1.25
| | | | (0.06, 0.54) | RR = 0.83 | (0.94, 1.67)
| | | | Analgesia use | (0.44, 1.56) | [underlined: Short term: 6 wks]
| | | | G1: 0% | | (exam/int)
| | | | G2: 1% | | Suturing removed
| | | | RR = 0.16 | | G1: 6%
| | | | (0.02, 1.34) | | G2: 10%
| | | | NS | | RR = 0.58
| | | | | | (0.36, 0.93)
| | | | | | Resuturing required
| | | | | | G1: 3%
| | | | | | G2: 4%
| | | | | | RR = 0.63
| | | | | | (0.30, 1.33)
| | | | | | [underlined: Long term: 3 mos]
| | | | | | (quest)
| | | | | | Suturing removed
| | | | | | G1: 6%
| | | | | | G2: 10%
| | | | | | RR = 0.62
| | | | | | (0.39, 0.99)
| | | | | | Resuturing required
| | | | | | G1: 3%
| | | | | | G2: 5%
| | | | | | RR = 0.60
| | | | | | (0.31, 1.19)
Author | Age (mean ± SD) | Mode of delivery | Episiotomy rate | [underlined: Short term: 24 to 48 hrs] | [underlined: Short term] | [underlined: Short term: 24 to 48 hrs] (int) | [underlined: Short term] | [underlined: Short term] | Overall quality
Gordon et al., 1998 | G1:28.5yrs ± 4.8 | G1: | G1: 36% | (int) | NR | Gaping perineum (exam) | NR | NR | Good
Setting | G2: 28.2yrs ± 5.0 | •Spont: 83% | G2: 38% | Any pain in past 24 hrs | [underlined: Long term: 3 mos] | G1: 23% | [underlined: Long term] | [underlined: Long term] | Randomization approach and implementation
UK | Primiparous | •Instr: 17% | Lacerations | Mild: NS | Resumption of sexual intercourse (quest) | G2: 4% | NR | NR | Good
Study design | NR | G2: | G1: | Mod: NS | Tried but | P < 0.0000001 | | | Masking
RCT | Previous vaginal delivery | •Spont: 82% | •First deg: 1% | Severe: NS | too painful: NS | Tight stitches | | | Good
2×2 factorial | G1: 40% | •Instr: 18% | •Sec deg: 62% | Analgesia requirements in past 24 hrs | By 3 mos: NS | NS | | | Operational definitions and measures
Inclusion criteria | G2: 43% | Birthweight (mean ± SD) | •Third deg: 1% | G1:42% | By 2 mos: NS | Stitches not comfortable | | | Good
•First and sec deg laceration or episiotomy | Previous perineal suturing | G1: 3507g ± 500 | G2: | G2:7% | By 1 mo: NS | NS | | | Post-randomization exclusions
•Spont delivery | G1: 37% | G2: 3503g ± 482 | •First deg: 2% | P = 0.03 | Not known: NS | [underlined: Short term: 10 days] | | | No
•Simple instr delivery (non-rotational forceps or vacuum extraction) | G2: 35% | | •Sec deg: 60% | [underlined: Short term: 10 days] | Dyspareunia at first, if resumed (quest) | Tight stitches (int) | | | Retention of participants
Exclusion criteria | | | •Third deg: 0% | (int) | NS | G1: 14% | | | 24 to 48 hrs
NR | | | Suture type | Any pain in past 24 hrs | Dyspareunia now, if resumed (quest) | G2: 18% | | | G1: 885 (99%)
Groups | | | G1: | Mild: NS | Mild: NS | P = 0.02 | | | G2: 889 (100%)
G1: 2-stage (unsutured perineal skin) | | | •PGA: 49% | Mod: NS | Mod: NS | Stitches not comfortable (int) | | | Total: 1774 (100%)
G2: 3-stage (sutured perineal skin) | | | •CC: 51% | Severe: NS | Severe: NS | NS | | | 10 days
N at randomization | | | •Both: 1% | Analgesia requirements in past 24 hrs | Not known: NS | Gaping perineum (exam) | | | G1: 886 (100%)
G1: 890 | | | G2: | NS | | G1: 26% | | | G2: 885 (99%)
G2: 890 | | | •PGA: 50% | [underlined: Long term: 3 mos] | | G2: 16% | | | Total: 1771 (99%)
Total: 1, 780 | | | •CC: 49% | (quest) | | P < 0.00001 | | | 3 mos
Followup | | | •Both: 1% | Any pain in past 24 hrs | | Nature of healing: First intention (exam) | | | G1: 828 (93%)
3 mos | | | Suture method | G1: | | G1: 75% | | | G2: 836 (94%)
| | | G1: | •Mild: 6% | | G2: 84% | | | Total: 1664 (93%)
| | | •2-stage only: 87% | •Mod: 1% | | P < 0.0001
| | | •Subcut: 2% | •Severe: 0% | | Nature of healing:
| | | •Interr: 10% | G2: | | Other levels (exam)
| | | •Both: 0% | •Mild: 7% | | Sec intention: NS
| | | G2: | •Mod: 2% | | Breaking down: NS
| | | •2-stage only: 1% | •Severe: 0% | | Not known: NS
| | | •Subcut: 26% | P (for trend) = 0.01 | | Sutures removed (exam)
| | | •Interr: 72% | | | G1: 3%
| | | •Both: 0% | | | G2: 8%
| | | | | | P < 0.0001
| | | | | | [underlined: Long term: 3 mos]
| | | | | | (quest)
| | | | | | Sutures removed at any time
| | | | | | G1: 7%
| | | | | | G2: 11%
| | | | | | P = 0.002
| | | | | | Resutured
| | | | | | NS
Author | Age (mean ± SD) | Mode of delivery | Episiotomy rate | [underlined: Short term] | [underlined: Long term: 1 yr] | [underlined: Long term: 1 yr] | [underlined: Long term] | [underlined: Long term] | Overall quality
Grant et al., 2001 | G1: 29.1yrs ± 4.7 | G1: | G1: 36% | NR | (quest) | (quest) | NR | NR | Good
Setting | G2: 28.6yrs ± 4.9 | •Spont: 69% | G2: 38% | [underlined: Long term: 1 yr] | Timing of resumption of sexual intercourse | Area cut or torn feels different | | | Randomization approach and implementation
UK | Primiparous | •Instr: 31% | Lacerations | (quest) | Tried but too painful: NS | G1: 30% | | | Good
Study design | G1: 48% | G2: | G1: | Still pain or general discomfort where stitched | By 6 mos: NS | G2: 40% | | | Masking
RCT 2×2 factorial | G2: 55% | •Spont: 69% | •First deg: 1% | Mild: NS | By 3 mos: NS | P < 0.01 | | | Good
Inclusion criteria | Previous vaginal delivery | •Instr: 31% | •Sec deg: 62% | Mod: NS | Could not remember: NS | Resutured | | | Operational definitions and measures
•First and sec deg laceration or episiotomy | G1: 35% | Other labor characteristics | •Third deg: 1% | Severe: NS | No partner: NS | NS | | | Good
•Spont delivery | G2: 36% | Birthweight (mean ± SD) | G2: | | Not known: NS | | | | Post-randomization exclusions
•Simple instr delivery (non-rotational forceps or vacuum extraction) from early 1993 | Previous perineal suture | G1: 3556g ± 528 | •First deg: 2% | | Dyspareunia at first, if resumed | | | | No
Exclusion criteria | G1: 34% | G2: 3504g ± 487 | •Sec deg: 60% | | NS | | | | Retention of participants
NR | G2: 33% | Episiotomy use | •Third deg: 0% | | Dyspareunia now, if resumed | | | | 1 yr
Groups | | G1: 43% | Repair by | | NS | | | | G1: 396
G1: Unsutured perineal skin (2-stage) | | G2: 47% | G1: | | Failure to resume pain-free intercourse | | | | G2: 397
G2: Sutured perineal skin (3-stage repair including skin closure with interr or subcut sutures) | | | •Student: 1% | | NS | | | | Total: 793
N at randomization | | | •Midwife: 60%
G1: 890 | | | •Registrar: 33%
G2: 890 | | | •SHO: 7%
Total: 1789 | | | G2:
Followup | | | •Student: 1%
1 yr (restricted to a subset of those randomized) | | | •Midwife: 62%
N at 1 yr | | | •Registrar: 32%
G1: NR | | | •SHO: 6%
G2: NR | | | Suture type
Total: 919 | | | G1:
| | | •PGA: 49%
| | | •CC: 50%
| | | •Both: 1%
| | | G2:
| | | •PGA: 50%
| | | •CC: 50%
| | | •Both: 1%
| | | Suture method
| | | G1:
| | | •Subcut: 2%
| | | •Subcut and interr: 0%
| | | •Interr: 0%
| | | •2-stage only: 89%
| | | G2:
| | | •Subcut: 34%
| | | •Subcut and interr: 0%
| | | •Interr: 64%
| | | •2-stage only: 2%

Evidence Table 4. Key Question 3: Methods - Continuous versus interrupted sutures

Study Characteristics | Demographic Characteristics | Labor, Delivery, and Repair Characteristics | Episiotomy and Repair Characteristics | Pain Outcomes | Sexual Function Outcomes | Healing Outcomes | Incontinence and Pelvic Floor Outcomes | Other Outcomes | Quality and Comments
Author | Age (mean ± SD) | Mode of delivery | Episiotomy rate | [underlined: Short term: 24 hrs] | [underlined: Long term: 3 mos] | [underlined: Short term: 2 days] | [underlined: Short term] | [underlined: Short term] | Overall quality
Kettle et al, 2002 | G1: 27.2yrs ± 5.4 | Spont | G1: 41% | (quest) | (quest filled by mother) | (quest) | NR | NR | Good
Setting | G2: 27.2yrs ± 5.3 | G1: 100% | G2: 42% | Pain relief | Dyspareunia | Wound gaping | [underlined: Long term] | [underlined: Long term: 3 mos] | Randomization approach and implementation
UK | Previous sutured perineal trauma | G2: 100% | Lacerations | G1: 8.5% | NS | OR = 0.69 | NR | Back to normal | Good
Study design | G1: 41% | Birthweight (mean ± SD) | G1: | G2: 13.5% | [underlined: Long term: 12 mos] | (0.30, 1.61) | | G1: 59% | Masking
RCT | G2: 39% | NR | • Sec deg: 58% • Third/fourth deg: <1% | OR = 0.60 | (quest filled by mother) | NS | | G2: 48% | Good
2x2 factorial | Primiparous | | G2 | (0.40, 0.92) | Dyspareunia | Sutures uncomfortable | | OR: 1.55 | Operational definitions and measures
Inclusion criteria | G1: 54% | | • Sec deg: 58% • Third/fourth deg: <1% | P = 0.002 | NS | G1: 35% | | (1.26, 1.92) | Good
Spont vaginal delivery with sec deg perineal tear or episiotomy | G2: 57% | | Episiotomy extend to third deg tear | Pain walking | | G2: 41% | | Satisfaction with repair | Post-randomization exclusions
Exclusion criteria | | | G1: 1% | G1: 32% | | OR = 0.78 (0.64, 0.96) | | G1: 84% | 2 fetal deaths
• Instr delivery | | | G2: 0% | G2: 43% | | Sutures tight | | G2: 76% | Retention of participants
• Extensive perineal trauma beyond scope of midwife's practice | | | Identity of the operator | OR = 0.62 | | G1: 2% | | OR: 1.64 | 24 to 48 hrs
• Previous perineal surgery other than primary repair after childbirth | | | Student midwife | (0.47, 0.82) | | G2: 4% | | (1.28, 2.11) | Total: 1540 (100%)
• Stillbirth or baby with extensive congenital abnormalities | | | G1: 0 | P < 0.0001 | | OR = 0.40 | | [underlined: Long term: 12 mos] | Day 10
• Women with AIDS or Hepatitis B, severe perineal warts, or extensive varicose veins of external genitalia | | | G2: <1% | Pain sitting | | (0.22, 0.74) | | Satisfaction with repair | Total: 1539 (100%)
• < 16 yrs | | | Midwife grade E | G1: 39% | | [underlined: Short term: 10 days] | | G1: 86% | 3 mos
• Unable to read, write or understand English | | | G1: 25% | G2: 55% | | (quest) | | G2: 77% | Total: 1492 (96.7%)
Groups | | | G2: 29% | OR = 0.54 | | Wound gaping | | OR: 1.68 | 12 mos
G1: Cont suture | | | Midwife grade F | (0.41, 0.70) | | G1: 3% | | (1.27, 2.21) | Total: 1389 (90.1%)
G2: Interr suture | | | G1: 26% | P < 0.0001 | | G2: 7% | | [underlined: Short term]
N at randomization | | | G2: 32% | Pain passing urine | | OR = 0.46 | | NR
G1:771 | | | Midwife grade G/H | G1: 26% | | (0.29, 0.74) | | [underlined: Long term: 3 mos]
G2:771 | | | G1: 48% | G2: 36% | | Sutures uncomfortable | | Back to normal
Followup | | | G2: 36% | OR = 0.63 | | G1: 17% | | G1: 54%
1 yr | | | Doctor/other | (0.47, 0.83) | | G2: 27% | | G2: 48%
| | | G1: 2% | P < 0.0001 | | OR = 0.58 | | OR: 1.55
| | | G2: 2% | [underlined: Short term: 2 days] | | (0.46, 0 .74) | | (1.26, 1.92)
| | | P < 0.0001 | (quest) | | Sutures tight | | Satisfaction with repair
| | | Suture method | Pain at the time of response | | G1: 3% | | G1: 84%
| | | G1: Cont: 100% | G1: 69% | | G2: 7% | | G2: 76%
| | | G2: Interr: 100% | G2: 79% | | OR = 0.43 | | OR: 1.64
| | | Materials (all PGA) | OR = 0.59 | | (0.27, 0.69) | | (1.28, 2.11)
| | | G1: | (0.44, 0.79) | | Sutures removed | | [underlined: Long term: 12 mos]
| | | • Rapidly absorbed: 50% • Standard: 50% | P < 0.0001 | | G1: 0.5% | | Satisfaction with repair
| | | G2: | [underlined: Short term: 10 days] | | G2: 7.2 | | G1: 86%
| | | • Rapidly absorbed: 50% • Standard: 50% | (quest) | | OR = 0.17 | | G2: 79%
| | | Number of sutures packets used | Pain at the time of response | | (0.10, 0.28) | | OR: 1.68
| | | 1 | G1: 26% | | [underlined: Short term: 10 days] | | (1.27, 2.21)
| | | G1: 79%G2: 32% | G2: 44% | | Sutures
| | | 2 | OR = 0.47 | | G1: 3%
| | | G1: 21%G2: 67% | (0.35, 0.61) | | G2: 9%
| | | 3 | P < 0.0001 | | OR = 0.36
| | | G1: < 1%G2: 1% | Pain opening bowels | | (0.23, 0.55)
| | | | G1: 41% | | [underlined: Short term: before 3 mos (after 10 days)]
| | | | G2: 48% | | Sutures removed
| | | | OR = 0.74 | | G1: 3%
| | | | (0.57, 0.97) | | G2: 12.5%
| | | | P = 0.004 | | OR: 0.27 (0.19, 0.40)
| | | | [underlined: Long term: 3 mos]
| | | | (quest)
| | | | Pain at the time of response
| | | | G1: 9%
| | | | G2: 13%
| | | | OR = 0.70
| | | | (0.46, 1.07)
| | | | P = 0.03
| | | | [underlined: Long term: 12 mos]
| | | | (quest)
| | | | Pain at the time of response
| | | | G1: 4%
| | | | G2: 7%
| | | | OR = 0.64
| | | | (0.35, 1.16)
| | | | P = 0.05
Author | Age (mean ± SD) | Mode of delivery Operative | Episiotomy rate | [underlined: Short term: 48 hrs] | [underlined: Short term] | [underlined: Short term] | [underlined: Short term] | [underlined: Short term] | Overall quality
Mahomed et al., 1989 | G1: 26.0yrs ± 4.8 | G1: 23% | G1: | (assessed by postnatal staff or community midwife) | NR | NR | NR | NR | Good
Setting | G2: 25.9yrs ± 5.0 | G2: 23% | • Episiotomy alone: 54% • Episiotomy+ext: 10% •Tear: 36% | Use of oral analgesia | [underlined: Long term: 3 mos] | [underlined: Long term: 3 mos] | [underlined: Long term] | [underlined: Long term] | Randomization approach and implementation
UK | Primiparous | Birthweight (mean ± SD) | G2: | NS | Sexual intercourse not resumed | (quest) | NR | NR | Good
Study design | G1: 48% | G1: 3383g ± 477 | • Episiotomy alone: 48% • Episiotomy+ext: 16% • Tear: 37% | Perineal pain "now" measured | NS | Absorbable material removed | | | Masking
RCT 2×3×2 factorial | G2: 55% | G2: 3341g ± 480 | Suture type | NS | Dyspareunia | G1: 26% | | | Good
Inclusion criteria | | | Vagina, deep tissues | [underlined: Short term: 10 days] | NS | G2: 37% | | | Operational definitions and measures
Required perineal repair | | | G1: | Use of oral analgesia | | P < 0.001 | | | Good
Exclusion criteria | | | • PGA: 49% • CC: 51% | NS | | Resutured | | | Post-randomization exclusions
NR | | | G2: | Perineal pain (assessed by mother) | | NS | | | No
Groups | | | • PGA: 48% • CC: 52% | None: NS | | | | | Retention of participants
G1: Cont subcut sutures | | | Perineal skin | Mild: NS | | | | | [underlined: Short term: <3 mos]
G2: Interr transcut sutures | | | G1: | Mod: NS | | | | | 48 hrs
N at randomization | | | • PGA: 46% • CC: 49% • Silk: 2% | Severe: NS | | | | | G1: 509 (95%)
G1: 533 | | | G2: | [underlined: Long term: 3 mos] | | | | | G2: 515 (98%)
G2: 524 | | | • PGA: 45% | (assessed by mother) | | | | | Total: 1024 (97%)
Followup | | | • CC: 48% | Perineal pain | | | | | Day 10
3 mos | | | • Silk: 2% | None: NS | | | | | G1: 447 (84%)
| | | Skin closure | Mild: NS | | | | | G2: 461 (88%)
| | | G1: | Mod: NS | | | | | Operator
| | | • Subcut: 70% | Severe: NS | | | | | G1:
| | | • Interr: 18% | | | | | | • Midwife: 25%
| | | • Both: 9% | | | | | | • SHO: 64%
| | | • None: 3% | | | | | | • Registrar: 9%
| | | G2: | | | | | | • GP: 3%
| | | • Subcut: 2% | | | | | | G2:
| | | • Interr: 93% | | | | | | • Midwife: 34%
| | | • Both: 1% | | | | | | • SHO: 53%
| | | • None: 4% | | | | | | • Registrar: 0%
| | | Operator | | | | | | • GP: 3%
| | | G1: | | | | | | [underlined: Long term: 3 mos]
| | | • Midwife: 25% | | | | | | GI: 465 (87%)
| | | • SHO: 64% | | | | | | G2: 451 (86%)
| | | • Registrar: 9% | | | | | | Total: 916 (87%)
| | | • GP: 3%
| | | G2:
| | | • Midwife: 34%
| | | • SHO: 53%
| | | • Registrar: 0%
| | | • GP: 3%

Evidence Table 5. Key Question 3: Materials - Absorbable sutures versus tissue adhesive

Study Characteristics | Demographic Characteristics | Episiotomy and Repair Characteristics | Perineal Trauma Outcomes | Pain Outcomes | Sexual Function Outcomes | Healing Outcomes | Incontinence and Pelvic Floor Outcomes | Other Outcomes | Quality and Comments
Author | Age (mean ± SD) | Mode of delivery | Episiotomy rate | [underlined: Short term: Days 1 to 6] | [underlined: Short term: 3 to 6 wks](quest)Mean time taken to achieve pain-free sex | [underlined: Short term] | [underlined: Short term] | [underlined: Short term] | Overall quality
Bowen and Selinger, 2002 | G1: 26yrs ± 4.2 | NR | G1: 100% mediolateral | Definition: Mean score of perineal pain (1 to 10 VAS) days 1, 2, 3, 4, 5 | G1: 34 | •No cases of wound infection or dehiscence | NR | NR | Poor
Setting | G2: 26yrs ± 5.4 | Birthweight (mean ± SD) | G2: 100% mediolateral | [underlined: Short term: Day 1] | G2: 52 | • No patients required the suture to be removed | [underlined: Long term] | [underlined: Long term] | Randomization approach and implementation
UK | Primiparous | NR | Suture type | Micturation | P = 0.0009 | [underlined: Long term] | NR | NR | Poor (randomization broken)
Study design | G1: 100% | | G1: 100% enbucrilate tissue adhesive | G1: 4.5 | [underlined: Long term] | NR | | | Masking
RCT | G2: 100% | | G2: 100% PGA | G2: 6.3 | NR | | | | Fair
Inclusion criteria | | | Repair by | P = 0.025 | | | | | Operational definitions and measures
Primiparous female expecting a normal delivery and requiring an episiotomy repair | | | G1: Gynecologist: 100% | Other pain measures | | | | | Good
Exclusion criteria | | | G2: Midwife: at least 90% or greater (not specified) | NS | | | | | Post-randomization exclusions
• Multiparous | | | | [underlined: Short term: Day 2] | | | | | Yes
• Perineal tear | | | | Walking | | | | | Retention of participants
• Unable to give consent | | | | G1: 2.7 | | | | | Days 1 to 5
• Prenatal treatment of vulvo-vaginal problems and symptoms where subjective assessment of pain scores would be difficult | | | | G2: 4.0 | | | | | Total: 57 (92%)
Groups | | | | P = 0.0015
G1: Enbucrilate tissue adhesive | | | | Other pain measures
G2: Subcut PGA sutures | | | | NS
N at randomization | | | | [underlined: Short term: Day 3]
G1: 32 | | | | Micturation
G2: 30 | | | | G1: 3.0
Followup | | | | G2: 4.0
3 to 6 wks | | | | P = 0.025
| | | | Defecation
| | | | G1: 2.2
| | | | G2: 4.3
| | | | P = 0.003
| | | | Other pain measures
| | | | NS
| | | | [underlined: Short term: Day 4]
| | | | Walking
| | | | G1: 2.1
| | | | G2: 2.8
| | | | P = 0.029
| | | | Defecation
| | | | G1: 2.1
| | | | G2: 3.7
| | | | P = 0.015
| | | | Other pain measures
| | | | NS
| | | | [underlined: Short term: Day 5]
| | | | All pain measures
| | | | NS
| | | | [underlined: Short term: 3 to 6 wks]
| | | | Mean time taken to achieve zero pain score
| | | | G1: 18
| | | | G2: 25
| | | | P = 0.0017
| | | | [underlined: Long term]
| | | | NR
Author | Age (mean ± SD) | Mode of delivery | Suture type | [underlined: Short term: 48 hrs] | [underlined: Short term] | [underlined: Short term] | [underlined: Short term] | [underlined: Short term] | Overall quality
Adoni and Anteby, 1991 | NR | NR | G1: CC: 100% | (quest) | NR | NR | NR | Needed sitting aids | Poor
Setting | Parity | Other labor characteristics | G2: CC: 100% | Needed analgesia drugs | [underlined: Long term] | [underlined: Long term] | [underlined: Long term] | G1: 20% | Randomization approach and implementation
Israel | NR | Birthweight (mean ± SD) | G3: Histoacryl: 100% | G1: 40% | NR | NR | NR | G3: 0% | Poor
Study design | Other demographics | NR | | G3: 0% | | | | [underlined: Long term] | Masking
RCT | NR | | | Mean score of perineal pain (1=minimum, 5=maximum) | | | | NR | Good
Inclusion criteria | | | | At episiotomy site | | | | | Operational definitions and measures
Episiotomy | | | | G1: 3.3 | | | | | Good
Exclusion criteria | | | | G3: 1.95 | | | | | Post-randomization exclusions
NR | | | | P < 0.001 | | | | | No
Groups | | | | Walking | | | | | Retention of participants
G1: First episiotomy, cont CC stitches | | | | G1: 2.6 | | | | | 2 days
G2: Repeat episiotomy, cont CC stitches | | | | G3: 1.6 | | | | | Total: 60 (100%)
G3: First episiotomy, Histoacryl-tissue adhesive | | | | P < 0.001
N at randomization | | | | Sitting
G1: 20 | | | | G1: 3.6
G2: 20 | | | | G3: 1.75
G3: 20 | | | | P < 0.0001
(G2 not randomized, not included in outcomes) | | | | Lying down
Followup | | | | G1: .2.35
2 days | | | | G3: 1.0
| | | | P < 0.001
| | | | Micturition
| | | | G1: 1.7
| | | | G3: 1.0
| | | | P < 0.03
| | | | [underlined: Long term]
| | | | NR

Evidence Table 6. Key Question 3: Materials: Absorbable sutures - standard versus rapidly absorbed sutures

Study Characteristics | Demographic Characteristics | Labor and Delivery Outcomes | Episiotomy and Repair Characteristics | Pain Outcomes | Sexual Function Outcomes | Healing Outcomes | Incontinence and Pelvic Floor Outcomes | Other Outcomes | Quality and Comments
Author | Age (mean ± SD) | Mode of delivery | Episiotomy rate | [underlined: Short term: 10 days] | [underlined: Short term] | [underlined: Short term: 2 days] | [underlined: Short term] | [underlined: Short term] | Overall quality
Kettle et al., 2002 | G1: 27.3yrs ± 5.4 | Spont | G1: 40% | Pain | NR | (quest) | NR | NR | Good
Setting | G2: 27.1yrs ± 5.4 | G1: 100% | G2: 43% | Cont | [underlined: Long term: 3 mos] | Wound gaping | [underlined: Long term] | [underlined: Long term: 3 mos] | Randomization approach and implementation
UK | Primiparous | G2: 100% | Lacerations | G1: 27% | (quest) | OR = 1.20 | NR | Back to normal | Good
Study design | G1: 54% | Birthweight (mean ± SD) | G1: | G2: 26% | Dyspareunia | (0.52, 2.79) | | OR = 1.22 | Masking
RCT 2×2 factorial | G2: 57% | NR | • Sec deg: 59% | OR = 1.06 | NS | Sutures uncomfortable | | (0.99, 1.51) | Good
Inclusion criteria | Previous sutured perineal trauma | | • Third/fourth deg: <1% | (0.70, 1.62) | [underlined: Long term: 12 mos] | OR = 1.02 | | Satisfaction with repair | Operational definitions and measures
Spont vaginal delivery with sec deg perineal tear or episiotomy | G1: 41% | | • Extend to third deg: <1% | Interr | (quest) | (0.83, 1.25) | | OR = 1.25 | Good
Exclusion criteria | G2: 39% | | G2: | G1: 39% | Dyspareunia | Sutures tight | | (0.97, 1.61) | Post-randomization exclusions
• Instr delivery | | | • Sec deg: 56% | G2: 48% | NS | OR = 1.15 | | [underlined: Long term: 12 mos] | 2 fetal deaths
• Extensive perineal trauma beyond scope of midwife practice | | | • Third/fourth deg tear: <1% | OR = 0.70 | | (0.63, 2.12) | | Satisfaction with repair | Retention of participants
• Previous perineal surgery other than primary repair after childbirth | | | • Extend to third deg tear: 1% | (0.48, 1.01) | | [underlined: Short term: 10 days] | | OR = 1.09 | 24 hrs
• Stillbirth or baby with extensive congenital abnormalities | | | Suture type | Test for heterogeneity between groups: P = 0.05 | | (quest) | | (0.83, 1.44) | G1: 770 (100%)
• Women with AIDS or Hepatitis B, severe perineal warts, extensive varicose veins of external genitalia | | | Method | (P for heterogeneity = 0.3) | | Wound gaping | | | G2: 770 (100%)
• <16 yrs | | | G1: | NS | | OR = 1.83 | | | Total: 1540 (100%)
• Unable to read, write, understand English | | | • Cont: 50% | [underlined: Short term: 24 hrs relief] | | (1.14, 2.92) | | | Day 10
Groups | | | • Interr: 50% | (10 days quest from mother and midwife) | | Sutures uncomfortable | | | G1: 769 (100%)
G1: Rapidly absorbed (polyglactin) | | | G2: | Pain | | OR = 0.88 | | | G2: 770 (100%)
G2: Standard (polyglactin) | | | • Cont: 50% | G1: 8% | | (0.69, 1.12) | | | Total: 1539 (99.9%)
N | | | • Interr: 50% | G2: 14% | | Sutures tight | | | 3 mos
G1: 772 | | | Materials | OR = 0.55 | | OR = 0.77 | | | G1: 753 (98%)
G2: 770 | | | G1: | (0.3, 0.83) | | (0.48, 1.24) | | | G2: 739 (96%)
Followup | | | • Rapidly absorbed: 99% | P = 0.0002 | | Sutures removed | | | Total: 1492 (96.9%)
1 yr | | | • Standard: 1% | Pain walking | | G1: 2% | | | 12 mos
| | | G2: | G1: 34% | | G2: 6% | | | G1: 703 (91%)
| | | • Standard: 100% | G2: 41% | | OR: 0.38 | | | G2: 686 (89%)
| | | Operator | OR = 0.74 | | (0.23, 0.64) | | | Total: 1389 (90.2%)
| | | Doctor | (0.56, 0.97) | | [underlined: Short term: 10 days to 3 mos]
| | | G1: 2% | P = .004 | | Sutures removed
| | | G2: 2% | Pain sitting | | G1: 1%
| | | Midwife E | G1: 45% | | G2: 10%
| | | G1: 27% | G2: 49% | | OR: 0.19
| | | G2: 26% | OR = 0.84 | | (0.13, 0.30)
| | | Midwife F | (0.65, 1.10)
| | | G1: 30% | P = 0.10
| | | G2: 28% | Pain passing
| | | Midwife G/H | NS
| | | G1: 27% | Pain opening bowels
| | | G2: 26% | NS
| | | N suture packets used | [underlined: Long term]
| | | 1 | NR
| | | G1: 56%
| | | G2: 55%
| | | 2
| | | G1: 43%
| | | G2: 45%
| | | 3
| | | G1: 1%
| | | G2: < 1%
Author | Age | Mode of delivery | NR | [underlined: Short term: 24 hrs] | [underlined: Short term] | [underlined: Short term: 6 wks] | [underlined: Short term] | [underlined: Short term] | Overall quality
McElhinney et al., 2000 | NR | NR | | Perineal pain (measured with VAS) | NR | Wound problems (infection, gaping wound, pain or residual material requiring removal) | NR | NR | Poor
Setting | Primiparous | Birthweight (mean ± SD) | | NS | [underlined: Long term: 12 wks] | G1: 2% | [underlined: Long term] | [underlined: Long term] | Randomization approach and implementation
Ireland | G1: 53% | NR | | [underlined: Short term: 3 days] | Dyspareunia (int) | G2: 30% | NR | NR | Fair
Study design | G2: 56% | | | (Measured by 4-pt pain scale) | G1: Mean score of 0.05 in 5% of patients who had dyspareunia | [underlined: Long term: 12 wks] | | | Masking
RCT | | | | NS | G2: Mean score of 0.27 in 20% of patients who had dyspareunia | Wound problems of women experiencing wound problems at 6 wks | | | Poor
Inclusion criteria | | | | Analgesic use (Prior to discharge) | P < 0.05 | G1: 5% | | | Operational definitions and measures
• Parity of 0 to 2 | | | | NS | | G2: 95% | | | Fair
• 18 to 40 yrs old | | | | [underlined: Long term] | | “Still very significant” | | | Post-randomization exclusions
• Singleton fetus | | | | NR | | | | | No
• Normal vaginal delivery | | | | | | | | | Retention of participants
• Required an episiotomy or sustained a sec deg floor tear | | | | | | | | | 24 hrs
Exclusion criteria | | | | | | | | | Total: 153 (100%)
NR | | | | | | | | | Day 3
Groups | | | | | | | | | Total: 153 (100%)
G1: Vicryl rapide | | | | | | | | | 6 wks
G2: Vicryl | | | | | | | | | Total: 118 (77%)
N at completion | | | | | | | | | 12 wks
G1: 75 | | | | | | | | | Total: 118 (77%)
G2: 78
Total: 153
Followup
12 wks

Evidence Table 7. Key Question 3: Materials: Materials - Untreated catgut versus treated catgut

Study Characteristics | Demographic Characteristics | Labor and Delivery Characteristics | Episiotomy and Repair Characteristics | Pain Outcomes | Sexual Function | Repair and Healing | Incontinence | Other description of Outcome | Quality and Comments
Author | Age (mean ± SD) | Mode of delivery | Episiotomy rate | [underlined: Short term: 10 to 12 days] | [underlined: Short term] | [underlined: Short term: 10 days] (assessed by midwife) | [underlined: Short term] | [underlined: Short term] | Quality
Spencer et al., 1986 | G1: 26.5yrs ± 5.1 | Spont: 100% | G1: 36.1% | (quest) | NR | Sutures removed | NR | NR | Fair
Grant et al., 1989 | G2: 27.1yrs ± 5.3 | Birthweight (mean ± SD) | G2: 7.8% | Experienced perineal pain within last 24 hrs (asked at 10 to 12 days) | [underlined: Long term: 3 mos] | G1: 2.4% | [underlined: Long term] | [underlined: Long term] | Randomization approach and implementation
Setting | Primiparous | G1: 3419g ± 440 | Note: Article reports 7.8%, which we believe is a typo because the percentages in that particular column would add to 100%. We believe the correct value is 37.8% | None | (quest) | G2: 11.5% | NR | NR | Fair
UK | G1: 49.1% | G2: 3384g ± 435 | Episiotomy and ext | G1: 68.1% | Dyspareunia | P < 0.0001 | | | Masking
Study design | G2: 44.4% | (Collected at 3 year followup) | G1: 5.0% | G2: 76.6% | None: | [underlined: Short term: 10 to 12 days] (assessed by midwife) | | | Good
RCT | Married | GA | G2: 4.7% | Mild | G1: 38.0% | Perineal breakdown | | | Post-randomization exclusions
Inclusion criteria | G1: 89.9% | G1: 39.9wks ± 1.2 | Posterior tear alone | G1: 20.9% | G2: 50.7% | NS | | | No
• Spont vaginal deliveries | G2: 88.8 % | G2: 39.8wks ± 1.1 | G1: 53.8% | G2: 14.3% | At first but not at 3 mos | Healing by secondary intention | | | Retention of participants
• Required perineal repairs | Babies born since study | (mean, SD) | G2: 53.9% | Mod | G1: 36% | NS | | | 10 to 12 days
Exclusion criteria | G1: | Episiotomy performed in next pregnancy | Labial tear alone | G1: 9.6% | G2: 29.8% | [underlined: Long term: 3 mos] (quest) | | | G1: 336 (89%)
NR | • 0: 56% | G1: 25% | G1: 5.0% | G2: 9.0% | Mild | Sutures removed | | | G2: 322 (89%)
Groups | • 1: 41% | G2: 14% | G2: 3.6% | Severe | G1: 23.3% | G1: 6.9% | | | Total: 658 (89%)
G1: Chromic “softgut” | • 2: 3% | | Suture type | G1: 1.5% | G2: 18.1% | G2: 16.4% | | | 3 mos
G2: Untreated CC | G2: | | G1: | G2: 0% | Mod | P < 0.001 | | | G1: 332 (88%)
N at randomization | • 0: 62% | | • CC: 8.0% | P = 0.15 (overall) | G1: 2.7% | | | | G2: 323 (90%)
G1: 377 | • 1: 37% | | • Soft-gut: 91.8% | Used oral analgesics | G2: 1.4% | | | | Total: 655 (89%)
G2: 360 | • 2: 1% | | G2: | NS | P < 0.025 | | | | 3 yrs
Total: 737 | | | • CC: 95.3% | Use of salt bath for pain on that day | Recommencement of sexual intercourse | | | | G1: 263 (70%)
Followup | | | • Soft-gut: 4.4% | G1: 42% | NS | | | | G2: 253 (70%)
3 mos | | | Suture method | G2: 34% | [underlined: Long term: 3 yrs] | | | | Total: 516 (70%)
| | | G1: | P = 0.03 | (quest)
| | | •Subcut: 31.9% | [underlined: Long term: 3 mos] | Sexual intercourse painful
| | | •Interr: 60.9% | Experienced perineal pain within last 7 days (asked at 3 mos, quest) | G1: 19%
| | | •Both: 7.2% | None: NS | G2: 11%
| | | G2: | Mild: NS | OR: 1.7
| | | • Subcut: 32.4% | Mod: NS | (1.1, 2.6)
| | | • Interr: 59.5% | Severe: NS | P < 0.02
| | | • Both: 8.1% | | Soreness
| | | Repair done by | | G1: 16%
| | | G1: | | G2: 11%
| | | • SHO: 87% | | Tightness
| | | • Student: 8.5% | | G1: 0.8%
| | | • Registrar: 4.5% | | G2: 0%
| | | G2: | | Other
| | | • SHO: 85.8% | | G1: 2.3%
| | | • Student: 9.7% | | G2: 0.4%
| | | • Registrar: 4.5%

Evidence Table 8. Key Question 3: Materials - Nonabsorbable versus absorbable

Study Characteristics | Demographic Characteristics | Characteristics of Labor, Delivery and Repair | Episiotomy and Repair Characteristics | Pain Outcomes | Sexual Function Outcomes | Healing Outcomes | Incontinence and Pelvic Floor Outcomes | Other Outcomes | Quality and Comments
Author | Age (mean ± SD or median) | Mode of delivery | Suture type | [underlined: Short term: (Days 1 to 6)] | [underlined: Short term] | [underlined: Short term] | [underlined: Short term] | [underlined: Short term] | Overall quality
Buchan and Nicholls, 1980 | NR | G1: Spont: 100% | G1: CC/black silk: 100% | Analgesic requirements (mean N of tablets ± SD) | NR | NR | NR | NR | Fair
Setting | Primiparous | G2: Spont: 100% | G2: CC/Dexon: 100% | Day 1 | [underlined: Long term: 4 mos] | [underlined: Long term] | [underlined: Long term] | [underlined: Long term] | Randomization approach and implementation
UK | G1: 100% | Birthweight (mean ± SD) | | G1: 3.42 ± 2.83 | (quest) | NR | NR | NR | Poor
Study design | G2: 100% | NR | | G2: 2.82 ± 2.93 | Coital assessment | | | | Masking
RCT | | | | NS | No pain at all | | | | NR
Inclusion criteria | | | | Day 2 | G1: 21% | | | | Operational definitions and measures
• Primigravidae | | | | G1: 5.80 ± 2.89 | G2: 11% | | | | Poor
• Spont vaginal delivery | | | | G2: 5.77 ± 2.63 | P < 0.001 | | | | Post-randomization exclusions
• Mediolateral episiotomy | | | | NS | Pain for < 4 wks after initial coitus | | | | No
Exclusion criteria | | | | Day 3 | G1: 33% | | | | Retention of participants
• Extended episiotomy | | | | G1: 5.31 ± 2.66 | G2: 27% | | | | 1 to 6 days:
• Additional lacerations | | | | G2: 4.34 ± 2.93 | Pain for <8 wks after initial coitus | | | | G1: 70
Groups | | | | (P < 0.001) | G1: 33% | | | | G2: 70
G1: Interr black silk sutures (Ethicon 562) | | | | Day 4 | G2: 45% | | | | Total: 140
G2:Absorbable subcut Dexon suture | | | | G1:5.85 ± 3.23 | P < 0.001 | | | | 4 mos
N at randomization | | | | G2: 3.93 ± 3.34 | Pain for > 8 wks after initial coitus | | | | G1: 45 (64%)
G1: 70 | | | | (P < 0.001) | G1: 13% | | | | G2: 55 (79%)
G2: 70 | | | | Day 5 | G2: 17% | | | | Total: 100
Total: 140 | | | | G1: 5.62 ± 2.94 | P < 0.001
Followup | | | | G2: 3.38 ± 3.28 | No association between timing of first coitus and presence or persistence of dyspareunia
4 mos | | | | (P < 0.001) | NR
| | | | Day 6
| | | | G1: 2.61 ± 2.34
| | | | G2: 2.28 ± 2.06
| | | | NS
| | | | [underlined: Long term]
| | | | NR
Author | Age (mean ± SD) | Mode of delivery | Episiotomy rate | [underlined: Short term: 48 hrs] | [underlined: Short term] | [underlined: Short term: 48 hrs] | [underlined: Short term] | [underlined: Short term] | Overall quality
Mahomed et al., 1989 | G1: 26.1yrs ± 5.0 | Operative vaginal deliveries | G1: | Use of oral analgesia (assessed by postnatal staff or community midwife) | NR | Edema, bruising, healing (clinically assessed) | NR | NR | Good
Setting | G2: 26.2yrs ± 4.8 | G1: 27% | • Episiotomy alone: 52% | NS | [underlined: Long term: 3 mos] | NS | [underlined: Long term] | [underlined: Long term] | Randomization approach and implementation
UK | G3: 26.2yrs ± 4.9 | G2: 21% | • Episiotomy+ext: 13% | Perineal pain “now” measured | Sexual intercourse not resumed | [underlined: Long term] | NR | NR | Good
Study design | Primiparous | G3: 21% | • Tear: 35% | NS | G1: 11% | Absorbable material removed | | | Masking
RCT | G1: 52% | Birthweight (mean ± SD) | G2: | [underlined: Short term: Day 10] | G2: 9% | G1: 39% | | | Good
2×3×2 factorial | G2: 51% | G1: 3386g ± 480 | • Episiotomy alone: 50% | (assessed by mother) | G3: 15% | G2: 23% | | | Operational definitions and measures
Inclusion criteria | G3 . 52% | G2: 3338g ± 472 | • Episiotomy+ext: 13% | Use of oral analgesia | P < 0.05 between G2 and G3 | G3: 7% | | | Good
Required perineal repair | | G3. 3358g ± 488 | • Tear: 37% | NS | Dyspareunia | P < 0.001 | | | Post-randomization exclusions
Exclusion criteria | | | G3: | Perineal pain | NS | [underlined: Long term: 3 mos] | | | No
NR | | | • Episiotomy alone: 50% | None: NS | | Resutured (quest) | | | Retention of participants
Groups | | | • Episiotomy+ext: 12% | Mild: NS | | NS | | | 48 hrs
G1: PGA | | | • Tear: 38% | Mod: NS | | | | | G1: 519 (97%)
G2: CC | | | Suture type | Severe: NS | | | | | G2: 505 (97%)
G3: Silk | | | Vagina, deep tissues | [underlined: Long term: 3 mos] | | | | | G3: 498 (96%)
N at randomization | | | G1: | (assessed by mother) | | | | | Total: 1522 (97%)
G1: 535 | | | • PGA: 52% | Perineal pain | | | | | Day 10
G2: 522 | | | • CC: 48% | None: NS | | | | | G1: 450 (84%)
G3: 517 | | | G2: | Mild: NS | | | | | G2: 458 (88%)
Followup | | | • PGA: 44% | Mod: NS | | | | | G3: 444 (86%)
3 mos | | | • CC: 55% | Severe: NS | | | | | Total: 1352 (86%)
| | | G3: | | | | | | 3 mos
| | | • PGA: 48% | | | | | | G1: 458 (86%)
| | | • CC: 51% | | | | | | G2: 458 (88%)
| | | Perineal skin | | | | | | G3: 450 (87%)
| | | G1: | | | | | | Total: 1366 (87%)
| | | • PGA: 87%
| | | • CC: 7%
| | | • Silk: 2%
| | | • None: 4%
| | | G2:
| | | • PGA: 3%
| | | • CC: 90%
| | | • Silk: 2%
| | | • None: 5%
| | | G3:
| | | • PGA: 2%
| | | • CC: 3%
| | | • Silk: 89%
| | | • None: 5%
| | | Skin closure
| | | G1:
| | | • Subcut: 36%
| | | • Interr: 54%
| | | • Both: 6%
| | | • None: 3%
| | | G2:
| | | • Subcut: 36%
| | | • Interr: 56%
| | | • Both: 4%
| | | • None: 3%
| | | G3:
| | | • Subcut: 1%
| | | • Interr: 93%
| | | • Both: 0%
| | | • None: 4%

Evidence Table 9. Key Question 3: Materials - Polyglycolic acid versus chromic catgut

Study Characteristics | Demographic Characteristics | Labor and Delivery Characteristics | Episiotomy and Repair Characteristics | Pain Outcomes | Sexual Function Outcomes | Healing Outcomes | Incontinence and Pelvic Floor Outcomes | Other Outcomes | Quality and Comments
Author | Age (mean ± SD) | Mode of delivery | Episiotomy rate | [underlined: Short term: 1 day] | [underlined: Short term 6 wks] | [underlined: Short term: 6 wks] | [underlined: Short term] | [underlined: Short term] | Overall quality
Upton et al., 2002 | G1:29.6yrs ± 5.5 | G1:Spont: 100% | G1:20.6% | Any perineal pain | (int) | (measured by quest) | NR | NR | Fair
Setting | G2:29.5yrs ± 5.2 | G2:Spont: 100% | G2:17.8% | G1:71% | Dyspareunia | Problems with sutures | [underlined: Long term] | [underlined: Long term] | Randomization approach and implementation
Australia | NS | Birthweight (mean ± SD) | Lacerations | G2:76% | G1:35% | G1:4.4% | NR | NR | Fair
Study design | Primiparous | G1:3440g ± 467 | G1: | OR:0.75 | G2:35% | G2:1.6% | | | Masking
RCT | G1:54.6% | G2:3410g ± 498 | • First deg: 11.9% | (0.47, 1.22) | OR: 1.03 | OR: 2.74 | | | Fair
Inclusion criteria | G2:40.1% | Estimated GA | • Sec deg: 67.0% | NS | (0.51, 2.12) | (0.65, 13.26) | | | Operational definitions and measures
• Singleton gestation | | G1:39.5wks ± 1.4 | G2: | Mod to severe suture pain | Recommencement of sexual intercourse | [underlined: Long term] | | | Good
• ≥ 34 wks | | G2:39.4wks ± 1.4 | • First deg: 10.7% | G1:24% | G1:35% | NR | | | Post-randomization exclusions
• Episiotomy or first/sec deg laceration | | | • Sec deg: 70.6% | G2:20% | G2:39% | | | | No
• Spont vaginal delivery | | | Suture method | NS | OR: 0.83 | | | | Retention of participants
Exclusion criteria | | | Interr for perineal muscle and subcut perineal skin (all repairs) | [underlined: Short term: 3 days] | (0.54, 1.27) | | | | Day 1
• Third deg tear | | | | Any perineal pain | [underlined: Long term: 3 mos] | | | | G1:172 (89%)
• Forceps/vacuum (“instr delivery”) | | | | G1:60% | (int) | | | | G2:174 (88%)
• Repair by “medical officer” | | | | G2:66% | Dyspareunia | | | | Total: 346 (88%)
Groups | | | | OR:0.77 | G1:27% | | | | Day 3
G1:PGA | | | | (0.51, 1.17) | G2:19% | | | | G1:187 (96%)
G2:CC | | | | Mod to severe suture pain | OR: 1.56 | | | | G2:188 (95%)
N at randomization | | | | G1:9% | (0.89, 2.76) | | | | Total: 375 (96%)
G1:194 | | | | G2:8% | Recommencement of sexual intercourse | | | | 6 wks
G2:197 | | | | NS | G1:79% | | | | G1:184 (95%)
Total: 391 | | | | [underlined: Short term: 6 wks] | G2:85% | | | | G2:184 (93%)
Followup | | | | Any perineal pain | OR:0.66 | | | | Total: 368 (94%)
6 mos | | | | G1:15% | (0.38, 1.16) | | | | 3 mos
| | | | G2:13% | [underlined: Long term: 6 mos] | | | | G1:167 (86%)
| | | | OR:1.15 | Dyspareunia | | | | G2:174 (88%)
| | | | (0.63, 2.07) | G1:16% | | | | Total: 341 (87%)
| | | | NS | G2:13% | | | | 6 mos
| | | | [underlined: Long term: 3 mos] | OR:1.30 | | | | G1:158 (81%)
| | | | Any perineal pain | (0.68, 2.50) | | | | G2:159 (81%)
| | | | G1:10% | Recommencement of sexual intercourse | | | | Total: 317 (81%)
| | | | G2:8% | G1:96%
| | | | OR:1.3 | G2:95%
| | | | (0.62, 2.72) | OR: 1.00
| | | | [underlined: Long term: 6 mos] | (0.95, 1.05)
| | | | Any perineal pain | NS
| | | | G1:6% | [underlined: Long term]
| | | | G2:3% | NR
| | | | OR:1.86
| | | | (0.61, 5.68)
Author | Age (mean ± SD) | Mode of delivery | Episiotomy rate | [underlined: Short term: 24 hrs] | [underlined: Short term] | [underlined: Short term: 24 to 48 hrs] (int) | [underlined: Short term] | [underlined: Short term] | Overall quality
Mackrodt et al., 1998 | G1:28.2yrs ± 5.1 | G1: | G1:39% | (int) | NR | Tight stitches | NR | NR | Good
Setting | G2:28.4yrs ± 4.7 | • Spont: 82% | G2:35% | Analgesia requirements | [underlined: Long term: 3 mos] (quest) | G1:17% | [underlined: Long term] | [underlined: Long term] | Randomization approach and implementation
UK | Primiparous | • Instr: 18% | Laceration | G1:42% | Timing of resumption of sexual intercourse | G2:23% | NR | NR | Good
Study design | G1:62% | G2: | G1: | G2:7% | Tried but too painful: NS | P = 0.001 | | | Masking
RCT | G2:60% | • Spont: 83% | • First deg: 1% | P = 0.03 | By 3 mos: NS | Stitches not comfortable | | | Good
Inclusion criteria | | • Instr: 17% | • Sec deg: 59% | Any pain | By 2 mos: NS | G1:33% | | | Operational definitions and measures
• First and sec deg laceration or episiotomy | | Birthweight (mean ± SD) | • Third deg: 0% | Mild | By 1 mo: NS | G2:40% | | | Good
• Spont delivery | | G1:3517g ± 480 | G2: | G1:35% | Not known: NS | P = 0.003 | | | Post-randomization exclusions
• Simple instr delivery (non-rotational forceps or vacuum extraction) | | G2:3492g ± 502 | • First deg: 2% | G2:37% | Dyspareunia at first, if resumed | [underlined: Short term: 24 to 48 hrs] (midwife exam) | | | No
Exclusion criteria | | Previous perineal suturing | • Sec deg: 62% | Mod | NS | Appearance of perineum (gaping) | | | Retention of participants
NR | | G1:36% | • Third deg: 0% | G1:21% | Dyspareunia now, if resumed | NS | | | 24 to 48 hrs
Groups | | G2:37% | Suture type | G2:28% | Mild: NS | [underlined: Short term: 10 days (int)] | | | G1:886 (100%)
G1:PGA sutures | | | G1: | Severe | Mod: NS | Tight stitches | | | G2:888 (100%)
G2:CC sutures | | | • PGA: 98% | G1:3% | Severe: NS | NS | | | Total: 1774 (100%)
N at randomization | | | • CC: 1% | G2:2% | Not known: NS | Stitches not comfortable | | | 10 days
G1:889 | | | • Both: 1% | P (for trend) = 0.002 | Failure to resume pain-free intercourse | G1:19% | | | G1:884 (99%)
G2:891 | | | G2: | [underlined: Short term: 10 days] | NS | G2:26% | | | G2:887 (99%)
Total: 1780 | | | • PGA: 99% | (int) | | P < 0.001 | | | Total: 1771 (99%)
Followup | | | • CC: 1% | Analgesia requirements | | Appearance of perineum (midwife exam) | | | 3 mos
3 mos | | | • Both: 0% | G1:6% | | G1:16% | | | G1:829 (93%)
| | | Method | G2:10% | | G2:26% | | | G2:835 (94%)
| | | G1: | P = 0.01 | | P < 0.00001 | | | Total: 1664 (93%)
| | | • Subcut: 14% | Any pain | | Nature of healing (midwife exam)
| | | • Interr: 41% | Mild | | First intention
| | | • 2-Stage only: 44% | G1:14% | | G1:84%
| | | • None: 1% | G2:17% | | G2:74%
| | | G2: | Mod | | P < 0.00001
| | | • Subcut: 13% | G1:7% | | Sec intention
| | | • Interr: 42% | G2:10% | | NS
| | | • 2-Stage only: 44% | Severe | | Breaking down
| | | • None: 1% | G1:2% | | NS
| | | | G2:2% | | Sutures removed
| | | | P (for trend) = 0.05 | | NS
| | | | [underlined: Short term: 24 hrs] | | [underlined: Long term: 3 mos (quest)]
| | | | Analgesia requirements | | Suture material removed at any time
| | | | NS | | G1:12%
| | | | Any pain | | G2:7%
| | | | Mild: NS | | P = 0.002
| | | | Mod: NS | | Resutured
| | | | Severe: NS | | NS
| | | | [underlined: Long term: 3 mos]
| | | | (quest)
| | | | NS
Author | Age (mean ± SD) | Mode of delivery | Episiotomy rate | [underlined: Long term: 1 yr (quest)] | [underlined: Long term: 1 yr] | [underlined: Long term: 1 yr] | [underlined: Long term] | [underlined: Long term] | Overall quality
Grant et al., 2001 | G1:28.5yrs ± 5.0 | G1: | G1:48% | Pain or general discomfort where stitched | (quest) | (quest) | NR | NR | Good
Setting | G2:29.2yrs ± 4.6 | • Spont: 68% | G2:43% | Mild: NS | Timing of resumption of sexual intercourse | Area cut or torn feels different | | | Randomization approach and implementation
UK | Primiparous | • Instr: 32% | Laceration | Mod: NS | Tried but too painful: NS | G1:31% | | | Good
Study design | G1:65% | G2: | G1: | Severe: NS | By 6 mos: NS | G2:38% | | | Masking
RCT | G2:64% | • Spont: 70% | • First deg: 1% | | By 3 mos: NS | P = 0.07 | | | Good
Inclusion criteria | Previous perineal suturing | • Instr: 30% | • Sec deg: 50% | | Could not remember: NS | Resutured | | | Operational definitions and measures
• First and sec deg laceration or episiotomy | G1:33% | Birthweight (mean ± SD) | • Third deg: 1% | | No partner: NS | NS | | | Good
• Spont delivery | G2:33% | G1:3556g ± 504 | G2: | | Not known: NS | | | | Post-randomization exclusions
• Simple instr delivery (non-rotational forceps or vacuum extraction) | | G2:3504g ± 512 | • First deg: 2% | | Dyspareunia at first, if resumed | | | | No
Exclusion criteria | | | • Sec deg: 65% | | G1:32% | | | | Retention of participants
NR | | | • Third deg: 0% | | G2:41% | | | | 1 yr
Groups | | | Repair by | | P = 0.01 | | | | G1:395
G1:PGA sutures | | | G1: | | Dyspareunia now, if resumed | | | | G2:398
G2:CC sutures | | | • Student: 1% | | G1:8% | | | | Total: 793 (86%)
N at randomization | | | • Midwife: 60% | | G2:13%
G1:889 | | | • Registrar: 34% | | P = 0.02
G2:891 | | | • SHO: 6% | | Failure to resume pain-free intercourse
Total: 1780 | | | G2: | | G1:8%
Followup | | | • Student: 1% | | G2:14%
1 yr | | | • Midwife: 62% | | P = 0.01
N eligible at followup | | | • Registrar: 30%
G1:NR | | | • SHO: 7%
G2:NR | | | Suture type
Total: 919 | | | G1:
Note: The 1-yr postpartum followup was not part of the original plan for the study. All women recruited after June 1993 who had responded at the 3-mo followup were eligible for 1-yr followup (n = 919). | | | • PGA: 99%
| | | • CC: 1%
| | | • Both: 1%
| | | G2:
| | | • PGA: 1%
| | | • CC: 99%
| | | • Both: 1%
| | | Suture method
| | | G1:
| | | • Subcut: 21%
| | | • Interr: 34%
| | | • 2-Stage only: 45%
| | | • None: 0%
| | | G2:
| | | • Subcut: 15%
| | | • Interr: 38%
| | | • 2-Stage only: 45%
| | | • None: 1%
Author | Age (mean ± SD) | Mode of delivery | Episiotomy rate: | [underlined: Short term: Days 1 to 5] | [underlined: Short term] | [underlined: Short term] | [underlined: Short term] | [underlined: Short term] | Overall quality
Olah, 1990 | G1:26.5yrs ± 5.1 | Instr 100% for both groups | G1:Type not specified 100% | Patient's subjective assessment of discomfort/pain using a 10cm visual analog scale on (mean ± SD) | NR | Edema (observer assessment, 0 (none) to 3 (severe)) | NR | NR | Fair
Setting | G2:27.0yrs ± 5.0 | Anesthesia at time of delivery | G2:Type not specified 100% | Day 1 | [underlined: Long term] | NS | [underlined: Long term] | [underlined: Long term] | Randomization approach and implementation
UK | Primiparous | G1:22% epidural/ spinal anesthesia | Ext of episiotomy | NS | NR | Bruising (observer assessment, 0 (none) to 3 (severe)) | NR | NR | Fair
Study design | G1:47% | G2:26% epidural/ spinal anesthesia | G1:4% | Day 3 | | NS | | | Masking
RCT | G2:45% | Estimated GA | G2:6% | NS | | [underlined: Long term] | | | NR
Inclusion criteria | | • 39.5wks ± 1.2 | | Day 5 | | NR | | | Operational definitions and measures
Require episiotomy repair following instr delivery (forceps or venthouse extraction) | | • 39.8wks ± 1.1 | | NS | | | | | Good
Exclusion criteria | | Birthweight (mean ± SD) | | [underlined: Long term] | | | | | Post-randomization exclusions
NR | | G1:3.4kg ± 0.4 | | NR | | | | | No
Groups | | G2:3.4kg ± 0.4 | | | | | | | Retention of participants
G1:CC | | | | | | | | | 1 day
G2:PGA | | | | | | | | | G1:60 (100%)
N at randomization | | | | | | | | | G2:60 (100%)
G1:60 | | | | | | | | | Total: 120 (100%)
G2:60 | | | | | | | | | (Assumed, not stated)
Total: 120 | | | | | | | | | 3 days
Followup | | | | | | | | | G1:60 (100%)
5 days | | | | | | | | | G2:60 (100%)
| | | | | | | | | Total: 120 (100%)
| | | | | | | | | (Assumed, not stated)
| | | | | | | | | 5 days
| | | | | | | | | G1:60 (100%)
| | | | | | | | | G2:60 (100%)
| | | | | | | | | Total: 120 (100%)
| | | | | | | | | (Assumed, not stated)
Author | Age (mean ± SD or median) | Mode of delivery | Episiotomy rate | [underlined: Short term: 48 hrs] | [underlined: Long term: 3 mos] | [underlined: Short term: 48 hrs] | [underlined: Short term] | [underlined: Short term] | Overall quality
Mahomed, 1989 | G1:26.0yrs ± 4.9 | Operative vaginal delivery | G1: | Use of oral analgesia (assessed by postnatal staff or community midwife) | Sexual intercourse not resumed | (clinically assessed) | NR | NR | Good
Setting | G2:26.1yrs ± 4.9 | G1:23% | • Episiotomy alone: 49% | G1:48% | NS | Edema, bruising, healing | [underlined: Long term] | [underlined: Long term] | Randomization approach and implementation
UK | Primiparous | G2:23% | • Episiotomy+ext: 13% | G2:54% | Dyspareunia | NS | NR | NR | Good
Study design | G1:53% | Birthweight (mean ± SD) | • Tear: 38% | RR = 0.9 (0.8, 1.0) P = 0.03 | NS | [underlined: Short term: 10 days] | | | Masking
RCT 2×3×2 factorial | G2:50% | G1:3371g ± 488 | G2: | Perineal pain “now” measured | | Edema, bruising, healing | | | Good
Inclusion criteria | | G2:3350g ± 475 | • Episiotomy alone: 52% | NS | | NS | | | Operational definitions and measures
Required perineal repair | | | • Episiotomy+ext: 12% | [underlined: Short term: 10 days] | | [underlined: Long term] | | | Good
Exclusion criteria | | | • Tear: 35% | Use of oral analgesia | | Absorbable material removed | | | Post-randomization exclusions
NR | | | Suture type | NS | | G1:25% | | | No
Groups | | | Vagina, deep tissues | Perineal pain (assessed by mother) | | G2:21% | | | Retention of participants
G1:PGA | | | G1: | None: NS | | RR = 1.2 | | | 2 days
G2:CC | | | • PGA: 93% | Mild: NS | | (1.0, 1.5) | | | G1:768 (96%)
N at randomization | | | • CC: 7% | Mod: NS | | P = 0.06 | | | G2:752 (97%)
G1:796 | | | G2: | Severe: NS | | [underlined: Long term: 3 mos] | | | Total: 1520 (97%)
G2:778 | | | • PGA: 2% | [underlined: Long term: 3 mos] | | (quest) | | | 10 days
Total:1574 | | | • CC: 98% | Perineal pain (assessed by mother) | | Resutured | | | G1:679 (85%)
Followup | | | Perineal skin | None: NS | | NS | | | G2:670 (86%)
3 mos | | | G1: | Mild: NS | | | | | Total: 1349 (86%)
| | | • PGA: 35% | Mod: NS | | | | | 3 mos
| | | • CC: 30% | Severe: NS | | | | | G1:687 (86%)
| | | • Silk: 31% | | | | | | G2:679 (87%)
| | | • None: 4% | | | | | | Total: 1366 (87%)
| | | G2:
| | | • PGA: 28%
| | | • CC: 36%
| | | • Silk: 31%
| | | • None: 5%
| | | Skin closure
| | | G1:
| | | • Subcut: 25%
| | | • Interr: 68%
| | | • Both: 3%
| | | • None: 3%
| | | G2:
| | | • Subcut: 25%
| | | • Interr: 67%
| | | • Both: 4%
| | | • None: 4%
| | | Midwife
| | | G1:30%
| | | G2:30%
| | | SHO
| | | G1:55%
| | | G2:57%
| | | GP
| | | G1:4%
| | | G2:3%
| | | Registrar
| | | G1:11%
| | | G2:9%
| | | Student
| | | G1:0%
| | | G2:0%
Author | Age (mean ± SD) | Mode of delivery | Episiotomy rate | [underlined: Short term (NR)] | [underlined: Short term] | [underlined: Short term] | [underlined: Short term] | [underlined: Short term: (3 days)] | Overall quality
Ping and Kee, 1975 | G1:26.7yrs ± 4.9 | G1: | (all mediolateral | Patients without pain at the episiotomy site | NR | NR | NR | Ease of movement | Fair
Setting | G2:26.4yrs ± 4.8 | • Spont: 66% | G1:100% | G1:13% | [underlined: Long term] | [underlined: Long term] | [underlined: Long term] | Good | Randomization approach and implementation
Malaysia | Primiparous | • Vacuum: 8%, | G2:100% | G2:1.6% | NR | NR | NR | G1:66% | Fair
Study design | G1:Nulliparous: 59% | • Forceps: 23% | | P < 0.05 | | | | G2:56% | Masking
RCT | G2:Nulliparous: 65% | • Breech: 3% | | Deg of pain at episiotomy site | | | | Restricted | NR
Inclusion criteria | | G2: | | Note: 1 = mild pain, only volunteered on questioning; 2 = mod pain, complained of when patient moved; 3 = severe, discomfort even at rest, needing analgesics | | | | G1:18% | Operational definitions and measures
Mediolateral episiotomy | | • Spont: 59% | | G1:1.207 | | | | G2:56% | Good
Exclusion criteria | | • Vacuum: 8% | | G2:1.666 | | | | Very restricted | Post-randomization exclusions
• Additional lacerations | | • Forceps: 26% | | P < 0.05 | | | | G1:0% | No
• Exts | | • Breech: 7% | | [underlined: Long term] | | | | G2:5% | Retention of participants
Groups | | Birthweight | | NR | | | | P < 0.01 | 18 to 36 hrs
G1:PGA (Dexon) | | NR | | | | | | [underlined: Long term] | G1:61 (100%)
G2:CC (Ethicon) | | | | | | | | NR | G2:61 (100%)
N at randomization
G1:61
G2:61
Total: 122
Note: Not explicitly stated but can be inferred from first paragraph of results section
Followup
18 to 36 hrs
Author | Age (mean ± SD) | Mode of delivery | Episiotomy rate | [underlined: Short term: 6 wks] | [underlined: Short term] | [underlined: Short term] | [underlined: Short term] | [underlined: Short term] | Overall quality
Rogers, 1974 | G1:23.5yrs ± 4.5 | G1:NR | Midline | Pain absent in stitches | NR | NR | NR | NR | Poor
Setting | G2:22.8yrs ± 4.7 | G2:NR | G1:90% | G1:48% | [underlined: Long term] | [underlined: Long term] | [underlined: Long term] | [underlined: Long term] | Randomization approach and implementation
USA | Parity | Birthweight | G2:88% | G2:25% | NR | NR | NR | NR | Poor (suture materials in envelopes)
Study design | NR | NR | | P < 0.001 | | | | | Masking
RCT | | | | Deg of pain in stitches | | | | | NR
Inclusion criteria | | | | G1:3.35 | | | | | Operational definitions and measures
Episiotomy | | | | G2:7.08 | | | | | Fair
Exclusion criteria | | | | P < 0.001 | | | | | Post-randomization exclusions
NR | | | | [underlined: Subanalysis by type of episiotomy] | | | | | No
Groups | | | | Deg of pain for median episiotomies only | | | | | Retention of participants
G1:PGA | | | | Stitches | | | | | NR
G2:CC | | | | G1:3.13
N at randomization | | | | G2:6.39
G1:299 | | | | P <0.001
G2:301 | | | | Deg of pain for mediolateral episiotomies only
Note: These numbers were not explicitly stated in the article but can be inferred from the first paragraph of the results section | | | | Stitches
Followup | | | | G1:5.33
NR | | | | G2:12.03
| | | | P <0.001
| | | | [underlined: Subanalysis by complication in delivery]
| | | | Deg of pain in stitches in complicated delivery
| | | | G1:4.06
| | | | G2:7.75
| | | | P < 0.05
| | | | Deg of pain in stitches in uncomplicated delivery
| | | | G1:3.26
| | | | G2:7.01
| | | | P < 0.001
| | | | [underlined: Long term]
| | | | NR
| | | | *Note: Definition: At time of analgesic request up to 6 wks, deg of pain calculated as a relative pain code (1 = mild, 2 = mod, 3 = severe) summed across each site and divided by total N; in addition, a total pain factor entered by experienced obstetric nurses
Author | Age | Mode of delivery | Episiotomy rate | [underlined: Short term: Day 3] | [underlined: Short term] | [underlined: Short term: Day 3] | [underlined: Short term] | [underlined: Short term: Day 3] | Overall quality
Livingstone et al., 1974 | NR | G1: | Mediolateral | Pain definition: Measured by interview using a card with a short explanation and a choice of deg of pain felt | NR | (exam) | NR | (exam) | Poor
Setting | Parity | • Spont: 40% | G1:100% | No pain | [underlined: Long term] | Stitch line integrity | [underlined: Long term] | Ease of movement | Randomization approach and implementation
Scotland | NR | • Forceps or venthouse: 38% | G2:100% | G1:22% | NR | NS | NR | Good | Poor (lottery cards)
Study design | | • Rotation and forceps: 22% | | G2:4% | | Edema at perineotomy site | | G1:68% | Masking
RCT | | G2: | | Uncomfortable | | None | | G2:52% | Good
Inclusion criteria | | • Spont: 36% | | G1:56% | | G1:86% | | Restricted | Operational definitions and measures
• Primigravidae | | • Forceps or venthouse: 46% | | G2:48% | | G2:64% | | G1:28% | Good
• Mediolateral episiotomy | | • Rotation and forceps: 18% | | Painful | | Mod | | G2:40% | Post-randomization exclusions
Exclusion criteria | | Birthweight (mean ± SD) | | G1:18% | | G1:14% | | Very restricted | No
• Additional lacerations | | NR | | G2:26% | | G2:32% | | G1:4% | Retention of participants
• If episiotomy extended | | | | Very painful | | Marked | | G2:4% | Good
Groups | | | | G1:4% | | G1:0% | | Bad | Day 3
G1:PGA (Dexon) | | | | G2:14% | | G2:4% | | G1:0 | G1:100 (100%)
G2:Catgut (Ethicon) | | | | Unbearably painful | | [underlined: Long term] | | G2:4% | G2:100 (100%)
N at randomization | | | | G1:0% | | NR | | [underlined: Long term] | Total: 200 (100%)
G1:50 | | | | G2:8% | | | | NR
G2:50 | | | | P < 0.005
Followup | | | | [underlined: Long term]
3 days | | | | NR
Author | Age | Mode of delivery | Episiotomy rate | [underlined: Short term: Days 1 to 3] | [underlined: Short term] | [underlined: Short term] | [underlined: Short term] | [underlined: Short term] | Overall quality
Beard et al., 1974 | NR | NR | Mediolateral | N in each pain category | NR | • Wound breakdown: NS | NR | NR | Fair
Setting | Primiparous | Birthweight | G1:100% | Days 1 to 2 | [underlined: Long term] | • Inflammation: NS | [underlined: Long term] | [underlined: Long term] | Randomization approach and implementation
UK | G1:53% | NR | G2:100% | NS | NR | [underlined: Long term] | NR | NR | Poor
Study design | G2:48% | | | Day 3 | | NR | | | Masking
RCT | | | | G1: | | | | | Good
Inclusion criteria | | | | • None: 36 | | | | | Operational definitions and measures
• Mediolateral episiotomy | | | | • Slight: 54 | | | | | Good
• Normal deliveries | | | | • Mod: 10 | | | | | Post-randomization exclusions
Exclusion criteria | | | | • Severe: 0 | | | | | No
• Patients with lacerations or those booked for 48-hr discharge | | | | G2: | | | | | Retention of participants
Groups | | | | • None:28 | | | | | 3 days
G1:PGA | | | | • Slight:45 | | | | | G1:100 (100%
G2:CC | | | | • Mod: 23 | | | | | G2:100 (100%)
N at randomization | | | | • Severe:4 | | | | | Total:200 (100%)
G1:100 | | | | 0.02 > P > 0.01
G2:100 | | | | [underlined: Short term: 3 days]
Followup | | | | N of patients in perineal pain category
3 days | | | | G1:
| | | | • None/slight: 90
| | | | • Mod/severe: 10
| | | | G2:
| | | | • None/slight: 73
| | | | • Mod/severe: 27
| | | | P > 0.01
| | | | [underlined: Short term: Day 1]
| | | | N of patients requiring analgesia
| | | | None
| | | | G1:49
| | | | G2:31
| | | | Tablets
| | | | G1:46
| | | | G2:69
| | | | Injections
| | | | G1:5
| | | | G2:0
| | | | P < 0.01
| | | | [underlined: Short term: Day 2]
| | | | N of patients requiring analgesia
| | | | None
| | | | G1:63
| | | | G2:43
| | | | Tablets
| | | | G1:36
| | | | G2:57
| | | | Injections
| | | | G1:2
| | | | G2:0
| | | | P < 0.02
| | | | [underlined: Short term: Day 3]
| | | | N of patients requiring analgesia
| | | | NS
| | | | [underlined: Short term: Days 1 to 3]
| | | | N of patients requiring analgesia
| | | | None
| | | | G1:191
| | | | G2:138
| | | | Tablets
| | | | G1:103
| | | | G2:162
| | | | Injections
| | | | G1:7
| | | | G2:0
| | | | P < 0.001
| | | | [underlined: Long term]
| | | | NR

Evidence Table 10. Key Question 3: Combination of methods and materials

Study Characteristics | Demographic Characteristics | Labor and Delivery Characteristics | Episiotomy and Repair Characteristics | Pain Outcomes | Sexual Function Outcomes | Healing Outcomes | Incontinence and Pelvic Floor Outcomes | Other Outcomes | Quality and Comments
Author | Age at enrollment | Mode of delivery | NR | [underlined: Short term: Day 3] | [underlined: Short term] | [underlined: Short term: Day 3] | [underlined: Short term] | [underlined: Short term] | Overall quality
Doyle et al., 1993 | NR | Normal delivery | | Perineal pain | NR | Bruising | NR | NR | Poor
Setting | Primiparous | G1: 58% | | Mild: NS | [underlined: Long term: 3 mos] | NS | [underlined: Long term] | [underlined: Long term] | Randomization approach and implementation
UK | G1: 68% | G2: 45% | | Mod: NS | (assessed by quest) | [underlined: Long term] | NR | NR | Fair
Study design | G2: 76% | Other baseline differences in clinical characteristics | | Severe: NS | Pain | NR | | | Masking
RCT | Other demographics | NS | | “Analgesia” | NS | | | | NR
Inclusion criteria | Previous repair | Birthweight | | Mild: NS | Intercourse yet | | | | Operational definitions and measures
Female with perineal trauma following childbirth that required a surgical repair | G1: 31% | NR | | Mod: NS | NS | | | | Good
Groups | G2: 18% | | | Severe: NS | Painful now | | | | Post-randomization exclusions
G1: | | | | [underlined: Short term: Day 10] | NS | | | | Yes: Loss-to-follow-up (n = 2), declined after randomization (n = 2), third deg tear (n = 1)
• Vagina: Cont CC | | | | Perineal pain | Mild, mod, severe | | | | 3 days
• Skin: 2-layer interr CC | | | | Mild: NS | Mild: NS | | | | G1: 72
G2: | | | | Mod: NS | Mod: NS | | | | G2: 82
• Vagina: Cont CC | | | | Severe: NS | Severe: NS | | | | Total: 154 (77%)
• Skin: Subcut Prolene suture | | | | “Analgesia” | | | | | 10 days
N at randomization | | | | Mild: NS | | | | | G1: 40 (42%)
G1: 95 | | | | Mod: NS | | | | | G2: 58 (56%)
G2: 104 | | | | Severe: NS | | | | | Total: 98 (49%)
Total: 199 | | | | [underlined: Long term: 3 mos] | | | | | 3 mos
Followup | | | | (quest) | | | | | G1: 58 (61%)
3 mos | | | | Perineal pain | | | | | G2: 76 (73%)
| | | | Mild: NS | | | | | Total: 132 (66%)
| | | | Mod: NS | | | | | Retention of participants
| | | | Severe: NS | | | | | Note: The text reports total followup of 153 but the tables show a total of 154.
| | | | | | | | | 3 days
| | | | | | | | | Total: 153 (77%)
| | | | | | | | | 10 days
| | | | | | | | | Total: 98 (50%)
| | | | | | | | | 3 mos
| | | | | | | | | Total: 132 (66%)
Author | Age (mean) | Mode of delivery | Episiotomy alone | [underlined: Short term: 5 days] | [underlined: Short term] | [underlined: Short term: 5 days] | [underlined: Short term] | | Overall quality
Isager-Sally et al., 1986 | G1: 27.0 yrs | NR | G1: 95% | Perineal pain | NR | (exam) | NR | | Fair
Setting | G2: 27.5 yrs | | G2: 93% | No discomfort | [underlined: Long term: 3 mos] | Edema of perineum | [underlined: Long term: 3 mos] | | Randomization app and imp
Denmark | G3: 27.1 yrs | | G3: 95% | G1: 12% | (quest) | G1: 30% | (quest) | | Good
Study design | Primiparous | | Episiotomy and tear of perineal muscle | G2: 18% | Dyspareunia | G2: 23% | Discomfort with defecation | | Masking
RCT | G1: 60% | | G1: 3% | G3: 40% | G1: 21% | G3: 11% | G1: 5% | | Good
Inclusion criteria | G2: 60% | | G2: 5% | P < 0.001 | G2: 23% | P <0.005 | G2: 8% | | Operational defs and measures
Mediolateral episiotomy | G3: 61% | | G3: 4% | G3 was better | G3: 17% | G3 was better | G3: 4% | | No
Exclusion criteria | Previous episiotomy | | Episiotomy and partial tear of sphincter | Slight discomfort | (No individual statistic reported. Combined with other complaints and tested, P <0.025 for G2 vs. G3) | Infection of the wound | (No individual statistic reported. Combined with other complaints and tested, P <0.025 for G2 vs. G3) | | Post-randomization exclusions
NR | G1: 34% | | G1: 2% | G1: 60% | | NS | Incontinence or flatus | | Yes (98 women who left hospital before follow-up)
Groups | G2: 31% | | G2: 2% | G2: 59% | | Hematoma | G1: 14% | | Retention of participants
G1: | G3: 33% | | G3: 2% | G3: 49% | | NS | G2: 20% | | 3 days
• Vagina: Cont catgut | | | | P < 0.001 | | [underlined: Long term: 3 mos] | G3: 13% | | G1: 272 (100%)
• Muscle: Interr catgut | | | | G3 was better | | (quest) | (No individual statistic reported. Combined with other complaints and tested, P <0.025 for G2 vs. G3) | | G2: 263 (100%)
• Skin: Interr nylon | | | | Pain | | Cosmetically unsatisfactory: | Discomfort when sitting | | G3: 267 (100%)
G2: | | | | G1: 25% | | G1: 5% | G1: 2% | | Total: 802 (100%)
• Vagina: Cont PGA | | | | G2: 21% | | G2: 6% | G2: 1% | | 5 days
• Muscle: Interr PGA | | | | G3: 8% | | G3: 3% | G3: 2% | | G1: 272 (100%)
• Skin: Interr PGA | | | | P < 0.001 | | (No individual statistic reported. Combined with other complaints and tested, P <0.025 for G2 vs. G3) | (No individual statistic reported. Combined with other complaints and tested, P <0.025 for G2 vs. G3) | | G2: 263 (100%)
G3: | | | | G3 was better | | | Discomfort during micturation | | G3: 267 (100%)
• Vagina: Subcut PGA | | | | Severe pain | | | G1: 2% | | Total: 802 (100%)
• Muscle: Subcut PGA | | | | G1: 2% | | | G2: 1% | | 3 mos
• Skin: Subcut PGA | | | | G2: 2% | | | G3: 2% | | G1: 266 (100%)
N at randomization | | | | G3: 1% | | | (No individual statistic reported. Combined with other complaints and tested, P <0.025 for G2 vs. G3) | | G2: 250 (100%)
Total: 802 | | | | P < 0.001 | | | | | G3: 265 (100%)
G1: 272 | | | | G3 was better | | | | | Total: 802 (100%)
G2: 263 | | | | Hurts when sitting
G3: 267 | | | | G1: 59%
Note: 900 women were randomized but 98 were excluded because they transferred to another hospital or left the hospital before the fifth day after delivery. Three groups did not differ in age, parity, or frequency of previous episiotomy. | | | | G2: 53%
Followup | | | | G3: 28%
3 mos | | | | P < 0.001
| | | | G3 was better
| | | | Hurts when walking
| | | | G1: 42%
| | | | G2: 37%
| | | | G3: 29%
| | | | Hurts during bowel motion
| | | | G1: 17%
| | | | G2: 13%
| | | | G3: 6%
| | | | P <0.001
| | | | G3 was better
| | | | [underlined: Long term]
| | | | NR

Evidence Table 11. Key Question 4: Urinary incontinence, fecal incontinence, and pelvic floor defects

Study Characteristics | Demographic Characteristics | Labor, Delivery, and Repair Characteristics | Perineal Trauma Outcomes | Incontinence and Pelvic Floor Outcomes | Quality and comments
Author | Age (mean ± SD) | Delivery by | Third/fourth deg tear | [underlined: Short term: 3 mos] | Overall quality
Sleep et al., 1984 | G1: 26.7yrs ± 5.3y | Student and midwife | (ext through anal sphincter or through to the rectal mucosa or to the upper third of vagina) | Involuntary loss of urine | Good
Setting | G2: 26.6yrs ± 5.2y | G1: 35.9% | G1: 1 | G1: 19% | Population
UK | Primiparous | G2: 35.2% | G2: 4 | G2: 19% | Good
Study design | G1: 46.3% | Midwife | Anterior labial tears | NS | Measures
RCT | G2: 40.4% | G1: 32.1% | G1: 17.3% | Need to wear pad for loss of urine | Good
Inclusion criteria | | G2: 30.1% | G2: 26.3% | G1: 69% | Analysis
• Live singleton fetus of at least 37 wks GA | | Obstetrician | P < 0.00l | G2: 6% | Good
• Presented cephalically | | G1: 1.8% | RR = 1.52 | NS | Retention of participants
• Spont vaginal delivery expected at end of sec stage labor | | G2: 8% | (1.19 to 1.94) | [underlined: Long term] | Good
Exclusion criteria | | Other (“sister”) | | NR
• Elected episiotomy | | G1: 31.3%
• No consent | | G2: 32.7%
• Private patient | | Episiotomy rate (all mediolateral)
• Precipitate delivery | | G1: 51.4%
Groups | | G2: 10.2%
G1: Liberal (instructed to “try to prevent a tear”) | | Estimated GA
G2: Restrictive (instructed to “try to avoid episiotomy and restrict episiotomy to fetal indications”) | | G1: 39.8wks ± 1.2
N at enrollment | | G2: 39.8wks ± 1.2
G1: 502 | | Birthweight (mean ± SD)
G2: 498 | | G1: 3367g ± 4.38
Total: 1000 | | G2: 3393g ± 4.48
Followup
10 days to 3 mos
Author | Age | Mode of delivery | [underlined: Short term] | [underlined: Short term] | Overall quality
Gordon and Logue, 1985 | NS, details NR | Spont | NR | NR | Poor
Setting | Primiparious | G1: Spont: 100% | [underlined: Long term] | [underlined: Long term] | Population
UK | 100% | G2: Spont: 100% | NR | NR | Poor
Study design | | G3: Spont: 100% | | | Measures
Prospective cohort | | G4: Cesarean: 100% | | | Fair: Operator performing repair blind to allocation, mother in most cases blind to allocation
Inclusion criteria | | Birthweight (mean ± SD) | | | Analysis
• Participation in a prior prospective study of perineal wound healing | | NS, details NR | | | Poor
• European primipara | | Suture type | | | Retention of participants
• All degs of perineal trauma | | NR | | | Good
Exclusion criteria
NR
Groups
G1: Intact perineum
G2: Sec deg perineal laceration
G3: Episiotomy assisted with normal vaginal delivery
G4: LSCS
N at enrollment
G1: 14
G2: 14
G3: 14
G4: 14
Control: 14
Total: 70
Followup
1 yr
Author | Age (mean ± SD) | Episiotomy use | [underlined: Short term] | [underlined: Short term] | Overall quality
Sleep et al., 1987 | NS | G1: 12% | NR | NR | Good
Setting | G1: 27.0yrs ± 4.9 | G2: 46% | [underlined: Long term] | [underlined: Long term] | Population
UK | G2: 27.0yrs ± 5.0 | Episiotomy rate | NR | (quest) | Good
Study design | Primiparous | G1: 49% (329/674) | | Urine | Measures
RCT | G1: 41% | G2: 51% (345/674) | | <1× in past week | NA
Inclusion criteria | G2: 44% | Birthweight (mean ± SD) | | G1: 22% | Analysis
Ability to find address | Percent unmarried | G1: 3426g ± 430 | | G2: 25% | NA
Exclusion criteria | G1: 91% | G2: 3407g ± 451 | | 1 to 2 × in past week | Retention of participants
• 8 spoke little English | G2: 92% | NS | | G1: 12% | NA
• 3 gave babies up for adoption | | Estimated GA | | G2: 11%
• 1 baby was given to social services | | G1: 39.8wks ± 1.2 | | 3+ in past week
• 1 neonatal death | | G2: 46.0wks ± 1.2 | | G1: 2%
• 2 refused | | | | G2: 2%
Groups | | | | Total
G1: Restricted | | | | G1: 34%
G2: Liberal | | | | G2: 36%
N at enrollment | | | | RR = 0.97 (0.79–1.19)
G1: 329 | | | | P = 0.77
G2: 345 | | | | Incontinence of urine sufficiently severe to wear a pad, urgency and stress incontinence all NS
Total: 674
Author | Age (mean) | Mode of delivery | [underlined: Short term] | Urinary incontinence after delivery | Overall quality
Rockner, 1990 | G1: 30yrs | G1: | NR | G1: 25% | Fair
Setting | G2: 31yrs | • Spont: 83% | [underlined: Long term] | G2: 26% | Population
Sweden | Parity | • Vacuum: 16% | NR | NS | Fair
Study design | NR | • Forceps: 1% | | [underlined: Short term] | Measures
Prospective cohort | Maternal weight (mean) | G2: | | NR | Good
Inclusion criteria | G1: 61kg | • Spont: 95% | | [underlined: Long term: 4 yrs] | Analysis
Consecutive primiparas with episiotomy | G2: 63kg | • Vacuum: 5% | | quest | Poor
Exclusion criteria | Infants born since earlier study | Episiotomy use | | Urinary incontinence | Retention of participants
• Consecutive primiparas with spont tears | G1 | G1: 100% done, not specified | | • After first delivery | Good
Groups | • 0 to 39% | Birthweight (mean ± SD) | | • After sec delivery
G1: Episiotomy | • 1 to 58% | NR | | • After third delivery
G2: Spont tears | • 2 to 3% | | | • Overall
N at enrollment | • 3 to 0.7% | | | NS
G1: 157 | G2: | | | Involuntary loss of urine (coughing, laughing, sneezing)
G2: 48 | • 0 to 36% | | | NS
N responders | • 1 to 59% | | | Climbing stairs
G1: 140 | • 2 to 5% | | | NS
G2: 45 | • 3 to 0% | | | Urinary incontinence severe enough to wear a pad
Total: 185 | | | | • Sometimes
Followup | | | | • Always
4 yrs | | | | NS
| | | | Severe urinary incontinence symptoms:
| | | | • Occasionally
| | | | • Once a wk
| | | | • 2 or 3 times/wk
| | | | • > 3 times/wk
| | | | NS
Author | Age | Mode of delivery | Short term | [underlined: Short term: 8 wks] | Overall quality
Rockner et al., 1991 | NR | G1 | NR | Decrease in pelvic floor muscle | Fair
Setting | Parity | • Spont: 81% | [underlined: Long term] | (PFMS measured by weight of heaviest cone retained in vagina for 1 min while standing erect or walking) | Population
Sweden | NR | • Vacuum: 19% | NR | G1: 30.0 ± 11.8 | Fair
Study design | | G2: | | G2: 18.9 ± 9.1 | Measures
Prospective cohort | | • Spont: 92.3 % | | G3: 19.2 ± 16.2 | Good
Inclusion criteria | | • Vacuum: 7.7% | | G4: 0 | Analysis
• > 36 wks gestation | | G3: Spont: 100% | | P < 0.001 | Poor
• Every sec mother | | G4: Cesarean: 100% | | PFMS in episiotomy group continues to be significantly decreased compared with spont laceration or intact perineum | Retention of participants
Exclusion criteria | | Episiotomy rate | | [underlined: Long term] | Good
NR | | G1: 22% (21/97) | | NR | • 2 patients changed their minds
Groups | | G2: 27% (26/97) | | | • 3 had emergency cesareans
G1: Episiotomy | | G3: 25% (24/97)
G2: Spont laceration | | G4: 27% (26/97)
G3: Intact perineum | | Episiotomy rate
G4: Cesarean section | | G1: 100% mediolateral
N at enrollment | | G2: 0%
92 | | G3: 0%
N at completion | | G4: 0%
G1: 21 | | Birthweight (mean)
G2: 26 | | G1: 3596g
G3: 24 | | G2: 3640g
G4: 16 | | G3: 3366g
Followup | | G4: 3190g
8 wks
Author | Age (mean ± SD) | Episiotomy rate (all median) | Intact perineum | [underlined: Short term] | Overall quality
Klein et al., 1992 | G1a: 27.9yrs ± 3.9 | G1a: 81% | Measured at delivery | NR | Fair
Setting | G1b: 27.9yrs ± 4.4 | G1b: 52% | G1a: 12 (6.6%) | [underlined: Long term: 3 mos] | Population
Canada | G2a: 31.0yrs ± 3.7 | G2a: 47% | G1b: 13 (7.5%) | Urinary incontinence | Fair
Study design | G2b: 30.3yrs ± 9.1 | G2b: 31% | OR = 1.16 | G1a: 26 (14.5%) | Measures
RCT | Primiparous | Height | (0.48, 2.8) | G1b: 35 (21.1%) | Fair
Inclusion criteria | G1: 100% | Sig diff NR | G2a: 32 | P = 0.11 | Analysis
• 18 to 40 yrs old | G2: 100% | Weight during pregnancy | G2b: 56 | G2a: 34 (21.5) | Good
• Parity of 0, 1, 2 | Education (yrs) (Sig diff NR) | Sig diff NR | OR = 1.85 | G2b: 22 (12.9) | Retention of participants
• Single fetus | G1a: 15.4 | Previous episiotomy | (1.1, 3.2) | P = 0.04 | Fair
• Spoke English or French | G1b: 15.0 | NS | Sec deg tear | [underlined: Short term] | Overall quality
• Low medical and obstetrical risk | G2a: 15.4 | Birthweight (mean ± SD) | Measured at delivery | NR | Poor
Exclusion criteria | G2b: 15.0 | G1a: 3325g ± 416 | G1a: 22 (12.6%) | [underlined: Long term] | Population
• Prematurity (gestation < 37wks) | Stable Relationship | G1b: 3377g ± 432 | G1b: 61 (35.3%) | NR | Good
• Fetal distress | (Diff NS) | G2a: 3496g ± 449 | OR = 3.99 | | Measures
• Cesarean deliveries | Employment | G2b: 3467g ± 497 | (2.2, 7.1) | | Good
• Planned forceps | (Diff NS) | GA | G2a: 56 | | Analysis
• Medical condition developed late in pregnancy | | NS | G2b: 68 | | Fair
Groups | | | NS | | Retention of participants
G1: Primiparous | | | [underlined: Short term] | | Good
G1a: Liberal (attempted to avoid a tear/separated by parity) | | | NR
G1b: Restricted (attempted to avoid an episiotomy/separated by parity) | | | [underlined: Long term]
G2: Multiparous | | | NR
G2a: Liberal
G2b: Restricted
N at enrollment
G1a: 184
G1b: 175
G2a: 166
G2b: 178
Total: 703
Followup
1 day to 3 mos
Author | Age | Mode of delivery | See groups for rates | [underlined: Short Term] | Overall quality
Klein et al., 1994 | NR | NR | OR of third and fouth deg tears for primiparous women in the presence of episiotomy compared with those not receiving episiotomy | NR | Fair
Setting | Parity | Suture type | 22.08 (2.84, 171.53) | [underlined: Long Term] | Population
Canada | • Overall: Primiparous: 51% | NR | Third deg tears | NR | Good
Study design | • Details NR by group | Birthweight (mean ± SD) | 93/16583 (0.6%) | | Measures
Prospective cohort, secondary analysis of an RCT of liberal vs. selective midline episiotomy | Other demographics | NR | Episiotomy use (not exclusive of breech and/or instr delivery) | | Good
Inclusion criteria | • Race | | G1: 74% | | Analysis
• Parity: 0, 1, 2 | • Employment | | G2: 28% | | Fair/poor
• Low risk | • Marital status | | (P < 0.001) | | Retention of participants
• 18 to 40 yrs of age | • Intendedness of pregnancy | | | | Good
• Singleton fetus | • “No difference” | | | | Overall quality
• Spoke English or French | | | | | Poor
Exclusion criteria | | | | | Population
NR | | | | | Poor
Groups | | | | | Measures
G1: Intact | | | | | Fair
G2: Spont tear | | | | | Analysis
G3: Episiotomy alone | | | | | Poor
G4: Third or fourth deg tear | | | | | Retention of participants
N at enrollment | | | | | Good
G1: 110
G2: 208
G3: 313
G4: 66
Followup
3 mos
Author | Age (mean ± SD) | Mode of delivery | [underlined: Short term] | [underlined: Short term: 10 mos] | Overall quality
MacArthur et al., 1997 | G1a: 27.9yrs ± 5.5 | G1a: | NR | Episiotomy has no effect on incontinence | Good
Setting | G1b: 26.7yrs ± 5.2 | • Spont: 27.8% | [underlined: Long term] | [underlined: Long term] | Population
UK | G2a: 30.9yrs ± 4.8 | • Vacuum: 16.7% | NR | NR | Fair
Study design | G2b: 29.6yrs ± 4.6 | • Forceps: 27.8% | | | Measures
Cohort study, selection based on a group of symptoms including incontinence (final outcome) | Parity | • Emergency (cesarean) section: 27.8% | | | Good
Inclusion criteria | G1: Primiparous: 41% | G1b: | | | Analysis
• Delivered between April and September at a maternity hospital in Birmingham (UK) | G2: Multiparous: 59% | • Spont: 53.3% | | | Good
• After enrollment in the study, 760 women with one or more of 9 symptoms (including incontinence) within 3 mos of birth and lasting 6 wks were recruited. In addition 146 women were randomly chosen from the nonsymptomatic group | | • Vacuum: 3.2% | | | Retention of participants
Exclusion criteria | | • Forceps: 23.5% | | | Good
Women with fecal or urge incontinence related to a previous birth | | • Emergency (cesarean) section: 15.7%
Groups | | • Elective (cesarean) section: 3.8%
G1a: Primiparae new fecal incontinence | | G2a:
G1b: Primiparae, never had fecal incontinence | | • Spont: 72.2%
G2a: Multiparae, new fecal incontinence | | • Vacuum: 5.6%
G2b: Multiparae, never had fecal incontinence | | • Forceps: 16.7%
N eligible for enrollment | | • Emergency (cesarean) section: 5.6%
1667 | | G2b:
N interviewed | | • Spont: 74.1%
906 | | • Vacuum: 0.6%
Followup | | • Forceps: 4.3%
Contacted 6 to 7 mos, interviewed 45 wks on average | | • Emergency (cesarean) section: 10.7%
| | • Elective (cesarean) section: 9.7%
| | Episiotomy use
| | G1a: 33.3%
| | G1b: 36.2%
| | G2a: 27.8%
| | G2b: 10.5%
| | First stage labor ≥ 10hrs
| | Sec stage labor ≥ 2hrs
| | Active sec stage labor ≥ 2hrs
| | Head circumference
| | Birthweight (mean ± SD)
| | G1a: 3306g ± 804.7
| | G1b: 3318g ± 661.3
| | G2a: 3443.9g ± 435.3
| | G2b: 3431.7g ± 633.5
Author | Age | Mode of delivery
Viktrup and Lose, 2001 | NR | NR
Setting | Nulliparous | Suture type
Denmark | G1: 100% | NR
Study design | G2: 100% | Birthweight (mean ± SD)
Prospective cohort | | NR
Inclusion criteria
• Nulliparous
• 17 to 41 yrs of age
Exclusion criteria
NR
Groups (for multivariate analysis)
G1: Episiotomy
G2: No episiotomy
N at enrollment
305
Followup
5 yrs
Author | Age | Mode of delivery | Intact perineum | [underlined: Short term] NR | Overall quality Good
Eason et al., 2002 | NR | NR by groups overall | 25.7% | [underlined: Long term: 3 mos] | Population
Setting | Parity | G1: for subset for first vaginal birth | First deg tear | Frequency of incontinence of stool | Good
Canada | NR | • Spont: 52.4% | 19.2% | • None: 96.9% | Measures
Study design | | • Vacuum: 16.4% | Sec deg tear | • < once/wk: 2.3% | Good
Prospective cohort | | • Forceps: 31.2% | 27.1% | • 1 to 6 wks: 0.4% | Analysis
Inclusion criteria | | G2: for subset for first vaginal birth | Episiotomy without ext into anal sphincter | • Once daily: 0.2% | Good
• Participant of an RCT of perineal massage | | • Spont: 83.9% | 21.9% | • > once daily: 0.1% | Retention of participants
• 34 to 35 wks gestation | | • Vacuum: 10.9% | Third and fourth deg tear | Frequency of incontinence of flatus | Fair
Exclusion criteria | | • Forceps: 5.2% | 22.7% | • None: 74.5%
• NR | | Anesthesia at time of delivery (epidural) | | • < once/wk: 16.0%
Groups (multivariate analysis) | | NR by groups | | • 1 to 6 wks: 6.8%
G1: No episiotomy | | Episiotomy rate | | • Once daily: 1.2%
G2: Episiotomy | | 26.7% | | • > once daily: 1.5%
N at enrollment | | NR by groups | | Risk ratio for episiotomy
1198 | | Birthweight (mean ± SD) | | NS in univariate or multivariate models
N for prospective cohort | | NR by groups | | Risk ratio for perineal injury (classified by extent of laceration including episiotomy as a category)
949 | | | | NS in univariate models. Only third or fourth deg tears significant in multivariate models compared to intact perineum
Followup | | | | RR: 2.1 (1.4–3.1)
3 mos | | | | Adjusted risk ratio compared to spont with no episiotomy
| | | | • Spont with episiotomy: 9.6 (3.2, 28.5)
| | | | • Vacuum with no episiotomy: 7.4 (1.9, 28.5)
| | | | • Vacuum with episiotomy: 15.7 (4.6, 53.2)
| | | | • Forceps with no episiotomy: 12.3 (3.0, 50.4)
| | | | • Forceps with episiotomy: 25.3 (8.9, 72.0)
Author | Age | Mode of delivery | [underlined: Short term] | [underlined: Short term] | Overall quality
Fleming et al., 2003 | G1: 28.8yrs | Overall | NR | NR | Fair
Setting | G2: 29.8yrs | Cesarean: 9.8% | [underlined: Long term] | [underlined: Long term] | Population
USA | (weighted mean of means calculated) | Suture type | NR | NR | Poor
Study design | Parity | NR | | | Measures
Prospective cohort | NR | Women with episiotomy had higher muscle function scores AP than other groups, reason for this unclear | | | Good
Inclusion criteria | | Birthweight (mean ± SD) | | | Analysis
• Singleton pregnancies | | G1: 8.1lbs ± 1.2lbs. | | | Fair
• Vertex presentation | | G2: 8.3lbs (weighted mean average) | | | Retention of participants
• Term birth | | | | | Good
• Normal pregnancies
Exclusion criteria
• Forceps/vacuum deliveries
• Epidural analgesia
• Gestational diabetes
• Preterm pregnancies
• Multiple gestations
• Medical complications
• Those requiring medical induction of labor
Groups (for multivariate analysis)
G1: Episiotomy
G2: No episiotomy
N at enrollment
102
Followup
6 mos
Author | Age (mean ± SD) | Mode of delivery | Spont laceration | [underlined: Short term: 12 wks] | Overall quality
Karacam and Eroglu 2003 | G1: 25.96yrs ± 3.9 | All 100% spont | G1: 54% | Stress incontinence | Poor
Setting | G2: 24.34yrs ± 2.7 | Types of intervention in labor | G2: 78% | G1: 24% | Population
Turkey | Multiparous | NS | P = 0.011 | G2: 30% | Poor
Study design | G1: 100% | Duration of labor | | P = 0.49 | Measures
Prospective cohort | G2: 100% | NS | | [underlined: Long term] | Poor
Inclusion criteria | Other demographics | Duration of the first stage | | NR | Analysis
• Multiparous | • Had health insurance NS | NS | | | Poor
• Resident of the relevant city boundaries | • Graduated from primary school NS | Duration of the sec stage | | | Retention of participants
• Had telephone | • Did not have paying jobs NS | NS | | | Good
• Age 18 to 35 yrs | | Involvement of women in labor
• 37 and 42 wks GA | | NS
• Singleton live birth | | Birthweight
• Birthweight 2500 to 4500g | | 2500 to 3499g
• Vaginal vertex position delivery | | G1: 59.18%
Exclusion criteria | | G2: 63.27%
• Experienced medical illness (cardiac disease, diabetes, vaginal/ perineal infection, anemia, renal disease, pre-eclampsia and/or antepartum hemorrhage during pregnancy) | | NS
• Malpresented/malpositioned babies | | 3500 to 4310g
• “Large” babies | | G1: 40.82%
• Intrauterine growth retardation | | G2: 36.73%
• Congenital abnormality | | NS
• Rigid perineal tissue | | Diameter of infant's head
• Vacuum/forceps | | NS
Groups
G1: Episiotomy (mediolateral)
G2: No episiotomy
N at enrollment
G1: 50
G2: 50
Followup
6 wks
Author | Age (mean) | Mode of delivery | [underlined: Short term] | [underlined: Short term] | Overall quality
Eason et al., 2004 | 29.8yrs | NR | NR | NR | Good
Setting | Parity | Suture type | [underlined: Long term] | [underlined: Long term: 3 mos] | Population
Canada | NR | NR | NR | Stress incontinence | Good
Study design | Other demographics | Birthweight (mean ± SD) | | G1: | Measures
Prospective cohort | Education | NR | | • 35% risk | Good
Inclusion criteria | 15.8 yrs mean education of responders | | | • Crude OR: 1.00 | Analysis
• Pregnant with or without a previous vaginal birth | | | | G2: | Good
• Delivering in five secondary and tertiary care hospitals in Quebec | | | | • 29% risk | Retention of participants
• 30 to 35 wks GA | | | | • Crude OR: 0.75 | Fair
• Participants in an RCT of perineal massage | | | | (0.54, 1.05)
Exclusion criteria | | | | Adjusted for maternal age, BMI, previous vaginal birth, timing, onset of urinary incontinence, type of delivery, duration of sec stage and episiotomy
NR | | | | G1: OR: 1.00
Groups (multivariate analysis) | | | | G2: OR: 0.68
G1: No episiotomy | | | | (0.47, 1.01)
G2: Episiotomy
Followup
3 mos
Author | Age (mean ± SD) | Mode of delivery | G2: Intact perineum: 82 | [underlined: Short term] | Overall quality
Sartore et al., 2004 | G1: 30.9yrs ± 3.9 | Spont | G2: First deg tear: 127 | NR | Poor
Setting | G2: 30.7yrs ± 4.3 | G1: 100% | G2: Sec deg tear: 56 | [underlined: Long term: 3 mos] | Population
Italy | Primiparous | G2: 100% | | Stress incontinence | Good
Study design | G1: 100% | Maternal weight before pregnancy | | G1: 12.9% | Measures
Prospective cohort | G2: 100% | NS | | G2: 12.1% | Fair
Inclusion criteria | | Weight gain in pregnancy | | OR = 1.01 | Analysis
• Primiparous | | NS | | (0.61, 1.69) | Poor
• Singleton pregnancy | | Epidural rate | | P = 0.95 | Retention of participants
• Spont vaginal delivery | | G1: 14.2% | | Urge incontinence | Good
• Fetal head in occiput anterior position | | G2: 7.9% | | G1: 1.9%
Exclusion criteria | | P = 0.023 | | G2: 0.7%
• Delivered in position other than lithotomy position | | Episiotomy type | | P = 0.23
• Cesarean delivery | | G1: Mediolateral: 100% | | Incidence of frequency and urgency
• Third and fourth deg perineal lacerations | | Birthweight (mean ± SD) | | G1: 0.8%
• Preterm breech | | G1: 3334.7g ± 429.5 | | G2: 2.3%
• Operative delivery | | G2: 3222.8g ± 428.1 | | P = 0.17
• Anal and urinary incontinence that pre-existed vaginal delivery | | P = 0.003 | | Incidence of dyspuria
• History of vaginal or anal surgery | | | | G1: 1.2%
Groups | | | | G2: 0.8%
G1: Received mediolateral episiotomy | | | | P = 0.61
G2: Intact perineum and spont perineal lacerations (first/sec deg) | | | | Anal incontinence
N at enrollment | | | | G1: 2.8%
G1: 254 | | | | G2: 1.9%
G2: 265 | | | | OR = 01.47
Followup | | | | (0.46, 4.1)
3 mos | | | | P = 0.51

Evidence Table 12. Key Question 5: Future sexual function

Study Characteristics | Demographic Characteristics | Labor, Delivery, and Repair Characteristics | Perineal Trauma Outcomes | Sexual function outcomes | Quality and Comments
Author | Age (mean ± SD) | Mode of delivery | Third/fourth deg tear | [underlined: Short term: 1 mo] | Overall quality
Sleep et al., 1984 | G1: 26.7yrs ± 5.3 | NR | (ext through anal sphincter or through to the rectal mucosa or to the upper third of vagina) | (quest) | Good
Setting | G2: 26.6yrs ± 5.2 | Delivery performed by | G1: 1 | Recommencement of sexual intercourse | Population
UK | Primiparous | Student and midwife | G2: 4 | G1: 27% | Good
Study design | G1: 46.3% | G1: 35.9% | Anterior labial tears | G2: 37% | Measures
RCT | G2: 40.4% | G2: 35.2% | G1: 17.3% | x^2^ = 8.67 | Good: Operator performing repair blind to allocation, mother in most cases blind to allocation
Inclusion criteria | | Midwife | G2: 26.3% | P < 0.01 | Analysis
• Live singleton fetus of at least 37 wks GA | | G1: 32.1% | P < 0.00l | [underlined: Long term: 3 mos] | Good
• Presented cephalically | | G2: 30.1% | RR = 1.52 | (quest) | Retention of participants
• Spont vaginal delivery expected at end of sec stage labor | | Obstetrician | (1.19 to 1.94) | Resumed sexual intercourse | Good
Exclusion criteria | | G1: 1.8% | | 90% overall, similar within groups
• Elected episiotomy | | G2: 8% | | Dyspareunia
• No consent | | Other (“sister”) | | G1: 18%
• Private patient | | G1: 31.3% | | G2: 22%
• Precipitate delivery | | G2: 32.7% | | Dyspareunia “at some time”
Groups | | Episiotomy rate (all mediolateral) | | G1: 51%
G1: Liberal (instructed to “try to prevent a tear”) | | G1: 51.4% | | G2: 52%
G2: Restrictive (instructed to “try to avoid episiotomy and restrict episiotomy to fetal indications”) | | G2: 10.2%
Followup | | Suture type
10 days to 3 mos | | NR by group
N at enrollment | | Estimated GA
G1: 502 | | G1: 39.8wks ± 1.2
G2: 498 | | G2: 39.8wks ± 1.2
N at 10 days | | Birthweight (mean ± SD)
G1: 446 | | G1: 3367g ± 438
G2: 439 | | G2: 3393g ± 4.48
N at 3 mos
G1: 457
G2: 438
N at Followup
G1: 329
G2: 345
Total: 674
Author | Age (mean ± SD) | Mode of delivery | [underlined: Short term] | [underlined: Short term] | Overall quality
Sleep et al., 1987 | NS | NR | NR | NR | Good
Setting | G1: 27.0yrs ± 4.9 | Episiotomy use | [underlined: Long term] | [underlined: Long term: 3 yrs] | Population
UK | G2: 27.0yrs ± 5.0 | G1: 12% | NR | Ever suffering painful sexual intercourse | Good
Study design | Primiparous | G2: 46% | | G1: 16% | Measures
RCT | G1: 41% | Episiotomy rate | | G2: 13% | NA: Operator performing repair blind to allocation, mother in most cases blind to allocation
Inclusion criteria | G2: 44% | (all mediolateral per Sleep et al., 1984) | | RR = 1.21 (0.84 to 1.75) | Analysis
Ability to find address | Percent unmarried | G1: 49% (329/674) | | P = 0.31 | NA
Exclusion criteria | G1: 91% | G2: 51% (345/674) | | Subanalysis of those with no more children | Retention of participants
• 8 spoke little English | G2: 92% | Birthweight (mean ± SD) | | G1: 15% | NA
• 3 gave babies up for adoption | | NS | | G2: 12%
• 1 baby was given to social services | | G1: 3426g ± 430 | | NS
• 1 neonatal death | | G2: 3407g ± 451
• 2 refused | | Estimated GA
Groups | | G1: 39.8wks ± 1.2
G1: Restricted | | G2: 46.0wks ± 1.2
G2: Liberal
Author | Age | Mode of delivery | First deg tear | [underlined: Short term] | Overall quality
Rockner et al., 1988 | (median) | G1: Vacuum: 15% | G1: Mediolateral: 15% | NR | Poor
Setting | G1: 25.5yrs | G2: Vacuum: 4% | G1: Midline: 3% | [underlined: Long term: 3 mos] | Population
Sweden | G2: 26.6yrs | NS | G2: 90% | Dyspareunia | Good
Study design | NS | Duration of sec stage labor | Third deg tear | G1: 44% | Measures
Prospective cohort | Parity | NS | G1: Mediolateral: 5% | G2: 43% | Poor
Inclusion criteria | All primiparous | Episiotomy type | G1: Midline: 0 | NS | Analysis
• ≥ 18 yrs of age | Attended antenatal classes | G1: | G2: 6% | | Poor
• ≥ 37 wks gestation | NS | • Midline: 12% | Fourth deg tear | | Retention of participants
• Singleton fetus | Feeling during pregnancy | • Mediolateral: 88% | G1: Mediolateral: 0% | | Good
• Swedish | NS | Suture type | G1: Midline: 1%
• Spont tear of ≥ 2 cm | | PGA: 100% | G2: 4%
• Consecutive | | Head circumference | Anterior (labia/clitoris)
• Primiparous | | NS | G1: Mediolateral: 18%
Exclusion criteria | | Birthweight (mean) | G1: Midline: 0
NR (refusal) | | G1: 3463g | G2: 33%
Groups | | G2: 3587g | (P < 0.05)
G1: Episiotomy | | NS
G2: Spont tear
N at enrollment
G1: 157
G2: 48
Followup
1 day to 3 mos
Author | Age (mean ± SD) | Mode of delivery | Third and fourth deg tear (partial or total rupture of the anal sphincter) | [underlined: Short term] | Overall quality
Larsson et al., 1991 | Overall: 27.2yrs ± 3.4 | NR | G1: 3.9% | Dyspareunia | Poor
Setting | Diff NS | Anesthesia at time of delivery | G2: 2.6% | G1: 16% | Population
Sweden | Primiparous | Paracervical blockade | NS | G2: 11% | Fair
Study design | G1: 52% | G1: NA | Primiparous only | P < 0.05 | Measures
Prospective cohort | G2: 30% | G2: 36.7% | G1: 4.3% | [underlined: Long term] | Poor
Inclusion criteria | G3: 38% | G3: NA | G2: 4.8% | NR | Analysis
Consecutive vaginal deliveries | | Pudendal block | NS | | Poor
Exclusion criteria | | G1: 72.4% | | | Retention of participants
Cesarean sections | | G2: 61.1% | | | Good
Groups | | G3: 53.9%
G1: Episiotomy | | P < 0.001
G2: Spont laceration | | Epidural
G3: Nontraumatic birth | | G1: 29.8%
N at enrollment | | G2: 9.7%
G1: 569 | | G3: 12.3%
G2: 627 | | P < 0.001
G3: 693 | | Episiotomy type
Followup | | G1: Mediolateral: 98%
1 to 5 days; 8 to 12 wks | | Suture type
| | NR
| | Birthweight (mean ± SD)
| | Overall: 3548g ± 518
| | Diff NS
Author | Age (mean ± SD) | Mode of delivery | Intact perineum | [underlined: Short term: 3 mos] | Overall quality
Klein et al., 1992 | G1a: 27.9yrs ± 3.9 | NR | Measured at delivery | Time to resumption of sexual intercourse | Fair
Setting | G1b: 27.9yrs ± 4.4 | Episiotomy rate (all median) | G1a: 12 (6.6%) | NS | Population
Canada | G2a: 31.0yrs ± 3.7 | G1a: 81% | G1b: 13 (7.5%) | Mean deg of pain at resumption of sexual intercourse | Fair
Study design | G2b: 30.3yrs ± 9.1 | G1b: 52% | OR = 1.16 | NS | Measures
RCT | Parity | G2a: 47% | (0.48, 2.8) | Female sexual satisfaction | Fair
Inclusion criteria | G1: Primiparous: 100% | G2b: 31% | G2a: 32 | NS | Analysis
• 18 to 40 yrs old | G2: Multiparous: 100% | Suture type | G2b: 56 | [underlined: Long term] | Good
• Parity = 0, 1, 2 | Education | NR | OR = 1.85 | NR | Retention of participants
• Single fetus | G1a: 3.0% | Height | (1.1, 3.2) | | Fair
• Spoke English or French | G1b: 3.1% | Sig diff NR | Sec deg tear
• Low medical and obstetrical risk | G2a: 3.0% | Weight during pregnancy | Measured at delivery
Exclusion criteria | G2b: 3.0% | Sig diff NR | G1a: 22 (12.6%)
• Prematurity (gestation < 37wks) | Sig diff | Previous episiotomy | G1b: 61 (35.3%)
• Fetal distress | NR | NS | OR = 3.99
• Cesarean deliveries | Stable Relationship | Birthweight (mean ± SD) | (2.2, 7.1)
• Planned forceps | Diff NS | G1a: 3325g ± 416 | G2a: 56
• Medical condition developed late in pregnancy | Employment | G1b: 3377g ± 432 | G2b: 68
Groups | Diff NS | G2a: 3496g ± 449 | NS
G1: Primiparous | | G2b: 3467g ± 497
G1a: Liberal (attempted to avoid a tear/separated by parity) | | GA
G1b: Restricted (attempted to avoid an episiotomy/ separated by parity) | | NS
G2: Multiparous
G2a: Liberal
G2b: Restricted
Author | Age | Mode of delivery | See groups for rates | [underlined: Short term: 6 wks] | Overall quality
Klein et al., 1994 | NR | NR | Odds ratio of third and fourth deg tears for primiparous women in the presence of episiotomy compared with those not receiving episiotomy | Resumed sex | Fair
Setting | Parity | Suture type | 22.08 (2.84, 171.53) | G1: 76.5% | Population
Canada | • Overall: Primiparous: 51% | NR | | G2: 62.5% | Good
Study design | • Details NR by group | Birthweight (mean ± SD) | | G3: 61.7% | Measures
Prospective cohort, secondary analysis of an RCT of liberal vs. selective midline episiotomy | Other demographics | NR | | G4: 55.4% | Good
Inclusion criteria | • Race | | | P < 0.016 | Analysis
• Parity: 0, 1, 2 | • Employment | | | Pain on first sex | Fair/poor
• Low risk | • Marital status | | | None vs. mild vs. discomforting vs. distressing (%) | Retention of participants
• 18 to 40 yrs | • Intendedness of pregnancy | | | G1: 32.7 vs. 37.6 vs. 22.8 vs. 6.9 | Good
• Singleton fetus | •“No difference” | | | G2: 20.8 vs. 27.3 vs. 27.3 vs. 24.6
• Spoke English or French | | | | G3: 14.4 vs. 22.7 vs. 34.1 vs. 28.8
Exclusion criteria | | | | G4: 8.2 vs. 23.0 vs. 39.3 vs. 29.5
NR | | | | P < 0.001
Groups | | | | [underlined: Long term: 3 mos]
G1: Intact | | | | Sexual satisfaction
G2: Spont tear | | | | Not satisfied vs. satisfied vs. very satisfied (%)
G3: Episiotomy alone | | | | G1: 5 vs. 50 vs. 45
G4: Third or fourth deg tear | | | | G2: 15.8 vs. 54.6 vs. 29.5
N at enrollment | | | | G3: 16.3 vs. 51.0 vs. 32.3
G1: 110 | | | | G4: 21.3 vs. 44.3 vs. 34.4
G2: 208 | | | | P = 0.022
G3: 313
G4: 66
Followup
3 mos
Author | Age | Mode of delivery | [underlined: Long term] | [underlined: Short term] | Overall quality
Signorello et al., 2001 | Overall | NR | NA | NA | Fair
Setting | • < 20yrs: 4.7% | Episiotomy rate | [underlined: Short term] | [underlined: Long term] | Population
USA | • 20 to 24yrs: 10.1% | 33.3% overall | NA | Sexual function at 6 mos (possibly includes pain, sexual sensation, sexual satisfaction, likelihood of reaching orgasm) | Good
Study design | • 25 to 29yrs: 28.8% | Suture type | | NS, details NR | Measures
Cohort identified retrospectively, data mostly retrospective with the exception of one time point | • 30 to 34yrs: 38.5% | NR | | | Fair
Inclusion criteria | • ≥ 35yrs: 17.9% | Birthweight (mean ± SD) | | | Analysis
• Parity: 1 | Parity | NR | | | Good
• Singleton fetus | NR | | | | Retention of participants
• Vertex | | | | | Poor
• Term
• Vaginal delivery
Exclusion criteria
NR
Groups at initial assignment
G1: Episiotomy
G2: No episiotomy but sec, third, or fourth deg spont perineal laceration
G3. Intact perineum
Groups for analysis
G1: Intact
G2: Sec deg
G3: High deg
G4: Not classified
N eligible from retrospective identified cohort
921
Followup
6 mos
Author | Age (mean ± SD) | Mode of delivery | Spont laceration | [underlined: Short term] | Overall quality
Karacam and Eroglu 2003 | G1: 25.96yrs ± 3.9 | All 100% spont | G1: 54% | Dyspareunia | Poor
Setting | G2: 24.34yrs ± 2.7 | Types of intervention in labor | G2: 78% | G1: 64.6% | Population
Turkey, L&D/MU | Parity | NS | P = 0.011 | G2: 54.2% | Poor
Study design | 100% multiparous | Duration of labor | | P = 0.299 | Measures
Prospective cohort | Other demographics | NS | | [underlined: Long term] | Poor
Inclusion criteria | • Had health insurance NS | Duration of the first stage | | NR | Analysis
• Multiparous | • Graduated from primary school | NS | | | Poor
• Resident of the relevant city boundaries | • NS | Duration of the sec stage | | | Retention of participants
• Had telephone | • Did not have paying jobs NS | NS | | | Good
• Age 18 to 35 yrs | | Involvement of women in labor
• 37 and 42 wks GA | | NS
• Singleton live birth | | Suture type
• Birthweight 2, 500g to 4, 500g | | NR
• Vaginal vertex position delivery | | Birthweight
Exclusion criteria | | 2, 500 to 3, 499g
• Experienced medical illness (cardiac disease, diabetes, vaginal/ perineal infection, anemia, renal disease, pre-eclampsia and/or antepartum hemorrhage during pregnancy) | | G1: 59.18%
• Malpresented/ malpositioned babies | | G2: 63.27%
•“Large”babies | | NS
• Intrauterine growth retardation | | 3, 500 to 4, 310g
• Congenital abnormality | | G1: 40.82%
• Rigid perineal tissue | | G2: 36.73%
• Vacuum/forceps | | NS
Groups | | Diameter of infant's head
G1: Episiotomy (mediolateral) | | NS
G2: No episiotomy
N at enrollment
G1: 50
G2: 50
Followup
1, 3, and 12 wks
Author | Age (mean ± SD) | Mode of delivery | G2: Intact perineum: 82 | [underlined: Short term: 3 mos] | Overall quality
Sartore et al., 2004 | G1: 30.9yrs ± 3.9 | Spont | G2: First deg tear: 127 | Mild dyspareunia | Good
Setting | G2: 30.7yrs ± 4.3 | G1: 100% | G2: Sec deg tear: 56 | G1: 5.9% | Population
Italy | Primiparous | G2: 100% | | G2: 2.6% | Good
Study design | G1: 100% | Birthweight (mean ± SD) | | Mod dyspareunia | Measures
Prospective cohort | G2: 100% | G1: 3334.7g ± 429.5 | | G1: 1.9% | Fair
Inclusion criteria | | G2: 3222.8g ± 428.1 | | G2: 0.8% | Analysis
• Primiparous | | P = 0.003 | | Overall dyspareunia | Good
• Singleton pregnancy | | Maternal weight before pregnancy | | G1: 7.9% | Retention of participants
• Spont vaginal delivery | | NS | | G2: 3.4% | Good
• Fetal head in occiput anterior position | | Weight gain in pregnancy | | OR = 2.43
Exclusion criteria | | NS | | (1.08, 5.45)
• Delivered in position other than lithotomy position | | Epidural rate | | P = 0.26
• Cesarean delivery | | G1: 14.2% | | [underlined: Long term]
• Third and fourth deg perineal lacerations | | G2: 7.9% | | NR
• Preterm breech | | P = 0.023
• Operative delivery | | Episiotomy type
• Anal and urinary incontinence that pre-existed vaginal delivery | | G1: Mediolateral: 100%
• History of vaginal or anal surgery
Groups
G1: Received mediolateral episiotomy
G2: Intact perineum and spont perineal lacerations (first/sec deg)
N at enrollment
G1: 254
G2: 265
Followup
3 mos

* Tables do not match text on time period