# Appendix B: Sample Abstraction Forms/Quality Rating Forms

## Systematic Review of Episiotomy Abstract Review Form

First Author: _____________________________________________________________

Journal: _________________________________________________________________

Year of Article: ________ Abstractor Initials: ___ ___ ___

1. Original research | Yes | No | Cannot Determine
(Exclude editorials, commentaries, letters to editor, reviews, etc.)
2. Includes females of reproductive age | Yes | No | Cannot Determine
3. Addresses one or more of the following. (Check all that apply.) | Yes | No | Cannot Determine
____ Outcomes of routine episiotomy (KQ1)
____ Outcomes of episiotomy incision type (KQ2)
____ Approach/outcomes of repair of perineal defects (KQ3)
____ Urinary/fecal incontinence/pelvic floor defects/prolapse (KQ4)
____ Sexual function (KQ5)
If any KQ is checked, circle “Yes” in box.
4. Study N is greater than or equal to 40 subjects. | Yes | No | Cannot Determine
5. Study published between 1950 and 2004. | Yes | No | Cannot Determine
6. If KQ1, 2 or 3 (outcomes of routine episiotomy / episiotomy incision type / repair of the perineal defect on maternal postpartum outcomes): | Yes | No | Cannot Determine
RCT study design used.
7. If KQ4 or KQ5 (outcomes of episiotomy on urinary and fecal incontinence/pelvic floor/prolaspe/sexual function): | Yes | No | Cannot Determine
____ RCT study design used
____ Prospective cohort
If either is checked, circle “Yes” in box.
8. Published in English. | Yes | No | Cannot Determine
If non-English, specify language: _______________________
Applies to key question # _____________________________

_____ CHECK HERE IF ARTICLE TO BE PULLED FOR BACKGROUND CITATION.

- IF ANY ITEMS IN GRAY BOX, THE ARTICLE IS EXCLUDED.
- IF ITEMS 7, 8 OR 9 MARKED “NO,” ARTICLE MAY BE EXCLUDED IN FUTURE.
- IF CANNOT DETERMINE, ARTICLE WILL BE PULLED FOR REVIEW.

## Systematic Review of Episiotomy: Full Text Inclusion/Exclusion Form

Article #: __________ | | First Author: ______________ | | Reviewer's Initials: ___ ___

[underlined: Criteria for Inclusion/Exclusion] | [underlined: Meets criteria]
1. Original research that includes routine episiotomy (i.e., not for distress or assisted vaginal deliveries) | Yes | No (STOP!)
(Excludes editorials, commentaries, letters to editor, reviews, etc.)
2. Addresses sequelae of vaginal child birth | Yes | No (STOP!)
3. N is greater than or equal to 40 subjects | Yes | No
4. Addresses at least one of the key questions with the appropriate study design | Yes | No
(See below to determine. If at least one line has both columns of boxes checked, circle Yes. Otherwise, circle No.)
5. Published in English | Yes | No
If no, what language: _________________________
6. Published between 1950 and 2004 | Yes | No

Please check all outcomes that apply. If outcome is checked, please check if the listed design applies to the study:

Outcomes and Key Questions | | Study Design
KQ1 | [image] Outcomes of routine episiotomy | [image] RCT
KQ2 | [image] Outcomes of episiotomy incision type | [image] RCT
KQ3 | [image] Outcomes of repair and/or repair method of perineal defects | [image] RCT
KQ4 | [image] Urinary/fecal incontinence/pelvic floor defects/prolapse | [image] RCT
| | [image] Prospective cohort
KQ5 | [image] Sexual function | [image] RCT
| | [image] Prospective cohort

If “Yes” is circled for ALL criteria… | [image] Full text INCLUDED
If ANY “No” is circled… | [image] Full text EXCLUDED OR…
[image]Full text EXCLUDED but used for BACKGROUND CITATION

## SYSTEMATIC REVIEW OF EPISIOTOMY: Data Abstraction Form

### SECTION 1: ABSTRACTION IDENTIFIERS

1. Article number: _______________________________
2. Abstractor Name: _______________________________
3. Date of abstraction: __ / __ / ___
4. Name of second abstractor/reviewer: _______________________________
5. Date of review: __ / __ / ___

### SECTION 2: ARTICLE IDENTIFIERS

1. Year Published: _______________________________
2. Surname of first author: _______________________________

### SECTION 3: HEALTH & GEOGRAPHIC SETTINGS

8. Healthcare Setting
a. Labor & Delivery/Maternity Unit | [image] Yes | [image] No
b. ED | [image] Yes | [image] No
c. ICU | [image] Yes | [image] No
d. Other (Please specify :_________________________) | [image] Yes | [image] No
e. Not specified | [image] Yes | [image] No

1. Where was the study conducted? (List all countries)
  _____________________________________________
  _____________________________________________
  _____________________________________________
  _____________________________________________

### SECTION 4: FUNDING SOURCE

10. What is the funding source of the study? (Mark all that apply)
| a. Industry | [image] Yes | [image] No
| b. Government | [image] Yes | [image] No
| c. Professional Society | [image] Yes | [image] No
| d. Hospital/Managed Care Organization | [image] Yes | [image] No
| e. Foundation | [image] Yes | [image] No
| f. Consumer/Patient Organization | [image] Yes | [image] No
| g. Not reported | [image] Yes | [image] No
| h. Unclear | [image] Yes | [image] No
| i. Other (specify): ___________________________________ | [image] Yes | [image] No

### SECTION 5: OBJECTIVE OF THE STUDY

1. _______________________________________________________________________________
  __________________________________________________________________________________
  __________________________________________________________________________________
  __________________________________________________________________________________
  __________________________________________________________________________________
  __________________________________________________________________________________

### SECTION 6: INCLUSION/EXCLUSION CRITERIA, STUDY DESIGN, DATA COLLECTION

1. Inclusion Criteria
  __________________________________________________
  __________________________________________________
  __________________________________________________
  __________________________________________________
2. Exclusion Criteria
  __________________________________________________
  __________________________________________________
  __________________________________________________
  __________________________________________________

14. Is the study an RCT? | [image] Yes (Continue) | [image] No (Skip to Question #18)

1. Total number of randomization arms in this study ___________________
2. Description of each randomization arm
  Group 1: _______________________________________________________________________
  Group 2: _______________________________________________________________________
  Group 3. _______________________________________________________________________
3. Describe randomization methods
  _____________________________________________________________________________________
  _____________________________________________________________________________________
  _____________________________________________________________________________________
  _____________________________________________________________________________________
4. Describe blinding/masking methods and how maintained
  _____________________________________________________________________________________
  _____________________________________________________________________________________
  _____________________________________________________________________________________
  _____________________________________________________________________________________

Comments: _____________________________________________________________________________________

______________________________________________________________________________________

______________________________________________________________________________________

### SECTION 7: CHARACTERISTICS OF PARTICIPANT

| | Group #1 | Group #2 | Group #3 or Totals for Whole Study | Overall (t tests/p values were given)
19. Defining characteristic of each group/ trial arm (Please label all subsequent table columns with characteristic)
20. Age at enrollment/randomization
| a. Minimum age
| b. Maximum age
| c. Mean age
| d. Standard deviation
21. Number of participants at enrollment/randomization (see section #10 on page 9 for numbers of participants available at followup)
22. Race (Record as presented in article, as N or %. Follow percent with %. If race categories do not match the below list, please describe each category as explained in the article)*
| a. White
| b. Hispanic
| c. African-American
| d. Asian
| e. Native American
| f. Other (describe)
23. Parity (Record as presented in article, as N or %. Follow percent with %)*
| a. Nulliparous
| b. Primiparous
| c. Multiparous
24. Education (please describe categories)
| a.
| b.
| c.
| d.
| e.
| f.
| g.
Don't forget to label your columns! [image] | | Group #1 _____________ _____________ _____________ _____________ _____________ | Group #2 _____________ _____________ _____________ _____________ _____________ | Group #3 or Totals for Whole Study _____________ _____________ _____________ | Overall (t tests/p values were given)
25. Other demographic variable #1 (please describe)
26. Other demographic variable #2 (please describe)
27. Other demographic variable #3 (please describe)

* If percent is calculated from the numbers abstracted from the table, please describe how calculated.

Comments: _______________________________________________________________________________

__________________________________________________________________________________________

__________________________________________________________________________________________

### SECTION 8: CHARACTERISTICS OF LABOR & DELIVERY

Don't forget to label your columns! [image] | | Group #1 _____________ _____________ _____________ _____________ _____________ | Group #2 _____________ _____________ _____________ _____________ _____________ | Group #3 or Totals for Whole Study _____________ _____________ _____________ | Overall (t tests/p values were given)
28. Duration of second stage labor (Describe definition from article and list quantitative values if possible)
29. Delivery attendant (Record as presented in article, as N or %. Follow percent with %. If categories below do no match those presented in article, please adjust the categories)
| a. Unspecified
| b. Student
| c. Midwife
| d. Obstetrician
| e. Other (e.g., family physician…please specify)
30. Anesthesia at time of delivery (Record as presented in article, as N or %. Follow percent with %)
| a. None
| b. Local
| c. Epidural
| d. Spinal
| e. Sacral block
31. Delivery Position (Describe-will be classified at a later time. Possible positions include: dorsal/supine, horizontal, lateral, semisitting, squatting, kneeling)
32. Episiotomy use (Record as presented in article, as N or %. Follow percent with %)
| a. None
| b. Midline
| c. Mediolateral
| d. Done, not specified
33. Mode of Delivery (Record as presented in article, as N or %. Follow percent with %)
| a. Spontaneous
| b. Vacuum
| c. Forceps
| d. Other (specify)
34. Birthweight (Specify units of weight)
| a. Minimum weight
| b. Maximum weight
| c. Mean weight
| d. Standard deviation
| e. Other (please specify)
35. Estimated gestational age (specify units)
| a. Minimum age
| b. Maximum age
| c. Mean age
| d. Standard deviation
| e. Other (please specify)

Comments: _______________________________________________________________________________

_________________________________________________________________________________________

_________________________________________________________________________________________

### SECTION 9: CHARACTERISTICS OF REPAIR

Don't forget to label your columns! [image] | | Group #1 _____________ _____________ _____________ _____________ _____________ | Group #2 _____________ _____________ _____________ _____________ _____________ | Group #3 or Totals for Whole Study _____________ _____________ _____________ | Overall (t tests/p values were given)
36. Description of repair approach
37. Repair done by (Record as presented in article, as N or %. Follow percent with %. If categories below do no match those presented in article, please adjust the categories)
| a. Unspecified
| b. Student
| c. Midwife
| d. Obstetrician
| e. Other (e.g., family physician… please specify)
38. Suture Type (Record as presented in article, as N or %. Follow percent with %)
| a. Chromic catgut
| b. Polyglycolic acid
| c. Other (specify)

Comments: ______________________________________________________________________________

_________________________________________________________________________________________

_________________________________________________________________________________________

### SECTION 10: DESCRIPTION OF PARTICIPANTS AVAILABLE @ EACH POINT OF FOLLOWUP

Please describe the number of participants that contributed data to each timepoint of followup during the study and reasons for missing data if applicable. Please refer to section 7, question #20 on page 4 of this form for number of participants in each group at the time of randomization or enrollment.

Don't forget to label your columns! [image] | Group #1 _____________ _____________ _____________ _____________ _____________ | Group #2 _____________ _____________ _____________ _____________ _____________ | Group #3 or Totals for Whole Study _____________ _____________ _____________ | If data is missing, please describe why
39. Timepoint #1:
40. Timepoint #2:
41. Timepoint #3:
42. Timepoint #4:
43. Timepoint #5:

Comments: ______________________________________________________________________________

_________________________________________________________________________________________

_________________________________________________________________________________________

_________________________________________________________________________________________

_________________________________________________________________________________________

### SECTION 11: OUTCOMES (Record as presented in article, as N or %. Follow percent with %)

*Additional space for outcomes can be found in the section 11 addendum on page 16.

Definition of Outcome (Please describe how the authors defined/operationalized the outcome in the space below the outcome name) | | How is outcome measured? (e.g., visual inspection, interview) | Length of time since delivery (Specify units) | Group #1 _____________ _____________ _____________ _____________ _____________ | Group #2 _____________ _____________ _____________ _____________ _____________ | Group #3 or Totals for Whole Study _____________ _____________ _____________ | Overall (RR/OR with CI & p values where given)
44.Posterior Lacerations/Defects
| a. Intact perineum _______________________________________________________________________________________
| b. First degree tear _______________________________________________________________________________________
| c. Second degree tear _______________________________________________________________________________________
| d. Third degree tear _______________________________________________________________________________________
| e. Fourth degree tear _______________________________________________________________________________________
| f. Third/fourth degree tear combined _______________________________________________________________________________________
45. Other Lacerations/Defects
| a. Anterior _______________________________________________________________________________________
| b. Other vaginal _______________________________________________________________________________________
46. Perineal Pain (see page 17 for additional room) ___________________________________________________________________________________________________
47. Analgesia Requirements ___________________________________________________________________________________________________
48. Suturing Required ___________________________________________________________________________________________________
49. Infection ___________________________________________________________________________________________________
50. Wound breakdown ___________________________________________________________________________________________________
51. Texture/appearance of scar ___________________________________________________________________________________________________
52. Satisfaction with birth experience ___________________________________________________________________________________________________
53. Pelvic floor defects ___________________________________________________________________________________________________
54. Urinary Incontinence
| a. Stress incontinence _______________________________________________________________________________________
| b. Urgency incontinence _______________________________________________________________________________________
55. Fecal Incontinence
| a. Incontinence of flatus _______________________________________________________________________________________
56. Fecal Incontinence (continued)
| b. Incontinence of liquid stool _______________________________________________________________________________________
| c. Incontinence of formed stool _______________________________________________________________________________________
57. Dyspareunia ___________________________________________________________________________________________________
58. Recommencement of sexual intercourse ___________________________________________________________________________________________________
59. Satisfaction from sexual intercourse ___________________________________________________________________________________________________
60. Additional outcome #1 ___________________________________________________________________________________________________
61. Additional outcome #2 ___________________________________________________________________________________________________
62. Additional outcome #3 ___________________________________________________________________________________________________

### ADDENDUM: SECTION 11

Please use this table for additional information on outcomes from above

Definition of Outcome (Please describe how the authors defined/operationalized the outcome in the space below the outcome name) | How is outcome measured? (e.g., visual inspection, interview) | Length of time since delivery (Specify units) | Group #1 _____________ _____________ _____________ _____________ _____________ | Group #2 _____________ _____________ _____________ _____________ _____________ | Group #3 or Totals for Whole Study _____________ _____________ _____________ | Overall (RR/OR with CI & p values where given)
Additional information for outcome # _____ in section 11 above. (Enter a number between 42 and 60)
Additional information for outcome # _____ in section 11 above. (Enter a number between 42 and 60)
Additional information for outcome # _____ in section 11 above. (Enter a number between 42 and 60)

### PAIN ADDENDUM: SECTION 11, #46 PERINEAL PAIN

Please use this table for additional information on perineal pain

Definition of perineal pain (Please describe how the authors defined/operationalized the outcome in the space below the outcome name) | How is outcome measured? (e.g., visual inspection, interview) | Length of time since delivery (Specify units) | Group #1 _____________ _____________ _____________ _____________ _____________ | Group #2 _____________ _____________ _____________ _____________ _____________ | Group #3 or Totals for Whole Study _____________ _____________ _____________ | Overall (RR/OR with CI & p values where given)

### SECTION 12: QUALITY ASSESSMENT

Abstractor's Initials ___ ___

Article #: ________________

63. Was the randomization plan adequate? | | [image]Yes | [image] No | [image] N/A (prospective cohort)
64. Was the randomization plan carried out adequately? | | [image] Yes | [image] No | [image] N/A (prospective cohort)
65. Was similarity of groups at baseline reported? | | [image] Yes | [image] No
| a. Were statistics reported? | [image] Yes | [image] No
| b. Were there statistically significant differences between the groups at baseline? | [image] Yes | [image] No | [image] Not reported
66. Were eligibility criteria specified? | | [image] Yes | [image] No
67. Were the outcome assessors masked? | | [image] Yes | [image] No | [image] Not reported
68. Was crossover (from one group to another) reported? | | [image] Yes | [image] No
69. Was loss-to-followup reported? | | [image] Yes | [image] No
70. Please give the number of participants remaining in the analyses for each group in the study for the primary outcome (see section 10). | | Group 1 | Group 2 | Group 3
i.e.: [underlined: # remaining]
# at randomization
71. Were there post-randomization exclusions? | | [image] Yes | [image] No | [image] Not reported
72. Was intention-to-treat (ITT) analysis reported? | | [image] Yes | [image] No | [image] Not reported
73. Overall quality rating | | [image] Good | [image] Fair | [image] Poor

Assessment of Quality of Individual Articles for RCT's

Randomization Approach | | Randomization Implementation | | Masking of Outcome Assessors and/or Participants | | | Operational Definitions and Measurements
Is there description of the approach to randomization? | | Is there proven good balance with statistical significance? | | (Please circle one) | | | (Please circle one)
Yes | No | Yes | No | Good | Fair | Poor | Good | Fair | Poor
Is there a fatal flaw in the approach (such as lottery cards)? | | Is there good balance achieved as shown in table? | | NR | | | Notes:
Yes^1^ | No | Yes | No | Notes:
Explain:
Overall Randomization Approach and Implementation
(Please circle one)
Good^2^ Fair Poor
Post-Randomization Exclusions | | Loss to Follow-up: Short-term | | Loss to Follow-up: Long-term | | | Overall Quality^3^
(Please circle one) | | (Please list numbers and percentages for each follow-up time point) | | (Please list numbers and percentages for each follow-up time point) | | | (Please circle one)
Yes | No | T1 (describe): | | T1 (describe): | | | GOOD
Please describe: | | T2 (describe): | | T2 (describe): | | | FAIR
| | T3 (describe): | | T3 (describe): | | | POOR
| | T4 (describe): | | T4 (describe):

1 If fatal flaw in randomization approach exists, overall randomization approach and implementation is poor and overall quality of the article/trial is also poor

2 Approach must be described and there must be good balance in order to achieve an overall randomization and implementation score of good

3 All component ratings must be good with minimal loss to follow-up for the article/trial to receive an overall quality rating of good. If an article has one or two fair or poor ratings, an overall quality score of fair should be assigned. If an article/trial has three or more fair or poor ratings and/or large loss to follow-up, the overall quality should be poor.