# Appendix A

## Exact Search Strings

Focused search terms and results from MEDLINE

Search Terms | Results
“Episiotomy” [MeSH] Field: All Fields, Limits: English, Randomized Controlled Trial, Human | 75
“Episiotomy”[MeSH], English, Review, Human | 68
Labor Stage, Second [mh], English, Review, Human | 40
Labor Stage, Second [mh], English, Randomized Controlled Trial, Human | 58

Additional Search Terms and Results from MEDLINE

Search Number | Search Terms | Results
#1 | “Episiotomy”[MeSH:NoExp] Field: All Fields, Limits: English, Human | 676
#2 | “Episiotomy” English, Editorial, Human | 14
#3 | “Episiotomy” English, Letter, Human | 58
#4 | “Episiotomy” English, Review, Human | 68
#5 | “Episiotomy” English, Meta-Analysis, Human | 3
#6 | “Episiotomy” English, Practice Guideline, Human | 0
#7 | #2 OR #3 OR #4 OR #5 OR #6 | 140
#8 | #1 NOT #7 | 536
#9 | Repair | 138222
#10 | #1 AND #9 | 86
#11 | labor stage, second [mh] | 638
#12 | #9 AND #11 | 6

Search Terms and Results from CINAHL

Search Number | Search Terms | Results
#1 | “Episiotomy”[MeSH:NoExp] Field: All Fields, Limits: English, Human | 306

Search Terms and Results from COCHRANE

Search Number | Search Terms | Results
#1 | “Episiotomy”[MeSH:NoExp] Field: All Fields, Limits: English, Human | 49