# List of Acronyms/Abbreviations

AE | adverse events
AHRQ | Agency for Healthcare Research and Quality
CI | confidence interval
cx | control
d | day
F | female
f/u | followup
FDA | U.S. Food and Drug Administration
GaAl | gallium-aluminum
GaAs | gallium-arsenide
HeNe | helium-neon
hr | hour
LLL | low-level laser
M | male
mn | mean
mo | month
NR | not reported
NS | not significant
PMN | polymorphonuclear
QOL | quality of life
rng | range
ROM | range of motion
SC | standard care
SC | subcutaneous
SD | standard deviation
SW | software
t_c_pO_2_ | transcutaneous oxygen tension
TEP: | Technical Expert Panel
tx | treatment
U.S. | United States
US | ultrasound
UV | ultraviolet
VAC | vacuum-assisted closure
wk | week
WOCN | Wound, Ostomy and Continence Nurses Society
yr | year