# Listing of Excluded Studies

### Excluded Studies, Laser Therapy

An Y M. [Effect of He-Ne laser on the infected wound]. Chinese Journal of Physical Therapy. 1991;14(1):26-7. not a randomized controlled trial.
Babadzhanov BR, Sultanov IA. [Combined therapy of trophic ulcers with protracted healing]. Khirurgiia (Mosk) 1998; (4):42–5. non-relevant patient population
Babapour R, Glassberg E, Lask G P. Low-energy laser systems. Clin Dermatol. 1995;13(1):87-90. no primary data. [pmid: 7704862].
Basford J R. Low-energy laser treatment of pain and wounds: hype, hope, or hokum?. Mayo Clin Proc. 1986;61(8):671-5. no primary data. [pmid: 3523062].
Basford J R. Low-energy laser therapy: controversies and new research findings. Lasers Surg Med. 1989;9(1):1-5. no primary data. [pmid: 2648091].
Bulyakova NV, Zubkova SM, Azarova VS, et al. Effect of pulsed laser radiation on regeneration of injured muscles with different regeneration capacities and the state of the thymus. Dokl Biol Sci 2002; 38265–70. non-relevant study question
Chen W M. [He-Ne laser for wound]. Chinese Journal of Physical Therapy. 1994;17(4):241. not a randomized controlled trial.
Cullum N, Nelson E A, Flemming K, et al. Systematic reviews of wound care management: (5) beds; (6) compression; (7) laser therapy, therapeutic ultrasound, electrotherapy and electromagnetic therapy. Health Technol Assess. 2001;5(9):1-221. no primary data. [pmid: 11368833].
Dolan MSTaVP. Experimental placebo controlled investigation into infrared laser treatment of wound healing in ulcers. 1988. not a published article
Dolan M S T V, Pa S H J C M. Infra-red softlaser treatment of decubitus. Versus Tijdschrift Fysiotherapie. 1989;7(3):124-40. not a randomized controlled trial.
Fernando S, Hill C M, Walker R. A randomised double blind comparative study of low level laser therapy following surgical extraction of lower third molar teeth. Br J Oral Maxillofac Surg. 1993;31(3):170-2. non-relevant patient population. [pmid: 8512911].
Flemming K, Cullum N. Laser therapy for venous leg ulcers. Cochrane Database Syst Rev 2000; (2):CD001182. no primary data
Flemming K A, Cullum N A, Nelson E A. A systematic review of laser therapy for venous leg ulcers. J Wound Care. 1999;8(3):111-4. no primary data. [pmid: 10362987].
Gogia PP, Marquez RR. Effects of helium-neon laser on wound healing. Ostomy Wound Manage 1992; 38(6):33, 36, 38–41. not a randomized controlled trial
Gostishchev V K, Vert'ianov V A, Novochenko A N, et al. [Use of low-intensity laser irradiation in the treatment of suppurative wounds]. Vestn Khir Im I I Grek. 1987;138(3):61-3. not a randomized controlled trial. [pmid: 3617379].
Gostishchev V K, Vert'ianov V A, Shur V V, et al. [The helium-neon laser in the treatment of suppurative wounds]. Vestn Khir Im I I Grek. 1985;134(3):57-60. not a randomized controlled trial. [pmid: 3890341].
Howell R M, Cohen D M, Powell G L, et al. The use of low energy laser therapy to treat aphthous ulcers. Ann Dent. 1988;47(2):16-8. not a randomized controlled trial. [pmid: 3218939].
Juri H, Palma J A. CO2 laser in decubitus ulcers: a comparative study. Lasers Surg Med. 1987;7(4):296-9. non-relevant intervention. [pmid: 3683061].
Koev K, Rousseva M, Zaprianov Z, et al. Experimental study on the effect of low intensity helium-neon laser radiation on the restorative processes in the front epithelium and substantia propria of the cornea. 2. After nonperforative traumatic damage. Folia Med (Plovdiv). 1991;33(1):46-51. non-relevant study question. [pmid: 1823057].
Krol P, Franek A, Hunka-Zurawinska W, et al. [Laser's biostimulation in healing or crural ulcerations]. Pol Merkuriusz Lek. 2001;11(65):418-21. not a randomized controlled trial. [pmid: 11852812].
Lagan K M, Clements B A, McDonough S, et al. Low intensity laser therapy (830nm) in the management of minor postsurgical wounds: a controlled clinical study. Lasers Surg Med. 2001;28(1):27-32. non-relevant patient population. [pmid: 11430439].
Liu L W. [Ultraviolet or He-Ne laser therapy for 50 cases with weapon wound]. Chinese Journal of Physical Therapy. 1980;3(1):44-6. not a randomized controlled trial.
Lucas C, Criens-Poublon L J, Cockrell C T, et al. Wound healing in cell studies and animal model experiments by Low Level Laser Therapy; were clinical studies justified? a systematic review. Lasers Med Sci. 2002;17(2):110-34. no primary data. [pmid: 12143832].
Schindl A, Heinze G, Schindl M, et al. Systemic effects of low-intensity laser irradiation on skin microcirculation in patients with diabetic microangiopathy. Microvasc Res. 2002;64(2):240-6. non-relevant outcome. [pmid: 12204648].
Schindl A, Schindl M, Schind L. Phototherapy with low intensity laser irradiation for a chronic radiation ulcer in a patient with lupus erythematosus and diabetes mellitus. Br J Dermatol. 1997;137(5):840-1. not a randomized controlled trial. [pmid: 9415264].
Schindl A, Schindl M, Schon H, et al. Low-intensity laser irradiation improves skin circulation in patients with diabetic microangiopathy. Diabetes Care. 1998;21(4):580-4. non-relevant outcome. [pmid: 9571346].
Schindl A. Low-intensity laser irradiation improves skin circulation in patients with diabetic microangiopathy. Diabetes Care. 1998;21(4):580-4. non-relevant outcome. [pmid: 9571346].
Sliney D. Low level laser therapy wound treatment update. J Laser Appl. 1999;11(5):221-4. no primary data. [pmid: 10623342].
Zapryanov Z, Koev K, Tanev V, et al. An experimental study of the effect of low level helium-neon laser irradiation on the reparative processes of the cornea after perforative injury. Folia Med (Plovdiv). 1990;32(2):39-44. non-relevant study question. [pmid: 2103917].
Zimmermann M. [Studies on the therapeutic efficacy of a HeNe laser]. [German]. Deutsche Zeitschrift fur Mund-, Kiefer- und Gesichtschirurgie. 1990;14(4):313-9. non-relevant patient population.

### Excluded Articles, Vacuum-Assisted Closure

Azad S, Nishikawa H. Topical negative pressure may help chronic wound healing. BMJ. 2002;324(7345):1100. no primary data. [pmid: 11991928].
Ballard K, Baxter H. Vacuum-assisted closure. Nurs Times. 2001;97(35):51-2. not a randomized controlled trial. [pmid: 11957602].
Banwell P, Withey S, Holten I. The use of negative pressure to promote healing. Br J Plast Surg. 1998;51(1):79. no primary data. [pmid: 9577325].
Banwell P E. Topical negative pressure therapy in wound care. J Wound Care. 1999;8(2):79-84. no primary data. [pmid: 10232203].
Baxandall T. Tissue viability. Healing cavity wounds with negative pressure. Nurs Stand. 1996;11(6):49-51. not a randomized controlled trial. [pmid: 8998055].
Bonnema J, van Geel A N, Ligtenstein D A, et al. A prospective randomized trial of high versus low vacuum drainage after axillary dissection for breast cancer. Am J Surg. 1997;173(2):76-9. non-relevant comparison. [pmid: 9074367].
Buttenschoen K, Fleischmann W, Haupt U, et al. The influence of vacuum-assisted closure on inflammatory tissue reactions in the postoperative course of ankle fractures. Foot Ankle Surg. 2001;7(3):165-173. non-relevant outcom.
Collier M. Know how: vacuum-assisted closure (VAC). Nurs Times. 1997;93(5):32-3. not a randomized controlled trial. [pmid: 9069995].
Cooper S M, Young E. Topical negative pressure in the treatment of pressure ulcers. J Am Acad Dermatol. 1999;41(2 Pt 1):280. no primary data. [pmid: 10426905].
Cooper S M, Young E. Topical negative pressure. Int J Dermatol. 2000;39(12):896-8. no primary data. [pmid: 11168656].
de Vooght A, Feruzi G, Detry R, et al. Vacuum-assisted closure for abdominal wound dehiscence with prosthesis exposure in hernia surgery. Plast Reconstr Surg. 2003;112(4):1188-9. not a randomized controlled trial. [pmid: 12973257].
Deaton W R Jr, Clutts G R. Use of negative pressure as a method of draining extensive wounds. Am Surg. 1957;23(3):278-80. no primary data. [pmid: 13424976].
Deva A K, Siu C, Nettle W J. Vacuum-assisted closure of a sacral pressure sore. J Wound Care. 1997;6(7):311-2. not a randomized controlled trial. [pmid: 9325823].
Dunlop M G, Fox J N, Stonebridge P A, et al. Vacuum drainage of groin wounds after vascular surgery: a controlled trial. Br J Surg. 1990;77(5):562-3. not a vacuum-assisted wound healing device. [pmid: 2191752].
Duxbury M S, Finlay I G, Butcher M, et al. Use of a vacuum assisted closure device in pilonidal disease. J Wound Care. 2003;12(9):355. not a randomized controlled trial. [pmid: 14601229].
Erdmann D, Drye C, Heller L, et al. Abdominal wall defect and enterocutaneous fistula treatment with the Vacuum-Assisted Closure (V.A.C) system. Plast Reconstr Surg. 2001;108(7):2066-8. not a randomized controlled trial. [pmid: 11743402].
Evans D, Land L. Topical negative pressure for treating chronic wounds. Cochrane Database Syst Rev 2001; (1):CD001898. no primary data
Finnegan D. Pressure sores. 1. Positive living or negative existence? Nurs Times 1983; 79(24):51–2, 53. not a randomized controlled trial
Genecov D G, Schneider A M, Morykwas M J, et al. A controlled subatmospheric pressure dressing increases the rate of skin graft donor site reepithelialization. Ann Plast Surg. 1998;40(3):219-25. not a randomized controlled trial. [pmid: 9523602].
Giovanni U M, Demaria R G, Otman S, et al. Treament of poststernotomy wounds with negative pressure. Plast Reconstr Surg. 2002;109(5):1747. not a randomized controlled trial. [pmid: 11932637].
Greer S, Kasabian A, Thorne C, et al. The use of a subatmospheric pressure dressing to salvage a Gustilo grade IIIB open tibial fracture with concomitant osteomyelitis to avert a free flap. Ann Plast Surg. 1998;41(6):687. not a randomized controlled trial. [pmid: 9869150].
Greer SE. Whither subatmospheric pressure dressing? Ann Plast Surg 2000; 45(3):332–4; discussion 335–6. no primary data
Harlan J W. Treatment of open sternal wounds with the vacuum-assisted closure system: a safe, reliable method. Plast Reconstr Surg. 2002;109(2):710-2. no primary data. [pmid: 11818858].
Heath T, Moisidis E, Deva A. A prospective controlled trial of vacuum assisted closure (VAC) in the treatment of acute surgical wounds requiring split skin grafting. Fourth Australian Wound Management Association Conference 2002; 41. unpublished
Huang J, Yao Y Z, Huang X K. [Treatment of open fracture by vacuum sealing technique and internal fixation]. Zhongguo Xiu Fu Chong Jian Wai Ke Za Zhi. 2003;17(6):456-8. not a randomized controlled trial. [pmid: 14663941].
Kalailieff D. Vacuum-assisted closure: wound care technology for the new millennium. Perspectives (Montclair). 1998;22(3):28-9. not a randomized controlled trial.
Kamolz L P, Andel H, Haslik W, et al. Use of subatmospheric pressure therapy to prevent burn wound progression in human: first experiences. Burns. 2004;30(3):253-8. not a randomized controlled trial. [pmid: 15082354].
Kirby J P, Fantus R J, Ward S, et al. Novel uses of a negative-pressure wound care system. J Trauma. 2002;53(1):117-21. not a randomized controlled trial. [pmid: 12131402].
Kloth L C. 5 questions-and answers-about negative pressure wound therapy. Adv Skin Wound Care. 2002;15(5):226-9. no primary data. [pmid: 12368712].
McLean WC. The role of closed wound negative pressure suction in radical surgical procedures of the head and neck. Laryngoscope 1964; 7470–94. not a randomized controlled trial
Mendez-Eastman S. Guidelines for using negative pressure wound therapy. Adv Skin Wound Care. 2001;14(6):314-22. no primary data. [pmid: 11794443].
Mendez-Eastman S. New treatment for an old problem: negative-pressure wound therapy. Nursing (Lond). 2002;32(5):58-63. no primary data.
Mullner T, Mrkonjic L, Kwasny O, et al. The use of negative pressure to promote the healing of tissue defects: a clinical trial using the vacuum sealing technique. Br J Plast Surg. 1997;50(3):194-9. not a randomized controlled trial. [pmid: 9176007].
Nelson R P, Merrill D C. Use of negative pressure suction in urology. Urology. 1974;4(5):574-6. not a randomized controlled trial. [pmid: 4428556].
Neubauer G, Ujlaky R. The cost-effectiveness of topical negative pressure versus other wound-healing therapies. J Wound Care. 2003;12(10):392-3. no primary data. [pmid: 14648965].
Nienhuijs S W, Manupassa R, Strobbe L J, et al. Can topical negative pressure be used to control complex enterocutaneous fistulae?. J Wound Care. 2003;12(9):343-5. not a randomized controlled trial. [pmid: 14601226].
Patel C T, Kinsey G C, Koperski-Moen K J, et al. Vacuum-assisted wound closure. Am J Nurs. 2000;100(12):45-8. not a randomized controlled trial. [pmid: 11202784].
Philbeck T E Jr, Whittington K T, Millsap M H, et al. The clinical and cost effectiveness of externally applied negative pressure wound therapy in the treatment of wounds in home healthcare Medicare patients. Ostomy Wound Manage. 1999;45(11):41-50. no primary data, Not counted for purposes of computing percent agreement. [pmid: 10687657].
Prokuski L. Negative pressure dressings for open fracture wounds. Iowa Orthop J 2002; 2220–4. not a randomized controlled trial
Saklani AP, Delicata RJ. Vacuum assisted closure system in the management of enterocutaneous fistula. Postgrad Med J 2002; 78(925):699; author reply 699. not a randomized controlled trial
Schaum K D. Medicare Part B negative pressure wound therapy pump policy. A partner for Medicare Part A PPS. Home Healthc Nurse. 2002;20(1):57-8. no primary data. [pmid: 11839966].
Shaer W D. Inexpensive vacuum-assisted closure employing a conventional disposable closed-suction drainage system. Plast Reconstr Surg. 2001;107(1):292-3. not a randomized controlled trial. [pmid: 11176648].
Silvis R S, Potter L E, Robinson D W, et al. The use of continuous suction negative pressure instead of pressure dressing. Ann Surg. 1955;142(2):252-6. not a randomized controlled trial. [pmid: 13239059]. [pmcid: 1464994].
Skillman J, Kirkpatrick N, Coombes A, et al. Vacuum Assisted Closure (VAC) dressing for skin graft application following exenteration of the orbit. Orbit. 2003;22(1):63-5. not a randomized controlled trial. [pmid: 12759869].
Yao Y Z, Huang X K, Ma X L. [Treatment of traumatic soft tissue defect by vacuum sealing]. Zhongguo Xiu Fu Chong Jian Wai Ke Za Zhi. 2002;16(6):388-90. not a randomized controlled trial. [pmid: 12508428].