# References and Included Studies

Armstrong DG, Lavery LA, Frykberg RG, et al. VAC therapy appears to heal complex DFU. Abstract presented at the 2^nd^ World Union of Wound Healing Societies' Meeting, July 8–13, 2004; Paris, France.
Babadzhanov BR, Sultanov IA. [Combined therapy of trophic ulcers with protracted healing]. Khirurgiia (Mosk) 1998; (4):42–5.
Basford J R, Hallman H O, Sheffield C G, et al. Comparison of cold-quartz ultraviolet, low-energy laser and occlusion in wound healing in a swine model. Arch Phys Med Rehab. 1986;67:151-154.
Bayer L, Orgill DP. Has the wound VAC become the standard of care for sternal wounds? Abstract presented at the 2^nd^ World Union of Wound Healing Societies' Meeting, July 8–13, 2004; Paris, France.
Bennett S P, Griffiths G D, Schor A M, et al. Growth factors in the treatment of diabetic foot ulcers. Br J Surg. 2003;90:133-146. [pmid: 12555288].
Bihari I, Mester A R. The biostimulative effect of low level laser therapy of long-standing crural ulcers using helium neon laser, helium neon plus infrared lasers, and noncoherent light: Preliminary report of a randomized double blind comparative study. Laser Ther. 1989;1(2):97-8.
Buttenschoen K, Fleischmann W Haupt U Kinzl L Carli Buttenschoen D. <04 Article Title>. Foot & Ankle Surgery 2001; 7(3):<25 Page(s)>.
Cross K J, Mustoe T A. Growth factors in wound healing. Surg Clin N Am. 2003;83(3):202-205.
Crous L C, Malherbe C P. Laser and ultraviolet light irradiation in the treatment of chronic ulcers. South Aft J Physiother. 1988;44(3):73-7.
Cullum N, Nelson E A, Flemming K, et al. Systematic reviews of wound care management: (5) beds; (6) compression; (7) laser therapy, therapeutic ultrasound, electrotherapy and electromagnetic therapy. Health Technol Assess. 2001;5(9):1-221. [pmid: 11368833].
de Araujo T, Valencia I, Federman DG, et al. Managing the patient with venous ulcers. Ann Intern Med 138:326–334.
Deery H G 2nd, Sangeorzan J A. Saving the diabetic foot with special reference to the patient with chronic renal failure. Infect Dis Clin North Am. 2001;15(3):953-81. [pmid: 11570148].
Douglass J. Wound bed preparation: a systematic approach to chronic wounds. Br J Community Nurs. Jun. 2003;8(6 Suppl):S26-34. [pmid: 12819592].
ECRI. Occlusive dressings for the treatment of chronic wounds [technology assessment report]. Plymouth Meeting, PA: ECRI; Feb 2000; p 141.
Eells J T, Henry M M, Summerfelt T, et al. Therapeutic photobiomodulation for methanol-induced retinal toxicity. Proc Natl Acad Sci. 2003;100(6):3439-3444. [pmid: 12626762]. [pmcid: 152311].
Eginton M T, Brown K R, Seabrook G R, et al. A prospective randomized evaluation of negative-pressure wound dressings for diabetic foot wounds. Ann Vasc Surg. 2003;17(6):645-9. [pmid: 14534844].
Eming S A, Smola H, Krieg T. Treatment of chronic wounds: State of the art and future concepts. Cells Tissues Organs. 2002;172:105-117. [pmid: 12426487].
Evans D, Land L. Topical negative pressure for treating chronic wounds. Cochrane Database Syst Rev 2001; (1):CD001898.
Falanga V, Margolis D, Alvarez O, et al. Rapid healing of venous ulcers and lack of clinical rejection with an allogeneic cultured human skin equivalent. Arch Dermatol. 1998;134(3):293-300. [pmid: 9521027].
Falanga V, Sabolinski M. A bilayered living skin construct (APLIGRAF) accelerates complete closure of hard to heal venous ulcers. Wound Repair Regen. 1999;7(4):201-7. [pmid: 10781211].
Fernando S, Hill C M, Walker R. A randomised double blind comparative study of low level laser therapy following surgical extraction of lower third molar teeth. Br J Oral Maxillofac Surg. 1993;31(3):170-2. [pmid: 8512911].
Flemming K, Cullum N. Laser therapy for venous leg ulcers. Cochrane Database Syst Rev 2000; (2):CD001182.
Flemming K A, Cullum N A, Nelson E A. A systematic review of laser therapy for venous leg ulcers. J Wound Care. 1999;8(3):111-4. [pmid: 10362987].
Foo LSS, Chua BSY, Chia GT, et al. Vacuum assisted closure vs moist gauze dressing in post-operative diabetic foot wounds: Early results from a randomized controlled trial. Abstract presented at the 2^nd^ World Union of Wound Healing Societies' Meeting, July 8–13, 2004; Paris, France.
Ford C N, Reinhard E R, Yeh D, et al. Interim analysis of a prospective, randomized trial of vacuum-assisted closure versus the healthpoint system in the management of pressure ulcers. Ann Plast Surg. 2002;49(1):55-61. [pmid: 12142596].
Franek A, Krol P, Kucharzewski M. Does low output laser stimulation enhance the healing of crural ulceration? Some critical remarks. Med Eng Phys. 2002;24(9):607-15. [pmid: 12376047].
Frykberg R G, Armstrong D G, Giurini J, et al. Diabetic foot disorders: a clinical practice guideline. American College of Foot and Ankle Surgeons. J Foot Ankle Surg. 2000;39(5 Suppl):S1-60. [pmid: 11280471].
Frykberg R G. Diabetic foot ulcers: pathogenesis and management. Am Fam Physician. 2002;66(9):1655-62. Available online at: http://www.aafp.org/afp/20021101/1655.html. [pmid: 12449264].
Genecov D G, Schneider A M, Morykwas M J, et al. A controlled subatmospheric pressure dressing increases the rate of skin graft donor site reepithelialization. Ann Plast Surg. 1998;40(3):219-25. [pmid: 9523602].
Gostishchev V K, Vert'ianov V A, Novochenko A N, et al. [Use of low-intensity laser irradiation in the treatment of suppurative wounds]. Vestn Khir Im I I Grek. 1987;138(3):61-3. [pmid: 3617379].
Gostishchev V K, Vert'ianov V A, Shur V V, et al. [The helium-neon laser in the treatment of suppurative wounds]. Vestn Khir Im I I Grek. 1985;134(3):57-60. [pmid: 3890341].
Harding K G, Morris H L, Patel G K. Science, medicine and the future: healing chronic wounds. BMJ. 2002;324(7330):160-3. [pmid: 11799036]. [pmcid: 1122073].
Harris R P, Helfand M, Woolf S H, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
Henry G, Garner W L. Inflammatory mediators in wound healing. Surg Clin N Am. 2003;83(3):200-201.
Huang J, Yao Y Z, Huang X K. [Treatment of open fracture by vacuum sealing technique and internal fixation]. Zhongguo Xiu Fu Chong Jian Wai Ke Za Zhi. 2003;17(6):456-8. [pmid: 14663941].
Iusim M, Kimchy J, Pillar T, et al. Evaluation of the degree of effectiveness of Biobeam low level narrow band light on the treatment of skin ulcers and delayed postoperative wound healing. Orthopedics. 1992;15(9):1023-6. [pmid: 1437861].
Jeffcoate W J, Harding K G. Diabetic foot ulcers. Lancet. 2003;361:1545-1551. [pmid: 12737879].
Jones JE, Nelson EA. Skin grafting for venous leg ulcers. Cochrane Database Syst Rev, 2000; (2):CD001737.
Joseph E, Hamori C A, Bergman S, et al. A prospective randomized trial of vacuum-assisted closure versus standard therapy of chronic nonhealing wounds. Wounds. 2002;12(3):60-7.
Kana J S, Hutchenreiter G, Haina D, et al. Effects of lower power density laser irradiation of the healing of open skin wounds in rats. Arch Surg. 1981;122:532-535.
Lagan K M, Clements B A, McDonough S, et al. Low intensity laser therapy (830nm) in the management of minor postsurgical wounds: a controlled clinical study. Lasers Surg Med. 2001;28(1):27-32. [pmid: 11430439].
Lagan K M, McKenna T, Witherow A, et al. Low-intensity laser therapy/combined phototherapy in the management of chronic venous ulceration: a placebo-controlled study. J Clin Laser Med Surg. 2002;20(3):109-16. [pmid: 12165122].
Lantis JC, Gendics C. VAC therapy appears to facilitate STSG take when applied to venous leg ulcers. Abstract presented at the 2^nd^ World Union of Wound Healing Societies' Meeting, July 8–13, 2004; Paris, France.
Lazarus G S, Cooper D M, Knighton D R, et al. Definitions and guidelines for assessment of wounds and evaluation of healing. Arch Dermatol. 1994;130(4):489-93. [pmid: 8166487].
Lionelli G T, Lawrence W T. Wound dressings. Surg Clin N Am. 2003;83(3):192-195.
Lucas C, Coenen C H M, De Haan R J. The effect of low level laser therapy (LLLT) on stage III decubitus ulcers (pressure sores); A prospective randomised single blind, multicentre pilot study. Lasers Med Sci. 2000;15(2):94-100.
Lucas C, van Gemert M J, de Haan R J. Efficacy of low-level laser therapy in the management of stage III decubitus ulcers: a prospective, observer-blinded multicentre randomised clinical trial. Lasers Med Sci. 2003;18(2):72-7. [pmid: 12928815].
Lundeberg T, Malm M. Low-power HeNe laser treatment of venous leg ulcers. Ann Plast Surg. 1991;27(6):537-9. [pmid: 1793238].
Malm M, Lundeberg T. Effect of low power gallium arsenide laser on healing of venous ulcers. Scand J Plast Reconstr Surg Hand Surg. 1991;25(3):249-51. [pmid: 1780722].
McCallon S K, Knight C A, Valiulus J P, et al. Vacuum-assisted closure versus saline-moistened gauze in the healing of postoperative diabetic foot wounds. Ostomy Wound Manage. 2000;46(8):28-32. 34. [pmid: 11189545].
Molnar JA, Heimbach DM, Tredgett EE, et al. Prospective, randomized controlled, multicenter trial applying subatmospheric pressure to acute hand burns: An interim report. Abstract presented at the 2^nd^ World Union of Wound Healing Societies' Meeting, July 8–13, 2004; Paris, France.
Morykwas MJ, Argenta LC. Nonsurgical modalities to enhance healing and care of soft tissue wounds. J South Orthop Assoc 1997 Winter; 6(4) 279–88
Moues CM, van den Bemd GJCM, Heule F, et al. A prospective randomized trial comparing vacuum therapy to conventional moist gauze therapy. Abstract presented at the 2^nd^ World Union of Wound Healing Societies' Meeting, July 8–13, 2004; Paris, France.
Moues C M, Vos M C, van den Bemd G J, et al. Bacterial load in relation to vacuum-assisted closure wound therapy: a prospective randomized trial. Wound Repair Regen. 2004;12(1):11-7. [pmid: 14974959].
Mustoe T. Understanding chronic wounds: a unifying hypothesis on their pathogenesis and implications for therapy. Am J Surg. 2004;187S:65S-70S. [pmid: 15147994].
Niezgoda JA, the VAC Pressure Ulcer Study Group. A comparison of vacuum assisted closure therapy to moist wound care in the treatment of pressure ulcers: Preliminary results of a multicenter trial. Abstract presented at the 2^nd^ World Union of Wound Healing Societies' Meeting, July 8–13, 2004; Paris, France.
Nussbaum E L, Biemann I, Mustard B. Comparison of ultrasound/ultraviolet-C and laser for treatment of pressure ulcers in patients with spinal cord injury. Phys Ther. 1994;74(9):812-23. [pmid: 8066108].
Obdeijn MC, Braakenburg A, Feit R, et al. VAC therapy versus hydrocolloids in acute and chronic wounds. Abstract presented at the 2^nd^ World Union of Wound Healing Societies' Meeting, July 8–13, 2004; Paris, France.
Orgill DP, Bayer L. Preliminary results indicate VAC therapy facilitates faster closure of open abdominal wounds. Abstract presented at the 2^nd^ World Union of Wound Healing Societies' Meeting, July 8–13, 2004; Paris, France.
Petrie N C, Yao F, Eriksson E. Gene therapy in wound healing. Surg Clin N Am. 2003;83(3):194-199.
Pierce G F. Inflammation in nonhealing diabetic wounds. Am J Pathol. 2001;159:399-403. [pmid: 11485896]. [pmcid: 1850546].
Ratliff CR, Bryant DE, Dutcher JA, et al. Guideline for prevention and management of pressure ulcers. Wound Ostomy and Continence Nurses Society (WOCN) Clinical Practice Guideline Series; 2002.
Reiber GE, Boyko EJ, Smith DG. Lower extremity foot ulcers and amputations in diabetes. Chapter 18. In: National Diabetes Data Group (U.S.). Diabetes in America. 2d ed. Bethesda, Md.: National Institutes of Health, National Institute of Diabetes and Digestive and Kidney Diseases, 1995; NIH publication no. 95–1468.
Robinson J K, Garden J M, Taute P M, et al. Wound healing in porcine skin following low-output carbon dioxide laser radiation of the incision. Ann Plast Surg. 1987;18:499-505. [pmid: 3605985].
Schindl A, Heinze G, Schindl M, et al. Systemic effects of low-intensity laser irradiation on skin microcirculation in patients with diabetic microangiopathy. Microvasc Res. 2002;64(2):240-6. [pmid: 12204648].
Santoianni P, Monfrecola G, Martellotta D, et al. Inadequated effect of helium-neon laser on venous leg ulcers. Photodermatology 1984; 1245–9.
Stadelman W K, Digenis A G, Tobin G R. Physiology and healing dynamics of chronic cutaneous wounds. Am J Surg. 1998a;176(Suppl 2A):26S-38S. [pmid: 9777970].
Stadelman W K, Digenis A G, Tobin G R. Impediments to wound healing. Am J Surg. 1998b;176(Suppl 2A):39S-47S.
Stannard JP, Volgas DA, Robinson J, et al. Topical negative pressure therapy as a treatment for draining hematomas following surgical stabilization of skeletal trauma: Preliminary results. Abstract presented at the 2^nd^ World Union of Wound Healing Societies' Meeting, July 8–13, 2004; Paris, France.
Stannard JP, Volgas DA, Robinson J, et al. Topical negative pressure therapy as an adjunct to soft tissue healing following open reduction and internal fixation of high risk fractures: Preliminary results. Abstract presented at the 2^nd^ World Union of Wound Healing Societies' Meeting, July 8–13, 2004; Paris, France.
Stannard JP, Volgas DA, Robinson J, et al. Topical negative pressure therapy for soft tissue management of open fractures: Preliminary results. Abstract presented at the 2^nd^ World Union of Wound Healing Societies' Meeting, July 8–13, 2004; Paris, France.
Payne W. VAC therapy vs. moist wound therapy in the treatment of diabetic foot amputation wounds: Preliminary results of a multicenter trial.
Steed D L. Foundations of good ulcer care. Am J Surg. 2003a;176(Suppl A):20S-25S. [pmid: 9777969].
Steed D L. Wound-healing trajectories. Surg Clin N Am. 2003b;83(3):206-208.
U.S. Food and Drug Administration (FDA). Draft guidance for industry: Chronic cutaneous ulcer and burn wounds – Developing products for treatment. U.S. Department of Health and Human Services, Food and Drug Administration, Center for Biologicals Evaluation and Research (CBER), Center for Devices and Radiologic Health (CDRH), and Center for Drug Evaluation and Research (CDER). June 2000. Available at http://www.fda.gov/cber/gdlns/ulcburn.pdf. Last accessed 12/22/03.
Valencia I C, Falabella A, Kirsner R S, et al. Chronic venous insufficiency and venous leg ulceration. J Am Acad Dermatol. 2001;44:401-421. [pmid: 11209109].
Veves A, Falanga V, Armstrong D G, et al. Graftskin, a human skin equivalent, is effective in the management of noninfected neuropathic diabetic foot ulcers. Diabetes Care. 2001;24:290-295. [pmid: 11213881].
Vuerstaek JDD, Wuite J, Neuman H, et al. The management of recalcitrant leg ulcers. Abstract presented at the 2^nd^ World Union of Wound Healing Societies' Meeting, July 8–13, 2004; Paris, France.
Wanner M B, Schwarzl F, Strub B, et al. Vacuum-assisted wound closure for cheaper and more comfortable healing of pressure sores: a prospective study. Scand J Plast Reconstr Surg Hand Surg. 2003;37(1):28-33. [pmid: 12625392].
Williams J Z, Barbul A. Nutrition and wound healing. Surg Clin N Am. 2003;83(3):193-197.
Wound, Ostomy and Continence Nurses Society. Standard of Care: Patients with Dermal Wound; Pressure Ulcers, 1992. WOCN, Glenview, Illinois.
Wound, Ostomy and Continence Nurses Society. Standards of Care: Patients with Dermal Wound: Lower Extremity Ulcers, 1993. WOCN, Glenview, Illinois.
Wound, Ostomy and Continence Nurses Society. Venous Insufficient (Stasis) Clinical Fact Sheet, 1996. WOCN, Glenview, Illinois.
Yao Y Z, Huang X K, Ma X L. [Treatment of traumatic soft tissue defect by vacuum sealing]. Zhongguo Xiu Fu Chong Jian Wai Ke Za Zhi. 2002;16(6):388-90. [pmid: 12508428].
Zimmermann M. [Studies on the therapeutic efficacy of a HeNe laser]. [German]. Deutsche Zeitschrift fur Mund-, Kiefer- und Gesichtschirurgie. 1990;14(4):313-9.