# Acknowledgments

The research team would like to acknowledge the efforts of Kathleen M. Ziegler, Pharm.D., for clinical and technical input, editing, and layout; Claudia J. Bonnell, B.S.N., M.L.S., for information services; Maxine A. Gere, M.S., for general editorial assistance; Carol Gold-Boyd for administrative support; Tracey Perez, R.N., J.D., for program support; and Stacie Schilling Jones and Carmen Kelly, Pharm.D., of the Agency for Healthcare Research and Quality for advice as our Task Order Officers.