# Discussion

Chronic wounds are a source of major disability, morbidity, and increased risk of mortality, and thus have a significant impact on the public health and the expenditure of health care resources. There are many factors that can impede wound healing and may predispose a patient to the development of chronic wounds. Local factors include severity of wound (area/depth), viability of surrounding tissue, presence of infection or foreign body. Systemic factors include age, functional status, nutritional status, and comorbid illnesses such as diabetes and/or renal disease. Moreover, in clinical practice, there is a high degree of variability in wound treatment, and evidence that standard wound care deviates substantially from optimal guidelines. Thus, patients who present with nonhealing ulcers may actually heal with an adequate trial of optimal care.

Drawing on a draft U.S. Food and Drug Administration guidance document and other sources, this systematic review identified key features of trials that are necessary to provide good quality evidence on the effects of an intervention on wound healing. First, randomized controlled trials are required to control for the many confounding factors that affect the course of wound healing. Trials should be double-blinded or use independent blinded assessment of outcome if double-blinding is not feasible. The patient population should represent a single type of wound, since each type of wound has distinct physiologic characteristics, which may differ in their response to a particular therapy. Well-defined entry criteria or a run-in period of optimal treatment can establish whether a study population is refractory to best conventional care. The intensity and quality of care provided to study and control groups should differ only with respect to the use or absence of the intervention under study. The outcomes of greatest clinical significance are the percent of patients with complete healing and time to complete healing. Secondary outcomes such as wound size and facilitation of surgical closure are of interest, but are not sufficient.

The evidence for this systematic review consisted of 11 (n=419) randomized, controlled trials of low-level laser therapy and six (n=135) randomized, controlled trials of vacuum assisted closure. Overall, these trials were of poor quality. All six of the vacuum-assisted closure studies were rated as poor quality. Nine of 11 laser studies were rated poor quality; one was rated good and another fair. Quality concerns center on: adequacy of randomization methods, the comparability of groups at baseline and followup, use of complete healing as the primary endpoint, adjustment for confounders, and intent-to-treat analysis. Sample sizes were generally small, making it difficult to find statistically significant differences between groups. As to results, the best available trial did not show a higher probability of complete healing at 6 weeks with the addition of low-level laser treatment care compared to sham laser treatment added to standard care. Weaknesses in the available low-level laser studies were not likely to have concealed existing effects. Future studies may determine whether different dosing parameters or use of lasers other than the helium-neon and gallium-arsenide types may lead to different results. Trials using the vacuum-assisted closure device did not find a significant advantage for the intervention on the primary endpoint, complete healing, and did not consistently find significant differences on secondary endpoints. The small vacuum-assisted closure studies may have been insufficiently powered to detect differences. Given the sparse evidence for these two wound healing interventions, it is not possible to find variables in these trials that may be associated with better results.

KCI, the manufacturer of the V.A.C.® device, has shared protocol documents for 10 randomized trials in progress. These protocols cover a wide variety of wound types, including burns, pressure ulcers, diabetic ulcers, traumatic and surgical wounds, venous stasis wounds, and diabetic wounds. Large sample sizes are planned, determined by power analyses. Sophisticated randomization techniques will be used in many trials. A wide range of outcomes will be assessed, often by a blinded observer. Plans to adjust for confounders in the analysis, if necessary, are common. Concerns remain about the overly broad criteria for allowable withdrawals, including: noncompliance; worsened condition; complications; and treatment difficulties/failures. Excluding patients for these reasons may give an unrealistic sense of the effectiveness of vacuum-assisted closure therapy. However, if intention-to treat analyses are reported, these trials have the potential to substantially advance the evidence base for vacuum-assisted closure therapy.

It is notable that surprisingly large numbers of control patients achieved complete healing in these trials, implying that optimal conventional treatment is often not delivered. Of the 4 trials that reported on complete healing as an outcome, 24 of the total of 81 patients (30 percent) in the control arm had complete healing. Similar improvement in the control groups has been observed in randomized trials of other wound healing interventions. For example, in two recent trials of bioengineered skin substitute versus standard care, 38 percent and 49 percent of “refractory” ulcers, healed completely in the standard care arm. Even in wounds present for at least 1 year, a substantial minority (19 percent) healed with standard treatment.

This systematic review focused on two specific interventions for wound healing, but the issues raised in the discussion should be applied broadly. Due to the large size of populations with nonhealing and other types of wounds, the impact on healthcare expenditures is considerable. Future research should address how to improve the delivery of care, quality of care and outcomes of treatment of wounds in various settings. There is potential to reduce the frequency of nonhealing wounds and thus the overall costs of care. New interventions have the potential to improve wound care, but outcomes must be demonstrated in well-controlled randomized trials. Strategies for reducing the occurrence of wounds in various susceptible populations also have a place in the research portfolio. Given significant costs of chronic wounds, future comparisons of the cost-effectiveness of various strategies for preventing wounds, managing wounds and improving quality of care would be of value to clinical decisionmakers.