# Results

## Part I: Low-Level Laser Therapy

The first part of this chapter reviews evidence on the following questions:

In the treatment of chronic nonhealing wounds, what are the outcomes of low-level laser therapy for specific indications and patient types:

a. as a substitute for standard therapy; or
b. as an adjunct to standard therapy, compared with standard therapy alone?

### Overview

The only previous systematic reviews available on the use of laser therapy for wound healing have been produced by a single group in the United Kingdom (Flemming and Cullum, 2003; Cullum, Nelson, Flemming et al. 2001; Flemming, Cullum and Nelson, 1999). These reviews found no supportive evidence for a benefit of low level laser therapy in healing of venous leg ulcers. All 4 studies abstracted by these reviews are included in the present review.

Among excluded studies, 3 were randomized controlled trials. Two were excluded because they did not select patients with chronic wounds (Lagan, Clements, McDonough, et al., 2001; Fernando, Hill, and Walker, 1993). The third study reported only on an outcome that was not of interest to this review, skin temperature (Schindl, Heinze, Schindl et al., 2002). Four comparative studies published in foreign languages were excluded. One German study was excluded because it did not select patients with chronic wounds (Zimmerman, 1990). Three Russian studies were examined by a Russian reader who determined that subjects were not assigned to groups randomly (Babadzhanov and Sultanov, 1998; Gostishchev, Vertianov, Novochenko, et al., 1987; Gostishchev, Vertianov, Shur, et al., 1985). No other nonrandom comparative studies published in English were found. All other excluded studies were case series or case reports.

Review of search results identified a total of 11 studies (n=413; (Bihari and Mester, 1989; Crous and Malherbe, 1988; Franek, Krol, and Kucharzewski, 2002; Iusim, Kimchy, Pillar, et al., 1992; Lagan, McKenna, Witherow, et al., 2002; Lucas, Coenen, and De Haan, 2000; Lucas, van Gemert, and de Haan, 2003; Lundeberg and Malm, 1991; Malm and Lundeberg, 1991; Nussbaum, Biemann, and Mustard, 1994; Santoianni, Monfrecola, Martellotta, et al., 1984) that met study selection criteria for low-level laser therapy (Evidence Table 1).

Details about studies meeting selection criteria are provided in Evidence Tables 2–5, each of which is divided into three subsets. The “A” subsets include seven studies with placebo controls, the “B” subsets contain three studies assessing the effects of low-level laser therapy plus standard treatment versus standard treatment alone, and the “C” subsets describe one study comparing the use of ultraviolet light and low-level laser therapy. Evidence Table 2 presents patient characteristics. Evidence Table 3 focuses on treatment details. Evidence Table 4 describes outcomes assessment. Evidence Table 5 provides results. Information shown in Evidence Tables 1–5 served as the basis for study quality ratings. Study quality ratings are included in Evidence Table 6 (See Table 3, Chapter 2, Methods, for study quality criteria and ratings).

Evidence Table 1. Summary of Low-Level Laser Therapy Studies

Evidence Table 1. Summary of Low-Level Laser Therapy Studies

Study | n Randomized | Patient Selection | Control (Cx) | Treatment (Tx) | Comparable Characteristics | Allocation | Tx Description | Wound Measurement | Complete Healing | Adjustment | Intent-to-Treat
Franek, Krol, and Kucharzewski, 2002 | 65; | LE venous ulcers | Cx1: SC+sham | SC+laser | Yes: age, size | random | Cx, Tx clear | Digital, planimetry SW | NR | ? | ?
| Cx1: 22; | | Cx2: SC | | No: duration
| Cx2: 22;
| Tx: 21
Lagan, McKenna, Witherow, et al., 2002 | 15; | Chronic LE venous ulcers | SC+sham | SC+laser | ?: age, size, duration | random | Cx, Tx clear | Digital, SW, blind | NR | ? | Yes
| Cx: 7;
| Tx: 8
Malm and Lundeberg, 1991 | 42; | LE venous ulcers | SC+sham | SC+laser | Yes: age, size | random | Cx, Tx clear | Tracings, blind | Tx=Cx | ? | No
| Cx: 21; | | | | ?: duration
| Tx: 21
Lundeberg and Malm, 1991 | 46; | LE venous ulcers | SC+sham | SC+laser | Yes: age, size | random | Cx, Tx clear | Tracings, blind | Tx=Cx | ? | No
| Cx: 23; | | | | ?: duration
| Tx: 23
Bihari and Mester, 1989 | 45; | Resistant LE ulcers | SC+sham | Tx1: SC+hand laser; | ?: age, size, duration | random | Cx, Tx clear | Blind | Tx1=Cx | ? | Yes
| Cx: 15; | | | Tx2; SC+machine laser | | | | | Tx2>Cx
| Tx1: 15;
| Tx2: 15
Santoianni, Monfrecola, Martellotta, et al., 1984 | >28 | Chronic LE venous ulcers | SC+laser misdirection | Tx1: SC+1 J laser; | ?: age, size, duration | random | Cx, Tx clear | Photos, tracings | NR | ? | ?
| | | | Tx2: SC+4 J laser
Iusim, Kimchy, Pillar, et al., 1992 | 21; | Resistant postop wounds | SC+sham | Tx1: SC+red laser; | Yes: age, size | random | Cx, Tx clear | Photos | NR | ? | Yes
| Cx: 7, | | | Tx2: SC+IR laser | ?: duration
| Tx1: 8;
| Tx2: 6
Lucas, van Gemert, and de Haan, 2003 | 86; | Pressure ulcers | SC | SC+Laser | Yes: age, size, duration | Centrally random | Cx, Tx clear | Photos, tracing, blind | Tx=Cx | ? | Yes
| Cx: 47;
| Tx: 39
Nussbaum, Biemann, and Mustard, 1994 | 20; | Pressure ulcers | SC | Tx1: SC+Laser; | Yes: age, duration | random | Cx, Tx clear | Digital, blind | Tx1=Cx | ? | No
| Cx: 9 | | | Tx2: SC+US/UV | No: size | | | | Tx2=Cx
| Tx1: 6 | | | | | | | | Tx2>Tx1
| Tx2: 5
Lucas, Coenen, and De Haan, 2000 | 16 | Pressure ulcers | SC | SC+Laser | Yes: age, duration, size | random | Cx, Tx clear | Photos, tracing, blind | Tx=Cx | ? | Yes
| Cx: 8
| Tx: 8
Crous and Malherbe, 1988 | 6 | Chronic LE venous ulcers | SC+UV | SC+Laser | ?: age, duration, size | random | Cx, Tx clear | Photos, blind | NR | ? | Yes
| Cx: 3
| Tx: 3

Abbreviations: See end of Report

Evidence Table 2. Low-Level Laser Therapy, Patient Characteristics

Evidence Table 2. Low-Level Laser Therapy, Patient Characteristics

Study | Comparison | Inclusion | Exclusion | n, Randomized | n, Withdrew | Age | Gender | Wound Duration | Wound Area | Wound Location
A. Placebo-Controlled Studies
Franek, Krol, and Kucharzewski, 2002; Bytom, Poland | Cx1: compressive/ topical therapy + sham laser | symptomatic venous crural ulceration; chronic venous insufficiency; ABI > 0.8, Doppler US ruled out arterial component | | 65 | | Cx1: mn 65, rng 41–88 | Cx1: 10 M, 12 F | Cx1: mn 30 mo, rng 1 wk - 18 yr | Cx1: mn 13.25 sq cm, rng 0.41–55.14 | (Cx1, Cx2, Tx): lateral ankle (4, 3, 5); medial ankle (5, 10, 4); lateral crural (4, 0, 7); medial crural (4, 1, 2); posterior crural (1, 3, 0); anterior crural (4, 5, 2); foot (0, 0, 1)
| Cx2: compressive/ topical therapy | | | Cx1: 22 | | Cx2: mn 66, rng 43–86 | Cx2: 3 M, 19 F | Cx2: mn 51 mo, rng 4 mo - 16 yr | Cx2: mn 16.20, rng 1.9–87.62
| Tx: compressive/ topical therapy + laser | | | Cx2: 22 | | Tx: mn 65, rng 44–80 | Tx: 4 M, 17 F | Tx: mn 41 mo, rng 2 wk - 24 yr | Tx: mn 15.76, rng 0.51–59.64
| | | | Tx: 21
Lagan, McKenna, Witherow, et al., 2002; Ulster, UK | Cx: standard nursing care + sham laser | 15 pts with 16 chronic venous/ mixed venous/ arterial ulcers; recruited from specialized outpatient leg ulcer clinic; age 30–85; able to attend weekly assessment; no current/ previous laser; | grossly infected wounds; medications contraindicated for laser; noncompliant pts; active/ suspected carcinoma; photosensitive skin; contra-indications for laser; referral source requests particular treatment | 15 | | Cx+Tx: mn 69.9, SD 13.8 | Cx+Tx: 5 M, 10 F | Cx+Tx: mn 11.3 mo, SD 8.5
| Tx: standard nursing care + laser | | | Cx: 7
| | | | Tx: 8
Malm and Lundeberg, 1991; Stockholm, Sweden | Cx: standard conservative treatment + sham laser | venous leg ulcers | skin allergy to standard treatment, peripheral arterial disease, rheumatoid arthritis, diabetes mellitus, traumatic venous ulcer, ankle pressure < 75 mmHg | 42 | 10 | Cx: mn 61, rng 46–76 | Cx: 9 M, 12 F | | Cx: mn 14 sq cm, rng 3–44
| Tx: standard conservative treatment + laser | | | Cx: 21 | Cx: 6 | Tx: mn 60, rng 43–77 | Tx: 10 M, 11 F | | Tx: mn 12, rng 4–52
| | | | Tx: 21 | Tx: 4
| | | | | (2 allergy to paste bandage, 7 unable to attend laser treatment regularly, 1 excessive pain)
Lundeberg and Malm, 1991; Stockholm, Sweden | Cx: standard treatment + sham laser | venous leg ulcers | skin allergy to standard treatment, peripheral arterial disease, rheumatoid arthritis, diabetes mellitus, traumatic venous ulcer | 46 | 12 | Cx: mn 54, rng 41–69 | Cx: 9 M, 14 F | | Cx: mn 11 sq cm, rng 4–36
| Tx: standard treatment + laser | | | Cx: 23 | Cx: 4 | Tx: mn 62, rng 49–73 | Tx: 8 M, 15 F | | Tx: 9, rng 3–32
| | | | Tx: 23 | Tx: 8
| | | | | (4 allergy to paste bandage, 2 excessive pain, 6 unable to attend regularly)
Bihari and Mester, 1989; Budapest, Hungary | Cx: adjuvant therapy + sham laser | crural ulcers proven resistant to conventional therapy (‘torpid’ ulcers) | | 45
| Tx1: adjuvant therapy + hand-held laser | | | Cx: 15
| Tx2: adjuvant therapy + machine-scanned laser | | | Tx1: 15
| | | | Tx2: 15
Santoianni, Monfrecola, Martellotta, et al., 1984; Naples, Italy | Cx: compresses + laser pointed away from wound | chronic venous leg ulcers; hospitalized | | ≥30 | | | | 2–23 mo
| Tx1: compresses + laser 1 J/sq cm
| Tx2: compresses + laser 4 J/sq cm
Iusim, Kimchy, Pillar, et al., 1992; Haifa | Cx: regular treatment + placebo | Postoperative wounds resistant to conventional therapy: neuropathic foot ulcer, pressure sores, venous ulcers, diabetic foot, amputation/ other surgery with delayed wound healing | | 21 pts: Cx: 7, Tx1: 8 | | Cx: mn 74.5, rng 60–87 | Cx: 4 M, 4 F | resistant to conventional therapy | Cx: mn 3.8 sq cm, rng 0.25–18
| Tx1: regular treatment + red light laser | | | Tx2: 6; | | Tx1: mn 71.1, rng 57–85 | Tx1: 3 M, 4 F | | Tx1: mn 3.2, 0.1–10.5
| Tx2: regular treatment + infrared light laser | | | 31 wounds: Cx: 11, Tx1: 9, Tx2: 11 | | Tx2: 74.5, rng 44–88 | Tx2: 4 M, 2 F | | Tx2: mn 4.7, rng 0.25–19
B. Studies of Incremental Effect over Standard Treatment
Lucas, van Gemert, and de Haan, 2003; Amsterdam, Netherlands | Cx: consensus therapies | Consecutive pts, stage III (full-thickness, into subcutaneous/fat layer) decubitus ulcers, 3 nursing homes; 1 wound/pt; no age restriction | Wound area > 30 sq cm; wound completely occluded by eschar; wound duration > 1 yr; diabetic pts with serious metabolic disorders; terminally ill pts | 86 | 5 | Cx: mn 83.5, SD 8.9, med 85, rng 49–100 | Cx: 18 M, 29 F | Cx: mn 3.3 wk, SD 5.1, med 2, rng 0.5–30, msg 3 | Cx: mn 350 sq mm, SD 378, < 100 - 17, 100–500 - 22, > 500 - 8 | (Cx, Tx): gluteal (8, 4), sacrum/ coccyx (14, 14), greater trochanter (1, 0), medial femoral condyle (0, 1), calcaneus (14, 13), lateral malleolus (5, 3), other (5, 4)
| Tx: consensus therapies + low level laser therapy | | | Cx: 47 | Cx: 3 | Tx: mn 81.3, SD 9.6, med 82, rng 49–94 | Tx: 14 M, 25 F | Tx: mn 2.9, SD 4, med 2, rng 0.5–22, msg 3 | Tx: mn 317, SD 396, < 100 - 14, 100–500 - 20, > 500 – 5
| | | | Tx: 39 | (1 died, 1 hospitalized, 1 stage IV)
| | | | (19/105 refused consent) | Tx: 2
| | | | | (1 died, 1 stage IV)
Nussbaum, Biemann, and Mustard, 1994; Toronto, Canada | Cx: standard treatment alone | hospitalized, spinal cord injury, skin wound | | 20 pts | 4 | Cx: mn 36, rng 15–46 | Cx: 5 M, 1 F | > 6 wk: Cx: 4 | Cx: mn 2.1 sq cm, rng 0.7 – 3.3 | (Cx, Tx1, Tx2): ankle (3, 1, 0); coccyx (2, 1, 2); trochanter (1, 1, 1); calf (0, 1, 0); chest (0, 1, 1); heel (0, 0, 1); ischium (0, 0, 1); thigh (0, 1, 0)
| Tx1: standard treatment + laser | | | Cx: 9 | Cx: 3 | Tx1: mn 42, rng 30–61 | Tx1: 5 M, 1 F | Tx1: 6 | Tx1: 2.8, rng 0.9 – 5.4
| Tx2: standard treatment + US/ UV-C | | | Tx1: 6 | Tx1: 1 | Tx2: mn 42.2, rng 26–59 | Tx2: 6 M, 0 F | Tx2: 6; | Tx2: 1.9, rng 0.9 – 3.1 (NS)
| | | | Tx2: 5; | (2 transferred to acute care hospitals, 2 elected surgical closure) | | | < 1 wk: Cx: 2
| | | | 22 wounds | | | | Tx1: 0
| | | | Cx: 9 | | | | Tx2: 0
| | | | Tx1: 7
| | | | Tx2: 6
Lucas, Coenen, and De Haan, 2000; Amsterdam, Netherlands | Cx: consensus treatment | consecutive pts, stage III pressure ulcers, 4 nursing homes | Wounds > 30 sq cm, wounds completely occluded by eschar, constant/ invariable ulceration > 1 yr, diabetics with serious metabolic disorders, terminal pts | 16 | | Cx: med 88, rng 72–95 | Cx: 0 M, 8 F | (wk) Cx: med 3, rng 1–10 | Cx: mn 82.5 sq mm, rng 30–527 | (Cx, Tx): gluteal (3, 1); sacrum/coccyx (2, 1); calcaneus (2, 2); medical femoral condyle (1, 1); lateral malleolus (0, 2)
| Tx: consensus treatment + LLLT | | | Cx: 8 | | Tx: med 87.5, rng 73–92 | Tx: 2 M, 6 F | Tx: med 3, rng 1–9 | Tx: mn 94, rng 9–513
| | | | Tx: 8
C. Laser Treatment versus Ultraviolet Light
Crous and Malherbe, 1988 | Cx: medical treatment + ultraviolet light | Distal lower extremity chronic venous ulcers; 5 of 6 hospitalized | | 6 | | Cx: rng 70–79 | Cx: 2 M, 1 F | Cx: rng 0.4–30 yr
| Tx: medical treatment + laser | | | Cx: 3 | | Tx: rng 65–77 | Tx: 1 M, 2 F | Tx: rng 6–12 yr
| | | | Tx: 3

Evidence Table 3. Low-Level Laser Therapy, Treatments

Evidence Table 3. Low-Level Laser Therapy, Treatments

Study | Allocation | Comparison | Control | Treatment | Treatment Regimen
A. Placebo-Controlled Studies
Franek, Krol, and Kucharzewski, 2002; Bytom, Poland | groups established at random, Cx1 and Tx groups in Dermatology Ward of same hospital, Cx2 group treated in different hospital | Cx1: compressive/topical therapy + sham laser | compressive: single layer elastic dressings; topical: baths of potassium permanganate, 0.1% copper sulfate, compresses with colistins, fibrolaan, chloramphenicol and gentamicin under a dressing; changed every few days; sham: radiation absorbing system in laser | GaA1As 810 nm, 4 J/sq cm, 65 mW; duration of treatment adjusted to ulcer size keeping dose constant | 5x/wk, mn 4.5–5.0 wk
| | Cx2: compressive/topical therapy
| | Tx: compressive/topical therapy + laser
Lagan, McKenna, Witherow, et al., 2002; Ulster, UK | prepared random allocation listing held by the physical therapist delivering the sham/laser treatment, only unblinded party, played no other role in the trial | Cx: standard nursing care + sham laser | standard nursing care: cleansing with water, debridement, dressings and/or compression bandaging; sham laser: nonemitting array | Biotherapy 3ML system (Omega Laser Systems, UK) GaA1As 660–950 nm, 12 J/sq cm, 532 mW, noncontact technique, unit maintained 0.5 cm from surface | 1x/wk, 4 wk
| | Tx: standard nursing care + laser
Malm and Lundeberg, 1991; Stockholm, Sweden | Randomized by permuted blocks | Cx: standard conservative treatment + sham laser | conservative wound care: cleaning with saline, paste bandage, elastic bandage at 15–25 mmHg; exercise program given on instruction sheet; sham laser: light removed | Irradia GaAs, 904 nm, 1.96 J/sq cm, 4 mW; laser held perpendicular to wound for 10 min | 2x/wk, 12 wk
| | Tx: standard conservative treatment + laser,
Lundeberg and Malm, 1991; Stockholm, Sweden | Assigned randomly, by permuted blocks | Cx: standard treatment + sham laser | Cleansing with saline, paste bandage followed by support bandage, exercise program | HeNe, 632.8 nm, 4 J/sq cm, 6 mW | 2x/wk, 12 wk
| | Tx: standard treatment + laser
Bihari and Mester, 1989; Budapest, Hungary | randomly divided into groups by age | Cx: adjuvant therapy + sham laser | adjuvant therapy: compressive bandages, antibiotics; sham: noncoherent nonpolarized filtered light | Hand-held Lasotronic HeNe; machine scanned Lasotronic HeNe/pulsed infrared, 904 nm, 4800 Hz, 4 J/sq cm | 1x/wk, 9 mo
| | Tx1: adjuvant therapy + hand-held laser
| | Tx2: adjuvant therapy + machine-scanned laser
Santoianni, Monfrecola, Martellotta, et al., 1984; Naples, Italy | pts randomly assigned to laser group or control group; if single ulcer < 5 cm, whole ulcer irradiated, if single ulcer > 5 cm, 1 half irradiated, other half kept as control; if bilateral ulcers, < 30% difference in area, 1 irradiated, 1 used as control (within subjects?) | Cx: compresses + laser pointed away from wound | no surgery; antiseptic compresses changed 2x/d | Valfivre LCS 25 HeNe 632.8 nm, 1 or 4 J/sq cm, 25 mW, beam expander to cover entire wound | 6 d/wk, > 1 mo
| | Tx1: compresses + laser 1 J/sq cm
| | Tx2: compresses + laser 4 J/sq cm
Iusim, Kimchy, Pillar, et al., 1992; Haifa, Israel | randomly allocated | Cx: regular treatment + placebo | patients continued to receive regular local and general treatment (Milton, Rivanol, Neomycin, H2O2, Synto, Dermalar) | Biobeam red light (660 nm, 7.5–18 mW); infrared light (940 nm, 2.7–25 mW), 7 min on continuous wave, 7 min on pulsed wave, focused on single point | 7 min cont, 7 min pulsed, daily
| | Tx1: regular treatment+red light laser
| | Tx2: regular treatment+infrared light laser
B. Studies of Incremental Effect over Standard Treatment
Lucas, van Gemert, and de Haan, 2003; Amsterdam, Netherlands | randomly assigned by central computerized telephone service; minimization performed on wound size category and treatment center | Cx: consensus therapies | consensus therapies, daily over 6 wk, based on NPUAP recommendations: pt info/instruction, wound cleansing, simple moist dressings, frequent position alteration | Combilaser C-501 GaAs, 904 nm, 1 J/sq cm, 12 × 8 mW, irradiated area 12 sq cm, 125 sec, no corticosteroids/concurrent adjunctive interventions; probe at < 1 mm from center of wound surface | 5x/wk, 6 wk
| | Tx: consensus therapies+low level laser therapy
Nussbaum, Biemann, and Mustard, 1994; Toronto, Canada | Randomly assigned | Cx: standard treatment alone | standard wound care: cleansing 2x/d with Hygeol, Jelonet moist dressings, avoidance of lying or sitting on existing ulcers; participation in rehabilitation program | plastic covered Intelect 800 cluster probe; 820 nm laser diode, 4 J/sq cm, 15 mW, treatment time 35 sec; probe in contact with wound; one exposure for small wounds; central and perimeter application for large wounds | 3x/wk, to closure
| | Tx1: standard treatment+laser
| | Tx2: standard treatment+US/ UV-C
Lucas, Coenen, and De Haan, 2000; Amsterdam, Netherlands | randomly assigned | Cx: consensus treatment | consensus treatment: information/instruction, cleansing, simple moist dressings, frequent position alteration, no additional medication (corticosteroids), no concurrent physical therapy | Combilaser C-501 GaAs, 904 nm, 830 Hz, 1 J/sq cm, 8 mW, exposure time 2 min 5 sec | 5x/wk, 6 wk
| | Tx: consensus treatment+LLLT
C. Laser Treatment Versus Ultraviolet Light
Crous and Malherbe, 1988 | Randomly referred | Cx: ultraviolet light | Medical treatment: dressings using saline, Granuflex and betadine, ultraviolet light, dose E4 for necrotic tissue, dose E1 for granulation tissue | Medical treatment, M3-UP scanning laser, 16 cm from ulcer, beam diameter 2 cm wider than ulcer, 1.4 mW, 10 min | 3x/wk, 4 wk
| | Tx: laser

Evidence Table 4. Low-Level Laser Therapy, Outcome Assessment

Evidence Table 4. Low-Level Laser Therapy, Outcome Assessment

Study | Primary Outcomes | Secondary Outcomes | Wound Measurement | Observer | F/U | Unit of Analysis | Intention-to-Treat?
A. Placebo-Controlled Studies
Franek, Krol, and Kucharzewski, 2002; Bytom, Poland | Wound area, volume, suppurative area, granulation area | | planimetry, traced transparency, digitizing tablet | | 4.5–5.0 wk | Pt | ?
Lagan, McKenna, Witherow, et al., 2002; Ulster, UK | wound surface area | visual analogue scale pain | traced on sterile transparency by one investigator following debridement; digitizing tablet; photography | analysis of wound surface area measurements completed under blinded conditions | 1, 2, 3, 4, 8, 12 wk | pt | ?
Malm and Lundeberg, 1991; Stockholm, Sweden | time to complete healing | rate of healing | tracings | tracings identified by code number to exclude observer bias | 12 wk | pt | no
Lundeberg and Malm (1991); Stockholm, Sweden | time to complete healing | rate of healing | tracings | tracings identified by code number to exclude observer bias | 12 wk | pt | no
Bihari and Mester, 1989; Budapest, Hungary | | | | independent trained technician unaware which therapy pts received | 9 mo | pt | ?
Santoianni, Monfrecola, Martellotta, et al., 1984; Naples | epithelialization | | photographs, traced transparencies | | 30 d | | no
Iusim, Kimchy, Pillar, et al., 1992; Haifa | complete healing, wound area | | photographs | | 20 d | pt (wound) | ?
B. Studies of Incremental Effect over Standard Treatment
Lucas, van Gemert, and de Haan, 2003; Amsterdam, Netherlands | absolute, relative wound area reduction | Incidence stage IV, Norton Score | 1:1 Polaroid; traced transparency | Independent evaluator outlined wound on transparency, area determined by another blinded evaluator | 6 wk | pt | ?, used last observation carried forward for Cx, not for Tx
Nussbaum, Biemann, and Mustard, 1994; Toronto, Canada | healing rate | time to complete healing | traced on transparency, digitizer tablet, stylus pen | tracings made by 1 investigator blinded to group assignment | < 20 wk, to complete healing | wound | ?
Lucas, Coenen, and De Haan, 2000; Amsterdam, Netherlands | wound area | Complete healing | 1:1 Polaroid, outlined perimeter, transposed to transparency | investigator blinded to clinical details measured wound area | 6 wk | pt | ?
C. Laser Treatment versus Ultraviolet Light
Crous and Malherbe, 1988 | ulcer size (perimeter and area) | | Photography | Physiotherapist not involved with the investigation | | pt

Evidence Table 5. Low-Level Laser Therapy, Results

Evidence Table 5. Low-Level Laser Therapy, Results

Study | Comparison | Complete Healing | | | | Wound Area
A. Placebo-Controlled Studies
Franek, Krol, and Kucharzewski, 2002; Bytom, Poland | Cx1: compressive/ topical therapy + sham laser | | | | | f/u average rate of change in relative area (%/wk):
| Cx2: compressive/ topical therapy | | | | | Cx1: 15 Tx: | Cx2: 9 | Tx: 16 (NS)
| Tx: compressive/ topical therapy + laser | | | | | average rate of change of relative suppurative area (%/wk):
| | | | | | Cx1: 19 | Cx2: 20 | Tx: 9 (NS)
Lagan, McKenna, Witherow, et al., 2002; Ulster, UK | Cx: standard nursing care + sham laser | | | | | (% change):
| Tx: standard nursing care + laser | | | | | 4 wk | Cx mn -23 | Tx mn-26
| | | | | | 8 wk | Cx mn -7 | Tx mn -45.1
| | | | | | | SEM 20.6 | SEM 16.6
| | | | | | 12 wk | Cx mn+11.6 | Tx mn-61.3
| | | | | | | SEM 41.2 | SEM 15.6
| | | | | | (p=0.14)
Malm and Lundeberg, 1991; Stockholm, Sweden | Cx: standard conservative treatment + sham laser | 12 wk | | | | (% change/wk): NS
| Tx: standard conservative treatment + laser, | | Cx | Tx
| | Dropped | 6/21 | 4/21
| | Healed | 11/21 | 13/21
| | Not healed | 4/21 | 4/21
| | Life-table analysis NS
Lundeberg and Malm, 1991; Stockholm, Sweden | Cx: standard treatment + sham laser | 12 wk | | | | (% of original ulcer size):
| Tx: standard treatment + laser | | Cx | Tx | | Cx: mn 49, SD 12
| | Dropped | 4/23 | 8/23 | | Tx: mn 48, SD 9 (NS)
| | Healed | 3/23 | 4/23
| | Not healed | 16/23 | 11/23
| | Life-table analysis NS
Bihari and Mester, 1989; Budapest, Hungary | Cx: adjuvant therapy + sham laser | | Cx | Tx1 | Tx2
| Tx1: adjuvant therapy + hand-held laser | Dropped | 2/15
| Tx2: adjuvant therapy + machine-scanned laser | Complete | 5/15 | 10/15 | 12/15
| | Improved | 3/15 | 4/15 | 2/15
| | No change | 3/15 | 1/15 | 1/15
| | Worse | 2/15 | 0/15 | 0/15
| | Complete healing:
| | RR (95% CI) Tx1:Cx: 2.0 (0.9, 4.5)
| | RR (95% CI) Tx2:Cx: 2.4 (1.1, 5.1)
Santoianni, Monfrecola, Martellotta, et al., 1984; Naples, Italy | Cx: compresses + laser pointed away from wound | | | | | (area epithelialized, sq cm, ulcer < 5 cm):
| Tx1: compresses + laser 1 J/sq cm | | | | | Cx: n=14, mn 3.3, SD 2.13
| Tx2: compresses + laser 4 J/sq cm | | | | | Tx1: n=9, mn 3.21, SD 3.15 (p<0.95)
| | | | | | Tx2: n=5, mn 4.52, SD 3.49 (p<0.5)
| | | | | | (area epithelialized, ulcer > 5 cm, by half, control vs. laser):
| | | | | | Tx1: n=7, mn (SD) 2.99 (2.55) vs. 2.3 (1.94) (NS)
| | | | | | Tx2: n=10, mn (SD) 3.03 (4.47) vs. 3.22 (4.25) (NS)
Iusim, Kimchy, Pillar, et al., 1992; Haifa, Israel | Cx: regular treatment + placebo | Cx: 3/11 | | | | (% change):
| Tx1: regular treatment + red light laser | Tx1: 3/9 | | | | Cx: mn -41
| Tx2: regular treatment + infrared light laser | Tx2: 4/11 | | | | Tx1: mn -89 (p=0.0345)
| | | | | | Tx2: mn -58 (p=0.46)
B. Studies of Incremental Effect over Standard Treatment
Lucas, van Gemert, and de Haan, 2003; Amsterdam, Netherlands | Cx: consensus therapies | | Cx | Tx | | (sq mm), Cx n=47/47, Tx n=36/39
| Tx: consensus therapies + low level laser therapy | N | 43/47 | 36/39 | | absolute improvement:
| | Complete | 15/43 | 18/36 | | | Cx | Tx
| | Incomplete | 26/43 | 12/36 | | Mn | 138 | 48
| | Larger | 2/43 | 6/36 | | SD | 270 | 394 (p=0.23)
| | | | | | relative improvement (%):
| | | | | | | Cx | Tx
| | | | | | Mn | 34 | 5
| | | | | | SD | 204 | 194 (p=0.42)
| | | | | | LN improvement:
| | | | | | | Cx | Tx
| | | | | | mn | 2.3 | 2.6
| | | | | | SD | 2.2 | 2.6 (p=0.59)
Nussbaum, Biemann, and Mustard, 1994; Toronto, Canada | Cx: standard treatment alone | | Cx | Tx1 | Tx2 | (% change/wk):
| Tx1: standard treatment + laser | Mn wks to complete healing | 7.0 | 11.0 | 4.2 | Cx: - 32.4 | Tx1: -23.7 | Tx2: -53.5
| Tx2: standard treatment + US/ UV-C | | | | | (p=0.032, Tx2 better than Tx1, Tx1 not different from Cx; Tx2 not different from Cx)
Lucas, Coenen, and De Haan, 2000; Amsterdam, Netherlands | Cx: consensus treatment | 6 wk: | | | | (% change):
| Tx: consensus treatment + LLLT | | Cx | Tx | | Cx: med 95
| | Complete | 4/8 | 3/8 | | Tx: med 83 (p=0.47)
C. Low-Level Laser Treatment, Results, Laser Treatment versus Ultraviolet Light
Crous and Malherbe, 1988 | Cx: medical treatment + ultraviolet light | | | | | (% change):
| Tx: medical treatment + laser | | | | | Cx: mn -34, SD 21
| | | | | | Tx: mn -50, SD 7

Evidence Table 6. Study Quality Ratings, Low-Level Laser Therapy

Evidence Table 6. Study Quality Ratings, Low-Level Laser Therapy

Study | Yr | Initial Assembly of Comparable Groups | Low Loss to Followup, Maintenance of Comparable Groups | Measurements Reliable, Valid, Equal | Interventions Comparable/ Clearly Defined | Appropriate Analysis of Results | Overall Rating
Franek, Krol, and Kucharzewski | 2002 | No | Yes | No | Yes | No | Poor
Lagan, McKenna, Witherow, et al. | 2002 | ? | Yes | Yes | Yes | Partial | Poor
Malm and Lundeberg | 1991 | ? | No | Partial | Yes | No | Poor
Lundeberg and Malm | 1991 | ? | No | Partial | No | No | Poor
Bihari and Mester | 1989 | ? | Yes | Partial | Yes | Partial | Poor
Santoianni, Monfrecola, Martellotta, et al. | 1984 | ? | ? | No | Yes | No | Poor
Iusim, Kimchy, Pillar, et al. | 1992 | No | Yes | No | No | Partial | Poor
Lucas, van Gemert, and de Haan | 2003 | Yes | Yes | Yes | Yes | Yes | Good
Nussbaum, Biemann, and Mustard | 1994 | ? | No | Yes | Yes | No | Poor
Lucas, Coenen, and De Haan | 2000 | Partial | Yes | Yes | Yes | Yes | Fair
Crous and Malherbe | 1988 | ? | Yes | Partial | Yes | Partial | Poor

Placebo-controlled studies. Of the 11 studies meeting study selection criteria, seven studies enrolling 262 patients compared standard treatment plus sham low-level laser versus standard treatment plus active low-level laser (Bihari and Mester, 1989; Franek, Krol, and Kucharzewski, 2002; Iusim, Kimchy, Pillar, et al., 1992; Lagan, McKenna, Witherow, et al., 2002; Lundeberg and Malm, 1991; Malm and Lundeberg, 1991; Santoianni, Monfrecola, Martellotta, et al., 1984). Six of seven studies included patients with primarily lower extremity venous ulcers, while the seventh (Santoianni, Monfrecola, Martellotta, et al., 1984) selected a heterogeneous group of patients with diabetes or peripheral vascular disease.

Study quality. Overall study quality ratings were poor for all seven placebo-controlled studies (Evidence Table 6). None of these seven studies demonstrated that groups were comparable on all three critical baseline characteristics: age, wound size and wound duration (Evidence Table 2). Randomization methods were poorly described. High loss to followup was common. It was rare for studies to use both reliable and valid measurement techniques and blinded outcome assessors. Less than half of the studies reported on the main outcome, complete healing, and none made it clear that analysis was by intention-to-treat and controlled for confounders.

It is unclear whether any study assembled groups that were comparable on a sufficient range of key baseline patient characteristics. The study by Franek, Krol, and Kucharzewski (2002) assembled a control group receiving compressive and topical therapy plus sham low-level laser treatment that had a shorter mean wound duration (30 months) than the group receiving standard care plus active low-level laser therapy (41 months). The other six placebo-controlled studies did not provide comparisons between groups on wound duration at baseline. The studies by Franek, Krol, and Kucharzewski (2002), Malm and Lundeberg (1991), Lundeberg and Malm (1991), and Iusim, Kimchy, Pillar, et al. (1992) enrolled patient groups of comparable mean age, as well as comparable wound size.

In order for this review to describe the randomization method as adequate, the article had to state either that central randomization was performed or opaque (concealed) envelopes were employed. None of the seven placebo-controlled studies satisfied this quality component. Loss to followup exceeded 20 percent of the initial sample size in two studies: Malm and Lundeberg (1991) and Lundeberg and Malm (1991). Description of treatment and control procedures was clear in all cases.

Wound measurement was assumed to be reliable and valid if the article described use of photographic or digital transfer of wound tracings and/or use of computer software to calculate wound size. The studies by Franek, Krol, and Kucharzewski (2002) and Lagan, McKenna, Witherow, et al. (2002) satisfied this quality component. Data abstraction also sought information on whether a blinded observer performed outcome assessment. Blinded outcome assessors were used by Lagan, McKenna, Witherow, et al. (2002), Malm and Lundeberg (1991), Lundeberg and Malm (1991), and Bihari and Mester (1989). In only one study (Lagan, McKenna, Witherow, et al., 2002) was it clear that investigators used both blinded assessment and measurement that was reliable and valid.

None of these articles stated whether statistical analyses used adjustment procedures to deal with baseline confounding variables. Intention-to-treat analysis was performed by Lagan, McKenna, Witherow, et al. (2002), Bihari and Mester (1989), and Iusim, Kimchy, Pillar, et al. (1992). The primary endpoint, complete healing, was reported in three studies: Malm and Lundeberg (1991), Lundeberg and Malm (1991), and Bihari and Mester (1989). Analysis of results was considered appropriate if both adjustment for confounders and intention-to-treat analysis was carried out. None of these studies satisfied both components.

Complete healing. Three of seven studies reported data on the primary outcome specified for this systematic review, complete healing. Using the GaAs laser, Malm and Lundeberg (1991, n=42) performed a life-table analysis of time to complete healing by 12 weeks and found no significant difference between groups. Lundeberg and Malm (1991, n=46) used the HeNe laser and similarly found no differences between groups on life-table analysis at 12 weeks. Selecting three groups of 15 subjects each, Bihari and Mester (1989) compared a sham low-level laser group with one group treated with a hand-held HeNe laser and another group treated with a machine-scanned HeNe/pulsed infrared laser. Results favored the hand-held laser group over sham, but the difference was not statistically significant: the relative risk and 95 percent confidence interval (RR, 95 percent CI) of complete healing at 9 months was 2.0 (0.9–4.5). Results were significant in the machine-scanned laser group (RR=2.4, 95 percent CI: 1.1–5.1); however, two control patients were excluded from the analysis. If they had achieved complete healing, the results would not be statistically significant. None of the available studies provides clear evidence that use of laser treatment leads to a higher probability of complete healing, compared with sham treatment.

Change in wound area. Six of seven studies reported on this outcome. At 12 weeks' followup, Franek, Krol, and Kucharzewski (2002) found no significant differences between groups on either the mean rate of change in relative area or in the mean rate of change of relative suppurative area. Lagan, McKenna, Witherow, et al. (2002) found no difference between groups on percent change in wound area at 12 weeks. Malm and Lundeberg (1991) reported no difference between groups in rate of wound area change over 12 weeks. Lundeberg and Malm (1991) found that the average percent change at 12 weeks did not differ between groups. Santoianni, Monfrecola, Martellotta, et al. (1984) observed no differences between groups in the area epithelialized. Iusim, Kimchy, Pillar, et al. (1992) compared sham low-level laser with one group treated by red light laser and another treated with infrared light laser. By percent change in area at 20 days, the red light laser performed significantly better than sham, which did not differ from the infrared laser group. Only one of six studies reported a significant advantage favoring low-level laser treatment over sham.

Other outcomes. Franek, Krol, and Kucharzewski (2002) reported that the rate of change in relative defect volume was better in the standard treatment alone arm versus the low-level laser arm. Lagan, McKenna, Witherow, et al. (2002) found that visual analog scale pain did not differ between groups.

Studies without a placebo control. Three studies enrolling 151 patients compared patients receiving standard treatment alone with those undergoing standard treatment plus low-level laser (Lucas, van Gemert, and de Haan, 2003; Lucas, Coenen, and De Haan, 2000; Nussbaum, Biemann, and Mustard, 1994). All three selected patients with pressure ulcers.

Study quality. Both the Lucas, van Gemert, and de Haan (2003) and the Lucas, Coenen, and De Haan (2000) studies showed that groups were comparable on age, wound size and wound duration. The groups in the study by Nussbaum, Biemann, and Mustard (1994) were comparable on age and wound duration, but not on wound size. The Lucas, van Gemert, and de Haan (2003) study stated that central randomization was used, while the other two studies provided insufficient details about the randomization technique. Loss to followup exceeded 20 percent of the initial sample in the Nussbaum, Biemann, and Mustard (1994) study. Wound measurement was reliable and valid in all three studies and blind outcome assessors were used in all. Both control and treatment interventions were clearly described in all three studies. The Lucas, van Gemert, and de Haan (2003) and the Lucas, Coenen, and De Haan (2000) studies analyzed results by intention-to-treat, while Nussbaum, Biemann, and Mustard (1994) did not; neither did it mention use of adjustment for confounders.

The Lucas, van Gemert, and de Haan (2003) study was the only study that met all five quality dimensions and received an overall good rating. The earlier study by Lucas, Coenen, and De Haan (2000) met all but one of the quality dimensions, and received an overall fair rating. The main detail lacking from this study was an adequate description of the randomization procedure. The Nussbaum, Biemann, and Mustard (1994) study was given an overall poor quality rating. Randomization was poorly described, wound size differed between groups, loss to followup was high and appropriate analysis of results was not carried out.

Complete healing. All three studies reported on complete healing, but none provide support that use of laser therapy results in a higher probability of complete healing as compared to standard treatment alone. Lucas, van Gemert, and de Haan (2003) did not show a higher probability of complete healing at 6 weeks with laser. In the study by Nussbaum, Biemann, and Mustard (1994), patients receiving low-level laser treatment had a higher mean number of weeks to complete healing than standard treatment alone, by a followup as high as 20 weeks, but no statistical test result was provided. Lucas, Coenen, and De Haan (2000) observed that four of eight control patients and three of eight low-level laser patients achieved complete healing by 6 weeks.

Change in wound area. In Lucas, van Gemert, and de Haan (2003), no significant differences between groups were observed for absolute improvement, relative improvement or natural log-transformed improvement. Nussbaum, Biemann, and Mustard (1994) found that the rate of wound size change for laser was not better than that of control. Lucas, Coenen, and De Haan (2000) found no significant difference between groups in percent change of wound area.

Other outcomes. Lucas, Coenen, and De Haan (2000) assessed the Norton wound scale and found no differences between groups. These authors also found no difference between groups in the incidence of stage IV pressure ulcers.

Studies comparing ultraviolet light and low-level laser therapy. One study of only six patients with chronic leg venous ulcers compared use of medical treatment plus ultraviolet light with medical treatment plus laser therapy (Crous and Malherbe, 1988). The overall study quality rating was poor. It is unclear whether the two groups of three subjects were comparable on age, wound duration or wound size. The randomization procedure was inadequately described. Interventions were clearly described. Wound measurement was performed with photographs and a blinded observer. Adjustment for confounders was not mentioned. Results were given for all randomized patients. Complete healing was not reported.

The article reported on percent change in wound area and wound perimeter. The mean change in area in the ultraviolet light group was 34 percent, compared with 50 percent for low-level laser. Mean change in perimeter was 18 percent for ultraviolet light and 27 percent for low-level laser. No statistical test results were reported, but t-tests performed for this systematic review did not find statistically significant differences between groups.

### Conclusions

Eleven studies (Bihari and Mester, 1989; Crous and Malherbe, 1988; Franek, Krol, and Kucharzewski, 2002; Iusim, Kimchy, Pillar, et al., 1992; Lagan, McKenna, Witherow, et al., 2002; Lucas, Coenen, and De Haan, 2000; Lucas, van Gemert, and de Haan, 2003; Lundeberg and Malm, 1991; Malm and Lundeberg, 1991; Nussbaum, Biemann, and Mustard, 1994; Santoianni, Monfrecola, Martellotta, et al., 1984) met the study selection criteria for Part I of this review, nine of which were rated poor in quality (Bihari and Mester, 1989; Crous and Malherbe, 1988; Franek, Krol, and Kucharzewski, 2002; Iusim, Kimchy, Pillar, et al., 1992; Lagan, McKenna, Witherow, et al., 2002; Lundeberg and Malm, 1991; Malm and Lundeberg, 1991; Nussbaum, Biemann, and Mustard, 1994; Santoianni, Monfrecola, Martellotta, et al., 1984), while one was rated good quality (Lucas, van Gemert, and de Haan, 2003) and one was rated fair (Lucas, Coenen, and De Haan, 2000).

Seven studies (n=262) compared standard care plus placebo with the combination of standard care and sham laser therapy (Bihari and Mester, 1989; Franek, Krol, and Kucharzewski, 2002; Lagan, McKenna, Witherow, et al., 2002; Iusim, Kimchy, Pillar, et al., 1992; Lundeberg and Malm, 1991; Malm and Lundeberg, 1991; Santoianni, Monfrecola, Martellotta, et al., 1984). Most of these patients had lower extremity venous ulcers. Of the three studies that reported on complete healing (Bihari and Mester, 1989; Lundeberg and Malm, 1991; Malm and Lundeberg, 1991), one provides weak evidence of a higher rate of healing for patients treated by machine-scanned laser versus those receiving sham laser (Bihari and Mester, 1989).

Standard treatment alone versus standard treatment plus laser was compared in three studies, which reported on a total of 151 patients with pressure ulcers (Lucas, Coenen, and De Haan, 2000; Lucas, van Gemert, and de Haan, 2003; Nussbaum, Biemann, and Mustard, 1994). All three studies reported on complete healing. One of these was rated as good in quality, and this higher quality study did not show a higher probability of complete healing at 6 weeks with the addition of laser treatment (Lucas, van Gemert, and de Haan, 2003), nor did it show benefit for any of the other reported outcomes. Use of medical treatment plus ultraviolet light with medical treatment plus low-level laser therapy was compared in one study of six patients with chronic venous ulcers (Crous and Malherbe, 1988). That study did not show a higher probability of complete healing at 6 weeks with the addition of laser treatment.

Overall, the quality of this body of evidence is poor, and does not permit definitive conclusions. However, the available data suggests that the addition of laser therapy does not improve wound healing, as the vast majority of comparisons in these studies do not report any group differences in the relevant outcomes. It is unlikely that the lack of significant differences is the result of a type II error, since there are no trends or patterns of outcomes that favor the laser group.

## Part II: Vacuum-Assisted Closure

The second part of this chapter reviews evidence on the following questions:

In the treatment of various wounds, what are the outcomes of vacuum-assisted closure for specific indications and patient types:

a. as a substitute for standard dressings; and
b. as an adjunct to standard therapy, compared with standard therapy alone?

### Overview

A single previous systematic review is available on the use of vacuum-assisted closure for treating chronic wounds (Evans and Land, 2003). The authors concluded that the 2 small trials (Joseph, Hamori, Bergman, et al., 2000; McCallon, Knight, Valiulus, et al., 2000) that met their selection criteria offer weak evidence that vacuum-assisted closure is more efficacious than moist dressings. They noted that small sample sizes and methodological limitations require that the results of these 2 studies be interpreted with extreme caution. While Evans and Land restricted themselves to chronic wounds, the present review is broader in focus. Both studies reviewed in that report are also included here.

Two randomized trials on the use of vacuum-assisted closure are excluded from the current review (Buttenschoen, Fleischmann, Haupt, et al., 2001; Genecov, Schneider, Morykwas, et al., 1998) because they provided data only on outcomes that were not of interest to this review. The former reported on immune response markers and the latter gave data on skin biopsies. Two comparative studies published in Chinese were reviewed by a Chinese reader and found to be nonrandomized (Huang, Yao, and Huang, 2003; Yao, Huang, and Ma, 2002). No other nonrandomized comparative studies published in English were found. All other excluded studies were case series or case reports.

Six studies using vacuum-assisted closure met study selection criteria, with a collective total of 135 patients (Eginton, Brown, Seabrook, et al., 2003; Ford, Reinhard, Yeh, et al., 2002; Moues, Vos, van den Bemd, et al., 2004; Joseph, Hamori, Bergman, et al., 2000; McCallon, Knight, Valiulus, et al., 2000; Wanner, Schwarzl, Strub, et al., 2003). Details about these studies are given in Evidence Tables 7–12; information in these tables served as the basis for study quality ratings, which may be viewed in Evidence Table 13. Evidence Table 7 summarizes the included studies. Evidence Table 8 presents patient inclusion and exclusion criteria. Evidence Table 9 shows patient characteristics. Evidence Table 10 gives details of treatment. Evidence Table 11 includes information on how outcomes were assessed. Evidence Table 12 depicts results.

Evidence Table 7. Summary of Vacuum-Assisted Closure Studies

Evidence Table 7. Summary of Vacuum-Assisted Closure Studies

Study | n Randomized | Patient Selection | Control (Cx) | Treatment (Tx) | Comparable Characteristics | Allocation | Treatment Description | Wound Measurement | Complete Healing | Adjustment | Intention-to-Treat
Moues, Vos, van den Bemd, et al., 2004 | 54; | Full-thickness wounds | SC/dressings | V.A.C.® | Yes: age; | Random, envelopes | Cx, Tx clear | Photo-copies, SW | NR | ? | No
| Cx: 25 | | | | ? size, duration
| Tx: 29
Wanner, Schwarzl, Strub, et al., 2003 | 22; | Pressure ulcers | SC/dressings | V.A.C.® | Yes: age, size | Random | Cx, Tx clear | Saline volume | NR | Yes | No
| Cx: 11; | | | | ?: duration
| Tx: 11
Joseph, Hamori, Bergman, et al., 2000 | 24; | Non-healing wounds | SC/dressings | V.A.C.® | Yes: age | Random | Cx, Tx clear | Plaster mold, blind | NR | ? | Yes
| Cx: 12; | | | | No: size
| Tx: 12 | | | | ?: duration
Ford, Reinhard, Yeh, et al., 2002 | 28 | Pressure ulcers | gel products | V.A.C.® | No: age | Random | Cx, Tx clear | Alginate mold, blind | Tx=Cx | ? | No
| | | | | ?: size, duration
Eginton, Brown, Seabrook, et al., 2003 | 10 | Diabetic foot wounds | SC/dressings | V.A.C.® | ?: age, size, duration | Random | Cx, Tx clear | Digital photos, planimetry SW, blind | NR | ? | No
McCallon, Knight, Valiulus, et al., 2000 | 10; | Non-healing diabetic foot wounds | SC/dressings | V.A.C.® | Yes: age | Coin flip, then alternate | Cx, Tx clear | Tracings, photos, biometric SW | Tx=Cx | ? | No
| Cx: 5; | | | | ?: size, duration
| Tx: 5

Evidence Table 8. Vacuum-Assisted Closure, Patient Selection Criteria

Evidence Table 8. Vacuum-Assisted Closure, Patient Selection Criteria

Study | Inclusion | Exclusion
Moues, Vos, van den Bemd, et al., 2004; Rotterdam | Full-thickness wound that could not be closed immediately because of infection, contamination, or chronic character; type: trauma (2), infection (17), dehiscence (5), pressure ulcer (20), miscellaneous (10) | Malignant disease, deep fistulas, sepsis, active bleeding, uncontrolled diabetes, psychiatric patients, and unstable skin around the wound
Wanner, Schwarzl, Strub, et al., 2003; Nottwil, Switzerland | all consecutive pts with a pressure sore in the pelvic region, deeper than grade 2 (at least into SC fat); paraplegics or tetraplegics | pressure ulcer not in pelvic region (7); < grade 3 (3); lack of data (1); severe diarrhea (1)
Joseph, Hamori, Bergman, et al., 2000; Boston | chronic, nonhealing wounds (open wound, any site no closure ≥ 4 wk), recalcitrant to multiple prior treatments; setting: hospital (5), nursing home (9), home (10); wound type (Cx, Tx): dehisced (3, 0); pressure (13, 12); pressure-recurrent (1, 2); radiated (0, 1); traumatic (1, 1); venous insufficiency (0,2) | Infection; albumin < 3 g/dL; chronic disease requiring ongoing therapy for stabilization, uncontrolled diabetes, thyroid disease, hypertension; steroids, immunosuppressants, anticoagulants; pregnant/lactating; biopsy-proven osteomyelitis; uncooperative/unsuitable participant in dressing changes; malignant/neoplastic diseases in wound margin; fistulas to the wound
Ford, Reinhard, Yeh, et al., 2002; Boston | Stage III–IV pressure ulcers, 21–80 yo; > 4 wk; albumin > 2.0 g/dl; post-debridement ulcer volume 10–150 mL | fistulas to organs/body cavities; malignancy in wound; pregnant/lactating; Hashimoto thyroiditis; Graves disease; iodine allergy; systemic sepsis; electrical burn; radiation exposure; chemical exposure; cancer; connective tissue disease; chronic renal/pulmonary disease; uncontrolled diabetes; steroids/immunosuppressants; pacemaker; ferromagnetic clamps; recently placed orthopedic hardware
Eginton, Brown, Seabrook, et al., 2003; Milwaukee | diabetic foot wounds of size not expected to heal in 1 mo | growth factors, hyperbaric oxygen < 30 d, untreated cellulitis, malignancy in wound, necrotic tissue, osteomyelitis, no insurance for VAC or f/u
McCallon, Knight, Valiulus, et al., 2000; Shreveport | nonhealing (> 1 mo) diabetic foot ulceration; 18–75 yo; | venous disease; active infections not resolved by initial debridement; coagulopathy

Evidence Table 9. Vacuum-Assisted Closure, Patient Characteristics

Evidence Table 9. Vacuum-Assisted Closure, Patient Characteristics

Study | Comparison | n, Randomized | n, Withdrew | Wound Duration | Age | Gender | Wound Size | Comorbidities
Moues, Vos, van den Bemd, et al., 2004; Rotterdam Full-thickness wound that could not be closed immediately | Cx: standard moist dressing | 54 | | < 4 wk: 8 Cx, 12 Tx | Cx: mn 47.9, SD 17.0 | Cx: 14 M, 11 F
| Tx: V.A.C.® | Cx: 25 | | > 4 wk: 17 Cx, 17 Tx | Tx: mn 47.7, SD 19.6 | Tx: 21 M, 8 F
| | Tx: 29
Wanner, Schwarzl, Strub, et al., 2003; Nottwil, Switzerland; Pelvic pressure ulcers into SC fat | Cx: traditional care | 22 | | | Cx: mn 53, mg 34–77 | Cx: 8 m, 3 F | (volume) | (Cx, Tx): diabetes (0, 0); vascular disorders (2, 0); zinc depletion (5, 5); hypoalbuminemia (1, 3); hypoproteinemia (3, 5); anemia (5, 8); nicotine (2, 3); steroids (0, 0)
| Tx: V.A.C.® | Cx: 11 | | | Tx: mn 49, mg 25–73 | Tx: 7 M, 4 F | Cx: mn 42 ml, SD 16, mg 5–68
| | Tx: 11 | | | | | Tx: mn 50, SD 33, mg 3–132
Joseph, Hamori, Bergman, et al., 2000; Boston Nonhealing wounds (> 4 wk, 78% pressure ulcers) | Cx: standard wound care | 24 pts | | > 4 wk | Cx: mn 49; | Cx: 5 M, 7 F | (volume) UA=pt
| Tx: V.A.C.® | Cx: 12 | | | Tx: mn 56 | Tx: 8 M, 4 F | Cx: mn 24 cu cm
| | Tx: 12 | | | (p=0.17) | (p=0.18) | Tx: mn 38 (p=0.08);
| | 36 wounds
| | Cx: 18
| | Tx: 18
Ford, Reinhard, Yeh, et al., 2002; Boston Full-thickness pressure ulcers | Cx: Healthpoint System (gel products) | 28 pts | 6 (3 lost to followup, 1 noncompliant, 2 died) | ≥ 4 wk | Cx: mn 54.4
| Tx: V.A.C.® | 41 wounds | | | Tx: mn 41.7
Eginton, Brown, Seabrook, et al., 2003; Milwaukee Diabetic foot wounds | Crossover | 10 pts | 4 (1 did not return for f/u, 1 coverage denied, 1 hyperbaric oxygen, 1 failed V.A.C.®) | | | | (length):
| Cx: moist dressings 2 wk | 11 wounds | | | | | Cx+Tx: mn 7.7 cm, SD 1.6
| Tx: V.A.C.® 2 wk | | | | | | (width):
| | | | | | | mn 3.5, SD 0.6
| | | | | | | (depth):
| | | | | | | mn 3.1, SD 0.9
McCallon, Knight, Valiulus, et al., 2000; Shreveport Nonhealing diabetic foot wounds | Cx: saline-moistened gauze dressings | 10 | | ≥ 1 mo | Cx: mn 50.2, SD 8.7 | | (area):
| Tx: V.A.C.® | Cx: 5 | | | Tx: mn 55.4, SD 12.8 | | Cx: 20 sq cm
| | Tx: 5 | | | | | Tx: 23

Evidence Table 10. Vacuum-Assisted Closure, Treatments

Evidence Table 10. Vacuum-Assisted Closure, Treatments

Study | Allocation | Comparison | Control | Treatment | Treatment Regimen
Moues, Vos, van den Bemd, et al., 2004; Rotterdam Full-thickness wounds that could not be closed immediately | Randomly assigned by patient picking a closed envelope | Cx: standard moist dressings | Debridement before and during therapy when clinically needed; standard moist gauze, using: 0.9% saline, 0.2% nitrofuralam, 1% acetic acid, 2% sodium hypochlorite, changed 2x/day | Debridement before an during therapy when clinically needed; V.A.C.®; 125 mmHg continuous suction, wounds inspected and dressings changed every 48 hr | Until ready for surgical therapy
| | Tx: V.A.C.®
Wanner, Schwarzl, Strub, et al., 2003 ; Nottwil, Switzerland; Pelvic pressure ulcers into SC fat | Randomized | Cx: traditional care | traditional care - 1 day after debridement, wet-to-dry/dry-to-wet dressings, Ringer's solution, changed 3x/d until granulation tissue, then 1–3x/d; closure with flap after 50% decrease in wound volume | V.A.C.®, <125 mmHg below ambient pressure; polyvinyl foam/transparent polyurethane dressing changed after 2–7 d (when canister full); closure with flap after 50% decrease in wound volume
| | Tx: V.A.C.®
Joseph, Hamori, Bergman, et al., 2000; Boston; Nonhealing wounds (> 4 wk, 78% pressure ulcers) | Prospectively randomized: folders in 2 colors randomly organized in locked cabinet; after consent, folder picked for each wound | Cx: standard wound care | standard wound care: wet-to-moist (saline) gauze dressings changed 3x/d, not allowed to dry the wound bed, occlusive covering; nutritional assessment, supplements, multivitamin, debridement; pressure-relieving surface; frequent assessment, pressure reduction | V.A.C.®, < 125 mmHg below ambient pressure; custom-cut foam dressings with film drape changed each 48 hr; nutritional assessment, supplements, multivitamin, debridement; pressure-relieving surface; frequent assessment, pressure reduction | 6 wk
| | Tx: V.A.C.®
Ford, Reinhard, Yeh, et al., 2002; Boston; Full-thickness pressure ulcers | random assignment; table of random letters (V, H) generated before trial began; 3 pts with 3 wounds each crossed over for 2nd 6-wk course of opposing treatment | Cx: Healthpoint System (gel products) | debridement, Healthpoint System - gel products (Iodosorb, Iodoflex, Panafil); pts with substantial exudate received Iodosorb or Iodoflex, clean/granulating wounds received Panafil; dressings changed 1–2x/d | debridement, V.A.C.®, dressings changed 3x/wk | 6 wk
| | Tx: V.A.C.®
Eginton, Brown, Seabrook, et al., 2003; Milwaukee Diabetic foot wounds | randomly assigned, random number generator: even numbers treated with V.A.C.® 1st, odd numbers treated with moist dressings 1st | Crossover | initial debridement, moist dressings, hydrocolloid gel, gauze, changed daily, 2 wk | initial debridement, V.A.C.®, - 125 mmHg continuous negative pressure, custom-cut foam dressings with transparent occlusive film changed > 3x/wk, 2 wk | 2 wk
| | Cx: moist dressings 2 wk
| | Tx: V.A.C.® 2 wk
McCallon, Knight, Valiulus, et al., 2000; Shreveport Nonhealing diabetic foot wounds | randomized by coin flip, then alternating groups | Cx: saline-moistened gauze dressings | debridement, physical therapy, saline-moistened gauze dressings, changed 2x/d; bedrest or strict nonweight bearing | V.A.C.®, 125 mmHg continuous suction 1st 48 hr, then intermittent suction; dressing changed each 48 hr; bedrest or strict nonweight bearing
| | Tx: V.A.C.®

Evidence Table 11. Vacuum-Assisted Closure, Outcome Assessment

Evidence Table 11. Vacuum-Assisted Closure, Outcome Assessment

Study | Comparison | Primary Outcomes | Secondary Outcomes | Wound Measurement | Observer | F/U | Unit of Analysis | Intention-to-Treat
Moues, Vos, van den Bemd, et al., 2004; Rotterdam | Cx: standard moist dressings | Median time to reach “ready for surgical therapy” | Wound surface area, bacterial load | Tracings onto polyethylene film, photocopying onto paper, computer software calculated area | Not blinded
| Tx: V.A.C.®
Wanner, Schwarzl, Strub, et al., 2003; Nottwil, Switzerland; Pelvic pressure ulcer into sc fat | Cx: traditional care | time to 50% decrease in wound volume | | ulcer covered with transparent sheet of elastic polymer, injected with saline until full, fluid volume measured | | 21–56 d | patient | ?
| Tx: V.A.C.®
Joseph, Hamori, Bergman, et al., 2000; Boston; Nonhealing wounds (> 4 wk, 78% pressure ulcers) | Cx: standard wound care | Time to target decline in wound volume | wound length, width, depth; wound biopsies | Photography, dimensions, volume by alginate impression molds | independent blinded observer, not involved in daily patient care | 6 wk | wound | ?
| Tx: V.A.C.®
Ford, Reinhard, Yeh, et al., 2002; Boston | Cx: Healthpoint System (gel products) | complete healing | wound length, width, depth, volume, bone biopsy | photography, dimensions, volume by plaster mold | blinded assessment | 3–10 mo | wound | ?
| Tx: V.A.C.®
Eginton, Brown, Seabrook, et al., 2003; Milwaukee Diabetic foot wounds | Crossover | Rate of wound healing, dimensions, area, volume | | digital photography, computerized planimetry software | blinded evaluation, wound length, width, depth, volume | 4 wk
| Cx: moist dressings 2 wk
| Tx: V.A.C.® 2 wk
McCallon, Knight, Valiulus, et al., 2000; Shreveport | Cx: saline-moistened gauze dressings | time to closure/ satisfactory healing (delayed primary intention - surgical closure, or secondary intention - granulation, epithelialization) | rate, wound area | tracings on acetate film, photography, area calculated by computer biometric software
| Tx: V.A.C.®

Evidence Table 12. Vacuum-Assisted Closure, Results

Evidence Table 12. Vacuum-Assisted Closure, Results

Study | Comparison | F/U | Complete Healing | Wound Area | Wound Volume | Wound Dimensions
Moues, Vos, van den Bemd, et al., 2004; Rotterdam Full-thickness wound | Cx: standard moist dressings (25) | | (time until “ready for surgical therapy”): | (% change/d):
| Tx: V.A.C.® (29) | | Cx: md 7.0, SEM 0.81 | Cx (n=13) mn 1.7, SEM 0.5
| | | Tx: md 6.0, SEM 0.52 (p=0.19) | Tx: (n=15) mn 3.8, SEM 0.5
| | | | (p<0.05)
Wanner, Schwarzl, Strub, et al., 2003; Nottwil, Switzerland; Pelvic pressure ulcers into SC fat | Cx: traditional care (11) | 21–56 days | | | (time to 50% drop in vol):
| Tx: V.A.C.® (11) | | | | Cx: mn 28 d, SD 7
| | | | | Tx: mn 27 d, SD 10; (unadjusted p=0.9, adjusted p=0.2)
Joseph, Hamori, Bergman, et al., 2000; Boston; Nonhealing wounds(> 4 wk, 78% pressure ulcers) | Cx: standard wound care (12) | 6 wk | | | (time to > 95% fall in vol): Cox Proportional Hazards Model significant predictors: | (% change, length):
| Tx: V.A.C.® (12) | | | | VAC (p=0.046), initial tendon/bone exposure (p=0.05) | Cx: -38;
| | | | | (% change): Cx: mn 30; Tx: mn 78 (p=0.038) | Tx: -46 (p=0.38)
| | | | | | (% change, width):
| | | | | | Cx: -35
| | | | | | Tx: -63 (p=0.02)
| | | | | | (% change, depth):
| | | | | | Cx: -20
| | | | | | Tx: -66 (p<0.001)
Ford, Reinhard, Yeh, et al., 2002; Boston Full-thickness pressure ulcers | Cx: Healthpoint System (gel products) | 3–10 mo | Cx: 2/15; Tx: 2/20 (8–10 wk) | | (% change): | (change, length):
| Tx: V.A.C.® | | Tx:Cx RR = 0.75, 95%CI: 0.12, 4.73 | | Cx: -42.1 | Cx: mn -18.7 cm
| Cx+Tx (22) | | | | Tx: -51.8 (p=0.46) | Tx: -36.9 (p=0.10)
| | | | | | (change, width):
| | | | | | Cx: -19.0
| | | | | | Tx: -40.0 (p=0.11)
| | | | | | (change, depth):
| | | | | | Cx: -31.0
| | | | | | Tx: -33.6 (p=0.90)
Eginton, Brown, Seabrook, et al., 2003; Molwaukee Diabetic foot wounds | Crossover, Cx: moist dressings 2 wk; | 4 wk | | (% change): | (% change): | (% change, length):
| Tx: V.A.C.® 2 wk | | | Cx: mn +5.9, SD 17.4 | Cx: mn -0.1, SD 14.7 | Cx: mn +6.7, SD 11.5
| Cx+Tx (6) | | | Tx: mn - 16.4, SD 6.2 (NS); | Tx: mn -59, SD 9.7 | Tx: mn -4.3, SD 4.7 (NS)
| | | | | (p<0.005) | (% change, width):
| | | | | | Cx: mn +2.4, SD 7.5
| | | | | | Tx: mn – 12.9, SD 5.2 (NS)
| | | | | | (% change, depth):
| | | | | | Cx: mn –7.7, SD 5.2
| | | | | | Tx: mn –49, SD 11.1 (p<0.05)
McCallon, Knight, Valiulus, et al., 2000; Shreveport Nonhealing diabetic foot wounds | Cx: saline-moistened gauze dressings (5) | | (time to satisfactory healing): | (% change):
| Tx: V.A.C.® (5) | | Cx: mn 42.8 d, SD 32.5 | Cx: mn +9.5, SD 16.9
| | | Tx: mn 22.8, SD 17.4 (NS); | Tx: mn -28.4, SD 24.3 (NS)
| | | (delayed 1° closure):
| | | Cx: 2/5; Tx: 4/5; (2° intention): Cx: 3/5; Tx: 1/5

Evidence Table 13. Vacuum-Assisted Closure, Study Quality Ratings

Evidence Table 13. Vacuum-Assisted Closure, Study Quality Ratings

Study | Yr | Initial Assembly of Comparable Groups | Low Loss to Followup, Maintenance of Comparable Groups | Measurements Reliable, Valid, Equal | Interventions Comparable/ Clearly Defined | Appropriate Analysis of Results | Overall Rating
Moues, Vos, van den Bemd, et al. | 2004 | Partial | ? | No | Yes | No | Poor
Wanner, Schwarzl, Strub, et al. | 2003 | ? | ? | Partial | Yes | No | Poor
Joseph, Hamori, Bergman, et al. | 2000 | ? | ? | Yes | Yes | Partial | Poor
Ford, Reinhard, Yeh, et al. | 2002 | ? | No | Yes | Yes | No | Poor
Eginton, Brown, Seabrook, et al. | 2003 | ? | No | Yes | Yes | No | Poor
McCallon, Knight, Valiulus, et al. | 2000 | ? | ? | No | Yes | No | Poor

All studies used the V.A.C.® (Kinetic Concepts, Inc., KCI) device. Three studies included patients who primarily had pressure ulcers (Wanner, Schwarzl, Strub, et al., 2003; Ford, Reinhard, Yeh, et al., 2002; Joseph, Hamori, Bergman, et al., 2000). Joseph, Hamori, Bergman, et al. (2000) selected patients with chronic (i.e., ≥4 weeks' duration) nonhealing wounds of various etiologies, of which 78 percent were pressure ulcers. Pressure ulcers in the Ford, Reinhard, Yeh, et al. (2002) study were of 4 weeks duration or longer. Wanner, Schwarzl, Strub, et al. (2003) did not specify the duration of the pressure ulcers. Eginton, Brown, Seabrook, et al. (2003) included diabetic foot wounds not expected to heal within 1 month and McCallon, Knight, Valiulus, et al. (2000) selected diabetic foot wounds of more than 1 month duration.

The comparison of interventions was conventional/standard wound care (mainly, moist dressings changed at least once daily) versus vacuum-assisted closure in five studies (Moues, Vos, van den Bemd, et al., 2004; Wanner, Schwarzl, Strub, et al., 2003; Joseph, Hamori, Bergman, et al., 2000; Eginton, Brown, Seabrook, et al., 2003; McCallon, Knight, Valiulus, et al., 2000). One study (Ford, Reinhard, Yeh, et al., 2002) compared vacuum-assisted closure with the Healthpoint® system, consisting of gel/pad products (Iodosorb®, Iodoflex™, Panafil®).

Study quality. All six studies were rated poor in quality (Evidence Table 13). Only one study made it clear that an adequate randomization method was used (i.e., sealed envelopes in Moues, Vos, van den Bemd, et al., 2004). One study (McCallon, Knight, Valiulus, et al., 2000) used an allocation method that was probably inadequate to be considered true randomization: coin flip to assign the first patient, then alternating group assignment.

No study indicated that groups were comparable on all three key baseline characteristics (age, wound duration, and wound size, see Evidence Table 9). Age was comparable between groups in these four studies: Moues, Vos, van den Bemd, et al. (2004); Wanner, Schwarzl, Strub, et al. (2003); Joseph, Hamori, Bergman, et al. (2000); and McCallon, Knight, Valiulus, et al. (2000). Vacuum-assisted closure patients were younger than control patients in the study by Ford, Reinhard, Yeh, et al. (2002). Wanner, Schwarzl, Strub, et al. (2003) assembled groups that were comparable in wound size. Wounds were smaller in the vacuum-assisted closure group than the control group in the study by Joseph, Hamori, Bergman, et al. (2000). None of the seven studies provided information on the comparability of groups with respect to wound duration. All studies gave clear descriptions of interventions. All studies also described reliable and valid measurement methods and three used blinded observers (Joseph, Hamori, Bergman, et al., 2000; Ford, Reinhard, Yeh, et al., 2002; Eginton, Brown, Seabrook, et al., 2003). One study (Ford, Reinhard, Yeh, et al., 2002) reported on the primary endpoint, complete healing, while McCallon, Knight, Valiulus, et al. (2000) provided data on time to satisfactory healing. Only Wanner, Schwarzl, Strub, et al. (2003) performed adjustment for confounders in the data analysis. Joseph, Hamori, Bergman, et al. (2000) provided the only intention-to-treat analysis.

Complete healing. The proportion of patients who achieved complete healing was reported in only one study (Ford, Reinhard, Yeh, et al., 2002). In the control group receiving gel products for full-thickness pressure ulcers, two of 15 wounds had complete healing within 8–10 weeks, compared with two of 20 in the vacuum-assisted closure group. The relative risk of complete healing was 0.75 with a 95 percent confidence interval from 0.12 to 4.73. Although the numerical rate of complete healing was lower in the vacuum-assisted closure group, the 95 percent confidence interval is quite wide and overlaps with 1.0, indicating a lack of statistical difference between groups.

McCallon, Knight, Valiulus, et al. (2000) defined a related outcome, “satisfactory healing,” as achieving definitive closure either by reaching a stage suitable for surgical intervention such as skin grafting (delayed primary intention) or by complete healing without surgical intervention (secondary intention). The mean time to satisfactory healing was 42.8 days in the control group and 22.8 days in the vacuum-assisted closure group, a difference that was not statistically significant in this study of 10 patients with diabetic foot wounds. Most of the vacuum-assisted closure wounds (4 of 5) were healed by delayed primary intention, while most of the control wounds (3 of 5) healed by secondary intention.

Facilitation of surgical closure. One study (Moues, Vos, van den Bemd, et al., 2004) reported on the time to readiness for surgical closure, among patients with full-thickness wounds of various etiologies. Log-rank test analysis of Kaplan-Meier time to readiness did not show any statistically significant differences between groups. The median time to readiness for surgical closure was 6 days for vacuum-assisted closure patients and 7 days for conventionally treated patients (p=0.19).

Change in wound area. Two studies of diabetic foot wounds reported nonsignificant results favoring vacuum-assisted closure over moist dressings in percent change in wound area, and one study of full-thickness wounds reported a similar finding. Eginton, Brown, Seabrook, et al. (2003) used a crossover design in six patients who first had 2 weeks of either moist dressings or vacuum-assisted closure, then switched to the other for 2 weeks. The mean change in area was an increase of 5.9 percent for the control intervention and a decrease of 16.4 percent for vacuum-assisted closure. In the study by McCallon, Knight, Valiulus, et al. (2000, n=10), the mean change in wound area in the control group was a gain of 9.5 percent, compared with a mean decrease of 28.4 percent in the vacuum-assisted closure group. In a subset of only 52 percent of the original group of patients with full-thickness wounds, Moues, Vos, van den Bemd, et al. (2004) found a significantly higher daily percent change in wound area among vacuum-assisted closure patients (3.8), compared with conventionally treated patients (1.7, p<0.05).

Change in wound volume. Four studies have reported on changes in wound volume: all three studies of pressure ulcers and one study on diabetic foot wounds. Wanner, Schwarzl, Strub, et al. (2003) included 22 patients with pelvic pressure ulcers. The endpoint was time to 50 percent decrease in wound volume. The mean time for traditional care was 28 days, compared with 27 days for vacuum-assisted closure. The unadjusted p value was 0.9, while adjustment for initial wound volume yielded a p value of 0.2. In the study by Ford, Reinhard, Yeh, et al. (2002) of 19 patients with full-thickness pressure ulcers, after 3–10 months, the mean percent change in wound volume was -42.1 percent in the group receiving gel products and -51.8 percent in the vacuum-assisted closure group (p=0.46). The group of 24 patients with nonhealing wounds (78 percent pressure ulcers) studied by Joseph, Hamori, Bergman, et al. (2000) were evaluated in two ways. First, the mean percent reduction in volume at 6 weeks was compared: 30 percent for standard wound care and 78 percent for vacuum-assisted closure (p=0.038). Second, a Cox proportional hazards model analysis found that use of vacuum-assisted closure and initial exposure of tendon or bone were significant predictors of time to greater than 95 percent reduction in volume. In the crossover study of six patients with diabetic foot wounds (Eginton, Brown, Seabrook, et al., 2003), the mean percent reduction in wound volume was 0.1 percent in the moist dressing phase and 59 percent in the vacuum-assisted closure phase (p<0.005).

Change in wound dimensions. Three studies report changes in length, width and depth of wounds, and two of the three studies report significant differences in favor of the vacuum-assisted closure group for one or more of these outcomes. In the Ford, Reinhard, Yeh, et al. (2002) study of pressure ulcers, the mean changes (cm) for the gel product group and vacuum-assisted closure group, respectively, were: -18.7 and -36.9 (length, p=0.10); -19.0 and -40.0 (width, p=0.11); and -31.0 and -33.6 (depth, p=0.90). Mean percent change in the Joseph, Hamori, Bergman, et al. (2000) study of nonhealing wounds, for standard care and vacuum-assisted closure, respectively, were: -38 and -46 (length, p=0.38); -35 and -63 (width, p=0.02); -20 and -66 (depth, p<0.001). In the crossover study by Eginton, Brown, Seabrook, et al. (2003) of diabetic foot wounds, the following comparisons of mean percent change values for moist dressings and vacuum-assisted closure, respectively, were observed: +6.7 and -4.3 (length, p>0.05); +2.4 and -12.9 (width, p>0.05); and -7.7 and -49 (depth, p<0.05).

Complications. Two studies reported data on complications during wound treatment. Ford, Reinhard, Yeh, et al. (2002) reported two deaths (group assignments not specified) and one vacuum-assisted closure patient with diabetes, hypertension, vascular insufficiency and sepsis who required distal lower extremity amputation. More cases of pre-existing osteomyelitis improved in the vacuum-assisted closure group (37.5 percent) than in the group receiving gel products (0 percent), but the difference was not statistically significant (p=0.25). In the Joseph, Hamori, Bergman, et al. (2000) study, eight of 18 wounds treated with standard care developed complications, compared with three of 18 vacuum-assisted closure wounds (p=0.0028). Complications included: fistulas; wound infection; osteomyelitis; and calcaneal fractures.

Biopsy results. The study comparing gel products and vacuum-assisted closure in 22 patients with full thickness pressure ulcers (Ford, Reinhard, Yeh, et al., 2002) reported quantitative biopsy results. The mean number of polymorphonuclear (PMN) leukocytes per high-powered field increased in the gel product group, but decreased in the vacuum-assisted closure group (p=0.13). Lymphocytes also increased in the gel product group and decreased in the vacuum-assisted closure group (p=0.41). The mean number of capillaries declined in both groups, but to a slightly lesser extent in the vacuum-assisted closure group (p=0.75).

Randomized trials in progress. KCI, the manufacturer of the V.A.C.® device, has shared protocol documents for 10 randomized trials in progress (Evidence Table 14). These protocols cover a wide variety of wound types, including burns, pressure ulcers, diabetic ulcers, traumatic and surgical wounds, venous stasis wounds, and diabetic wounds. Large sample sizes are planned, determined by power analyses. Sophisticated randomization techniques will be used in many trials. A wide range of outcomes will be assessed, often by a blinded observer. Plans to adjust for confounders in the analysis, if necessary, are common. Concerns remain about the criteria for allowable withdrawals, including: noncompliance; worsened condition; complications; and treatment difficulties/failures. If such withdrawals are excluded from analysis, it would constitute violation of the intention-to-treat principle.

Evidence Table 14. Vacuum-Assisted Closure, KCI Randomized Trials in Progress

Evidence Table 14. Vacuum-Assisted Closure, KCI Randomized Trials in Progress

Study | Patients | Target n | Randomization | Allowable Withdrawals | Treatments | Outcomes | F/U | Planned Adjustment for Confounders? | Planned Intent-to-Treat?
Molnar-Wake Forest | bilateral 2nd/3rd degree hand burns, 12–24 hrs post injury | | by hand, random fashion like toss of coin | | usual institutional regimen, V.A.C.®, 48 hr | photography, ROM, pinch/grip strength, need for surgery, general appearance | 30 d, 60 d
Protocol VAC2001-01 | stage III/IV pressure ulcer | 258, power analysis | by patient, standard tables of random numbers, opaque envelopes | investigator/ KCI discretion of noncompliance/ worsening, complications, treatment difficulties or failure, reasons documented | WOCN guideline (1992) moist therapy; V.A.C.®; 84 d | blinded, photography, bilayer tracing, complete closure (and time), facilitation of surgical closure, AEs, area, volume, pain | 84 d | yes | interim
Protocol VAC2001-02 | venous stasis ulcers, > 30 d duration, ABI 0.7–1.2 | 258, power analysis | by patient, standard tables of random numbers, opaque envelopes | investigator/KCI discretion of noncompliance/worsening, complications, treatment difficulties or failure, reasons documented | WOCN guideline (1996, 1993) moist therapy; V.A.C.®; 112 d | blinded, photography, bilayer tracing, complete closure (and time), area, AEs, pain, QOL, cost | 112 d | yes | interim
Protocol VAC2001-04 | draining hematoma, orthopedic surgical procedure following trauma | 258, power analysis | by patient, central computerized randomization | investigator/KCI discretion of noncompliance/ worsening, complications, treatment difficulties; reasons documented | pressure dressings; V.A.C.®; 10 d | incidence of draining hematomas, infections, wound dehiscence, AEs, QOL, cost | 12 mo | yes | yes
Protocol VAC2001-05 | surgically treated calcaneus, tibial plateau, pilon fractures | 348, power analysis | by patient, central computerized randomization | investigator/ KCI discretion of noncompliance/ worsening, complications, treatment difficulties; reasons documented; data up to withdrawal included in analysis | standard care; V.A.C.®; to discharge | drainage, wound healing, surgical revision, infection, wound dehiscence, AEs, QOL, cost | 12 mo | yes | yes
Protocol VAC2001-06 | open fractures | 258, power analysis | by patient, central computerized randomization | investigator discretion of noncompliance/ worsening, complications, treatment difficulties; reasons documented; data up to withdrawal included in analysis | standard care, V.A.C.®; until ready for surgical closure | postoperative AEs/complic-ations, time to closure | 12 mo | yes | yes
Protocol VAC2001-07 | amputation wounds of the diabetic foot | 146, power analysis | by patient, central computerized randomization, opaque envelopes | investigator/ KCI discretion of noncompliance/ worsening, complications, treatment difficulties or failure; reasons documented | guideline-based care; V.A.C.®; 112 d | complete closure (and time), facilitation of surgical closure, area, foot salvage, complications, QOL, cost | 38 wks | yes
Protocol VAC2001-08 | diabetic foot ulcers | 248, power analysis | by patient, central computerized randomization, opaque envelopes | investigator/KCI discretion of noncompliance/ worsening, complications, treatment difficulties or failure; reasons documented | guideline-based care; V.A.C.®; 112 d | blinded, complete closure (and time), facilitation of surgical closure, area, foot salvage, complications, QOL, cost | 38 wks | yes
Protocol VAC2002-09 | open chest wounds | 116, power analysis | by patient, central computerized randomization | investigator/KCI discretion of noncompliance/ worsening, complications, treatment difficulties or failure; reasons documented | guideline-based moist therapy; V.A.C.®; 84 d | blinded, facilitation of surgical closure, complications, pain, cost | 3 mo | yes
Protocol VAC2002-10 | open abdominal wounds | 116, power analysis | by patient, central computerized randomization | investigator/KCI discretion of noncompliance/ worsening, complications, treatment difficulties or failure; reasons documented | guideline-based moist therapy; V.A.C.®; 84 d | blinded, facilitation of surgical closure, complications, pain, cost | 3 mo | yes

KCI also furnished abstracts presented at the 2^nd^ World Union of Wound Healing Societies, which met in Paris, France, July 8–12, 2004. While these abstracts provide too little detail for meaningful analysis in this systematic review, they are summarized in Evidence Table 15 to document the progress of ongoing randomized trials.

### Conclusions

This body of evidence is insufficient to support conclusions about the effectiveness of vacuum-assisted closure in the treatment of wounds. There are only six trials that met the inclusion criteria for this review and the included trials were of small size and poor quality. With the exception of one study of 54 patients with incomplete followup, all studies included fewer than 25 patients. The randomization method was clearly adequate in only one study. No study made it clear that groups were comparable on all three key baseline characteristics (age, wound duration, wound size). None provided group information about wound duration. A single study adjusted for confounders in the data analysis and another performed an intention-to-treat analysis.

Some outcomes in the available trials show a significant benefit for the vacuum-assisted closure group, while others do not. Only one study gave data on the probability of complete healing, showing no significant difference between groups. A study reporting time to satisfactory healing also found no significant difference between groups. One study found no difference between vacuum-assisted closure and control in time to readiness for surgical closure. Three studies reported on change in wound area; one of which found a difference between vacuum-assisted closure and control, while two did not. Among four studies addressing change in wound volume, two found a significant advantage for vacuum-assisted closure and two did not achieve statistical significance. One study found significant changes in wound width and depth for vacuum-assisted closure and another found it only for depth. It is possible that the lack of significant results in some or all of these trials result from a type II error. In most cases, the numerical results favor the vacuum-assisted closure group. Power calculations are lacking for these trials, but their small size raises the possibility that they are underpowered.

The randomized, controlled trial protocols provided by KCI outline much larger trials that are condition-specific and address many of the quality problems found in the published studies. If implemented and completed successfully as planned, these trials will provide substantial advances in the evidence base for vacuum-assisted closure therapy, and may allow more definitive conclusions on the efficacy of vacuum-assisted closure.

Evidence Table 15. Abstracts Presented at the 2nd World Union of Wound Healing Societies, Paris, France; July 8–12, 2004

Evidence Table 15. Abstracts Presented at the 2^nd^ World Union of Wound Healing Societies, Paris, France; July 8–12, 2004

Abstract # | Author | Patient Selection | n | Cx | Tx | Tx=Cx | Tx>Cx Significant | Tx>Cx Significant? | Tx>Cx NS | Comment
A001 | Moues | full-thickness wounds | 54 | conventional moist gauze therapy | VAC® | | area | Surgical closure | | published, included
A016 | Foo | diabetic foot | 25 | moist gauze dressing | V.A.C.® | | area, granulation tissue formation | | | interim (target n=40)
D008 | Molnar | bilateral thermal hand burns | 23 | silver sulfadiazine | V.A.C.® | volume (14 d), range of motion | volume (3 d, 5 d), edema | | | interim; KCI Wake Forest protocol
E008 | Stannard | draining hematoma post-surgical stablization of skeletal trauma | 79 | pressure dressing | V.A.C.® | | | drainage time, surgical evacuation | | interim; Protocol VAC2001-04
E009 | Stannard | open reduction, internal fixation of high-risk fractures | 90 | standard postop dressings | V.A.C.® | | | drainage time to Grade 3/to wound sealing | | interim; Protocol VAC2001-05
E010 | Stannard | open fractures | 28 | wet-to-moist dressings | V.A.C.® | | | | deep infections, osteomyelitis, dehiscence | interim; Protocol VAC2001-06
E011 | Payne | diabetic foot amputation wounds | 43 | moist dressings | V.A.C.® | wound closure | | foot salvage | | interim; Protocol VAC2001-07
H013 | Armstrong | complex diabetic foot ulcers | 46 | moist dressings | V.A.C.® | | wound closure | area, volume | | interim; Protocol VAC2001-08
P029 | Vuerstaek | recalcitrant leg ulcers | 60 | control | V.A.C.® | | cleaning time, healing time
P036 | Lantis | venous stasis leg ulcers | | split-thickness skin graft | graft + V.A.C.® | | | | graft take, 4–7 d, 90d | premature stop
X001 | Niezgoda | pressure ulcers | 98 | moist wound healing | V.A.C.® | | | | area, volume | interim; Protocol VAC2001-01
DD004 | Bayer | median sternotomy wound | 8 | moist dressings | V.A.C.® | | | | | wound closure too early; Protocol VAC2001-09
DD010 | Orgill | open abdominal wounds | 30 | moist wound therapy | V.A.C.® | | depth (4/5 followup periods) | | wound closure | interim; Protocol VAC2001-10
E012 | Obdeijn | acute and chronic wounds | 35 | hydrocolloids and alginates | V.A.C.® | | | | | no data in abstract