# Introduction

## Scope and Objectives

Chronic wounds are a major source of morbidity, lead to considerable disability, and are associated with increased mortality; therefore, they have a significant impact on public health and the expenditure of healthcare resources (Petrie, Yao, and Eriksson, 2003).

The incidence of chronic wounds in the U.S. is approximately 5 to 7 million per year (Petrie, Yao, and Eriksson, 2003), and the annual costs for management of these wounds is greater than $20 billion (Frykberg, Armstrong, Giurini et al., 2000; Harding, Morris, and Patel, 2002). In addition, chronic wounds can lead to complications, such as infections, contractures, depression, or limb amputation (Jeffcoate and Harding, 2003). These complications are associated with a need for assisted living and with higher mortality (Deery and Sangeorzan, 2001; Reiber, Boyko, and Smith, 1995).

The objective of this report is to systematically review the evidence on the outcomes of two technologies for wound healing: low-level laser therapy and vacuum-assisted closure. This report addresses the following specific questions:

1. In the treatment of chronic nonhealing wounds, what are the outcomes of low-level laser therapy for specific indications and patient types:
  - as a substitute for conventional therapy? or
  - as an adjunct to conventional therapy, compared with conventional therapy alone?
2. In the treatment of acute or chronic wounds, what are the outcomes of vacuum-assisted closure for specific indications and patient types:
  - as a substitute for conventional dressings? and
  - as an adjunct to conventional therapy, compared with conventional therapy alone?

This Introduction chapter provides an overview of clinical and methodologic issues relevant to evaluating the evidence on interventions for wound healing. Many variables affect the course of wound healing; so well-controlled, randomized trials are necessary to reach conclusions on treatment efficacy.

## Clinical Overview

Wound healing progresses through well-recognized, pathophysiological stages, and those wounds that do not progress to healing as expected are considered to be chronic. Conventional treatment of wounds incorporates common principles for all wounds, along with specific treatment strategies targeted to wound type and overall clinical characteristics of the patient.

### Types of Skin Wounds/Ulcers

Skin wounds are a heterogeneous and complex group of disorders with a wide variety of causes (Table 1) (Pierce, 2001). Approximately 70 percent are classified as pressure ulcers, diabetic ulcers, or vascular ulcers (Stadelman, Digenis, and Tobin, 1998a; Valencia, Falabella, Kirsner, et al., 2001). Vascular ulcers are further classified as due to arterial or venous insufficiency. Other less-frequent causes include inflammatory conditions, malignancies, burns, and radiation injuries (Valencia, Falabella, Kirsner, et al., 2001). Often the causes of wounds are multifactorial, such as in the diabetic patient who has both arterial insufficiency and peripheral neuropathy (Valencia, Falabella, Kirsner, et al., 2001). Each wound type has distinct physiologic characteristics, and exists in a unique host environment with varied clinical and psychosocial factors (Valencia, Falabella, Kirsner, et al., 2001).

Table 1. Classification of Skin Wounds

Types of skin wounds
Pressure wounds | Inflammatory wounds
º Decubitus ulcers | º Autoimmune disorders
º Neuropathic ulcers | º Primary cutaneous disorders
Vascular insufficiency wounds | Malignant wounds
º Venous insufficiency | º Primary cutaneous malignancies
º Arterial insufficiency | º Secondary cutaneous malignancies
Miscellaneous wounds
º Burns | º Vasculitic ulcers
º Radiation injury | º Spider bites
º Frostbite

Wounds are often classified as acute or chronic. Acute wounds are generally less than 8 weeks in duration and have not yet completed the natural healing cycle. Chronic wounds are defined as wounds that have failed to proceed through an orderly and timely process that produces anatomic and functional integrity (Lazarus, Cooper, Knighton, et al., 1994). Chronic wounds either require a prolonged time to heal, do not heal completely, or recur frequently.

### Phases of Wound Healing

There are three phases of wound healing: (1) inflammatory, (2) proliferative, and (3) remodeling (Steed, 2003b; Harding, Morris, and Patel, 2002). These phases are distinct, but overlap in time during the healing process.

During the inflammatory phase, neutrophils and macrophages enter the wound site. Neutrophils act primarily to prevent and respond to infection; macrophages release inflammatory mediators such as cytokines and growth factors (Henry and Garner, 2003), which clear the wound of devitalized tissue and set the stage for cellular regeneration. The proliferative phase begins after two or three days and is marked by a predominance of fibroblasts and endothelial cells. Fibroblasts secrete growth factors and extracellular matrix components that lead to tissue regeneration (Henry and Garner, 2003). Endothelial cells form the new blood vessels that are also necessary for tissue regeneration. The final phase is the remodeling phase, in which intact skin replaces scar tissue. This phase is characterized by continued cycles of new cellular component formation and degradation of the scar by proteases (Eming, Smola, and Krieg, 2002; Henry and Garner, 2003).

Wounds that heal properly progress through these phases in an orderly fashion within about 8 weeks. Nonhealing wounds are often “stuck” in one of these stages, usually continued inflammation or proliferation (Douglass, 2003; Henry and Garner, 2003). A large number of factors can impede wound healing (Figure 1) and may predispose a patient to the development of chronic wound(s) (Williams and Barbul, 2003; Steed, 2003b). These include both systemic factors (e.g., poor nutrition, metabolic derangements, and drugs) and local factors (e.g., tissue hypoxia, infection, dry wound bed) (Stadelman, Digenis, and Tobin, 1998b).

Figure 1. Factors contributing to wound healing and chronic wound formation

(Source: Douglass 2003. Adapted with permission from the British Journal of Community Nursing.)

While the above paradigm is widely accepted in conceptualizing wound care, there are alternative frameworks that have been proposed. Mustoe (2004) addresses limitations of current wound-healing science by addressing unifying aspects of chronic wounds, rather than their differences. He proposes that most, if not all, chronic wounds share common features of (1) the cellular and systemic effects of aging, (2) repeated ischemia-reperfusion injury, and (3) bacterial colonization with the accompanying inflammatory response. In this model, treatment approaches logically address all three aspects of chronic wounds.

### Conventional Treatment of Chronic Skin Wounds

Optimal management of wounds starts with prompt recognition and accurate diagnosis in order to properly treat wounds at the earliest stage possible. Early recognition depends on identification of patients at risk, education for appropriate patients, and proper surveillance (U.S. Food and Drug Administration, 2000). An accurate diagnosis can be made from the appearance of the wound and the patient's risk factors in up to 75 percent of skin wounds (de Araujo, Valencia, Federman, et al., 2003). In some cases, specialized testing such as blood flow measurement is necessary (de Araujo, Valencia, Federman, et al., 2003; Valencia, Falabella, Kirsner, et al., 2001).

Conventional treatment for established wounds incorporates common principles that apply to the management of all wounds, including debridement of necrotic tissue, maintenance of a moist wound bed, and control of infection (Table 2). These common elements are combined with treatment modalities targeted to each wound type and the clinical characteristics of the patient (Lionelli and Lawrence, 2003; Steed, 1998a; U.S. Food and Drug Administration, 2000) (Table 2). Optimal treatment also entails consideration of the appropriate intensity of treatment (Ratliff, Bryant, Dutcher, et al., 2002). For example, depending on the context, dressing changes may be performed once a day or several times per day. Nutritional support can entail a wide variety of approaches that may differ considerably. Treatment regimens that are considered intensive often involve a multidisciplinary team of clinicians, nurses, therapists, and other ancillary staff. Unfortunately, there are no widely accepted, standardized protocols that define optimal standard treatment or the appropriate intensity of treatment delivery.

Table 2. Overview of Components of Standard Care for Skin Wounds

Common treatments | Wound-specific treatments
| Pressure ulcers | Diabetic ulcers | Vascular ulcers | Burns
• Debridement of necrotic or infected tissue | • Weight off-loading | • Weight off-loading | • Moisture permeable dressing(s) | • Hemodynamic resuscitation
• Maintenance of a moist wound environment | • Regular repositioning | • Moisture permeable dressing | For venous ulcers: | • Management of comorbidities
• Control of infection, and | • Protective dressing(s) | • Blood glucose control | • Compression therapy | • Infection control
• Nutritional support | • Unna boot | • Unna boot | • Elevation of legs | • Pain control
| • Bowel/bladder care for patients at risk for contamination | | For arterial ulcers: | • Nutritional support
| | | • Establishment of adequate circulation | • Rehabilitation

For wounds that do not heal with conservative therapy, surgical intervention may be considered. Surgical restoration of adequate blood flow is the goal for wounds caused by vascular insufficiency. Arterial revascularization procedures are often curative; however, venous surgery is of uncertain benefit for this purpose (de Araujo, Valencia, Federman, et al., 2003; Valencia, Falabella, Kirsner, et al., 2001).

Skin grafting can be performed for chronic, nonhealing skin wounds that are not amenable to surgical revascularization. Skin grafts are usually taken from a portion of intact skin of the same individual (autograft), but may also be taken from a cadaveric source (allograft). The specific indications for skin grafting are not well standardized (Valencia, Falabella, Kirsner, et al., 2001). Also, skin grafting is not always successful, as the donor skin may not “take” at the graft site in up to 25 percent of cases (Valencia, Falabella, Kirsner, et al., 2001). In addition, the procedure is associated with a substantial amount of morbidity, such as pain and wound infections (Jones and Nelson, 2000). A recent Cochrane review of skin grafting for venous ulcers found the available efficacy studies to be of poor methodologic quality and concluded that there was limited evidence on whether skin grafting improves the rate of healing (Jones and Nelson, 2003). Finally, amputation may be the treatment of last resort for wounds that fail all other methods, if the benefit of healing the wound outweighs the adverse effects of amputation.

The setting in which wounds are treated varies widely, from home treatment to specialized wound treatment centers. This may influence the specific treatment modalities used and/or the intensity of treatment provided. In clinical practice, there is a high degree of variability in wound treatment, and there is evidence that standard wound care deviates substantially from optimal treatment (ECRI, 2000). Thus, patients who present with nonhealing wounds may not have received similar prior care. It is possible that many of these “nonhealing” wounds may actually heal with an adequate trial of optimal care. The variability in prior care is also a concern for clinical trials, since this variability contributes to the heterogeneity of the study sample.

### Emerging Treatments for Skin Wounds

Vacuum-assisted closure and low-level laser therapy are two potential alternatives for treating skin wounds. Low-level laser-assisted wound healing uses a low-energy, low-power, low-level laser, also known as a “cold” laser. It is hypothesized that delivery of low-energy laser therapy in this way may stimulate the physiologic process of wound healing, thus facilitating and/or accelerating the healing process. This physiologic rationale is supported by in vitro studies, and some animal models (Basford, Hallman, Sheffield, et al., 1986; Kana, Hutchenreiter, Haina, et al., 1981; Robinson, Garden, Taute, et al., 1987).

Lasers used in wound-healing applications include the gallium-aluminum (GaAl), gallium-arsenide (GaAs), and helium-neon (HeNe) laser. The power of these lasers ranges from 0.001 watts (1 mW) to 0.05 watts (50 mW), producing minimal heating of tissue. These low-energy lasers do not damage tissue directly, as do high-energy lasers that are used to ablate or vaporize tissue. Critical aspects of laser treatment delivery include the wavelength, power density (mW/cm^2^), and energy density (Joules/cm^2^). Variability in these parameters may lead to variation in tissue response to treatment (Eells, Henry, Summerfelt, et al., 2003).

Vacuum-assisted closure uses negative pressure to assist wound healing. Negative pressure drains fluid from the wound, thus removing the substrate for growth of microorganisms. Negative pressure may also accelerate granulation tissue formation and promote angiogenesis (Lionelli and Lawrence, 2003). The mechanical stimulation of cells by tensile forces may also play a role, by increasing cellular proliferation and protein synthesis (Morykwas and Argenta, 1997).

The technique involves application of a sterile, open-pore foam dressing directly on the wound. The wound is then sealed with an occlusive drape in order to create a closed, controlled environment. A fenestrated vacuum tube is attached to the wound dressing, and connected to a collection device. Negative pressure is applied at 50–125 mm/Hg, resulting in a decrease in the local interstitial pressure, and effluent from the wound is drawn out into the collection device (Lionelli and Lawrence, 2003; Morykwas and Argenta, 1997). Initially, the vacuum pressure is applied continuously. As the amount of drainage decreases, the vacuum may subsequently be applied on an intermittent basis (Morykwas and Argenta, 1997). The vacuum dressing is usually changed at approximately 48-hour intervals (Morykwas and Argenta, 1997).

Both the lasers used in wound healing and vacuum-assisted closure devices have been cleared for marketing by the U.S. Food and Drug Administration's (FDA's) 510(k) process, a regulatory mechanism that does not require submission of data from controlled efficacy trials.

There are a variety of other emerging treatments for skin wounds that are in various stages of development and FDA approval/clearance (Bennett, Griffiths, Schor, et al., 2003; Cross and Mustoe, 2003; Eming, Smola, and Krieg, 2002; Lionelli and Lawrence, 2003; Petrie, Yao, and Eriksson, 2003). These include: topical growth factors; bioengineered skin products; electrical stimulation; therapeutic ultrasound; novel dressings (e.g., hydrocolloids, alginates); hyperbaric oxygen; and gene therapy. However, discussion of these technologies is outside the scope of this evidence report.

## Methodologic Issues in Wound-Healing Research

### Confounding Factors in Healing and Treatment

As summarized in Figure 1, many factors influence wound healing (Harding, Morris, and Patel, 2002). Local factors include severity of wound (size/depth), viability of surrounding tissue, or the presence of infection or a foreign body. Systemic factors include age, functional status, nutritional status, and comorbid illnesses, such as diabetes and/or renal disease. The large number of factors that contribute to wound healing, and the high degree of variability in wound characteristics, patient characteristics, and treatment delivery result in many potential confounding factors when attempting to measure treatment effect.

Since treatment varies widely in clinical practice, it is difficult to determine whether a patient has actually received an adequate course of treatment, and whether a nonhealing wound should truly be called “refractory.” In randomized, controlled trials, a relatively large proportion of “refractory” wounds heal with standard treatment (i.e., control arm). In two recent randomized, controlled trials of bioengineered skin substitute versus standard care (Falanga, Margolis, Alvarez, et al., 1998; Veves, Falanga, Armstrong, et al., 2001), 38 percent and 49 percent of “refractory” wounds, respectively, healed completely in the standard-care arm. Even in wounds present for at least 1 year (Falanga and Sabolinski, 1999), a substantial minority (19 percent) healed with standard treatment.

As a result of these multiple confounding factors, it is difficult to interpret outcomes from single-arm trials that lack a control group, since improvement may be due to factors other than the specific intervention being tested. A concurrent control group is necessary to permit measurement of a treatment effect above that related to optimization of standard treatment or due to the natural history of wound healing. Randomized assignment to treatment group is essential in maximizing the likelihood that confounding factors are equally distributed across treatment groups.

### Design of Randomized, Controlled Trials for Wound-Healing Treatments

The FDA has prepared a draft guidance document that outlines difficulties in conducting trials to assess the effectiveness of interventions for wound healing. This document offers guidance in optimal design of such trials (U.S. Food and Drug Administration, 2000). The principals set forth by the FDA are summarized here and have been adapted in the development of the protocol for this systematic review.

Patient selection. The study population should ideally consist of patients with one particular type of skin wound, because of the different pathophysiology of each wound type and potential differences in response to therapy. A standardized definition of an adequate course of optimal care should be used in order to enroll a clinically refractory population. Alternatively, a run-in treatment period in which all patients receive an adequate course of optimal care may be utilized in order to exclude patients who heal with optimal standard care. This ensures that patients who enter the study are truly refractory to standard care.

Specific enrollment criteria that exclude conditions known to impede healing, such as very deep wounds or immunosuppression, may be helpful in reducing variability in measured outcomes. This may aid in determining the specific effect of treatment, but may also lead to reduced generalizability.

Patient assessment. Thorough assessment prior to treatment is important in accurately characterizing the features of the wound and in measuring potential confounders of outcome. Accurate recording of wound size, depth, and duration are important, since these are major predictors of healing (de Araujo, Valencia, Federman, et al., 2003).

Wounds can be measured by a variety of objective means, including direct tracing, planimetry, and stereophotogrammetry (ECRI, 2000). Wound imaging by photographic methods may also aid in the objective measurement of wounds. Other objective measures such as transcutaneous oxygen tension (t_c_pO_2_), ankle/brachial index, and microfilament testing may also be helpful in assessing the baseline wound characteristics.

A thorough assessment and measurement of other potential confounding variables should be performed at baseline and at followup time points. These include patients' clinical and demographic characteristics, comorbid medical conditions, and prior treatment received.

Treatment issues. Double-blinding of treatment is the optimal study design to minimize bias in treatment delivery and outcome assessment. A sham placebo should be considered in the control arm to allow for double-blinding. However, double-blinding may be difficult for some devices, especially for a therapy such as vacuum-assisted closure. The difficulties of double-blinding need to be balanced against the benefit in minimizing bias in interpreting the trial outcomes.

Researchers should ensure that high-quality standard treatment is delivered to the control group. “High-quality” treatment means that all of the main modalities of standard care from wound treatment guidelines are included (Table 2). No definitive standard treatment guidelines exist, but there are guidelines that incorporate modalities of standard care (e.g., from the Wound Ostomy and Continence Nurses Society [www.wocn.org]).

It is also important to ensure that standard treatment modalities are identical between groups in order to avoid performance bias. The experimental treatment arm should not include additional elements of standard care that are not delivered to the control group. The experimental treatment arm should not incorporate a greater intensity of standard care than the control arm. The importance of equal intensity of care was demonstrated in a prior multicenter trial of platelet-derived growth factor for chronic wounds (Cross and Mustoe, 2003). In this study, the rate of healing was significantly higher in centers that incorporated more frequent debridement (Cross and Mustoe, 2003).

An adequate followup period is required to demonstrate durability of response and adverse effects. It is recommended that patients remain enrolled in studies for at least 3 months following initiation of treatment (U.S. Food and Drug Administration, 2000). This is the minimum amount of time required to evaluate the number of healed wounds that recur. Some experts recommend an even longer minimum duration. For example, Steed (2003b) recommends that the minimum duration of a clinical trial include a run-in period of standard care, followed by 20 weeks of treatment, and an additional 12 weeks of followup.

Outcomes and outcome measurement. Outcome measurement should focus on outcomes that are quantitative and clinically meaningful (Jeffcoate and Harding, 2003; Steed, 2003b). The most important outcomes to be considered are: (1) the percent of patients with complete healing; and (2) time to complete healing.

Other outcomes that may also be clinically meaningful are: (1) facilitating surgical wound closure; (2) change in wound size; (3) improved cosmesis; (4) improved activities of daily living; (5) improved quality of life; (6) pain; (7) transcutaneous oxygen tension; (8) infections; and (9) need for debridement.

In some cases, particularly for vacuum-assisted closure, the treatment may not be expected to result in complete healing. Rather, the treatment may be intended to advance the wound to a stage where healing is possible, either by continued conventional treatment or by surgical closure. These goals represent intermediate treatment outcomes. If the overall treatment strategy is successful, the benefit of these intermediate outcomes will ultimately be reflected in improved rates of complete healing. The intermediate outcome states are more difficult to measure, but are likely partly represented by the secondary outcomes of wound size and facilitation of surgical closure.

Outcome assessment should also include measurement of adverse events that result from the treatment or from the natural history of the disorder. These include: (1) local adverse effects (pain, discharge, dermatitis); (2) immune reactions; (3) infections; (4) limb amputations; and (5) discontinuation from treatment, including assessment of whether discontinuation is a result of the treatment.

Ascertainment of outcomes should be ideally performed by an independent, blinded individual. This is especially important in situations where patients and/or treating physicians are not blinded to treatment.