# Appendix B. Technical Expert Panel (TEP) and Reviewers

## Technical Expert Panel (TEP)

- David G. Armstrong, D.P.M., M.Sc., Ph.D.(c)
- Professor of Surgery
- Chair of Research and Assistant Dean
- Dr. William M. Scholl College of Podiatric Medicine at
- Rosalind Franklin University of Medicine and Science
- North Chicago, IL

- Sharon Baranoski, M.S.N., R.N., C.W.O.C.N., A.P.N., F.A.A.N.
- Administrator, Home Health and
- Administrative Director of Clinical Programs and Development
- Silver Cross Hospital
- Joliet, IL

- Harriet Williams Hopf, M.D.
- Associate Professor in Residence
- Department of Anesthesia and Perioperative Care and Surgery
- University of California, San Francisco
- San Francisco, CA

- Frank LoGerfo, M.D.
- William V. McDermott Professor of Surgery
- Harvard Medical School and
- Chief, Division of Vascular Surgery
- Beth Israel Deaconess Medical Center
- Boston, MA

- Harold R. Mancusi-Ungaro, Jr., M.D., F.A.C.S.
- Chief, Plastic Surgery
- Kaiser Permanente, Santa Rosa
- Santa Rosa, CA

- William S. Schwab, III, M.D., Ph.D.
- Chief of Geriatric Services
- Ohio Permanente Physician Group
- Willoughby, OH
- Nominee: American Association of Health Plans (AAHP; Partner Organization)

## External Peer Reviewers

- David Atkins, M.D., M.P.H.
- Chief Medical Officer
- Center for Outcomes and Quality
- Agency for Healthcare Research and Quality
- Rockville, MD

- Elise Berliner, Ph.D.
- Agency for Healthcare Research and Quality
- Rockville, MD

- Caroline Fife, M.D.
- Associate Professor of Anesthesiology
- Department of Anesthesiology
- The University of Texas-Houston Medical School and
- Director, Hermann Center for Wound Healing and Lymphedema Management
- Houston, TX

- Kenneth S. Fink, M.D., M.G.A., M.P.H.
- Director, Evidence-based Practice Centers (EPC) Program
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD

- Carmen Kelly, Pharm.D.
- LT, U.S. Public Health Service
- Pharmacist Officer and
- EPC Task Order Officer
- Agency for Healthcare Research and Quality
- Rockville, MD

- Steven R. Kravitz, D.P.M.
- President
- American Podiatric Wound Care Association
- Richboro, PA
- Nominee: American College of Foot and Ankle Surgeons

- Wayne J. Schroeder, M.D.
- Vice President, Medical Director
- Kinetic Concepts, Inc.
- San Antonio, TX

- James Spencer, M.D.
- Assistant Attending
- The Mount Sinai Hospital and
- Associate Professor
- Mount Sinai School of Medicine
- Department of Dermatology
- New York, NY
- Nominee: Association for the Advancement of Wound Care

- Jackson Streeter, M.D.
- President and CEO
- PhotoThera, Inc.
- Carlsbad, CA 92008

- Pamela G. Unger, P.T.
- The Center for Advanced Wound Care
- Partner, Director of Clinical and Administrative Services
- Wyomissing, PA

- Stephanie Yates, R.N., M.S.N., C.W.O.C.N.
- Clinical Nurse Specialist
- Rex Healthcare
- Raleigh, NC
- Nominee: Wound Ostomy and Continence Nurses Society