# Appendix A. Exact Search Strings

Electronic database searches using the following terms were completed of MEDLINE® (via PubMed), EMBASE, and the Cochrane Controlled Trials Register. The MEDLINE® search covered references entered onto the database from January 1, 1966 through June 8, 2004. The Cochrane Controlled Trials Register search was completed in 2003, through issue number 4. The EMBASE search covered references entered through June 14, 2004.

The search was limited to studies on human subjects with English-language abstracts. Papers published in foreign languages were reviewed if the English-language abstract appeared to meet inclusion criteria. Results of the search and study selection were reviewed by the Technical Expert Panel (TEP) for this project, in order to identify additional studies.

In addition, two companies that produce lasers used in wound healing were contacted (Microlight Corporation of America and Photothera), as well as the major producer of vacuum-assisted closure devices (V.A.C.®, Kinetics Concepts Inc. [KCI]) and invited them to submit evidence-based information for the review. The specific request was for “lists of published, randomized, controlled trials (RCTs), published abstracts of RCTs within the past 2 years, and published articles on study design, or protocols of any RCTs (published or in progress).”

## Low-Level Laser Therapy

For low-level laser therapy, the search is somewhat narrower than for vacuum-assisted closure because the question is limited to chronic, nonhealing wounds.

A Medical Subject Headings ® (MeSH®) term, “laser therapy, low-level,” was introduced in 2002. The following entry terms map to it:

- Laser Therapies, Low-Level
- Laser Therapy, Low Level
- Low-Level Laser Therapies
- Laser Irradiation, Low-Power
- Irradiation, Low-Power Laser
- Laser Irradiation, Low Power
- Laser Therapy, Low-Power
- Laser Therapies, Low-Power
- Laser Therapy, Low Power
- Low-Power Laser Therapies
- LLLT
- Laser Biostimulation
- Biostimulation, Laser Low-Level
- Laser Therapy Low Level
- Laser Therapy Low-Power
- Laser Irradiation Low Power
- Laser Irradiation Low-Power
- Laser Therapy Low Power
- Laser Therapy

The following text phrases will also be searched:

- “low level laser”
- “low power laser”
- “low intensity laser”
- “low energy laser”
- “low level energy laser”
- “low output laser”
- “nonablative laser”
- “cold laser”

These terms related to wounds will be searched:

- “skin ulcer[MeSH]”
  - “decubitus ulcer”
  - “foot ulcer”
  - “leg ulcer”
  - “varicose ulcer”
  - “diabetic foot”
- “wound*”
- “ulcer*”

The intersection of the laser therapy terms and wound terms served as the initial pool of references. These were cross-referenced with the terms for randomized trials compiled by the Cochrane Collaboration (Clark and Oxman, 2003).

## Vacuum-Assisted Closure

Searches on the terms below relate to vacuum-assisted closure:

- “topical negative pressure”
- “sub-atmospheric pressure therapy” (also “subatmospheric”)
- “sub-atmospheric pressure dressing” (also “subatmospheric”)
- “vacuum sealing”
- “vacuum assisted closure”
- “negative pressure dressing”
- “negative pressure therapy”
- “foam suction dressing”
- “vacuum compression”
- “vacuum pack”
- “sealed surface wound suction”
- “sealing aspirative therapy”

These terms related to wounds will be searched:

- “wound*;”
- “ulcer*”
- “decubit*”
- “incision*”
- “dressing”
- “free flap”
- “skin graft*”
- “skin transplantation”
- “degloving injuries”
- “degloving injury”

Excluded terms:

- “mechanical ventilation”
- “ear pressure”
- “venous pressure”
- “hypertension”
- “abortion”
- “core needle”
- “colonic anastomos*”

The intersection of the vacuum-assisted closure terms and wound terms served as the initial pool of references. These were cross-referenced with the terms for randomized trials compiled by the Cochrane Collaboration (Clark and Oxman, 2003).