# Methods

## Task Order Questions

The National Institute on Nursing Research, National Institutes of Health, requested this systematic review in preparation for a State of the Science conference to be held in December 2004. The following key questions were originally posed in the Request for Task Order (RFTO):

1. What outcome variables are valid indicators of the quality of the end-of-life experience for the dying person and for the surviving loved ones?
  a. What individual outcome measures are most strongly associated with overall satisfaction with end-of-life care?
  b. What is the reliability and validity of specific instruments for measuring quality of life or quality of care at end of life?
2. What patient, family, and healthcare system factors are associated with better or worse outcomes at end of life?
  a. What individual patient factors (e.g., age, gender, race/ethnicity, underlying illness, education) are associated with better or worse outcomes at end of life?
  b. What family factors (e.g., relationship to patient, race/ethnicity) are associated with better or worse outcomes at end of life, including both outcomes reported by the family and how the family affects outcomes experienced by the patient?
  c. What healthcare system factors (e.g., site of care, type of provider, support services) are associated with better or worse outcomes?
3. What processes and interventions are associated with improved or worsened outcomes?
  a. What is the effectiveness of specific healthcare interventions for improving specific outcomes in patients at end of life?
  b. Does effectiveness of specific interventions vary among different populations?
4. What are future research directions for improving end-of-life care?

## Overview

In order to proceed with the task order, we assembled a team of clinical and methodological experts and staff and worked closely with the directors and staff of the Southern California Evidence Based Practice Center. Dr. Karl Lorenz led the day-to-day work of the review and writing teams with the close assistance and regular involvement of Drs. Joanne Lynn, Paul Shekelle, and Sally Morton. Our team included eight literature reviewers (with Dr. Lorenz) whose interests span broad concerns in palliative care and represented nursing, medicine, and gerontology. Reviewers possessed diverse clinical experience and included an oncology nurse, one intensivist, and two general internist/palliative care physicians. Our gerontologist reviewers possess special expertise in nursing home and hospice issues. The overall team met weekly to review and refine the methodology of the task order. Meetings and teleconferences of the SCEPC staff with technical experts helped specify issues central to this report within the framework of the key questions provided by AHRQ and NINR. The SCEPC conducted a comprehensive search of the medical literature to identify studies addressing the key questions. Staff reviewed relevant articles, compiled tables of study characteristics and results, appraised the methodological quality of the controlled trials, and summarized results.

## Technical Expert Panel—Scope and Approach to the Report

In consultation with our Agency for Healthcare Research and Quality (AHRQ) Task Order Officer and the NIH Conference Panel Chair, we created a Technical Expert Panel (TEP) to guide the evidence report. We invited a multidisciplinary group of leading scientists and clinicians with expertise in nursing, gerontology, and palliative medicine and a broad knowledge of research and policy issues in the field of palliative care in both the United States and Europe to participate. The list of potential technical experts and their curriculum vitae were submitted to the Task Order Officer for approval, and a list of members is included in Appendix F.

Project staff worked closely with AHRQ, the Chair of the State of the Science Conference, and the TEP to refine the research questions and focus on the relevant outcomes in the topic areas. Before the contract was awarded, the sponsors had decided not to focus upon children or drugs used in palliative care. In considering the scientific literature that our review might address, we found it necessary to further focus and narrow the research questions.

One consideration was to represent the field by focusing on important, representative clinical conditions. We wanted to address important settings of care and also to illuminate important aspects of the patient and caregiver experience. Cancer patients experience a somewhat predictable decline, and are often served by hospice in their final weeks. ^1^ In contrast, patients with organ system failure (e.g., CHF, COPD) may experience stable but impaired function punctuated by unpredictable, severe illness and rather sudden death ^62–64^ and are less often served by hospice. Patients with dementia have prolonged declines and often reside in nursing homes. ^9,^ ^65^ As an organizing principle, our analysis deliberately highlighted evidence that illuminated the experience of living through the end of life with

- cancer
- chronic heart failure
- dementia.

A second consideration in approaching the topic is that the category “end of life” has been undergoing substantial changes in recent years, and the lack of a settled definition has greatly limited the coherence of the research literature. ^21^ Previous systematic reviews concerned with end-of-life care have focused on well-bounded disease states (e.g., cancer), clinical conditions, (e.g., pain), or specific treatments (e.g., palliative services). ^66–69^ In organizing a review around the “end of life” population, George observed variation among operational definitions used in research, including diagnosis; prognostic criteria including diagnosis; symptom expression; functional capacity; provider, patient, and family estimates of life expectancy; or particular healthcare settings (e.g., ICU). ^21^

These varying operational approaches reflect a few clinically relevant distinctions. Some investigators may use “end of life” to mean the last few days or hours, roughly corresponding to what hospice nurses call “active dying.” Others mean a larger group of people who would be eligible for hospice with the six-month prognosis required for hospice admission or some other arbitrary prognostic interval. The broadest approach uses “end of life” to denote the part of life when a person is impaired with an eventually fatal condition, even if the prognosis is ambiguous. We did not distinguish among these approaches in our review and implicitly accepted the broadest definition—of a period of time when a person and his or her family are living with the challenges of advanced illness.

The first of a series of calls was held April 28, 2004 with our Chair and the TEP, and we narrowed the scope in a fashion consistent with the sponsor's priorities not to include chemotherapy, radiotherapy, stents, surgery, and other similar medically invasive or technically complex procedures. The TEP and the project sponsor also added a preliminary question of the evidence underlying various potential definitions of the field. For that reason, in addition to the task order questions, we also examined a preliminary question (Appendix A) of prognostication within the end-of-life literature.

Furthermore, since the RFTO was organized around outcomes in the end-of-life literature, we discussed considerations related to specific outcomes with the TEP and conducted a modified Cambridge ballot (see Appendix G) to prioritize those outcomes for inquiry. ^70^ TEP members rated aspects of end-of-life care, on the basis of

- relative importance
- relationship to patient experience
- feasibility
- relevance to clinical care and healthcare policy
- the availability of recent reviews on the topic
- ability to illuminate differences in the strength of research
- modifiability in clinical practice and policy.

Each potential topic that included pain, affective symptoms, other symptoms, quality of life, spiritual or existential well-being, caregiver well-being and satisfaction, provider communication, advance care planning, continuity and coordination, utilization of services, and site of death was rated independently by each TEP member on each of the above attributes on a scale of 0–10. We totaled the score for each topic area and discussed the findings with TEP members, asking them to reflect on their rankings. The TEP and the sponsors agreed that the EPC search would not include grief and bereavement, spiritual issues, highly technical care (defined as surgery, stents, laser therapy, chemotherapy, and radiation therapy and similar technological innovations), or general issues of communication including giving bad news. Keeping in mind the sponsor's priorities of focusing on aspects of the patient and family experience, and healthcare system concerns, this process resulted in our final decision to focus on the following topic areas in addition to satisfaction with care (specified in Question 1a).

- The patient's experience, focused on Symptoms, particularly
  - Pain
  - Dyspnea (shortness of breath)
  - Depression or anxiety
  - Behavioral issues in dementia.
- The family's experience, focused on Caregiving (excluding bereavement).
- The healthcare system's performance, focused on Continuity.
- The joint endeavor of decision-making and providing care consistent with preferences, focused upon Advance Care Planning.

Table 1 illustrates the task order questions and how we organized the report to address the sponsor's priorities of the patient and family's experience, and the healthcare system's performance.

Table 1. Report Section by Key Question

Key Question | Section of Report
Preliminary | The scope of the population (Appendix A)
Q 1a | Chapter 3 A. Better and worse outcomes, especially patient and family satisfaction
Q 1b | Chapter 3 B. Measurement of outcome elements for the patient and family
Q 2 and 3 | Chapter 3 C. The patient experience, especially symptoms
| Chapter 3 D. The family experience
| Chapter 3 E. Health-care system performance, especially continuity of services
| Chapter 3 F. Decision-making, especially advance care planning
Q2 | Chapter 3 G. Summary of patient, family, and health system factors associated with better or worse outcomes
Q3 | Chapter 3 H. Summary of the effectiveness of interventions
Q 4 | Chapter 4. Future research directions for improving end-of-life care

The reader will note that this implements a general strategy of including a broad scope, but also providing focus on a specific important issue within each dimension of that scope. This strategy deliberately leaves some important issues incompletely addressed or not addressed at all. In addition to the exclusion of children and drugs mentioned earlier, this strategy means that this report does not address, except in passing, such issues as spirituality, bereavement, rehabilitation, withdrawal of life support, or any of an array of additional symptoms (fatigue, seizures, delirium, hallucinations, pressure ulcers, and so on). The report also does not focus on many important illnesses such as HIV/AIDS, multi-organ system failure, end-stage renal disease, chronic obstructive lung disease, frailty of old age, or neurological degenerative conditions other than dementia. Finally, articles on advanced illness but which did not include the search terms we used related to “end of life” in the title, abstract, or indexing terms were not are likely not to be included, except by nomination of one of the expert reviewers.

## Analytic Framework

Donabedian's quality-of-care framework structures our examination of the associations among outcomes considered by the project. Donabedian described the relationship between outcomes, processes, and structure of care. ^71^ Quality of care, quality of dying, quality of life, and satisfaction are various distal outcomes that apply in varying degrees to both patients and caregivers. ^21,^ ^22^ Other topics we chose to examine (e.g., pain and symptoms, advance care planning, caregiver burdens, and continuity/coordination) could be considered as both processes of care related to these more global outcomes or as outcome themselves. In addition, some of these concerns may be understood as processes that affect other considerations as outcomes (e.g., improved pain and symptom management could reduce caregiver anxiety or improved continuity could improve pain management).

## Evidence Sources and Searches

### Literature Searches

Sources for our review included Medline, the Database of Reviews of Effects (DARE), the National Consensus Project for Palliative Care, and several recent unpublished systematic reviews from National Institute for Clinical Excellence (NICE) and Health Canada. National Library of Medicine (NLM) staff performed most of the searches, complemented by RAND library searches. Members of the project team worked closely with the TEP and librarians at NLM to decide how to refine the search strategy. We limited the searches to published articles in the English language, appearing in journals between the years 1990 through 2004, involving human subjects, and excluding individual case reports. The first search of PubMed was conducted by NLM staff in April 2004. The main search strategy included an extensive list of terms intended to identify all research publications associated with

- palliative or end-of-life care
- both overall (e.g., quality of life, quality of care, quality of death, satisfaction) and specific outcomes (e.g., pain and other symptoms) of interest
- measures and measurement
- individual, family or caregiver, and health system factors
- the full scope of healthcare settings relevant to end-of-life care.

The initial search strategy can be found in Appendix B1.

RAND and NLM created supplemental search strategies (Appendix B2) one week after the initial searches to enrich the initial set of citations. One revised search included terms on psychological and physical symptoms (i.e., pain, depression, anxiety) and specific healthcare services (i.e., nursing homes, hospice, home care) related to end-of-life care. The other new search focused on our three exemplary clinical conditions: cancer, heart failure, and dementia. Given the large number of citations identified through Medline, additional searches of other electronic databases simply were not possible within the resources and time constraints of the project.

### Database of Abstracts of Reviews of Effectiveness

DARE contains structured abstracts of high-quality systematic reviews published in the scientific literature. DARE also contains references to other reviews which may be useful for background information. The reviews are identified by searching through key medical journals, bibliographic databases, and less widely available “gray literature.” DARE includes papers that review the effectiveness of healthcare interventions or organization. The quality of the database content relies upon ensuring that all reviewers work to specified guidelines, and that independent checks on the review process are carried out. DARE is produced by the Centre for Reviews and Dissemination (CRD) at the University of York, UK. Full information about the database is available on the DARE website at http://york.ac.uk/inst/crd/darehp.

As displayed in Appendix B3, we searched for systematic reviews on cancer, heart failure, dementia, palliative care, and the topics we focused on for this review. One of us (KL) searched DARE using relevant terms and conducted an implicit title review of the resulting citations.

### National Consensus Project

In February 2004, the National Consensus Project (NCP) for quality palliative care published guidelines to improve the delivery of palliative care in the United States. NCP conducted a search of the end-of-life literature that, although not strictly systematic, was extensive and gathered the input of clinical, research, and policy leaders in palliative care selected through a national nomination process. Five palliative care organizations oversaw the National Consensus Project including the American Academy of Hospice and Palliative Medicine (http://www.aahpm.org), the Center to Advance Palliative Care (http://www.capc.org), the Hospice and Palliative Nurses Association: (http://www.hpna.org), the National Hospice and Palliative Care Organization (http://www.nhpco.org), and the Last Acts Partnership (http://www.lastactspartnership.org). We incorporated the entire reference list, eliminated duplicates, and screened studies that were not otherwise identified through our computerized searches.

### Major Recent Systematic Reviews of Palliative Care

In addition to systematic review citations identified via DARE and Medline, the project identified several unpublished but important reviews (listed chronologically by recency) of the end-of-life literature relevant to our task order directives and topics. These were evaluated for quality, and those accepted as high-quality reviews (see below) were key sources for certain topics of the review.

2003 NICE Systematic Review of Supportive Care for Cancer. TEP member Prof. Irene Higginson provided a systematic review on Improving Supportive and Palliative Care for Adults with Cancer that was conducted for the National Institute for Clinical Excellence (NICE) in 2003. ^72^ This recently published review (available at http://www.nice.org.uk/page.aspx?o=110005) evaluated studies from Medline, EMBASE, CINAHL, Cochrane Registry of Controlled Clinical Trials (CENTRAL), Cochrane Database of Systematic Reviews, and an Effective Practice and Organization of Care (EPOC) specialist register published from 1966 to 2003, and was organized around a wide variety of supportive interventions in oncology including coordination of care, patient activation, communication, information provision, psychological support, social support, spiritual support, palliative care services, rehabilitation, complementary therapies, and family and caregiver support. Of 5263 studies reviewed, 443 potentially eligible studies were accepted after abstract review.

2003 Health Canada Reports. Health Canada, Canada's federal department of health provided an unpublished review that evaluated studies from nine databases (Medline, EMBASE, CINAHL, AHMED, PsychInfo, Eric, HealthStar, Sociological Abstracts, and Cochrane and covered the period 1987-2003). This Health Canada project generated 32 recent reports on a wide variety of topics, our review by two project investigators identified 14 of these as relevant to our task order directive and principal topic areas. Titles of all 32 reports are listed in Appendix C.

2000 Toolkit of Measures for End of Life Care (TIME). TEP member Dr. Joan Teno published the Toolkit, which arose from a review of over 928 articles identified from 1967 through 2000 and which selected 293 measures as potentially relevant to end-of-life care research. The Toolkit review through 2000 recommended 35 unique measures based on the criteria that (1) measures should be patient-focused, family-centered, clinically meaningful, and manageable in their application; (2) measures should strive for reliability, validity, and responsiveness; (3) measures should be user-friendly and relevant to quality evaluation and improvement; (4) measures should incorporate both the patient and family perspectives; and (5) measures should examine both the process and the outcomes of care. The website, http://www.chcr.brown.edu/pcoc/bibliographies.htm, gives an extensive summary of the Toolkit. The Toolkit is a well-known and widely used resource within the palliative care community and served as a foundation for our review of measurement.

### Gray Literature

We sought supplemental publications from experts on our team and others involved in the review process, including the occasional “gray literature.” We did not make an exhaustive effort to solicit this information however because a recent and well-conducted systematic review that evaluated the efficacy of palliative care teams demonstrated that the gray literature did not affect the results. ^73^

## Title Screening, Abstract Review, and Selection of Individual Studies

Eight researcher reviewers, six with clinical backgrounds in palliative care and all with established research careers in the area, conducted the study selection process. We trained the group in the critical analysis of scientific literature. The principal investigators resolved any questions or needs for clarification that arose throughout the literature review. Reviewers screened all titles found through our NLM searches or the NCP database or that were submitted by content experts for pertinence to the key questions and therefore their relevance to this project. We established screening criteria to facilitate the identification of articles concerning patient, caregiver, or health system factors related to patient and family-centered outcomes. At the title screening stage, we marked for exclusion citations that were

- exclusively pediatric (≤18 years of age)
- case studies with ≤ 30 cases
- not on palliative care content (e.g., not about people who are living with serious illness or not an appropriate outcome)
- exclusively non-Western (i.e., North America, Europe, Australia/New Zealand)— either the population or the journal of origin
- nonsystematic review articles
- clinical trials about chemotherapy, radiotherapy, stent, laser, endoscopy, surgery
- descriptive of ethics, legal, or regulatory issues (nonclinical discussions)
- descriptive of the process of research
- editorials, history, personal narrative or other descriptive, nonclinical articles
- about palliative care professional education (unless effects on clinical, patient outcome(s) are described)
- about organ transplantation and/or organ donation
- clearly discussing research data only from before 1990
- studies in which the outcome was a lab, radiological test, or physiologic indicator (articles about strictly medical/technical outcomes even in the appropriate population).

We only eliminated citations at the title screening stage that clearly met any of the above criteria; we generally retained ambiguous citations. Some of the exclusions warrant explanation. Of the above criteria, as noted, we took the broadest possible view of the “end of life” population. We did not accept articles from the non-Western literature or those that focused exclusively on non-Western populations because (a) health systems and cultural factors are known to vary profoundly, limiting their applicability, and (b) these studies have qualitatively made little to no contribution to major recent systematic reviews of palliative care. ^72,^ ^74^ We did not include clearly nonsystematic reviews in the title stage because so many citations fell into this category and we searched secondary sources (e.g., DARE) to supplement systematic reviews of relevant topics in the most efficient fashion. We excluded articles arising from data before 1990 because George ^21^ found that articles published before 1990 constituted just 10% of her unlimited review and articles more than fifteen years old are harder to locate in a short time. We decided to limit on the basis of when the data were generated, rather than when the article was published, since articles can take varying times to be published. We eliminated small case reports because one of the principal investigators (KL) reviewed a random sample of 30 such citations and corresponding reports and determined that they would add little substantive information, even descriptively, to understanding the issues in this review.

Approved titles moved on to the abstract screening phase. We designed a one-page data collection instrument specifically for this project and pilot-tested it with all reviewers after training conducted by SCEPC staff. This abstract screener (see Appendix D1) contained questions about outcomes, population, age, location, design, research topics, and diseases studied. The abstract screener phase included the same exclusion criteria as the title review stage. We added additional exclusion criteria based on the outcomes within the scope of the review that were chosen in consultation with our TEP and Conference Chair. Therefore, we excluded abstracts that clearly dealt with topics other than

- “good death” or “quality of dying”
- patient or family satisfaction
- measures
- family or informal caregiver concerns (other than bereavement alone)
- advance care planning
- continuity and coordination
- ain
- dyspnea
- depression or anxiety
- behavioral issues in dementia.

We provided definitions of these topics that were consistent with the general approach and definitions articulated in the field (see Introduction). Articles that focused on background or prognosis were marked for separate examination, as described below. Project staff entered data from the forms into an electronic database and tracked all studies through the screening process. We ordered all articles that were accepted after abstract screening and sent them out for further review based on topic area.

## Procedures to Reduce Bias, Enhance Consistency, and Check Accuracy

Because of the very large number of citations to be evaluated and the short time to completion, we determined that the EPC's usual method of dual independent reviews of all titles was not feasible. Therefore, we used single review of titles and abstracts and employed the following techniques to improve the reliability and accuracy of our method.

- Reviewers were trained in principles of citation review and use of a “training set” for title review to encourage consistent application of the definitions and criteria of the project.
- One of the principal investigators (KL) served as the “gold standard reviewer.” Outlier sets were identified by a second abstraction of a random subset of titles within each reviewer's citation set, and the proportion of retained titles was compared. Dr. Lorenz subjected high and low outlier title sets to a second review.
- Specific definitions were used for both exclusion criteria and categorization of abstracts as described above. These criteria were similar at the title and abstract review stages.
- Reviewers were instructed that in any situations where they were not certain of their categorization to request a “second review” of abstracts, both to facilitate reviewer learning and enhance concordance with the ‘gold standard’ reviewer.
- A second review of a random subset of abstracts from all reviewers was conducted.

Following title and abstract review, accepted articles were reviewed by topic teams. The teams of at least two reviewers reached consensus on inclusion of final article sets for each topic area as well as consensus on data abstraction from these articles. Because of the large number of articles and the short time for our review, in practice articles were not dual-abstracted even though team members worked together closely, but abstraction results and findings were reviewed by the principal investigators for accuracy.

## Summarizing the Evidence (Key Questions 1–3)

### Previous systematic reviews—Definitions

As described above, we had three sources of reviews: our DARE search, experts, and titles identified in broad library searches that abstract review identified as systematic reviews or meta-analyses, using the definitions above (nonsystematic reviews were excluded). Before we begin discussion of the screening and assessment of reviews, we note the definitions that we used: ^75,^ ^76^

- Review: A review article that summarizes a number of different studies and may draw conclusions about a particular intervention. The methods used to identify, select, and appraise the studies are not systematic or necessarily reproducible. The summary in a review is generally narrative.
- Systematic review: A review of a clearly formulated question that uses systematic and explicit methods to identify, select, and critically appraise relevant research and to collect and analyze data from the studies that are included in the review. Statistical methods are NOT used to analyze and summarize the results of the included studies.
- Meta-analysis: A systematic review that uses statistical methods to integrate the results of the individual studies. A meta-analysis contains at least one estimate formed by pooling results across individual studies, i.e., an overall odds ratio.

We applied these definitions in the following manner. If a publication addressed a number of studies, then it was a review. If it was a review, then we assessed if the methods (search methods, inclusion/exclusion criteria, quality assessment, etc.) were systematic. If it was a systematic review, then we assessed if it produced a pooled estimate, i.e., applied meta-analytic procedures. If a review was clearly not a systematic review or meta-analysis, then we simply called it a review.

### Screening of Reviews

We assessed all resulting reviews using a Systematic Review Screener (Appendix D2). Mostly, we relied upon the abstract; but, if an abstract was not available, we obtained the original article for screening. We excluded all that were not true reviews (i.e., did not address more than one study); were not systematic reviews or meta-analyses; or were not appropriate to our topics (using the same exclusion criteria as on the general screener above). Generally, reviews were not appropriate if they did not address palliative care.

All systematic reviews and meta-analyses that passed screening were sent to the appropriate topic team. For example, if the review addressed symptoms and advanced care planning, it was sent to both the symptoms and advanced care planning teams. The topic teams read each review with particular attention to the team's specific topic. They recorded the publication date and the date that the search for literature ended. Using these dates as well as the topic the review addressed, they assessed how relevant the review was to their topic. All reviews that were considered “highly” or “possibly” relevant were then assessed for quality.

### Implicit Quality Assessment of Systematic Reviews

Two reviewers (PS and SM) reviewed all highly or possibly relevant systematic reviews or meta-analyses for quality independently. They then discussed their findings and reached consensus on the quality determination. No situations arose in which consensus could not be reached.

The reviewers categorized each review as either good, fair or poor quality. Good and fair reviews were acceptable to be used by the topic teams as evidence. The quality assessment was implicit. In this assessment the reviewers considered several characteristics of the review, drawing upon guidelines for assessing the quality of systematic reviews and meta-analyses. ^77,^ ^78^ Good systematic reviews and meta-analyses met almost all of the standards below, and fair systematic reviews or meta-analyses met the majority:

- The search should be comprehensive, systematic and reproducible. Publication bias should be minimized, its existence assessed, and its possible impact on the conclusions discussed.
- The inclusion/exclusion criteria for studies should be clear, reproducible, and defensible, and a flowchart of studies should be provided.
- The study quality assessment criteria and process should be described and evidence-based.
- Data abstraction should be done by two independent readers with a consensus process, or by one reader after a reliability test.
- Individual study characteristics should be presented and possible causes for study heterogeneity considered and investigated.
- If the review is a meta-analysis, the pooling methods should be described and appropriate.
- The results of the review should follow from the evidence presented. Potential biases in the review process and their possible impact on the conclusions should be evaluated and discussed.

All systematic reviews assessed as good or fair quality were summarized by the topic area teams with a narrative description including an in-text table.

### Intervention and Observational Studies

Intervention studies included a variety of designs, and we included all types in our report, being sure to emphasize study design and quality in the narratives. We used the following definitions:

Randomized controlled trial (RCT): A trial in which the participants (or other units) are definitely assigned prospectively into either “control” or “study” groups using a process of random allocation (e.g., random number generation, coin flips). “Study” groups receive a specific procedure, maneuver, or intervention.

Controlled clinical trial (CCT); A trial in which participants (or other units) are either

a. definitely assigned prospectively to one (or more) “control” or “study” groups using a quasi-random allocation method (e.g., alternation, date of birth, patient identifier) OR
b. possibly assigned prospectively to one (or more) “control” or “study” groups using a process of random or quasi-random allocation.

Intervention trial with comparison group but not RCT/CCT: A trial in which the participants (or other units) receive one of two (or more) forms of health care; some or all participants are either:

a. not assigned to one of two (or more) forms of health care by the investigator, OR
b. are not assigned prospectively to one of two (or more) forms of health care (e.g., historical control).

Intervention study without comparison group. A trial in which all participants (or other units) receive the same form of health care (e.g., pre-post).

Observational studies. We also evaluated a variety of other observational designs employed in nonexperimental studies. These designs may be retrospective, cross-sectional, or prospective.

### Assessment of Quality—Intervention and Observational Studies

To evaluate the quality of the individual intervention studies, we collected information on the study design, withdrawal/dropout rate, method of random assignment (and blinding), and method for concealment of allocation (the attempt to prevent selection bias by concealing the assignment sequence prior to allocation) consistent with requirements for ODS-OMAR-supported EPC evidence reports. The elements of design and execution (randomization, blinding, and withdrawals) have been aggregated into a summary score developed by Jadad. The Jadad score rates studies on a 0 to 5 scale, based on the answer to three questions:

1. Was the study randomized?
2. Was the study described as double-blind?
3. Was there a description of withdrawals and dropouts?

One point is awarded for each “yes” answer, and no points are given for a “no” answer. Additional points are awarded if the randomization method and method of blinding were described and were appropriate. A point is deducted if the method is described but is not appropriate. Empirical evidence in other clinical settings has shown that studies scoring 2 or fewer points show larger apparent differences between treatment groups than do studies scoring 3 or more. ^79,^ ^80^

Observational studies were assessed using ODS-OMAR procedures. Because of the extremely large number of observational studies identified, we were forced to limit our review of observational studies by definitely accepting only those that met the following criteria consistent with the task order goals:

a. If the study dealt with the topic of race / ethnicity as a single description of a racial group OR in the results reports racial differences, THEN it was included. If it did not do that AND it did not meet other criteria (b or c), then it was rejected.
b. If the study dealt with a setting of care other than hospice or compared settings of care, then it was included. If it did not do that AND it did not meet other criteria (a or c) then it was rejected.
c. If the study deals with the topic of CHF or dementia it is included, OR if it dealt with a comparison of a non-cancer disease state with cancer, then it was included. If it did not do that AND it did not meet other criteria (a or b), then it was rejected.

We defined a cohort as “a group of people who share a common experience or condition.” For example, a birth cohort shares the same year of birth; a cohort of smokers has smoking as the common experience. ^81^ We also distinguished prospective cohorts as those that were forward looking or longitudinal in design and in which the measurement of exposure preceded the measurement of the outcome. We included all prospective cohorts that met criteria a-c. Selected observational studies were included in the evidence tables at the implicit discretion of our expert reviewers if they addressed an important aspect of the topic even if they did not meet criteria a-c.

Qualitative research studies were included only in the discussion of satisfaction and its relationship to other outcomes (question 1a). These studies were reviewed by a single reviewer (KL) to examine common themes in the literature. Most qualitative studies involved focus groups or unstructured individual interviews.

### Qualitative Data Analysis

We report the evidence in several forms. First, the evidence tables (in Appendix E—Interventions and Appendix L —Observational Studies) offer a detailed description of the studies that we identified, addressing each of the topic areas. At the end of the printed report, summary tables report on systematic reviews and intervention studies in an abbreviated form, using summary measures of the main outcomes. Narrative text summarizes the findings and provides qualitative analysis of the key questions as they relate to the topic area. The synergistic impact of multiple or sequential interventions is not considered with this methodology.

The evidence tables provide detailed information consistent with ODS-OMAR criteria about the study design, patient characteristics, inclusion and exclusion criteria, interventions evaluated, and the outcomes. The study sample size offers a measure of the weight of the evidence. (In general, larger studies provide a more precise estimate of the effect in question, although patient population governs more the applicability of any given study.) Again, we graded the quality of the studies according to the Jadad scale; this is also presented in the evidence tables. The evidence tables are condensed into in-text summary tables to provide a concise overview of study results. Summarizing the data in such a way allows for ease of comparison among studies.

## Review of Articles Relevant to the Scope of “End of Life”

Starting with the articles that the core literature review had identified as related to background and prognosis, and supplemented by articles pointed out by experts and other reviewers, three reviewers examined the titles and abstracts for this preliminary task of defining the scope of “end of life” care. They then categorized the articles into potentially useful categories and implicitly reviewed them for research quality. Then, the team categorized the articles and qualitatively described the implications for defining the “end of life” as a target for care. This work was essential to our overall effort but lies outside the scope of the RFTO and we have summarized it completely in Appendix A. Because this issue as a whole is also relevant to how we understood the literature, some of the insights from this preliminary task are discussed in Chapter 4.

### Peer Review Process

We identified potential peer reviewers through project staff, the TEP and AHRQ. Based on these inquiries we contacted 12 individuals with wide expertise in the field and with deep knowledge of the literature, 9 of whom provided recommendations in addition to our TEP members. We selected reviewers because of their international stature, knowledge of both the North American and European literature, and research experience. The list of peer reviewers and their affiliations can be found in Appendix F.

A copy of the draft evidence report was mailed to each peer reviewer and TEP member. All reviewers were asked to respond with their comments. We compiled the peer reviewer comments and made appropriate changes to the draft report, based on these comments. The reviewer comments and the EPC's responses are provided in Appendix K.