# Introduction

## Background and Context

Only a century ago, death was common at every age and dying usually quickly followed the onset of disease or injury. Now, public health measures and health care prevent or cure many previously fatal illnesses or injuries, allowing most Americans to live into old age. Medications and treatments now often allow prolonged survival with serious chronic conditions. More than 75% of Americans now live past age 65, ^1^ and 83% of Americans now die while covered by Medicare. ^1^ In 2000, the average life expectancy was 80 years for women and 74 years for men, compared to just 49 years in 1900. ^2^ By 2050, life expectancy for women and men will likely increase to 84 and 80, respectively. ^3^

Rather than a brief, well-defined period, the “end of life” today refers to a prolonged, uncertain period of difficulty because many Americans today live their last years with a advanced, chronic illness. In fact, such conditions affect 15% of the adult U.S. population. ^4,^ ^5^ Of these, one-twelfth have severe cognitive impairments, ^6^ almost one-third have difficulty walking, ^7^ and one-fifth have impaired vision. ^8^ With advancing age, the likelihood of disability increases dramatically. ^9^ After age 85, only one person in twenty reports being fully mobile. ^10^ Age and disability are strongly associated with further declines in functioning, recurrent hospitalization, institutionalization, and death, even after accounting for other risk factors. ^11,^ ^12^

An important group of chronic conditions consists of those that typically worsen and eventually cause death (e.g., cancer; chronic heart, lung, liver, or renal disease; dementia; and stroke). Nine-tenths of the elderly insured by Medicare live with one or more of these conditions in the year before death. ^1^ Most Americans will have a substantial period of serious illness before dying, with onset months or years before death. Already, half of Americans who live to be 85 years have major memory loss in their final years. ^13^ By 2030, persons over 80 years of age will increase from approximately 3% to over 5% of the population, numbering 19 million. ^14^ Trends in the rates of late-life disability are uncertain, ^15^ but the growing size of the aging population suggests that many Americans will face chronic illness and impairment when the baby boomers grow old.

Over the past several decades, analyses underscored the cost of caring for chronic illness during the last years of life. For example, more than one-third of lifetime expenditures are still ahead of a person who is alive at age 85, and more than half are still ahead of a person at age 65. ^16^ Reports have consistently and repeatedly demonstrated that the last year of life consumes about 30% of lifetime Medicare expenditures. ^1,^ ^17–19^ The length of time a person lives is relatively unimportant in predicting total costs, and lifetime medical expenditures are similar for those who start retirement healthier and those who start more disabled, because even healthier persons eventually reach the disabled state at the end of life, and that period of time is very costly. ^20^

## Framework for the Systematic Review

For persons living with advanced, chronic disease, neither prevention nor cure is ordinarily possible. Rather than a simple, straightforward aim like survival, which makes sense as a priority for most of life, people who are living with advanced and eventually fatal illness have complicated priorities like living well as long as possible but not suffering unduly, and being close to and cared for by family but also not being a weighty burden on them. In this phase of life, care must serve multiple and complex goals and is affected by patient, caregiver, and healthcare system factors. A comprehensive description of the experience of patients living with advanced illness and their caregivers requires consideration of a range of conceptually overlapping measures including satisfaction, quality of care, quality of dying, and quality of life. ^21,^ ^22^

Both expert opinion and research on the end-of-life experiences of patients, caregivers, and providers inform a description of the major domains for evaluating the end-of-life experience. These core considerations arise from the experience of both patients and caregivers and include ^23–31^

- pain and other symptom prevention and treatment
- adequate support for families and caregivers including bereavement
- continuity of health care
- treatment consistent with patient and family preferences and medical knowledge
- effective, empathic communication about diagnoses, prognosis, and care plans
- well-being, including addressing existential and spiritual concerns
- function and self-determination
- length of survival.

For this report, we addressed several categories among these outcomes that are relevant to particular aspects of the patient's and family's experience, and healthcare system concerns. To examine the patient's experience, we focused upon symptoms, particularly pain, dyspnea, depression and anxiety, and behavioral issues in dementia. To examine the family's experience, we focused on caregiving (excluding bereavement). To examine on the healthcare system's performance, we focused on continuity of care. The joint endeavor of decision-making and providing care consistent with preferences focused on advance care planning.

### Pain, Dyspnea, Depression and Anxiety, and Behavioral Symptoms in Dementia

When a person is living with advanced illness and coming to the end of life, effective prevention and relief of symptoms becomes a high priority. Symptoms are subjective indicators of distress and the primary reason patients seek care, and they remain important in and of themselves even when the underlying causes of illness are increasingly difficult to modify.

Effective pain management is a palliative focus for many conditions, and pain is among the most debilitating and feared symptoms that patients and families face. Studies demonstrate a pain prevalence of 70–100% among cancer patients, ^32–34^ and an Institute of Medicine conference recently named pain in advanced cancer as one of five high-leverage targets for national reform. ^35^ Undertreatment and inequitable access to pain treatment have been described among many cancer patients presenting with pain. ^36,^ ^37^ Pain is also prevalent among patients with advanced health conditions other than cancer ^38–40^ underscoring the importance of evaluating the scientific evidence relevant to pain in both cancer and non-cancer conditions.

Dyspnea, or shortness of breath, is an especially troublesome symptom that is characteristic of conditions including advanced chronic obstructive lung disease (COPD) and congestive heart failure (CHF). ^38,^ ^40,^ ^41^ The Institute of Medicine also named improving palliative care for CHF and COPD as one of five national priority areas for quality improvement. ^35^ Understanding and treating dyspnea better would represent important progress in these priority conditions. ^1^ Dyspnea is also an important symptom in cancer—in primary malignancies (e.g., lung), metastatic disease (e.g., metastasis to the lung), and as a consequence of treatment or progressive disease (e.g., associated with anemia).

Depression has increasingly come to attention as a cause of suffering in advancing illness. ^42^ Similarly, the suffering that anxiety causes might well be mitigated with better care arrangements and medications. ^43^ These and other behavioral symptoms such as wandering are especially important as manifestations of dementia. ^44^ Such symptoms create difficulties for caregivers of demented patients, including nursing homes where Americans increasingly reside during their final years. ^45^ Certain approaches to these symptoms (e.g., restraints) can be particularly harmful, and disseminating effective alternatives could improve palliative care in nursing homes and other settings for these patients.

### Caregiver Experience

Families and other informal caregivers are essential in meeting an individual's physical and psychosocial needs and in accomplishing treatment goals. Caregivers provide substantial amounts of assistance with daily living tasks, watching over symptoms and general health, monitoring and administering medications, and coordinating care among health and social service providers, as well as through emotional support. This is particularly true when patients live with prolonged illness such as dementia, which has a median life expectancy of 3.5 years according to a large, recent prospective cohort study. ^46^ Caregiver responsibilities do not end with admission to a nursing home because caregivers continue to provide significant personal support even in the nursing home. ^47–49^

Families and other caregivers face emotional, physical, and economic consequences as a result and may lack reliable support for their responsibilities. ^39,^ ^50,^ ^51^ Emanuel surveyed nearly 1000 caregivers and found that 35% reported substantial care needs that consumed time, money, and affected employment and borrowing, and that financial and nonfinancial caregiving burdens were related to depression as well as thoughts about physician-assisted suicide and euthanasia. ^52^ Almost half of personal bankruptcy is associated with medical illness, ^53^ and adverse financial circumstances may affect family decision-making. ^54^ Caregiver stresses do not diminish even after institutional placement. ^49^

### Continuity of Care

Continuity is an important goal that is mostly the responsibility of healthcare providers to foster. When a patient has complex illness, care is often characterized by multiple providers and settings, and continuity is important and elusive. A recent review identified irreducible elements of continuity including a focus on the individual patient and a concern with care delivery over time. ^55^ Aspects of continuity include a patient's having an ongoing relationship with specific providers, standardizing approaches to care so that services are delivered in an integrated, consistent fashion, and ensuring that information about the disease process or the preferences and values of the individual follow the patient into every setting of care. ^30,^ ^55^

Evidence suggests that discontinuity is a significant but addressable problem at the end of life. Discontinuity has been demonstrated in communicating treatment preferences, and in events related to late transfers among settings of care. ^56–58^ Hospice might be effective in promoting continuity—family members of hospice patients are less likely to report that providers do not know enough about a family member's clinical situation to provide the best care. ^59^ Important aspects of care related to continuity include record keeping, various settings of care, and effective planning for the acute problems and symptoms patients face when they are near the end of life.

### Advance Care Planning

Advance care planning (ACP) depends upon forecasting the challenges that the patient and family will face due to illness, medical treatment, and other concerns. When an important decision can be anticipated, the decision-making process is usually envisioned as including a prediction of the situation, awareness of alternative care plans, elicitation of preferences, and a final melding of preferences and alternatives into a coherent plan. Closely related issues include the need to make advance care plans available when patients need them and across settings, implementing advance care plans, and understanding their overall effects.

The early emphasis of advance care planning was on legal initiatives, although the concept has been broadened to emphasize the need to plan ahead and shape the course of care. ^60^ The 1990 Patient Self-Determination Act (PSDA) required states to articulate their statutory provisions and healthcare providers to inform patients of their rights and record any advance directives (ADs). The legalistic origins of ADs emphasized protecting patients' rights by granting them enforceable authority to make their own decisions. A broader construction of ACP recognizes that concerned parties are allied to discern what course best serves the patient and to ensure specific steps to make that course more likely. In addition to ADs, this requires practical arrangements (e.g., having the right medications in place). A number of authors have suggested that ACP should be targeted based on age, medical conditions, the patient's health status, social circumstances, and beliefs. ^60,^ ^61^

## Summary

Given these significant concerns, the present offers an opportune time to conduct a systematic review to inform the research agenda for palliative care. Research to target gaps in knowledge will facilitate the quality, effectiveness, and affordability of care as well as access to care for patients and caregivers living with advanced illness. Thus, in order to evaluate progress and to propose research priorities the National Institute for Nursing Research, with the Agency for Healthcare Research and Quality, commissioned this Evidence Report as the basis for a State of the Science Conference in December 2004.