# Appendix I. Bibliography of Excluded Abstracts

“Do not attempt resuscitation” directives in the out-of-hospital setting. American College of Emergency Physicians. Ann Emerg Med 96;27(5):684. [Rec#: 40006] Exclude at abstract screening: Title Only
A statement of assumptions and principles concerning psychological care of dying persons and their families. Psychological Work Group of the International Work Group on Death, Dying, and Bereavement. J Palliat Care 93;9(3):29–32. [Rec#: 15492] Exclude at abstract screening: Title Only
Aapro M S. Oral etoposide and palliative treatment for small-cell lung cancer. Lancet 96;348(9027):559. Comment on: Lancet. Aug 31. 1996;348(9027):563-6. PMID: 8774567. [Rec#: 30002] Exclude at abstract screening: Title Only.
Abang A M. Chemotherapy versus best supportive care for advanced non-small-cell lung cancer. Am J Health Syst Pharm. 96;53(24):2980-4. [Rec#: 9007] Exclude at abstract screening: Title Only. [pmid: 8974162].
Abbott K, Sago J G, Breen C M, Abernethy A P, Tulsky J A. Families looking back: one year after discussion of withdrawal or withholding of life-sustaining support. Critical Care Medicine. 2001;29(1):197-201. [Rec#: 50165] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11176185].
Abdulkader R C, Zanetta D M, Oliveira G M, Burdmann E A. Risk factors for hospital death of patients with end-stage renal disease without previous diagnosis of severe chronic renal failure arriving in an emergency situation at the hospital. Ren Fail. 2003;25(4):631-8. [Rec#: 40038] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 12911168].
Abel J. Complementary therapy programme at St Luke's Hospice, Plymouth. Complementary Therapies in Nursing & Midwifery. 2000;6(3):116-9. [Rec#: 50166] Exclude at abstract screening: Title Only. [pmid: 11858467].
Abrahm J L, Hansen-Flaschen J. Hospice care for patients with advanced lung disease. Chest 2002;121(1):220–9. Comment in: Chest. Jan. 2002;121(1):11-2. PMID: 11796425. [Rec#: 9027] Exclude at abstract screening: no outcomes specified.
Abrahm J L, Snyder L. Pain assessment and management. Prim Care. 2001;28(2):269-97. [Rec#: 9028] Exclude at abstract screening: useful only for background. [pmid: 11406435].
Abrahm J L, Cooley M, Ricacho L. Efficacy of an educational bereavement program for families of veterans with cancer. J Cancer Educ. 95;10(4):207-12. [Rec#: 9026] Exclude at abstract screening: Study Design - Unclear.
Ackermann R J. Withholding and withdrawing life-sustaining treatment. Am Fam Physician 2000;62(7):1555–60, 1562, 1564. Comment in: Am Fam Physician. Jan 1. 2001;63(1):42-44. PMID: 11195771. [Rec#: 9039] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Acres J C. Home mechanical ventilation for end-stage chronic obstructive pulmonary disease (for all)?. Canadian Respiratory Journal. 2000;7(2):122. [Rec#: 50167] Exclude at abstract screening: Title Only. [pmid: 10859398].
Acton G J, Kang J. Interventions to reduce the burden of caregiving for an adult with dementia: a meta-analysis. Res Nurs Health. 2001;24(5):349-60. [Rec#: 50111] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 11746065].
Acton G J, Winter M A. Interventions for family members caring for an elder with dementia. Annu Rev Nurs Res. 2002;20:149-79. [Rec#: 50112] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 12092509].
Addington-Hall J, McPherson C. After-death interviews with surrogates/bereaved family members: some issues of validity. J Pain Symptom Manage. 2001;22(3):784-90. [Rec#: 9058] Exclude at abstract screening: Non-systematic review. [pmid: 11532591].
Addington-Hall J M, MacDonald L D, Anderson H R. Can the Spitzer Quality of Life Index help to reduce prognostic uncertainty in terminal care?. Br J Cancer. 90;62(4):695-9. [Rec#: 51] Exclude at abstract screening: primarily prognosis or trajectories.
Adelbratt S, Strang P. Death anxiety in brain tumour patients and their spouses. Palliat Med. 2000;14(6):499-507. [Rec#: 54] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11219880].
Adelstein W, Burton S. Palliative care in the acute hospital setting. J Neurosci Nurs. 98;30(3):200-4. [Rec#: 55] Exclude at abstract screening: no outcomes specified. [pmid: 9689612].
Adolfsson J. Health-related quality-of-life assessments in patients with advanced cancer of the prostate. Pharmacoeconomics. 2003;21(4):241-7. [Rec#: 9070] Exclude at abstract screening: no outcomes specified. [pmid: 12600219].
Adriaansen M J, van Achterberg T. A test instrument for palliative care. Int J Nurs Stud. 2004;41(1):107-17. [Rec#: 9072] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14670400].
Advocate's disease management program reduces readmissions for CHF and asthma. Perform Improv Advis 2003;7(3):44–7. [Rec#: 50000] In abstract review process
Afzal A, Ananthasubramaniam K, Sharma N, al-Malki Q, Ali A S, Jacobsen G, Jafri S M. Racial differences in patients with heart failure. Clin Cardiol. 99;22(12):791-4. [Rec#: 50001] Exclude at abstract screening: not about end of life. [pmid: 10626081].
Agarwal, R. and Shaw, P. Pleurodesis for malignant effusions. Cochrane Database of Systematic Reviews 2003;3. [Rec#: 50170] Exclude at abstract screening: Title Only
Agra Y, Badia X. Spanish version of the Rotterdam Symptom Check List: cross-cultural adaptation and preliminary validity in a sample of terminal cancer patients. Psychooncology. 98;7(3):229-39. [Rec#: 66] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Agra Y, Sacristan A, Gonzalez M, Ferrari M, Portugues A, Calvo M J. Efficacy of senna versus lactulose in terminal cancer patients treated with opioids. J Pain Symptom Manage. 98;15(1):1-7. [Rec#: 67] Exclude at abstract screening: Other symptoms only.
Agraharkar M, Barclay C, Agraharkar A. Staff-assisted home hemodialysis in debilitated or terminally ill patients. Int Urol Nephrol. 2002;33(1):139-44. [Rec#: 68] Exclude at abstract screening: Observational study. [pmid: 12090321].
Agrawal M, Danis M. End-of-life care for terminally ill participants in clinical research. J Palliat Med 2002;5(5):729–37. Comment in: J Palliat Med. Oct. 2002;5(5):661-5. PMID: 12572963. [Rec#: 9077] Exclude at abstract screening: useful only for background.
Ahmed, N., Ahmedzai, S., Vora, V., Hillam, S., and Paz, S. Supportive care for patients with gastrointestinal cancer. Cochrane Database of Systemic Reviews 2003;3. [Rec#: 50171] Exclude at abstract screening: Title Only
Ahmedzai S. Measuring quality of life in hospice care. Oncology (Huntingt) 90;4(5):115–9; discussion 129. [Rec#: 9083] Exclude at abstract screening: no outcomes specified
Ajemian I. Palliative management of dyspnea. Journal of Palliative Care. 91;7(3):44-5. [Rec#: 50172] Exclude at abstract screening: Study Design - Unclear. [pmid: 1719173].
Akosah K O, Schaper A M, Havlik P, Barnhart S, Devine S. Improving care for patients with chronic heart failure in the community: the importance of a disease management program. Chest 2002;122(3):906–12. Comment in: Chest. May. 2003;123(5):1770. author reply 1770–1. PMID: 12740302. [Rec#: 50002] Exclude at abstract screening: not about end of life.
Albert N M, Davis M, Young J. Improving the care of patients dying of heart failure. Cleve Clin J Med. 2002;69(4):321-8. [Rec#: 9097] Exclude at abstract screening: no outcomes specified. [pmid: 11996202].
Albert S M, Costa R, Merchant C, Small S, Jenders R A, Stern Y. Hospitalization and Alzheimer's disease: results from a community-based study. J Gerontol A Biol Sci Med Sci. 99;54(5):M267-71. [Rec#: 101] Exclude at abstract screening: not about end of life.
Albert S M, Murphy P L, Del Bene M, Rowland L P, Mitsumoto H. Incidence and predictors of PEG placement in ALS/MND. J Neurol Sci. 2001;191(12):115-9. [Rec#: 102] Exclude at abstract screening: not about end of life. [pmid: 11677001].
Albinsson L, Strang P. A palliative approach to existential issues and death in end-stage dementia care. J Palliat Care. 2002;18(3):168-74. [Rec#: 108] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12418367].
Albinsson L, Strang P. Differences in supporting families of dementia patients and cancer patients: a palliative perspective. Palliat Med. 2003;17(4):359-67. [Rec#: 9099] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12822853].
Albinsson L, Strang P. Existential concerns of families of late-stage dementia patients: questions of freedom, choices, isolation, death, and meaning. J Palliat Med. 2003;6(2):225-35. [Rec#: 107] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12854939].
Aldred M J, Addy M, Bagg J, Finlay I. Oral health in the terminally ill: a cross-sectional pilot survey. Spec Care Dentist. 91;11(2):59-62. [Rec#: 9103] Exclude at abstract screening: Study Design - Unclear.
Algozino B. Palliative management of dehydration in patients receiving hospice care at home. Oncol Nurs Forum. 96;23(1):119. [Rec#: 9114] Exclude at abstract screening: no outcomes specified. [pmid: 8628707].
Allard P, Maunsell E, Labbe J, Dorval M. Educational interventions to improve cancer pain control: a systematic review. J Palliat Med. 2001;4(2):191-203. [Rec#: 50113] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 11441627].
Allen R S, Shuster J L Jr. The role of proxies in treatment decisions: evaluating functional capacity to consent to end-of-life treatments within a family context. Behav Sci Law. 2002;20(3):235-52. [Rec#: 9123] Exclude at abstract screening: no outcomes specified. [pmid: 12111986].
Alter C L. Palliative and supportive care of patients with pancreatic cancer. Semin Oncol. 96;23(2):229-40. [Rec#: 9131] Exclude at abstract screening: useful only for background. [pmid: 8623059].
Ambuel B. Conducting a family conference. Principles and Practices of Supportive Oncology Updates. 99;3(3):1-12. [Rec#: 50175] Exclude at abstract screening: Title Only.
American Association of Colleges of Nursing. Peaceful Death: Recommended Competencies and Curricular Guidelines for End-of-Life Nursing Care. 2002;<25 Page(s)>. [Rec#: 50176] Exclude at abstract screening: Title Only
American Association of Critical-Care Nurses. Designing an Agenda for Nursing Profession on End-of-Life Care. Report of the Nursing Leadership Consortium on End-of-Life Care. 1999;<25 Page(s)>. [Rec#: 50177] Exclude at abstract screening: Title Only
American Board of Internal Medicine Committee on Evaluation of Clinical Competence. Caring for the Dying: Identification and Promotion of Physician Competency. 1998;<25 Page(s)>. [Rec#: 50178] Exclude at abstract screening: Title Only
American College of Physicians--American Society of Internal Medicine End-of-Life Care Consensus Panel. Ethics manual. Fourth edition. Annals of Internal Medicine. 98;128(7):576-94. [Rec#: 50179] Exclude at abstract screening: Title Only.
American College of Surgeons. Statement on principles guiding care at the end of life. Journal of the American College of Surgeons. 2002;194(5):664. [Rec#: 50180] Exclude at abstract screening: Title Only. [pmid: 12022608].
American Geriatric Society Panel on Persistent Pain in Older Persons. The management of persistent pain in older persons. Journal of the American Geriatrics Society. 2002;50(6 Suppl):S205-24. [Rec#: 50181] Exclude at abstract screening: Title Only. [pmid: 12067390].
American Geriatrics Society Ethics Committee. The care of dying patients: a position statement from the American Geriatrics Society. Journal of the American Geriatrics Society. 94;43(5):577-578. [Rec#: 50182] Exclude at abstract screening: Title Only.
American Medical Association CoEaJA. Elements of Quality Care for Patients in the Last Phase of Life. 2003;<25 Page(s)>. [Rec#: 50183] Exclude at abstract screening: Title Only
American Medical Directors Association. White Paper on Hospice in Long-term Care. 2000;<25 Page(s)>. [Rec#: 50184] Exclude at abstract screening: Title Only
American Society of Clinical Oncology End of Life Task Force. Cancer care during the last phase of life. Journal of Clinical Oncology. 98;16:1986-1996. [Rec#: 50186] Exclude at abstract screening: Title Only.
American Thoracic Society. Dyspna mechanisms, assessment, and management: a consensus statement. American Journal of Respiratory & Critical Care Medicine. 99;159:321-340. [Rec#: 50187] Exclude at abstract screening: Title Only.
Anandarajah G, Hight E. Spirituality and medical practice: using the HOPE questions as a practical tool for spiritual assessment. Am Fam Physician 2001;63(1):81–9. Comment in: Am Fam Physician. 2001 Aug 1;64(3):373–4; author reply 380, 383–4, 386. PMID: 11515827. Comment in: Am Fam Physician. Aug 1. 2001;64(3):376-379. author reply 380, 383–4, 386. PMID: 11515829. [Rec#: 9149] Exclude at abstract screening: no outcomes specified.
Andersen B L. Psychological interventions for cancer patients to enhance the quality of life. J Consult Clin Psychol. 92;60(4):552-68. [Rec#: 9151] Exclude at abstract screening: no outcomes specified.
Andersen B L. Quality of life for women with gynecologic cancer. Curr Opin Obstet Gynecol. 95;7(1):69-76. [Rec#: 9152] Exclude at abstract screening: no outcomes specified. [pmid: 7742520].
Andershed B, Ternestedt B M. Development of a theoretical framework describing relatives' involvement in palliative care. J Adv Nurs. 2001;34(4):554-62. [Rec#: 9155] Exclude at abstract screening: no outcomes specified. [pmid: 11380724].
Andershed B, Ternestedt B M. Involvement of relatives in care of the dying in different care cultures: development of a theoretical understanding. Nurs Sci Q. 99;12(1):45-51. [Rec#: 175] Exclude at abstract screening: Study Design - Qualitative.
Andershed B, Ternestedt B M. Involvement of relatives in the care of the dying in different care cultures: involvement in the dark or in the light?. Cancer Nurs. 98;21(2):106-16. [Rec#: 176] Exclude at abstract screening: Study Design - Qualitative.
Andershed B, Ternestedt B M. Patterns of care for patients with cancer before and after the establishment of a hospice ward. Scand J Caring Sci. 97;11(1):42-50. [Rec#: 177] Exclude at abstract screening: Other topic only. [pmid: 9275821].
Anderson B. Quality of life in progressive ovarian cancer. Gynecol Oncol. 94;55(3 Pt 2):S151-5. [Rec#: 9157] Exclude at abstract screening: no outcomes specified. [pmid: 7530679].
Anderson B J. Withdrawing life-sustaining treatment from minimally conscious patients: who decides?. J Med Pract Manage. 2002;18(2):101-3. [Rec#: 40095] Exclude at abstract screening: Title Only. [pmid: 12389332].
Anderson F, Downing G M, Hill J, Casorso L, Lerch N. Palliative performance scale (PPS): a new tool. J Palliat Care. 96;12(1):5-11. [Rec#: 9162] Exclude at abstract screening: Study Design - Unclear. [pmid: 8857241].
Anderson H. Spiritual care: the power of an adjective. Journal of Pastoral Care. 2001;55(3):233-7. [Rec#: 50188] Exclude at abstract screening: Title Only. [pmid: 11565474].
Anderson H, Card C, Eardley A, Gomm S A, Connolly M, Coppinger T, Corgie D, Williams J L, Makin W P. The concerns of patients under palliative care and a heart failure clinic are not being met. Palliative Medicine. 2001;15:279-286. [Rec#: 50189] Exclude at abstract screening: Duplicate already in the flow. [pmid: 12054145].
Andresen J. Cultural competence and health care: Japanese, Korean, and Indian patients in the United States. J Cult Divers. 2001;8(4):109-21. [Rec#: 9169] Exclude at abstract screening: not about end of life. [pmid: 11908075].
Andrewes T. The management of breathlessness in palliative care. Nurs Stand 2002;17(5):43–52; quiz 54–5. [Rec#: 194] Exclude at abstract screening: useful only for background
Annas G J. Informed consent, cancer, and truth in prognosis. N Engl J Med 94;330(3):223–5. Comment in: N Engl J Med. 1994 Sep 22;331(12):810; author reply 811–2. PMID: 8065418. Comment in: N Engl J Med. 1994 Sep 22;331(12):811. PMID: 8065419. Comment in: N Engl J Med. Sep 22. 1994;331(12):811. PMID: 8065420. Comment in: N Engl J Med. 1994. [Rec#: 203] Exclude at abstract screening: Title Only.
Appleton M. Hospice and skilled nursing facilities. Am J Hosp Palliat Care 96;13(3):11–2. Comment in: Am J Hosp Palliat Care. Nov-Dec. 1996;13(6):3. PMID: 8945092. [Rec#: 9191] Exclude at abstract screening: Title Only.
Approaching death: improving care at the end of life--a report of the Institute of Medicine. Health Serv Res 98;33(1):1–3. [Rec#: 9193] Exclude at abstract screening: Title Only
Aranda S, Peerson A. Caregiving in advanced cancer: lay decision making. J Palliat Care. 2001;17(4):270-6. [Rec#: 220] Exclude at abstract screening: Title Only. [pmid: 11813346].
Aranda S, Hayman-White K, Devilee L, O'Connor M, Bence G. Inpatient hospice triage of ‘after-hours’ calls to a community palliative care service. Int J Palliat Nurs. 2001;7(5):214-20. [Rec#: 9195] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12148971].
Aranda S K, Kelso J. The nurse as coach in care of the dying. Contemp Nurse. 97;6(34):117-22. [Rec#: 222] Exclude at abstract screening: no outcomes specified. [pmid: 9511653].
Arbour R. Sedation and pain management in critically ill adults. Crit Care Nurse 2000;20(5):39–56; quiz 57–8. Comment in: Crit Care Nurse. Jun. 2001;21(3):19-20. PMID: 11858672. [Rec#: 40123] Exclude at abstract screening: Title Only.
Archer K C, Boyle D P. Toward a measure of caregiver satisfaction with hospice social services. Hosp J. 99;14(2):1-15. [Rec#: 226] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Archibald G. The needs of South Asians with a terminal illness. Prof Nurse. 2000;15(5):316-9. [Rec#: 9207] Exclude at abstract screening: no outcomes specified. [pmid: 10986956].
Arenson C A, Novielli K D, Chambers C V, Perkel R L. The importance of advance directives in primary care. Prim Care. 96;23(1):67-82. [Rec#: 9211] Exclude at abstract screening: no outcomes specified. [pmid: 8900507].
Argent J, Faulkner A, Jones A, O'Keeffe C. Communication skills in palliative care: development and modification of a rating scale. Medical Education. 94;28(6):559-65. [Rec#: 50190] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Aristides M, Shiell A. The effects on hospital use and costs of a domiciliary palliative care nursing service. Aust Health Rev. 93;16(4):405-13. [Rec#: 230] Exclude at abstract screening: Study Design - Unclear.
Armes P J, Addington-Hall J M. Perspectives on symptom control in patients receiving community palliative care. Palliat Med. 2003;17(7):608-15. [Rec#: 9214] Exclude at abstract screening: Study Design - Qualitative. [pmid: 14594152].
Armstrong J and Holland J. Surviving the stresses of clinical oncology by improving communication. Oncology (Huntingt) 2004;18(3): 363–8; discussion 373–5. [Rec#: 232] Exclude at abstract screening: outcome unrelated to pts/family/non-prof
Armstrong J. Advances in radiation technology can improve survival and quality of life for cancer patients. Ir J Med Sci. 2001;170(1):63-8. [Rec#: 30198] Exclude at abstract screening: Title Only. [pmid: 11440417].
Arnaud J P, Schloegel M, Ollier J C, Adloff M. Colorectal cancer in patients over 80 years of age. Dis Colon Rectum. 91;34(10):896-8. [Rec#: 233] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Arnold J. Rethinking grief: nursing implications for health promotion. Home Healthc Nurse 96;14(10):777–83; quiz 784–5. [Rec#: 235] Exclude at abstract screening: no outcomes specified
Asai A, Fukuhara S, Lo B. Attitudes of Japanese and Japanese-American physicians towards life-sustaining treatment. Lancet 95;346(8971):356–9. Comment in: Lancet. 1995 Aug 5;346(8971):327–8. PMID: 7623528. Comment in: Lancet. 1995 Oct 7;346(8980):970–1. PMID: 7564756. Comment in: Lancet. Oct 7. 1995;346(8980):971. PMID: 7564757. [Rec#: 239] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Asch D A, Hansen-Flaschen J, Lanken P N. Decisions to limit or continue life-sustaining treatment by critical care physicians in the United States: conflicts between physicians' practices and patients' wishes. American Journal of Respiratory & Critical Care Medicine. 95;151(2 Pt 1):288-92. [Rec#: 50191] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Ashby L, Shepherd B. The nurse's role in the withdrawal of medical treatment. Adv Clin Care. 90;5(5):35-6. [Rec#: 9245] Exclude at abstract screening: no outcomes specified. [pmid: 2393503].
Ashby M, Jackson K. Opioids in palliative care: emerging clinical trends. Intern Med J. 2003;33(7):265-6. [Rec#: 9246] Exclude at abstract screening: no outcomes specified. [pmid: 12823669].
Ashby M, Wakefield M. Attitudes to some aspects of death and dying, living wills and substituted health care decision-making in South Australia: public opinion survey for a parliamentary select committee. Palliat Med. 93;7(4):273-82. [Rec#: 247] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Ashby M A, Kissane D W, Beadle G F, Rodger A. Psychosocial support, treatment of metastatic disease and palliative care Med J Aust 96;164(1):43–9. Comment in: Med J Aust. Jun 17. 1996;164(12):759-60. PMID: 8668095. [Rec#: 9248] Exclude at abstract screening: no outcomes specified.
Ashby M E, Dowding C. Hospice care and patients' pain: communication between patients, relatives, nurses and doctors. Int J Palliat Nurs. 2001;7(2):58-67. [Rec#: 9249] Exclude at abstract screening: Study Design - Unclear. [pmid: 12271251].
Aspinal F, Addington-Hall J, Hughes R, Higginson I J. Using satisfaction to measure the quality of palliative care: a review of the literature. J Adv Nurs 2003;42(4):324–39. Comment in: J Adv Nurs. 2003 Sep;43(5):531–2. PMID: 12919271. Comment in: J Adv Nurs. 2003 Sep;43(5):532–3. PMID: 12919272. Comment in: J Adv Nurs. Sep. 2003;43(5):533-4. PMID: 12919273. [Rec#: 9252] Exclude at abstract screening: Study Design - Review/Meta.
Astin J A, Shapiro S L, Eisenberg D M, Forys K L. Mind-body medicine: state of the science, implications for practice. J Am Board Fam Pract. 2003;16(2):131-47. [Rec#: 50114] Exclude at abstract screening: not about end of life. [pmid: 12665179].
Astrow A B, Puchalski C M, Sulmasy D P. Religion, spirituality, and health care: social, ethical, and practical considerations. American Journal of Medicine. 2001;110(4):283-7. [Rec#: 50192] Exclude at abstract screening: no outcomes specified. [pmid: 11247596].
Astudillo W, Mendinueta C, Astudillo E, Munoz A, Horcajada J P. How can relations be improved between the family and the support team during the care of terminally ill patients?. Support Care Cancer. 95;3(1):72-7. [Rec#: 9256] Exclude at abstract screening: no outcomes specified.
Aszalos R, Richardson J P. Hydration and alimentation in terminal patients: a hospice approach. Md Med J. 95;44(3):221-2. [Rec#: 9257] Exclude at abstract screening: Title Only. [pmid: 7535879].
Athlin E, Furaker C, Jansson L, Norberg A. Application of primary nursing within a team setting in the hospice care of cancer patients. Cancer Nurs. 93;16(5):388-97. [Rec#: 256] Exclude at abstract screening: Observational study.
Atkinson K. Informing older patients of a terminal illness. Prof Nurse. 2000;15(5):343-6. [Rec#: 258] Exclude at abstract screening: no outcomes specified. [pmid: 10986961].
Auchter R M, Scholtens D, Adak S, Wagner H, Cella D F, Mehta M P. Quality of life assessment in advanced non-small-cell lung cancer patients undergoing an accelerated radiotherapy regimen: report of ECOG study 4593. Eastern Cooperative Oncology Group. Int J Radiat Oncol Biol Phys. 2001;50(5):1199-206. [Rec#: 30248] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 11483329].
Auret K, Bulsara C, Joske D. Australasian haematologist referral patterns to palliative care: lack of consensus on when and why. Intern Med J. 2003;33(12):566-71. [Rec#: 263] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14656229].
Aus G, Hugosson J, Norlen L. Long-term survival and mortality in prostate cancer treated with noncurative intent. J Urol 95;154(2 Pt 1):460–5. Comment in: J Urol. 1996 Jan;155(1):296–8. PMID: 7490872 Comment in: J Urol. 1996 Jun;155(6):2039; author reply 2039–41. PMID: 8618328. Comment in: J Urol. Jun. 1996;155(6):2039. author reply 2039–41. PMID: 8618329. [Rec#: 266] Exclude at abstract screening: Title Only.
Aus G, Hugosson J, Norlen L. Need for hospital care and palliative treatment for prostate cancer treated with noncurative intent. J Urol. 95;154(2 Pt 1):466-9. [Rec#: 267] Exclude at abstract screening: Title Only. [pmid: 7541865].
Ausband S C, March J A, Brown L H. National prevalence of palliative care protocols in emergency medical services. Prehosp Emerg Care. 2002;6(1):36-41. [Rec#: 9266] Exclude at abstract screening: useful only for background. [pmid: 11789648].
Austin B, Melbourne P. Hospices services for the terminal Alzheimer's patient. Caring. 90;9(11):60-2. [Rec#: 268] Exclude at abstract screening: no outcomes specified. [pmid: 10170630].
Austin L, Luker K, Caress A, Hallett C. Palliative care: community nurses' perceptions of quality. Qual Health Care. 2000;9(3):151-8. [Rec#: 9267] Exclude at abstract screening: no outcomes specified. [pmid: 10980075].
Avis M, Jackson J G, Cox K, Miskella C. Evaluation of a project providing community palliative care support to nursing homes. Health Soc Care Community. 99;7(1):32-38. [Rec#: 272] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Axelsson B, Chirstensen S B. Medical care utilization by incurable cancer patients in a Swedish county. Eur J Surg Oncol. 97;23(2):145-50. [Rec#: 276] Exclude at abstract screening: Title Only. [pmid: 9158190].
Axelsson B, Christensen S B. Place of death correlated to sociodemographic factors. A study of 203 patients dying of cancer in a rural Swedish county in 1990. Palliat Med. 96;10(4):329-35. [Rec#: 277] Exclude at abstract screening: Other topic only.
Ayers E, Harrold J, Lynn J. A good death: improving care inch-by-inch. Bioethics Forum. 97;13(1):38-40. [Rec#: 280] Exclude at abstract screening: Title Only. [pmid: 11655071].
Azevedo A, Pimenta J, Dias P, Bettencourt P, Ferreira A, Cerqueira-Gomes M. Effect of a heart failure clinic on survival and hospital readmission in patients discharged from acute hospital care. Eur J Heart Fail. 2002;4(3):353-9. [Rec#: 30268] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 12034162].
Azoulay E, Pochard F. Communication with family members of patients dying in the intensive care unit. Curr Opin Crit Care. 2003;9(6):545-50. [Rec#: 9282] Exclude at abstract screening: Non-systematic review. [pmid: 14639077].
Babar M, ul Haq S M. Self-esteem in a palliative care population. Am J Hosp Palliat Care. 2000;17(5):327-32. [Rec#: 9284] Notes: “EXCLUDE: Location, non-Western”. [pmid: 11886057].
Babayan Z V, McNamara R L, Nagajothi N, Kasper E K, Armenian H K, Powe N R, Baughman K L, Lima J A. Predictors of cause-specific hospital readmission in patients with heart failure. Clin Cardiol. 2003;26(9):411-8. [Rec#: 50003] Exclude at abstract screening: not about end of life. [pmid: 14524597].
Bachmann P, Marti-Massoud C, Blanc-Vincent M P, Desport J C, Colomb V, Dieu L, Kere D, Melchior J C, Nitenberg G, Raynard B, Roux-Bournay P, Schneider S, Senesse P. FNCLCC. Summary version of the Standards, Options and Recommendations for palliative or terminal nutrition in adults with progressive cancer (2001). Br J Cancer. 2003;89(Suppl 1):S107-10. [Rec#: 291] Exclude at abstract screening: Title Only. [pmid: 12915911].
Back A L, Arnold R M, Quill T E. Hope for the best, and prepare for the worst Ann Intern Med 2003;138(5):439–43. Comment in: Ann Intern Med. Nov 4. 2003;139(9):791-2. PMID: 14597469. [Rec#: 292] Exclude at abstract screening: Title Only.
Back A L, Arnold R M, Tulsky J A, Baile W F, Fryer-Edwards K A. Teaching communication skills to medical oncology fellows. Journal of Clinical Oncology. 2003;21(12):2433-6. [Rec#: 50194] Exclude at abstract screening: Title Only. [pmid: 12805343].
Baggs J G, Mick D J. Collaboration: a tool addressing ethical issues for elderly patients near the end of life in intensive care units. J Gerontol Nurs. 2000;26(9):41-7. [Rec#: 299] Exclude at abstract screening: Title Only. [pmid: 11883613].
Baggs J G, Schmitt M H. End-of-life decisions in adult intensive care: current research base 158 and directions for the future. Nurs Outlook. 2000;48(4):158-64. [Rec#: 300] Exclude at abstract screening: Title Only. [pmid: 10953074].
Baggs J G. End-of-life care for older adults in ICUs. Annu Rev Nurs Res. 2002;20:181-229. [Rec#: 298] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 12092510].
Baggs J G, Ryan S A. ICU nurse-physician collaboration & nursing satisfaction. Nursing Economics. 90;8(6):386-92. [Rec#: 50197] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Baggs J G, Schmitt M H. Collaboration between nurses and physicians. Image - the Journal of Nursing Scholarship. 88;20(3):145-9. [Rec#: 50198] Exclude at abstract screening: Title Only. [pmid: 3049311].
Baggs J G, Schmitt M H. Intensive care decisions about level of aggressiveness of care. Research in Nursing & Health. 95;18(4):345-55. [Rec#: 50199] Exclude at abstract screening: not about end of life.
Baggs J G, Schmitt M H. Nurses' and resident physicians' perceptions of the process of collaboration in an MICU. Research in Nursing & Health. 97;20(1):71-80. [Rec#: 50200] Exclude at abstract screening: not about end of life.
Baggs J G. Intensive care unit use and collaboration between nurses and physicians. Heart & Lung: Journal of Acute & Critical Care. 89;18(4):332-8. [Rec#: 50195] Exclude at abstract screening: no outcomes specified.
Baggs J G. Women in the intensive care unit. American Journal of Critical Care. 99;8(4):207-9. [Rec#: 50196] Exclude at abstract screening: Title Only. [pmid: 10392219].
Baggs J G, Schmitt M H, Mushlin A I, Eldredge D H, Oakes D, Hutson A D. Nurse-physician collaboration and satisfaction with the decision-making process in three critical care units. American Journal of Critical Care. 97;6(5):393-9. [Rec#: 50201] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Baggs J G, Schmitt M H, Mushlin A I, Mitchell P H, Eldredge D H, Oakes D, Hutson A D. Association between nurse-physician collaboration and patient outcomes in three intensive care units. Critical Care Medicine. 99;27(9):1991-8. [Rec#: 50202] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Baider L, Russak S M, Perry S, Kash K, Gronert M, Fox B, Holland J, Kaplan-Denour A. The role of religious and spiritual beliefs in coping with malignant melanoma: an Israeli sample. Psycho-Oncology. 99;8(1):27-35. [Rec#: 50203] Notes: “EXCLUDE: Location, non-Western”.
Baile W F, Lenzi R, Parker P A, Buckman R, Cohen L. Oncologists' attitudes toward and practices in giving bad news: an exploratory study. J Clin Oncol. 2002;20(8):2189-96. [Rec#: 9303] Exclude at abstract screening: no outcomes specified. [pmid: 11956281].
Baile W F, Lenzi R, Kudelka A P, Maguire P, Novack D, Goldstein M, Myers E G, Bast R C Jr. Improving physician-patient communication in cancer care: outcome of a workshop for oncologists. Journal of Cancer Education. 97;12(3):166-73. [Rec#: 50204] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Bailey C M, Gilbert J M. Avoiding inappropriate surgery for secondary rectal cancer. Eur J Surg Oncol. 2002;28(3):220-4. [Rec#: 303] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 11944953].
Bain K T, Weschules D J, Knowlton C H, Gallagher R. Toward evidence-based prescribing at end of life: a comparative review of temazepam and zolpidem for the treatment of insomnia. Am J Hosp Palliat Care. 2003;20(5):382-8. [Rec#: 9308] Exclude at abstract screening: Other topic only. [pmid: 14529041].
Baker A, Bowring L, Brignell A, Kafford D. Chronic pain management in cognitively impaired patients: a preliminary research project. Perspectives. 96;20(2):4-8. [Rec#: 315] Exclude at abstract screening: Title Only. [pmid: 8900744].
Baker D W, Einstadter D, Husak S S, Cebul R D. Trends in postdischarge mortality and readmissions: has length of stay declined too far?. Arch Intern Med. 2004;164(5):538-44. [Rec#: 50004] Exclude at abstract screening: Title Only. [pmid: 15006831].
Baker D W, Fitzgerald D, Moore C L. Quality of care for Medicare patients hospitalized with heart failure in rural Georgia. South Med J. 99;92(8):782-9. [Rec#: 30292] Exclude at abstract screening: not about end of life.
Baker M E. Economic, political and ethnic influences on end-of-life decision-making: a decade in review. J Health Soc Policy. 2002;14(3):27-39. [Rec#: 321] Exclude at abstract screening: useful only for background. [pmid: 12086011].
Bakkevold K E, Kambestad B. Palliation of pancreatic cancer. A prospective multicentre study. Eur J Surg Oncol. 95;21(2):176-82. [Rec#: 328] Exclude at abstract screening: Title Only. [pmid: 7536691].
Baldry C, Balmer S. An audit of out-of-hours advice services provided by hospice staff. Int J Palliat Nurs. 2000;6(7):352-6. [Rec#: 9324] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11309907].
Ballantyne J C, Carr D B, Berkey C S, Chalmers T C, Mosteller F. Comparative efficacy of epidural, subarachnoid, and intracerebroventricular opioids in patients with pain due to cancer. Reg Anesth. 96;21(6):542-56. [Rec#: 50115] Exclude at abstract screening: Non-systematic review.
Ballinger A B, McHugh M, Catnach S M, Alstead E M, Clark M L. Symptom relief and quality of life after stenting for malignant bile duct obstruction. Gut. 94;35(4):467-70. [Rec#: 350] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Balsano A E, Cella P M. The changing role of hospice and its fit in an integrated delivery system. Hosp Technol Ser. 96;15(8 Spec No):1-28. [Rec#: 9331] Exclude at abstract screening: Title Only. [pmid: 10159433].
Banaszak-Holl J and Mor V. Differences in patient demographics and expenditures among Medicare hospice providers. Hosp J 96;11(3):1–19. Erratum in: Hosp J 1996;11(4):97. [Rec#: 354] Exclude at abstract screening: useful only for background
Barber M D, Fearon K C, Delmore G, Loprinzi C L. Should cancer patients with incurable disease receive parenteral or enteral nutritional support?. Eur J Cancer. 98;34(3):279-85. [Rec#: 9340] Exclude at abstract screening: no outcomes specified.
Barclay S, Todd C, McCabe J, Hunt T. Primary care group commissioning of services: the differing priorities of general practitioners and district nurses for palliative care services. Br J Gen Pract 99;49(440):181–6. Comment in: Br J Gen Pract. Jul. 1999;49(444):576. PMID: 10621997. [Rec#: 9341] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Barclay S, Wyatt P, Shore S, Finlay I, Grande G, Todd C. Caring for the dying: how well prepared are general practitioners? A questionnaire study in Wales. Palliat Med 2003;17(1):27–39. Comment in: Palliat Med. Oct. 2003;17(7):646-7. PMID: 14594161. [Rec#: 364] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Barker G, Loftus L, Cuddy P, Barker B. The effects of sucralfate suspension and diphenhydramine syrup plus kaolin-pectin on radiotherapy-induced mucositis. Oral Surg Oral Med Oral Pathol. 91;71(3):288-93. [Rec#: 369] Exclude at abstract screening: Other symptoms only.
Barker L. Effective leadership within hospice and specialist palliative care units. J Manag Med. 2000;14(56):291-309. [Rec#: 9342] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11200297].
Barnato A E, McClellan M B, Kagay C R, Garber A M. Trends in inpatient treatment intensity among Medicare beneficiaries at the end of life. Health Serv Res. 2004;39(2):363-75. [Rec#: 374] Exclude at abstract screening: useful only for background. [pmid: 15032959]. [pmcid: 1361012].
Barnes E A, Bruera E. Fatigue in patients with advanced cancer: a review. Int J Gynecol Cancer. 2002;12(5):424-8. [Rec#: 9352] Exclude at abstract screening: no outcomes specified. [pmid: 12366656].
Barnes E A, DeBoer G, Chow E. Symptom control and palliative care content of abstracts presented at the Canadian Association of Radiation Oncologists annual meetings. Support Care Cancer. 2004;12(2):91-4. [Rec#: 375] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14655042].
Barnes E A, Hanson J, Neumann C M, Nekolaichuk C L, Bruera E. Communication between primary care physicians and radiation oncologists regarding patients with cancer treated with palliative radiotherapy. J Clin Oncol. 2000;18(15):2902-7. [Rec#: 376] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10920139].
Barnes R, Barrett C, Weintraub S, Holowacz G, Chan M, LeBlanc E. Hospital response to psychosocial needs of AIDS inpatients. J Palliat Care. 93;9(2):22-8. [Rec#: 377] Exclude at abstract screening: not about end of life.
Barnes E A, Palmer J L, Bruera E. Prevalence of symptom control and palliative care abstracts presented at the Annual Meeting of the American Society for Therapeutic Radiology and Oncology. International Journal of Radiation Oncology, Biology, Physics. 2002;54(1):211-4. [Rec#: 50205] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12182994].
Barr A. Care of a patient with breathing difficulties. Br J Nurs. 92;1(13):660-5. [Rec#: 382] Exclude at abstract screening: not about end of life. [pmid: 1467641].
Barr H, Krasner N. Prospective quality-of-life analysis after palliative photoablation for the treatment of malignant dysphagia. Cancer. 91;68(7):1660-4. [Rec#: 383] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Barreto P, Bayes R, Comas MD, Martinez E, Pascual A, Roca J, Gomez-Batiste X, Garcia-Conde J.Assessment of the perception and worries [corrected] in terminally ill patients in Spain. J Palliat Care 96;12(2):43–6. Erratum in: J Palliat Care 1996 Autumn;12(3):50. [Rec#: 388] Exclude at abstract screening: Title Only
Barrett J J, Haley W E, Powers R E. Alzheimer's disease patients and their caregivers: medical care issues for the primary care physician. South Med J. 96;89(1):1-9. [Rec#: 50005] In abstract review process. [pmid: 8545685].
Barroso P, Osuna E, Luna A. Doctors' death experience and attitudes towards death, euthanasia and informing terminal patients. Med Law. 92;11(78):527-33. [Rec#: 392] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Barry B, Henderson A. Nature of decision-making in the terminally ill patient. Cancer Nurs. 96;19(5):384-91. [Rec#: 393] Exclude at abstract screening: Observational study. [pmid: 8885487].
Barsevik A, Sweeney C, Haney E, Chung E. A systemic qualitative analysis of psychoeducational interventions for depression in patients with cancer. Oncology Nursing Forum. 2002;29:73-87. [Rec#: 50206] Exclude at abstract screening: Title Only. [pmid: 11817494].
Barta K, Neighbors M. Nurses' knowledge of--and role in--patients' end-of-life decision-making. Trends Health Care Law Ethics. 93;8(4):50-2. [Rec#: 396] Exclude at abstract screening: no outcomes specified.
Baruch J M. Informed consent and advance directives. J Am Podiatr Med Assoc. 2004;94(2):198-205. [Rec#: 405] Exclude at abstract screening: no outcomes specified. [pmid: 15028798].
Bassett C, McSherry R. Quality assurance and the palliative care team. Nurs Stand. 96;10(23):45-7. [Rec#: 9391] Exclude at abstract screening: no outcomes specified. [pmid: 8695464].
Basta L L. Proper planning for end-of-life medical care; confronting the near irrelevance of currently used living wills. Am J Geriatr Cardiol. 2003;12(2):110-2. [Rec#: 421] Exclude at abstract screening: Title Only. [pmid: 12624581].
Bates D W, Tolle S W, Elliot D L. Subspecialty differences in responding to patient death--comparing cardiologists with oncologists. Western Journal of Medicine. 88;148(4):471-3. [Rec#: 50207] Exclude at abstract screening: Title Only.
Bates M S, Rankin-Hill L, Sanchez-Ayendez M. The effects of the cultural context of health care on treatment of and response to chronic pain and illness. Social Science & Medicine. 97;45(9):1433-47. [Rec#: 50208] Exclude at abstract screening: not about end of life.
Batikas Whedon M, Meyer L P. Metastatic pancreatic cancer: meeting palliative care needs. Cancer Pract. 2001;9(4):164-8. [Rec#: 430] Exclude at abstract screening: useful only for background. [pmid: 11879306].
Baumrucker S J. Differential advantage and hospice care. Am J Hosp Palliat Care. 2004;21(1):11-2. [Rec#: 436] Exclude at abstract screening: Title Only. [pmid: 14748517].
Baumrucker S J. Spirituality in hospice and palliative care. Am J Hosp Palliat Care 2003;20(2):90–2. Comment on: Am J Hosp Palliat Care. Mar-Apr. 2003;20(2):135-9. PMID: 12693646. [Rec#: 438] Exclude at abstract screening: Title Only.
Baumrucker S J. The Palliative Care Quality of Life Instrument (PQLI): a new tool for measuring quality of life. Am J Hosp Palliat Care. 2004;21(2):87-9. [Rec#: 437] Exclude at abstract screening: useful only for background. [pmid: 15055507].
Bauwens S, Distelmans W, Storme G, Kaufman L. Attitudes and knowledge about cancer pain in Flanders. The educational effect of workshops regarding pain and symptom control. Palliat Med. 2001;15(3):181-9. [Rec#: 9416] Exclude at abstract screening: not about end of life. [pmid: 11407189].
Bayer D L. Women approaching death. Am J Hosp Palliat Care. 93;10(3):28-32. [Rec#: 9419] Exclude at abstract screening: Title Only. [pmid: 8312077].
Beach M C, Morrison R S. The effect of do-not-resuscitate orders on physician decision-making. J Am Geriatr Soc. 2002;50(12):2057-61. [Rec#: 442] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12473020].
Becker J E. Oncology social workers' attitudes toward hospice care and referral behavior. Health Soc Work. 2004;29(1):36-45. [Rec#: 453] Exclude at abstract screening: Study Design - Unclear. [pmid: 15024917].
Beck-Friis B, Strang P. The organization of hospital-based home care for terminally ill cancer patients: the Motala model. Palliat Med. 93;7(2):93-100. [Rec#: 448] Exclude at abstract screening: Title Only. [pmid: 7505177].
Beck-Friis B, Strang P, Sjoden P O. Caring for severely ill cancer patients. A comparison of working conditions in hospital-based home care and in hospital. Support Care Cancer. 93;1(3):145-51. [Rec#: 9437] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Becvar D S. The impact on the family therapist of a focus on death, dying, and bereavement. J Marital Fam Ther. 2003;29(4):469-77. [Rec#: 9446] Exclude at abstract screening: no outcomes specified. [pmid: 14593689].
Bedard J, Dionne A, Dionne L. The experience of La Maison Michel Sarrazin (1985-1990): profile analysis of 952 terminal-phase cancer patients. J Palliat Care. 91;7(1):42-53. [Rec#: 458] Exclude at abstract screening: Title Only.
Beddar S A, Holden-Bennett L, McCormick A M. Development and evaluation of a protocol to manage fecal incontinence in the patient with cancer. J Palliat Care. 97;13(2):27-38. [Rec#: 459] Exclude at abstract screening: no outcomes specified.
Bedford S, Melzer D, Guralnik J. Problem behavior in the last year of life: prevalence, risks, and care receipt in older Americans. J Am Geriatr Soc. 2001;49(5):590-5. [Rec#: 40233] Exclude at abstract screening: Other topic only. [pmid: 11380752].
Beel A, McClement S E, Harlos M. Palliative sedation therapy: a review of definitions and usage. International Journal of Palliative Nursing. 2002;8(4):190-9. [Rec#: 50209] Exclude at abstract screening: no outcomes specified. [pmid: 12048448].
Belasco J B, Danz P, Drill A, Schmid W, Burkey E. Supportive care: palliative care in children, adolescents, and young adults--model of care, interventions, and cost of care: a retrospective review. J Palliat Care. 2000;16(4):39-46. [Rec#: 474] Exclude at abstract screening: Title Only. [pmid: 11965934].
Benditt J O, Smith T S, Tonelli M R. Empowering the individual with ALS at the end-of-life: disease-specific advance care planning. Muscle Nerve 2001;24(12):1706–9. Comment in: Muscle Nerve. Jun. 2002;25(6):923. PMID: 12115987. [Rec#: 9474] Exclude at abstract screening: Title Only.
Benditt J O. Noninvasive ventilation at the end of life. Respir Care. 2000;45(11):1376-81. [Rec#: 481] Exclude at abstract screening: useful only for background. [pmid: 11063525].
Benedetti C, Brock C, Cleeland C, Coyle N, Dube J E, Ferrell B, Hassenbusch S 3rd, Janjan N A, Lema M J, Levy M H, Loscalzo M J, Lynch M, Muir C, Oakes L, O'Neill A, Payne R, Syrjala K L, Urba S, Weinstein S M. National Comprehensive Cancer, Network. NCCN Practice Guidelines for Cancer Pain. Oncology (Huntington). 2000;14(11A):135-50. [Rec#: 50211] Exclude at abstract screening: no outcomes specified.
Benett I J, Danczak A F. Terminal care: improving teamwork in primary care using Significant Event Analysis. Eur J Cancer Care (Engl). 94;3(2):54-7. [Rec#: 9477] Exclude at abstract screening: no outcomes specified.
Benko I, Molnar T F, Horvath O P. Palliative treatment of malignant pleural effusions by video-assisted thoracoscopic surgery. Acta Chir Hung. 99;38(2):131-3. [Rec#: 30404] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Bennett M, Corcoran G. The impact on community palliative care services of a hospital palliative care team. Palliat Med. 94;8(3):237-44. [Rec#: 9484] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Bennett S J, Huster G A, Baker S L, Milgrom L B, Kirchgassner A, Birt J, Pressler M L. Characterization of the precipitants of hospitalization for heart failure decompensation. Am J Crit Care. 98;7(3):168-74. [Rec#: 30408] Exclude at abstract screening: not about end of life.
Bennett S J, Oldridge N B, Eckert G J, Embree J L, Browning S, Hou N, Chui M, Deer M, Murray M D. Comparison of quality of life measures in heart failure. Nurs Res. 2003;52(4):207-16. [Rec#: 30410] Exclude at abstract screening: not about end of life. [pmid: 12867777].
Ben-Zacharia A B, Lublin F D. Palliative care in patients with multiple sclerosis. Neurologic Clinics. 2001;19(4):801-27. [Rec#: 50210] Exclude at abstract screening: no outcomes specified. [pmid: 11854101].
Benzein E, Berg A. The Swedish version of Herth Hope Index--an instrument for palliative care. Scand J Caring Sci. 2003;17(4):409-15. [Rec#: 496] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14629644].
Benzein E, Saveman B I. Nurses' perception of hope in patients with cancer: a palliative care perspective. Cancer Nurs. 98;21(1):10-6. [Rec#: 497] Exclude at abstract screening: no outcomes specified.
Benzein E, Norberg A, Saveman B I. The meaning of the lived experience of hope in patients with cancer in palliative home care. Palliat Med. 2001;15(2):117-26. [Rec#: 9491] Exclude at abstract screening: no outcomes specified. [pmid: 11301662].
Berardo D H, Berardo F M. Quality of life across age and family stage. J Palliat Care. 92;8(3):52-5. [Rec#: 498] Exclude at abstract screening: no outcomes specified. [pmid: 1432376].
Berenthal J A. A welcome break for carers? The role of voluntary services in caring for dying people. Prof Nurse. 94;9(4):267-70. [Rec#: 9493] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Berger,A., Pereira, D., Baker, K., O'Mara, A., and Bolle, J. A commentary: social and cultural determinants of end-of-life care for elderly persons. Gerontologist 2002;42 Spec No 3:49–53. [Rec#: 50212] Exclude at abstract screening: Title Only
Berghmans R. Advance directives and dementia. Ann N Y Acad Sci. 2000;913:105-10. [Rec#: 9517] Exclude at abstract screening: no outcomes specified. [pmid: 11040832].
Bergman B, Aaronson N K. Quality-of-life and cost-effectiveness assessment in lung cancer. Curr Opin Oncol 95;7(2):138-43. Comment in: Curr Opin Oncol. Mar. 1995;7(2):131-3. PMID: 7756377. [Rec#: 30433] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Berlowitz D R, Young G J, Hickey E C, Joseph J, Anderson J J, Ash A S, Moskowitz M A. Clinical practice guidelines in the nursing home. Am J Med Qual. 2001;16(6):189-95. [Rec#: 9527] Exclude at abstract screening: not about end of life. [pmid: 11816849].
Berman P, Braverman C. Utilization review of hospice home care. Am J Hosp Palliat Care. 96;13(2):14-6. [Rec#: 9530] Exclude at abstract screening: Title Only. [pmid: 8716322].
Bernard S A, Bruera E. Drug interactions in palliative care. Journal of Clinical Oncology. 2000;18(8):1780-99. [Rec#: 50215] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10764440].
Bern-Klug M, Ekerdt D J, Wilkinson D S. What families know about funeral-related costs: implications for social work practice. Health & Social Work. 99;24(2):128-37. [Rec#: 50213] Exclude at abstract screening: not about end of life.
Berry D L, Wilkie D J, Huang H Y, Blumenstein B A. Cancer pain and common pain: a comparison of patient-reported intensities. Oncol Nurs Forum. 99;26(4):721-6. [Rec#: 30452] Exclude at abstract screening: not about end of life.
Berthelot J M, Will B P, Evans W K, Coyle D, Earle C C, Bordeleau L. Decision framework for chemotherapeutic interventions for metastatic non-small-cell lung cancer. J Natl Cancer Inst. 2000;92(16):1321-9. [Rec#: 9542] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 10944554].
Bertman S. Ars Moriendi: illuminations on ‘the good death’ from the arts and humanities. Hosp J. 98;13(12):5-28. [Rec#: 9543] Exclude at abstract screening: Title Only. [pmid: 9644387].
Bezjak A. Palliative therapy for lung cancer. Semin Surg Oncol. 2003;21(2):138-47. [Rec#: 30463] Exclude at abstract screening: no outcomes specified. [pmid: 14508864].
Bialecki L, Woodward R S. Predicting death after CPR. Experience at a nonteaching community hospital with a full-time critical care staff. Chest 95;108(4):1009–17. Comment in: Chest. Oct. 1995;108(4):892-3. PMID: 7555153. [Rec#: 40294] Exclude at abstract screening: primarily prognosis or trajectories.
Bickerstaff K A, Grasser C M, McCabe B. How elderly nursing home residents transcend losses of later life. Holist Nurs Pract. 2003;17(3):159-65. [Rec#: 552] Exclude at abstract screening: not about end of life. [pmid: 12784900].
Biernacki C. Should dementia patients be informed about their diagnosis?. Prof Nurse. 2003;19(4):198-202. [Rec#: 9560] Exclude at abstract screening: Non-systematic review. [pmid: 14692252].
Billings JA and Pantilat S. Survey of palliative care programs in United States teaching hospitals. J Palliat Med 2001;4(3):309–14. Comment in: J Palliat Med. 2001 Fall;4(3):307–8. PMID: 11596540. [Rec#: 9577] Exclude at abstract screening: outcome unrelated to pts/family/non-prof
Billings J A, Gardner M, Putnam A T. A one-day, hospital-wide survey of dying inpatients. J Palliat Med. 2002;5(3):363-74. [Rec#: 9576] Exclude at abstract screening: useful only for background. [pmid: 12133242].
Billings JA. On being a reluctant physician-strains and rewards in caring for the dying at home. Outpatient Management of Advances Cancer 1985;<25 Page(s)>. [Rec#: 50218] Exclude at abstract screening: Title Only
Billings J A. Depression. Journal of Palliative Care. 95;11(1):48-54. [Rec#: 50216] Exclude at abstract screening: Study Design - Unclear. [pmid: 7751987].
Billings J A. Neuropathic pain. Journal of Palliative Care. 94;10(4):40-3. [Rec#: 50217] Exclude at abstract screening: Study Design - Unclear. [pmid: 7699519].
Billings J A. What is palliative care?. Journal of Palliative Medicine. 98;1(1):73-78. [Rec#: 50219] Exclude at abstract screening: Title Only. [pmid: 15859874].
Bilu Y, Witztum E. Working with Jewish ultra-orthodox patients: guidelines for a culturally sensitive therapy. Cult Med Psychiatry. 93;17(2):197-233. [Rec#: 563] Exclude at abstract screening: not about end of life.
Binsack T. Caring for terminally ill patients. The Johannes Hospiz in Munich: a palliative care unit in Southern Bavaria, Germany. Support Care Cancer. 99;7(6):377-8. [Rec#: 9581] Exclude at abstract screening: Title Only.
Bird C E, Shugarman L R, Lynn J. Age and gender differences in health care utilization and spending for medicare beneficiaries in their last years of life. J Palliat Med. 2002;5(5):705-12. [Rec#: 574] Exclude at abstract screening: Other topic only. [pmid: 12572969].
Bisset A F, MacPherson I A. Patients with dementia: the view from general practice in Grampian. Health Bull (Edinb). 96;54(1):32-6. [Rec#: 50006] Exclude at abstract screening: not about end of life. [pmid: 8820227].
Black B, Kovacs P J. Direct care and nondirect care hospice volunteers: motivations, acceptance, satisfaction and length of service. J Volunt Adm. 96;14(2):21-32. [Rec#: 9591] Exclude at abstract screening: Title Only. [pmid: 10156302].
Blackford J, Street A. The role of the palliative care nurse consultant in promoting continuity of end-of-life care. Int J Palliat Nurs. 2001;7(6):273-8. [Rec#: 9593] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12066021].
Blanchard B. Care for dying people in nursing homes. Nurs Older People 2001;13(8):39. Comment on: Nurs Older People. Apr. 2001;13(2):21-5. quiz 26. PMID: 12008570. [Rec#: 596] Exclude at abstract screening: Title Only.
Bland R, Darlington Y. The nature and sources of hope: perspectives of family caregivers of people with serious mental illness. Perspect Psychiatr Care. 2002;38(2):61-8. [Rec#: 598] Exclude at abstract screening: no outcomes specified. [pmid: 12132632].
Blank K. Respectful decisions at the end of life. Am J Geriatr Psychiatry 2002;10(4):362–4. Comment on: Am J Geriatr Psychiatry. 2002 Jul-Aug;10(4):365–72. PMID: 12095896. Comment in: Am J Geriatr Psychiatry. Jan-Feb. 2003;11(1):113-4. PMID: 12527550. [Rec#: 599] Exclude at abstract screening: Title Only.
Blank L L. Defining and evaluating physician competence in end-of-life care. A matter of awareness and emphasis. Western Journal of Medicine. 95;163:297-301. [Rec#: 50220] Exclude at abstract screening: Title Only. [pmid: 7571595].
Blatt L. Working with families in reaching end-of-life decisions. Clin Nurse Spec 99;13(5):219–23; quiz 224–6. Comment in: Clin Nurse Spec. Sep. 1999;13(5):218. PMID: 11188551. [Rec#: 9601] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Blazeby J M, Farndon J R, Donovan J, Alderson D. A prospective longitudinal study examining the quality of life of patients with esophageal carcinoma. Cancer. 2000;88(8):1781-7. [Rec#: 602] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 10760752].
Blazeby J M, Williams M H, Brookes S T, Alderson D, Farndon J R. Quality of life measurement in patients with oesophageal cancer. Gut. 95;37(4):505-8. [Rec#: 603] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Bledsoe B E, Myers J. Pain & comfort: the pathophysiology of pain & prehospital treatment options. JEMS 2003;28(6):50–67. Comment on: JEMS. 2003 Jun;28(6):74–6, 78–82, 84–8 passim; quiz 102–3. PMID: 12792597. Comment in: JEMS. Aug. 2003;28(8):20. author reply 20. PMID: 14518506. [Rec#: 9602] Exclude at abstract screening: no outcomes specified.
Bledsoe T A. Point of view: respecting patient's wishes at the end of life: hospital and physician concerns. Med Health R I. 2001;84(8):279-80. [Rec#: 9603] Exclude at abstract screening: Title Only. [pmid: 11517717].
Bleehen N M, Girling D J, Machin D, Stephens R J. A randomised trial of three or six courses of etoposide cyclophosphamide methotrexate and vincristine or six courses of etoposide and ifosfamide in small cell lung cancer (SCLC). II: Quality of life. Medical Research Council Lung Cancer Working Party. Br J Cancer. 93;68(6):1157-66. [Rec#: 605] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Blevins C. Death of a home care agency: is there an educator in the house?. Home Healthc Nurse Manag. 99;3(5):22-5. [Rec#: 40317] Exclude at abstract screening: Title Only. [pmid: 10776124].
Blevins D, Deason-Howell L M. End-of-life care in nursing homes: the interface of policy, research, and practice. Behav Sci Law. 2002;20(3):271-86. [Rec#: 9605] Exclude at abstract screening: no outcomes specified. [pmid: 12111988].
Bliss J, While A. Decision-making in palliative and continuing care in the community: an analysis of the published literature with reference to the context of UK care provision. Int J Nurs Stud. 2003;40(8):881-8. [Rec#: 9607] Exclude at abstract screening: Non-systematic review. [pmid: 14568369].
Block P J, Schoors D, van Camp G. Substantial variations in clinical outcome following hospitalization for heart failure. Eur Heart J 2002;23(8):597–9. Comment on: Eur Heart J. Apr. 2002;23(8):650-7. PMID: 11969280. [Rec#: 50007] Exclude at abstract screening: Title Only.
Block S D. Assessing and managing depression in the terminally ill patient. Annals of Internal Medicine. 2000;132:209-213. [Rec#: 50221] Exclude at abstract screening: Title Only. [pmid: 10651602].
Block, Susan D. Psychological Considerations, Growth, and Transcendance at the End of Life: the Art of the Possible. JAMA. 2001;285(22):2898-2905. [Rec#: 50222] Exclude at abstract screening: Title Only. [pmid: 11401612].
Bloom B S, Amenta M O. Prospective payment and the Medicare hospice benefit. Am J Hosp Palliat Care. 93;10(2):32-8. [Rec#: 612] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Bloomfield D J. Should bisphosphonates be part of the standard therapy of patients with multiple myeloma or bone metastases from other cancers? An evidence-based review. J Clin Oncol. 98;16(3):1218-25. [Rec#: 50116] Exclude at abstract screening: Study Design - Review/Meta.
Bluestine S, Lesko L. Psychotropic medications in oncology and in AIDS patients. Adv Psychosom Med. 94;21:107-37. [Rec#: 9617] Exclude at abstract screening: no outcomes specified. [pmid: 7528461].
Blumhuber H, de Conno F, Hanks G W. Report of the European Association for Palliative Care. J Pain Symptom Manage. 96;12(2):82-4. [Rec#: 9620] Exclude at abstract screening: Title Only. [pmid: 8754984].
Blumhuber H, Kaasa S, De Conno F. The European Association for Palliative Care. J Pain Symptom Manage. 2002;24(2):124-7. [Rec#: 9621] Exclude at abstract screening: Title Only. [pmid: 12231128].
Blustein J. The family in medical decisionmaking. Hastings Cent Rep. 93;23(3):6-13. [Rec#: 617] Exclude at abstract screening: no outcomes specified. [pmid: 8496054].
Bly J L, Kissick P. Hospice care for patients living alone: results of a demonstration program. Hosp J. 94;9(4):9-20. [Rec#: 618] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Blyth A C. Audit of terminal care in a general practice. BMJ 90;300(6730):983–6. Comment in: BMJ. May 26. 1990;300(6736):1400-1. PMID: 2242142. [Rec#: 619] Exclude at abstract screening: data older than 1990.
Boakes J, Gardner D, Yuen K, Doyle S. General practitioner training in palliative care: an experiential approach. J Palliat Care. 2000;16(2):11-9. [Rec#: 9623] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10887727].
Bohnet N L. Hospice concepts in home care. Caring. 96;15(11):44-50. [Rec#: 9634] Exclude at abstract screening: no outcomes specified. [pmid: 10162304].
Bolmsjo I, Hermeren G. Challenging assumptions in end-of-life situations. Palliat Med. 98;12(6):451-6. [Rec#: 638] Exclude at abstract screening: Observational study. [pmid: 10621865].
Bolmsjo I, Hermeren G. Interviews with patients, family, and caregivers in amyotrophic lateral sclerosis: comparing needs. J Palliat Care. 2001;17(4):236-40. [Rec#: 639] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11813340].
Bolmsjo I, Hermern G. Conflicts of interest: experiences of close relatives of patients suffering from amyotrophic lateral sclerosis. Nurs Ethics. 2003;10(2):186-98. [Rec#: 640] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12659489].
Bolmsjo I, Hermeren G, Ingvar C. Meeting existential needs in palliative care--who, when, and why?. J Palliat Care. 2002;18(3):185-91. [Rec#: 9641] Exclude at abstract screening: no outcomes specified. [pmid: 12418369].
Bolmsjo I. Existential issues in palliative care: interviews of patients with amyotrophic lateral sclerosis. J Palliat Med. 2001;4(4):499-505. [Rec#: 636] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11798482].
Bolmsjo I. Existential issues in palliative care--interviews with cancer patients. J Palliat Care. 2000;16(2):20-4. [Rec#: 637] Exclude at abstract screening: Study Design - Qualitative. [pmid: 10887728].
Bonham V L. Race, ethnicity, and pain treatment: striving to understand the causes and solutions to the disparities in pain treatment. J Law Med Ethics. 2001;29(1):52-68. [Rec#: 9651] Exclude at abstract screening: Title Only. [pmid: 11521272].
Bonica J J. Evolution and current status of pain programs. J Pain Symptom Manage. 90;5(6):368-74. [Rec#: 9652] Exclude at abstract screening: no outcomes specified. [pmid: 1702822].
Bonito V, Primavera A, Borghi L, Mori M, Defanti C A. Working Group on Bioethics and Palliative Care in Neurology. The discontinuation of life support measures in patients in a permanent vegetative state. Neurol Sci 2002;23(3):131–9. Comment in: Neurol Sci. 2002 Dec;23(5):251–4. PMID: 12528687. Comment in: Neurol Sci. Jun. 2003;24(2):90-1. PMID: 12846221. [Rec#: 9654] Exclude at abstract screening: Title Only.
Bonneux L. How to measure the burden of mortality?. J Epidemiol Community Health. 2002;56(2):128-31. [Rec#: 655] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11812812].
Bonomi P, Kim K, Fairclough D, Cella D, Kugler J, Rowinsky E, Jiroutek M, Johnson D. Comparison of survival and quality of life in advanced non-small-cell lung cancer patients treated with two dose levels of paclitaxel combined with cisplatin versus etoposide with cisplatin: results of an Eastern Cooperative Oncology Group trial. J Clin Oncol. 2000;18(3):623-31. [Rec#: 30569] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 10653877].
Bono-Snell B. The role of the psychiatric nurse in a home care palliative care program. Caring. 2003;22(11):20-1. [Rec#: 9655] Exclude at abstract screening: no outcomes specified. [pmid: 14658199].
Bonura D, Fender M, Roesler M, Pacquiao D F. Culturally congruent end-of-life care for Jewish patients and their families. J Transcult Nurs. 2001;12(3):211-20. [Rec#: 657] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11989036].
Bookbinder M, Romer A L. Raising the standard of care for imminently dying patients using quality improvement. J Palliat Med. 2002;5(4):635-44. [Rec#: 9656] Exclude at abstract screening: Title Only. [pmid: 12243689].
Booker R. Implementing a discharge assessment tool in palliative home care. Canadian Oncology Nursing Journal. 2002;12(3):169-76. [Rec#: 50223] Exclude at abstract screening: no outcomes specified. [pmid: 12271918].
Bookwala J, Coppola K M, Fagerlin A, Ditto P H, Danks J H, Smucker W D. Gender differences in older adults' preferences for life-sustaining medical treatments and end-of-life values. Death Stud. 2001;25(2):127-49. [Rec#: 660] Exclude at abstract screening: Study Design - Unclear. [pmid: 11708352].
Booth K, Maguire P M, Butterworth T, Hillier V F. Perceived professional support and the use of blocking behaviours by hospice nurses. J Adv Nurs. 96;24(3):522-7. [Rec#: 9662] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Booth S, Anderson H, Swannick M, Wade R, Kite S, Johnson M. Expert Working Group of the Scientific Committee of the Association of Palliative Medicine. The use of oxygen in the palliation of breathlessness. A report of the expert working group of the Scientific Committee of the Association of Palliative Medicine. Respir Med. 2004;98(1):66-77. [Rec#: 664] Exclude at abstract screening: useful only for background. [pmid: 14959816].
Booth K, Maguire P, Hillier V F. Measurement of communication skills in cancer care: myth or reality?. Journal of Advanced Nursing. 99;30(5):1073-9. [Rec#: 50224] Exclude at abstract screening: no outcomes specified.
Borasio G D, Voltz R. Discontinuation of mechanical ventilation in patients with amyotrophic lateral sclerosis. J Neurol. 98;245(11):717-22. [Rec#: 9668] Exclude at abstract screening: no outcomes specified.
Borasio G D, Voltz R. Palliative care in amyotrophic lateral sclerosis. J Neurol. 97;244(Suppl 4):S11-7. [Rec#: 9669] Exclude at abstract screening: useful only for background. [pmid: 9402548].
Borasio G D, Voltz R, Miller R G. Palliative care in amyotrophic lateral sclerosis. Neurol Clin. 2001;19(4):829-47. [Rec#: 9670] Exclude at abstract screening: no outcomes specified. [pmid: 11854102].
Borlase B C, Baxter J T, Benotti P N, Stone M, Wood E, Forse R A, Blackburn G L, Steele G Jr. Surgical intensive care unit resource use in a specialty referral hospital: I Predictors of early death and cost implications. Surgery. 91;109(6):687-93. [Rec#: 9671] Exclude at abstract screening: primarily prognosis or trajectories.
Bosek M S, Lowry E. When care is futile. Medsurg Nurs. 94;3(3):225-7. [Rec#: 689] Exclude at abstract screening: Title Only. [pmid: 8055042].
Bosnjak S, Jelic S, Susnjar S, Luki V. Gabapentin for relief of neuropathic pain related to anticancer treatment: a preliminary study. J Chemother. 2002;14(2):214-9. [Rec#: 691] Exclude at abstract screening: not about end of life. [pmid: 12017380].
Boston P, Towers A, Barnard D. Embracing vulnerability: risk and empathy in palliative care. J Palliat Care. 2001;17(4):248-53. [Rec#: 694] Exclude at abstract screening: no outcomes specified. [pmid: 11813342].
Boston P H. Culturally responsive cancer care in a cost-constrained work-classification system: a qualitative study of palliative care nurses. J Cancer Educ. 99;14(3):148-53. [Rec#: 9678] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Botsford A L. Integrating end of life care into services for people with an intellectual disability. Soc Work Health Care. 2000;31(1):35-48. [Rec#: 699] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10989873].
Bottomley A, Efficace F, Thomas R, Vanvoorden V, Ahmedzai S H. Health-related quality of life in non-small-cell lung cancer: methodologic issues in randomized controlled trials. J Clin Oncol. 2003;21(15):2982-92. [Rec#: 30590] Exclude at abstract screening: not about end of life. [pmid: 12885819].
Bottomley A. Metastatic colorectal cancer: treatment challenges and quality of life. Lancet 2002;359(9317):1537-8. Comment on: Lancet. May 4. 2002;359(9317):1555-63. PMID: 12047964. [Rec#: 9682] Exclude at abstract screening: useful only for background.
Bottorff J L, Steele R, Davies B, Garossino C, Porterfield P, Shaw M. Striving for balance: palliative care patients' experiences of making everyday choices. J Palliat Care. 98;14(1):7-17. [Rec#: 701] Exclude at abstract screening: Study Design - Qualitative.
Bottorff J L, Steele R, Davies B, Porterfield P, Garossino C, Shaw M. Facilitating day-to-day decision making in palliative care. Cancer Nurs. 2000;23(2):141-50. [Rec#: 702] Exclude at abstract screening: Study Design - Qualitative. [pmid: 10763286].
Bottrell M M, O'sullivan J F, Robbins M A, Mitty E L, Mezey M D. Transferring dying nursing home residents to the hospital: DON perspectives on the nurse's role in transfer decisions. Geriatr Nurs. 2001;22(6):313-7. [Rec#: 9683] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11780005].
Boussat S, El'rini T, Dubiez A, Depierre A, Barale F, Capellier G. Predictive factors of death in primary lung cancer patients on admission to the intensive care unit. Intensive Care Med. 2000;26(12):1811-6. [Rec#: 40375] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 11271089].
Bouton B L. The interdisciplinary bereavement team: defining and directing appropriate bereavement care. Hosp J. 96;11(4):15-24. [Rec#: 9692] Exclude at abstract screening: no outcomes specified. [pmid: 9256678].
Bouvette M, Fothergill-Bourbonnais F, and Perreault A. Implementation of the pain and symptom assessment record (PSAR). J Adv Nurs 2002;40(6):685–700. Erratum in: J Adv Nurs. 2003 Jun;42(6):647. [Rec#: 9693] Exclude at abstract screening: Study Design - Qualitative
Bowman G S. Emotions and illness. J Adv Nurs. 2001;34(2):256-63. [Rec#: 9697] Exclude at abstract screening: no outcomes specified. [pmid: 11430288].
Bowman K W, Singer P A. Chinese seniors' perspectives on end-of-life decisions. Soc Sci Med. 2001;53(4):455-64. [Rec#: 720] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11459396].
Bowman K W, Martin D K, Singer P A. Quality end-of-life care. J Eval Clin Pract. 2000;6(1):51-61. [Rec#: 9699] Exclude at abstract screening: Title Only. [pmid: 10807024].
Bowman K W. Communication, negotiation, and mediation: dealing with conflict in end-of-life decisions. J Palliat Care. 2000;16(Suppl):S17-23. [Rec#: 719] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11075529].
Boyce A, McHugh M, Lyon P. Proactive palliative care choices for haematology day unit patients. Int J Palliat Nurs. 2003;9(12):544-50. [Rec#: 9702] Exclude at abstract screening: Study Design - Unclear. [pmid: 14765012].
Boyd K J, Beeken L. Tube feeding in palliative care: benefits and problems. Palliat Med. 94;8(2):156-8. [Rec#: 730] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 7521716].
Boyd K J. Hospice home care in the United Kingdom. Ann Acad Med Singapore. 94;23(2):271-4. [Rec#: 9703] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 8080228].
Boyd K J. Palliative care in the community: views of general practitioners and district nurses in east London. J Palliat Care. 93;9(2):33-8. [Rec#: 9704] Exclude at abstract screening: no outcomes specified.
Boyd K J. The role of specialist home care teams: views of general practitioners in south London. Palliat Med. 95;9(2):138-44. [Rec#: 9705] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Boykin L. The role of the dietitian in palliative care. Health Care Food Nutr Focus. 97;13(9):8-7. [Rec#: 9706] Exclude at abstract screening: Title Only. [pmid: 10166849].
Boyle D A. Pathos in practice: exploring the affective domain of oncology nursing. Oncol Nurs Forum. 2000;27(6):915-9. [Rec#: 9707] Exclude at abstract screening: Title Only. [pmid: 10920831].
Boyle D M, Abernathy G, Baker L, Wall A C. End-of-life confusion in patients with cancer. Oncol Nurs Forum 98;25(8):1335–43. Comment in: Oncol Nurs Forum. Apr. 1999;26(3):497-8. PMID: 10214580. [Rec#: 9711] Exclude at abstract screening: Study Design - Review/Meta.
Boyle D M. “Coding” the patient with cancer: nurses facilitate family acceptance and grief. Oncol Nurs Forum. 97;24(3):458. [Rec#: 9710] Exclude at abstract screening: Title Only. [pmid: 9127358].
Boyle D M. The cultural context of dying from cancer. International Journal of Palliative Nursing. 98;4(2):70-83. [Rec#: 50225] Exclude at abstract screening: Title Only.
Boys L. Using morphine for effective pain control in palliative care. Community Nurse. 2000;5(12):33-4. [Rec#: 9712] Exclude at abstract screening: Title Only. [pmid: 11189663].
Boyte W R. The curtain. What happens when doctors reach out to bereaved family members. Health Aff (Millwood). 2002;21(4):242-5. [Rec#: 9714] Exclude at abstract screening: Title Only. [pmid: 12117136].
Bozzetti F, Cozzaglio L, Biganzoli E, Chiavenna G, De Cicco M, Donati D, Gilli G, Percolla S, Pironi L. Quality of life and length of survival in advanced cancer patients on home parenteral nutrition. Clin Nutr 2002;21(4):281–8. Comment in: Clin Nutr. Aug. 2002;21(4):269-71. PMID: 12135585. [Rec#: 733] Exclude at abstract screening: primarily prognosis or trajectories.
Bozzetti F. Home total parenteral nutrition in incurable cancer patients: a therapy, a basic humane care or something in between?. Clin Nutr. 2003;22(2):109-11. [Rec#: 9715] Exclude at abstract screening: Title Only. [pmid: 12706125].
Braddock C H 3rd, Edwards K A, Hasenberg N M, Laidley T L, Levinson W. Informed decision making in outpatient practice: time to get back to basics. JAMA. 99;282(24):2313-20. [Rec#: 50226] Exclude at abstract screening: not about end of life.
Bradley E H, Cherlin E, McCorkle R, Fried T R, Kasl S V, Cicchetti D V, Johnson-Hurzeler R, Horwitz S M. Nurses' use of palliative care practices in the acute care setting. J Prof Nurs. 2001;17(1):14-22. [Rec#: 9719] Exclude at abstract screening: useful only for background. [pmid: 11211378].
Bradley E H, Cicchetti D V, Fried T R, Rousseau D M, Johnson-Hurzeler R, Kasl S V, Horwitz S M. Attitudes about care at the end of life among clinicians: a quick, reliable, and valid assessment instrument. J Palliat Care. 2000;16(1):6-14. [Rec#: 741] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10802958].
Bradley E H, Fried T R, Kasl S V, Cicchetti D V, Johnson-Hurzeler R, Horwitz S M. Referral of terminally ill patients for hospice: frequency and correlates. J Palliat Care. 2000;16(4):20-6. [Rec#: 9720] Exclude at abstract screening: Other topic only. [pmid: 11965930].
Bradley W G. Advanced care planning in ALS. Muscle & Nerve. 2002;25(6):923. [Rec#: 50227] Exclude at abstract screening: Title Only. [pmid: 12115987].
Bradshaw A. The spiritual dimension of hospice: the secularization of an ideal. Soc Sci Med. 96;43(3):409-19. [Rec#: 9723] Exclude at abstract screening: no outcomes specified. [pmid: 8844942].
Bradshaw P J. Characteristics of clients referred to home, hospice and hospital palliative care services in Western Australia. Palliat Med. 93;7(2):101-7. [Rec#: 747] Exclude at abstract screening: Other topic only. [pmid: 7505169].
Brady A, Cleeland C, Goldstein G, Lefkowitz M, Linden-Malek P, Martens G, Miller SJ, Portenoy RK, and Simmonds MA. Pain management guidelines: implications for managed care--a roundtable discussion. Med Interface 97;Suppl:10–32. [Rec#: 9724] Exclude at abstract screening: no outcomes specified
Brady M J, Cella D. Assessing quality of life in palliative care. Cancer Treat Res. 99;100:203-16. [Rec#: 9726] Exclude at abstract screening: Title Only. [pmid: 10645504].
Brady M J, Peterman A H, Fitchett G, Mo M, Cella D. A case for including spirituality in quality of life measurement in oncology. Psycho-Oncology. 99;8(5):417-28. [Rec#: 50228] Exclude at abstract screening: not about end of life.
Brajtman S. The impact on the family of terminal restlessness and its management. Palliat Med. 2003;17(5):454-60. [Rec#: 9728] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12882264].
Bral E E. Caring for adults with chronic cancer pain. Am J Nurs 98;98(4):26–32; quiz 33. Comment in: Am J Nurs. Aug. 1998;98(8):18. PMID: 9711143. [Rec#: 748] Exclude at abstract screening: Title Only.
Brallier LW. The suffering of terminal illness: cancer. NLN Publ 92;(15–2461):203–25. [Rec#: 9729] Exclude at abstract screening: Title Only
Brameld K J, Holman C D, Bass A J, Codde J P, Rouse I L. Hospitalisation of the elderly during the last year of life: an application of record linkage in Western Australia 1985-1994. J Epidemiol Community Health. 98;52(11):740-4. [Rec#: 40393] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Branch W T Jr, Pels R J, Hafler J P. Medical students' empathic understanding of their patients. Acad Med. 98;73(4):360-2. [Rec#: 9732] Exclude at abstract screening: no outcomes specified. [pmid: 9580711].
Branco K, Teno J, Mor V. Advance care planning among nursing home residents prior to the Patient Self-Determination Act. J Health Soc Policy. 95;7(1):37-52. [Rec#: 40395] Exclude at abstract screening: Title Only. [pmid: 10156190].
Brandenburg M, Gifford J. Developing a multidisciplinary brochure to teach patients and families about life-sustaining treatments. Dimens Crit Care Nurs. 97;16(6):328-33. [Rec#: 9735] Exclude at abstract screening: no outcomes specified.
Brandt K. The physician-hospice partnership: expanding opportunities to improve end-of-life care. J Med Pract Manage. 2001;16(5):232-6. [Rec#: 9736] Exclude at abstract screening: no outcomes specified. [pmid: 11345876].
Branicki F J, Law S Y, Fok M, Poon R T, Chu K M, Wong J. Quality of life in patients with cancer of the esophagus and gastric cardia: a case for palliative resection. Arch Surg. 98;133(3):316-22. [Rec#: 9738] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Brant J M. The art of palliative care: living with hope, dying with dignity. Oncol Nurs Forum 98;25(6):995–1004. Comment in: Oncol Nurs Forum. Jan-Feb. 1999;26(1):17. PMID: 9921565. [Rec#: 9741] Exclude at abstract screening: Title Only.
Brasseur L, Larue F. France: status of cancer pain and palliative care. J Pain Symptom Manage. 93;8(6):412-5. [Rec#: 9743] Exclude at abstract screening: no outcomes specified. [pmid: 7525764].
Braun K L, Zir A. Roles for the church in improving end-of-life care: perceptions of Christian clergy and laity. Death Stud. 2001;25(8):685-704. [Rec#: 9744] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11883451].
Braun T C, Hagen N A, Clark T. Development of a clinical practice guideline for palliative sedation. J Palliat Med 2003;6(3):345–50. Comment in: J Palliat Med. Jun. 2003;6(3):425-7. PMID: 14509488. [Rec#: 9745] Exclude at abstract screening: Other topic only.
Braun T C, Hagen N A, Smith C, Summers N. Oncologists and family physicians. Using a standardized letter to improve communication. Can Fam Physician 2003;49:882–6. Comment in: Can Fam Physician. Oct. 2003;49:1272-3. PMID: 14594092. [Rec#: 9746] Exclude at abstract screening: not about end of life.
Brauner D J, Muir J C, Sachs G A. Treating nondementia illnesses in patients with dementia. JAMA. 2000;283(24):3230-5. [Rec#: 50229] Exclude at abstract screening: not about end of life. [pmid: 10866871].
Braveman C, Rodrigues C. Performance improvement in pain management for home care and hospice programs. Am J Hosp Palliat Care 2001;18(4):257–63. Comment in: Am J Hosp Palliat Care. Jul-Aug. 2001;18(4):222-3. PMID: 11467094. [Rec#: 9747] Exclude at abstract screening: Study Design - Unclear.
Braveman C, Wright K. Total turnaround: how to use national benchmarks, an operational review, and focus change strategies to totally turn an agency around. Caring. 2003;22(6):12-6. [Rec#: 9748] Exclude at abstract screening: Title Only. [pmid: 12905567].
Breen C M, Abernethy A P, Abbott K H, Tulsky J A. Conflict associated with decisions to limit life-sustaining treatment in intensive care units. Journal of General Internal Medicine. 2001;16(5):283-9. [Rec#: 50231] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11359545].
Breitbart W, Jacobsen P B. Psychiatric symptom management in terminal care. Clin Geriatr Med. 96;12(2):329-47. [Rec#: 9753] Exclude at abstract screening: useful only for background. [pmid: 8799351].
Breitbart W, Strout D. Delirium in the terminally ill. Clin Geriatr Med. 2000;16(2):357-72. [Rec#: 9754] Exclude at abstract screening: no outcomes specified. [pmid: 10783433].
Breitbart W. Reframing hope: meaning-centered care for patients near the end of life. Interview by Karen S. Heller. J Palliat Med. 2003;6(6):979-88. [Rec#: 40410] Exclude at abstract screening: Title Only. [pmid: 14733692].
Breitbart W. Spirituality and meaning in supportive care: spirituality- and meaning-centered group psychotherapy interventions in advanced cancer. Support Care Cancer. 2002;10(4):272-80. [Rec#: 9752] Exclude at abstract screening: useful only for background. [pmid: 12029426].
Breitbart W. Spirituality and meaning in supportive care: spirituality- and meaning-centered group psychotherapy interventions in advanced cancer. Supportive Care in Cancer. 2002;10(4):272-80. [Rec#: 50232] Exclude at abstract screening: useful only for background. [pmid: 12029426].
Breitbart W, Bruera E, Chochinov H, Lynch M. Neuropsychiatric syndromes and psychological symptoms in patients with advanced cancer. Journal of Pain & Symptom Management. 95;10(2):131-41. [Rec#: 50233] Exclude at abstract screening: Study Design - Unclear.
Breitbart W, Marotta R, Platt M M, Weisman H, Derevenco M, Grau C, Corbera K, Raymond S, Lund S, Jacobson P. A double-blind trial of haloperidol, chlorpromazine, and lorazepam in the treatment of delirium in hospitalized AIDS patients. American Journal of Psychiatry. 96;153(2):231-7. [Rec#: 50235] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Breivik H. Opioids in cancer and chronic non-cancer pain therapy-indications and controversies. Acta Anaesthesiologica Scandinavica. 2001;45(9):1059-66. [Rec#: 50238] Exclude at abstract screening: no outcomes specified. [pmid: 11683653].
Brennan J. Adjustment to cancer - coping or personal transition?. Psychooncology. 2001;10(1):1-18. [Rec#: 9756] Exclude at abstract screening: not about end of life. [pmid: 11180573].
Brenneis C, Bruera E. The interaction between family physicians and palliative care consultants in the delivery of palliative care: clinical and educational issues. J Palliat Care. 98;14(3):58-61. [Rec#: 9757] Exclude at abstract screening: Title Only.
Brenneis C, Michaud M, Bruera E, MacDonald R N. Local toxicity during the subcutaneous infusion of narcotics (SCIN). A prospective study. Cancer Nursing. 87;10(4):172-6. [Rec#: 50239] Exclude at abstract screening: Title Only. [pmid: 3664456].
Brenner P R. Hospice care and palliative care: a perspective from experience. Hosp J. 99;14(34):155-66. [Rec#: 9759] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10839008].
Brenner P R. Issues of access in a diverse society. Hosp J. 97;12(2):9-16. [Rec#: 9760] Exclude at abstract screening: no outcomes specified. [pmid: 9248392].
Brenner P R. Managing patients and families at the ending of life: hospice assumptions, structures, and practice in response to staff stress. Cancer Invest. 97;15(3):257-64. [Rec#: 9761] Exclude at abstract screening: no outcomes specified.
Brenner P R. Palliative care and hospice: one approach. Am J Hosp Palliat Care. 2000;17(4):241-4. [Rec#: 9762] Exclude at abstract screening: no outcomes specified. [pmid: 11883799].
Brenner P R. Useful HIV disease multimedia resources for hospices. Hosp J. 91;7(12):171-86. [Rec#: 9763] Exclude at abstract screening: Title Only. [pmid: 1718839].
Brenner Z R, Krenzer M E. Using complementary and alternative therapies to promote comfort at end of life. Crit Care Nurs Clin North Am. 2003;15(3):355-62. [Rec#: 9764] Exclude at abstract screening: useful only for background. [pmid: 12943142].
Brescia F J. Pain management issues as part of the comprehensive care of the cancer patient. Semin Oncol. 93;20(2 Suppl 1):48-52. [Rec#: 9767] Exclude at abstract screening: no outcomes specified. [pmid: 7682730].
Bressler L R, Geraci M C, Schatz B S. Misperceptions and inadequate pain management in cancer patients. DICP. 91;25(11):1225-30. [Rec#: 9770] Exclude at abstract screening: no outcomes specified. [pmid: 1722370].
Brett A S, Jersild P. “Inappropriate” treatment near the end of life: conflict between religious convictions and clinical judgment. Archives of Internal Medicine. 2003;163(14):1645-9. [Rec#: 50240] Exclude at abstract screening: no outcomes specified. [pmid: 12885678].
Bricker L J, Lambing A, Markey C. Enhancing communication for end-of-life care: an electronic advance directive process. J Palliat Med. 2003;6(3):511-9. [Rec#: 9778] Exclude at abstract screening: no outcomes specified. [pmid: 14509500].
Bridges-Webb C, Wolk J, Britt H, Pond D. The management of dementia in general practice. A field test of guidelines. Aust Fam Physician. 2003;32(4):283-5. [Rec#: 50008] Exclude at abstract screening: not about end of life. [pmid: 12735272].
Briggs L, Colvin E. The nurse's role in end-of-life decision-making for patients and families. Geriatr Nurs. 2002;23(6):302-10. [Rec#: 9782] Exclude at abstract screening: no outcomes specified. [pmid: 12494001].
Briggs, M. and Nelson, E. A. Topical agents or dressings for pain in venous leg ulcers. Cochrane Database of Systematic Reviews 2003;(1):CD001177. [Rec#: 50241] Exclude at abstract screening: not about end of life
Brinson S V, Brunk Q. Hospice family caregivers: an experience in coping. Hosp J. 2000;15(3):1-12. [Rec#: 801] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11249379].
BrintzenhofeSzoc K M, Smith E D, Zabora J R. Screening to predict complicated grief in spouses of cancer patients. Cancer Pract. 99;7(5):233-9. [Rec#: 802] Exclude at abstract screening: Bereavement only. [pmid: 10687592].
Broback G, Bertero C. How next of kin experience palliative care of relatives at home. Eur J Cancer Care (Engl). 2003;12(4):339-46. [Rec#: 807] Exclude at abstract screening: Study Design - Qualitative. [pmid: 14982313].
Brock C, Simpson W M. Dementia, depression, or grief? The differential diagnosis. Geriatrics. 90;45(10):37-43. [Rec#: 808] Exclude at abstract screening: Non-systematic review. [pmid: 2210392].
Brock D B, Foley D J. Demography and epidemiology of dying in the U.S. with emphasis on deaths of older persons. Hosp J. 98;13(12):49-60. [Rec#: 809] Exclude at abstract screening: useful only for background.
Brockopp D Y, Warden S, Colclough G, Brockopp G. Elderly hospice patients' perspective on pain management. Hosp J. 96;11(3):41-53. [Rec#: 813] Exclude at abstract screening: Study Design - Qualitative. [pmid: 8920314].
Brodaty H, McGilchrist C, Harris L, Peters K E. Time until institutionalization and death in patients with dementia. Role of caregiver training and risk factors. Arch Neurol. 93;50(6):643-50. [Rec#: 814] Exclude at abstract screening: primarily prognosis or trajectories.
Brodaty H, Green A, Koschera A. Meta-analysis of psychosocial interventions for caregivers of people with dementia. Journal of the American Geriatric Society. 2003;51(5):657-64. [Rec#: 50242] Exclude at abstract screening: not about end of life.
Brodeur D. Redefining long-term care, personal choices and “futile care”. J Long Term Care Adm 93;21(3):78–80. Comment on: J Long Term Care Adm. 1993 Fall;21(3):66–74. PMID: 10133933. [Rec#: 9791] Exclude at abstract screening: Title Only
Brody H, Campbell M L, Faber-Langendoen K, Ogle K S. Withdrawing intensive life-sustaining treatment -- recommendations for compassionate clinical management. New England Journal of Medicine. 97;336(9):652-7. [Rec#: 50243] Exclude at abstract screening: Title Only.
Bromberg M H, Higginson I. Bereavement follow-up: what do palliative support teams actually do?. J Palliat Care. 96;12(1):12-7. [Rec#: 820] Exclude at abstract screening: Bereavement only. [pmid: 8857242].
Brooks D J, Gamble W, Ahmedzai S. A regional survey of opioid use by patients receiving specialist palliative care. Palliat Med. 95;9(3):229-38. [Rec#: 825] Exclude at abstract screening: Other topic only. [pmid: 7582179].
Brooks R G, Hardy M, Moseley R, Myrick J, Jones A. Advancing End-of-Life Care: lessons learned from a statewide panel. J Palliat Med. 2003;6(5):821-9. [Rec#: 9802] Exclude at abstract screening: not about end of life. [pmid: 14622469].
Broomhead A, Kerr R, Tester W, O'Meara P, Maccarrone C, Bowles R, Hodsman P. Comparison of a once-a-day sustained-release morphine formulation with standard oral morphine treatment for cancer pain. J Pain Symptom Manage. 97;14(2):63-73. [Rec#: 827] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Brophy J M, Deslauriers G, Boucher B, Rouleau J L. The hospital course and short term prognosis of patients presenting to the emergency room with decompensated congestive heart failure. Can J Cardiol. 93;9(3):219-24. [Rec#: 30656] Exclude at abstract screening: primarily prognosis or trajectories.
Brown AE, McDaniel JL, and Birx EC. Stressors, needs, and resources: what AIDS home caregivers have to say. Caring 95;14(4):60–1, 63–4. [Rec#: 9807] Exclude at abstract screening: Study Design - Unclear
Brown C. Limiting care: is CPR for everyone?. AACN Clin Issues Crit Care Nurs. 90;1(1):161-8. [Rec#: 9809] Exclude at abstract screening: no outcomes specified. [pmid: 2357436].
Brown J B, Sangster M, Swift J. Factors influencing palliative care. Qualitative study of family physicians' practices. Can Fam Physician. 98;44:1028-34. [Rec#: 843] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Brown M. Participating in end of life decisions. The role of general practitioners. Aust Fam Physician. 2002;31(1):60-2. [Rec#: 849] Exclude at abstract screening: not about end of life. [pmid: 11840892].
Brown M A, Stetz K. The labor of caregiving: a theoretical model of caregiving during potentially fatal illness. Qual Health Res. 99;9(2):182-97. [Rec#: 855] Exclude at abstract screening: Study Design - Qualitative.
Brown P, Davies B, Martens N. Families in supportive care--Part II: Palliative care at home: a viable care setting. J Palliat Care. 90;6(3):21-7. [Rec#: 9821] Exclude at abstract screening: Study Design - Qualitative.
Brown S and Degner LF. Delirium in the terminally-ill cancer patient: aetiology, symptoms and management. Int J Palliat Nurs 2001;7(6):266–8, 270–2. [Rec#: 9824] Exclude at abstract screening: useful only for background
Brown ST, Blacker S, Walsh-Burke K, Christ GH, Altilio T. Care at the End of Life. 2001;<25 Page(s)>. [Rec#: 50245] Exclude at abstract screening: Title Only
Bruera E, Beattie-Palmer L N. Pharmacologic management of nonpain symptoms in surgical patients. Surg Oncol Clin N Am. 2001;10(1):89-107. [Rec#: 9835] Exclude at abstract screening: no outcomes specified. [pmid: 11406453].
Bruera E, Lawlor P. Defining palliative care interventions. J Palliat Care. 98;14(2):23-4. [Rec#: 9838] Exclude at abstract screening: Title Only. [pmid: 9686492].
Bruera E, Neumann C M. Respective limits of palliative care and oncology in the supportive care of cancer patients. Support Care Cancer. 99;7(5):321-7. [Rec#: 9841] Exclude at abstract screening: useful only for background.
Bruera E, Sweeney C. Palliative care models: international perspective. J Palliat Med. 2002;5(2):319-27. [Rec#: 9848] Exclude at abstract screening: useful only for background. [pmid: 12006235].
Bruera E, Sweeney C. The development of palliative care at the University of Texas M.D. Anderson Cancer Center. Support Care Cancer. 2001;9(5):330-4. [Rec#: 9847] Exclude at abstract screening: Title Only. [pmid: 11497385].
Bruera E, Miller L, McCallion J, Macmillan K, Krefting L, Hanson J. Cognitive failure in patients with terminal cancer: a prospective study. J Pain Symptom Manage. 92;7(4):192-5. [Rec#: 869] In abstract review process. [pmid: 1517640].
Bruera E, Neumann C, Brenneis C, Quan H. Frequency of symptom distress and poor prognostic indicators in palliative cancer patients admitted to a tertiary palliative care unit, hospices, and acute care hospitals. J Palliat Care. 2000;16(3):16-21. [Rec#: 871] Exclude at abstract screening: no outcomes specified. [pmid: 11019503].
Bruera E, Neumann C M, Mazzocato C, Stiefel F, Sala R. Attitudes and beliefs of palliative care physicians regarding communication with terminally ill cancer patients. Palliat Med. 2000;14(4):287-98. [Rec#: 9843] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10974980].
Bruera E, Neumann C M, Pituskin E, Calder K, Ball G, Hanson J. Thalidomide in patients with cachexia due to terminal cancer: preliminary report. Ann Oncol. 99;10(7):857-9. [Rec#: 872] Exclude at abstract screening: Title Only. [pmid: 10470435].
Bruera E, Palmer J L, Bosnjak S, Rico M A, Moyano J, Sweeney C, Strasser F, Willey J, Bertolino M, Mathias C, Spruyt O, Fisch M J. Methadone versus morphine as a first-line strong opioid for cancer pain: a randomized, double-blind study. J Clin Oncol. 2004;22(1):185-92. [Rec#: 874] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 14701781].
Bruera E, Russell N, Sweeney C, Fisch M, Palmer J L. Place of death and its predictors for local patients registered at a comprehensive cancer center. J Clin Oncol. 2002;20(8):2127-33. [Rec#: 9845] Exclude at abstract screening: Other topic only. [pmid: 11956274].
Bruera E, Schoeller T, MacEachern T. Symptomatic benefit of supplemental oxygen in hypoxemic patients with terminal cancer: the use of the N of 1 randomized controlled trial. J Pain Symptom Manage. 92;7(6):365-8. [Rec#: 876] Exclude at abstract screening: Observational study.
Bruera E, Suarez-Almazor M, Velasco A, Bertolino M, MacDonald S M, Hanson J. The assessment of constipation in terminal cancer patients admitted to a palliative care unit: a retrospective review. J Pain Symptom Manage. 94;9(8):515-9. [Rec#: 878] Exclude at abstract screening: Other topic only.
Bruera E, Sweeney C, Russell N, Willey J S, Palmer J L. Place of death of Houston area residents with cancer over a two-year period. J Pain Symptom Manage. 2003;26(1):637-43. [Rec#: 880] Exclude at abstract screening: Other topic only. [pmid: 12850646].
Bruera E. Ambulatory infusion devices in the continuing care of patients with advanced diseases. J Pain Symptom Manage. 90;5(5):287-96. [Rec#: 9831] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Bruera E. Issues of symptom control in patients with advanced cancer. Am J Hosp Palliat Care. 93;10(2):12-8. discussion 19–22. [Rec#: 9833] Exclude at abstract screening: Title Only. [pmid: 7509613].
Bruera E. Palliative care in Latin America. J Pain Symptom Manage. 93;8(6):365-8. [Rec#: 9834] Exclude at abstract screening: useful only for background. [pmid: 7525752].
Bruera E, Castro M. Cannabinoids in supportive care: are they necessary?. Supportive Care in Cancer. 2003;11(3):133-4. [Rec#: 50260] Exclude at abstract screening: Title Only. [pmid: 12618920].
Bruera E, Lawlor P. Cancer pain management. Acta Anaesthesiologica Scandinavica. 97;41(1 Pt 2):146-53. [Rec#: 50272] Exclude at abstract screening: no outcomes specified. [pmid: 9061098].
Bruera E, MacDonald N. Intractable pain in patients with advanced head and neck tumors: a possible role of local infection. Cancer Treatment Reports. 86;70(5):691-2. [Rec#: 50274] Exclude at abstract screening: Title Only. [pmid: 3708626].
Bruera, E. and MacDonald, R. N. Asthenia in patients with advanced cancer. Issues in symptom control. Part 1.[erratum appears in Journal of Pain and Symptom Management 1988 Fall;3(4):211]. Journal of Pain & Symptom Management 88;3(1):9–14. [Rec#: 50275] Exclude at abstract screening: Study Design - Unclear
Bruera E, Miller M J. Non-cardiogenic pulmonary edema after narcotic treatment for cancer pain. Pain. 89;39(3):297-300. [Rec#: 50287] Exclude at abstract screening: Observational study. [pmid: 2616181].
Bruera E, Neumann C M. Management of specific symptom complexes in patients receiving palliative care. CMAJ Canadian Medical Association Journal. 98;158(13):1717-26. [Rec#: 50290] Exclude at abstract screening: no outcomes specified.
Bruera E, Neumann C M. Role of methadone in the management of pain in cancer patients. Oncology (Huntington). 1291;13(9):1275-82. discussion 1285–8. [Rec#: 50291] Exclude at abstract screening: no outcomes specified.
Bruera E, Neumann C M. The uses of psychotropics in symptom management in advanced cancer. Psycho-Oncology. 98;7:346-58. [Rec#: 50292] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Bruera E, Suarez-Almazor M. Cost effectiveness in palliative care. Palliative Medicine. 98;12(5):315-6. [Rec#: 50301] Exclude at abstract screening: Title Only. [pmid: 9924594].
Bruera E, Sweeney C. Methadone use in cancer patients with pain: a review. Journal of Palliative Medicine. 2002;5(1):127-38. [Rec#: 50302] Exclude at abstract screening: Study Design - Unclear. [pmid: 11839235].
Bruera E, Watanabe S. Psychostimulants as adjuvant analgesics. Journal of Pain & Symptom Management. 94;9(6):412-5. [Rec#: 50304] Exclude at abstract screening: not about end of life. [pmid: 7963794].
Bruera E D, Chadwick S, Bacovsky R, Macdonald N. Continuous subcutaneous infusion of narcotics using a portable disposable pump. Journal of Palliative Care. 85;1(1):46-7. [Rec#: 50307] Exclude at abstract screening: not about end of life.
Bruera E, Belzile M, Pituskin E, Fainsinger R, Darke A, Harsanyi Z, Babul N, Ford I. Randomized, double-blind, cross-over trial comparing safety and efficacy of oral controlled-release oxycodone with controlled-release morphine in patients with cancer pain. Journal of Clinical Oncology. 98;16(10):3222-9. [Rec#: 50247] Exclude at abstract screening: not about end of life.
Bruera E, Brenneis C, MacDonald R N. Continuous Sc infusion of narcotics for the treatment of cancer pain: an update. Cancer Treatment Reports. 87;71(10):953-8. [Rec#: 50248] Exclude at abstract screening: Title Only. [pmid: 2443242].
Bruera E, Brenneis C, Michaud M, MacDonald R N. Influence of the pain and symptom control team (PSCT) on the patterns of treatment of pain and other symptoms in a cancer center. Journal of Pain & Symptom Management. 89;4(3):112-6. [Rec#: 50252] Exclude at abstract screening: data older than 1990.
Bruera E, Brenneis C, Michaud M, Jackson P I, MacDonald R N. Muscle electrophysiology in patients with advanced breast cancer. Journal of the National Cancer Institute. 88;80(4):282-5. [Rec#: 50251] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Bruera E, Brenneis C, Michaud M, Rafter J, Magnan A, Tennant A, Hanson J, Macdonald R N. Association between asthenia and nutritional status, lean body mass, anemia, psychological status, and tumor mass in patients with advanced breast cancer. Journal of Pain & Symptom Management. 89;4(2):59-63. [Rec#: 50254] Exclude at abstract screening: Study Design - Unclear.
Bruera E, Brenneis C, Michaud M, Rafter J, Magnan A, Tennant A, Hanson J, MacDonald R N. Asthenia in breast cancer. AJN, American Journal of Nursing. 89;89(5):737-8. [Rec#: 50255] Exclude at abstract screening: Title Only.
Bruera E, Brenneis C, Paterson A H, MacDonald R N. Narcotics plus methylphenidate (Ritalin) for advanced cancer pain. AJN, American Journal of Nursing. 88;88(11):1555-6. [Rec#: 50256] Exclude at abstract screening: Title Only.
Bruera E, Brenneis C, Paterson A H, MacDonald R N. Use of methylphenidate as an adjuvant to narcotic analgesics in patients with advanced cancer. Journal of Pain & Symptom Management. 89;4(1):3-6. [Rec#: 50257] Exclude at abstract screening: Study Design - Unclear.
Bruera E, Chadwick S, Weinlick A, MacDonald N. Delirium and severe sedation in patients with terminal cancer. Cancer Treatment Reports. 87;71(78):787-8. [Rec#: 50262] Exclude at abstract screening: Title Only. [pmid: 3607791].
Bruera E, Fainsinger R L, Miller M J, Kuehn N. The assessment of pain intensity in patients with cognitive failure: a preliminary report. Journal of Pain & Symptom Management. 92;7(5):267-70. [Rec#: 50267] Exclude at abstract screening: Observational study.
Bruera E, Fainsinger R L, Schoeller T, Ripamonti C. Rapid discontinuation of hypnotics in terminal cancer patients: a prospective study. Annals of Oncology. 96;7(8):855-6. [Rec#: 50268] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Bruera E, Fainsinger R, Moore M, Thibault R, Spoldi E, Ventafridda V. Local toxicity with subcutaneous methadone. Experience of two centers. Pain. 91;45(2):141-3. [Rec#: 50264] Exclude at abstract screening: Observational study.
Bruera E, Fainsinger R, Spachynski K, Babul N, Harsanyi Z, Darke A C. Clinical efficacy and safety of a novel controlled-release morphine suppository and subcutaneous morphine in cancer pain: a randomized evaluation. Journal of Clinical Oncology. 95;13(6):1520-7. [Rec#: 50265] Exclude at abstract screening: not about end of life.
Bruera E, Fainsinger R, Spachynski K, Babul N, Harsanyi Z, Darke A C. Steady-state pharmacokinetic evaluation of a novel, controlled-release morphine suppository and subcutaneous morphine in cancer pain. Journal of Clinical Pharmacology. 95;35(7):666-72. [Rec#: 50266] Exclude at abstract screening: not about end of life.
Bruera E, Fox R, Chadwick S, Brenneis C, MacDonald N. Changing pattern in the treatment of pain and other symptoms in advanced cancer patients. Journal of Pain & Symptom Management. 87;2(3):139-44. [Rec#: 50269] Exclude at abstract screening: Study Design - Unclear.
Bruera E, Franco J J, Maltoni M, Watanabe S, Suarez-Almazor M. Changing pattern of agitated impaired mental status in patients with advanced cancer: association with cognitive monitoring, hydration, and opioid rotation. Journal of Pain & Symptom Management. 95;10(4):287-91. [Rec#: 50270] Exclude at abstract screening: Study Design - Unclear.
Bruera E, Gibney N, Stollery D, Marcushamer S. Use of the subcutaneous route of administration of morphine in the intensive care unit. Journal of Pain & Symptom Management. 91;6(4):263-5. [Rec#: 50271] Exclude at abstract screening: Observational study.
Bruera E, Legris M A, Kuehn N, Miller M J. Hypodermoclysis for the administration of fluids and narcotic analgesics in patients with advanced cancer. Journal of the National Cancer Institute. 89;81(14):1108-9. [Rec#: 50273] Exclude at abstract screening: Title Only.
Bruera E, MacEachern T, Macmillan K, Miller M J, Hanson J. Local tolerance to subcutaneous infusions of high concentrations of hydromorphone: a prospective study. Journal of Pain & Symptom Management. 93;8(4):201-4. [Rec#: 50276] Exclude at abstract screening: Observational study.
Bruera E, MacMillan K, Hanson J, MacDonald R N. The Edmonton injector: a simple device for patient-controlled subcutaneous analgesia. Pain. 91;44(2):167-9. [Rec#: 50278] Exclude at abstract screening: Observational study.
Bruera E, Macmillan K, Kuehn N, Hanson J, MacDonald R N. A controlled trial of megestrol acetate on appetite, caloric intake, nutritional status, and other symptoms in patients with advanced cancer. Cancer. 90;66(6):1279-82. [Rec#: 50280] Exclude at abstract screening: Other symptoms only.
Bruera E, Macmillan K, Kuehn N, Moore M, Bliss A. Evaluation of a spring-loaded syringe driver for the subcutaneous administration of narcotics. Journal of Pain & Symptom Management. 91;6(3):115-8. [Rec#: 50282] Exclude at abstract screening: Observational study.
Bruera E, Macmillan K, Pither J, MacDonald R N. Effects of morphine on the dyspnea of terminal cancer patients. Journal of Pain & Symptom Management. 90;5(6):341-4. [Rec#: 50283] Exclude at abstract screening: Observational study.
Bruera E, Macmillan K, Selmser P, MacDonald R N. Decreased local toxicity with subcutaneous diamorphine (heroin): a preliminary report. Pain. 90;43(1):91-4. [Rec#: 50284] Exclude at abstract screening: Observational study.
Bruera E, Martinez-Garcia M, Sweeney C, Palmer L. Re: Perception of discomfort among relatives of unresponsive terminally ill patients. Journal of Palliative Care. 2000;16(4):59-60. [Rec#: 50285] Exclude at abstract screening: Study Design - Unclear. [pmid: 11965938].
Bruera E, Navigante A, Barugel M, Macmillan K, MacDonald R N, Chacon R. Treatment of pain and other symptoms in cancer patients: patterns in a North American and a South American hospital. Journal of Pain & Symptom Management. 90;5(2):78-82. [Rec#: 50289] Exclude at abstract screening: Study Design - Unclear.
Bruera E, Pereira J, Watanabe S, Belzile M, Kuehn N, Hanson J. Opioid rotation in patients with cancer pain. A retrospective comparison of dose ratios between methadone, hydromorphone, and morphine. Cancer. 96;78(4):852-7. [Rec#: 50293] Exclude at abstract screening: Other topic only.
Bruera E, Schoeller T, Montejo G. Organic hallucinosis in patients receiving high doses of opiates for cancer pain. Pain. 92;48(3):397-9. [Rec#: 50297] Exclude at abstract screening: Observational study.
Bruera E, Schoeller T, Fainsinger R L, Kastelan C. Custom-made suppositories of methadone for severe cancer pain. Journal of Pain & Symptom Management. 92;7(6):372-4. [Rec#: 50296] Exclude at abstract screening: Study Design - Unclear.
Bruera E, Schoeller T, Wenk R, MacEachern T, Marcelino S, Hanson J, Suarez-Almazor M. A prospective multicenter assessment of the Edmonton staging system for cancer pain. Journal of Pain & Symptom Management. 95;10(5):348-55. [Rec#: 50298] Exclude at abstract screening: not about end of life.
Bruera E, Spachynski K, MacEachern T, Hanson J. Cognitive failure in cancer patients in clinical trials. Lancet. 93;341(8839):247-8. [Rec#: 50299] Exclude at abstract screening: Title Only. [pmid: 8093535].
Bruera E, Strasser F, Palmer J L, Willey J, Calder K, Amyotte G, Baracos V. Effect of fish oil on appetite and other symptoms in patients with advanced cancer and anorexia/cachexia: a double-blind, placebo-controlled study. Journal of Clinical Oncology. 2003;21(1):129-34. [Rec#: 50300] Exclude at abstract screening: Other topic only. [pmid: 12506181].
Bruera E, Sweeney C, Willey J, Palmer J L, Tolley S, Rosales M, Ripamonti C. Breast cancer patient perception of the helpfulness of a prompt sheet versus a general information sheet during outpatient consultation: a randomized, controlled trial. Journal of Pain & Symptom Management. 2003;25(5):412-9. [Rec#: 50303] Exclude at abstract screening: not about end of life. [pmid: 12727038].
Brugha TS. Depression in the terminally ill. Br J Hosp Med 93;50(4):175, 177–81. [Rec#: 9849] Exclude at abstract screening: Non-systematic review
Brumley R D. Future of end-of-life care: the managed care organization perspective. J Palliat Med. 2002;5(2):263-70. [Rec#: 884] Exclude at abstract screening: Title Only. [pmid: 12006228].
Brummel-Smith K, London M R, Drew N, Krulewitch H, Singer C, Hanson L. Outcomes of pain in frail older adults with dementia. J Am Geriatr Soc. 2002;50(11):1847-51. [Rec#: 50009] Exclude at abstract screening: not about end of life. [pmid: 12410905].
Brundage M D, Feldman-Stewart D, Cosby R, Gregg R, Dixon P, Youssef Y, Mackillop W J. Cancer patients' attitudes toward treatment options for advanced non-small cell lung cancer: implications for patient education and decision support. Patient Educ Couns. 2001;45(2):149-57. [Rec#: 886] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 11687329].
Brundage M, Leis A, Bezjak A, Feldman-Stewart D, Degner L, Velji K, Zetes-Zanatta L, Tu D, Ritvo P, Pater J. Cancer patients' preferences for communicating clinical trial quality of life information: a qualitative study. Quality of Life Research. 2003;12(4):395-404. [Rec#: 50308] Exclude at abstract screening: not about end of life. [pmid: 12797712].
Bruner D W. Cost-effectiveness and palliative care. Semin Oncol Nurs. 98;14(2):164-7. [Rec#: 9853] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 9580941].
Brusamolino E, Surbone A. Telling the truth to the patient with cancer. A cross-cultural dialogue. Ann N Y Acad Sci. 97;809:411-21. [Rec#: 9854] Exclude at abstract screening: Title Only. [pmid: 9103592].
Brushwood D B. From confrontation to collaboration: collegial accountability and the expanding role of pharmacists in the management of chronic pain. J Law Med Ethics. 2001;29(1):69-93. [Rec#: 9855] Exclude at abstract screening: Title Only. [pmid: 11521273].
Brushwood D B. Maximizing the value of electronic prescription monitoring programs. J Law Med Ethics. 2003;31(1):41-54. [Rec#: 9856] Exclude at abstract screening: not about end of life. [pmid: 12762101].
Buccheri G F, Ferrigno D, Tamburini M, Brunelli C. The patient's perception of his own quality of life might have an adjunctive prognostic significance in lung cancer. Lung Cancer. 95;12(12):45-58. [Rec#: 30694] Exclude at abstract screening: primarily prognosis or trajectories.
Buchanan A, Tan R S. Congestive heart failure in elderly patients. The treatment goal is improved quality, not quantity, of life. Postgrad Med 97;102(4):207–8, 211–5. Comment in: Postgrad Med. Feb. 1998;103(2):25-6. PMID: 9479305. [Rec#: 30696] Exclude at abstract screening: no outcomes specified.
Buchanan R J. Medicaid policies for the hospice care needed by people with Alzheimer's disease. J Health Hum Serv Adm. 98;20(3):348-88. [Rec#: 896] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Buchman T G, Cassell J, Ray S E, Wax M L. Who should manage the dying patient?: Rescue, shame, and the surgical ICU dilemma. J Am Coll Surg. 2002;194(5):665-73. [Rec#: 9863] Exclude at abstract screening: Title Only. [pmid: 12022609].
Buchman T G, Ray S E, Wax M L, Cassell J, Rich D, Niemczycki M A. Families' perceptions of surgical intensive care. J Am Coll Surg. 2003;196(6):977-83. [Rec#: 9864] Exclude at abstract screening: Title Only. [pmid: 12788436].
Buck J. Home hospice versus home health: cooperation, competition, and cooptation. Nurs Hist Rev. 2004;12:25-46. [Rec#: 9866] Exclude at abstract screening: Title Only. [pmid: 14608846].
Buckle S. Aromatherapy and massage: the evidence. Paediatr Nurs. 2003;15(6):24-7. [Rec#: 9867] Exclude at abstract screening: Title Only. [pmid: 12889317].
Buckle S. Aromatherapy and massage: the evidence. Paediatric Nursing. 2003;15(6):24-7. [Rec#: 50310] Exclude at abstract screening: Title Only. [pmid: 12889317].
Buckley J. Holism and a health-promoting approach to palliative care. Int J Palliat Nurs. 2002;8(10):505-8. [Rec#: 9868] Exclude at abstract screening: no outcomes specified. [pmid: 12419990].
Buckman R. Communication skills in palliative care: a practical guide. Neurol Clin. 2001;19(4):989-1004. [Rec#: 9870] Exclude at abstract screening: not about end of life. [pmid: 11854110].
Buckwalter G L. Addressing the spiritual & religious needs of persons with profound memory loss. Home Healthc Nurse. 2003;21(1):20-4. [Rec#: 9873] Exclude at abstract screening: Title Only. [pmid: 12544458].
Buechner J S. Trends and patterns in place of death, 1989-2000. Med Health R I. 2002;85(9):289-90. [Rec#: 40467] Exclude at abstract screening: Title Only. [pmid: 12371216].
Buehler D A. CQ sources/bibliography. Camb Q Healthc Ethics. 98;7(1):88-9. [Rec#: 9875] Exclude at abstract screening: Title Only. [pmid: 9523044].
Bulkin W, Lukashok H. Training physicians to care for the dying. Am J Hosp Palliat Care. 91;8(2):10-5. [Rec#: 9878] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 1931310].
Bullinger M. Quality of life assessment in palliative care. J Palliat Care. 92;8(3):34-9. [Rec#: 9881] Exclude at abstract screening: Title Only. [pmid: 1279148].
Bunn P A Jr, Kelly K. New chemotherapeutic agents prolong survival and improve quality of life in non-small cell lung cancer: a review of the literature and future directions. Clin Cancer Res. 98;4(5):1087-100. [Rec#: 30714] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Bunn P A Jr. Chemotherapy for advanced non-small-cell lung cancer: who, what, when, why?. J Clin Oncol. 2002;20(18 Suppl):23S-33S. [Rec#: 9888] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 12235221].
Buntin MB and Huskamp H. What is known about the economics of end-of-life care for medicare beneficiaries? Gerontologist 2002;42 Spec No 3:40–8. [Rec#: 913] Exclude at abstract screening: useful only for background
Burack O R, Chichin E R. A support group for nursing assistants: caring for nursing home residents at the end of life. Geriatr Nurs. 2001;22(6):299-305. quiz 306–7. [Rec#: 914] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11780003].
Burch P L, Hunter K A. Pharmaceutical care applied to the hospice setting: a cancer pain model. Hosp J 96;11(3):55–69. Comment in: Hosp J. 1997;12(3):1-3. PMID: 9256683. [Rec#: 9891] Exclude at abstract screening: no outcomes specified.
Burge F, Johnston G, Lawson B, Dewar R, Cummings I. Population-based trends in referral of the elderly to a comprehensive palliative care programme. Palliat Med. 2002;16(3):255-6. [Rec#: 916] Exclude at abstract screening: Title Only. [pmid: 12047004].
Burge F, Lawson B, Johnston G. Trends in the place of death of cancer patients, 1992-1997. CMAJ. 2003;168(3):265-70. [Rec#: 918] Exclude at abstract screening: useful only for background. [pmid: 12566330]. [pmcid: 140467].
Burge F, McIntyre P, Kaufman D, Cummings I, Frager G, and Pollett A. Family Medicine residents' knowledge and attitudes about end-of-life care. J Palliat Care 2000;16(3):5–12. Erratum in: J Palliat Care 2001 Summer:17(2):85. [Rec#: 9896] Exclude at abstract screening: outcome unrelated to pts/family/non-prof
Burge F, McIntyre P, Twohig P, Cummings I, Kaufman D, Frager G, Pollett A. Palliative care by family physicians in the 1990s. Resilience amid reform. Can Fam Physician. 2001;47:1989-95. [Rec#: 920] Exclude at abstract screening: Observational study. [pmid: 11723593]. [pmcid: 2018440].
Burge F. The epidemiology of palliative care in cancer. J Palliat Care. 92;8(1):18-23. [Rec#: 9895] Exclude at abstract screening: Title Only. [pmid: 1583562].
Burge F I. Dehydration and provision of fluids in palliative care. What is the evidence?. Can Fam Physician. 96;42:2383-8. [Rec#: 9897] Exclude at abstract screening: data older than 1990. [pmid: 8969857].
Burge F I. Dehydration symptoms of palliative care cancer patients. J Pain Symptom Manage. 93;8(7):454-64. [Rec#: 921] Exclude at abstract screening: Other symptoms only. [pmid: 7525778].
Burge F I. Medical care of the dying. Where do family physicians fit in?. Can Fam Physician. 95;41:376-8. [Rec#: 9898] Exclude at abstract screening: no outcomes specified. [pmid: 7773023].
Burgess D. Denial and terminal illness. Am J Hosp Palliat Care. 94;11(2):46-8. [Rec#: 9899] Exclude at abstract screening: no outcomes specified. [pmid: 7880638].
Burgess J R, Shepherd J J, Murton F J, Parameswaran V, Greenaway T M. Effective control of bone pain by octreotide in a patient with metastatic gastrinoma. Med J Aust. 96;164(12):725-7. [Rec#: 925] Exclude at abstract screening: Title Only.
Burgio L, Stevens A, Guy D, Roth D L, Haley W E. Impact of two psychosocial interventions on white and African American family caregivers of individuals with dementia. Gerontologist. 2003;43(4):568-79. [Rec#: 50915] In abstract review process. [pmid: 12937335].
Burke C, Gerraughty S M. An oncology unit's initiation of a bereavement support program. Oncol Nurs Forum 94;21(10):1675–80. Comment in: Oncol Nurs Forum. Oct. 1995;22(9):1333. PMID: 8539174. [Rec#: 9900] Exclude at abstract screening: Study Design - Unclear.
Burkett T M, Boone, Smith, Davis, Hurst, Dickman. An Oklahoma perspective: end-of-life decision-making and termination of treatment. J Okla State Med Assoc. 2001;94(8):334-42. [Rec#: 9905] Exclude at abstract screening: no outcomes specified. [pmid: 11515381].
Burman M E, Steffes M, Weinert C. Cancer home care in Montana. Home Health Care Serv Q. 93;14(23):37-52. [Rec#: 9906] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10133718].
Burman R. Generic palliative care. Eur J Cancer Care (Engl). 97;6(1):8-10. [Rec#: 9907] Exclude at abstract screening: no outcomes specified. [pmid: 9238923].
Burnard P. The psychosocial needs of people with HIV and AIDS: a view from nurse educators and counsellors. J Adv Nurs. 93;18(11):1779-86. [Rec#: 9910] Exclude at abstract screening: not about end of life.
Burnett P, Middleton W, Raphael B, Martinek N. Measuring core bereavement phenomena. Psychol Med. 97;27(1):49-57. [Rec#: 932] Exclude at abstract screening: Study Design - Qualitative. [pmid: 9122308].
Burns J P, Edwards J, Johnson J, Cassem N H, Truog R D. Do-not-resuscitate order after 25 years. Crit Care Med 2003;31(5):1543–50. Comment in: Crit Care Med. May. 2003;31(5):1593-5. PMID: 12771647. [Rec#: 9915] Exclude at abstract screening: Non-systematic review.
Burns S. The spirituality of dying. Pastoral care's holistic approach is crucial in hospice. Health Prog 91;72(7):48–52, 54. [Rec#: 9918] Exclude at abstract screening: no outcomes specified
Burns SS. Spiritual care at the end of life. Hospice uses teamwork to address spiritual and physical needs. Health Prog 98;79(3):45–6, 49. [Rec#: 9919] Exclude at abstract screening: Title Only
Burns R B, McCarthy E P, Moskowitz M A, Ash A, Kane R L, Finch M. Outcomes for older men and women with congestive heart failure. Journal of the American Geriatric Society. 97;45(3):276-80. [Rec#: 50311] Exclude at abstract screening: primarily prognosis or trajectories.
Burns R, Nichols L O, Martindale-Adams J, Graney M J, Lummus A. Primary care interventions for dementia caregivers: 2-year outcomes from the REACH study. Gerontologist. 2003;43(4):547-55. [Rec#: 50916] In abstract review process. [pmid: 12937333].
Burrs F A. The African American experience: breaking the barriers to hospices. Hosp J. 95;10(2):15-8. [Rec#: 9923] Exclude at abstract screening: useful only for background. [pmid: 7557930].
Burt R A. The limitations of protocols for end-of-life care. Respir Care. 2000;45(12):1523-9. discussion 1529–33. [Rec#: 9924] Exclude at abstract screening: no outcomes specified. [pmid: 11107218].
Burton L C, German P S, Gruber-Baldini A L, Hebel J R, Zimmerman S, Magaziner J. Medical care for nursing home residents: differences by dementia status. Epidemiology of Dementia in Nursing Homes Research Group. J Am Geriatr Soc. 2001;49(2):142-7. [Rec#: 940] Exclude at abstract screening: Title Only. [pmid: 11207867].
Burton R. Spiritual pain: a brief overview and an initial response within the Christian tradition. J Pastoral Care Counsel. 2003;57(4):437-46. [Rec#: 9928] Exclude at abstract screening: no outcomes specified. [pmid: 14748219].
Bush E. The use of human touch to improve the well-being of older adults. A holistic nursing intervention. J Holist Nurs. 2001;19(3):256-70. [Rec#: 942] Exclude at abstract screening: useful only for background. [pmid: 11847871].
Butcher H K, Holkup P A, Buckwalter K C. The experience of caring for a family member with Alzheimer's disease. West J Nurs Res. 2001;23(1):33-55. [Rec#: 946] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11216023].
Butters E, Higginson I, George R, McCarthy M. Palliative care for people with HIV/AIDS: views of patients, carers and providers. AIDS Care. 93;5(1):105-16. [Rec#: 9940] Exclude at abstract screening: Study Design - Qualitative.
Butters E, Higginson I, Wade A, McCarthy M, George R, Smits A. Community HIV/AIDS teams. Health Trends. 91;23(2):59-62. [Rec#: 50313] Exclude at abstract screening: not about end of life. [pmid: 10116893].
Butterworth A M. Reality check: 10 barriers to advance planning. Nurse Pract. 2003;28(5):42-3. [Rec#: 9941] Exclude at abstract screening: Title Only. [pmid: 12792268].
Butticaz G, Zulian G B, Preumont M, Budtz-Jorgensen E. Evaluation of a nystatin-containing mouth rinse for terminally ill patients in palliative care. J Palliat Care. 2003;19(2):95-9. [Rec#: 951] Exclude at abstract screening: Other symptoms only. [pmid: 12955925].
Byass R. Auditing complementary therapies in palliative care: the experience of the day-care massage service at Mount Edgcumbe Hospice. Complement Ther Nurs Midwifery. 99;5(2):51-60. [Rec#: 9943] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Bylewski C M, Beardi L Y, O'Brien-McKenna A M, Thomas S L. Care-givers' support group: one hospice's approach. Am J Hosp Palliat Care. 90;7(2):44-8. [Rec#: 956] Exclude at abstract screening: data older than 1990.
Byock I, Norris K, Curtis J R, Patrick D L. Improving end-of-life experience and care in the community: a conceptual framework. J Pain Symptom Manage. 2001;22(3):759-72. [Rec#: 9951] Exclude at abstract screening: useful only for background. [pmid: 11532589].
Byock I. Completing the continuum of cancer care: integrating life-prolongation and palliation. CA Cancer J Clin 2000;50(2):123–32. Comment in: CA Cancer J Clin. Mar-Apr. 2000;50(2):68-9. PMID: 10870486. [Rec#: 9944] Exclude at abstract screening: no outcomes specified.
Byock I R, Merriman M P. Measuring quality of life for patients with terminal illness: the Missoula-VITAS quality of life index. Palliat Med. 98;12(4):231-44. [Rec#: 960] Exclude at abstract screening: Study Design - Qualitative.
Byock I R. End-of-life care: a public health crisis and an opportunity for managed care. Am J Manag Care 2001;7(12):1123–32. Comment in: Am J Manag Care. Dec. 2001;7(12):1162-4. PMID: 11767302. [Rec#: 957] Exclude at abstract screening: no outcomes specified.
Byock I R. The nature of suffering and the nature of opportunity at the end of life. Clin Geriatr Med. 96;12(2):237-52. [Rec#: 50859] Exclude at abstract screening: no outcomes specified. [pmid: 8799345].
Byock I R, Teno J M, Field M J. Measuring quality of care at life's end. Journal of Pain & Symptom Management. 99;17(2):73-4. [Rec#: 50314] Exclude at abstract screening: Title Only.
Byrd L. Terminal dementia in the elderly Awareness leads to more appropriate care. Adv Nurse Pract. 2003;11(9):65-8. [Rec#: 961] Exclude at abstract screening: Title Only. [pmid: 14521110].
Byrne G J, Raphael B. A longitudinal study of bereavement phenomena in recently widowed elderly men. Psychol Med. 94;24(2):411-21. [Rec#: 964] Exclude at abstract screening: Title Only. [pmid: 8084936].
Byrne G J, Raphael B. Depressive symptoms and depressive episodes in recently widowed older men. Int Psychogeriatr. 99;11(1):67-74. [Rec#: 963] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Byrne G J, Raphael B, Arnold E. Alcohol consumption and psychological distress in recently widowed older men. Aust N Z J Psychiatry. 99;33(5):740-7. [Rec#: 966] Exclude at abstract screening: not about end of life.
Byszewski A M, Graham I D, Amos S, Man-Son-Hing M, Dalziel W B, Marshall S, Hunt L, Bush C, Guzman D. A continuing medical education initiative for canadian primary care physicians: the driving and dementia toolkit: a pre- and postevaluation of knowledge, confidence gained, and satisfaction. J Am Geriatr Soc. 2003;51(10):1484-9. [Rec#: 9959] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14511173].
Cable D G. Caring for the terminally ill: communicating with patients and family. Henry Ford Hosp Med J. 91;39(2):85-8. [Rec#: 9961] Exclude at abstract screening: no outcomes specified. [pmid: 1890013].
Cadd A, Keatinge D, Henssen M, O'Brien L, Parker D, Rohr Y, Schneider J, Thompson J. Assessment and documentation of bowel care management in palliative care: incorporating patient preferences into the care regimen. J Clin Nurs. 2000;9(2):228-35. [Rec#: 969] Exclude at abstract screening: not about end of life. [pmid: 11111614].
Caddow P and Grayson G. A team to ensure sensitive continuing care. Setting up a symptom control/support team. Prof Nurse 92;7(11):719–20, 722–4. [Rec#: 9962] Exclude at abstract screening: no outcomes specified
Cain J, Stacy L, Jusenius K, Figge D. The quality of dying: financial, psychological, and ethical dilemmas. Obstet Gynecol. 90;76(1):149-52. [Rec#: 9964] Exclude at abstract screening: no outcomes specified.
Cain J M, Hammes B J. Ethics and pain management: respecting patient wishes. J Pain Symptom Manage. 94;9(3):160-5. [Rec#: 9968] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Cain J M. Practical aspects of hospice care at home. Best Pract Res Clin Obstet Gynaecol. 2001;15(2):305-11. [Rec#: 9966] Exclude at abstract screening: no outcomes specified. [pmid: 11358404].
Cairns A B. Spirituality and religiosity in palliative care. Home Healthc Nurse. 99;17(7):450-5. [Rec#: 9969] Exclude at abstract screening: no outcomes specified. [pmid: 10562032].
Calam B, Far S, Andrew R. Discussions of “code status” on a family practice teaching ward: what barriers do family physicians face?. CMAJ. 2000;163(10):1255-9. [Rec#: 9974] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11107460]. [pmcid: 80314].
Calder K, Glajchen M, Blum D. Patient advocacy in cancer pain relief: the Cancer Care model. J Pain Symptom Manage. 93;8(6):381-4. [Rec#: 9975] Exclude at abstract screening: Title Only. [pmid: 7525756].
Caldwell J, Scott J P. Effective hospice volunteers: demographic and personality characteristics. Am J Hosp Palliat Care. 94;11(2):40-5. [Rec#: 976] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Califf R M, Vidaillet H, Goldman L. Advanced congestive heart failure: What do patients want?. Am Heart J. 98;135(6 Pt 2 Su):S320-6. [Rec#: 30759] Exclude at abstract screening: no outcomes specified. [pmid: 9630094].
Calkins D R, Davis R B, Reiley P, Phillips R S, Pineo K L, Delbanco T L, Iezzoni L I. Patient-physician communication at hospital discharge and patients' understanding of the postdischarge treatment plan. Archives of Internal Medicine. 97;157(9):1026-30. [Rec#: 50315] Exclude at abstract screening: not about end of life.
Callahan D and Parens E. The ends of medicine: shaping new goals. Bull N Y Acad Med 95;72(1):95–117. Comment in: Bull N Y Acad Med. 1995 Winter;72(2):540–1. PMID: 10101389. [Rec#: 9990] Exclude at abstract screening: Title Only
Callahan D. International perspectives. Hastings Cent Rep. 98;28(1):45-6. [Rec#: 9986] Exclude at abstract screening: Title Only. [pmid: 11645052].
Callahan D. Necessity, futility, and the good society. J Am Geriatr Soc. 94;42(8):866-7. [Rec#: 9987] Exclude at abstract screening: no outcomes specified. [pmid: 8046196].
Callahan D. Terminating life-sustaining treatment of the demented. Hastings Cent Rep. 95;25(6):25-31. [Rec#: 9989] Exclude at abstract screening: Title Only. [pmid: 8609015].
Callahan H E. Families dealing with advanced heart failure: a challenge and an opportunity. Crit Care Nurs Q. 2003;26(3):230-43. [Rec#: 30764] Exclude at abstract screening: no outcomes specified. [pmid: 12930039].
Callanan M. Dealing with death. Farewell messages Am J Nurs 94;94(5):19–20. Comment in: Am J Nurs. Aug. 1994;94(8):19. PMID: 8093176. [Rec#: 9994] Exclude at abstract screening: Title Only.
Camberg L C Smith N E Beaudet M Daley J Cagan M Thibault G Discharge destination and repeat hospitalizations Med Care9735 8 756 67 [Rec#: 50010] Exclude at abstract screening: data older than 1990 9268249
Campagnutta E, Cannizzaro R, Gallo A, Zarrelli A, Valentini M, De Cicco M, Scarabelli C. Palliative treatment of upper intestinal obstruction by gynecological malignancy: the usefulness of percutaneous endoscopic gastrostomy. Gynecol Oncol. 96;62(1):103-5. [Rec#: 989] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Campbell D E, Lynn J, Louis T A, Shugarman L R. Medicare program expenditures associated with hospice use. Ann Intern Med. 2004;140(4):269-77. [Rec#: 992] Exclude at abstract screening: useful only for background. [pmid: 14970150].
Campbell M L, Carlson R W. Terminal weaning from mechanical ventilation: ethical and practical considerations for patient management. Am J Crit Care. 92;1(3):52-6. [Rec#: 10013] Exclude at abstract screening: no outcomes specified.
Campbell M L, Field B E. Management of the patient with do not resuscitate status: compassion and cost containment. Heart Lung. 91;20(4):345-8. [Rec#: 998] Exclude at abstract screening: Study Design - Unclear.
Campbell M L, Hoyt J W, Nelson L J. HealthCare Ethics Forum '94: perspectives on withholding and withdrawal of life-support. AACN Clin Issues Crit Care Nurs. 94;5(3):353-9. [Rec#: 10014] Exclude at abstract screening: Title Only.
Campbell M L. Managing terminal dyspnea: caring for the patient who refuses intubation or ventilation. Dimens Crit Care Nurs. 96;15(1):4-12. quiz 13. [Rec#: 10009] Exclude at abstract screening: no outcomes specified.
Campbell M L. Program assessment through outcomes analysis: efficacy of a comprehensive supportive care team for end-of-life care. AACN Clin Issues. 96;7(1):159-67. [Rec#: 10010] Exclude at abstract screening: Study Design - Unclear.
Campbell T, Draper S, Reid J, Robinson L. The management of constipation in people with advanced cancer. Int J Palliat Nurs. 2001;7(3):110-9. [Rec#: 10016] Exclude at abstract screening: no outcomes specified. [pmid: 12192327].
Campbell W B. Non-intervention and palliative care in vascular patients. Br J Surg. 2000;87(12):1601-2. [Rec#: 10017] Exclude at abstract screening: no outcomes specified. [pmid: 11122169].
Campbell F A, Tramer M R, Carroll D, Reynolds D J, Moore R A, McQuay H J. Are cannabinoids an effective and safe treatment option in the management of pain? A qualitative systematic review. BMJ. 2001;323(7303):13-6. [Rec#: 50117] Exclude at abstract screening: Non-systematic review. [pmid: 11440935]. [pmcid: 34324].
Campbell M L, Carlson R W. Impact of patient consciousness on the intensity of the DNR therapeutic plan. American Journal of Critical Care. 92;5:339-45. [Rec#: 50317] Exclude at abstract screening: Title Only. [pmid: 8870857].
Campbell M L, Frank R R. Experience with an end-of-life practice at a university hospital. Critical Care Medicine. 97;25(1):197-202. [Rec#: 50318] Exclude at abstract screening: Other topic only. [pmid: 8989198].
Campbell, M. Managing terminal dyspnea: caring for the patient who refuses intubation or ventilation. Dimensions in Critical Care Nursing 96;15(4–13). [Rec#: 50316] Exclude at abstract screening: Title Only
Campora E, Naso C, Vitullo M T, Giudici S, Camoirano A, Repetto L, Rosso R. The impact of chemotherapy on the quality of life of breast cancer patients. J Chemother. 92;4(1):59-63. [Rec#: 1002] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Canave-Jimenez F. Innovative practices improve end-of-life care. SCI Nurs. 2003;20(4):263-5. [Rec#: 1004] Exclude at abstract screening: Title Only. [pmid: 15005059].
Cancer care during the last phase of life. Journal of Clinical Oncology 98;16(5):1986-96. [Rec#: 50159] Exclude at abstract screening: no outcomes specified
Cancer pain relief and palliative care. Report of a WHO Expert Committee. World Health Organ Tech Rep Ser. 90;804:1-75. [Rec#: 10022] Exclude at abstract screening: Title Only.
Cantor J C, Blustein J, Carlson M J, Gould D A. Next-of-kin perceptions of physician responsiveness to symptoms of hospitalized patients near death. J Palliat Med. 2003;6(4):531-41. [Rec#: 1013] Exclude at abstract screening: Title Only. [pmid: 14516495].
Cantor M D, Braddock C H, Derse A R, Edwards D M, Logue G, Nelson W, Prudhomme A, Pearlman R, Reagan J E, Wlody G S, Fox E. Do-not-resuscitate orders and medical futility. Archives of Internal Medicine. 2003;163:2689-2694. [Rec#: 50319] Exclude at abstract screening: no outcomes specified. [pmid: 14662622].
Cantwell B M, Ramirez A J. Doctor-patient communication: a study of junior house officers. Med Educ. 97;31(1):17-21. [Rec#: 1015] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Cantwell P, Turco S, Brenneis C, Hanson J, Neumann C M, Bruera E. Predictors of home death in palliative care cancer patients. J Palliat Care. 2000;16(1):23-8. [Rec#: 1016] Exclude at abstract screening: Other topic only. [pmid: 10802960].
Capomolla S, Febo O, Ceresa M, Caporotondi A, Guazzotti G, La Rovere M, Ferrari M, Lenta F, Baldin S, Vaccarini C, Gnemmi M, Pinna G, Maestri R, Abelli P, Verdirosi S, Cobelli F. Cost/utility ratio in chronic heart failure: comparison between heart failure management program delivered by day-hospital and usual care. J Am Coll Cardiol 2002;40(7):1259–66. Comment in: J Am Coll Cardiol. May 21. 2003;41(10):1850. author reply 1850–1. PMID: 12767681. [Rec#: 50011] Exclude at abstract screening: Title Only.
Caraceni A, Cherny N, Fainsinger R, Kaasa S, Poulain P, Radbruch L, De Conno F. Pain measurement tools and methods in clinical research in palliative care: recommendations of an Expert Working Group of the European Association of Palliative Care. J Pain Symptom Manage. 2002;23(3):239-55. [Rec#: 10035] Exclude at abstract screening: useful only for background. [pmid: 11888722].
Caralis P V, Davis B, Wright K, Marcial E. The influence of ethnicity and race on attitudes toward advance directives, life-prolonging treatments, and euthanasia. Journal of Clinical Ethics. 93;4(2):155-65. [Rec#: 50320] Exclude at abstract screening: Title Only.
Cardozo L, Aherns S. Assessing the efficacy of a clinical pathway in the management of older patients hospitalized with congestive heart failure. J Healthc Qual. 99;21(3):12-6. quiz 16–7. [Rec#: 50012] In abstract review process.
Care for the terminally ill: a life-affirming paradigm. Healthc Demand Dis Manag 97;3(2):29–32. [Rec#: 10037] Exclude at abstract screening: no outcomes specified
Care of the dying: a Catholic perspective. Part III: Clinical context--good palliative care eases the dying process. Catholic Health Association. Health Prog 93;74(4):22–6, 31. [Rec#: 10038] Exclude at abstract screening: useful only for background
Care of the dying: a Catholic perspective. Part IV: Theological, moral, and pastoral response--the transformation of suffering. Catholic Health Association. Health Prog 93;74(5):46–54. [Rec#: 10039] Exclude at abstract screening: no outcomes specified
Carey I, Forbes K. The experiences of donor families in the hospice. Palliat Med. 2003;17(3):241-7. [Rec#: 10041] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12725477].
Carline J D, Curtis J R, Wenrich M D, Shannon S E, Ambrozy D M, Ramsey P G. Physicians' interactions with health care teams and systems in the care of dying patients: perspectives of dying patients, family members, and health care professionals. J Pain Symptom Manage. 2003;25(1):19-28. [Rec#: 10045] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12565185].
Carlson J, Youngblood R, Dalton J A, Blau W, Lindley C. Is patient satisfaction a legitimate outcome of pain management?. J Pain Symptom Manage. 2003;25(3):264-75. [Rec#: 10051] Exclude at abstract screening: useful only for background. [pmid: 12614961].
Carlson M C, Brandt J, Steele C, Baker A, Stern Y, Lyketsos C G. Predictor index of mortality in dementia patients upon entry into long-term care. J Gerontol A Biol Sci Med Sci. 2001;56(9):M567-70. [Rec#: 30798] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 11524449].
Carlson R W, Shahryar S K. Quality of death after discontinuation of dialysis. Archives of Internal Medicine. 95;155(1):13. [Rec#: 50322] Exclude at abstract screening: Title Only. [pmid: 7802516].
Carrese J. A. and Rhodes, L. A. Bridging cultural differences in medical practice. The case of discussing negative information with Navajo patients. Journal of General Internal Medicine. 2000;15(2):92-6. [Rec#: 50324] Exclude at abstract screening: useful only for background. [pmid: 10672111]. [pmcid: 1495335].
Carrese J A, Rhodes L A. Western bioethics on the Navajo reservation. Benefit or harm?. JAMA. 95;274(10):826-9. [Rec#: 50325] Exclude at abstract screening: Study Design - Qualitative. [pmid: 7650807].
Carrese, J A, Mullaney J L, Faden R R, Finucane T E. Planning for death but not serious future illness: qualitative study of housebound elderly patients. BMJ. 2002;325(7356):125. [Rec#: 50323] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12130597]. [pmcid: 117227].
Carrillo J E, Green A R, Betancourt J R. Cross-cultural primary care: a patient-based approach. Annals of Internal Medicine. 99;130(10):829-34. [Rec#: 50326] Exclude at abstract screening: not about end of life.
Carroll D S. An audit of place of death of cancer patients in a semi-rural Scottish practice. Palliat Med. 98;12(1):51-3. [Rec#: 10059] Exclude at abstract screening: Title Only. [pmid: 9616459].
Carroll D, Seers K. Relaxation for the relief of chronic pain: a systematic review. J Adv Nurs. 98;27(3):476-87. [Rec#: 50118] Exclude at abstract screening: not about end of life. [pmid: 9543032].
Carroll M L, Griffin R. Reframing life's puzzle: support for bereaved children. American Journal of Hospice &. Palliative Care. 97;14(5):231-235. [Rec#: 50327] Exclude at abstract screening: Title Only.
Carson S S, Bach P B. Predicting mortality in patients suffering from prolonged critical illness: an assessment of four severity-of-illness measures. Chest. 2001;120(3):928-33. [Rec#: 40543] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 11555531].
Carter G T, Miller R G. Comprehensive management of amyotrophic lateral sclerosis. Phys Med Rehabil Clin N Am. 98;9(1):271-84. viii. ix. [Rec#: 10075] Exclude at abstract screening: no outcomes specified.
Carter G T, Bednar-Butler L M, Abresch R T, Ugalde V O. Expanding the role of hospice care in amyotrophic lateral sclerosis. Am J Hosp Palliat Care 99;16(6):707–10. Comment in: Am J Hosp Palliat Care. Nov-Dec. 1999;16(6):696-7. PMID: 11094904. [Rec#: 10074] Exclude at abstract screening: no outcomes specified.
Carter H, MacLeod R, Hicks E, Carter J. The development of funding policies for hospices: is casemix-based funding an option?. N Z Med J. 99;112(1090):236-9. [Rec#: 10076] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Carter H, McKenna C, MacLeod R, Green R. Health professionals' responses to multiple sclerosis and motor neurone disease. Palliat Med. 98;12(5):383-94. [Rec#: 10077] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Carter H, Mckinlay E, Scott I, Wise D, MacLeod R. Impact of a hospital palliative care service: perspective of the hospital staff. J Palliat Care. 2002;18(3):160-7. [Rec#: 10078] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12418366].
Carter J. Can hospice care be provided to people who live alone?. Home Healthc Nurse. 96;14(9):710-6. [Rec#: 10079] Exclude at abstract screening: no outcomes specified. [pmid: 8991892].
Carter C. Hospice residential care center. The first year. Kansas Nurse. 98;73(3):2-3. [Rec#: 50328] Exclude at abstract screening: Study Design - Unclear. [pmid: 10603827].
Cartier C. From home to hospital and back again: economic restructuring, end of life, and the gendered problems of place-switching health services. Social Science & Medicine. 2003;56(11):2289-301. [Rec#: 50329] Exclude at abstract screening: not about end of life. [pmid: 12719182].
Cartledge J D, Weller I V. Shared care in HIV and AIDS: shifting care or shifting costs?. J R Coll Physicians Lond. 98;32(4):376-9. [Rec#: 10081] Exclude at abstract screening: Title Only. [pmid: 9762635].
Cartwright J C. Nursing homes and assisted living facilities as places for dying. Annu Rev Nurs Res. 2002;20:231-64. [Rec#: 10085] Exclude at abstract screening: useful only for background. [pmid: 12092511].
Cartwright-Alcarese F, Sung M W, Brenner B, Zambodla A, Geduld A, Desjardins L. An interdisciplinary approach to the provision of patient support resources across the oncology care continuum: description of a performance improvement project. J Nurs Care Qual. 2003;18(1):61-72. [Rec#: 10084] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12518840].
Casarett D, Kutner J S, Abrahm J. End-of-Life Care Consensus Panel. Life after death: a practical approach to grief and bereavement. Ann Intern Med. 2001;134(3):208-15. [Rec#: 10090] Exclude at abstract screening: useful only for background. [pmid: 11177334].
Casarett D, Inouye S. Diagnosis and management of delirium near the end of life. Annals of Internal Medicine. 2001;135(1):32-40. [Rec#: 50330] Exclude at abstract screening: no outcomes specified. [pmid: 11434730].
Cassel C K, Ludden J M, Moon G M. Perceptions of barriers to high-quality palliative care in hospitals. Health Aff (Millwood). 2000;19(5):166-72. [Rec#: 10102] Exclude at abstract screening: Title Only. [pmid: 10992665].
Cassell E J. Diagnosing suffering: a perspective. Ann Intern Med. 99;131(7):531-4. [Rec#: 10104] Exclude at abstract screening: no outcomes specified. [pmid: 10507963].
Cassell EJ. The nature of suffering: physical, psychological, social, and spiritual aspects. NLN Publ 92;(15–2461):1–10. [Rec#: 10105] Exclude at abstract screening: no outcomes specified
Cassell J, Buchman T G, Streat S, Stewart R M. Surgeons, intensivists, and the covenant of care: administrative models and values affecting care at the end of life--Updated Crit Care Med 2003;31(5):1551–7; discussion 1557–9. Corrected, republished from: Crit Care Med. Apr. 2003;31(4):1263-70. PMID: 12682502. [Rec#: 10106] Exclude at abstract screening: useful only for background.
Cassidy J. Innovations in pain management. Catholic providers are in the forefront of treating the pain of chronic and terminal illness. Health Prog. 99;80(6):22-9. [Rec#: 10108] Exclude at abstract screening: Title Only.
Cassidy K. Partners in healing: home care, hospice, and parish nurses. Home Healthc Nurse. 2002;20(3):179-83. [Rec#: 10109] Exclude at abstract screening: no outcomes specified. [pmid: 11984179].
Castle N G. Advance directives in nursing homes: resident and facility characteristics. Omega (Westport). 96-97;34(4):321-32. [Rec#: 40550] Exclude at abstract screening: Title Only. [pmid: 11656918].
Castro R, Orozco E, Eroza E, Manca M C, Hernandez J J, Aggleton P. AIDS-related illness trajectories in Mexico: findings from a qualitative study in two marginalized communities. AIDS Care. 98;10(5):583-98. [Rec#: 10121] Notes: “EXCLUDE: Location, non-Western”.
Cattell E, Arance A, and Middleton M. Assessing outcomes in palliative chemotherapy. Expert Opin Pharmacother 2002;3(6):693?700. Erratum in: Expert Opin Pharmacother. 2002 Jul;3(7):1029. [Rec#: 10126] Exclude at abstract screening: no outcomes specified
Cavalieri T A, Latif W, Ciesielski J, Ciervo C A, Forman L J. How physicians approach advance care planning in patients with mild to moderate Alzheimer's disease. J Am Osteopath Assoc. 2002;102(10):541-4. [Rec#: 10129] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12401040].
Cawthorn A, Carter A. Aromatherapy and its application in cancer and palliative care. Complement Ther Nurs Midwifery. 2000;6(2):83-6. [Rec#: 10132] Exclude at abstract screening: Title Only. [pmid: 10844746].
Cazzoli P A, Oppenheimer E A. Home mechanical ventilation for amyotrophic lateral sclerosis: nasal compared to tracheal intermittent positive pressure ventilation. Journal of Neurological Science. 96;139:123-128. [Rec#: 50331] Exclude at abstract screening: not about end of life.
Cella D F. Measuring quality of life in palliative care. Semin Oncol. 95;22(2 Suppl 3):73-81. [Rec#: 10134] Exclude at abstract screening: no outcomes specified. [pmid: 7537908].
Cella D F. Quality of life: the concept. J Palliat Care. 92;8(3):8-13. [Rec#: 10135] Exclude at abstract screening: Title Only. [pmid: 1279152].
Centeno C, Arnillas P, Hernansanz S, Flores L A, Gomez M, Lopez-Lara F. The reality of palliative care in Spain. Palliat Med. 2000;14(5):387-94. [Rec#: 10136] Exclude at abstract screening: Other topic only. [pmid: 11064785].
Centeno C, Hernansanz S, Flores L A, Rubiales A S, Lopez-Lara F. Spain: palliative care programs in Spain, 2000: a national survey. J Pain Symptom Manage. 2002;24(2):245-51. [Rec#: 10137] Exclude at abstract screening: Title Only. [pmid: 12231157].
Centers L C. Beyond denial and despair: ALS and our heroic potential for hope. J Palliat Care. 2001;17(4):259-64. [Rec#: 10139] Exclude at abstract screening: not about end of life. [pmid: 11813344].
Cepeda M S, Africano J M, Polo R, Alcala R, Carr D B. What decline in pain intensity is meaningful to patients with acute pain?. Pain. 2003;105(12):151-7. [Rec#: 1130] Exclude at abstract screening: not about end of life. [pmid: 14499431].
Cerminara K L. Eliciting patient preferences in today's health care system. Psychol Public Policy Law. 98;4(3):688-702. [Rec#: 10140] Exclude at abstract screening: no outcomes specified. [pmid: 12803223].
Chaitin E, Stiller R, Jacobs S, Hershl J, Grogen T, Weinberg J. Physician-patient relationship in the intensive care unit: erosion of the sacred trust?. Crit Care Med. 2003;31(5 Suppl):S367-72. [Rec#: 10146] Exclude at abstract screening: no outcomes specified. [pmid: 12771585].
Chambers N. The holistic management of pressure sores in terminal illness. J Wound Care. 97;6(8):359-60. [Rec#: 1145] Exclude at abstract screening: Title Only. [pmid: 9341422].
Chan A, Woodruff R K. Palliative care in a general teaching hospital. 1. Assessment of needs. Med J Aust 91;155(9):597–9. Comment in: Med J Aust. Mar 16. 1992;156(6):438. PMID: 1372080. [Rec#: 1149] Exclude at abstract screening: Title Only.
Chan G K. End-of-life models and emergency department care. Acad Emerg Med. 2004;11(1):79-86. [Rec#: 1156] Exclude at abstract screening: useful only for background. [pmid: 14709435].
Chan D, Brennan N. Delirium: making the diagnosis, improving the prognosis. Geriatrics. 99;54(3):28-42. [Rec#: 50332] Exclude at abstract screening: Title Only. [pmid: 10086025].
Chang B L, Rubenstein L V, Keeler E B, Miura L N, Kahn K L. The validity of a nursing assessment and monitoring of signs and symptoms scale in ICU and non-ICU patients. Am J Crit Care. 96;5(4):298-303. [Rec#: 30868] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Chao C S, Chen C H, Yen M. The essence of spirituality of terminally ill patients. J Nurs Res. 2002;10(4):237-45. [Rec#: 1169] Exclude at abstract screening: Observational study. [pmid: 12522736].
Chao Y, Chan W K, Wang S S, Lai K H, Chi C W, Lin C Y, Chan A, Whang-Peng J, Lui W Y, Lee S D. Phase II study of megestrol acetate in the treatment of hepatocellular carcinoma. J Gastroenterol Hepatol. 97;12(4):277-81. [Rec#: 1170] Exclude at abstract screening: Other symptoms only.
Chao C, Studts J L, Abell T, Hadley T, Roetzer L, Dineen S, Lorenz D, YoussefAgha A, McMasters K M. Adjuvant chemotherapy for breast cancer: how presentation of recurrence risk influences decision-making. Journal of Clinical Oncology. 2003;21(23):4299-305. [Rec#: 50334] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 14581440].
Chaplin D. A bereavement care service to address multicultural user needs. Nurs Times. 2003;99(39):26-9. [Rec#: 10160] Exclude at abstract screening: not about end of life. [pmid: 14562658].
Chapman CR and Gavrin J. Suffering and its relationship to pain. J Palliat Care 93;9(2):5–13. Comment in: J Palliat Care. 1993 Summer;9(2):3–4. PMID: 8377068. [Rec#: 10162] Exclude at abstract screening: useful only for background
Chapman K J, Pepler C. Coping, hope, and anticipatory grief in family members in palliative home care. Cancer Nurs. 98;21(4):226-34. [Rec#: 1174] Exclude at abstract screening: Bereavement only. [pmid: 9691503].
Chapman K Y, Bass L. A comparison of hospice in the UK and the US. Am J Hosp Palliat Care. 2000;17(3):173-7. [Rec#: 10163] Exclude at abstract screening: no outcomes specified. [pmid: 11886068].
Char DF, Tom KS, Young GC, Murakami T, and Ames R. A view of death and dying among the Chinese and Japanese. Hawaii Med J 96;55(12):286–90, 295. [Rec#: 10164] Exclude at abstract screening: no outcomes specified
Charles C, Gafni A, Whelan T. Shared decision-making in the medical encounter: what does it mean? (or it takes at least two to tango). Social Science & Medicine. 97;44(5):681-92. [Rec#: 50335] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Charlton R, Dovey S, Mizushima Y. Attitudes to death and dying in the UK, New Zealand, and Japan. J Palliat Care. 95;11(1):42-7. [Rec#: 10170] Exclude at abstract screening: Title Only. [pmid: 7751986].
Charlton R, Field S, Faull C, Campbell I, Harper C, Harper L. The effect of the general practice registrar year on perceived skills in palliative care in the West Midlands. Med Educ 2000;34(11):928–35. Comment in: Med Educ. 2001 Aug;35(8):809. PMID: 11489116. Erratum in: Med Educ. Apr. 2001;35(4):417-8. [Rec#: 1180] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Charlton R, Smith G, White D, Austin C, Pitts M. Audit tools for palliative care services: identification of neglected aspects of care. Am J Hosp Palliat Care. 2002;19(6):397-402. [Rec#: 10174] Exclude at abstract screening: not about end of life. [pmid: 12442975].
Charlton R. Palliative care in non-cancer patients and the neglected caregiver. J Clin Epidemiol. 92;45(12):1447-9. [Rec#: 1179] Exclude at abstract screening: useful only for background. [pmid: 1460481].
Charlton R C. Attitudes towards care of the dying: a questionnaire survey of general practice attenders. Fam Pract. 91;8(4):356-9. [Rec#: 10175] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Charlton R C. Spiritual need of the dying and bereaved--views from the United Kingdom and New Zealand. J Palliat Care. 92;8(4):38-40. [Rec#: 1184] Exclude at abstract screening: Title Only. [pmid: 1487791].
Charnes L S, Moore P S. Meeting patients' spiritual needs: the Jewish perspective. Holist Nurs Pract. 92;6(3):64-72. [Rec#: 10176] Exclude at abstract screening: useful only for background. [pmid: 1564074].
Chater S, Viola R, Paterson J, Jarvis V. Sedation for intractable distress in the dying--a survey of experts Palliat Med 98;12(4):255–69. Comment in: Palliat Med. May. 1999;13(3):262-4. PMID: 10474717. [Rec#: 1188] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Chaves J F. Recent advances in the application of hypnosis to pain management. Am J Clin Hypn. 94;37(2):117-29. [Rec#: 10181] Exclude at abstract screening: no outcomes specified. [pmid: 7527615].
Cheesman S, Christian R, Cresswell J. Exploring the value of shiatsu in palliative care day services. Int J Palliat Nurs. 2001;7(5):234-9. [Rec#: 1192] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12148974].
Chelluri L, Grenvik A, Silverman M. Intensive care for critically ill elderly: mortality, costs, and quality of life Review of the literature. Arch Intern Med. 95;155(10):1013-22. [Rec#: 40592] Exclude at abstract screening: useful only for background.
Chen L K, Chou Y C, Hsu P S, Tsai S T, Hwang S J, Wu B Y, Lin M H, Chen T W. Antibiotic prescription for fever episodes in hospice patients. Support Care Cancer. 2002;10(7):538-41. [Rec#: 1202] Exclude at abstract screening: not about end of life. [pmid: 12324808].
Chen Y C, Lin S F, Liu C J, Jiang D D, Yang P C, Chang S C. Risk factors for ICU mortality in critically ill patients. J Formos Med Assoc. 2001;100(10):656-61. [Rec#: 40600] Notes: “EXCLUDE: Location, non-Western”. [pmid: 11760370].
Cheng B K. Cultural clash between providers of majority culture and patients of Chinese culture. J Long Term Home Health Care. 97;16(2):39-43. [Rec#: 10187] Exclude at abstract screening: Title Only. [pmid: 10168382].
Cheng E Y. Prospective quality of life research in bony metastatic disease. Clin Orthop. 2003;(415 Suppl):S289-97. [Rec#: 10188] Exclude at abstract screening: no outcomes specified.
Cheng T O. Hospital readmissions for elderly patients with congestive heart failure Arch Intern Med 97;157(12):1393. Comment on: Arch Intern Med. Jan13. 1997;157(1):99-104. PMID: 8996046. [Rec#: 50013] Exclude at abstract screening: Title Only.
Cheng W C, Schuckers P L, Hauser G, Burch J, Emmett J G, Walker B, Law E, Wakefield D, Boyle D, Lee M, et al. Psychosocial needs of family caregivers of terminally ill patients. Psychol Rep. 94;75(3 Pt 1):1243-50. [Rec#: 1210] Exclude at abstract screening: Observational study.
Cheng C, Roemer-Becuwe C, Pereira J. When midazolam fails. Journal of Pain & Symptom Management. 2002;23(3):256-65. [Rec#: 50336] Exclude at abstract screening: Observational study. [pmid: 11888723].
Chentsova-Dutton Y, Shucter S, Hutchin S, Strause L, Burns K, Dunn L, Miller M, Zisook S. Depression and grief reactions in hospice caregivers: from pre-death to 1 year afterwards. J Affect Disord. 2002;69(13):53-60. [Rec#: 1212] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12103452].
Cher D J, Lenert L A. Method of Medicare reimbursement and the rate of potentially ineffective care of critically ill patients. JAMA 97;278(12):1001–7. Comment in: JAMA. 1997 Sep 24;278(12):1025–6. PMID: 9307355. Comment in: JAMA. 1998 Mar 4;279(9):651–2; author reply 653–4. PMID: 9496973. Comment in: JAMA. 1998 Mar 4;279(9):651; author reply 653–4. PMID: 9496972. Comment in: JAMA. Mar. 1998;4:279. [Rec#: 1213] Exclude at abstract screening: useful only for background.
Cherin D, Enguidanos S, Brumley R. Reflection in action in caring for the dying: applying organizational learning theory to improve communications in terminal care. Home Health Care Serv Q. 2001;19(4):65-78. [Rec#: 10189] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11727289].
Cherin D A, Simmons W J, Hillary K. The transprofessional model: blending intents in terminal care of AIDS. Home Health Care Serv Q. 98;17(1):31-54. [Rec#: 10190] Exclude at abstract screening: no outcomes specified.
Cherny N I, Catane R. Palliative medicine and the medical oncologist. Defining the purview of care. Hematol Oncol Clin North Am. 96;10(1):1-20. [Rec#: 10192] Exclude at abstract screening: no outcomes specified.
Cherny N I, Portenoy R K. Sedation in the management of refractory symptoms: guidelines for evaluation and treatment. J Palliat Care. 94;10(2):31-8. [Rec#: 10195] Exclude at abstract screening: Title Only. [pmid: 8089815].
Cherny N I, Catane R. European Society of Medical Oncology Taskforce on Palliative and Supportive Care. Attitudes of medical oncologists toward palliative care for patients with advanced and incurable cancer: report on a survery by the European Society of Medical Oncology Taskforce on Palliative and Supportive Care. Cancer. 2003;98(11):2502-10. [Rec#: 1216] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14635087].
Cherny N I, Coyle N, Foley K M. Guidelines in the care of the dying cancer patient. Hematol Oncol Clin North Am. 96;10(1):261-86. [Rec#: 10193] Exclude at abstract screening: useful only for background. [pmid: 8821571].
Cherny N I, Coyle N, Foley K M. Suffering in the advanced cancer patient: a definition and taxonomy. J Palliat Care. 94;10(2):57-70. [Rec#: 10194] Exclude at abstract screening: Title Only. [pmid: 8089819].
Cherny N, Ripamonti C, Pereira J, Davis C, Fallon M, McQuay H, Mercadante S, Pasternak G, Ventafridda V. Expert Working Group of the European Association of Palliative Care, Network Strategies to manage the adverse effects of oral morphine: an evidence-based report. Journal of Clinical Oncology. 2001;19(9):2542-54. [Rec#: 50337] Exclude at abstract screening: no outcomes specified. [pmid: 11331334].
Chertow G M, Christiansen C L, Cleary P D, Munro C, Lazarus J M. Prognostic stratification in critically ill patients with acute renal failure requiring dialysis Arch Intern Med 95;155(14):1505–11. Comment in: Arch Intern Med. May 13. 1996;156(9):1023-1027. PMID: 8624168. [Rec#: 40607] Exclude at abstract screening: primarily prognosis or trajectories.
Chervenak F A, McCullough L B. Preventive ethics and end-of-life decisions. Womens Health Issues 96;6(5):304–6. Comment on: Womens Health Issues. Sep-Oct. 1996;6(5):295-301. PMID: 8870509. [Rec#: 10196] Exclude at abstract screening: Title Only.
Chessick R D. The death instinct revisited. J Am Acad Psychoanal. 92;20(1):3-28. [Rec#: 10197] Exclude at abstract screening: Title Only. [pmid: 1607302].
Chevrier F, Steuer R, MacKenzie J. Factors affecting satisfaction among community-based hospice volunteer visitors. Am J Hosp Palliat Care. 94;11(4):30-7. [Rec#: 10200] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Chibnall J T, Jeral J M, Cerullo M, Knorp J F, Duckro P N. Medical school exposure to spirituality and response to a hypothetical cancer patient. J Cancer Educ. 2002;17(4):188-90. [Rec#: 10201] Exclude at abstract screening: no outcomes specified. [pmid: 12556053].
Chidwick A, Borrill J. Dealing with a life-threatening diagnosis: the experience of people with the human immunodeficiency virus. AIDS Care. 96;8(3):271-84. [Rec#: 1232] Exclude at abstract screening: Observational study.
Chin M H, Wang J C, Zhang J X, Sachs G A, Lang R M. Differences among geriatricians, general internists, and cardiologists in the care of patients with heart failure: a cautionary tale of quality assessment. Journal of the American Geriatric Society. 98;46(11):1349-54. [Rec#: 50338] Exclude at abstract screening: not about end of life.
Chinner T L, Dalziel F R. An exploratory study on the viability and efficacy of a pet-facilitated therapy project within a hospice. J Palliat Care. 91;7(4):13-20. [Rec#: 1239] Exclude at abstract screening: Study Design - Qualitative.
Chio A, Silani V, Italian A L S. Amyotrophic lateral sclerosis care in Italy: a nationwide study in neurological centers. J Neurol Sci. 2001;191(12):145-50. [Rec#: 10202] Exclude at abstract screening: not about end of life. [pmid: 11677006].
Chipps J, Grey A, Hilton G, Linford J, Pearce S, Thomas T. The discharge process for palliative care patients. Nurs Stand. 97;11(42):41-4. [Rec#: 10206] Exclude at abstract screening: no outcomes specified. [pmid: 9283415].
Chirikos T N. Appraising the economic efficiency of cancer treatment: an exploratory analysis of lung cancer. Health Care Manag Sci. 2003;6(2):87-95. [Rec#: 30920] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12733612].
Chochinov H M, Hack T, McClement S, Kristjanson L, Harlos M. Dignity in the terminally ill: a developing empirical model. Soc Sci Med. 2002;54(3):433-43. [Rec#: 10210] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11824919].
Chochinov H M, Wilson K G, Enns M, Lander S. Depression, Hopelessness, and suicidal ideation in the terminally ill. Psychosomatics. 98;39(4):366-70. [Rec#: 1255] Exclude at abstract screening: Study Design - Qualitative.
Chodosh J, Ferrell B A, Shekelle P G, Wenger N S. Quality indicators for pain management in vulnerable elders. Ann Intern Med. 2001;135(8 Pt 2):731-5. [Rec#: 40621] Exclude at abstract screening: Title Only. [pmid: 11601956].
Choi Y S, Billings J A. Changing perspectives on palliative care. Oncology (Huntingt). 2002;16(4):515-22. [Rec#: 10212] Exclude at abstract screening: useful only for background. [pmid: 12017537].
Choi Y S, Billings J A. Opioid antagonists: a review of their role in palliative care, focusing on use in opioid-related constipation. Journal of Pain & Symptom Management. 2002;24(1):71-90. [Rec#: 50339] Exclude at abstract screening: useful only for background. [pmid: 12183097].
Chow E, Fung K, Panzarella T, Bezjak A, Danjoux C, Tannock I. A predictive model for survival in metastatic cancer patients attending an outpatient palliative radiotherapy clinic. Int J Radiat Oncol Biol Phys. 2002;53(5):1291-302. [Rec#: 1267] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 12128132].
Christ G H, Sormanti M. Advancing social work practice in end-of-life care. Soc Work Health Care. 99;30(2):81-99. [Rec#: 10219] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Christakis N A, Escarce JJ. Survival of Medicare patients after enrollment in hospice programs N Engl J Med 96;335(3):172–8. Comment in: N Engl J Med. 1996 Dec 19;335(25):1925–6; author reply 1926–7. PMID: 8965916. Comment in: N Engl J Med. 1996 Dec 19;335(25):1926; author reply 1926–7. PMID: 8965917. Comment in: N Engl J Med. Jul 18. 1996;335(3):201-2. PMID: 8657221. [Rec#: 1277] Exclude at abstract screening: useful only for background.
Christakis N A, Iwashyna T J. Attitude and self-reported practice regarding prognostication in a national sample of internists. Arch Intern Med. 98;158(21):2389-95. [Rec#: 1278] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Christakis N A, Iwashyna T J. Impact of individual and market factors on the timing of initiation of hospice terminal care. Med Care. 2000;38(5):528-41. [Rec#: 1280] Exclude at abstract screening: useful only for background. [pmid: 10800979].
Christakis N A, Lamont E B. Extent and determinants of error in doctors' prognoses in terminally ill patients: prospective cohort study BMJ 2000;320(7233):469–72. Comment in: BMJ. 2000 Feb 19;320(7233):472–3. PMID: 10722294. Comment in: BMJ. Feb 19. 2000;320(7233):473. PMID: 10722295. [Rec#: 10223] Exclude at abstract screening: primarily prognosis or trajectories.
Christakis N A. Predicting patient survival before and after hospice enrollment. Hosp J. 98;13(12):71-87. [Rec#: 10220] Exclude at abstract screening: no outcomes specified. [pmid: 9644394].
Christakis N A. Prognostication and bioethics. Daedalus. 99;128(4):197-214. [Rec#: 10221] Exclude at abstract screening: Title Only. [pmid: 11645875].
Christakis N A, Sachs G A. The role of prognosis in clinical decision making. Journal of General Internal Medicine. 96;11(7):422-5. [Rec#: 50340] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 8842935].
Christiaans M H, Kelder J C, Arnoldus E P, Tijssen C C. Prediction of intracranial metastases in cancer patients with headache. Cancer. 2002;94(7):2063-8. [Rec#: 30937] Exclude at abstract screening: Other topic only. [pmid: 11932910].
Chu W, Hynes-Gay P. The influence of DNR orders on patient care in adult ICUs: a review of the evidence. Dynamics. 2002;13(4):14-21. [Rec#: 50119] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 12640835].
Chung E S, Packer M, Lo K H, Fasanmade A A, Willerson J T. Anti-TNF Therapy Against Congestive Heart Failure Investigators. Randomized, double-blind, placebo-controlled, pilot trial of infliximab, a chimeric monoclonal antibody to tumor necrosis factor-alpha, in patients with moderate-to-severe heart failure: results of the anti-TNF Therapy Against Congestive Heart Failure (ATTACH) trial. Circulation. 2003;107(25):3133-40. [Rec#: 30949] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 12796126].
Chung K. Brief social work intervention in the hospice setting: person-centred work and crisis intervention synthesized and distilled. Palliat Med. 93;7(1):59-62. [Rec#: 10231] Exclude at abstract screening: no outcomes specified.
Ciccarello G P. Strategies to improve end-of-life care in the intensive care unit. Dimens Crit Care Nurs. 2003;22(5):216-22. [Rec#: 10237] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14508248].
Cicirelli V G. Personal meanings of death in older adults and young adults in relation to their fears of death. Death Stud. 2001;25(8):663-83. [Rec#: 1297] Exclude at abstract screening: not about end of life. [pmid: 11883450].
Cicirelli V G. Personal meanings of death in relation to fear of death. Death Stud. 98;22(8):713-33. [Rec#: 1298] Exclude at abstract screening: not about end of life. [pmid: 10346699].
Cicirelli V G. Personality and demographic factors in older adults' fear of death. Gerontologist. 99;39(5):569-79. [Rec#: 1299] Exclude at abstract screening: not about end of life. [pmid: 10568081].
Cider A, Schaufelberger M, Sunnerhagen K S, Andersson B. Hydrotherapy--a new approach to improve function in the older patient with chronic heart failure. Eur J Heart Fail. 2003;5(4):527-35. [Rec#: 30950] Exclude at abstract screening: not about end of life. [pmid: 12921815].
Cimino J E. Palliative care: overview of the major hospice movement--some issues and some answers. J Long Term Home Health Care. 98;17(4):26-32. [Rec#: 10240] Exclude at abstract screening: useful only for background.
Cintron A, Hamel M B, Davis R B, Burns R B, Phillips R S, McCarthy E P. Hospitalization of hospice patients with cancer. J Palliat Med. 2003;6(5):757-68. [Rec#: 1301] Exclude at abstract screening: useful only for background. [pmid: 14622455].
Ciocon J O, Galindo-Ciocon D, Galinda D J. Raised leg exercises for leg edema in the elderly. Angiology. 95;46(1):19-25. [Rec#: 30953] Exclude at abstract screening: not about end of life. [pmid: 7818153].
Circle of Life Award winner. A full continuum of hospice service: the Hospice of the Florida Suncoast. Continuum Soc Soc Work Leadersh Health Care. 2000;20(2):10-1. [Rec#: 10241] Exclude at abstract screening: Title Only.
Cist, F. M., Truog, R. D., Brackett, S. E., and Hurford, W. E. Practice Guidelines on the Withdrawal of Life-Sustaining Therapies. International Anesthesiology Clinics 2001;39(3). [Rec#: 50341] Exclude at abstract screening: Title Only
Civetta J M. Managing the cancer patient and family. Bull Am Coll Surg. 94;79(11):25-7. [Rec#: 10244] Exclude at abstract screening: no outcomes specified. [pmid: 10138521].
Claessens M T, Lynn J, Zhong Z, Desbiens N A, Phillips R S, Wu A W, Harrell F E, Connors A F Jr. Dying with lung cancer or chronic obstructive pulmonary disease: insights from SUPPORT. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatments. J Am Geriatr Soc. 2000;48(5 Suppl):S146-53. [Rec#: 1305] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 10809468].
Clare J and De Bellis A. Palliative care in South Australian nursing homes. Aust J Adv Nurs 97;14(4):20–8. Erratum in: Aust J Adv Nurs 1997 Sep-Nov;15(1):19. [Rec#: 10245] Exclude at abstract screening: no outcomes specified
Clark A P. Can we improve the quality of dying in hospitals?. Clin Nurse Spec. 2002;16(4):180-1. [Rec#: 10246] Exclude at abstract screening: Title Only. [pmid: 12172486].
Clark D, Malson H, Small N, Daniel T, Mallett K. Needs assessment and palliative care: the views of providers. J Public Health Med. 97;19(4):437-42. [Rec#: 10253] Exclude at abstract screening: no outcomes specified.
Clark D, Neale B, Heather P. Contracting for palliative care. Soc Sci Med. 95;40(9):1193-202. [Rec#: 10254] Exclude at abstract screening: no outcomes specified. [pmid: 7541918].
Clark D, Seymour J, Douglas H R, Bath P, Beech N, Corner J, Halliday D, Hughes P, Haviland J, Normand C, Marples R, Skilbeck J, Webb T. Clinical nurse specialists in palliative care. Part 2. Explaining diversity in the organization and costs of Macmillan nursing services. Palliat Med. 2002;16(5):375-85. [Rec#: 10255] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12380655].
Clark D, ten Have H, Janssens R. Common threads? Palliative care service developments in seven European countries. Palliat Med. 2000;14(6):479-90. [Rec#: 10256] Exclude at abstract screening: useful only for background. [pmid: 11219878].
Clark D B, Ram M D, MacDonald J S, Rees E D, Engelberg J, Noble R C. How physicians deal with their own impending death. South Med J. 90;83(4):441-7. [Rec#: 10257] Exclude at abstract screening: Title Only. [pmid: 2321072].
Clark J M, Lurie J D, Claessens M T, Reed V A, Jernstedt G C, Goodlin S G. Factors associated with palliative care knowledge among internal medicine house staff. J Palliat Care. 2003;19(4):253-7. [Rec#: 1314] Exclude at abstract screening: outcome unrelated to pts/family/non?prof. [pmid: 14959595].
Clark M, Bostwick J M, Rummans T A. Group and Individual Treatment Strategies for Distress in Cancer Patients. Mayo Clinic Proceedings. 2003;78:1538-1543. [Rec#: 50342] Exclude at abstract screening: Title Only. [pmid: 14661683].
Clarke S P, Frasure-Smith N, Lesperance F, Bourassa M G. Psychosocial factors as predictors of functional status at 1 year in patients with left ventricular dysfunction. Res Nurs Health. 2000;23(4):290-300. [Rec#: 30965] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 10940954].
Claxton J W. Paving the way to acceptance. Psychological adaptation to death and dying in cancer. Prof Nurse. 93;8(4):206-11. [Rec#: 10266] Exclude at abstract screening: no outcomes specified. [pmid: 8419950].
Clay D. Mental health and psychosocial issues in HIV care. Lippincotts Prim Care Pract. 2000;4(1):74-82. [Rec#: 10267] Exclude at abstract screening: useful only for background. [pmid: 11022521].
Clayton J, Butow P, Tattersall M, Chye R, Noel M, Davis J M, Glare P. Asking questions can help: development and preliminary evaluation of a question prompt list for palliative care patients. Br J Cancer. 2003;89(11):2069-77. [Rec#: 1328] Exclude at abstract screening: not about end of life. [pmid: 14647140].
Clayton PJ. Bereavement and depression. J Clin Psychiatry 90;51 Suppl:34–8; discussion 39–40. [Rec#: 1330] Exclude at abstract screening: useful only for background
Cleeland C S, Gonin R, Hatfield A K, Edmonson J H, Blum R H, Stewart J A, Pandya K J. Pain and its treatment in outpatients with metastatic cancer N Engl J Med 94;330(9):592–6. Comment in: N Engl J Med. 1994 Dec 1;331(22):1528. PMID: 7969315. Comment in: N Engl J Med. 1994 Jul 21;331(3):199; author reply 201. PMID: 7516494. Comment in: N Engl J Med. Jul 21. 1994;331(3):200. author reply 201. PMID: 8008037. Comment in: N En. [Rec#: 1333] Exclude at abstract screening: Title Only.
Cleeland C S, Gonin R, Baez L, Loehrer, Pandya K J. Pain and treatment of pain in minority patients with cancer. Annals of Internal Medicine. 97;127:813-816. [Rec#: 50343] Exclude at abstract screening: Title Only. [pmid: 9382402].
Cleland J G. Are symptoms the most important target for therapy in chronic heart failure?. Prog Cardiovasc Dis. 98;41(1 Suppl 1):59-64. [Rec#: 10275] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Clement D. Considering the alternatives. Minn Med 94;77(2):10–6. Comment in: Minn Med. Apr. 1994;77(4):2-3. PMID: 8007907. [Rec#: 10276] Exclude at abstract screening: Title Only.
Clements P T, Vigil G J, Manno M S, Henry G C, Wilks J, Das Sarthak, Kellywood R, Foster W. Cultural perspectives of death, grief, and bereavement. J Psychosoc Nurs Ment Health Serv 2003;41(7):18–26. Comment in: J Psychosoc Nurs Ment Health Serv. Nov. 2003;41(11):8. author reply 8–9. PMID: 14621441. [Rec#: 10278] Exclude at abstract screening: Non-systematic review.
Clermont G, Angus D C. Severity scoring systems in the modern intensive care unit. Ann Acad Med Singapore. 98;27(3):397-403. [Rec#: 10279] Exclude at abstract screening: sudden/violent/non-chronic deaths.
Cline C M, Willenheimer R B, Erhardt L R, Wiklund I, Israelsson B Y. Health-related quality of life in elderly patients with heart failure. Scand Cardiovasc J. 99;33(5):278-85. [Rec#: 30982] Exclude at abstract screening: not about end of life.
Cline D J. The psychosocial impact of HIV infection--what clinicians can do to help. J Am Acad Dermatol. 90;22(6 Pt 2):1299-302. [Rec#: 10281] Exclude at abstract screening: not about end of life. [pmid: 2362020].
Clingerman E M. Bereavement tasks for nursing students. Nurse Educ. 96;21(3):19-22. [Rec#: 10282] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 8788822].
Clipp E C, Elder G H. Elderly confidants in geriatric assessment. Compr Gerontol [B]. 87;1(1):35-40. [Rec#: 50861] Exclude at abstract screening: not about end of life.
Closs S J, Ferguson A, Thompson D. Collaborating on the integration of cancer nursing services. Nurs Stand. 96;10(50):37-40. [Rec#: 10284] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Coackley A, Hutchinson T, Saltmarsh P, Kelly A, Ellershaw J E, Marshall E, Brunston H. Assessment and management of fatigue in patients with advanced cancer: developing guidelines. Int J Palliat Nurs. 2002;8(8):381-8. [Rec#: 10289] Exclude at abstract screening: no outcomes specified. [pmid: 12271259].
Coady D A, Wynne H A. Are continuing care beds in private nursing homes the answer to providing care for the longer-term dying?. Palliat Med. 2001;15(2):155-6. [Rec#: 1352] Exclude at abstract screening: Title Only. [pmid: 11301667].
Coates A. Quality of life and supportive care. Support Care Cancer. 97;5(6):435-8. [Rec#: 10292] Exclude at abstract screening: useful only for background. [pmid: 9406355].
Coats A J. Origin of symptoms in patients with cachexia with special reference to weakness and shortness of breath. Int J Cardiol. 2002;85(1):133-9. [Rec#: 30988] Exclude at abstract screening: Study Design - Unclear. [pmid: 12163218].
Cochrane J. The experience of uncertainty for individuals with HIV/AIDS and the palliative care paradigm. Int J Palliat Nurs. 2003;9(9):382-8. [Rec#: 1358] Exclude at abstract screening: Study Design - Qualitative. [pmid: 14593274].
Cody C P, Naierman N. Evaluation of the cost effectiveness of a collaborative liaison program. Hosp J. 90;6(3):47-61. [Rec#: 10301] Exclude at abstract screening: Study Design - Unclear. [pmid: 2125972].
Cody M, Beck C, Shue V M, Pope S. Reported practices of primary care physicians in the diagnosis and management of dementia. Aging Ment Health. 2002;6(1):72-6. [Rec#: 50014] Exclude at abstract screening: Title Only. [pmid: 11827625].
Cody W K. The lived experience of grieving for persons living with HIV who have used injection drugs. J Assoc Nurses AIDS Care. 2000;11(3):82-92. [Rec#: 1362] Exclude at abstract screening: Observational study. [pmid: 10826306].
Cody WK. The lived experience of grieving, for families living with AIDS. NLN Publ 94;(15–2670):197–242. [Rec#: 1361] Exclude at abstract screening: useful only for background
Cody W K. The meaning of grieving for families living with AIDS. Nurs Sci Q. 95;8(3):104-14. [Rec#: 1363] Exclude at abstract screening: Study Design - Unclear. [pmid: 7651627].
Coe RM and Miller DK. Communication between the hospitalized older patient and physician. Clin Geriatr Med 2000;16(1):109–18, x. [Rec#: 1365] Exclude at abstract screening: not about end of life
Coetzee R H, Leask S J, Jones R G. The attitudes of carers and old age psychiatrists towards the treatment of potentially fatal events in end-stage dementia. Int J Geriatr Psychiatry. 2003;18(2):169-73. [Rec#: 1367] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12571827].
Cohen C A, Colantonio A, Vernich L. Positive aspects of caregiving: rounding out the caregiver experience. Int J Geriatr Psychiatry. 2002;17(2):184-8. [Rec#: 30999] Exclude at abstract screening: not about end of life. [pmid: 11813283].
Cohen C A, Pringle D, LeDuc L. Dementia caregiving: the role of the primary care physician. Can J Neurol Sci. 2001;28(Suppl 1):S72-6. [Rec#: 50016] Exclude at abstract screening: Title Only. [pmid: 11237314].
Cohen C A. Caregivers for people with dementia. What is the family physician's role?. Can Fam Physician. 2000;46:376-80. [Rec#: 50015] In abstract review process. [pmid: 10690494]. [pmcid: 1987706].
Cohen I L. Establishing and justifying specialized teams in intensive care units for nutrition, ventilator management, and palliative care. Crit Care Clin. 93;9(3):511-20. [Rec#: 10306] Exclude at abstract screening: no outcomes specified.
Cohen L M, Germain M J, Poppel D M. Practical considerations in dialysis withdrawal: “to have that option is a blessing”. JAMA 2003;289(16):2113–9. Comment in: JAMA. Aug 13. 2003;290(6):815. PMID: 12915435. [Rec#: 1371] Exclude at abstract screening: no outcomes specified.
Cohen LM, Poppel DM, Cohn GM, and Reiter GS. A very good death: measuring quality of dying in end-stage renal disease. J Palliat Med 2001;4(2):167–72. Comment in: J Palliat Med. 2001 Summer;4(2):149–51. PMID: 11441622. [Rec#: 1374] Exclude at abstract screening: Observational study
Cohen M H, Anderson A J, Krasnow S H, Spagnolo S V, Citron M L, Payne M, Fossieck B E Jr. Continuous intravenous infusion of morphine for severe dyspnea. South Med J. 91;84(2):229-34. [Rec#: 1379] Exclude at abstract screening: Study Design - Qualitative.
Cohen S R, Leis A. What determines the quality of life of terminally ill cancer patients from their own perspective?. J Palliat Care. 2002;18(1):48-58. [Rec#: 1383] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12001403].
Cohen S R, Mount B M. Living with cancer: “good” days and “bad” days--what produces them? Can the McGill quality of life questionnaire distinguish between them?. Cancer. 2000;89(8):1854-65. [Rec#: 10314] Exclude at abstract screening: Title Only. [pmid: 11042583].
Cohen S R, Mount B M. Quality of life in terminal illness: defining and measuring subjective well-being in the dying. J Palliat Care. 92;8(3):40-5. [Rec#: 1384] Exclude at abstract screening: Title Only. [pmid: 1279149].
Cohen S R, Mount B M, Strobel M G, Bui F. The McGill Quality of Life Questionnaire: a measure of quality of life appropriate for people with advanced disease. A preliminary study of validity and acceptability. Palliat Med. 95;9(3):207-19. [Rec#: 1385] Exclude at abstract screening: Study Design - Unclear.
Cohen S R, Steiner W, Mount B M. Phototherapy in the treatment of depression in the terminally ill. J Pain Symptom Manage. 94;9(8):534-6. [Rec#: 1386] Exclude at abstract screening: Observational study. [pmid: 7852760].
Cohen S R, Hassan S A, Lapointe B J, Mount B M. Quality of life in HIV disease as measured by the McGill quality of life questionnaire. AIDS. 96;10(12):1421-7. [Rec#: 50863] Exclude at abstract screening: Study Design - Unclear.
Cohen S R, Mount B M, MacDonald N. Defining quality of life. European Journal of Cancer. 96;32A(5):753-4. [Rec#: 50345] Exclude at abstract screening: Title Only. [pmid: 9081349].
Cohen-Almagor R. Language and reality at the end of life. J Law Med Ethics 2000;28(3):267–78. Comment in: J Law Med Ethics. 2000 Fall;28(3):279–84. PMID: 11210380. [Rec#: 10304] Exclude at abstract screening: Title Only
Cohen-Mansfield J, Lipson S. Medical decisions for troubled breathing in nursing home residents. Int J Nurs Stud. 2002;39(5):557-61. [Rec#: 1377] Exclude at abstract screening: no outcomes specified. [pmid: 11996876].
Cohen-Mansfield J, Marx M S, Lipson S, Werner P. Predictors of mortality in nursing home residents. J Clin Epidemiol. 99;52(4):273-80. [Rec#: 1378] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 10235167].
Cohen-Mansfield J, Werner P, Freedman L. Sleep and agitation in agitated nursing home residents: an observational study. Sleep. 95;18(8):674-80. [Rec#: 31005] Exclude at abstract screening: not about end of life.
Cohen-Mansfield J. Nonpharmacologic interventions for inappropriate behaviors in dementia: a review, summary, and critique. Am J Geriatr Psychiatry. 2001;9(4):361-81. [Rec#: 31003] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 11739063].
Cohodes D R. Through the looking glass: decision making and chemotherapy. Health Aff (Millwood). 95;14(4):203-8. [Rec#: 10317] Exclude at abstract screening: Title Only. [pmid: 8690345].
Coia L R, Owen J B, Maher E J, Hanks G E. Factors affecting treatment patterns of radiation oncologists in the United States in the palliative treatment of cancer. Clin Oncol (R Coll Radiol). 92;4(1):6-10. [Rec#: 1388] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Coia L R. Palliative radiation therapy in the United States. Can J Oncol. 96;6(Suppl 1):62-8. discussion 84. [Rec#: 10318] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 8853540].
Cole D J. The reversibility of death. J Med Ethics. 92;18(1):26-30. discussion 31–3. [Rec#: 10322] Exclude at abstract screening: no outcomes specified. [pmid: 1573646].
Cole E J. The near death experience. Intensive Crit Care Nurs. 93;9(3):157-61. [Rec#: 10323] Exclude at abstract screening: no outcomes specified. [pmid: 8400743].
Cole R. Meditation in palliative care--a practical tool for self-management. Palliat Med. 97;11(5):411-3. [Rec#: 10325] Exclude at abstract screening: no outcomes specified. [pmid: 9472600].
Coleman E A. Falling through the cracks: challenges and opportunities for improving transitional care for persons with continuous complex care needs. Journal of the American Geriatrics Society. 2003;51(4):549-55. [Rec#: 50347] Exclude at abstract screening: no outcomes specified. [pmid: 12657078].
Coleman E A, Boult C. American Geriatrics Society Health Care Systems, Committee. Improving the quality of transitional care for persons with complex care needs. Journal of the American Geriatrics Society. 2003;51(4):556-7. [Rec#: 50348] Exclude at abstract screening: Title Only. [pmid: 12657079].
Coleman E A, Grothaus L C, Sandhu N, Wagner E H. Chronic care clinics: a randomized controlled trial of a new model of primary care for frail older adults.[see comment]. Journal of the American Geriatrics Society. 99;47(7):775-83. [Rec#: 50349] Exclude at abstract screening: not about end of life.
Collaud T, Rapin C H. Dehydration in dying patients: study with physicians in French-speaking Switzerland. J Pain Symptom Manage. 91;6(4):230-40. [Rec#: 10331] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
College of Family Physicians, Canada's Palliative Care Committee. What is happening in palliative care? Can Fam Physician 2001;47:2065–6, 2072–3. [Rec#: 10332] Exclude at abstract screening: Title Only
Collier K, Orme K, Sellers J B. How do you help family members of patients with cancer prepare for end-of-life care at home?. ONS News. 97;12(8):3-10. [Rec#: 10333] Exclude at abstract screening: Title Only. [pmid: 9335895].
Collins C, Ogle K. Patterns of predeath service use by dementia patients with a family caregiver. J Am Geriatr Soc. 94;42(7):719-22. [Rec#: 1404] Exclude at abstract screening: Other topic only. [pmid: 8014345].
Collins J, Shimoyama N, Bruera E, Takeda F, Kakizoe T, Sugimura T. Report of the Fourteenth International Symposium of the Foundation for Promotion of Cancer Research: Pain Control, Palliative Medicine and Psycho-oncology. Japanese Journal of Clinical Oncology. 2001;31(9):459-68. [Rec#: 50350] Exclude at abstract screening: Title Only. [pmid: 11689603].
Collopy B J. The moral underpinning of the proxy-provider relationship: issues of trust and distrust. J Law Med Ethics. 99;27(1):37-45. [Rec#: 10336] Exclude at abstract screening: no outcomes specified.
Colombo M, Sangiovanni A. The European approach to hepatocellular carcinoma. Hepatogastroenterology. 2002;49(43):12-6. [Rec#: 10337] Exclude at abstract screening: not about end of life. [pmid: 11941934].
Colombo N, Parma G, Bocciolone L, Franchi D, Sideri M, Maggioni A. Medical therapy of advanced malignant epithelial tumours of the ovary. Forum (Genova). 2000;10(4):323-32. [Rec#: 10338] Exclude at abstract screening: Title Only. [pmid: 11535983].
Colon K M. Bearing the bad news. Minn Med 95;78(2):10–4. Comment in: Minn Med. Feb. 1995;78(2):5. PMID: 7534377. [Rec#: 10339] Exclude at abstract screening: Title Only.
Colquhoun J P. Battles fought; battles lost. Aust Fam Physician. 90;19(12):1860-1. [Rec#: 10340] Exclude at abstract screening: Title Only. [pmid: 2275667].
Coluccio M, Maguire P. Collaborative practice: becoming a reality through primary nursing. Nursing Administration Quarterly. 83;7(4):59-63. [Rec#: 50351] Exclude at abstract screening: Title Only. [pmid: 6554479].
Coluzzi P H, Grant M, Doroshow J H, Rhiner M, Ferrell B, Rivera L. Survey of the provision of supportive care services at National Cancer Institute-designated cancer centers. J Clin Oncol. 95;13(3):756-64. [Rec#: 10346] Exclude at abstract screening: useful only for background.
Coluzzi P H, Schwartzberg L, Conroy J D, Charapata S, Gay M, Busch M A, Chavez J, Ashley J, Lebo D, McCracken M, Portenoy R K. Breakthrough cancer pain: a randomized trial comparing oral transmucosal fentanyl citrate (OTFC) and morphine sulfate immediate release (MSIR). Pain. 2001;91(12):123-30. [Rec#: 1414] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 11240084].
Coluzzi P H. Cancer pain management: newer perspectives on opioids and episodic pain. Am J Hosp Palliat Care. 98;15(1):13-22. [Rec#: 10345] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Colyer H. Women's experience of living with cancer. J Adv Nurs. 96;23(3):496-501. [Rec#: 10347] Exclude at abstract screening: not about end of life. [pmid: 8655824].
Comas-Diaz L, Jacobsen F M. Politics and South African mental health: hope, truth, and reconciliation. Cult Divers Ment Health. 96;2(2):133-8. [Rec#: 10348] Exclude at abstract screening: Title Only. [pmid: 9225569].
Comley A L, DeMeyer E. Assessing patient satisfaction with pain management through a continuous quality improvement effort. J Pain Symptom Manage. 2001;21(1):27-40. [Rec#: 1416] Exclude at abstract screening: not about end of life. [pmid: 11223312].
Conley V M, Burman M E. Informational needs of caregivers of terminal patients in a rural state. Home Healthc Nurse. 97;15(11):808-17. [Rec#: 1426] Exclude at abstract screening: Study Design - Qualitative.
Conn D K, Lieff S. Diagnosing and managing delirium in the elderly. Canadian Family Physician. 2001;47:101-108. [Rec#: 50352] Exclude at abstract screening: Title Only. [pmid: 11212421]. [pmcid: 2014716].
Connolly M. Palliative care Partners in care. Nurs Times. 94;90(44):58-61. [Rec#: 10364] Exclude at abstract screening: no outcomes specified. [pmid: 7527141].
Connolly M. Patients with non-malignant disease deserve an equitable service. Int J Palliat Nurs. 2000;6(2):91-3. [Rec#: 10365] Exclude at abstract screening: Title Only. [pmid: 11035628].
Connor S and Adams J. Caregiving at the end of life. Hastings Cent Rep 2003;Suppl:S8–9. [Rec#: 10366] Exclude at abstract screening: Title Only
Connor S R, McMaster J K. Hospice, bereavement intervention and use of health care services by surviving spouses. HMO Practice. 96;10(1):20-3. [Rec#: 50353] Exclude at abstract screening: Title Only. [pmid: 10155754].
Connors P. Should relatives be allowed in the resuscitation room?. Nurs Stand. 96;10(44):42-4. [Rec#: 10368] Exclude at abstract screening: no outcomes specified. [pmid: 8850759].
Connors R B Jr, Smith M L. Religious insistence on medical treatment. Christian theology and re-imagination. Hastings Center Report. 96;26(4):23-30. [Rec#: 50354] Exclude at abstract screening: no outcomes specified.
Conrad M. When it's time to say ‘good-bye’. Contemp Longterm Care. 2002;25(12):30. [Rec#: 10369] Exclude at abstract screening: Title Only. [pmid: 12528396].
Constantino R E, Bricker P L. Nursing postvention for spousal survivors of suicide. Issues Ment Health Nurs. 96;17(2):131-52. [Rec#: 10370] Exclude at abstract screening: Study Design - Unclear. [pmid: 8707534].
Continuum improves CHF patient education. Hosp Case Manag 99;7(2):29–32. [Rec#: 50017] Exclude at abstract screening: Title Only
Cook A M, Finlay I G, Butler-Keating R J. Recruiting into palliative care trials: lessons learnt from a feasibility study. Palliat Med. 2002;16(2):163-5. [Rec#: 10372] Exclude at abstract screening: Title Only. [pmid: 11969148].
Cook D, Rocker G, Heyland D. Dying in the ICU: strategies that may improve end-of-life care: [Mourir a l'USI : les strategies qui peuvent ameliorer les soins en fin de vie]. Can J Anaesth. 2004;51(3):266-272. [Rec#: 1445] Exclude at abstract screening: Study Design - Unclear. [pmid: 15010412].
Cook D J, Doolittle G C, Whitten P S. Administrator and provider perceptions of the factors relating to programme effectiveness in implementing telemedicine to provide end-of-life care. J Telemed Telecare. 2001;7(Suppl 2):17-9. [Rec#: 10379] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 11747648].
Cooke M A. The challenge of hospice nursing in the 90's. Am J Hosp Palliat Care. 92;9(1):34-7. [Rec#: 10381] Exclude at abstract screening: Title Only. [pmid: 1540426].
Cooke S, Wakefiel A, Chew-Graham C, Boggis C. Collaborative training in breaking bad news to patients. J Interprof Care. 2003;17(3):307-9. [Rec#: 10384] Exclude at abstract screening: Title Only. [pmid: 12879906].
Cooke D D, McNally L, Mulligan K T, Harrison M J, Newman S P. Psychosocial interventions for caregivers of people with dementia: a systematic review. Aging Ment Health. 2001;5(2):120-35. [Rec#: 50120] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 11511059].
Cooksley VG. Aromatherapy treatments for the respiratory system. Aromatherapy: A Lifetime Guide to Healing with Essential Oils 1996;<25 Page(s)>. [Rec#: 50355] Exclude at abstract screening: Title Only
Cooley C. Communication skills in palliative care. Prof Nurse. 2000;15(9):603-5. [Rec#: 10385] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11129941].
Cooley M E. Bereavement care. A role for nurses. Cancer Nurs. 92;15(2):125-9. [Rec#: 10386] Exclude at abstract screening: no outcomes specified. [pmid: 1617618].
Cooley M E. Quality of life in persons with non-small cell lung cancer: a concept analysis. Cancer Nurs. 98;21(3):151-61. [Rec#: 31064] Exclude at abstract screening: no outcomes specified. [pmid: 9615505].
Cooley M E. Symptoms in adults with lung cancer A systematic research review. J Pain Symptom Manage. 2000;19(2):137-53. [Rec#: 31065] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 10699541].
Coolican M B, Pearce T. After care bereavement program. Crit Care Nurs Clin North Am. 95;7(3):519-27. [Rec#: 10388] Exclude at abstract screening: sudden/violent/non-chronic deaths. [pmid: 7546514].
Coolican M B. After the loss--offering families something more. Nursing. 94;24(6):60-2. [Rec#: 10387] Exclude at abstract screening: Title Only. [pmid: 8008285].
Cooney J P Jr, Landers G M, Williams J M. Hospital executive leadership: a critical component for improving care at the end of life. Hosp Top. 2002;80(3):25-9. [Rec#: 10393] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12471882].
Cooper J K, Weber J A, Evans P, Juozapavicius K. End-of-life decisions: physicians as advocates for advance directives. J Am Osteopath Assoc. 2001;101(10):571-5. [Rec#: 1449] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11681163].
Cope D. Addressing patients' end-of-life needs: the role of the oncology nurse. Clin J Oncol Nurs. 2002;6(1):50-1. [Rec#: 10402] Exclude at abstract screening: Title Only. [pmid: 11842489].
Copp G, Dunn V. Frequent and difficult problems perceived by nurses caring for the dying in community, hospice and acute care settings. Palliat Med. 93;7(1):19-25. [Rec#: 10407] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Coppola K M, Danks J H, Ditto P H, Smucker W D. Perceived benefits and burdens of life-sustaining treatments: differences among elderly adults, physicians, and young adults. J Ethics Law Aging. 98;4(1):3-13. [Rec#: 1454] Exclude at abstract screening: Title Only.
Cordes M E, Brueggen C. Diffuse malignant pleural mesothelioma: Part II. Symptom management. Clin J Oncol Nurs. 2003;7(5):545-52. [Rec#: 10410] Exclude at abstract screening: no outcomes specified. [pmid: 14603551].
Cordice J W Jr. Carcinoma of the esophagus seen in a 12-year period at Queens Hospital Center. J Natl Med Assoc. 90;82(4):273-9. [Rec#: 10411] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Coristine M, Crooks D, Grunfeld E, Stonebridge C, Christie A. Caregiving for women with advanced breast cancer. Psychooncology. 2003;12(7):709-19. [Rec#: 10412] Exclude at abstract screening: Study Design - Qualitative. [pmid: 14502595].
Cork R C, Saleemi S, Ibrahim I, Mansour R, Alexander L. A survey of the adequacy of pain management in end-stage cancer patients. J La State Med Soc. 2003;155(3):150-3. [Rec#: 10413] Exclude at abstract screening: Title Only. [pmid: 12873101].
Corless I B, Nicholas P K. Long-term continuum of care for people living with HIV/AIDS. J Urban Health. 2000;77(2):176-86. [Rec#: 10416] Exclude at abstract screening: useful only for background. [pmid: 10855999].
Corless I B, Fulton R, Lamers E P, Bendiksen R, Hysing-Dahl B, MacElveen-Hoehn P, O'Conner P, Harvei U, Schjolberg T, Stevenson E. International Work Group on Death Dying and Bereavement. Assumptions and principles concerning care for persons affected by HIV disease. AIDS Public Policy J. 92;7(1):28-31. [Rec#: 10415] Exclude at abstract screening: Title Only.
Corless I B. Dying well: symptom control within hospice care. Annu Rev Nurs Res. 94;12:125-46. [Rec#: 10414] Exclude at abstract screening: Title Only. [pmid: 7527235].
Cornell D H. Can we manage pain?. N J Med. 97;94(5):41-4. [Rec#: 10418] Exclude at abstract screening: Title Only. [pmid: 9164103].
Corner J, O'Driscoll M. Development of a breathlessness assessment guide for use in palliative care. Palliat Med. 99;13(5):375-84. [Rec#: 10422] Exclude at abstract screening: no outcomes specified. [pmid: 10659109].
Corner J, Plant H, A'Hern R, Bailey C. Non-pharmacological intervention for breathlessness in lung cancer Palliat Med 96;10(4):299–305. Comment in: Palliat Med. Mar. 1997;11(2):170. PMID: 9156118. [Rec#: 31084] Exclude at abstract screening: Observational study.
Corner J. Nursing management in palliative care. Eur J Cancer. 2001;37(Suppl 7):S289-96. [Rec#: 10421] Exclude at abstract screening: no outcomes specified. [pmid: 11888002].
Corr C A, Doka K J. Current models of death, dying, and bereavement. Crit Care Nurs Clin North Am. 94;6(3):545-52. [Rec#: 10427] Exclude at abstract screening: no outcomes specified. [pmid: 7946209].
Corrigan F M. Parapsychotic grief, theory of mind and the concept of the soul. Med Hypotheses. 97;49(4):301-2. [Rec#: 10429] Exclude at abstract screening: no outcomes specified. [pmid: 9352498].
Cort M A. Cultural mistrust and use of hospice care: challenges and remedies. J Palliat Med. 2004;7(1):63-71. [Rec#: 1470] Exclude at abstract screening: no outcomes specified. [pmid: 15000784].
Costantini M, Camoirano E, Madeddu L, Bruzzi P, Verganelli E, Henriquet F. Palliative home care and place of death among cancer patients: a population-based study. Palliat Med. 93;7(4):323-31. [Rec#: 1477] Exclude at abstract screening: data older than 1990.
Costello J, Horne M. Nurses and health support workers' views on cardiopulmonary resuscitation in a hospice setting. Int J Palliat Nurs 2003;9(4):157–65. Comment in: Int J Palliat Nurs. Aug. 2003;9(8):360-1. author reply 361. PMID: 12971374. [Rec#: 10432] Exclude at abstract screening: no outcomes specified.
Costello J. Do Not Resuscitate orders and older patients: findings from an ethnographic study of hospital wards for older people. J Adv Nurs. 2002;39(5):491-9. [Rec#: 1481] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12175359].
Costello J. Helping relatives cope with the grieving process. Prof Nurse. 95;11(2):89-92. [Rec#: 10430] Exclude at abstract screening: no outcomes specified. [pmid: 7480059].
Costello P, Wiseman J, Douglas I, Batten B, Bennett M. Assessing hospice inpatients with pain using numerical rating scales. Palliat Med. 2001;15(3):257-8. [Rec#: 1486] Exclude at abstract screening: Title Only. [pmid: 11407198].
Cotton PB and Schmitt C. Quality of Life in palliative management of malignant obstructive jaundice. Scand J Gastroenterol Suppl 93;199:44–6. [Rec#: 10438] Exclude at abstract screening: no outcomes specified
Couldrick A. Optimizing bereavement outcome: reading the road ahead. Soc Sci Med. 92;35(12):1521-3. [Rec#: 10439] Exclude at abstract screening: no outcomes specified. [pmid: 1485199].
Coulehan J. A piece of my mind. Attention must be paid. JAMA. 2000;283(8):976. [Rec#: 10442] Exclude at abstract screening: Title Only. [pmid: 10697044].
Coulehan J. Building the ship of death. Am J Hosp Palliat Care. 2000;17(4):273-7. [Rec#: 10440] Exclude at abstract screening: Title Only. [pmid: 11883805].
Coulombe L. Talking with patients. Is it different when they are dying?. Can Fam Physician. 95;41:423-37. [Rec#: 10443] Exclude at abstract screening: no outcomes specified. [pmid: 7539652].
Council on Ethical and Judicial Affairs, American Medical Association. Decisions near the end of life. JAMA. 92;267:2229-2233. [Rec#: 50356] Exclude at abstract screening: Title Only.
Council on Ethical and Judicial Affairs, American Medical Association. Medical futility in end-of-life care. JAMA. 99;281(10):937-41. [Rec#: 50357] Exclude at abstract screening: no outcomes specified.
Council on Scientific Affairs, American Medical Association. Good care of the dying patient. JAMA. 96;275(6):474-478. [Rec#: 50358] Exclude at abstract screening: Title Only.
Counsell C and Guin P. Exploring family needs during withdrawal of life support in critically ill patients. Crit Care Nurs Clin North Am 2002;14(2):187–91, ix. [Rec#: 10447] Exclude at abstract screening: Study Design - Qualitative
Counsell C, Adorno G, Guin P. Establishing an end-of-life program in an academic acute care hospital. SCI Nurs. 2003;20(4):238-49. [Rec#: 1494] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 15005055].
Counts D A, Counts D. The good, the bad, and the unresolved death in Kaliai. Soc Sci Med. 2004;58(5):887-97. [Rec#: 10448] Notes: “EXCLUDE: Location, non-Western”. [pmid: 14732603].
Courneya K S, Friedenreich C M. Framework PEACE: an organizational model for examining physical exercise across the cancer experience. Ann Behav Med. 2001;23(4):263-72. [Rec#: 10449] Exclude at abstract screening: not about end of life. [pmid: 11761343].
Coviello J S, Hricz-Borges L, Masulli P S. Accomplishing quality of life in end-stage heart failure: a hospice multidisciplinary approach. Home Healthc Nurse. 2002;20(3):195-8. [Rec#: 1499] Exclude at abstract screening: not about end of life. [pmid: 11984182].
Covinsky K E, Eng C, Lui L Y, Sands L P, Yaffe K. The last 2 years of life: functional trajectories of frail older people. J Am Geriatr Soc. 2003;51(4):492-8. [Rec#: 1500] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 12657068].
Covinsky K E, Martin G E, Beyth R J, Justice A C, Sehgal A R, Landefeld C S. The relationship between clinical assessments of nutritional status and adverse outcomes in older hospitalized medical patients. Journal of the American Geriatrics Society. 99;47(5):532-8. [Rec#: 50360] Exclude at abstract screening: primarily prognosis or trajectories.
Covinsky K E, Wu A W, Landefeld C S, Connors A F Jr, Phillips R S, Tsevat J, Dawson N V, Lynn J, Fortinsky R H. Health status versus quality of life in older patients: does the distinction matter?. American Journal of Medicine. 99;106(4):435-40. [Rec#: 50361] Exclude at abstract screening: not about end of life.
Cowan J D, Palmer T W. Practical guide to palliative sedation. Curr Oncol Rep. 2002;4(3):242-9. [Rec#: 10454] Exclude at abstract screening: no outcomes specified. [pmid: 11937015].
Cowan J D, Burns D, Palmer T W, Scott J, Feeback E. A palliative medicine program in a community setting: 12 points from the first 12 months. Am J Hosp Palliat Care. 2003;20(6):415-33. [Rec#: 1503] Exclude at abstract screening: useful only for background. [pmid: 14649559].
Cowan J D, Walsh D, Homsi J. Palliative medicine in a United States cancer center: a prospective study. Am J Hosp Palliat Care. 2002;19(4):240-50. [Rec#: 1504] Exclude at abstract screening: Title Only. [pmid: 12141788].
Cowan J D. The dying patient. Curr Oncol Rep. 2000;2(4):331-7. [Rec#: 10453] Exclude at abstract screening: no outcomes specified. [pmid: 11122861].
Cowan J D, Walsh D. Terminal sedation in palliative medicine--definition and review of the literature. Support Care Cancer. 2001;9(6):403-7. [Rec#: 50121] Exclude at abstract screening: not about end of life. [pmid: 11585266].
Coward D D, Reed P G. Self-transcendence: a resource for healing at the end of life. Issues Ment Health Nurs. 96;17(3):275-88. [Rec#: 10455] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Coward D D. Meaning and purpose in the lives of persons with AIDS. Public Health Nurs. 94;11(5):331-6. [Rec#: 1507] Exclude at abstract screening: Observational study. [pmid: 7971698].
Cowart D, Burt R. Confronting death. Who chooses, who controls? A dialogue between Dax Cowart and Robert Burt. Hastings Cent Rep. 98;28(1):14-24. [Rec#: 10456] Exclude at abstract screening: Title Only. [pmid: 9539043].
Cowen A R. Death, dying and grieving. Dealing with personal and work-related tragedies. Emerg Med Serv. 98;27(1):110-109. [Rec#: 10457] Exclude at abstract screening: Title Only. [pmid: 10177855].
Cowie M R, Fox K F, Wood D A, Metcalfe C, Thompson S G, Coats A J, Poole-Wilson P A, Sutton G C. Hospitalization of patients with heart failure: a population-based study. Eur Heart J 2002;23(11):877–85. Comment in: Eur Heart J. Jun. 2002;23(11):842-5. PMID: 12042004. [Rec#: 50018] Exclude at abstract screening: Title Only.
Cowles K V, Rodgers B L. Concept of grief. J Adv Nurs 96;23(5):1055–7. Comment on: J Adv Nurs. Nov. 1993;18(11):1787-94. PMID: 8288825. [Rec#: 10458] Exclude at abstract screening: Title Only.
Cowles K V. Cultural perspectives of grief: an expanded concept analysis. J Adv Nurs. 96;23(2):287-94. [Rec#: 1508] Exclude at abstract screening: Study Design - Qualitative. [pmid: 8708241].
Cowley G, Hager M. Terminal care: too painful, too prolonged. Newsweek. 95;126(23):74-5. [Rec#: 10461] Exclude at abstract screening: Title Only. [pmid: 10153298].
Cowley S. Continuing care. Who qualifies for terminal care?. Nurs Times. 90;86(22):29-31. [Rec#: 10462] Exclude at abstract screening: Title Only. [pmid: 2112742].
Cox C. Hospice care for persons with AIDS: findings from a national study. Hosp J. 98;13(3):21-34. [Rec#: 1513] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 9677955].
Cox C. Non-pharmacological treatment of breathlessness. Nurs Stand. 2002;16(24):33-6. [Rec#: 10463] Exclude at abstract screening: useful only for background. [pmid: 11917513].
Cox J M, Pappagallo M. Modafinil: a gift to portmanteau. Am J Hosp Palliat Care. 2001;18(6):408-10. [Rec#: 10464] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 11712723].
Coyle D, Small N, Ashworth A, Hennessy S, Jenkins-Clarke S, Mannion R, Rice N, Ahmedzai S. Costs of palliative care in the community, in hospitals and in hospices in the UK. Crit Rev Oncol Hematol. 99;32(2):71-85. [Rec#: 1515] Exclude at abstract screening: Title Only.
Coyle M A. Meeting the needs of the family: the role of the specialist nurse in the management of brain death. Intensive Crit Care Nurs. 2000;16(1):45-50. [Rec#: 10467] Exclude at abstract screening: useful only for background. [pmid: 10790714].
Coyle N, Adelhardt J, Foley K M, Portenoy R K. Character of terminal illness in the advanced cancer patient: pain and other symptoms during the last four weeks of life. J Pain Symptom Manage 90;5(2):83–93. Comment in: J Pain Symptom Manage. Oct. 1991;6(7):408-10. PMID: 1940484. [Rec#: 1519] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Coyne P J, Lyne M E, Watson A C. Symptom management in people with AIDS. Am J Nurs. 2002;102(9):48-56. [Rec#: 1522] Exclude at abstract screening: Title Only. [pmid: 12394019].
Coyne P J, Viswanathan R, Smith T J. Nebulized fentanyl citrate improves patients' perception of breathing, respiratory rate, and oxygen saturation in dyspnea. J Pain Symptom Manage. 2002;23(2):157-60. [Rec#: 1523] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 11844637].
Craig M. Volunteer services. American Journal of Hospice & Palliative Care. 94;11(2):33-5. [Rec#: 50362] Exclude at abstract screening: no outcomes specified. [pmid: 7880635].
Crain M. A cross-cultural study of beliefs, attitudes and values in Chinese-born American and non-Chinese frail homebound elderly. J Long Term Home Health Care. 96;15(1):9-18. [Rec#: 1529] Exclude at abstract screening: Title Only.
Cramer L D, McCorkle R, Cherlin E, Johnson-Hurzeler R, Bradley E H. Nurses' attitudes and practice related to hospice care. J Nurs Scholarsh. 2003;35(3):249-55. [Rec#: 10482] Exclude at abstract screening: no outcomes specified. [pmid: 14562493].
Cramond W, Fraenkel M, Barratt L. On letting go: the patient, haemodialysis and opting out. Aust N Z J Psychiatry. 90;24(2):268-75. [Rec#: 1530] Exclude at abstract screening: no outcomes specified. [pmid: 2396968].
Crane R A, Wilson P C, Behrens G. Pain control in hospice home care: management guidelines. Am J Hosp Palliat Care. 90;7(6):39-42. [Rec#: 10484] Exclude at abstract screening: useful only for background.
Cranford R E. Medical futility: transforming a clinical concept into legal and social policies. J Am Geriatr Soc. 94;42(8):894-8. [Rec#: 10485] Exclude at abstract screening: useful only for background.
Craun M J, Watkins M, Hefty A. Hospice care of the psychotic patient. Am J Hosp Palliat Care. 97;14(4):205-8. [Rec#: 10486] Exclude at abstract screening: no outcomes specified. [pmid: 9295431].
Craven O. Palliative care provision and its impact on psychological morbidity in cancer patients. Int J Palliat Nurs. 2000;6(10):501-7. [Rec#: 1535] Exclude at abstract screening: no outcomes specified. [pmid: 12271249].
Cravens D D, Anderson C M. Relieving non-pain suffering at the end-of-life. Mo Med. 2003;100(1):76-81. [Rec#: 10487] Exclude at abstract screening: no outcomes specified. [pmid: 12664709].
Crawford G B, Price S D. Team working: palliative care as a model of interdisciplinary practice. Med J Aust. 2003;179(6 Suppl):S32-4. [Rec#: 10488] Exclude at abstract screening: no outcomes specified. [pmid: 12964934].
Crawford H. Patient information for pain control in palliative care. Nurs Stand. 97;11(48):42-4. [Rec#: 10489] Exclude at abstract screening: no outcomes specified. [pmid: 9335865].
Crawley L, Payne R, Bolden J, Payne T, Washington P, Williams S. Initiative to Improve Palliative and End-of-Life Care in the African American Community. Palliative and end-of-life care in the African American community. JAMA. 2000;284(19):2518-21. [Rec#: 10492] Exclude at abstract screening: useful only for background. [pmid: 11074786].
Crawley L M, Marshall P A, Lo B, Koenig B A. End-of-Life Care Consensus Panel. Strategies for culturally effective end-of-life care. Ann Intern Med. 2002;136(9):673-9. [Rec#: 1538] Exclude at abstract screening: useful only for background. [pmid: 11992303].
Crawley L M. Miracles and medicine: helping families navigate the cours. J Pain Symptom Manage 2003;25(2):192–4. Comment on: J Pain Symptom Manage. Feb. 2003;25(2):191-2. PMID: 12590035. [Rec#: 10493] Exclude at abstract screening: no outcomes specified.
Crawley L M. Palliative care in African American communities. Journal of Palliative Medicine. 2002;5(5):775-9. [Rec#: 50364] Exclude at abstract screening: useful only for background. [pmid: 12572983].
Crawley L, Payne R, Bolden J, Payne T, Washington P, Williams S. Initiative to Improve, Palliative, and End-of-Life Care in the African American, Community. Palliative and end-of-life care in the African American community. JAMA. 2000;284(19):2518-21. [Rec#: 50363] Exclude at abstract screening: Title Only. [pmid: 11074786].
Creagan E T. How to break bad news--and not devastate the patient. Mayo Clin Proc. 94;69(10):1015-7. [Rec#: 10495] Exclude at abstract screening: Title Only. [pmid: 7934184].
Crego P J, Lipp E J. Nurses' knowledge of advance directives. Am J Crit Care 98;7(3):218–23. Comment in: Am J Crit Care. Sep. 1998;7(5):398. PMID: 9740892. [Rec#: 1542] Exclude at abstract screening: useful only for background.
Cressey R W, Winbolt-Lewis M. The forgotten heart of care: a model of spiritual care in the National Health Service. Accid Emerg Nurs. 2000;8(3):170-7. [Rec#: 10498] Exclude at abstract screening: no outcomes specified. [pmid: 10893562].
Cresswell S M, English P J, Hall R R, Roberts J T, Marsh M M. Pain relief and quality-of-life assessment following intravenous and oral clodronate in hormone-escaped metastatic prostate cancer. Br J Urol. 95;76(3):360-5. [Rec#: 10499] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Cringles M C. Developing an integrated care pathway to manage cancer pain across primary, secondary and tertiary care. Int J Palliat Nurs. 2002;8(5):247-55. [Rec#: 10501] Exclude at abstract screening: no outcomes specified. [pmid: 12048508].
Critchley P, Jadad A R, Taniguchi A, Woods A, Stevens R, Reyno L, Whelan T J. Are some palliative care delivery systems more effective and efficient than others? A systematic review of comparative studies. J Palliat Care. 99;15(4):40-7. [Rec#: 10504] Exclude at abstract screening: Title Only.
Critchley P P, Grantham M, Plach N, Bedard M, Oglan G. An evaluation of the use of and satisfaction with the Palliative Care Pain and Symptom Pocket Card. J Palliat Care. 2002;18(4):307-11. [Rec#: 10505] Exclude at abstract screening: Title Only. [pmid: 12611323].
Critchlow J, Bauer-Wu S M. Dehydration in terminally ill patients. Perceptions of long-term care nurses. J Gerontol Nurs. 2002;28(12):31-9. quiz 48–9. [Rec#: 1549] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12567824].
Crow HE. How to help patients understand and conquer grief. Avoiding depression in the midst of sadness. Postgrad Med 91;89(8):117–8, 121–2. [Rec#: 10516] Exclude at abstract screening: no outcomes specified
Cull A, Gregor A, Hopwood P, Macbeth F, Karnicka-Mlodkowska H, Thatcher N, Burt P, Stout R, Stepniewska K, Stewart M. Neurological and cognitive impairment in long-term survivors of small cell lung cancer. Eur J Cancer. 94;30A(8):1067-74. [Rec#: 31139] Exclude at abstract screening: not about end of life.
Culture, Projects in Death in America and the Center on Crime and. Proceedings from the First National Conference on death and dying in prisons and jails: Caring for prisoners, families, and caregivers. Journal of Law and Medicine 99;27(3). [Rec#: 50365] Exclude at abstract screening: useful only for background
Cummings C M. Advance planning for end-of life care. Adv Nurse Pract. 98;6(7):24. [Rec#: 10524] Exclude at abstract screening: Title Only.
Cummings S M. Adequacy of discharge plans and rehospitalization among hospitalized dementia patients. Health Soc Work. 99;24(4):249-59. [Rec#: 50019] In abstract review process. [pmid: 10605630].
Cunningham D, Pyrhonen S, James R D, Punt C J, Hickish T F, Heikkila R, Johannesen T B, Starkhammar H, Topham C A, Awad L, Jacques C, Herait P. Randomised trial of irinotecan plus supportive care versus supportive care alone after fluorouracil failure for patients with metastatic colorectal cancer. Lancet 98;352(9138):1413–8. Comment in: Lancet. 1998 Oct 31;352(9138):1402. PMID: 9807982. Comment in: Lancet. Apr 10. 1999;353(9160):1275-6. PMID: 10217115. [Rec#: 1577] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Cunningham L, Nagy V T. Bereavement support in the HMO. HMO Pract. 94;8(1):43-5. [Rec#: 10528] Exclude at abstract screening: Title Only. [pmid: 10132941].
Curl A. When family caregivers grieve for the Alzheimer's patient. Family caregivers face special difficulties in grieving for loved ones whose personalities die long before they do. Geriatr Nurs. 92;13(6):305-7. [Rec#: 10529] Exclude at abstract screening: Title Only.
Currow D C. Palliative service provision in Australia. Med J Aust 2001;175(10):534–6. Comment on: Med J Aust. 2001 Nov 19;175(10):526–9. PMID: 11795541. Comment on: Med J Aust. Nov 19. 2001;175(10):530-3. PMID: 11795542. [Rec#: 10532] Exclude at abstract screening: no outcomes specified.
Curtin L L. Promoting comfort and relieving pain in dying patients. Nurs Manage. 95;26(8):64-5. [Rec#: 10536] Exclude at abstract screening: Title Only.
Curtis C. Hypnotherapy in a specialist palliative care unit: evaluation of a pilot service. Int J Palliat Nurs. 2001;7(12):604-9. [Rec#: 10537] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11842684].
Curtis E B, Walsh T D. Prescribing practices of a palliative care service. J Pain Symptom Manage. 93;8(5):312-6. [Rec#: 1582] Exclude at abstract screening: Other topic only. [pmid: 7525747].
Curtis J R, Patrick D L. Barriers to communication about end-of-life care in AIDS patients. J Gen Intern Med 97;12(12):736–41. Comment in: J Gen Intern Med. Dec. 1997;12(12):784-6. PMID: 9436900. [Rec#: 1584] Exclude at abstract screening: Study Design - Qualitative.
Curtis J R, Engelberg R A, Wenrich M D, Nielsen E L, Shannon S E, Treece P D, Tonelli M R, Patrick D L, Robins L S, McGrath B B, Rubenfeld G D. Studying communication about end-of-life care during the ICU family conference: development of a framework. J Crit Care. 2002;17(3):147-60. [Rec#: 1583] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12297990].
Curtis J R, Patrick D L, Engelberg R A, Norris K, Asp C, Byock I. A measure of the quality of dying and death. Initial validation using after-death interviews with family members. J Pain Symptom Manage. 2002;24(1):17-31. [Rec#: 1588] Exclude at abstract screening: Title Only. [pmid: 12183092].
Curtis J R, Patrick D L, Shannon S E, Treece P D, Engelberg R A, Rubenfeld G D. The family conference as a focus to improve communication about end-of-life care in the intensive care unit: opportunities for improvement. Crit Care Med. 2001;29(2 Suppl):N26-33. [Rec#: 10541] Exclude at abstract screening: no outcomes specified. [pmid: 11228570].
Curtis J R, Wenrich M D, Carline J D, Shannon S E, Ambrozy D M, Ramsey P G. Patients' perspectives on physician skill in end-of-life care: differences between patients with COPD, cancer, and AIDS. Chest 2002;122(1):356–62. comment in: Chest. Aug. 2003;124(2):771-2. PMID: 12907579. [Rec#: 1589] Exclude at abstract screening: Study Design - Qualitative.
Curtis J R, Wenrich M D, Carline J D, Shannon S E, Ambrozy D M, Ramsey P G. Understanding physicians' skills at providing end-of-life care perspectives of patients, families, and health care workers. J Gen Intern Med 2001;16(1):41–9. Comment in: J Gen Intern Med. 2001;16(1):68-9. PMID: 11251753. [Rec#: 1590] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Curtis J R. Communicating with patients and their families about advance care planning and end-of-life care. Respir Care. 2000;45(11):1385-94. discussion 1394–8. [Rec#: 10538] Exclude at abstract screening: Title Only. [pmid: 11063526].
Curtis J R. The long-term outcomes of mechanical ventilation: what are they and how should they be used?. Respir Care. 2002;47(4):496-505. discussion 505–7. [Rec#: 10539] Exclude at abstract screening: useful only for background. [pmid: 11929620].
Cutcliffe J R, Black C, Hanson E, Goward P. The commonality and synchronicity of mental health nurses and palliative care nurses: closer than you think? Part two. J Psychiatr Ment Health Nurs. 2001;8(1):61-6. [Rec#: 10545] Exclude at abstract screening: not about end of life. [pmid: 11879495].
Cutcliffe J R, Black C, Hanson E, Goward P. The commonality and synchronicity of mental health nurses and palliative care nurses: closer than you think? Part one. J Psychiatr Ment Health Nurs. 2001;8(1):53-9. [Rec#: 10546] Exclude at abstract screening: not about end of life. [pmid: 11879494].
Cutcliffe J R. Hope, counselling and complicated bereavement reactions. J Adv Nurs. 98;28(4):754-61. [Rec#: 10543] Exclude at abstract screening: no outcomes specified. [pmid: 9829663].
Cutcliffe J R. How do nurses inspire and instil hope in terminally ill HIV patients?. J Adv Nurs. 95;22(5):888-95. [Rec#: 10544] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Cutler R B, Fishbain D A, Lu Y, Rosomoff R S, Rosomoff H L. Prediction of pain center treatment outcome for geriatric chronic pain patients. Clin J Pain 94;10(1):10–7. comment in: Clin J Pain. Mar. 1994;10(1):1-2. PMID: 7514912. [Rec#: 1597] Exclude at abstract screening: not about end of life.
Cyhan T. Dying for relief. When pain relief could result in death. Am J Nurs. 2001;101(2):59. [Rec#: 10547] Exclude at abstract screening: Title Only. [pmid: 11227231].
Cykert S, Joines J D, Kissling G, Hansen C J. Racial differences in patients' perceptions of debilitated health states. J Gen Intern Med 99;14(4):217–22. comment in: J Gen Intern Med. Apr. 1999;14(4):260-1. PMID: 10203641. [Rec#: 1604] Exclude at abstract screening: not about end of life.
Czerwiec M. When a loved one is dying: families talk about nursing care. Am J Nurs. 96;96(5):32-6. [Rec#: 1606] Exclude at abstract screening: Title Only. [pmid: 8644792].
Daaleman T P, Frey B. Prevalence and patterns of physician referral to clergy and pastoral care providers. Arch Fam Med. 98;7(6):548-53. [Rec#: 1611] Exclude at abstract screening: Other topic only. [pmid: 9821829].
Daaleman T P, VandeCreek L. Placing religion and spirituality in end-of-life care. JAMA. 2000;284(19):2514-7. [Rec#: 10552] Exclude at abstract screening: Title Only. [pmid: 11074785].
Daeninck P J, Bruera E. Opioid use in cancer pain. Is a more liberal approach enhancing toxicity?. Acta Anaesthesiologica Scandinavica. 99;43(9):924-38. [Rec#: 50366] Exclude at abstract screening: no outcomes specified.
Daggett L M. Living with loss: middle-aged men face spousal bereavement. Qual Health Res. 2002;12(5):625-39. [Rec#: 1613] Exclude at abstract screening: Observational study. [pmid: 11993560].
Dahl J L. Effective pain management in terminal care. Clin Geriatr Med. 96;12(2):279-300. [Rec#: 10556] Exclude at abstract screening: no outcomes specified. [pmid: 8799348].
Dahl J L. State cancer pain initiatives. J Pain Symptom Manage. 93;8(6):372-5. [Rec#: 10557] Exclude at abstract screening: no outcomes specified. [pmid: 7525754].
Dahlin C M. Access to care. Hosp J. 99;14(34):75-84. [Rec#: 10558] Exclude at abstract screening: no outcomes specified. [pmid: 10839003].
Dalrymple J L, Levenback C, Wolf J K, Bodurka D C, Garcia M, Gershenson D M. Trends among gynecologic oncology inpatient deaths: is end-of-life care improving?. Gynecol Oncol. 2002;85(2):356-61. [Rec#: 1625] Exclude at abstract screening: useful only for background. [pmid: 11972400].
Dalton S O, Boesen E H, Ross L, Schapiro I R, Johansen C. Mind and cancer. do psychological factors cause cancer?. Eur J Cancer. 2002;38(10):1313-23. [Rec#: 10562] Exclude at abstract screening: useful only for background. [pmid: 12091060].
Dalton V. Death and dying in prison in Australia: national overview, 1980-1998. J Law Med Ethics 99;27(3):269–74, 210. [Rec#: 1628] Exclude at abstract screening: not about end of life
Daly B J. Organizational change and delivery of multidisciplinary palliative care. Respir Care. 2000;45(12):1501-10. [Rec#: 10563] Exclude at abstract screening: useful only for background. [pmid: 11107216].
Daly BJ Withholding nutrition and hydration revisited. Nurs Manage 95;26(5):30, 33, 37–9 Comment on: Nurs Manage 1994 Oct 25 (10) 30, 33, 37–9. Comment on: Nurs Manage. 1994 Oct;25(10):81–2, 85–9. PMID: 7605423. [Rec#: 10564] Exclude at abstract screening: no outcomes specified
Damato A N, Chokhavatia S, Grigoriu A, Patel A, Cronin T. Advance directives for HIV-positive patients. N J Med. 93;90(8):589-94. [Rec#: 1632] Exclude at abstract screening: not about end of life. [pmid: 8414205].
Damato A N, Reddy T K, Rusche P, Ramakrishna S, Christoffersen G, Getsos J, Feinsod R, Reisner M, Costa D, McCreath J. Advance directives for the elderly: a survey. N J Med. 93;90(3):215-20. [Rec#: 1633] Exclude at abstract screening: not about end of life.
Danforth J C. Quality of life is the issue in care for terminally ill. Mod Healthc. 96;26(36):49. [Rec#: 10567] Exclude at abstract screening: Title Only. [pmid: 10159818].
Daniels G A, Adjei A A. Advances in systemic therapy of small cell cancer of the lung. Expert Rev Anticancer Ther. 2001;1(2):211-21. [Rec#: 10569] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 12113026].
Daniels L, Linnane J. Developing a framework for primary palliative care services. Br J Community Nurs. 2001;6(11):592-600. [Rec#: 1638] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11832804].
Daniels L. Palliative care in a primary care-led NHS. Prof Nurse. 2000;15(7):471-5. [Rec#: 10571] Exclude at abstract screening: useful only for background. [pmid: 11129932].
Darr K. The manager and pain control for patients. Hosp Top. 2001;79(4):27-9. [Rec#: 10581] Exclude at abstract screening: no outcomes specified. [pmid: 11942088].
Das A, Sivak M V Jr. Endoscopic palliation for inoperable pancreatic cancer. Cancer Control. 2000;7(5):452-7. [Rec#: 10582] Exclude at abstract screening: Other topic only. [pmid: 11000615].
Datson S L, Marwit S J. Personality constructs and perceived presence of deceased loved ones. Death Stud. 97;21(2):131-46. [Rec#: 1647] Exclude at abstract screening: Bereavement only. [pmid: 10169688].
Daugherty SJ. It's never over. Addressing AIDS bereavement. Caring 93;12(5):42–4, 46. [Rec#: 10584] Exclude at abstract screening: no outcomes specified
Daugird A, Spencer D. Physician reactions to the health care revolution. A grief model approach. Arch Fam Med. 96;5(9):497-500. discussion 501. [Rec#: 10585] Exclude at abstract screening: not about end of life.
David A S, Mary R, Neil S, James G. Deaths from heart failure in general practice: implications for palliative care. Palliat Med. 2002;16(6):495-8. [Rec#: 10586] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 12465696].
Davidhizar R, Giger J N. Patients' use of denial: coping with the unacceptable. Nurs Stand. 98;12(43):44-6. [Rec#: 10591] Exclude at abstract screening: no outcomes specified. [pmid: 9776932].
Davidhizar R, Poole V, Giger J N, Henderson M. When your patient uses denial. J Pract Nurs. 98;48(2):10-4. [Rec#: 10594] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Davidson J R, Gaylord S. Homeopathic and psychiatric perspectives on grief. Altern Ther Health Med. 98;4(5):30-5. [Rec#: 10596] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 9737029].
Davidson K M. Evidence-based protocol. Family bereavement support before and after the death of a nursing home resident. J Gerontol Nurs. 2003;29(1):10-8. [Rec#: 1656] Exclude at abstract screening: no outcomes specified. [pmid: 12596333].
Davidson P, Introna K, Daly J, Paull G, Jarvis R, Angus J, Wilds T, Cockburn J, Dunford M, Dracup K. Cardiorespiratory nurses' perceptions of palliative care in nonmalignant disease: data for the development of clinical practice. Am J Crit Care. 2003;12(1):47-53. [Rec#: 10598] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12526237].
Davidson P M, Introna K, Cockburn J, Daly J, Dunford M, Paull G, Dracup K. Synergizing acute care and palliative care to optimise nursing care in end-stage cardiorespiratory disease. Aust Crit Care. 2002;15(2):64-9. [Rec#: 10599] Exclude at abstract screening: useful only for background. [pmid: 12154699].
Davidson S N. Pain and opiophobia. Healthc Forum J. 97;40(3):64-7. [Rec#: 10601] Exclude at abstract screening: no outcomes specified. [pmid: 10172996].
Davies A N. A comparison of artificial saliva and chewing gum in the management of xerostomia in patients with advanced cancer. Palliat Med. 2000;14(3):197-203. [Rec#: 1660] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 10858827].
Davies B, Oberle K. Dimensions of the supportive role of the nurse in palliative care. Oncol Nurs Forum. 90;17(1):87-94. [Rec#: 10602] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Davies B, Reimer J C, Martens N. Families in supportive care--Part I: The transition of fading away: the nature of the transition. J Palliat Care. 90;6(3):12-20. [Rec#: 1666] Exclude at abstract screening: Study Design - Qualitative.
Davies B, Reimer J C, Martens N. Family functioning and its implications for palliative care. J Palliat Care. 94;10(1):29-36. [Rec#: 1667] Exclude at abstract screening: Study Design - Unclear. [pmid: 7518507].
Davies J, McVicar A. Balancing efficiency, cost-effectiveness and patient choice in opioid selection. Int J Palliat Nurs. 2000;6(10):470-8. [Rec#: 10605] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 12271245].
Davies M, Sque M. Living on the outside looking in: a theory of living with advanced breast cancer. Int J Palliat Nurs. 2002;8(12):583-90. [Rec#: 1674] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12560800].
Davies N, Curtis M. Providing palliative care in end-stage heart failure. Prof Nurse. 2000;15(6):389-92. [Rec#: 10609] Exclude at abstract screening: useful only for background. [pmid: 11144184].
Davila F. The impact of do-not-resuscitate and patient care category policies on CPR and ventilator support rates. Arch Intern Med. 96;156(4):405-8. [Rec#: 40795] Exclude at abstract screening: data older than 1990.
Davis B D, Cowley S A, Ryland R K. The effects of terminal illness on patients and their carers. J Adv Nurs. 96;23(3):512-20. [Rec#: 1681] Exclude at abstract screening: Study Design - Unclear. [pmid: 8655826].
Davis C G, Nolen-Hoeksema S, Larson J. Making sense of loss and benefiting from the experience: two construals of meaning. J Pers Soc Psychol. 98;75(2):561-74. [Rec#: 1682] Exclude at abstract screening: Study Design - Unclear.
Davis C G, Wortman C B, Lehman D R, Silver R C. Searching for meaning in loss: are clinical assumptions correct. Death Stud 2000;24(6):497–540. Comment in: Death Stud. Sep. 2000;24(6):541-58. PMID: 11503667. [Rec#: 10616] Exclude at abstract screening: Study Design - Unclear.
Davis D P. Cultural differences and the practice of medicine. Health Care Anal. 93;1(1):101-2. [Rec#: 10619] Exclude at abstract screening: Title Only. [pmid: 10134351].
Davis J M, Hoshiko B R, Jones S, Gosnell D. The effect of a support group on grieving individuals' levels of perceived support and stress. Arch Psychiatr Nurs. 92;6(1):35-9. [Rec#: 1687] Exclude at abstract screening: Observational study.
Davis M P, Dickerson E D, Pappagallo M, Varga J, Shuster J Jr, Benedetti C. Palliative care: a long-term solution for long-term care. Part 3: analgesic therapy. Home Care Provid. 2001;6(5):164-70. quiz 171, 1p after 176. [Rec#: 10629] Exclude at abstract screening: useful only for background. [pmid: 11581590].
Davis M P, Walsh D, Nelson K, Konrad D, LeGrand S B. The business of palliative medicine: management metrics for an acute-care inpatient unit. Am J Hosp Palliat Care. 2001;18(1):26-9. [Rec#: 10631] Exclude at abstract screening: not about end of life. [pmid: 11406874].
Davis N, Pohlman A, Gehlbach B, Kress J P, McAtee J, Herlitz J, Hall J. Improving the process of informed consent in the critically ill. JAMA 2003;289(15):1963–8. Comment in: JAMA. 2003 Aug 13;290(6):751; author reply 752. PMID: 12915421. Comment in: JAMA. Aug 13. 2003;290(6):751. author reply 752. PMID: 12915420. [Rec#: 40799] Exclude at abstract screening: not about end of life.
Davis M P, Walsh D, LeGrand S B, Naughton M. Symptom control in cancer patients: the clinical pharmacology and therapeutic role of suppositories and rectal suspensions. Supportive Care in Cancer. 2002;10(2):117-38. [Rec#: 50367] Exclude at abstract screening: no outcomes specified. [pmid: 11862502].
Davison D, Johnston G, Reilly P, Stevenson M. Where do patients with cancer die in Belfast?. Ir J Med Sci. 2001;170(1):18-23. [Rec#: 1697] Exclude at abstract screening: useful only for background. [pmid: 11440406].
Davison S N. Quality end-of-life care in dialysis units. Semin Dial. 2002;15(1):41-4. [Rec#: 1698] Exclude at abstract screening: no outcomes specified. [pmid: 11874592].
Davison B J, Goldenberg S L, Gleave M E, Degner L F. Provision of individualized information to men and their partners to facilitate treatment decision making in prostate cancer. Oncol Nurs Forum. 2003;30(1):107-14. [Rec#: 50369] Exclude at abstract screening: not about end of life. [pmid: 12515988].
Davison B J, Kirk P, Degner L F, Hassard T H. Information and patient participation in screening for prostate cancer. Patient Education & Counseling. 99;37(3):255-63. [Rec#: 50370] Exclude at abstract screening: not about end of life.
Dawe U, Verhoef M, Roman-Smith H. Personal directives: Part IV. Alberta nurses see benefits for patients, families and caregivers. AARN News Lett. 97;53(4):15-6. [Rec#: 10635] Exclude at abstract screening: no outcomes specified.
Dawson S, Kristjanson L J. Mapping the journey: family carers' perceptions of issues related to end-stage care of individuals with muscular dystrophy or motor neurone disease. J Palliat Care. 2003;19(1):36-42. [Rec#: 10639] Exclude at abstract screening: Observational study. [pmid: 12710113].
Dawson S. The role of occupational therapy groups in an Australian hospice. Am J Hosp Palliat Care. 93;10(4):13-7. [Rec#: 10638] Exclude at abstract screening: Study Design - Qualitative. [pmid: 8329244].
Dawson R, Spross J A, Jablonski E S, Hoyer D R, Sellers D E, Solomon M Z. Probing the paradox of patients' satisfaction with inadequate pain management. Journal of Pain & Symptom Management. 2002;23(3):211-20. [Rec#: 50371] Exclude at abstract screening: Study Design - Unclear. [pmid: 11888719].
Day L, Drought T, Davis A J. Principle-based ethics and nurses' attitudes towards artificial feeding. J Adv Nurs. 95;21(2):295-8. [Rec#: 10641] Exclude at abstract screening: Study Design - Qualitative. [pmid: 7714286].
Day L. Practical limits to the Uniform Determination of Death Act. J Neurosurg Nurs. 95;27(5):319-22. [Rec#: 10640] Exclude at abstract screening: Title Only. [pmid: 11658139].
Day R. The use of epidural and intrathecal analgesia in palliative care. Int J Palliat Nurs. 2001;7(8):369-74. [Rec#: 10643] Exclude at abstract screening: Non-systematic review. [pmid: 11951780].
Dayidhizar R, Shearer R. It can never be the way it was: helping elderly women adjust to change and loss. Home Healthc Nurse. 94;12(1):43-6. [Rec#: 1699] Exclude at abstract screening: no outcomes specified.
De Conno F, Ripamonti C, Caraceni A, Saita L. Palliative care at the National Cancer Institute of Milan. Support Care Cancer. 2001;9(3):141-7. [Rec#: 10649] Exclude at abstract screening: no outcomes specified. [pmid: 11401097].
De Conno F, Saita L, Ripamonti C, Ventafridda V. On the “last days of life”. J Palliat Care. 93;9(3):47-9. [Rec#: 10650] Exclude at abstract screening: no outcomes specified. [pmid: 8271109].
De Conno F, Ripamonti C, Saita L, MacEachern T, Hanson J, Bruera E. Role of rectal route in treating cancer pain: a randomized crossover clinical trial of oral versus rectal morphine administration in opioid-naive cancer patients with pain. Journal of Clinical Oncology. 95;13(4):1004-8. [Rec#: 50372] Exclude at abstract screening: not about end of life.
De Conno F, Ripamonti C, Sbanotto A, Ventafridda V. Oral complications in patients with advanced cancer. Journal of Palliative Care. 89;5(1):7-15. [Rec#: 50373] Exclude at abstract screening: no outcomes specified.
de Gonzalez Victorica M I, Bertolino L, Pavlovsky S. Argentina. Telling the truth to cancer patients in a multicultural society. Ann N Y Acad Sci. 97;809:152-62. [Rec#: 1706] Exclude at abstract screening: Title Only. [pmid: 9103566].
de Graaff F M, Francke A L. Home care for terminally ill Turks and Moroccans and their families in the Netherlands: carers' experiences and factors influencing ease of access and use of services. Int J Nurs Stud. 2003;40(8):797-805. [Rec#: 1709] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14568362].
de Haes H, Koedoot N. Patient centered decision making in palliative cancer treatment: a world of paradoxes. Patient Educ Couns. 2003;50(1):43-9. [Rec#: 10652] Exclude at abstract screening: useful only for background. [pmid: 12767584].
De Jong M J, Beatty D S. Family perceptions of support interventions in the intensive care unit. Dimens Crit Care Nurs. 2000;19(5):40-7. [Rec#: 40815] Exclude at abstract screening: not about end of life. [pmid: 11998067].
De Jonghe B, Cook D, Appere-De-Vecchi C, Guyatt G, Meade M, Outin H. Using and understanding sedation scoring systems: a systematic review. Intensive Care Med. 2000;26(3):275-85. [Rec#: 40817] Exclude at abstract screening: sudden/violent/non-chronic deaths. [pmid: 10823383].
de Lemos J, Tweeddale M, Chittock D. Measuring quality of sedation in adult mechanically ventilated critically ill patients. the Vancouver Interaction and Calmness Scale. Sedation Focus Group. J Clin Epidemiol. 2000;53(9):908-19. [Rec#: 40823] Exclude at abstract screening: not about end of life. [pmid: 11004417].
De Leo D, Spathonis K. Suicide and euthanasia in late life. Aging Clin Exp Res. 2003;15(2):99-110. [Rec#: 1717] Exclude at abstract screening: sudden/violent/non-chronic deaths. [pmid: 12889840].
De Leo D, Predieri M, Melodia C, Vella J, Forza G, de Bertolini C. Suicide attitude in breast cancer patients. Psychopathology. 91;24(2):115-9. [Rec#: 1716] Exclude at abstract screening: sudden/violent/non-chronic deaths. [pmid: 1886969].
De Lima L. Colombia: status of cancer pain and palliative care. J Pain Symptom Manage. 93;8(6):404-6. [Rec#: 10656] Exclude at abstract screening: Title Only. [pmid: 7525761].
De Ridder D, Gastmans C. Dehydration among terminally ill patients: an integrated ethical and practical approach for caregivers. Nurs Ethics. 96;3(4):305-16. [Rec#: 10661] Exclude at abstract screening: no outcomes specified.
de Ridder D, Schreurs K. Developing interventions for chronically ill patients: is coping a helpful concept?. Clin Psychol Rev. 2001;21(2):205-40. [Rec#: 50122] Exclude at abstract screening: not about end of life. [pmid: 11293366].
de Stoutz N D, Glaus A. Supportive and palliative care of cancer patients at the Kantonsspital St. Gallen, Switzerland. Support Care Cancer. 95;3(4):221-6. [Rec#: 10665] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
de Stoutz N D, Bruera E, Suarez-Almazor M. Opioid rotation for toxicity reduction in terminal cancer patients. J Pain Symptom Manage. 95;10(5):378-84. [Rec#: 1728] Exclude at abstract screening: Title Only. [pmid: 7673770].
De Valck C, Vinck J. Health locus of control and quality of life in lung cancer patients. Patient Educ Couns. 96;28(2):179-86. [Rec#: 31250] Exclude at abstract screening: not about end of life. [pmid: 8852092].
de Vos R, Oosterom L, Koster R W, de Haan R J. Decisions to terminate resuscitation. Resuscitation Committee. Resuscitation. 98;39(12):7-13. [Rec#: 40834] Exclude at abstract screening: not about end of life.
de Vries B, Bluck S, Birren J E. The understanding of death and dying in a life-span perspective. Gerontologist. 93;33(3):366-72. [Rec#: 1730] Exclude at abstract screening: no outcomes specified. [pmid: 8325524].
Dean A, Bridge D, Lickiss J N. The palliative effects of octreotide in malignant disease. Ann Acad Med Singapore. 94;23(2):212-5. [Rec#: 10669] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Dean R A. Occupational stress in hospice care: causes and coping strategies. Am J Hosp Palliat Care. 98;15(3):151-4. [Rec#: 10672] Exclude at abstract screening: useful only for background. [pmid: 9729960].
Dear S. Breaking bad news: caring for the family. Nurs Stand. 95;10(11):31-3. [Rec#: 1736] Exclude at abstract screening: Title Only. [pmid: 8546926].
Debrix I, Flahault A, Becker A, Schwartz L, Kanfer A, Milleron B. Impact of guidelines implemented in a paris university hospital: application to the use of antiemetics by cancer patients. Br J Clin Pharmacol. 99;48(4):616-22. [Rec#: 10679] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Dechesne M, Pyszczynski T, Arndt J, Ransom S, Sheldon K M, van Knippenberg A, Janssen J. Literal and symbolic immortality: the effect of evidence of literal immortality on self-esteem striving in response to mortality salience. J Pers Soc Psychol. 2003;84(4):722-37. [Rec#: 10680] Exclude at abstract screening: no outcomes specified. [pmid: 12703645].
Decker S D, Young E. Self-perceived needs of primary caregivers of home-hospice clients. J Community Health Nurs. 91;8(3):147-54. [Rec#: 1740] Exclude at abstract screening: Study Design - Unclear. [pmid: 1885962].
DeCosse JJ and Cennerazzo WJ. Quality-of-life management of patients with colorectal cancer. CA Cancer J Clin 97;47(4):198–206. Erratum in: CA Cancer J Clin 1997 Sep-Oct;47(5):319. [Rec#: 10681] Exclude at abstract screening: no outcomes specified
DeCoster C, Roos N P, Bogdanovic B. Utilization of nursing home resources. Med Care. 95;33(12 Suppl):DS73-83. [Rec#: 40838] Exclude at abstract screening: not about end of life. [pmid: 7500672].
Deeken J F, Taylor K L, Mangan P, Yabroff K R, Ingham J M. Care for the caregivers: a review of self-report instruments developed to measure the burden, needs, and quality of life of informal caregivers. Journal of Pain and Symptom Management. 2003;26(4):922-53. [Rec#: 50374] Exclude at abstract screening: Study Design - Unclear. [pmid: 14527761].
Degenholtz H B, Thomas S B, Miller M J. Race and the intensive care unit: disparities and preferences for end-of-life care. Crit Care Med. 2003;31(5 Suppl):S373-8. [Rec#: 10684] Exclude at abstract screening: Title Only. [pmid: 12771586].
Degner L F, Sloan J A. Symptom distress in newly diagnosed ambulatory cancer patients and as a predictor of survival in lung cancer. J Pain Symptom Manage. 95;10(6):423-31. [Rec#: 31260] Exclude at abstract screening: primarily prognosis or trajectories.
Degner L F, Gow C M, Thompson L A. Critical nursing behaviors in care for the dying. Cancer Nurs. 91;14(5):246-53. [Rec#: 10686] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 1933844].
Degner L F. Ethics and decision-making: lessons from the “cancer wars”. Canadian Journal of Nursing Research. 2002;34(3):9-13. [Rec#: 50376] Exclude at abstract screening: Title Only. [pmid: 12425007].
Degner L F, Kristjanson L J, Bowman D, Sloan J A, Carriere K C, O'Neil J, Bilodeau B, Watson P, Mueller B. Information needs and decisional preferences in women with breast cancer. JAMA. 97;277(18):1485-92. [Rec#: 50377] Exclude at abstract screening: not about end of life.
Degner L. The relationship between some beliefs held by physicians and their life-prolonging decisions. Omega (Westport). 74;5(3):223-32. [Rec#: 50375] Exclude at abstract screening: Title Only. [pmid: 11663252].
Deitz J. The psychodynamics and psychotherapy of depression: contrasting the self-psychological and the classical psychoanalytic approaches. Am J Psychoanal. 91;51(1):61-70. [Rec#: 1748] Exclude at abstract screening: Title Only.
Del Giudice M E, Leszcz M, Pritchard K I, Vincent L, Goodwin P. Attitudes of Canadian oncology practitioners toward psychosocial interventions in clinical and research settings in women with breast cancer. Psychooncology. 97;6(3):178-89. [Rec#: 1751] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Delay A, Sheidler V R, Scherer L, Dropkin S A, Portenoy R K. Family participation in hospice home care. Cancer Pract. 96;4(5):235-8. [Rec#: 1754] Exclude at abstract screening: Title Only. [pmid: 9004568].
Dellasega C A, Fisher K M. Posthospital home care for frail older adults in rural locations. J Community Health Nurs. 2001;18(4):247-60. [Rec#: 40851] Exclude at abstract screening: not about end of life. [pmid: 11775558].
DeLoach R. Job satisfaction among hospice interdisciplinary team members. Am J Hosp Palliat Care. 2003;20(6):434-40. [Rec#: 1764] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14649560].
Delvecchio Good M J, Good B J, Schaffer C, Lind S E. American oncology and the discourse on hope. Cult Med Psychiatry. 90;14(1):59-79. [Rec#: 1768] Exclude at abstract screening: not about end of life. [pmid: 2340733].
Demmer C, Sauer J. Assessing complementary therapy services in a hospice program. Am J Hosp Palliat Care. 2002;19(5):306-14. [Rec#: 1774] Exclude at abstract screening: not about end of life. [pmid: 12269776].
Demmer C. AIDS attitudes and attitudes toward caring for dying patients. Death Stud. 99;23(5):433-42. [Rec#: 10696] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10558507].
Demmer C. Dealing with AIDS-related loss and grief in a time of treatment advances. Am J Hosp Palliat Care. 2001;18(1):35-41. [Rec#: 10697] Exclude at abstract screening: no outcomes specified. [pmid: 11406876].
Demmer C. Death anxiety, coping resources, and comfort with dying patients among nurses in AIDS care facilities. Psychol Rep. 98;83(3 Pt 1):1051-7. [Rec#: 1772] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Demmer C. The relationship between death-related experiences, death anxiety, and patient care attitudes among AIDS nursing staff. J Nurses Staff Dev. 2000;16(3):118-23. [Rec#: 1773] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11913010].
DeMong S A. Provision of recreational activities in hospices in the United States. Hosp J. 97;12(4):57-67. [Rec#: 10699] Exclude at abstract screening: Other topic only. [pmid: 9305025].
Dendaas N R. Prognostication in advance cancer: nurses' perceptions of the dying process. Oncol Nurs Forum. 2002;29(3):493-9. [Rec#: 1778] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 11979282].
Denham J W, Walker Q J, Lamb D S, Hamilton C S, O'Brien P C, Spry N A, Hindley A, Poulsen M, O'Brien M, Tripcony L. Mucosal regeneration during radiotherapy. Trans Tasman Radiation Oncology Group (TROG). Radiother Oncol. 96;41(2):109-18. [Rec#: 10700] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Dennis L I, Blue C L, Stahl S M, Benge M E, Shaw C J. The relationship between hospital readmissions of medicare beneficiaries with chronic illnesses and home care nursing interventions. Home Healthc Nurse. 96;14(4):303-9. [Rec#: 50020] Exclude at abstract screening: Title Only.
Dennis R G. Love is as strong as death: meeting the pastoral needs of the Jewish hospice patient. Am J Hosp Palliat Care. 99;16(4):598-604. [Rec#: 10704] Exclude at abstract screening: useful only for background.
Dent A, Condon L, Blair P, Fleming P. A study of bereavement care after a sudden and unexpected death. Arch Dis Child 96; 74(6):522–6. Comment in: Arch Dis Child. Jan. 1997;76(1):80-1. PMID: 9059174. [Rec#;: 40860] Exclude at abstract screening: sudden/violent/non-chronic deaths.
Depaola S J, Griffin M, Young J R, Neimeyer R A. Death anxiety and attitudes toward the elderly among older adults: the role of gender and ethnicity. Death Stud. 2003;27(4):335-54. [Rec#: 1780] Exclude at abstract screening: not about end of life. [pmid: 12749378].
DePaola S J, Neimeyer R A, Lupfer M B, Fiedler J. Death concern and attitudes toward the elderly in nursing home personnel. Death Stud. 92;16(6):537-55. [Rec#: 1781] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Derrickson B S. The spiritual work of the dying: a framework and case studies. Hosp J. 96;11(2):11-30. [Rec#: 1783] Exclude at abstract screening: useful only for background. [pmid: 8949011].
Derse AR. Assessment of decision-making capacity. Prinicples and Practice of Palliative Care and Supportive Oncology 2002; <25 Page(s)>. [Rec#: 50378] Exclude at abstract screening: Title Only
Dershimer R A. Completing the hospice organizational model. Am J Hosp Palliat Care. 91;8(5):30-6. [Rec#: 10708] Exclude at abstract screening: not about end of life. [pmid: 1742141].
Desbiens N A, Mueller Rizner N, Connors A F Jr, Wenger N S, Lynn J. Investigators, for the SUPPORT. The symptom burden of seriously ill hospitalized patients: Study to understand prognoses and Preferences for Outcomes and Risks of Treatments. Journal of Pain & Symptom Management. 99;17:248-255. [Rec#: 50379] Exclude at abstract screening: primarily prognosis or trajectories.
DeShano C L. Physicians play key role as hospice system grows. Mich Med. 97;96(1):28-31. [Rec#: 10709] Exclude at abstract screening: Title Only. [pmid: 9014414].
DeShano J A. Quality of life: what does it mean?. Henry Ford Hosp Med J. 91;39(2):89-91. [Rec#: 10710] Exclude at abstract screening: Title Only. [pmid: 1890014].
DeSilva D L, Dillon J E, Teno J M. The quality of care in the last month of life among Rhode Island nursing home residents. Med Health R I. 2001;84(6):195-8. [Rec#: 1791] Exclude at abstract screening: Title Only. [pmid: 11434148].
Desmedt M, Michel H. Palliative home care: improving co-operation between the specialist team and the family doctor. Support Care Cancer. 2002;10(4):343-8. [Rec#: 1793] Exclude at abstract screening: no outcomes specified. [pmid: 12029435].
Deswal A, Petersen N J, Souchek J, Ashton C M, Wray N P. Impact of race on health care utilization and outcomes in veterans with congestive heart failure. J Am Coll Cardiol 2004;43(5):778–84. Comment in: J Am Coll Cardiol. Mar 3. 2004;43(5):785-6. PMID: 14998617. [Rec#: 50021] Exclude at abstract screening: not about end of life.
Devers E, Robinson K M. The making of a grounded theory: after death communication. Death Stud. 2002;26(3):241-53. [Rec#: 10718] Exclude at abstract screening: useful only for background. [pmid: 11973837].
Devettere R J. Neocortical death and human death. Law Med Health Care. 90;18(12):96-104. [Rec#: 10720] Exclude at abstract screening: no outcomes specified. [pmid: 2374457].
Devi R. Conquering pain. Interview by Daloni Carlisle. Nurs Times. 92;88(44):23. [Rec#: 10721] Exclude at abstract screening: Title Only. [pmid: 1280815].
Devich L, Field BE, and Carlson RE. Supportive care for the hopelessly ill. Nurs Outlook 90;38(3):140–2, 124. [Rec#: 10722] Exclude at abstract screening: Title Only
Devine E C, Pearcy J. Meta-analysis of the effects of psychoeducational care in adults with chronic obstructive pulmonary disease. Patient Educ Couns. 96;29(2):167-78. [Rec#: 50124] Exclude at abstract screening: not about end of life.
Devine E C, Westlake S K. The effects of psychoeducational care provided to adults with cancer: meta-analysis of 116 studies. Oncol Nurs Forum. 95;22(9):1369-81. [Rec#: 50125] Exclude at abstract screening: Study Design - Review/Meta.
Devine E C. Meta-analysis of the effect of psychoeducational interventions on pain in adults with cancer. Oncol Nurs Forum. 2003;30(1):75-89. [Rec#: 50123] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 12515986].
Devine E C. Meta-analysis of the effect of psychoeducational interventions on pain in adults with cancer. Oncology Nursing Forum. Online. 2003;30(1):75-89. [Rec#: 50380] Exclude at abstract screening: Duplicate already in the flow.
DeVries H M, Hamilton D W, Lovett S, Gallagher-Thompson D. Patterns of coping preferences for male and female caregivers of frail older adults. Psychol Aging. 97;12(2):263-7. [Rec#: 40866] Exclude at abstract screening: not about end of life.
Devulder J, De Laat M, Dumoulin K, Ghys L, Rolly G. Palliative care: knowledge and attitudes of general practitioners: the results of a questionnaire after training. Acta Clin Belg. 97;52(4):207-10. [Rec#: 10729] Exclude at abstract screening: no outcomes specified.
Devulder J. Persisting misconceptions of Belgian physicians and nurses about cancer pain treatment. Acta Clin Belg. 99;54(6):346-50. [Rec#: 10728] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Dey AN. Characteristics of elderly home health care users. Data from the 1993 National Home and Hospice Care Survey. Adv Data 96(272):1–12 [Rec#: 1802] Exclude at abstract screening: Title Only
Dey AN. Characteristics of elderly home health care users: data from the 1994 National Home and Hospice Care Survey. Adv Data 96;(279):1–12. [Rec#: 1803] Exclude at abstract screening: not about end of life
Dharmarajan T S, Unnikrishnan D, Pitchumoni C S. Percutaneous endoscopic gastrostomy and outcome in dementia. Am J Gastroenterol. 2001;96(9):2556-63. [Rec#: 31310] Exclude at abstract screening: no outcomes specified. [pmid: 11569675].
Dharmasena H P, Forbes K. Palliative care for patients with non-malignant disease: will hospital physicians refer?. Palliat Med. 2001;15(5):413-8. [Rec#: 10732] Exclude at abstract screening: useful only for background. [pmid: 11591093].
Di Blasi Z, Harkness E, Ernst E, Georgiou A, Kleijnen J. Health and patient practitioner interactions: a systematic review. 1996;<25 Page(s)>. [Rec#: 50848] Exclude at abstract screening: not about end of life
Di Lorenzo G, Autorino R, Ciardiello F, Raben D, Bianco C, Troiani T, Pizza C, De Laurentiis M, Pensabene M, D'Armiento M, Bianco A R, De Placido S. External beam radiotherapy in bone metastatic prostate cancer: impact on patients' pain relief and quality of life. Oncol Rep. 2003;10(2):399-404. [Rec#: 1810] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 12579279].
Di Maio M, Perrone F, Gallo C, Iaffaioli R V, Manzione L, Piantedosi F V, Cigolari S, Illiano A, Barbera S, Robbiati S F, Piazza E, Ianniello G P, Frontini L, Veltri E, Castiglione F, Rosetti F, De Maio E, Maione P, Gridelli C, Rossi A, Barletta E, Barzelloni M L, Signoriello G, Bilancia D, Dinota A, Rosati G, Germano D, Lamberti A, Pontillo V, Brancacio L, Crispino C, Esposito M, Battiloro C, Tufano G, Cioffi A, Guardasole V, Angelini V, Guidetti G, Barbera S, Renda F, Romano F, Volpintesta A, Robbiati S F, Sannicolo M, Filipazzi V, Esani G, Gambaro A, Ferrario S, Tinessa V, Caprio M G, Zonato S, Cabiddu M, Raina A, Veltri E, D'Aprile M, Pistillucci G, Porcile G, Ostellino O, Vinante O, Azzarello G, Gebbia V, Borsellino N, Testa A, Gasparini G, Morabito A, Gattuso D, Romito S, Carrozza F, Fava S, Calcagno A, Grimi E, Bertetto O, Ciuffreda L, Parello G, Maiorino L, Santoro A, Santoro M, Failla G, Aiello R A, Bearz A, Sorio R, Scalone S, Clerici M, Bollina R, Belloni P, Sacco C, Sibau A, Adamo V, Altavilla G, Scimone A, Spatafora M, Bellia V, Hopps M R, Monfardini S, Favaretto A, Stefani M, Corradini G M, Pavia G, Scagliotti G, Novello S, Selvaggi G, Tonato M, Darwish S, Michetti G, Belometti M O, Labianca R, Quadri A, De Marinis F, Migliorino M R, Martelli O, Colucci G, Galetta D, Giotta F, Isa L, Candido P, Rossi N, Calandriello A, Ferrau F, Malaponte E, Barni S, Cazzaniga M, Gebbia N, Valerio M R, Belli M, Colantuoni G, Capuano M A, Angiolillo M, Sollitto F, Ardizzoia A, Luporini G, Locatelli M C, Pari F, Aitini E, Pedicini T, Febbraro A, Zollo C, Di Costanzo F, Bartolucci R, Gasperoni S, Gaion F, Palazzolo G, Galligioni E, Caffo O, Cortesi E, D'Auria G, Curcio C, Vasta M, Bumma C, Celano A, Bretti S, Nettis G, Anselmo A, Mattioli R, Nistico C, Aschelter A, Foa P. Supportive care in patients with advanced non-small-cell lung cancer. Br J Cancer. 2003;89(6):1013-21. [Rec#: 1812] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 12966418].
Di Mauro S, Scalia G, Leotta C, Giuffrida F, Di Stefano A, Malaguarnera M. The care of elderly, terminally ill oncological patients in caregiving sanitary residences. Arch Gerontol Geriatr. 2000;31(1):85-94. [Rec#: 1813] Exclude at abstract screening: useful only for background. [pmid: 10989167].
Di Mola G, Crisci M T. Attitudes towards death and dying in a representative sample of the Italian population. Palliat Med. 2001;15(5):372-8. [Rec#: 10734] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11591088].
Di Mola G, Tamburini M, Fusco C. The role of volunteers in alleviating grief. J Palliat Care. 90;6(1):6-10. [Rec#: 10735] Exclude at abstract screening: Title Only. [pmid: 2332826].
Diamond E F. Linacre Institute. Determination of death. Linacre Q. 90;57(4):46-58. [Rec#: 10739] Exclude at abstract screening: Title Only. [pmid: 11651104].
Diamond E F. Brain-based determination of death revisited. Linacre Q. 98;65(4):71-80. [Rec#: 10737] Exclude at abstract screening: Title Only. [pmid: 12199256].
Dick B W, Gordon R L, LaBerge J M, Doherty M M, Ring E J. Percutaneous transhepatic placement of biliary endoprostheses: results in 100 consecutive patients. J Vasc Interv Radiol. 90;1(1):97-100. [Rec#: 10742] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Dickerson D A. A doctor's duty to disclose life expectancy information to terminally ill patients. Clevel State Law Rev. 95;43(2):319-50. [Rec#: 10745] Exclude at abstract screening: Title Only. [pmid: 11660488].
Dickey N W. Pain management at the end of life. J Orthop Sports Phys Ther. 96;24(4):237-9. [Rec#: 10746] Exclude at abstract screening: useful only for background. [pmid: 8892138].
Dickinson G E, Field D. Teaching end-of-life issues: current status in United Kingdom and United States medical schools. Am J Hosp Palliat Care. 2002;19(3):181-6. [Rec#: 10748] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12026041].
Dickinson G E, Tournier R E. A decade beyond medical school: a longitudinal study of physicians' attitudes toward death and terminally-ill patients. Soc Sci Med. 94;38(10):1397-400. [Rec#: 1821] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Dickinson G E, Tournier R E. A longitudinal study of sex differences in how physicians relate to dying patients. J Am Med Womens Assoc. 93;48(1):19-22. [Rec#: 1822] Exclude at abstract screening: data older than 1990.
Dickinson G E, Tournier R E, Still B J. Twenty years beyond medical school: physicians' attitudes toward death and terminally ill patients. Arch Intern Med. 99;159(15):1741-4. [Rec#: 1823] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Dicks B. Palliative care for cancer patients. Nurs Stand. 90;4(33):24-5. [Rec#: 10749] Exclude at abstract screening: no outcomes specified. [pmid: 2115797].
Dicks B. Rehydration or dehydration?. Support Care Cancer. 94;2(2):88-90. [Rec#: 10750] Exclude at abstract screening: no outcomes specified. [pmid: 8156270].
Diehl V. Controversies in terminal cancer care. Support Care Cancer. 94;2(2):82-7. [Rec#: 10751] Exclude at abstract screening: no outcomes specified. [pmid: 7512418].
Diehr P, Patrick L. Trajectories of health for older adults over time: accounting fully for death. Ann Intern Med. 2003;139(5 Pt 2):416-20. [Rec#: 1827] Exclude at abstract screening: no outcomes specified. [pmid: 12965968].
Diehr P, Patrick D L, Spertus J, Kiefe C I, McDonell M, Fihn S D. Transforming self-rated health and the SF-36 scales to include death and improve interpretability. Med Care. 2001;39(7):670-80. [Rec#: 1828] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11458132].
Diehr P, Williamson J, Burke G L, Psaty B M. The aging and dying processes and the health of older adults. J Clin Epidemiol. 2002;55(3):269-78. [Rec#: 1829] Exclude at abstract screening: useful only for background. [pmid: 11864798].
Diener E, Wirtz D, Oishi S. End effects of rated life quality: the James Dean Effect. Psychol Sci. 2001;12(2):124-8. [Rec#: 1831] Exclude at abstract screening: no outcomes specified. [pmid: 11340920].
Diller P M, Smucker D R, David B. Comanagement of patients with congestive heart failure by family physicians and cardiologists: frequency, timing, and patient characteristics. J Fam Pract 99;48(3):188–95. Comment in: J Fam Pract. Mar. 1999;48(3):177-9. PMID: 10086759. [Rec#: 50022] In abstract review process.
Dillon M, Lucas C. Auricular stud acupuncture in palliative care patients. Palliat Med. 99;13(3):253-4. [Rec#: 1841] Exclude at abstract screening: Title Only. [pmid: 10474714].
DiMaggio J R. Educating psychiatry residents about death and dying. A national survey. Gen Hosp Psychiatry. 93;15(3):166-70. [Rec#: 1842] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Dimoliatis I. Lord, now you are letting your servant depart in peace: a theoretical model, combining quality of life and years of life, which offers clues for the proper time to die with dignity. Med Law. 2000;19(3):635-55. [Rec#: 10754] Exclude at abstract screening: useful only for background. [pmid: 11143895].
Dimond E P. The oncology nurse's role in patient advance directives. Oncol Nurs Forum. 92;19(6):891-6. [Rec#: 1846] Exclude at abstract screening: useful only for background. [pmid: 1635870].
Dimond M, Caserta M, Lund D. Understanding depression in bereaved older adults. Clin Nurs Res. 94;3(3):253-68. [Rec#: 1847] Exclude at abstract screening: Observational study. [pmid: 7804120].
Dinwiddie L C. Insight into the ESRD Workgroup Final Report Summary on end-of-life care. Nephrol Nurs J. 2003;30(1):58. [Rec#: 10761] Exclude at abstract screening: Title Only. [pmid: 12674950].
Disease management programs help cut costs, improve care. Health Care Cost Reengineering Rep 98;3(12):181–6. [Rec#: 50023] Exclude at abstract screening: outcome unrelated to pts/family/non-prof
Ditillo B A. Planning end of life care. J Am Acad Nurse Pract. 99;11(6):243-8. [Rec#: 10765] Exclude at abstract screening: Title Only. [pmid: 10514645].
Ditillo B A. Should there be a choice for cardiopulmonary resuscitation when death is expected? Revisiting an old idea whose time is yet to come. J Palliat Med. 2002;5(1):107-16. [Rec#: 10766] Exclude at abstract screening: no outcomes specified. [pmid: 11839233].
Ditillo B A. The emergence of palliative care: a new specialized field of medicine requiring an interdisciplinary approach. Crit Care Nurs Clin North Am. 2002;14(2):127-32. [Rec#: 10764] Exclude at abstract screening: no outcomes specified. [pmid: 12038498].
Ditto P H, Danks J H, Smucker W D, Bookwala J, Coppola K M, Dresser R, Fagerlin A, Gready R M, Houts R M, Lockhart L K, Zyzanski S. Advance directives as acts of communication: a randomized controlled trial. Arch Intern Med. 2001;161(3):421-30. [Rec#: 1852] Exclude at abstract screening: Other topic only. [pmid: 11176768].
Ditto P H, Smucker W D, Danks J H, Jacobson J A, Houts R M, Fagerlin A, Coppola K M, Gready R M. Stability of older adults' preferences for life-sustaining medical treatment. Health Psychol. 2003;22(6):605-15. [Rec#: 1854] Exclude at abstract screening: not about end of life. [pmid: 14640858].
Diver F, Molassiotis A, Weeks L. The palliative care needs of ethnic minority patients: staff perspectives. Int J Palliat Nurs 2003;9(8):343–51. Comment in: Int J Palliat Nurs. 2003 Oct;9(10):454–5. PMID: 14649658. Comment in: Int J Palliat Nurs. Oct. 2003;9(10):454-5. [Rec#: 1855] Exclude at abstract screening: no outcomes specified.
Diver F, Molassiotis A, Weeks L. The palliative care needs of ethnic minority patients attending a day-care centre: a qualitative study. Int J Palliat Nurs. 2003;9(9):389-96. [Rec#: 10768] Exclude at abstract screening: not about end of life. [pmid: 14593275].
Diver F, Molassiotis A, Weeks L. The palliative care needs [correction neds] of ethnic minority patients attending a day-care centre: a qualitative study. International Journal of Palliative Nursing. 2003;9(9):389-96. [Rec#: 50383] Exclude at abstract screening: Study Design - Qualitative. [pmid: 14593275].
Dixon P. Palliative radiotherapy in Canada. Can J Oncol 96;6 Suppl 1:74–83; discussion 84. [Rec#: 10770] Exclude at abstract screening: data older than 1990
Dixon S, Fortner J, Travis S S. Barriers, challenges, and opportunities related to the provision of hospice care in assisted-living communities. Am J Hosp Palliat Care. 2002;19(3):187-92. [Rec#: 1857] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12026042].
DM programs take different roads to CHF success. Clin Resour Manag 2001: 2(2):20–5, 18. [Rec#: 50024] Exclude at abstract screening: no outcomes specified
Do hospital-based palliative teans improve care for patients or families at the end of life? 2003;3:<25 Page(s)>. [Rec#: 50160] Exclude at abstract screening: Duplicate already in the flow
Do specialist palliative care teams improve outcomes for cancer patients: a systematic literature review (Structured Abstract). 2003;3:<25 Page(s)>. [Rec#: 50161] Exclude at abstract screening: Title Only
Dobratz M C, Wade R, Herbst L, Ryndes T. Pain efficacy in home hospice patients. A longitudinal study. Cancer Nurs. 91;14(1):20-6. [Rec#: 1871] Exclude at abstract screening: Study Design - Unclear. [pmid: 2013048].
Dobratz MC. Causal influences of psychological adaptation in dying. West J Nurs Res 93; 15(6) 708–24; discussion 724–9. [Rec#: 1866] Exclude at abstract screening: Title Only
Dobratz M C. Hospice nursing. Present perspectives and future directives. Cancer Nurs. 90;13(2):116-22. [Rec#: 10774] Exclude at abstract screening: no outcomes specified. [pmid: 2331692].
Dobratz M C. The Life Closure Scale: a measure of psychological adaptation in death and dying. Hosp J. 90;6(3):1-15. [Rec#: 1868] Exclude at abstract screening: Study Design - Qualitative. [pmid: 2276714].
Dobrin A, Beder J. Death in a religious community. J Pastoral Care Counsel. 2002;56(3):233-42. [Rec#: 10775] Exclude at abstract screening: no outcomes specified. [pmid: 12385137].
Dodwell D, Bond M, Elwell C, Gildersleve J, Parmar S, Owens J, Bulman A, Crellin A, Ash D. Effect of medical audit on prescription of palliative radiotherapy. BMJ. 93;307(6895):24-5. [Rec#: 10778] Exclude at abstract screening: Title Only. [pmid: 7688252].
Dodwell D J, Rathmell A J, Ash D V. Assessment of palliative chemotherapy: a step beyond response. Clin Oncol (R Coll Radiol). 93;5(2):114-7. [Rec#: 10779] In abstract review process. [pmid: 7683201].
Dolan J T, Miltenburg D M, Granchi T S, Miller C C 3rd, Brunicardi F C. Treatment of metastatic breast cancer with somatostatin analogues--a meta-analysis. Ann Surg Oncol. 2001;8(3):227-33. [Rec#: 50126] Exclude at abstract screening: not about end of life. [pmid: 11314939].
D'Olimpio J. Contemporary drug therapy in palliative care: new directions. Cancer Invest. 2001;19(4):413-23. [Rec#: 10548] Exclude at abstract screening: Title Only. [pmid: 11405180].
Donaghy K, Devlin B. An evaluation of teamwork within a specialist palliative care unit. Int J Palliat Nurs. 2002;8(11):518-25. [Rec#: 10788] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12514461].
Donaldson M S, Field M J. Measuring quality of care at the end of life. Arch Intern Med. 98;158(2):121-8. [Rec#: 10791] Exclude at abstract screening: useful only for background. [pmid: 9448550].
Donaldson M S. The importance of measuring quality of care at the end of life. Hosp J. 98;13(12):117-38. [Rec#: 10790] Exclude at abstract screening: no outcomes specified. [pmid: 9644397].
Donaldson N. Terminal fears and panic. Accid Emerg Nurs. 98;6(1):41-2. [Rec#: 10792] Exclude at abstract screening: no outcomes specified. [pmid: 9528517].
Donnelly J M, Kornblith A B, Fleishman S, Zuckerman E, Raptis G, Hudis C A, Hamilton N, Payne D, Massie M J, Norton L, Holland J C. A pilot study of interpersonal psychotherapy by telephone with cancer patients and their partners. Psychooncology. 2000;9(1):44-56. [Rec#: 1894] Exclude at abstract screening: not about end of life. [pmid: 10668059].
Donnelly S. Quality-of-life assessment in advanced cancer. Curr Oncol Rep. 2000;2(4):338-42. [Rec#: 10797] Exclude at abstract screening: useful only for background. [pmid: 11122862].
Donnelly S. Traditions associated with dying in the west of Scotland. J Palliat Care. 99;15(4):64-9. [Rec#: 10798] Exclude at abstract screening: Title Only. [pmid: 10693308].
D'Onofrio C and Ryndes T. The relevance of public health in improving access to end of life care. Hastings Cent Rep 2003;Suppl:S30–2. [Rec#: 10549] Exclude at abstract screening: Title Only
Donovan J M. Validation of a Portuguese form of Templer's Death Anxiety Scale. Psychol Rep. 93;73(1):195-200. [Rec#: 1898] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 8367559].
Donovan M I, Miaskowski C. Striving for a standard of pain relief. Am J Nurs. 92;92(3):106-7. [Rec#: 10800] Exclude at abstract screening: Title Only. [pmid: 1371373].
Doolittle G C, Yaezel A, Otto F, Clemens C. Hospice care using home-based telemedicine systems. J Telemed Telecare. 98;4(Suppl 1):58-9. [Rec#: 10803] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Doolittle G C. A cost measurement study for a home-based telehospice service. J Telemed Telecare. 2000;6(Suppl 1):S193-5. [Rec#: 10801] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10794017].
Doorenbos A Z, Schim S M. Cultural competence in hospice. Am J Hosp Palliat Care. 2004;21(1):28-32. [Rec#: 1904] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14748520].
Doorenbos A Z, Schim S M. Cultural competence in hospice. Am J Hosp Palliat Care. 2004;21(1):28-32. [Rec#: 40898] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14748520].
Doorley J, Hobbs M, Delaney E, Murphy J. The role of nebulized opioids in managing terminal dyspnea: implications for the clinical nurse specialist. Clin Nurse Spec. 2003;17(1):19-21. [Rec#: 10804] Exclude at abstract screening: Title Only. [pmid: 12544116].
Doran M. The presence of family during brain stem death testing. Intensive Crit Care Nurs. 2004;20(1):32-7. [Rec#: 10805] Exclude at abstract screening: no outcomes specified. [pmid: 14726251].
Dorfman L T, Holmes C A, Berlin K L. Service utilization by wife caregivers of frail older veterans. Soc Work Health Care. 97;26(2):33-52. [Rec#: 40900] Exclude at abstract screening: not about end of life.
Dossetor J, MacDonald N. Ethics of palliative care in the context of limited resources: an essay on the need for attitudinal change. J Palliat Care. 94;10(3):39-42. [Rec#: 10806] Exclude at abstract screening: Title Only. [pmid: 7531232].
Doty L, Heilman K M, Stewart J T, Bowers D, Rothi L J. Case management in Alzheimer's disease. J Case Manag. 93;2(4):130-6. [Rec#: 10809] Exclude at abstract screening: no outcomes specified. [pmid: 8142912].
Dougenis D, Petsas T, Bouboulis N, Leukaditou C, Vagenas C, Kardamakis D, Kalfarentzos F. Management of non resectable malignant esophageal stricture and fistula. Eur J Cardiothorac Surg. 97;11(1):38-45. [Rec#: 1914] Exclude at abstract screening: Title Only.
Dougherty C M. The near-death experience as a major life transition. Holist Nurs Pract. 90;4(3):84-90. [Rec#: 10812] Exclude at abstract screening: no outcomes specified. [pmid: 2329140].
Doughty R N, Sharpe N. Effects of beta-blockers on symptoms and exercise tolerance in patients with heart failure. J Cardiovasc Risk. 99;6(3):151-6. [Rec#: 31372] Exclude at abstract screening: Title Only. [pmid: 10463141].
Doughty R N, Wright S P, Pearl A, Walsh H J, Muncaster S, Whalley G A, Gamble G, Sharpe N. Randomized, controlled trial of integrated heart failure management: The Auckland Heart Failure Management Study. Eur Heart J 2002 23(2):139–46. Comment in: Eur Heart J. Jan. 2002;23(2):101-2. PMID: 11785989. [Rec#: 31373] Exclude at abstract screening: not about end of life.
Douglas C. For all the saints. BMJ. 92;304(6826):479. [Rec#: 10814] Exclude at abstract screening: Title Only. [pmid: 1643446].
Douglas D B. Hypnosis: useful, neglected, available. Am J Hosp Palliat Care. 99;16(5):665-70. [Rec#: 1916] Exclude at abstract screening: no outcomes specified. [pmid: 11141670].
Douglas H R, Halliday D, Normand C, Corner J, Bath P, Beech N, Clark D, Hughes P, Marples R, Seymour J, Skilbeck J, Webb T. Economic evaluation of specialist cancer and palliative nursing: Macmillan evaluation study findings. Int J Palliat Nurs 2003;9(10):429–38. Comment in: Int J Palliat Nurs. Oct. 2003;9(10):438. PMID: 14649656. [Rec#: 10815] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Douglas H R, Normand C E, Higginson I J, Goodwin D M, Myers K. Palliative Day Care Project Group. Palliative day care: what does it cost to run a centre and does attendance affect use of other services?. Palliat Med. 2003;17(7):628-37. [Rec#: 10817] Exclude at abstract screening: useful only for background. [pmid: 14594155].
Douglas R, Brown H N. Patients' attitudes toward advance directives. J Nurs Scholarsh. 2002;34(1):61-5. [Rec#: 1918] Exclude at abstract screening: not about end of life. [pmid: 11901969].
Douglas S, Daly B, Rudy E, Song R, Dyer M A, Montenegro H. The cost-effectiveness of a special care unit to care for the chronically critically ill. J Nurs Adm. 95;25(11):47-53. [Rec#: 40908] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Doukas D J, Gorenflo D W. Analyzing the values history: an evaluation of patient medical values and advance directives. J Clin Ethics. 93;4(1):41-5. [Rec#: 1921] Exclude at abstract screening: Title Only. [pmid: 8490218].
Doukas D J, Hardwig J. Using the family covenant in planning end-of-life care: obligations and promises of patients, families, and physicians. J Am Geriatr Soc. 2003;51(8):1155-8. [Rec#: 10823] Exclude at abstract screening: useful only for background. [pmid: 12890082].
Doukas D J, McCullough L B. The values history. The evaluation of the patient's values and advance directives. J Fam Pract 91:32(2):145–53. Comment in: Fam Med. Nov-Dec. 1994;26(10):610-1. PMID: 7859949. [Rec#: 10824] Exclude at abstract screening: no outcomes specified.
Dow K H. The enduring seasons in survival. Oncol Nurs Forum 90;17(4):511–6. Comment in: Oncol Nurs Forum. Apr. 1991;18(3):476. PMID 2057392. [Rec#: 10825] Exclude at abstract screening: Title Only.
Dowd S B, Poole V L, Davidhizar R, Giger J N. Death, dying and grief in a transcultural context: application of the Giger and Davidhizar assessment model. Hosp J. 98;13(4):33-56. [Rec#: 10826] Exclude at abstract screening: no outcomes specified.
Dowdney L. Childhood bereavement following parental death. J Child Psychol Psychiatry. 2000;41(7):819-30. [Rec#: 40914] In abstract review process. [pmid: 11079425].
Downey R J. Surgical management of lung cancer. J Thorac Imaging. 99;14(4):266-9. [Rec#: 10832] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 10524807].
Doyle C, Crump M, Pintilie M, Oza A M. Does palliative chemotherapy palliate? Evaluation of expectations, outcomes, and costs in women receiving chemotherapy for advanced ovarian cancer. J Clin Oncol. 2001;19(5):1266-74. [Rec#: 1930] Exclude at abstract screening: Observational study. [pmid: 11230467].
Doyle C, Stockler M, Pintilie M, Panesar P, Warde P, Sturgeon J, Oza A M. Resource implications of palliative chemotherapy for ovarian cancer. J Clin Oncol. 97;15(3):1000-7. [Rec#: 1931] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Doyle D. A home care service for terminally ill patients in Edinburgh. Health Bull (Edinb). 91;49(1):14-23. [Rec#: 1932] Exclude at abstract screening: Title Only. [pmid: 1938371].
Doyle D. Have we looked beyond the physical and psychosocial? J Pain Symptom Manage 92;7(5):302–11. Comment in: J Pain Symptom Manage. Aug. 1994;9(6):359-61. PMID: 7963788. [Rec#: 10835] Exclude at abstract screening: no outcomes specified.
Doyle M, Johnstone P A, Watkins E B. Role of radiation therapy in management of pulmonary Kaposi's sarcoma. South Med J. 93;86(3):285-8. [Rec#: 10839] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Doyle J, Walker P, Bruera E. Nebulized scopolamine. Journal of Pain & Symptom Management. 2000;19(5):327-8. [Rec#: 50386] Exclude at abstract screening: no outcomes specified. [pmid: 10928852].
Doyle-Brown M. The transitional phase: the closing journey for patients and family caregivers. Am J Hosp Palliat Care. 2000;17(5):354-7. [Rec#: 10834] Exclude at abstract screening: no outcomes specified. [pmid: 11886061].
Dozor R B, Addison R B. Toward a good death: an interpretive investigation of family practice residents' practices with dying patients. Fam Med. 92;24(7):538-43. [Rec#: 10840] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Draper B M, Poulos C J, Cole A M, Poulos R G, Ehrlich F. A comparison of caregivers for elderly stroke and dementia victims. J Am Geriatr Soc 92;40(9):896–901. Comment in: J Am Geriatr Soc. Apr. 1993;41(4):466-7. PMID: 8463543. [Rec#: 31391] Exclude at abstract screening: not about end of life.
Draper B M. Prevention of suicide in old age. Med J Aust. 95;162(10):533-4. [Rec#: 1935] Exclude at abstract screening: sudden/violent/non-chronic deaths. [pmid: 7776915].
Draper P. Compromise, massive encouragement and forcing: a discussion of mechanisms used to limit the choices available to the older adult in hospital. J Clin Nurs. 96;5(5):325-31. [Rec#: 40920] Exclude at abstract screening: not about end of life.
Drayer R A. Patients who refuse food and fluids to hasten death. New England Journal of Medicine. 2003;349(18):1777-9. [Rec#: 50387] Exclude at abstract screening: Title Only. [pmid: 14585951].
Drazen JM. Decisions at the end of life. N Engl J Med 2003; 349(12):1109–10. Comment on: N Engl J Med. 2003 Sep 18;349(12):1123–32. PMID: 13679526. Comment in: N Engl J Med. 2003 Dec 25;349(26):2565–7; author reply 2565–7. PMID: 14699649. [Rec#: 10843] Exclude at abstract screening: Title Only
Drew M, Irwin M. Providing hospice care in rural Texas. Tex Med. 2001;97(8):52-5. [Rec#: 1937] Exclude at abstract screening: no outcomes specified. [pmid: 11503478].
Driscoll J. Spirituality and religion in end-of-life care. Journal of Palliative Medicine. 2001;4(3):333-5. [Rec#: 50388] Exclude at abstract screening: no outcomes specified. [pmid: 11596544].
Drolet J L. Transcending death during early adulthood: symbolic immortality, death anxiety, and purpose in life. J Clin Psychol. 90;46(2):148-60. [Rec#: 1940] Exclude at abstract screening: not about end of life.
Droughton M L. Head and neck carcinomas. J Palliat Care. 90;6(4):43-6. [Rec#: 1941] Exclude at abstract screening: Title Only. [pmid: 1704913].
Druley J A, Ditto P H, Moore K A, Danks J H, Townsend A, Smucker W D. Physicians' predictions of elderly outpatients' preferences for life-sustaining treatment. J Fam Pract. 93;37(5):469-75. [Rec#: 1943] Exclude at abstract screening: not about end of life.
Drummond S H, Peterson G M, Galloway J G, Keefe P A. National survey of drug use in palliative care. Palliat Med. 96;10(2):119-24. [Rec#: 10850] Exclude at abstract screening: useful only for background. [pmid: 8800819].
Du Pen S L, Du Pen A R, Polissar N, Hansberry J, Kraybill B M, Stillman M, Panke J, Everly R, Syrjala K. Implementing guidelines for cancer pain management: results of a randomized controlled clinical trial. Journal of Clinical Oncology. 99;17(1):361-70. [Rec#: 50389] Exclude at abstract screening: not about end of life.
Du W, DiLuca C, Growdon J H. Weight loss in Alzheimer's disease. J Geriatr Psychiatry Neurol. 93;6(1):34-8. [Rec#: 31399] Exclude at abstract screening: Other symptoms only. [pmid: 8422270].
Dubler N N. The collision of confinement and care: end-of-life care in prisons and jails. J Law Med Ethics. 98;26(2):149-56. [Rec#: 1950] Exclude at abstract screening: Title Only. [pmid: 11657351].
Dubois M Y, Fine P G, Fischberg D, Ferrell B, Taylor M L. Pain management at the end of life: often a difficult call. Pain Med. 2003;4(1):81-4. [Rec#: 10855] Exclude at abstract screening: no outcomes specified. [pmid: 12873281].
Ducharme J. Acute pain and pain control: state of the art Ann Emerg Med 2000;35(6):592–603. Erratum in: Ann Emerg Med 2000 Aug 36(2):171. [Rec#: 10857] Exclude at abstract screening: outcome unrelated to pts/family/non-prof
Duckworth R M, Sproat G W, Morien M, Jeffrey T B. Acute bereavement services and routine referral as a mechanism to increase donation. J Transpl Coord. 98;8(1):16-8. [Rec#: 10858] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Duda M, Herman J, Stehlik D. The role of a surgeon in a palliative treatment of tumours. Acta Univ Palacki Olomuc Fac Med. 2000;143:80-1. [Rec#: 10859] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 11144126].
Dudgeon DJ. Managing dyspnea and cough. Hematol Oncol Clin North Am 2002;16(3):557–77, viii. [Rec#: 10860] Exclude at abstract screening: useful only for background
Dudgeon D J. Physician/nursing roles and perspectives in relationship to delivery of palliative care. Ann Acad Med Singapore. 94;23(2):249-51. [Rec#: 10861] Exclude at abstract screening: no outcomes specified.
Dudgeon D J, Kristjanson L. Home versus hospital death: assessment of preferences and clinical challenges. CMAJ Canadian Medical Association Journal. 95;152(3):337-40. [Rec#: 50390] Exclude at abstract screening: no outcomes specified.
Dudgeon D J, Kristjanson L, Sloan J A, Lertzman M, Clement K. Dyspnea in cancer patients: prevalence and associated factors. Journal of Pain & Symptom Management. 2001;21(2):95-102. [Rec#: 50391] Exclude at abstract screening: Study Design - Unclear. [pmid: 11226761].
Dudley J R, Smith C, Millison M B. Unfinished business: assessing the spiritual needs of hospice clients. Am J Hosp Palliat Care. 95;12(2):30-7. [Rec#: 10863] Exclude at abstract screening: Title Only. [pmid: 7605730].
Duffey G. Can we afford to be passive in an aggressive environment?. Am J Hosp Palliat Care. 98;15(6):361-3. [Rec#: 10864] Exclude at abstract screening: Title Only. [pmid: 9866459].
Duffy J. How we die in America--our crisis in American health caring. Conn Med. 2002;66(11):649-54. [Rec#: 10865] Exclude at abstract screening: Title Only. [pmid: 12476506].
Duffy S A, Jackson F. Stressors affecting hospice nurses. Home Healthc Nurse. 96;14(1):54-60. [Rec#: 1956] Exclude at abstract screening: Title Only. [pmid: 8698609].
Duffy T P. When to let go. N Engl J Med 92; 326(14):933–5. Comment in: N Engl J Med. Sep 3. 1992;327(10):737-8. PMID: 1463532. [Rec#: 1957] Exclude at abstract screening: Title Only.
Dugan D C. Pain and the ethics of pain management. HEC Forum. 96;8(6):330-9. [Rec#: 10866] Exclude at abstract screening: no outcomes specified. [pmid: 10165162].
Duggleby W. Elderly hospice cancer patients' descriptions of their pain experiences. Am J Hosp Palliat Care. 2000;17(2):111-7. [Rec#: 1958] Exclude at abstract screening: Observational study. [pmid: 11406955].
Duggleby W. Enduring suffering: a grounded theory analysis of the pain experience of elderly hospice patients with cancer. Oncol Nurs Forum 2000;27(5):825–31. Comment in: Oncol Nurs Forum. Oct. 2000;27(9):1353. PMID: 11058967. [Rec#: 1959] Exclude at abstract screening: Observational study.
Duggleby W. The language of pain at the end of life. Pain Manag Nurs. 2002;3(4):154-60. [Rec#: 1960] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12454807].
Duggleby W. The language of pain at the end of life. Pain Management Nursing. 2002;3(4):154-60. [Rec#: 50392] Exclude at abstract screening: Duplicate already in the flow. [pmid: 12454807].
Duhamel F, Dupuis F. Families in palliative care: exploring family and health-care professionals' beliefs. Int J Palliat Nurs. 2003;9(3):113-9. [Rec#: 10868] Exclude at abstract screening: no outcomes specified. [pmid: 12682573].
Duijts S F, Zeegers M P, Borne B V. The association between stressful life events and breast cancer risk: a meta-analysis. Int J Cancer. 2003;107(6):1023-9. [Rec#: 10870] Exclude at abstract screening: not about end of life. [pmid: 14601065].
Duke S. An analytical study of the changing health of a hospice population 1978–89. Palliat Med. 97;11(2):145-51. [Rec#: 1961] Exclude at abstract screening: data older than 1990. [pmid: 9156111].
Duke S. An exploration of anticipatory grief: the lived experience of people during their spouses' terminal illness and in bereavement. J Adv Nurs. 98;28(4):829-39. [Rec#: 10872] Exclude at abstract screening: Study Design - Qualitative.
Dukes R L, Denny H C. Prejudice toward persons living with a fatal illness. Psychol Rep. 95;76(3 Pt 2):1107-14. [Rec#: 1963] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 7480474].
Dunham W, Bolden J, Kvale E. Obstacles to the delivery of acceptable standards of care in rural home hospices. Am J Hosp Palliat Care 2003;20(4):259–61. Comment in: Am J Hosp Palliat Care. Sep-Oct. 2003;20(5):334. PMID: 14529034. [Rec#: 1971] Exclude at abstract screening: no outcomes specified.
Dunn A, Carter J, Carter H. Anemia at the end of life: prevalence, significance, and causes in patients receiving palliative care. J Pain Symptom Manage. 2003;26(6):1132-9. [Rec#: 1972] Exclude at abstract screening: Other symptoms only. [pmid: 14654265].
Dunn G P, Milch R A. Introduction and historical background of palliative care: where does the surgeon fit in?. J Am Coll Surg. 2001;193(3):325-8. [Rec#: 10880] Exclude at abstract screening: Title Only. [pmid: 11548803].
Dunn G P, Milch R A. Is this a bad day, or one of the last days? How to recognize and respond to approaching demise. J Am Coll Surg. 2002;195(6):879-87. [Rec#: 10881] Exclude at abstract screening: Title Only. [pmid: 12495320].
Dunn G P, Milch R A, Mosenthal A C, Lee K F, Easson A M, Huffman J L. Palliative care by the surgeon: how to do it. J Am Coll Surg. 2002;194(4):509-37. [Rec#: 10882] Exclude at abstract screening: no outcomes specified. [pmid: 11949756].
Dunn G P. Patient assessment in palliative care: how to see the “big picture” and what to do when “there is no more we can do”. J Am Coll Surg. 2001;193(5):565-73. [Rec#: 10879] Exclude at abstract screening: no outcomes specified. [pmid: 11708515].
Dunn M J. ‘Modern medicine’ includes pain management and sensitive end-of-life care. WMJ. 2001;100(5):67-8. [Rec#: 10883] Exclude at abstract screening: no outcomes specified. [pmid: 11579803].
Dunn R W, Reichenfeld H F. Quality end-of-life care. Ann R Coll Physicians Surg Can. 2002;35(4):246. [Rec#: 1973] Exclude at abstract screening: Title Only. [pmid: 14982088].
Dunne K, Coates V E. Care study: providing effective care in palliative nursing. Br J Nurs. 99;8(21):1428-34. [Rec#: 1975] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11011616].
Dunne K, Sullivan K. Family experiences of palliative care in the acute hospital setting. Int J Palliat Nurs. 2000;6(4):170-8. [Rec#: 10887] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11143643].
Dunne T. Spiritual care at the end of life. Hastings Cent Rep. 2001;31(2):22-6. [Rec#: 10888] Exclude at abstract screening: Title Only. [pmid: 11478104].
Dunniece U, Slevin E. Nurses' experiences of being present with a patient receiving a diagnosis of cancer. J Adv Nurs. 2000;32(3):611-8. [Rec#: 1978] Exclude at abstract screening: no outcomes specified. [pmid: 11012803].
Dunphy K, Finlay I, Rathbone G, Gilbert J, Hicks F. Rehydration in palliative and terminal care: if not--why not? Palliat Med 95;9(3):221–8. Comment in: Palliat Med. Apr. 1996;10(2):165-6. PMID: 8800825. [Rec#: 10891] Exclude at abstract screening: no outcomes specified.
Dunphy K. Futilitarianism: knowing how much is enough in end-of-life health care. Palliat Med 2000;14(4) 313–22. Comment in: Palliat Med. Mar. 2001;15(2):169. PMID: 11301671. [Rec#: 10890] Exclude at abstract screening: no outcomes specified.
Dunwoody L, Smyth A, Davidson R. Cancer patients' experiences and evaluations of aromatherapy massage in palliative care. Int J Palliat Nurs. 2002;8(10):497-504. [Rec#: 1979] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 12419989].
Dupree C Y. The attitudes of black Americans toward advance directives. J Transcult Nurs. 2000;11(1):12-8. [Rec#: 1980] Exclude at abstract screening: Observational study. [pmid: 11982070].
Durand R P, Dickinson G E, Sumner E D, Lancaster C J. Family physicians' attitudes toward death and the terminally-ill patient. Fam Pract Res J. 90;9(2):123-9. [Rec#: 1982] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Durham E and Weiss L. How patients die. Am J Nurs 97;97(12)416; quiz 47. [Rec#: 1983] Exclude at abstract screening: Title Only
Durham E S, Weiss L. Coming to terms with death. RN. 92;55(11):23-5. [Rec#: 10897] Exclude at abstract screening: Title Only. [pmid: 1470847].
Durkin A. Incorporating concepts of end-of-life care into a psychiatric nursing course. Nurs Educ Perspect. 2003;24(4):184-5. [Rec#: 10898] Exclude at abstract screening: no outcomes specified. [pmid: 14528863].
Durkin N. The importance of setting boundaries in home care and hospice nursing. Home Healthc Nurse. 2000;18(7):478-81. [Rec#: 10899] Exclude at abstract screening: Title Only. [pmid: 11951758].
Dush D M. High-tech, aggressive palliative care: in the service of quality of life. J Palliat Care. 93;9(1):37-41. [Rec#: 1988] Exclude at abstract screening: no outcomes specified. [pmid: 8492236].
DuVal G, Clarridge B, Gensler G, Danis M. A national survey of U.S internists' experiences with ethical dilemmas and ethics consultation. J Gen Intern Med. 2004;19(3):251-8. [Rec#: 1989] Exclude at abstract screening: Study Design - Unclear. [pmid: 15009780]. [pmcid: 1492156].
Dworkind M, Shvartzman P, Adler P S, Franco E D. Urban family physicians and the care of cancer patients. Can Fam Physician 94;40;47–50. Comment in: Can Fam Physician. 1994 Jan;40:16–9. PMID: 8312750. Comment in: Can Fam Physician. May. 1994;40:874. PMID: 8038630. [Rec#: 10905] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Dyer I D. Breaking the news: informing visitors that a patient has died. Intensive Crit Care Nurs. 93;9(1):2-10. [Rec#: 1993] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Dyer KA. Reshaping our views of death and dying. JAMA 92;267(9) 1265, 1269–70. [Rec#: 10908] Exclude at abstract screening: Title Only
Dzyacky S C, Sheldon M. An acute-care model in the management of end-of-life issues. Nurs Case Manag. 99;4(5):228-35. [Rec#: 10911] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Eagar K, Cromwell D, Kennedy C, Lee L. Classifying sub-acute and non-acute patients: results of the New South Wales Casemix Area Network study. Aust Health Rev. 97;20(2):26-42. [Rec#: 10913] In abstract review process. [pmid: 10169365].
Eakes G G, Burke M L, Hainsworth M A. Middle-range theory of chronic sorrow. Image J Nurs Sch. 98;30(2):179-84. [Rec#: 10915] Exclude at abstract screening: not about end of life. [pmid: 9775562].
Earle C C, Park E R, Lai B, Weeks J C, Ayanian J Z, Block S. Identifying potential indicators of the quality of end-of-life cancer care from administrative data. J Clin Oncol. 2003;21(6):1133-8. [Rec#: 10916] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12637481].
Early B P, Smith E D, Todd L, Beem T. The needs and supportive networks of the dying: an assessment instrument and mapping procedure for hospice patients. American Journal of Hospice & Palliative Care. 2000;17(2):87-96. [Rec#: 50394] Exclude at abstract screening: Study Design - Unclear. [pmid: 11406963].
Easson A M, Asch M, Swallow C J. Palliative general surgical procedures. Surg Oncol Clin N Am. 2001;10(1):161-84. [Rec#: 10918] Exclude at abstract screening: useful only for background. [pmid: 11406457].
Eastaugh A N. Approaches to palliative care by primary health care teams: a survey. J Palliat Care. 96;12(4):47-50. [Rec#: 10920] Exclude at abstract screening: Title Only. [pmid: 9019036].
Easterling L W, Gamino L A, Sewell K W, Stirman L S. Spiritual experience, church attendance, and bereavement. J Pastoral Care. 2000;54(3):263-75. [Rec#: 10921] Exclude at abstract screening: Bereavement only. [pmid: 11146994].
Eastham K. Dealing with bereavement in critical care. Intensive Care Nurs. 90;6(4):185-91. [Rec#: 10922] Exclude at abstract screening: Title Only. [pmid: 2273234].
Ebel S, Langer K. The role of the physical therapist in hospice care. Am J Hosp Palliat Care. 93;10(5):32-5. [Rec#: 10924] Exclude at abstract screening: no outcomes specified. [pmid: 8398475].
Ebell M H, Becker L A, Barry H C, Hagen M. Survival after in-hospital cardiopulmonary resuscitation. A meta-analysis. J Gen Intern Med. 98;13(12):805-16. [Rec#: 50127] Exclude at abstract screening: useful only for background.
Eberhardie C. Nutrition support in palliative care. Nurs Stand 2002;17(2):47–52; quiz 54–5. [Rec#: 10926] Exclude at abstract screening: no outcomes specified
Echenique M, Correia M I. Nutrition in advanced digestive cancer. Curr Opin Clin Nutr Metab Care. 2003;6(5):577-80. [Rec#: 10927] Exclude at abstract screening: useful only for background. [pmid: 12913676].
Edwards M. Barriers to effective pain/symptom control. Am J Hosp Palliat Care. 98;15(2):107-11. [Rec#: 10942] Exclude at abstract screening: no outcomes specified. [pmid: 9543898].
Edwards M. Being present: experiential connections between Zen Buddhist practices and the grieving process. Disabil Rehabil. 97;19(10):442-51. [Rec#: 10943] Exclude at abstract screening: not about end of life.
Edwards S D, Forbes K. Nursing practice and the definition of human death. Nurs Inq. 2003;10(4):229-35. [Rec#: 10944] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 14622369].
Efficace F, Bottomley A. Assessing HRQOL: a neglected issue for high-grade glioma. Lancet Oncol 2003;4(1):11–2. Comment on: Lancet Oncol. 2002 Sep;3(9):557–64. PMID: 12217793. Comment in: Lancet Oncol. May. 2003;4(5):269-70. PMID: 12732162. [Rec#: 10945] Exclude at abstract screening: Title Only.
Efinger J. Help wanted. A quality needs assessment creates a position for a psychiatric clinical nurse specialist. J Psychosoc Nurs Ment Health Serv. 95;33(10):24-30. [Rec#: 10946] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Egleston B L, Rudberg M A, Brody J A. State variation in nursing home mortality outcomes according to do-not-resuscitate status. J Gerontol A Biol Sci Med Sci. 2000;55(4):M215-20. [Rec#: 40980] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 10811151].
Eigentler T K, Caroli U M, Radny P, Garbe C. Palliative therapy of disseminated malignant melanoma: a systematic review of 41 randomised clinical trials. Lancet Oncol. 2003;4(12):748-59. [Rec#: 10953] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 14662431].
Eisdorfer C, Czaja S J, Loewenstein D A, Rubert M P, Arguelles S, Mitrani V B, Szapocznik J. The effect of a family therapy and technology-based intervention on caregiver depression. Gerontologist. 2003;43(4):521-31. [Rec#: 50917] In abstract review process. [pmid: 12937331].
Eisemann M, Eriksson M, Molloy D W, Nordenstam M, Richter J. Attitudes towards self-determination in health care -- a general population survey in northern Sweden. Eur J Public Health. 99;9(1):41-4. [Rec#: 10956] Exclude at abstract screening: Title Only.
Eisenberg B L. Surgical palliation of upper gastrointestinal cancer. Curr Probl Cancer. 95;19(6):338-47. [Rec#: 10957] Exclude at abstract screening: Title Only. [pmid: 8903671].
Eisenberger A and Zeleznik J. Pressure ulcer prevention and treatment in hospices: a qualitative analysis. J Palliat Care. 2003; 19(1):9–14. Comment in: J Palliat Care 2003 Spring;19(1):5–6. PMID: 12710108. [Rec#: 10958] Exclude at abstract screening: Study Design - Qualitative
Eiser A R, Weiss M D. The underachieving advance directive: recommendations for increasing advance directive completion. Am J Bioeth. 2001;1(4):W10. [Rec#: 10961] Exclude at abstract screening: no outcomes specified. [pmid: 11808576].
Ekblad S, Marttila A, Emilsson M. Cultural challenges in end-of-life care: reflections from focus groups' interviews with hospice staff in Stockholm. J Adv Nurs. 2000;31(3):623-30. [Rec#: 2053] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10718882].
Ekman I, Ehrenberg A. Fatigue in chronic heart failure--does gender make a difference?. Eur J Cardiovasc Nurs. 2002;1(1):77-82. [Rec#: 31455] Exclude at abstract screening: Other symptoms only. [pmid: 14622871].
Ekman I, Swedberg K. Home-based management of patients with chronic heart failure--focus on content not just form! Eur Heart J 2002;23(17):1323–5. Comment on: Eur Heart J. Sep. 2002;23(17):1369-78. PMID: 12191748. [Rec#: 50025] Exclude at abstract screening: no outcomes specified.
Ekman I, Ehnfors M, Norberg A. The meaning of living with severe chronic heart failure as narrated by elderly people. Scand J Caring Sci. 2000;14(2):130-6. [Rec#: 31454] Exclude at abstract screening: no outcomes specified. [pmid: 12035276].
Ekman I, Fagerberg B, Skoog I. The clinical implications of cognitive impairment in elderly patients with chronic heart failure. J Cardiovasc Nurs. 2001;16(1):47-55. [Rec#: 31458] Exclude at abstract screening: not about end of life. [pmid: 11587240].
Ekman I, Lundman B, Norberg A. The meaning of hospital care, as narrated by elderly patients with chronic heart failure. Heart Lung. 99;28(3):203-9. [Rec#: 31459] Exclude at abstract screening: Title Only. [pmid: 10330216].
Ekman P. Update on urology--prostate cancer. 3--Systemic and palliative treatment of prostate cancer. Eur J Surg Oncol 95;21(5):555–7; quiz 557, 567. [Rec#: 10963] Exclude at abstract screening: Title Only
Elash A. Freestanding hospices ease pressure on physicians, hospitals, MD says. CMAJ. 98;158(13):1757-8. [Rec#: 10966] Exclude at abstract screening: no outcomes specified. [pmid: 9676556].
Elder N C, Schneider F D, Zweig S C, Peters P G Jr, Ely J W. Community attitudes and knowledge about advance care directives. J Am Board Fam Pract. 92;5(6):565-72. [Rec#: 2058] Exclude at abstract screening: not about end of life.
Elger B S, Chevrolet J C. Attitudes of health care workers towards waking a terminally ill patient in the intensive care unit for treatment decisions. Intensive Care Med. 2003;29(3):487-90. [Rec#: 10967] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12557077].
Elger B S, Harding T W. Terminally ill patients and Jehovah's Witnesses: teaching acceptance of patients' refusals of vital treatments. Med Educ 2002;36(5):479–88. Comment in: Med Educ. May. 2002;36(5):410-1. PMID: 12028389. [Rec#: 2063] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Eliasson A H, Howard R S, Torrington K G, Dillard T A, Phillips Y Y. Do-not-resuscitate decisions in the medical ICU: comparing physician and nurse opinions. Chest. 97;111(4):1106-11. [Rec#: 40990] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Eliott J, Olver I. The discursive properties of “hope”: a qualitative analysis of cancer patients' speech. Qual Health Res. 2002;12(2):173-93. [Rec#: 10971] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11837369].
Eliott J A, Olver I N. Legitimating do-not-resuscitate orders: a discursive study of cancer patients' speech. J Palliat Care. 2003;19(2):100-6. [Rec#: 10972] Exclude at abstract screening: no outcomes specified. [pmid: 12955926].
Eliott J A, Olver I N. Perceptions of “good palliative care” orders: a discursive study of cancer patients' comments. J Palliat Med. 2003;6(1):59-68. [Rec#: 10973] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12710576].
el-Kamar F G, Grossbard M L, Kozuch P S. Metastatic pancreatic cancer: emerging strategies in chemotherapy and palliative care. Oncologist. 2003;8(1):18-34. [Rec#: 10964] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 12604729].
Ellermann C R, Reed P G. Self-transcendence and depression in middle-age adults. West J Nurs Res. 2001;23(7):698-713. [Rec#: 2072] Exclude at abstract screening: not about end of life. [pmid: 11675796].
Ellershaw J, Ward C. Care of the dying patient: the last hours or days of life. BMJ 2003;326(7379):30–4. Comment in: BMJ. 2003 Jan 4;326(7379):30–4. PMID: 12516617. Comment in: BMJ. 2003 Jul 26;327(7408):221–2. PMID: 12881271. Comment in: BMJ. 2003 Jul 26;327(7408):222. PMID: 12881276. Comment in: BMJ. Jul 26. 2003;327(7408):222-3. PMID: 12881275. Comme. [Rec#: 10975] Exclude at abstract screening: Title Only.
Ellershaw J, Smith C, Overill S, Walker S E, Aldridge J. Care of the dying: setting standards for symptom control in the last 48 hours of life. J Pain Symptom Manage. 2001;21(1):12-7. [Rec#: 2073] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11223310].
Ellershaw J E, Peat S J, Boys L C. Assessing the effectiveness of a hospital palliative care team. Palliat Med. 95;9(2):145-52. [Rec#: 10976] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Ellershaw J E, Sutcliffe J M, Saunders C M. Dehydration and the dying patient. J Pain Symptom Manage. 95;10(3):192-7. [Rec#: 2075] Exclude at abstract screening: Other symptoms only. [pmid: 7629413].
Ellershaw J E, Jack B A, Gambles M, Murphy D. ‘If only someone had told me …’ a review of the care of patients dying in hospital. Clin Med. 2003;3(5):483. [Rec#: 50397] Exclude at abstract screening: Title Only. [pmid: 14601954].
Elliott D. Measuring the health outcomes of general ICU patients: a systematic review of methods and findings. Aust Crit Care. 99;12(4):132-40. [Rec#: 40992] Exclude at abstract screening: useful only for background.
Elliott T E. Pain control at the end of life. Minn Med. 97;80(11):27-32. [Rec#: 10979] Exclude at abstract screening: no outcomes specified. [pmid: 9385810].
Ellis F H Jr, Williamson W A, Heatley G J. Cancer of the esophagus and cardia: does age influence treatment selection and surgical outcomes? J Am Coll Surg 98;187(4)345–51. Comment in: J Am Coll Surg. Oct. 1998;187(4):427-8. PMID: 9783791. [Rec#: 2078] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Ellis J. Pronouncing and certifying death. RNABC News. 90;22(1):22. [Rec#: 10981] Exclude at abstract screening: Title Only. [pmid: 2315633].
Ellis M R, Campbell J D, Detwiler-Breidenbach A, Hubbard D K. What do family physicians think about spirituality in clinical practice?. J Fam Pract. 2002;51(3):249-54. [Rec#: 40995] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11978236].
Ellis R, Gregor A. The treatment of brain metastases from lung cancer. Lung Cancer. 98;20(2):81-4. [Rec#: 10982] Exclude at abstract screening: Title Only. [pmid: 9711525].
Ellis S. The patient-centred care model: holistic/multiprofessional/reflective. Br J Nurs. 99;8(5):296-301. [Rec#: 10983] Exclude at abstract screening: no outcomes specified. [pmid: 10362931].
Ellis V, Hill J, and Campbell H. Strengthening the family unit through the healing power of massage. Am J Hosp Palliat Care 95; 12(5)19:19–20, 21. [Rec#: 10984] Exclude at abstract screening: Title Only
Ellison N M, Ptacek J T. Physician interactions with families and caregivers after a patient's death: current practices and proposed changes. J Palliat Med. 2002;5(1):49-55. [Rec#: 10988] Exclude at abstract screening: Bereavement only. [pmid: 11839227].
Ellison N M. Palliative chemotherapy. Am J Hosp Palliat Care. 98;15(2):93-103. [Rec#: 10987] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 9543897].
Ellison S. Nurses' attitudes toward family presence during resuscitative efforts and invasive procedures. J Emerg Nurs. 2003;29(6):515-21. [Rec#: 2082] Exclude at abstract screening: no outcomes specified. [pmid: 14631338].
Ellul J P, Morgan R. Palliation of malignant dysphagia from oesophageal cancer. Br J Hosp Med. 96;55(5):272-4. [Rec#: 10989] Exclude at abstract screening: no outcomes specified. [pmid: 8777520].
Elmstahl S, Wahlfrid C. Increased medical attention needed for frail elderly initially admitted to the emergency department for lack of community support. Aging (Milano). 99;11(1):56-60. [Rec#: 50027] Exclude at abstract screening: primarily prognosis or trajectories.
Elpern E H, Yellen S B, Burton L A. A preliminary investigation of opinions and behaviors regarding advance directives for medical care. Am J Crit Care. 93;2(2):161-7. [Rec#: 2086] Exclude at abstract screening: not about end of life.
el-Rayes B F, Shields A F, Vaitkevicius V, Philip P A. Developments in the systemic therapy of pancreatic cancer. Cancer Invest. 2003;21(1):73-86. [Rec#: 10965] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 12643012].
Elsdon R. Spiritual pain in dying people: the nurse's role. Prof Nurse. 95;10(10):641-3. [Rec#: 10992] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 7630907].
Elsey B, McIntyre J. Assessing a support and learning network for palliative care workers in a country area of South Australia. Aust J Rural Health. 96;4(3):159-64. [Rec#: 10994] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Ely J W, Levinson W, Elder N C, Mainous A G 3rd, Vinson D C. Perceived causes of family physicians' errors J Fam Pract 95;40(4):337–44. Comment in: J Fam Pract. Oct. 1995;41(4):328. PMID: 7561704. [Rec#: 2089] Exclude at abstract screening: not about end of life.
Emanuel EJ and Emanuel LL. The economics of dying. The illusion of cost savings at the end of life. N Engl J Med 94;330(8):540–4. Comment in: N Engl J Med. 1994 Aug 18;331(7):477–8; author reply 478–9. PMID: 8035850. Comment in: N Engl J Med. 1994 Aug 18;331(7):477; author reply 478–9. PMID: 8035848. Comment in: N Engl J Med. 1994 Aug 18;331(7):477; author reply 478–9. PMID. [Rec#: 2091] Exclude at abstract screening: Title Only
Emanuel E J, Ash A, Yu W, Gazelle G, Levinsky N G, Saynina O, McClellan M, Moskowitz M. Managed care, hospice use, site of death, and medical expenditures in the last year of life. Arch Intern Med. 2002;162(15):1722-8. [Rec#: 2090] Exclude at abstract screening: useful only for background. [pmid: 12153375].
Emanuel EJ. Cost savings at the end of life. What do the data show? JAMA 96;275(24):1907–14. Comment in: JAMA. 1996 Oct 16;276(15):1217; author reply 1217–8. PMID: 8849741. Comment in: JAMA. 1996 Oct 16;276(15):1217; author reply 1217–8. PMID: 8849740. [Rec#: 10995] Exclude at abstract screening: useful only for background
Emanuel L L, Emanuel E J. Decisions at the end of life. Guided by communities of patients. Hastings Cent Rep 93;23(5):6–14. Comment in: Hastings Cent Rep. Sep-Oct. 1993;23(5):14-5. PMID: 8262763. [Rec#: 10998] Exclude at abstract screening: no outcomes specified.
Emanuel L L, Barry M J, Emanuel E J, Stoeckle J D. Advance directives: can patients' stated treatment choices be used to infer unstated choices?. Med Care. 94;32(2):95-105. [Rec#: 2096] Exclude at abstract screening: not about end of life.
Emanuel L L, von Gunten C F, Ferris F D. Advance care planning. Arch Fam Med. 2000;9(10):1181-7. [Rec#: 10999] Exclude at abstract screening: useful only for background. [pmid: 11115227].
Emanuel L L, von Gunten C F, Ferris F D. Gaps in end-of-life care. Arch Fam Med. 2000;9(10):1176-80. [Rec#: 11000] Exclude at abstract screening: useful only for background. [pmid: 11115226].
Emanuel L L. Reexamining death. The asymptotic model and a bounded zone definition. Hastings Cent Rep. 95;25(4):27-35. [Rec#: 2095] Exclude at abstract screening: no outcomes specified. [pmid: 7591723].
Emanuel L L. Structured deliberation to improve decisionmaking for the seriously ill. Hastings Cent Rep. 95;25(6):S14-8. [Rec#: 10996] Exclude at abstract screening: Title Only. [pmid: 8608999].
Embey-Isztin D. Hungary: status of cancer pain and palliative care. J Pain Symptom Manage. 93;8(6):420. [Rec#: 11001] Exclude at abstract screening: Title Only. [pmid: 7525767].
Enck R E. Amyotrophic lateral sclerosis and hospice care. Am J Hosp Care. 90;7(1):9-11. [Rec#: 11006] Exclude at abstract screening: Title Only. [pmid: 2361099].
Enck R E. Drug-induced terminal sedation for symptom control. Am J Hosp Palliat Care. 91;8(5):3-5. [Rec#: 2102] Exclude at abstract screening: Title Only.
Enck R E. Prognostication of survival in hospice care. Am J Hosp Palliat Care. 90;7(2):11-3. [Rec#: 11008] Exclude at abstract screening: no outcomes specified.
Enck R E. The role of palliative surgery in hospice care. Am J Hosp Palliat Care. 91;8(6):3-6. [Rec#: 11009] Exclude at abstract screening: Title Only.
Ender M G, Hermsen J M. Working with the bereaved: U.S. Army experiences with nontraditional families. Death Stud. 96;20(6):557-75. [Rec#: 11013] Exclude at abstract screening: sudden/violent/non-chronic deaths.
Enes S P, de Vries K. A survey of ethical issues experienced by nurses caring for terminally ill elderly people. Nurs Ethics. 2004;11(2):150-64. [Rec#: 2105] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 15030023].
Enes S P. An exploration of dignity in palliative care. Palliat Med. 2003;17(3):263-9. [Rec#: 2104] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12725480].
Eng C. Future consideration for improving end-of-life care for older persons: Program of All-inclusive Care for the Elderly (PACE). J Palliat Med. 2002;5(2):305-10. [Rec#: 2106] Exclude at abstract screening: Title Only. [pmid: 12013013].
Eng M A. The hospice interdisciplinary team: a synergistic approach to the care of dying patients and their families. Holist Nurs Pract. 93;7(4):49-56. [Rec#: 11014] Exclude at abstract screening: Title Only. [pmid: 8320286].
Eng P M, Rimm E B, Fitzmaurice G, Kawachi I. Social ties and change in social ties in relation to subsequent total and cause-specific mortality and coronary heart disease incidence in men. Am J Epidemiol. 2002;155(8):700-9. [Rec#: 2107] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 11943687].
Engberg I B. Giving up and withdrawal by ventilator treated patients: nurses' experience. Intensive Care Nurs. 91;7(4):200-5. [Rec#: 11015] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Engel J, Ludwig M S, Schubert-Fritschle G, Tretter W, Holzel D. Cancer prevention and the contribution of cancer registries. J Cancer Res Clin Oncol. 2001;127(6):331-9. [Rec#: 11016] Exclude at abstract screening: not about end of life. [pmid: 11414192].
Engelberg J. On the dynamics of dying. Integr Physiol Behav Sci. 97;32(2):143-8. [Rec#: 2108] Exclude at abstract screening: no outcomes specified. [pmid: 9229241].
Engle V F, Fox-Hill E, Graney M J. The experience of living-dying in a nursing home: self-reports of black and white older adults. J Am Geriatr Soc. 98;46(9):1091-6. [Rec#: 2113] Exclude at abstract screening: not about end of life.
Engle V F. Care of the living, care of the dying: reconceptualizing nursing home care. J Am Geriatr Soc. 98;46(9):1172-4. [Rec#: 2112] Exclude at abstract screening: Title Only. [pmid: 9736117].
Enright B P, Marwit S J. Diagnosing complicated grief: a closer look. J Clin Psychol. 2002;58(7):747-57. [Rec#: 11023] Exclude at abstract screening: no outcomes specified. [pmid: 12205715].
Enting R H, Oldenmenger W H, van der Rijt C C, Koper P, Lieverse J, Sillevis S P. Nitrous oxide is not beneficial for breakthrough cancer pain. Palliat Med. 2002;16(3):257-9. [Rec#: 2114] Exclude at abstract screening: no outcomes specified. [pmid: 12047005].
Enyert G, Burman M E. A qualitative study of self-transcendence in caregivers of terminally ill patients. Am J Hosp Palliat Care. 99;16(2):455-62. [Rec#: 2115] Exclude at abstract screening: Study Design - Qualitative.
Epstein R M, Hundert E M. Defining and assessing professional competence. JAMA. 2002;287(2):226-35. [Rec#: 50399] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11779266].
Erdman L. Laughter therapy for patients with cancer. Oncol Nurs Forum. 91;18(8):1359-63. [Rec#: 2118] Exclude at abstract screening: no outcomes specified. [pmid: 1762976].
Ericksen J, Rodney P, Starzomski R. When is it right to die?. Can Nurse. 95;91(8):29-34. [Rec#: 11027] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 7553557].
Erickson S E, Fried T R, Cherlin E, Johnson-Hurzeler R, Horwitz S M, Bradley E H. The effect of inpatient hospice units on hospice use post-admission. Home Health Care Serv Q. 2002;21(2):73-83. [Rec#: 2119] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12363002].
Eriksson E, Somer S, Lauri S. How relatives adjust after the death of a patient with cancer in hospice. Cancer Nurs. 2001;24(6):436-45. [Rec#: 2121] Exclude at abstract screening: Bereavement only. [pmid: 11762506].
Erlen J A. Issues at the end of life. Orthop Nurs. 96;15(4):37-41. [Rec#: 11029] Exclude at abstract screening: no outcomes specified. [pmid: 8868786].
Ernst E, Filshie J, Hardy J. Evidence-based complementary medicine for palliative cancer care: does it make sense?. Palliat Med. 2003;17(8):704-7. [Rec#: 11032] Exclude at abstract screening: no outcomes specified. [pmid: 14694922].
Ernst E. Complementary cancer treatments: hope or hazard?. Clin Oncol (R Coll Radiol). 95;7(4):259-63. [Rec#: 11030] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 8845327].
Ernst E. Complementary therapies in palliative cancer care. Cancer. 2001;91(11):2181-5. [Rec#: 11031] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 11391600].
Ernst D S, Brasher P, Hagen N, Paterson A H, MacDonald R N, Bruera E. A randomized, controlled trial of intravenous clodronate in patients with metastatic bone disease and pain. Journal of Pain & Symptom Management. 97;13(6):319-26. [Rec#: 50400] Exclude at abstract screening: Study Design - Unclear.
Ersek M, Wilson S A. The challenges and opportunities in providing end-of-life care in nursing homes. J Palliat Med. 2003;6(1):45–57. Comment in: J Palliat Med. Feb. 2003;6(1):7-9. PMID: 12710570. [Rec#: 11035] Exclude at abstract screening: no outcomes specified.
Ersek M, Kagawa-Singer M, Barnes D, Blackhall L, Koenig B A. Multicultural considerations in the use of advance directives. Oncol Nurs Forum. 98;25(10):1683-90. [Rec#: 2128] Exclude at abstract screening: useful only for background.
Escalante C P, Martin C G, Elting L S, Rubenstein E B. Medical futility and appropriate medical care in patients whose death is thought to be imminent. Support Care Cancer. 97;5(4):274-80. [Rec#: 2133] Exclude at abstract screening: useful only for background.
Escalante C P, Martin C G, Elting L S, Price K J, Manzullo E F, Weiser M A, Harle T S, Cantor S B, Rubenstein E B. Identifying risk factors for imminent death in cancer patients with acute dyspnea. J Pain Symptom Manage. 2000;20(5):318-25. [Rec#: 2132] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 11068153].
Eshleman M J. Death with dignity: significance of religious beliefs and practices in Hinduism, Buddhism, and Islam. Todays OR Nurse. 92;14(11):19-23. [Rec#: 11038] Exclude at abstract screening: no outcomes specified.
Esper P, Redman B G. Supportive care, pain management, and quality of life in advanced prostate cancer. Urol Clin North Am. 99;26(2):375-89. [Rec#: 11040] Exclude at abstract screening: no outcomes specified.
Esper P, Hampton J N, Finn J, Smith D C, Regiani S, Pienta K J. A new concept in cancer care: the supportive care program. Am J Hosp Palliat Care. 99;16(6):713-22. [Rec#: 2139] Exclude at abstract screening: Study Design - Unclear.
Esper P, Lockhart J S, Murphy C M. Strengthening end-of-life care through specialty nursing certification. J Prof Nurs. 2002;18(3):130-9. [Rec#: 11039] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12096361].
Esper P S, Pienta K J. Supportive care in the patient with hormone refractory prostate cancer. Semin Urol Oncol. 97;15(1):56-64. [Rec#: 11041] Exclude at abstract screening: no outcomes specified. [pmid: 9050140].
Eth S, Leong G B, Garrick T R. Tales of the crypt for psychiatrists: mourning, melancholia, and mortuary malpractice. Bull Am Acad Psychiatry Law. 96;24(4):483-92. [Rec#: 2145] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Evangelista L S, Dracup K, Doering L V. Racial differences in treatment-seeking delays among heart failure patients. J Card Fail 2002;8(6);381–6. Comment in: J Card Fail. Dec. 2002;8(6):387-9. PMID: 12528091. [Rec#: 50028] Exclude at abstract screening: not about end of life.
Evangelista L S, Kagawa-Singer M, Dracup K. Gender differences in health perceptions and meaning in persons living with heart failure. Heart Lung. 2001;30(3):167-76. [Rec#: 31518] Exclude at abstract screening: not about end of life. [pmid: 11343002].
Evans D. Brain death: the family in crisis. Intensive Crit Care Nurs. 95;11(6):318-21. [Rec#: 11054] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 8574081].
Evans D. Music as an intervention for hospital patients: a systematic review. 2001;<25 Page(s)>. [Rec#: 50843] Exclude at abstract screening: not about end of life
Evans J V. Crisis, grief and loss. Can Nurse. 93;89(8):40-3. [Rec#: 11055] Exclude at abstract screening: not about end of life. [pmid: 8221585].
Evans M L, Englebardt S P. Evaluation of a multidisciplinary perinatal bereavement program. Neonatal Netw. 90;8(4):31-5. [Rec#: 11057] Exclude at abstract screening: Title Only. [pmid: 2308561].
Evans N, Palmer A. Controlling breakthrough pain in palliative care. Nurs Stand. 98;13(7):53-4. [Rec#: 11058] Exclude at abstract screening: no outcomes specified. [pmid: 9919202].
Evans N, Walsh H. The organisation of death and dying in today's society. Nurs Stand. 2002;16(25):33-8. [Rec#: 11059] Exclude at abstract screening: useful only for background. [pmid: 11917406].
Evans R, Stone D, Elwyn G. Organizing palliative care for rural populations: a systematic review of the evidence. Fam Pract. 2003;20(3):304-10. [Rec#: 11061] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 12738700].
Evans R. The effectiveness of transdermal fentanyl in palliative care. Nurs Times. 2003;99(41):24-5. [Rec#: 11060] Exclude at abstract screening: no outcomes specified. [pmid: 14603653].
Evans W M, Bibeau D L, Conley K M. Coping strategies used in residential hospice settings: findings from a national study. Am J Hosp Palliat Care. 2001;18(2):102-10. [Rec#: 2154] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11407126].
Eve A, Higginson I J. Minimum dataset activity for hospice and hospital palliative care services in the UK 1997/98. Palliat Med. 2000;14(5):395-404. [Rec#: 11063] Exclude at abstract screening: useful only for background. [pmid: 11064786].
Eve A, Smith A M. Palliative care services in Britain and Ireland--update 1991. Palliat Med. 94;8(1):19-27. [Rec#: 11064] Exclude at abstract screening: useful only for background. [pmid: 7514068].
Eve A, Smith A M, Tebbit P. Hospice and palliative care in the UK 1994-5, including a summary of trends 1990-5. Palliat Med. 97;11(1):31-43. [Rec#: 2155] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Evers K A. Hospice in Mississippi: an update. J Miss State Med Assoc. 2000;41(1):446-54. [Rec#: 11066] Exclude at abstract screening: Title Only. [pmid: 10646316].
Expert Working Group on Integrated Palliative Care for Persons with AIDS to Health and Welfare Canada Federal Centre for AIDS. Caring Together 87;Health and Welfare Canada Ottawa, ON. [Rec#: 50162] Exclude at abstract screening: Title Only
Experton B, Li Z, Branch L G, Ozminkowski R J, Mellon-Lacey D M. The impact of payor/provider type on health care use and expenditures among the frail elderly. Am J Public Health. 97;87(2):210-6. [Rec#: 41025] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Experton B, Ozminkowski R J, Branch L G, Li Z. A comparison by payor/provider type of the cost of dying among frail older adults. J Am Geriatr Soc. 96;44(9):1098-107. [Rec#: 2162] Exclude at abstract screening: not about end of life.
Faber-Langendoen, K. The clinical management of dying patients receiving mechanical ventilation: a survey of physician practice. Chest 94;106(880–8). [Rec#: 50402] Exclude at abstract screening: Title Only
Faber-Langendoen K, Spomer A, Ingbar D. A prospective study of withdrawing mechanical ventiliation from dying patients. American Journal of Respiratory & Critical Care Medicine. 96;153:A365. [Rec#: 50404] Exclude at abstract screening: Title Only.
Fade A E. End-of-life decisions affect health care providers. Am Nurse. 94;26(1):28-9. [Rec#: 11075] Exclude at abstract screening: Title Only. [pmid: 8304635].
Fade A E. The challenge of end-of-life decisions. Contemp Longterm Care. 95;18(5):63. [Rec#: 11074] Exclude at abstract screening: Title Only. [pmid: 10142838].
Fagerlin A, Ditto P H, Danks J H, Houts R M, Smucker W D. Projection in surrogate decisions about life-sustaining medical treatments. Health Psychol. 2001;20(3):166-75. [Rec#: 2169] Exclude at abstract screening: not about end of life. [pmid: 11403214].
Fainsinger R, Bruera E. The management of dehydration in terminally ill patients. J Palliat Care. 94;10(3):55-9. [Rec#: 11078] Exclude at abstract screening: no outcomes specified. [pmid: 7844647].
Fainsinger R L, Bruera E. Hypodermoclysis (HDC) for symptom control vs the Edmonton Injector (EI). J Palliat Care. 91;7(4):5-8. [Rec#: 11081] Exclude at abstract screening: Study Design - Unclear.
Fainsinger R L, Bruera E. When to treat dehydration in a terminally ill patient?. Support Care Cancer. 97;5(3):205-11. [Rec#: 11082] Exclude at abstract screening: Non-systematic review. [pmid: 9176966].
Fainsinger R L, Gramlich L M. How often can we justify parenteral nutrition in terminally ill cancer patients?. J Palliat Care. 97;13(1):48-51. [Rec#: 2174] Exclude at abstract screening: Title Only. [pmid: 9105158].
Fainsinger R L, Demoissac D, Cole J, Mead-Wood K, Lee E. Home versus hospice inpatient care: discharge characteristics of palliative care patients in an acute care hospital. J Palliat Care. 2000;16(1):29-34. [Rec#: 2173] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10802961].
Fainsinger R L, Pisani A, Bruera E. Use of somatostatin analogues in terminal cancer patients. J Palliat Care. 93;9(1):56-7. [Rec#: 2180] Exclude at abstract screening: Title Only. [pmid: 7684079].
Fainsinger R L, Tapper M, Bruera E. A perspective on the management of delirium in terminally ill patients on a palliative care unit. J Palliat Care. 93;9(3):4-8. [Rec#: 11083] Exclude at abstract screening: no outcomes specified.
Fainsinger R L, Waller A, Bercovici M, Bengtson K, Landman W, Hosking M, Nunez-Olarte J M, deMoissac D. A multicentre international study of sedation for uncontrolled symptoms in terminally ill patients. Palliat Med. 2000;14(4):257-65. [Rec#: 2183] Notes: “EXCLUDE: Location, non-Western”. [pmid: 10974977].
Fainsinger R L. Addressing quality of life at the Edmonton Palliative Care Program. Interview by Anna L. Romer. J Palliat Med. 2001;4(3):417-22. [Rec#: 11079] Exclude at abstract screening: Title Only. [pmid: 11596554].
Fainsinger R L. Palliative care in Edmonton. Support Care Cancer. 95;3(2):91-2. [Rec#: 11080] Exclude at abstract screening: no outcomes specified. [pmid: 7539703].
Fainsinger R, Bruera E. Urinary catheters in palliative care. Journal of Pain & Symptom Management. 91;6(7):449-51. [Rec#: 50405] Exclude at abstract screening: no outcomes specified. [pmid: 1940491].
Fainsinger R L, Bruera E. How should we use transdermal fentanyl (TF) for pain management in palliative care patients?. Journal of Palliative Care. 96;12(1):48-53. [Rec#: 50407] Exclude at abstract screening: no outcomes specified.
Fainsinger R L, Bruera E. Is this opioid analgesic tolerance?. Journal of Pain & Symptom Management. 95;10(7):573-7. [Rec#: 50408] Exclude at abstract screening: not about end of life. [pmid: 8537701].
Fainsinger R L, Bureau E, MacMillan K. Innovative palliative care in Edmonton. Canadian Family Physician. 89;43:1983-6. [Rec#: 50409] Exclude at abstract screening: no outcomes specified. [pmid: 9386885].
Fainsinger R, Schoeller T, Bruera E. Methadone in the management of cancer pain: a review. Pain. 93;52(2):137-47. [Rec#: 50406] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 8455961].
Fairtlough H, Closs S J. Patient focused menu planning: an ENB project in a hospice. Nurs Stand. 96;10(34):44-7. [Rec#: 11085] Exclude at abstract screening: Study Design - Unclear. [pmid: 8716444].
Fakhoury W K. Satisfaction with palliative care: what should we be aware of?. Int J Nurs Stud. 98;35(3):171-6. [Rec#: 11087] Exclude at abstract screening: useful only for background. [pmid: 9789780].
Faller H, Schilling S, Lang H. Causal attribution and adaptation among lung cancer patients. J Psychosom Res. 95;39(5):619-27. [Rec#: 31543] Exclude at abstract screening: not about end of life. [pmid: 7490696].
Fallon M T, Hanks G W. Control of common symptoms in advanced cancer. Ann Acad Med Singapore. 94;23(2):171-7. [Rec#: 11090] Exclude at abstract screening: Non-systematic review. [pmid: 8080222].
Fallowfield L. Quality of life: a new perspective for cancer patients. Nat Rev Cancer. 2002;2(11):873-9. [Rec#: 11091] Exclude at abstract screening: Title Only. [pmid: 12415257].
Fallowfield L J, Jenkins V A, Beveridge H A. Truth may hurt but deceit hurts more: communication in palliative care. Palliat Med. 2002;16(4):297-303. [Rec#: 2197] Exclude at abstract screening: useful only for background. [pmid: 12132542].
Fallowfield L, Jenkins V, Farewell V, Saul J, Duffy A, Eves R. Efficacy of a Cancer Research UK communication skills training model for oncologists: a randomised controlled trial. Lancet. 2002;359(9307):650-6. [Rec#: 50410] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11879860].
Fann J R, Sullivan A K. Delirium in the course of cancer treatment. Semin Clin Neuropsychiatry. 2003;8(4):217-28. [Rec#: 11097] Exclude at abstract screening: Non-systematic review. [pmid: 14613049].
Fanslow-Brunjes C, Schneider P E, Kimmel L H. Hope. Offering comfort and support for dying patients. Nursing. 97;27(3):54-7. [Rec#: 11099] Exclude at abstract screening: Title Only. [pmid: 9171631].
Fanslow-Brunjes C. Hospice nursing: guidance along the “third way”. J N Y State Nurses Assoc. 95;26(1):28-9. [Rec#: 11098] Exclude at abstract screening: Title Only. [pmid: 7636590].
Fantoni M, Ricci F, Del Borgo C, Izzi I, Damiano F, Moscati A M, Marasca G, Bevilacqua N, Del Forno A. Multicentre study on the prevalence of symptoms and symptomatic treatment in HIV infection. Central Italy PRESINT Group. Journal of Palliative Care. 97;13(2):9-13. [Rec#: 50411] Exclude at abstract screening: not about end of life.
Farber S. Sharing the mystery of death with new acquaintances. Fam Med. 2000;32(4):230-1. [Rec#: 11103] Exclude at abstract screening: Title Only. [pmid: 10782366].
Farber S J, Egnew T R, Herman-Bertsch J L. Defining effective clinician roles in end-of-life care. J Fam Pract. 2002;51(2):153-8. [Rec#: 2203] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11978213].
Farber S J, Egnew T R, Herman-Bertsch J L. Issues in end-of-life care: family practice faculty perceptions. J Fam Pract. 99;48(7):525-30. [Rec#: 2204] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Farber S J, Egnew T R, Herman-Bertsch J L, Taylor T R, Guldin G E. Issues in end-of-life care: patient, caregiver, and clinician perceptions. J Palliat Med. 2003;6(1):19-31. [Rec#: 2205] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12710572].
Farberow N L, Gallagher-Thompson D, Gilewski M, Thompson L. The role of social supports in the bereavement process of surviving spouses of suicide and natural deaths. Suicide Life Threat Behav. 92;22(1):107-24. [Rec#: 2208] Exclude at abstract screening: Bereavement only.
Fargason C A Jr, Fargason R E. The changing academic health center. The death of the traditional academic physician. Physician Exec. 96;22(8):22-4. [Rec#: 11104] Exclude at abstract screening: not about end of life.
Farley D R, Weaver A L, Nagorney D M. “Natural history” of unresected cholangiocarcinoma: patient outcome after noncurative intervention. Mayo Clin Proc. 95;70(5):425-9. [Rec#: 2212] Exclude at abstract screening: Study Design - Unclear.
Farncombe M. Dyspnea: assessment and treatment. Support Care Cancer 97;5(2):94–9. Comment in: Support Care Cancer. Mar. 1997;5(2):77-9. PMID: 9069602. [Rec#: 11105] Exclude at abstract screening: no outcomes specified.
Farncombe M L. Ambulatory supportive care for the cancer patient. Curr Opin Oncol. 94;6(4):335-9. [Rec#: 2214] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 7528545].
Farncombe M L. Symptom control in a regional cancer centre: an innovative outpatient approach. J Palliat Care. 91;7(4):21-5. [Rec#: 2215] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Farnon C, Hofmann M. Factors contributing to late hospice admission and proposals for change. Am J Hosp Palliat Care. 97;14(5):212-8. [Rec#: 2218] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Farnon C. A personal exploration of the German hospice system. Am J Hosp Palliat Care 96;13(4):32–7. Erratum in: Am J Hosp Palliat Care 1996 Sep-Oct;13(5):5. [Rec#: 2217] Exclude at abstract screening: no outcomes specified
Farquhar M, Grande G, Todd C, Barclay S. Defining patients as palliative: hospital doctors' versus general practitioners' perceptions. Palliat Med. 2002;16(3):247-50. [Rec#: 11107] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12047002].
Farr W C. The use of corticosteroids for symptom management in terminally ill patients. Am J Hosp Care. 90;7(1):41-6. [Rec#: 11108] Exclude at abstract screening: Title Only. [pmid: 2361097].
Farrar A. How much do they want to know? Communicating with dying patients. Prof Nurse. 92;7(9):606-10. [Rec#: 11109] Exclude at abstract screening: no outcomes specified. [pmid: 1598354].
Farrell M. A process of mutual support. Establishing a support network for nurses caring for dying patients. Prof Nurse 92;8(1):10–2, 14. [Rec#: 11110] Exclude at abstract screening: no outcomes specified
Farrell M. What to do after a bereavement. Prof Nurse. 90;5(10):539-42. [Rec#: 11111] Exclude at abstract screening: Title Only. [pmid: 2381914].
Farrell P M, Hammes B. A promise for palliative care at the end-of-life. WMJ. 2001;100(9):59-66. [Rec#: 11112] Exclude at abstract screening: Title Only. [pmid: 11868521].
Faulkner A, Regnard C. Handling difficult questions in palliative care--a flow diagram. Palliat Med. 94;8(3):245-50. [Rec#: 11118] Exclude at abstract screening: no outcomes specified. [pmid: 7524971].
Faulkner A, Maguire P, Regnard C. Breaking bad news--a flow diagram. Palliat Med. 94;8(2):145-51. [Rec#: 11117] Exclude at abstract screening: no outcomes specified. [pmid: 8081554].
Faulkner A. ABC of palliative care. Communication with patients, families, and other professionals. BMJ. 98;316(7125):130-2. [Rec#: 11116] Exclude at abstract screening: Title Only. [pmid: 9462321].
Faulkner A, Maguire P. Teaching ward nurses to monitor cancer patients. Clinical Oncology. 84;10(4):383-9. [Rec#: 50413] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 6509820].
Faulkner A, Argent J, Jones A. Effective communication in health care: exploring the skills of the teachers. Patient Education & Counseling. 2001;45(3):227-32. [Rec#: 50412]Exclude at abstract screening: not about end of life. [pmid: 11722859].
Faulkner A, Maguire P, Regnard C. Dealing with anger in a patient or relative: a flow diagram. Palliative Medicine. 94;8(1):51-7. [Rec#: 50414] Exclude at abstract screening: no outcomes specified. [pmid: 8180741].
Faull C, Hirsch C. Symptom management in palliative care. Prof Nurse. 2000;16(1):840-3. [Rec#: 11120] Exclude at abstract screening: no outcomes specified. [pmid: 12029721].
Fauri D P, Grimes D R. Bereavement services for families and peers of deceased residents of psychiatric institutions. Soc Work. 94;39(2):185-90. [Rec#: 11122] Exclude at abstract screening: Non-systematic review.
Fauri D P, Ettner B, Kovacs P J. Bereavement services in acute care settings. Death Stud. 2000;24(1):51-64. [Rec#: 11121] Exclude at abstract screening: no outcomes specified. [pmid: 10915447].
Fawcett C. Passionate about palliative care. Nurs Times. 2003;99(12):46-7. [Rec#: 11125] Exclude at abstract screening: Title Only. [pmid: 12710247].
Fawzy F I, Fawzy N W, Pasnau R O. Bereavement in AIDS. Psychiatr Med. 91;9(3):469-82. [Rec#: 11127] Exclude at abstract screening: Title Only. [pmid: 1924833].
Fayad L M, Mitchell D G. Magnetic resonance imaging of pancreatic adenocarcinoma. Int J Gastrointest Cancer. 2001;30(12):19-25. [Rec#: 11128] Exclude at abstract screening: not about end of life. [pmid: 12489577].
Fazeny B, Muhm M, Hauser I, Wenzel C, Mares P, Berzlanovich A, Hagmeister H, Marosi C. Barriers in cancer pain management. Wien Klin Wochenschr. 2000;112(22):978-81. [Rec#: 11129] Exclude at abstract screening: no outcomes specified. [pmid: 11142136].
Fearon R M, Mansell W. Cognitive perspectives on unresolved loss: insights from the study of PTSD. Bull Menninger Clin. 2001;65(3):380-96. [Rec#: 2227] Exclude at abstract screening: not about end of life. [pmid: 11531134].
Fee C. Death of a difficult patient. Ann Emerg Med. 2001;37(3):354-5. [Rec#: 11131] Exclude at abstract screening: Title Only. [pmid: 11223777].
Feenstra J, Lubsen J, Grobbee D E, Stricker B H. Heart failure treatments: issues of safety versus issues of quality of life. Drug Saf. 99;20(1):1-7. [Rec#: 31568] Exclude at abstract screening: no outcomes specified.
Feifel H. Psychology and death. Meaningful rediscovery. Am Psychol. 90;45(4):537-43. [Rec#: 11132] Exclude at abstract screening: no outcomes specified. [pmid: 2186680].
Feigelson C. Personality death, object loss, and the uncanny. Int J Psychoanal. 93;74(Pt 2):331-45. [Rec#: 2229] Exclude at abstract screening: not about end of life. [pmid: 8491536].
Feinsilver D B. The therapist as a person facing death: the hardest of external realities and therapeutic action. Int J Psychoanal. 98;79(Pt 6):1131-50. [Rec#: 2230] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Fekete F, Sauvanet A, Kaisserian G, Jauffret B, Zouari K, Berthoux L, Flejou J F. Associated primary esophageal and lung carcinoma: a study of 39 patients. Ann Thorac Surg. 94;58(3):837-42. [Rec#: 2232] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Feld R. Supportive care in patients with cancer: quality of life and ethical issues. Curr Opin Oncol. 90;2(5):924-8. [Rec#: 11136] Exclude at abstract screening: Title Only. [pmid: 1710503].
Feld S, George L K. Moderating effects of prior social resources on the hospitalizations of elders who become widowed. J Aging Health. 94;6(3):275-95. [Rec#: 2233] Exclude at abstract screening: Study Design - Unclear.
Felder S, Meier M, Schmitt H. Health care expenditure in the last months of life. J Health Econ. 2000;19(5):679-95. [Rec#: 2236] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11184799].
Felder S. Costs of dying: alternatives to rationing. Health Policy 97;39(2):167–76. Erratum in: Health Policy 1997 Jun;40(3):269 [Rec#: 2234] Exclude at abstract screening: useful only for background
Felder S. Health care expenditure towards the end of life. Cardiovasc Drugs Ther. 2001;15(4):345-7. [Rec#: 2235] Exclude at abstract screening: Title Only. [pmid: 11800419].
Feldman M. Some views on the manifestation of the death instinct in clinical work. Int J Psychoanal 2000;81 (Pt 1):53–65. Comment in: Int J Psychoanal. 2000 Oct;81 (Pt 5):1007. PMID: 11109582. Comment in: Int J Psychoanal. Oct. 2000;81(Pt 5):1007-9. PMID: 11109583. [Rec#: 2238] Exclude at abstract screening: no outcomes specified.
Feldman P H, Latimer E, Davidson H. Medicaid-funded home care for the frail elderly and disabled: evaluating the cost savings and outcomes of a service delivery reform. Health Serv Res 96;31(4):489–508. Comment in: Health Serv Res. Oct. 1996;31(4):509-13. PMID: 8885861. [Rec#: 41044] Exclude at abstract screening: Study Design - Unclear.
Feldman-Stewart D, Brundage M D, Hayter C, Groome P, Nickel J C, Downes H, Mackillop W J. What prostate cancer patients should know: variation in professionals' opinions. Radiotherapy & Oncology. 98;49(2):111-23. [Rec#: 50415] Exclude at abstract screening: not about end of life.
Feldman-Stewart D, Brundage M D, Brundage M D, Hayter C, Groome P, Nickel J C, Downes H, Mackillop W J. What questions do patients with curable prostate cancer want answered?. Medical Decision Making. 2000;20(1):7-19. [Rec#: 50416] Exclude at abstract screening: not about end of life. [pmid: 10638532].
Feldman-Stewart D, Chammas S, Hayter C, Pater J, Mackillop W J. An empirical approach to informed consent in ovarian cancer. Journal of Clinical Epidemiology. 96;49(11):1259-69. [Rec#: 50417] Exclude at abstract screening: not about end of life.
Feldstein M A, Gemma P B. Oncology nurses and chronic compounded grief. Cancer Nurs. 95;18(3):228-36. [Rec#: 11140] Exclude at abstract screening: Study Design - Unclear. [pmid: 7600555].
Felker G M, O'Connor C M. Inotropic therapy for heart failure: an evidence-based approach. Am Heart J. 2001;142(3):393-401. [Rec#: 11142] Exclude at abstract screening: not about end of life. [pmid: 11526351].
Fellowes D, Goodman M, Wilkinson S, Low J, Harvey F. District nurses' referrals to home-based palliative nursing services. Nurs Times. 2003;99(14):34-7. [Rec#: 11143] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12718284].
Fellowes D., Gambles M., Lockhart-Wood K., Wilkinson, S. Reflexology for symptom relief in patients with cancer. Cochrane Database of Systematic Reviews 2003;3. [Rec#: 50418] Exclude at abstract screening: Title Only
Fellowes, D., Lockhart-Wood, K., Gambles, M., and Wilkinson, S. Aromatherapy and massage for symptom relief in patients with cancer. Cochrane Database of Systematic Reviews 2003;3. [Rec#: 50419] Exclude at abstract screening: Title Only
Felt D H, Early J L, Welk T A. Attitudes, values, beliefs, and practices surrounding end-of-life care in selected Kansas communities. Am J Hosp Palliat Care. 2000;17(6):401-6. [Rec#: 2241] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11886042].
Fenig E, Eidelevich E, Njuguna E, Katz A, Gutman H, Sulkes A, Schechter J. Role of radiation therapy in the management of cutaneous malignant melanoma. Am J Clin Oncol. 99;22(2):184-6. [Rec#: 2243] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Fenollosa P, Pallares J, Cervera J, Pelegrin F, Inigo V, Giner M, Forner V. Chronic pain in the spinal cord injured: statistical approach and pharmacological treatment. Paraplegia. 93;31(11):722-9. [Rec#: 2244] Exclude at abstract screening: not about end of life.
Ferrand E, Lemaire F, Regnier B, Kuteifan K, Badet M, Asfar P, Jaber S, Chagnon J L, Renault A, Robert R, Pochard F, Herve C, Brun-Buisson C, Duvaldestin P. French RESSENTI Group. Discrepancies between perceptions by physicians and nursing staff of intensive care unit end-of-life decisions. Am J Respir Crit Care Med 2003; 167(10):1310–5. Comment in: Am J Respir Crit Care Med. May 15. 2003;167(10):1302-3. PMID: 12738596. [Rec#: 11149] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Ferrari V D, Lonardi F, Bonciarelli C, Jirillo A, Pavanato G. Evaluating the impact of radiotherapy on the quality of life of cancer patients by two simple indexes. A pilot study. Support Care Cancer. 96;4(1):27-30. [Rec#: 2256] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Ferrel B. Assessing Health-related Quality of Life at End of Life. in press;<25 Page(s)>. [Rec#: 50906] Exclude at abstract screening: Study Design - Review/Meta
Ferrell B, Ervin K, Smith S, Marek T, Melancon C. Family perspectives of ovarian cancer. Cancer Pract. 2002;10(6):269-76. [Rec#: 2258] Exclude at abstract screening: not about end of life. [pmid: 12406048].
Ferrell B, Virani R, Grant M, Coyne P, Uman G. End-of-life care: nurses speak out. Nursing. 2000;30(7):54-7. [Rec#: 2259] Exclude at abstract screening: Title Only. [pmid: 10983102].
Ferrell B A. Pain evaluation and management in the nursing home. Ann Intern Med. 95;123(9):681-7. [Rec#: 11155] Exclude at abstract screening: not about end of life. [pmid: 7574224].
Ferrell B R, Coyle N. An overview of palliative nursing care. Am J Nurs. 2002;102(5):26-31. [Rec#: 2262] Exclude at abstract screening: useful only for background. [pmid: 12006851].
Ferrell B R, Dean G. The meaning of cancer pain. Semin Oncol Nurs. 95;11(1):17-22. [Rec#: 2263] Exclude at abstract screening: no outcomes specified. [pmid: 7740218].
Ferrell B R, Dow K H. Portraits of cancer survivorship: a glimpse through the lens of survivors' eyes. Cancer Pract. 96;4(2):76-80. [Rec#: 2264] Exclude at abstract screening: not about end of life. [pmid: 8715444].
Ferrell B R, Ferrell B A, Rhiner M, Grant M. Family factors influencing cancer pain management. Postgrad Med J. 91;67(Suppl 2):S64-9. [Rec#: 2265] Exclude at abstract screening: Study Design - Qualitative. [pmid: 1758819].
Ferrell B R. Caring at the end of life. Insight. 2001;26(4):109-13. [Rec#: 11156] Exclude at abstract screening: no outcomes specified. [pmid: 11753279].
Ferrell B R. End-of-life care. How well do we serve our patients?. Nursing. 98;28(9):58. quiz 59–60. [Rec#: 11157] Exclude at abstract screening: Title Only. [pmid: 9775888].
Ferrell B R. The quality of lives: 1,525 voices of cancer. Oncol Nurs Forum. 96;23(6):909-16. [Rec#: 11161] Exclude at abstract screening: Title Only. [pmid: 8829161].
Ferrell B A, Stein W M, Beck J C. The Geriatric Pain Measure: validity, reliability and factor analysis. Journal of the American Geriatrics Society. 2000;48(12):1669-73. [Rec#: 50420] Exclude at abstract screening: not about end of life. [pmid: 11129760].
Ferrell B R, Juarez G, Borneman T, ter Veer A. Outcomes of pain education in community home care. Journal of Hospice and Palliative Nursing. 99;1(4):141-150. [Rec#: 50421] Exclude at abstract screening: not about end of life.
Ferrell B R, Virani R, Smith S, Juarez G. National Cancer Policy, Board, and Institute of, Medicine. The role of oncology nursing to ensure quality care for cancer survivors: a report commissioned by the National Cancer Policy Board and Institute of Medicine. Oncology Nursing Forum. Online. 2003;30(1):E1-E11. [Rec#: 50422] Exclude at abstract screening: useful only for background.
Ferris FD, Balfour HM, Bowen K, Farley J, Hardwick M, Lamonmtagne C, Lundy M, Syne A, West P. A Model Guide to Hospice Palliative Care. 2002;<25 Page(s)>. [Rec#: 50423] Exclude at abstract screening: Title Only
Ferris F D, Bezjak A, Rosenthal S G. The palliative uses of radiation therapy in surgical oncology patients. Surg Oncol Clin N Am. 2001;10(1):185-201. [Rec#: 11173] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 11406458].
Ferris F D, Kerr I G, De Angelis C, Sone M, Hume S. Inpatient narcotic infusions for patients with cancer pain. J Palliat Care. 90;6(2):51-9. [Rec#: 2268] Exclude at abstract screening: not about end of life. [pmid: 1695950].
Ferris F D, Von Gunten C F, Emanuel L L. Ensuring competency in end-of-life care: controlling symptoms. BMC Palliat Care. 2002;1(1):5. [Rec#: 2269] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12149128]. [pmcid: 126248].
Ferris F D, Wodinsky H B, Kerr I G, Sone M, Hume S, Coons C. A cost-minimization study of cancer patients requiring a narcotic infusion in hospital and at home. J Clin Epidemiol. 91;44(3):313-27. [Rec#: 2270] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Ferris F D, Balfour H M, Bowen K, Farley J, Hardwick M, Lamontagne C, Lundy M, Syme A, West P J. A model to guide patient and family care: based on nationally accepted principles and norms of practice. Journal of Pain & Symptom Management. 2002;24(2):106-23. [Rec#: 50424] Exclude at abstract screening: Title Only. [pmid: 12231127].
Ferrucci L, Guralnik J M, Pahor M, Corti M C, Havlik R J. Hospital diagnoses, Medicare charges, and nursing home admissions in the year when older persons become severely disabled. JAMA 97;277(9):728–34. Comment in: ACP J Club. 1997 Jul-Aug;127(1):19. Comment in: JAMA. Jul 23–30. 1997;278(4):287-8. PMID: 9228425. [Rec#: 41061] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Ferszt G G, Heineman L, Ferszt E J, Romano S. Transformation through grieving: art and the bereaved. Holist Nurs Pract. 98;13(1):68-75. [Rec#: 2273] Exclude at abstract screening: useful only for background.
Feser L, Bon Bernard C. Enhancing cultural competence in palliative care: perspective of an elderly Chinese community in Calgary. J Palliat Care. 2003;19(2):133-9. [Rec#: 11177] Exclude at abstract screening: Title Only. [pmid: 12955932].
Fesslova V, Hunter S, Stark J, Taylor J F. The long-term clinical outcome of patients with tricuspid atresia II. Influence of surgical procedures. J Cardiovasc Surg (Torino). 91;32(2):225-32. [Rec#: 11178] Exclude at abstract screening: data older than 1990.
Fetters M D, Churchill L, Danis M. Conflict resolution at the end of life. Crit Care Med 2001;29(5):921–5. Comment in: Crit Care Med. May. 2001;29(5):1078-9. PMID: 11383532. [Rec#: 2276] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Feuer D J, Higgins J P. Meta-analysis. Palliat Med. 99;13(5):433-7. [Rec#: 11180] Exclude at abstract screening: Other topic only. [pmid: 10659118].
Fialka-Moser V, Crevenna R, Korpan M, Quittan M. Cancer rehabilitation: particularly with aspects on physical impairments. J Rehabil Med. 2003;35(4):153-62. [Rec#: 11181] Exclude at abstract screening: not about end of life. [pmid: 12892240].
Field D, Addington-Hall J. Extending specialist palliative care to all?. Soc Sci Med. 99;48(9):1271-80. [Rec#: 11187] In abstract review process. [pmid: 10220025].
Field D, Copp G. Communication and awareness about dying in the 1990s. Palliat Med. 99;13(6):459-68. [Rec#: 11188] Exclude at abstract screening: no outcomes specified. [pmid: 10715752].
Field D, Johnson I. Satisfaction and change: a survey of volunteers in a hospice organisation. Soc Sci Med. 93;36(12):1625-33. [Rec#: 2285] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Field D, Wee B. Preparation for palliative care: teaching about death, dying and bereavement in UK medical schools 2000-2001. Med Educ. 2002;36(6):561-7. [Rec#: 11189] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12047672].
Field D, Douglas C, Jagger C, Dand P. Terminal illness: views of patients and their lay carers. Palliat Med. 95;9(1):45-54. [Rec#: 2284] Exclude at abstract screening: Study Design - Qualitative. [pmid: 7719517].
Field D. Communication with dying patients in coronary care units. Intensive Crit Care Nurs. 92;8(1):24-32. [Rec#: 11184] Exclude at abstract screening: no outcomes specified. [pmid: 1559021].
Field D. Palliative medicine and the medicalization of death. Eur J Cancer Care (Engl) 94;3(2):58–62. Comment in: Eur J Cancer Care (Engl). Dec. 1994;3(4):148. PMID: 7704349. [Rec#: 11185] Exclude at abstract screening: no outcomes specified.
Field D. Special not different: general practitioners' accounts of their care of dying people. Soc Sci Med. 98;46(9):1111-20. [Rec#: 11186] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Field G B, Parry J. Pain control: some aspects of day-to-day management. Eur J Cancer Care (Engl). 94;3(2):79-86. [Rec#: 11190] Exclude at abstract screening: not about end of life. [pmid: 7711973].
Field HL. Biopsychosocial aspects of AIDS. New Dir Ment Health Serv 93;(57):51–60. [Rec#: 2287] Exclude at abstract screening: Title Only
Field, M. J. Cassel, C. K. Approaching Death: Improving Care at the End of Life. 1997;<25 Page(s)>. [Rec#: 50425] Exclude at abstract screening: Title Only
Fielden J M. Grief as a transformative experience: weaving through different lifeworlds after a loved one has completed suicide. Int J Ment Health Nurs. 2003;12(1):74-85. [Rec#: 2292] Exclude at abstract screening: sudden/violent/non-chronic deaths. [pmid: 14685962].
Fife R B. Are existential questions the norm for terminally ill patients?. Journal of Palliative Medicine. 2002;5(6):815-7. [Rec#: 50426] Exclude at abstract screening: Title Only. [pmid: 12685527].
Fifield M Y. Relieving constipation and pain in the terminally ill. Am J Nurs. 91;91(7):18-9. [Rec#: 11195] Exclude at abstract screening: Title Only. [pmid: 1858839].
Filiberti A, Ripamonti C, Totis A, Ventafridda V, De Conno F, Contiero P, Tamburini M. Characteristics of terminal cancer patients who committed suicide during a home palliative care program. J Pain Symptom Manage. 2001;22(1):544-53. [Rec#: 2295] Exclude at abstract screening: sudden/violent/non-chronic deaths. [pmid: 11516596].
Filman J, Martin T. The Dorothy Ley Hospice Day Respite Program. J Palliat Care. 98;14(3):94-7. [Rec#: 11198] Exclude at abstract screening: Title Only. [pmid: 9770930].
Filshie J, Penn K, Ashley S, Davis C L. Acupuncture for the relief of cancer-related breathlessness. Palliat Med. 96;10(2):145-50. [Rec#: 2297] Exclude at abstract screening: not about end of life. [pmid: 8800822].
Filshie J. Safety aspects of acupuncture in palliative care. Acupunct Med. 2001;19(2):117-22. [Rec#: 11199] Exclude at abstract screening: no outcomes specified. [pmid: 11829159].
Finch M D, Butler J A. Palliation for nonpancreatic malignant obstruction of the biliary tract. Surg Gynecol Obstet. 90;170(5):437-40. [Rec#: 2300] Exclude at abstract screening: data older than 1990.
Fine P G, Busch M A. Characterization of breakthrough pain by hospice patients and their caregivers. J Pain Symptom Manage. 98;16(3):179-83. [Rec#: 2302] Exclude at abstract screening: Observational study.
Fine P G, Jackson S H. Do not resuscitate in the operating room: more than rights and wrongs. Am J Anesthesiol. 95;22(1):46-51. [Rec#: 11207] Exclude at abstract screening: Title Only. [pmid: 10150236].
Fine P G, Jennings B. CPR in hospice. Hastings Cent Rep. 2003;33(3):9. discussion 9–10. [Rec#: 2303] Exclude at abstract screening: Title Only. [pmid: 12854449].
Fine P G. Analgesia issues in palliative care: bone pain, controlled release opioids, managing opioid-induced constipation and nifedipine as an analgesic. J Pain Palliat Care Pharmacother. 2002;16(1):93-7. [Rec#: 2301] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 14650452].
Fine P G. Analgesic issues in palliative care gastroesophageal reflux pain and chronic non-cancer pain management. J Pain Palliat Care Pharmacother. 2002;16(2):87-9. [Rec#: 11200] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 14650464].
Fine P G. COX-2 selective NSAIDs and advancing legal issues in palliative care. J Pain Palliat Care Pharmacother. 2003;17(1):53-7. [Rec#: 11201] Exclude at abstract screening: no outcomes specified. [pmid: 14640341].
Fine P G. Fear and loathing on the care path: treating pain and suffering. West J Med. 2002;176(1):17. [Rec#: 11203] Exclude at abstract screening: Title Only. [pmid: 11788530]. [pmcid: 1071643].
Fine P G. Medications for patient comfort when weaning mechanical ventilation in palliative care. J Pain Palliat Care Pharmacother. 2002;16(4):61-4. [Rec#: 11205] Exclude at abstract screening: no outcomes specified. [pmid: 14635826].
Fine P G. Palliative radiation therapy in end-of-life care: evidence-based utilization. Am J Hosp Palliat Care 2002;19(3):166–70. Comment in: Am J Hosp Palliat Care. May-Jun. 2002;19(3):151-2. PMID: 12026034. [Rec#: 11206] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Fine R L, Mayo T W. Life-and-death decisions. Tex Med. 99;95(11):64-8. [Rec#: 11209] Exclude at abstract screening: no outcomes specified. [pmid: 10578625].
Fine R L, Mayo T W. Resolution of futility by due process: early experience with the Texas Advance Directives Act. Ann Intern Med 2003;138(9):743–6. Comment in: Ann Intern Med. 2004 Mar 2;140(5):402–3; author reply 404. PMID: 14996685. Comment in: Ann Intern Med. 2004 Mar 2;140(5):403–4; author reply 404. PMID: 14996687. Comment in: Ann Intern Med. Mar 2. 2004;140(5):403. author reply 404. PMID. [Rec#: 2304] Exclude at abstract screening: Study Design - Unclear.
Fine R L. Personal choices--communication among physicians and patients when confronting critical illness. Tex Med. 91;87(9):76-82. [Rec#: 11208] Exclude at abstract screening: no outcomes specified.
Fine P. Low-dose ketamine in the management of opioid nonresponsive, terminal cancer pain. Journal of Pain and Symptom Management. 99;17:296-300. [Rec#: 50427] Exclude at abstract screening: no outcomes specified.
Finkelstein D M, Cassileth B R, Bonomi P D, Ruckdeschel J C, Ezdinli E Z, Wolter J M. A pilot study of the Functional Living Index-Cancer (FLIC) Scale for the assessment of quality of life for metastatic lung cancer patients. An Eastern Cooperative Oncology Group study. Am J Clin Oncol. 88;11(6):630-3. [Rec#: 50866] Exclude at abstract screening: Study Design - Unclear.
Finlay I, Jones N, Wyatt P, Neil J. Use of an unstructured patient-held record in palliative care. Palliat Med. 98;12(5):397-8. [Rec#: 11214] Exclude at abstract screening: Title Only. [pmid: 9924603].
Finlay I. Difficult decisions in palliative care. Br J Hosp Med. 96;56(6):264-7. [Rec#: 11212] Exclude at abstract screening: no outcomes specified. [pmid: 8889094].
Finlay I. UK strategies for palliative care. J R Soc Med 2001;94(9):437–41. Comment in: J R Soc Med. Sep. 2001;94(9):427. PMID: 11535739. [Rec#: 11213] Exclude at abstract screening: Title Only.
Finlay I G, Dunlop R. Quality of life assessment in palliative care. Ann Oncol. 94;5(1):13-8. [Rec#: 11216] Exclude at abstract screening: no outcomes specified. [pmid: 7513536].
Finlay I G, Higginson I J, Goodwin D M, Cook A M, Edwards A G, Hood K, Douglas H R, Normand C E. Palliative care in hospital, hospice, at home: results from a systematic review. Ann Oncol. 2002;13(Suppl 4):257-64. [Rec#: 11217] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 12401699].
Finlay I G, Stott N C, Kinnersley P. The assessment of communication skills in palliative medicine: a comparison of the scores of examiners and simulated patients. Med Educ. 95;29(6):424-9. [Rec#: 11218] Exclude at abstract screening: not about end of life.
Finlay I G. Managing terminally ill prisoners: reflection and action. Palliat Med. 98;12(6):457-61. [Rec#: 11215] Exclude at abstract screening: no outcomes specified. [pmid: 10621866].
Finnema E, Droes R M, Ribbe M, Van Tilburg W. The effects of emotion-oriented approaches in the care for persons suffering from dementia: a review of the literature. Int J Geriatr Psychiatry. 2000;15(2):141-61. [Rec#: 50128] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 10679846].
Fins JJ and Callahan D. Palliation in the age of chronic disease. Hastings Cent Rep 92;22(1):41; discussion 41–2. Comment in: Hastings Cent Rep. 1992 Sep-Oct;22(5):45. PMID: 1385358. [Rec#: 2313] Exclude at abstract screening: no outcomes specified
Fins J J, Solomon M Z. Communication in intensive care settings: the challenge of futility disputes. Crit Care Med. 2001;29(2 Suppl):N10-5. [Rec#: 2316] Exclude at abstract screening: no outcomes specified. [pmid: 11228567].
Fins J J, von Gunten C. When the prognosis leads to indifference. J Palliat Med. 2002;5(4):571-3. [Rec#: 2317] Exclude at abstract screening: Title Only. [pmid: 12243684].
Fins J J. Principles in palliative care: an overview. Respir Care. 2000;45(11):1320-6. discussion 26–30. [Rec#: 11227] Exclude at abstract screening: Title Only. [pmid: 11063520].
Fins J J. Vowing to care. J Pain Symptom Manage 2002;23(1):54–7. Comment in: J Pain Symptom Manage. 2002 Jan;23(1):57–8. PMID: 11811154. Comment in: J Pain Symptom Manage. Jan. 2002;23(1):58-9. PMID: 11811155. [Rec#: 11228] Exclude at abstract screening: Title Only.
Finucane T E, Boyer J T, Bulmash J, Fanale J E, Garrell M, Johnson L E, Katz P R, Pattee J J, Rappaport S A, Ryan J J, et al. The incidence of attempted CPR in nursing homes. J Am Geriatr Soc. 91;39(6):624-6. [Rec#: 41074] Exclude at abstract screening: data older than 1990.
Finucane T E, Elon R D, Keenan J M. The medical director in non-institutional long-term care programs. Clin Geriatr Med. 95;11(3):391-402. [Rec#: 2319] Exclude at abstract screening: no outcomes specified.
Finucane T E. Care of patients nearing death: another view. J Am Geriatr Soc 2002;50(3):551–3. Comment in: J Am Geriatr Soc. Feb. 2003;51(2):281. PMID: 12558734. [Rec#: 2318] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Finucane T E, Christmas C, Travis K. Tube feeding in patients with advanced dementia: a review of the evidence. JAMA. 99;282(14):1365-70. [Rec#: 50429] Exclude at abstract screening: Study Design - Review/Meta.
Fioriglio G. A terminal disease state. Home Healthc Nurse. 99;17(5):336. [Rec#: 11231] Exclude at abstract screening: Title Only. [pmid: 10562009].
Firth S. Counseling model: creating a healing environment in hospitals. Patient Educ Couns. 99;36(1):81-9. [Rec#: 11232] Exclude at abstract screening: no outcomes specified. [pmid: 10036563].
Fischer G S, Arnold R M, Tulsky J A. Talking to the older adult about advance directives. Clin Geriatr Med. 2000;16(2):239-54. [Rec#: 2323] Exclude at abstract screening: no outcomes specified. [pmid: 10783427].
Fischer G S, Tulsky J A, Rose M R, Siminoff L A, Arnold R M. Patient knowledge and physician predictions of treatment preferences after discussion of advance directives. Journal of General Internal Medicine. 98;13(7):447-54. [Rec#: 50430] Exclude at abstract screening: Study Design - Unclear.
Fishbain D. Evidence-based data on pain relief with antidepressants. Ann Med. 2000;32(5):305-16. [Rec#: 50129] Exclude at abstract screening: not about end of life. [pmid: 10949061].
Fisher C. The invisible dimension: abuse in palliative care families. J Palliat Med. 2003;6(2):257-64. [Rec#: 2325] Exclude at abstract screening: Non-systematic review. [pmid: 12854943].
Fisher ES, Wennberg DE, Stukel TA, Gottlieb DJ, Lucas FL, and Pinder EL. The implications of regional variations in Medicare spending. Part 1: the content, quality, and accessibility of care. Ann Intern Med 2003;138(4):273–87. Comment in: Ann Intern Med. 2003 Feb 18;138(4):347–8. PMID: 12585834. Comment in: Ann Intern Med. 2003 Feb 18;138(4):348–9. PMID: 12585835. Comment in: Ann Intern Med. 2003 Feb 18;138(4):350–1. PMID: 12585836. Comment in: Ann Intern Med. 2004 Jan . [Rec#: 2327] Exclude at abstract screening: useful only for background
Fisher J. Harming and benefiting the dead. Death Stud. 2001;25(7):557-68. [Rec#: 11238] Exclude at abstract screening: no outcomes specified. [pmid: 11785539].
Fisher J A, Parker M C. Joint surgical/palliative care ward round in a district general hospital. Palliat Med. 99;13(3):249-50. [Rec#: 11239] Exclude at abstract screening: Title Only. [pmid: 10474712].
Fisher M. Can grief be turned into growth? Staff grief in palliative care. Prof Nurse. 91;7(3):178-82. [Rec#: 11241] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 1763084].
Fisher M. How do members of an interprofessional clinical team adjust to hospice care?. Palliat Med. 96;10(4):319-28. [Rec#: 2329] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Fisher M A, Mitchell G J. Patients' views of quality of life: transforming the knowledge base of nursing. Clin Nurse Spec 98;12(3):99–105. Comment in: Clin Nurse Spec. May. 1998;12(3):98. PMID: 9633325. [Rec#: 2330] Exclude at abstract screening: not about end of life.
Fishman B. The cognitive behavioral perspective on pain management in terminal illness. Hosp J. 92;8(12):73-88. [Rec#: 11244] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 1286853].
Fitch M I, Bakker D, Conlon M. Important issues in clinical practice: perspectives of oncology nurses. Can Oncol Nurs J. 99;9(4):151-64. [Rec#: 2335] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Fitzpatrick M E. Enhancing critical thinking with questions. Kans Nurse. 94;69(5):20-1. [Rec#: 11251] Exclude at abstract screening: Title Only. [pmid: 8007564].
Fitzsimmons D, Johnson C D. Quality of life after treatment of pancreatic cancer. Langenbecks Arch Surg. 98;383(2):145-51. [Rec#: 11253] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Flacker J M, Won A, Kiely D K, Iloputaife I. Differing perceptions of end-of-life care in long-term care. J Palliat Med. 2001;4(1):9-13. [Rec#: 11254] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11291400].
Flacker J M, Marcantonio E R. Delirium in the elderly-optimal management. Drugs and Aging. 98;13:119-130. [Rec#: 50431] Exclude at abstract screening: Title Only. [pmid: 9739501].
Flaherty J H, Morley J E, Murphy D J, Wasserman M R. The development of outpatient Clinical Glidepaths. J Am Geriatr Soc 2002;50(11):1886–901. Comment in: J Am Geriatr Soc. Nov. 2002;50(11):1905-6. PMID: 12410916. [Rec#: 11255] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Flamant R. The relationship with the cancer patient. Ann N Y Acad Sci. 97;809:361-6. [Rec#: 11256] Exclude at abstract screening: Title Only. [pmid: 9103587].
Flaming D. Improve care and comfort: use the label “dying”. J Palliat Care. 2000;16(2):30-6. [Rec#: 11257] Exclude at abstract screening: Title Only. [pmid: 10887730].
Flanagan J, Holmes S. Facing the issue of dependence: some implications from the literature for the hospice and hospice nurses. J Adv Nurs. 99;29(3):592-9. [Rec#: 11258] Exclude at abstract screening: no outcomes specified.
Flannelly K J, Weaver A J, Smith W J, Oppenheimer J E. A systematic review on chaplains and community-based clergy in three palliative care journals: 1990-1999. Am J Hosp Palliat Care. 2003;20(4):263-8. [Rec#: 11259] Exclude at abstract screening: Other topic only. [pmid: 12911070].
Flaskerud J H, Carter P A, Lee P. Distressing emotions in female caregivers of people with AIDS, age-related dementias, and advanced-stage cancers. Perspect Psychiatr Care. 2000;36(4):121-30. [Rec#: 2341] Exclude at abstract screening: Study Design - Unclear. [pmid: 12035204].
Flaskerud J H, Lesser J, Dixon E, Anderson N, Conde F, Kim S, Koniak-Griffin D, Strehlow A, Tullmann D, Verzemnieks I. Health disparities among vulnerable populations: evolution of knowledge over five decades in Nursing Research publications. Nursing Research. 2002;51(2):74-85. [Rec#: 50432] Exclude at abstract screening: not about end of life. [pmid: 11984377].
Fleischer T E. Suffering reclaimed: medicine according to Job. Perspect Biol Med. 99;42(4):475-88. [Rec#: 11264] Exclude at abstract screening: Title Only. [pmid: 11645175].
Fleming C, Mallepalli J, Brensilver JM, and Brandstetter RD. How--and when--to obtain consent for do-not-resuscitate orders. Clinical guidelines and strategies for resolving conflicts. J Crit Illn 95;10(10):679–81, 686, 690–1. [Rec#: 11266] Exclude at abstract screening: no outcomes specified
Fleming D A. Cultural sensitivity in end-of-life discussions. Mo Med. 2003;100(1):69-75. [Rec#: 11268] Exclude at abstract screening: no outcomes specified. [pmid: 12664708].
Fleming D A. The burden of caregiving at the end-of-life. Mo Med. 2003;100(1):82-6. [Rec#: 11267] Exclude at abstract screening: no outcomes specified. [pmid: 12664710].
Fleming SO. Does training in hospice care affect referrals? JAAPA 2003; 16(8):11–2, 15. [Rec#: 11271] Exclude at abstract screening: Title Only
Fletcher JC, Meyer MN, Benson JM, and Denk CE. When and why do Virginians choose to terminate treatment? Va Med Q 98;125(2):112–6, 119. [Rec#: 2345] Exclude at abstract screening: Title Only Exclude at abstract screening: Title Only
Fletcher L. Palliative care. Where there's a will. Nurs Times. 96;92(51):40-1. [Rec#: 11272] Exclude at abstract screening: no outcomes specified. [pmid: 9043348].
Fletcher P N. Experiences in family bereavement. Fam Community Health. 2002;25(1):57-70. [Rec#: 2346] Exclude at abstract screening: Observational study. [pmid: 11966417].
Fletcher W S. "Doctor, am I terminal? Am J Surg 92;163(5):460–2. Comment in: Am J Surg. Jul. 1993;166(1):82-3. PMID: 7687096. [Rec#: 11273] Exclude at abstract screening: Title Only.
Flint A J. Effects of respite care on patients with dementia and their caregivers. Int Psychogeriatr. 95;7(4):505-17. [Rec#: 50130] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 8833274].
Florian V, Mikulincer M. Symbolic immortality and the management of the terror of death: the moderating role of attachment style. J Pers Soc Psychol. 98;74(3):725-34. [Rec#: 2351] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Florian V, Mikulincer M, Hirschberger G. An existentialist view on mortality salience effects: personal hardiness, death-thought accessibility, and cultural worldview defence. Br J Soc Psychol. 2001;40(Pt 3):437-53. [Rec#: 2353] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11593943].
Florian V, Mikulincer M, Hirschberger G. The anxiety-buffering function of close relationships: evidence that relationship commitment acts as a terror management mechanism. J Pers Soc Psychol. 2002;82(4):527-42. [Rec#: 2352] Exclude at abstract screening: not about end of life. [pmid: 11999922].
Florio G A, Donnelly J P, Zevon M A. The structure of work-related stress and coping among oncology nurses in high-stress medical settings: a transactional analysis. J Occup Health Psychol. 98;3(3):227-42. [Rec#: 2355] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Flowers A, Levin V A. Management of brain metastases from breast carcinoma. Oncology (Huntingt). 93;7(3):21-6. discussion 31–4. [Rec#: 11274] Exclude at abstract screening: no outcomes specified. [pmid: 7680880].
Flowers B. Palliative care for patients with end-stage heart failure. Nurs Times. 2003;99(11):30-2. [Rec#: 31642] Exclude at abstract screening: no outcomes specified. [pmid: 12683043].
Flowers B. Palliative care for patients with end-stage heart failure. Nursing Times. 2003;99(11):30-2. [Rec#: 50433] Exclude at abstract screening: no outcomes specified. [pmid: 12683043].
Flume P A. Medicinal treatment of intractable dyspnea in terminally ill patients. J S C Med Assoc 2002;98(4):196–9. Comment in: J S C Med Assoc. Aug. 2002;98(4):200-2. PMID: 12216383. [Rec#: 11275] Exclude at abstract screening: no outcomes specified.
Fok M, Wong J. Cancer of the oesophagus and gastric cardia. Standard oesophagectomy and anastomotic technique. Ann Chir Gynaecol. 95;84(2):179-83. [Rec#: 11278] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Foley D J, Miles T P, Brock D B, Phillips C. Recounts of elderly deaths: endorsements for the Patient Self-Determination Act. Gerontologist. 95;35(1):119-21. [Rec#: 2362] Exclude at abstract screening: data older than 1990.
Foley F J, Flannery J, Graydon D, Flintoft G, Cook D. AIDS palliative care--challenging the palliative paradigm. J Palliat Care. 95;11(2):19-22. [Rec#: 2363] Exclude at abstract screening: Title Only. [pmid: 7541071].
Foley K M, Portenoy R K. World Health Organization-International Association for the Study of Pain: joint initiatives in Cancer Pain Relief. J Pain Symptom Manage. 93;8(6):335-9. [Rec#: 11281] Exclude at abstract screening: Title Only.
Foley K M. Controlling cancer pain. Hosp Pract (Off Ed). 2000;35(4):101-8. [Rec#: 11280] Exclude at abstract screening: no outcomes specified. [pmid: 10780186].
Foliart D E, Clausen M, Siljestrom C. Bereavement practices among California hospices: results of a statewide survey. Death Stud. 2001;25(5):461-7. [Rec#: 11282] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11806414].
Folkman S, Chesney M, Collette L, Boccellari A, Cooke M. Postbereavement depressive mood and its prebereavement predictors in HIV+ and HIV- gay men. J Pers Soc Psychol. 96;70(2):336-48. [Rec#: 2365] Exclude at abstract screening: Bereavement only.
Folland S. Palliative care. Nurs Manag (Harrow). 2000;6(10):5. [Rec#: 11286] Exclude at abstract screening: no outcomes specified. [pmid: 12004379].
Folstein M, Folstein S, McHugh P. Mini-mental state: a practical method for grading the cognitive state of patients for the clinician. Journal of Psychiatric Research. 75;12:189-198. [Rec#: 50434] Exclude at abstract screening: Title Only.
Fonarow G C. ADHERE Scientific Advisory Committee. The Acute Decompensated Heart Failure National Registry (ADHERE): opportunities to improve care of patients hospitalized with acute decompensated heart failure. Rev Cardiovasc Med. 2003;4(Suppl 7):S21-30. [Rec#: 50029] In abstract review process. [pmid: 14668697].
Fonarow G C, Stevenson L W, Walden J A, Livingston N A, Steimle A E, Hamilton M A, Moriguchi J, Tillisch J H, Woo M A. Impact of a comprehensive heart failure management program on hospital readmission and functional status of patients with advanced heart failure. J Am Coll Cardiol. 97;30(3):725-32. [Rec#: 50030] Exclude at abstract screening: not about end of life.
Fong Y, Kemeny N, Paty P, Blumgart L H, Cohen A M. Treatment of colorectal cancer: hepatic metastasis. Semin Surg Oncol. 96;12(4):219-52. [Rec#: 11287] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Fontaine D K. Nonpharmacologic management of patient distress during mechanical ventilation. Crit Care Clin. 94;10(4):695-708. [Rec#: 41099] Exclude at abstract screening: not about end of life. [pmid: 8000922].
Forbes K, Davis C. Managing terminal illness. J R Coll Physicians Lond. 96;30(3):257-9. [Rec#: 11293] Exclude at abstract screening: no outcomes specified. [pmid: 8811602].
Forbes S, Bern-Klug M, Gessert C. End-of-life decision making for nursing home residents with dementia. J Nurs Scholarsh. 2000;32(3):251-8. [Rec#: 2372] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12462819].
Forbes D A. Strategies for managing behavioural symptomatology associated with dementia of the Alzheimer type: a systematic overview. Can J Nurs Res. 98;30(2):67-86. [Rec#: 50131] Exclude at abstract screening: Study Design - Review/Meta.
Ford G. A palliative care system: the Marie Curie model. Am J Hosp Palliat Care. 92;9(3):15-7. [Rec#: 11294] Exclude at abstract screening: no outcomes specified. [pmid: 1280959].
Ford G. A palliative care system: the Marie Curie model. Am J Hosp Palliat Care. 93;10(4):27-9. [Rec#: 11295] Exclude at abstract screening: no outcomes specified. [pmid: 7687140].
Ford Pitorak E, Beckham Armour M, Sivec H D. Project safe conduct integrates palliative goals into comprehensive cancer care. J Palliat Med. 2003;6(4):645-55. [Rec#: 11296] Exclude at abstract screening: Title Only. [pmid: 14516511].
Ford S, Fallowfield L, Lewis S. Can oncologists detect distress in their out-patients and how satisfied are they with their performance during bad news consultations?. British Journal of Cancer. 94;70(4):767-70. [Rec#: 50435] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Fordham H, John W, Finn M D. “It is a privilege to care for the dying”. Mich Med. 93;92(7):22-4. [Rec#: 11297] Exclude at abstract screening: Title Only. [pmid: 8231946].
Fordham S, Dowrick C. Is care of the dying improving? The contribution of specialist and non-specialist to palliative care. Fam Pract. 99;16(6):573-9. [Rec#: 2374] Exclude at abstract screening: Study Design - Review/Meta.
Fordham S, Dowrick C, May C. Palliative medicine: is it really specialist territory? J R Soc Med 98;91(11):568–72. Comment in: J R Soc Med. 1998 Nov;91(11):563–4. PMID: 10325868. Comment in: J R Soc Med. 1999 Feb;92(2):100. PMID: 10450227. Comment in: J R Soc Med. 1999 Feb;92(2):100–1. PMID: 10450228. Comment in: J R Soc Med. Feb. 1999;92(2):101. PMID: 10450230. [Rec#: 11298] Exclude at abstract screening: no outcomes specified.
Formiga F, Espel E, Chivite D, Pujol R. Dying from heart failure in hospital: palliative decision making analysis. Heart. 2002;88(2):187. [Rec#: 2375] Exclude at abstract screening: Title Only. [pmid: 12117854]. [pmcid: 1767230].
Forster M. The meaning of death: some simulations of a model of healthy and unhealthy consumption. J Health Econ. 2001;20(4):613-38. [Rec#: 11301] Exclude at abstract screening: useful only for background. [pmid: 11463191].
Fossa S D, Aass N, Opjordsmoen S. Assessment of quality of life in patients with prostate cancer. Semin Oncol. 94;21(5):657-61. [Rec#: 11307] Exclude at abstract screening: Title Only. [pmid: 7524156].
Fossa S D. Management of hormone resistant prostate cancer. Acta Urol Belg. 94;62(1):73-6. [Rec#: 11305] Exclude at abstract screening: no outcomes specified. [pmid: 7515211].
Fossa S D. Quality of life after palliative radiotherapy in patients with hormone-resistant prostate cancer: single institution experience. Br J Urol. 94;74(3):345-51. [Rec#: 2382] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Fossa S D. Quality of life in advanced prostate cancer. Semin Oncol. 96;23(6 Suppl 14):32-4. [Rec#: 11306] Exclude at abstract screening: no outcomes specified. [pmid: 8996583].
Foster B A. Dying and death: one physician's perspective. W V Med J. 94;90(7):270-1. [Rec#: 11308] Exclude at abstract screening: Title Only. [pmid: 8091759].
Foster J M. The role of the pain clinic in hospice and palliative care. Middle East J Anesthesiol. 94;12(6):521-9. [Rec#: 11310] Exclude at abstract screening: Title Only. [pmid: 7530804].
Foster L W, McLellan L J. Translating psychosocial insight into ethical discussions supportive of families in end-of-life decision-making. Social Work in Health Care. 2002;35(3):37-51. [Rec#: 50436] Exclude at abstract screening: useful only for background. [pmid: 12371791].
Fothergill-Bourbonnais F, Wilson-Barnett J. A comparative study of intensive therapy unit and hospice nurses' knowledge on pain management. J Adv Nurs. 92;17(3):362-72. [Rec#: 2384] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Foulks C J, Holley J L, Moss A H. The use of cardiopulmonary resuscitation: how nephrologists and internists differ. Am J Kidney Dis. 91;18(3):379-83. [Rec#: 41113] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Foulstone S, Harvey B, Wright J, Jay M, Owen F, Cole R. Bereavement support: evaluation of a palliative care memorial service. Palliat Med. 93;7(4):307-11. [Rec#: 11312] Exclude at abstract screening: no outcomes specified.
Fountain A. Ethnic minorities and palliative care in Derby. Palliat Med. 99;13(2):161-2. [Rec#: 2387] Exclude at abstract screening: Title Only. [pmid: 10474700].
Fowler F J Jr, Cleary P D, Massagli M P, Weissman J, Epstein A. The role of reluctance to give up life in the measurement of the values of health states. Med Decis Making 95;15(3):195–200. Comment in: Med Decis Making. Jul-Sep. 1995;15(3):286-7. PMID: 7564943. [Rec#: 2391] Exclude at abstract screening: not about end of life.
Fowler F J Jr, Coppola K M, Teno J M. Methodological challenges for measuring quality of care at the end of life. J Pain Symptom Manage. 99;17(2):114-9. [Rec#: 11315] Exclude at abstract screening: useful only for background.
Fowler J. A welcome focus on a key relationship. Using Peplau's model in palliative care. Prof Nurse. 94;10(3):194-7. [Rec#: 11316] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Fowler J. Taking theory into practice: using Peplau's model in the care of a patient. Prof Nurse. 95;10(4):226-30. [Rec#: 2392] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Fowler-Kerry S. Palliative care within secure forensic environments. J Psychiatr Ment Health Nurs. 2003;10(3):367-9. [Rec#: 11317] Exclude at abstract screening: Title Only. [pmid: 12755923].
Fox E, Lynn J. Prognostic criteria for hospice eligibility. JAMA. 2000;283(19):2527. [Rec#: 2400] Exclude at abstract screening: Title Only. [pmid: 10815115].
Fox E, Landrum-McNiff K, Zhong Z, Dawson N V, Wu A W, Lynn J. Evaluation of prognostic criteria for determining hospice eligibility in patients with advanced lung, heart, or liver disease. SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatments. JAMA 99;282(17):1638–45. Comment in: JAMA. 1999 Nov 3;282(17):1670–2. PMID: 10553796. Comment in: JAMA. May 17. 2000;283(19):2527. PMID: 10815114. [Rec#: 2399] Exclude at abstract screening: primarily prognosis or trajectories.
Fox E T. IV hydration in the terminally ill: ritual or therapy?. Br J Nurs. 96;5(1):41-5. [Rec#: 2401] Exclude at abstract screening: no outcomes specified. [pmid: 8696112].
Fox P L, Raina P, Jadad A R. Prevalence and treatment of pain in older adults in nursing homes and other long-term care institutions: a systematic review. CMAJ. 99;160(3):329-33. [Rec#: 50132] Exclude at abstract screening: Study Design - Review/Meta.
Foxall M J, Zimmerman L, Standley R, Bene B. A comparison of frequency and sources of nursing job stress perceived by intensive care, hospice and medical-surgical nurses. J Adv Nurs. 90;15(5):577-84. [Rec#: 2404] Exclude at abstract screening: not about end of life.
Foxglove T. Music therapy for people with life-limiting illness. Nurs Times. 99;95(18):52-4. [Rec#: 2405] Exclude at abstract screening: no outcomes specified. [pmid: 10373911].
Francis K, Bach J R, DeLisa J A. Evaluation and rehabilitation of patients with adult motor neuron disease. Arch Phys Med Rehabil. 99;80(8):951-63. [Rec#: 2407] Exclude at abstract screening: no outcomes specified.
Franey SG. Three factors critical for end-of-life care. Health Prog 96;77(5):30–2, 44. [Rec#: 11330] Exclude at abstract screening: no outcomes specified
Frank C, Hobbs N R, Stewart G I. Rehabilitation on palliative care units: case discussion. J Palliat Care. 98;14(2):50-3. [Rec#: 2409] Exclude at abstract screening: Title Only. [pmid: 9686496].
Frank E, Prigerson H G, Shear M K, Reynolds C F 3rd. Phenomenology and treatment of bereavement-related distress in the elderly. Int Clin Psychopharmacol. 97;12(Suppl 7):S25-9. [Rec#: 2410] Exclude at abstract screening: no outcomes specified.
Frank C, Heyland D K, Chen B, Farquhar D, Myers K, Iwaasa K. Determining resuscitation preferences of elderly inpatients: a review of the literature. CMAJ. 2003;169(8):795-9. [Rec#: 50133] Exclude at abstract screening: Non-systematic review. [pmid: 14557319]. [pmcid: 203283].
Frankel S, Kammerling M. Assessing the need for hospice beds. Health Trends. 90;22(2):83-6. [Rec#: 11337] Exclude at abstract screening: not about end of life. [pmid: 10108615].
Franklin M. Acting on dilemmas in palliative care. Nurs Times. 2001;97(49):37-8. [Rec#: 11339] Exclude at abstract screening: Title Only. [pmid: 11966286].
Franklin MA. Death and dying fears overcome by progressive strategies. J Long Term Care Adm 94–95;22(4):4–9. Comment in: J Long Term Care Adm. 1994-95 Winter;22(4):10–1. PMID: 10141895. [Rec#: 2413] Exclude at abstract screening: Title Only
Franks PJ, Salisbury C, Bosanquet N, Wilkinson EK, Lorentzon M, Kite S, Naysmith A, and Higginson IJ. The level of need for palliative care: a systematic review of the literature. Palliat Med 2000;14(2):93–104. Erratum in: Palliat Med 2001 Sep;15(5):362. [Rec#: 11343] Exclude at abstract screening: useful only for background
Frantz A K. Breaking down the barriers to heart failure patient self-care. Home Healthc Nurse. 2004;22(2):109-15. [Rec#: 50031] Exclude at abstract screening: no outcomes specified. [pmid: 15076084].
Frantz T T, Lawrence J C, Somov P G, Somova M J. Factors in hospice patients' length of stay. Am J Hosp Palliat Care 99;16(2):449–54. Comment in: Am J Hosp Palliat Care. Mar-Apr;. 1999;16(2):438-9. PMID: 10232119. [Rec#: 2414] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Fraser G L, Riker R R. Monitoring sedation, agitation, analgesia, and delirium in critically ill adult patients. Crit Care Clin. 2001;17(4):967-87. [Rec#: 41124] Exclude at abstract screening: not about end of life. [pmid: 11762270].
Fraser J. Sharing the challenge: the integration of cancer and AIDS. J Palliat Care. 95;11(2):23-5. [Rec#: 2415] Exclude at abstract screening: Title Only. [pmid: 7541072].
Frayne S M, Crawford S L, McGraw S A, Smith K W, McKinlay J B. Help-seeking behaviors of blacks and whites dying from coronary heart disease. Ethn Health. 2002;7(2):77-86. [Rec#: 2418] Exclude at abstract screening: not about end of life. [pmid: 12511195].
Frazier S R. Nursing perspectives on patient management during chronic therapy for relapsed ovarian cancer. Cancer Control. 2001;8(6 Suppl 1):19-21. [Rec#: 11347] Exclude at abstract screening: no outcomes specified. [pmid: 11910333].
Frederich M E. Nonpain symptom management. Prim Care. 2001;28(2):299-316. [Rec#: 11348] Exclude at abstract screening: useful only for background. [pmid: 11406436].
Freeborne N, Lynn J, Desbiens N A. Insights about dying from the SUPPORT project. The Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatments. J Am Geriatr Soc. 2000;48(5 Suppl):S199-205. [Rec#: 2420] Exclude at abstract screening: useful only for background. [pmid: 10809476].
Freeborne N. The collected reports from SUPPORT and HELP: an annotated bibliography of manuscripts in print as of December 31, 1999, and SUPPORT prognostic formulas. Study to Understand Prognoses and Preferences and Risks of Treatment. Hospitalized Elderly Longitudinal Project. J Am Geriatr Soc. 2000;48(5 Suppl):S222-33. [Rec#: 11349] Exclude at abstract screening: useful only for background. [pmid: 10809479].
Freedman V A, Reschovsky J D. Differences across payors in charges for agency-based home health services: evidence from the National Home and Hospice Care Survey. Health Serv Res 97;32(4):433–52. Comment in: Health Serv Res. Oct. 1997;32(4):385-9. PMID: 9327808. [Rec#: 11351] Exclude at abstract screening: not about end of life.
Freer J P, Zinnerstrom K L. The palliative medicine extended standardized patient scenario: a preliminary report. J Palliat Med. 2001;4(1):49-56. [Rec#: 11354] Exclude at abstract screening: no outcomes specified. [pmid: 11291394].
Freichels T A. Palliative ventilatory support: use of noninvasive positive pressure ventilation in terminal respiratory insufficiency. Am J Crit Care 94;3(1):6–10. Comment in: Am J Crit Care. 1994 Jan;3(1):4–5. PMID: 8118491. Comment in: Am J Crit Care. May. 1994;3(3):250-1. PMID: 7518722. [Rec#: 2427] Exclude at abstract screening: Title Only.
Frenette G and Beauchemin JP. Sad but true: your father has dementia. An approach to announcing the diagnosis. Can Fam Physician 2003;49:1296–301. Comment in: Can Fam Physician. 2003 Oct;49:1255–6, 1262–4. PMID: 14594089. [Rec#: 50032] Exclude at abstract screening: Title Only
Frezza E E, Squillario D M, Smith T J. The ethical challenge and the futile treatment in the older population admitted to the intensive care unit. Am J Med Qual. 98;13(3):121-6. [Rec#: 41135] Exclude at abstract screening: primarily prognosis or trajectories.
Frich L M, Borgbjerg F M. Pain and pain treatment in AIDS patients: a longitudinal study. J Pain Symptom Manage. 2000;19(5):339-47. [Rec#: 2431] Exclude at abstract screening: Title Only. [pmid: 10869874].
Frick S, Uehlinger D E, Zuercher Zenklusen R M. Medical futility: predicting outcome of intensive care unit patients by nurses and doctors--a prospective comparative study. Crit Care Med 2003;31(2):456–61. Comment in: Crit Care Med. Feb. 2003;31(2):646-8. PMID: 12576984. [Rec#: 2432] Exclude at abstract screening: primarily prognosis or trajectories.
Frid I, Bergbom-Engberg I, Haljamae H. Brain death in ICUs and associated nursing care challenges concerning patients and families. Intensive Crit Care Nurs. 98;14(1):21-9. [Rec#: 41136] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Fried O. Palliative care for patients with end-stage renal failure: reflections from Central Australia. Palliat Med. 2003;17(6):514-9. [Rec#: 2434] Exclude at abstract screening: no outcomes specified. [pmid: 14526885].
Fried O. Providing palliative care for Aboriginal patients. Aust Fam Physician. 2000;29(11):1035-8. [Rec#: 11364] Exclude at abstract screening: no outcomes specified. [pmid: 11127059].
Fried T R, Bradley E H. What matters to seriously ill older persons making end-of-life treatment decisions?: A qualitative study. J Palliat Med. 2003;6(2):237-44. [Rec#: 2435] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12854940].
Fried T R, Gillick M R. Medical decision-making in the last six months of life: choices about limitation of care. J Am Geriatr Soc. 94;42(3):303-7. [Rec#: 2440] Exclude at abstract screening: Study Design - Unclear.
Fried TR, van Doorn C, O'Leary JR, Tinetti ME, and Drickamer MA. Older persons' preferences for site of terminal care. Ann Intern Med 99;131(2):109–12. Erratum in: Ann Intern Med 2000 Mar 7;132(5):419. [Rec#: 2442] Exclude at abstract screening: useful only for background
Fried T R, van Doorn C, Tinetti M E, Drickamer M A. Older persons' preferences for site of treatment in acute illness. J Gen Intern Med. 98;13(8):522-7. [Rec#: 41140] Exclude at abstract screening: Observational study.
Friedemann M L, Mouch J, Racey T. Nursing the spirit: the Framework of Systemic Organization. J Adv Nurs. 2002;39(4):325-32. [Rec#: 2443] Exclude at abstract screening: no outcomes specified. [pmid: 12139644].
Friedenberg R M. The end of life. Radiology. 2003;228(2):309-12. [Rec#: 11366] Exclude at abstract screening: Title Only. [pmid: 12893892].
Friedman B T, Harwood M K, Shields M. Barriers and enablers to hospice referrals: an expert overview. J Palliat Med. 2002;5(1):73-84. [Rec#: 11368] Exclude at abstract screening: useful only for background. [pmid: 11839229].
Friedman E. A sense of loss. Why do people make irrational demands for care and incomprehensible refusals of care?. Healthc Forum J. 95;38(2):9-12. [Rec#: 11369] Exclude at abstract screening: Title Only.
Friedman M M, King K B. Correlates of fatigue in older women with heart failure. Heart Lung. 95;24(6):512-8. [Rec#: 31733] Exclude at abstract screening: Other symptoms only. [pmid: 8582827].
Friedman M M. Designing home care processes to make organizational improvements: the Joint Commission Standards. Home Healthc Nurse. 2000;18(5):292-5. [Rec#: 11376] Exclude at abstract screening: Title Only. [pmid: 11951760].
Friedman M M. Improving organizational performance standards: data aggregation and analysis. Home Healthc Nurse. 2000;18(7):438-41. [Rec#: 11378] Exclude at abstract screening: Title Only. [pmid: 11951753].
Friedman M M. Infection control update for home care and hospice organizations. Home Healthc Nurse. 2003;21(11):753-8. quiz 759–60. [Rec#: 11379] Exclude at abstract screening: Title Only. [pmid: 14614386].
Friedman M M. Performance improvement: the final phase of an organization's performance. Home Healthc Nurse. 2000;18(8):505-6. [Rec#: 11381] Exclude at abstract screening: Title Only. [pmid: 11951302].
Friedman M M. The impact of the Needlestick Safety and Prevention Act on home care and hospice organizations. Home Healthc Nurse. 2001;19(6):356-60. quiz 361. [Rec#: 11377] Exclude at abstract screening: no outcomes specified. [pmid: 11985232].
Friedman M M. The Joint Commission's National Patient Safety Goals: implications for home care and hospice organizations. Home Healthc Nurse. 2003;21(7):481-8. quiz 489–90. [Rec#: 11380] Exclude at abstract screening: Title Only. [pmid: 12858097].
Friedman R I. Use of advance directives: facilitating health care decisions by adults with mental retardation and their families. Ment Retard. 98;36(6):444-56. [Rec#: 2446] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Friedman Y. Ethical issues in the critically ill patient. Curr Opin Crit Care. 2001;7(6):475-9. [Rec#: 11387] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11805555].
Friedmann J. The dietitian's role in withholding and withdrawing nutritional support: special considerations for the older adult. Nutrition. 97;13(6):587-8. [Rec#: 2448] Exclude at abstract screening: Title Only. [pmid: 9263249].
Friedrichsen M J, Strang P M. Doctors' strategies when breaking bad news to terminally ill patients. J Palliat Med. 2003;6(4):565-74. [Rec#: 41145] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14516498].
Friedrichsen M J, Strang P M, Carlsson M E. Breaking bad news in the transition from curative to palliative cancer care--patient's view of the doctor giving the information. Support Care Cancer 2000;8(6):472–8. Comment in: Support Care Cancer. Nov. 2000;8(6):437-8. PMID: 11094986. [Rec#: 2449] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Friedrichsen M J, Strang P M, Carlsson M E. Cancer patients' interpretations of verbal expressions when given information about ending cancer treatment. Palliat Med. 2002;16(4):323-30. [Rec#: 2450] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12132545].
Friedrichsen M J, Strang P M, Carlsson M E. Receiving bad news: experiences of family members. J Palliat Care. 2001;17(4):241-7. [Rec#: 2452] Exclude at abstract screening: not about end of life. [pmid: 11813341].
Friesen P, Manitt J. Nursing the remarried family in a palliative care setting. J Palliat Care. 90;6(4):32-9. [Rec#: 2454] Exclude at abstract screening: no outcomes specified. [pmid: 1704911].
Friesinger G C 2end, Butler J. End-of-life care for elderly patients with heart failure. Clin Geriatr Med. 2000;16(3):663-75. [Rec#: 2455] Exclude at abstract screening: no outcomes specified. [pmid: 10918653].
Frodin J E. Lung cancer. Acta Oncol. 96;35(Suppl 7):46-53. [Rec#: 50134] Exclude at abstract screening: not about end of life. [pmid: 9154094].
Froggatt K. The place of metaphor and language in exploring nurses' emotional work. J Adv Nurs. 98;28(2):332-8. [Rec#: 11388] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Froggatt K A, Hoult L. Developing palliative care practice in nursing and residential care homes: the role of the clinical nurse specialist. J Clin Nurs. 2002;11(6):802-8. [Rec#: 2460] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12427186].
Froggatt K A, Poole K, Hoult L. The provision of palliative care in nursing homes and residential care homes: a survey of clinical nurse specialist work. Palliat Med. 2002;16(6):481-7. [Rec#: 2461] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12465694].
Froggatt K A. Palliative care and nursing homes: where next?. Palliat Med. 2001;15(1):42-8. [Rec#: 2459] Exclude at abstract screening: no outcomes specified. [pmid: 11212467].
Froiland K G. Wound care of the advanced cancer patient. Hematol Oncol Clin North Am. 2002;16(3):629-39. [Rec#: 11390] Exclude at abstract screening: no outcomes specified. [pmid: 12170572].
Fromme E, Billings J A. Care of the dying doctor: on the other end of the stethoscope. JAMA. 2003;290(15):2048-55. [Rec#: 2462] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14559959].
Frost M. The role of physical, occupational, and speech therapy in hospice: patient empowerment. Am J Hosp Palliat Care. 2001;18(6):397-402. [Rec#: 11393] Exclude at abstract screening: no outcomes specified. [pmid: 11712721].
Frozena CL. Easing end-stage respiratory symptoms in dying patients. Home Healthc Nurse 98;16(4):256–60. Erratum in: Home Healthc Nurse 1998 Jun;16(6):421. [Rec#: 11394] Exclude at abstract screening: Title Only
Fry P S. A factor analytic investigation of home-bound elderly individuals' concerns about death and dying, and their coping responses. J Clin Psychol. 90;46(6):737-48. [Rec#: 2469] Exclude at abstract screening: Study Design - Qualitative.
Fry P S. Perceived self-efficacy domains as predictors of fear of the unknown and fear of dying among older adults. Psychol Aging. 2003;18(3):474-86. [Rec#: 2470] Exclude at abstract screening: not about end of life. [pmid: 14518809].
Fry P S. Predictors of health-related quality of life perspectives, self-esteem, and life satisfactions of older adults following spousal loss: an 18-month follow-up study of widows and widowers. Gerontologist. 2001;41(6):787-98. [Rec#: 2471] Exclude at abstract screening: Bereavement only. [pmid: 11723347].
Fry P S. The unique contribution of key existential factors to the prediction of psychological well-being of older adults following spousal loss. Gerontologist. 2001;41(1):69-81. [Rec#: 2472] Exclude at abstract screening: Study Design - Unclear. [pmid: 11220817].
Fry S T, Duffy M E. The development and psychometric evaluation of the Ethical Issues Scale. J Nurs Scholarsh. 2001;33(3):273-7. [Rec#: 11395] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11552555].
Fryback P B, Reinert B R. Facilitating health in people with terminal diagnoses by encouraging a sense of control. Medsurg Nurs. 93;2(3):197-201. [Rec#: 2474] Exclude at abstract screening: no outcomes specified.
Fryback P B, Reinert B R. Spirituality and people with potentially fatal diagnoses. Nurs Forum. 99;34(1):13-22. [Rec#: 2475] Exclude at abstract screening: Study Design - Qualitative. [pmid: 10426112].
Fryer J E. Psychiatry and HIV hospice care. Focus. 95;10(8):5-6. [Rec#: 11396] Exclude at abstract screening: Title Only. [pmid: 11362647].
Fuh J L, Wang S J, Liu H C, Liu C Y, Wang H C. Predictors of depression among Chinese family caregivers of Alzheimer patients. Alzheimer Dis Assoc Disord. 99;13(3):171-5. [Rec#: 31747] Exclude at abstract screening: not about end of life.
Fuhrer R, Dufouil C, Dartigues JF, and PAQUID Study. Exploring sex differences in the relationship between depressive symptoms and dementia incidence: prospective results from the PAQUID Study. J Am Geriatr Soc 2003;51(8):1055–63. Comment in: J Am Geriatr Soc. 2003 Aug;51(8):1178–80. PMID: 12890087. [Rec#: 31748] Exclude at abstract screening: not about end of life
Fujita L Y, Dungan J. High risk for ineffective management of therapeutic regimen: a protocol study. Rehabil Nurs. 94;19(2):75-9. [Rec#: 31750] Exclude at abstract screening: not about end of life. [pmid: 8128111].
Fujita M, Miyamoto S, Tambara K, Budgell B. Trepopnea in patients with chronic heart failure. Int J Cardiol. 2002;84(23):115-8. [Rec#: 31751] Exclude at abstract screening: no outcomes specified. [pmid: 12127363].
Fukui S. Care for bereaved families. Acta Paediatr Jpn. 94;36(3):304-6. [Rec#: 2483] Exclude at abstract screening: not about end of life. [pmid: 8091985].
Fullbrook S, Wilkinson M B. Some dilemmas of living wills. Br J Theatre Nurs. 96;6(1):13-7. [Rec#: 11402] Exclude at abstract screening: no outcomes specified.
Fulmer T T, Feldman P H, Kim T S, Carty B, Beers M, Molina M, Putnam M. An intervention study to enhance medication compliance in community-dwelling elderly individuals. J Gerontol Nurs. 99;25(8):6-14. [Rec#: 31759] Exclude at abstract screening: not about end of life.
Fulton G, Madden C, Minichiello V. The social construction of anticipatory grief. Soc Sci Med. 96;43(9):1349-58. [Rec#: 11403] Exclude at abstract screening: no outcomes specified. [pmid: 8913004].
Fultz N H, Herzog A R. Self-reported social and emotional impact of urinary incontinence. J Am Geriatr Soc 2001;49(7):892–9. Comment in: J Am Geriatr Soc. 2001 Jul;49(7):998–9. PMID: 11527497. Comment in: J Am Geriatr Soc. Jul. 2002;50(7):1311. PMID: 12133035. [Rec#: 2491] Exclude at abstract screening: not about end of life.
Furman J. Taking a holistic approach to the dying time. Nursing. 2000;30(6):46-9. [Rec#: 11408] Exclude at abstract screening: Title Only. [pmid: 10865663].
Furman J. What you should know about chronic grief. Nursing. 2002;32(2):56-7. [Rec#: 11409] Exclude at abstract screening: Title Only. [pmid: 11924167].
Furnish W L. The nurse's interaction with the AIDS patient. J Pract Nurs. 94;44(1):12-3. [Rec#: 11411] Exclude at abstract screening: not about end of life. [pmid: 8158561].
Furrow B R. Pain management and provider liability: no more excuses. J Law Med Ethics. 2001;29(1):28-51. [Rec#: 11412] Exclude at abstract screening: not about end of life. [pmid: 11521268].
Furst C J. Perspectives on palliative care: Sweden. Support Care Cancer. 2000;8(6):441-3. [Rec#: 11414] Exclude at abstract screening: Title Only. [pmid: 11094987].
Furst C J. The European Association for Palliative Care initiative in Eastern Europe. J Pain Symptom Manage. 2002;24(2):134-5. [Rec#: 11413] Exclude at abstract screening: Title Only. [pmid: 12231130].
Furton E J. Reflections on the status of brain death. Ethics Medics. 99;24(10):2-4. [Rec#: 11415] Exclude at abstract screening: Title Only. [pmid: 12201299].
Furukawa M M. Meeting the needs of the dying patient's family. Crit Care Nurse. 96;16(1):51-7. [Rec#: 11416] Exclude at abstract screening: no outcomes specified. [pmid: 8697776].
Futterman A, Gallagher D, Thompson L W, Lovett S, Gilewski M. Retrospective assessment of marital adjustment and depression during the first 2 years of spousal bereavement. Psychol Aging. 90;5(2):277-83. [Rec#: 2501] Exclude at abstract screening: Bereavement only.
Fuzi B L. Realization impact: nursing assessment and strategies. Dimens Crit Care Nurs. 95;14(6):316-26. [Rec#: 2502] Exclude at abstract screening: no outcomes specified. [pmid: 8631214].
Gabany J M. Factors contributing to the quality of end-of-life care. J Am Acad Nurse Pract. 2000;12(11):472-4. [Rec#: 2503] Exclude at abstract screening: Non-systematic review. [pmid: 11930387].
Gabbard G O, Nadelson C. Professional Boundaries in the Physician-Patient Relationship. Journal of the American Medical Association. 95;273(18):1445-1449. [Rec#: 50438] Exclude at abstract screening: Title Only. [pmid: 7723159].
Gabel J R, Hurst K M, Hunt K A. Health benefits for the terminally ill: reality and perception. Health Aff (Millwood). 98;17(6):120-7. [Rec#: 11420] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Gaby A R. Intravenous nutrient therapy: the “Myers' cocktail”. Altern Med Rev. 2002;7(5):389-403. [Rec#: 31775] Exclude at abstract screening: not about end of life. [pmid: 12410623].
Gadducci A, Cosio S, Fanucchi A, Genazzani A R. Malnutrition and cachexia in ovarian cancer patients: pathophysiology and management. Anticancer Res. 2001;21(4B):2941-7. [Rec#: 11422] Exclude at abstract screening: useful only for background. [pmid: 11712791].
Gadow S. Aging as death rehearsal: the oppressiveness of reason. J Clin Ethics. 96;7(1):35-40. [Rec#: 11423] Exclude at abstract screening: Title Only. [pmid: 8790696].
Gaffin J, Hill D, Penso D. Opening doors: improving access to hospice and specialist palliative care services by members of the black and minority ethnic communities. Commentary on palliative care. Br J Cancer Suppl. 96;29:S51-3. [Rec#: 2507] Exclude at abstract screening: no outcomes specified.
Gage B, Miller SC, Mor V, Harvell J. Synthesis and analysis of Medicare's Hospice benefit, executive summary and recommendations. 2000;<25 Page(s)>. [Rec#: 50439] Exclude at abstract screening: Title Only
Gagnon B, Mancini I, Pereira J, Bruera E. Palliative management of bleeding events in advanced cancer patients. J Palliat Care. 98;14(4):50-4. [Rec#: 2511] Exclude at abstract screening: useful only for background.
Gagnon B, Brucera E. Differences in the ratios of morphine to methadone in patients with neuropathic pain versus non-neuropathic pain. Journal of Pain & Symptom Management. 99;18(2):120-5. [Rec#: 50441] Exclude at abstract screening: Study Design - Unclear.
Gagnon B, Lawlor P G, Mancini I L, Pereira J L, Hanson J, Bruera E D. The impact of delirium on the circadian distribution of breakthrough analgesia in advanced cancer patients. Journal of Pain & Symptom Management. 2001;22(4):826-33. [Rec#: 50442] Exclude at abstract screening: Study Design - Unclear. [pmid: 11576799].
Galambos C M. Preserving end-of-life autonomy: the Patient Self-Determination Act and the Uniform Health Care Decisions Act. Health Soc Work. 98;23(4):275-81. [Rec#: 11425] Exclude at abstract screening: no outcomes specified.
Galasko D, Corey-Bloom J, Thal L J. Monitoring progression in Alzheimer's disease. J Am Geriatr Soc 91;39(9):932–41. Comment in: J Am Geriatr Soc. May. 1992;40(5):537-8. PMID: 1634715. [Rec#: 31780] Exclude at abstract screening: not about end of life.
Galatius S, Gustafsson F, Nielsen P H, Atar D, Hildebrandt P R. An integrated approach to diagnosis and therapeutic management of patients with systolic heart failure in the Copenhagen metropolitan area. Am Heart J. 2002;144(2):E2. [Rec#: 31782] Exclude at abstract screening: Study Design - Unclear. [pmid: 12177660].
Galazka M. Can hospice rehabilitate offenders?. Am J Hosp Care. 90;7(1):17-8. [Rec#: 11426] Exclude at abstract screening: Title Only. [pmid: 2361092].
Gall A. Post stroke depression. Hospital Medicine (London). 2001;62(5):268-73. [Rec#: 50443] Exclude at abstract screening: not about end of life.
Galla JH. Clinical practice guideline on shared decision-making in the appropriate initiation of and withdrawal from dialysis. The Renal Physicians Association and the American Society of Nephrology. J Am Soc Nephrol 2000;11(7):1340–2. Corrected, republished in: J Am Soc Nephrol. 2000 Sep;11(9):2 p following 1788. PMID: 11182927. [Rec#: 11427] Exclude at abstract screening: Title Only
Gallagher L M, Huston M J, Nelson K A, Walsh D, Steele A L. Music therapy in palliative medicine. Support Care Cancer. 2001;9(3):156-61. [Rec#: 11429] Exclude at abstract screening: no outcomes specified. [pmid: 11401099].
Gallagher RM. Primary care and pain medicine. A community solution to the public health problem of chronic pain. Med Clin North Am 99;83(3):555–83, v. [Rec#: 11431] Exclude at abstract screening: not about end of life
Gallagher SM. A discussion of futility and chronic wound care. Ostomy Wound Manage 98;44(5):18–20, 22–3. [Rec#: 2519] Exclude at abstract screening: outcome unrelated to pts/family/non-prof
Gallagher-Thompson D, Arean P, Coon D, Menendez A, Takagi K, Haley W, et al. Development and implementation of intervention strategies for culturally diverse caregiving populations. 2000;<25 Page(s)>. [Rec#: 50920] In abstract review process
Gallo J J, Straton J B, Klag M J, Meoni L A, Sulmasy D P, Wang N Y, Ford D E. Life-sustaining treatments: what do physicians want and do they express their wishes to others?. J Am Geriatr Soc. 2003;51(7):961-9. [Rec#: 2526] Exclude at abstract screening: no outcomes specified. [pmid: 12834516].
Gallo-Silver L, Pollack B. Behavioral interventions for lung cancer-related breathlessness. Cancer Pract. 2000;8(6):268-73. [Rec#: 31786] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11898143].
Galluzzi K E. Caring for the caregivers. J Am Osteopath Assoc. 99;99(9 Suppl):S17-20. [Rec#: 31787] Exclude at abstract screening: not about end of life. [pmid: 10730509].
Galvin J. An audit of pressure ulcer incidence in a palliative care setting. Int J Palliat Nurs. 2002;8(5):214-21. [Rec#: 2530] Exclude at abstract screening: not about end of life. [pmid: 12048504].
Galynker I, Ieronimo C, Miner C, Rosenblum J, Vilkas N, Rosenthal R. Methylphenidate treatment of negative symptoms in patients with dementia. J Neuropsychiatry Clin Neurosci. 97;9(2):231-9. [Rec#: 31789] Exclude at abstract screening: Observational study.
Gambassi G, Landi F, Lapane K L, Sgadari A, Mor V, Bernabei R. Is drug use by the elderly with cognitive impairment influenced by type of dementia?. Pharmacotherapy. 99;19(4):430-6. [Rec#: 31790] Exclude at abstract screening: Study Design - Unclear.
Gamble K. Communication and information: the experience of radiotherapy patients. Eur J Cancer Care (Engl). 98;7(3):153-61. [Rec#: 31792] Exclude at abstract screening: not about end of life. [pmid: 9793006].
Gambles M, Wilkinson S M, Dissanayake C. What are you like?: A personality profile of cancer and palliative care nurses in the United kingdom. Cancer Nurs. 2003;26(2):97-104. [Rec#: 2532] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12660558].
Gamborg H, Madsen L D. Palliative care in Denmark. Support Care Cancer. 97;5(2):82-4. [Rec#: 11433] Exclude at abstract screening: no outcomes specified. [pmid: 9069604].
Gamino L A, Hogan N S, Sewell K W. Feeling the absence: a content analysis from the Scott and White grief study. Death Stud. 2002;26(10):793-813. [Rec#: 11434] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12440420].
Gamino L A, Sewell K W, Easterling L W. Scott and White Grief Study--phase 2: toward an adaptive model of grief. Death Stud. 2000;24(7):633-60. [Rec#: 11435] Exclude at abstract screening: Bereavement only. [pmid: 11503673].
Gamlin R, Kinghorn S. Using hope to cope with loss and grief. Nurs Stand. 95;9(48):33-5. [Rec#: 11437] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 7662535].
Ganesan R, Standish T, Molloy D W, Darzins P, Orange J B. New treatments for dementia. Myth, magic, and science. Can Fam Physician. 94;40:1149-57. [Rec#: 2536] Exclude at abstract screening: useful only for background.
Gannon C, McNamara P. A retrospective observation of corticosteroid use at the end of life in a hospice. J Pain Symptom Manage. 2002;24(3):328-34. [Rec#: 11440] Exclude at abstract screening: Other topic only. [pmid: 12458114].
Gans M, Gunn W B Jr. End stage anorexia: criteria for competence to refuse treatment. Int J Law Psychiatry. 2003;26(6):677-95. [Rec#: 2540] Exclude at abstract screening: Title Only. [pmid: 14637208].
Ganz P A, Lee J J, Siau J. Quality of life assessment. An independent prognostic variable for survival in lung cancer. Cancer. 91;67(12):3131-5. [Rec#: 2542] Exclude at abstract screening: primarily prognosis or trajectories.
Ganz P A. Quality of Life Across the Continuum of Breast Cancer Care. Breast J. 2000;6(5):324-330. [Rec#: 2541] Exclude at abstract screening: no outcomes specified. [pmid: 11348391].
Ganzini L, Lee M A, Heintz R T, Bloom J D. Do-not-resuscitate orders for depressed psychiatric inpatients. Hosp Community Psychiatry. 92;43(9):915-9. [Rec#: 2543] Exclude at abstract screening: no outcomes specified.
Ganzini L, Lee M A, Heintz R T, Bloom J D, Fenn D S. The effect of depression treatment on elderly patients' preferences for life-sustaining medical therapy. American Journal of Psychiatry. 94;151(11):1631-6. [Rec#: 50446] Exclude at abstract screening: useful only for background.
Ganzini L, Smith D M, Fenn D S, Lee M A. Depression and mortality in medically ill older adults. Journal of the American Geriatrics Society. 97;45(3):307-12. [Rec#: 50447] Exclude at abstract screening: primarily prognosis or trajectories.
Ganzini L, Volicer L, Nelson W, Derse A. Pitfalls in assessment of decision-making capacity. Psychosomatics. 2003;44(3):237-43. [Rec#: 50448] Exclude at abstract screening: not about end of life. [pmid: 12724505].
Garattini S. Narcotic drug use for severe pain. Lancet. 93;341(8852):1061-2. [Rec#: 11442] Exclude at abstract screening: not about end of life. [pmid: 8096965].
Garcia de Lucio L, Garcia Lopez F J, Marin Lopez M T, Mas Hesse B, Caamano Vaz M D. Training programme in techniques of self-control and communication skills to improve nurses' relationships with relatives of seriously ill patients: a randomized controlled study. J Adv Nurs. 2000;32(2):425-31. [Rec#: 41170] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10964191].
Garcia J A, Romano P S, Chan B K, Kass P H, Robbins J A. Sociodemographic factors and the assignment of do-not-resuscitate orders in patients with acute myocardial infarctions. Med Care. 2000;38(6):670-8. [Rec#: 41174] Exclude at abstract screening: sudden/violent/non-chronic deaths. [pmid: 10843314].
Garcia O D. The unity of the human person: a central concept in the interface between medicine and theology. Linacre Q. 2001;68(1):71-89. [Rec#: 11446] Exclude at abstract screening: Title Only. [pmid: 11770570].
Garcia-Aguilar J, Cromwell J W, Marra C, Lee S H, Madoff R D, Rothenberger D A. Treatment of locally recurrent rectal cancer. Dis Colon Rectum. 2001;44(12):1743-8. [Rec#: 2546] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 11742153].
Garden D. Advance medical directives (living wills). J Med Assoc Thai. 99;82(4):414-23. [Rec#: 11447] Exclude at abstract screening: Title Only. [pmid: 10410506].
Gardner A, Sibthorpe B. Will he get back to normal? Survival and functional status after intensive care therapy. Intensive Crit Care Nurs. 2002;18(3):138-45. [Rec#: 41175] Exclude at abstract screening: not about end of life. [pmid: 12405268].
Gardner-Nix J S, Brodie R, Tjan E, Wilton M, Zoberman L, Barnes F, Friedrich J, Wood J. Scarborough's Palliative ‘At-home’ Care Team (PACT): a model for a suburban physician palliative care team. J Palliat Care. 95;11(3):43-9. [Rec#: 11449] Exclude at abstract screening: Title Only.
Garfield F B, Getsios D, Caro J J, Wimo A, Winblad B. Assessment of Health Economics in Alzheimer's Disease (AHEAD): treatment with galantamine in Sweden. Pharmacoeconomics. 2002;20(9):629-37. [Rec#: 31806] Exclude at abstract screening: not about end of life. [pmid: 12141890].
Garner J. Dementia: an intimate death. Br J Med Psychol. 97;70(Pt 2):177-84. [Rec#: 2549] Exclude at abstract screening: no outcomes specified. [pmid: 9210994].
Garner P D, Hall L D, Johnstone P A. Palliation of unresectable hilar cholangiocarcinoma. J Surg Oncol 2000;75(2):95–7. Comment on: J Surg Oncol. Oct. 2000;75(2):89-94. PMID: 11064386. [Rec#: 11452] Exclude at abstract screening: no outcomes specified.
Garnett M. Sustaining the cocoon: the emotional inoculation produced by complementary therapies in palliative care. Eur J Cancer Care (Engl). 2003;12(2):129-36. [Rec#: 11453] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12787010].
Garnett M. Sustaining the cocoon: the emotional inoculation produced by complementary therapies in palliative care. European Journal of Cancer Care. 2003;12(2):129-36. [Rec#: 50449] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12787010].
Garrett G. A natural way to go? Death and bereavement in old age. Prof Nurse 91;6(12):744–6, 748–9. [Rec#: 11454] Exclude at abstract screening: no outcomes specified
Garrett J M, Harris R P, Norburn J K, Patrick D L, Danis M. Life-sustaining treatments during terminal illness: who wants what?. J Gen Intern Med. 93;8(7):361-8. [Rec#: 2552] Exclude at abstract screening: data older than 1990.
Garvey C. AIDS care for the elderly. A community-based approach. AIDS Patient Care. 94;8(3):118-20. [Rec#: 2555] Exclude at abstract screening: Title Only. [pmid: 11362132].
Garwin M. The duty to care--the right to refuse. Changing roles of patients and physicians in end--life decision making. J Leg Med. 98;19(1):99-125. [Rec#: 11455] Exclude at abstract screening: Title Only. [pmid: 9564096].
Garza-Guerrero C. Idealization and mourning in love relationships: normal and pathological spectra. Psychoanal Q. 2000;69(1):121-50. [Rec#: 11456] Exclude at abstract screening: not about end of life. [pmid: 10729945].
Gaskins S, Brown K. Psychosocial responses among individuals with human immunodeficiency virus infection. Appl Nurs Res. 92;5(3):111-21. [Rec#: 2556] Exclude at abstract screening: not about end of life.
Gatchel R J, Noe C E, Pulliam C, Robbins H, Deschner M, Gajraj N M, Vakharia A S. A preliminary study of multidimensional pain inventory profile differences in predicting treatment outcome in a heterogeneous cohort of patients with chronic pain. Clin J Pain. 2002;18(3):139-43. [Rec#: 2558] Exclude at abstract screening: not about end of life. [pmid: 12048414].
Gates E A. Understanding the goals of care in end-of-life decision making: a committee opinion at the bedside. Womens Health Issues. 96;6(5):302-3. [Rec#: 2559] Exclude at abstract screening: Title Only. [pmid: 8870510].
Gates K M. The experience of caring for a loved one: a phenomenological study. Nurs Sci Q. 2000;13(1):54-9. [Rec#: 2560] Exclude at abstract screening: not about end of life. [pmid: 11847782].
Gates M F, Kaul M, Speece M W, Brent S B. The attitudes of beginning nursing and medical students toward care of dying patients: a preliminary study. Hosp J. 92;8(4):17-32. [Rec#: 2561] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Gates MF. Culture Care theory for study of dying patients in hospital and hospice contexts. NLN Publ 91;(15–2402):281–304. [Rec#: 11461] Exclude at abstract screening: Title Only
Gates M F. Transcultural comparison of hospital and hospice as caring environments for dying patients. J Transcult Nurs. 91;2(2):3-15. [Rec#: 11462] Exclude at abstract screening: Study Design - Unclear.
Gates R A, Weaver M J, Gates R H. Patient acceptance of an information sheet about cardiopulmonary resuscitation options. J Gen Intern Med. 93;8(12):679-82. [Rec#: 2563] Exclude at abstract screening: not about end of life.
Gates R P. Throw “hospice” out the window. Am J Hosp Palliat Care. 93;10(2):4-5. [Rec#: 11463] Exclude at abstract screening: Title Only. [pmid: 8117484].
Gatrad A R, Sheikh A. Palliative care for Muslims and issues before death. Int J Palliat Nurs. 2002;8(11):526-31. [Rec#: 2564] Exclude at abstract screening: useful only for background. [pmid: 12514462].
Gatrad R, Sheikh A. Palliative care for Muslims and issues after death. Int J Palliat Nurs. 2002;8(12):594-7. [Rec#: 11467] Exclude at abstract screening: useful only for background. [pmid: 12560802].
Gatrad R P P, Brown E, Sheikh A. Palliative care for Hindus. Int J Palliat Nurs. 2003;9(10):442-8. [Rec#: 11465] Exclude at abstract screening: useful only for background. [pmid: 14593282].
Gatrad R, Panesar S S, Brown E, Notta H, Sheikh A. Palliative care for Sikhs. Int J Palliat Nurs. 2003;9(11):496-8. [Rec#: 11466] Exclude at abstract screening: useful only for background. [pmid: 14676727].
Gatrell A C, Harman J C, Francis B J, Thomas C, Morris S M, McIllmurray M. Place of death: analysis of cancer deaths in part of North West England. J Public Health Med. 2003;25(1):53-8. [Rec#: 11468] Exclude at abstract screening: Other topic only. [pmid: 12669919].
Gatter R. Unnecessary adversaries at the end of life: mediating end-of-life treatment disputes to prevent erosion of physician-patient relationships. Boston Univ Law Rev. 99;79(5):1091-137. [Rec#: 11469] Exclude at abstract screening: Title Only.
Gattis W A, Hasselblad V, Whellan D J, O'Connor C M. Reduction in heart failure events by the addition of a clinical pharmacist to the heart failure management team: results of the Pharmacist in Heart Failure Assessment Recommendation and Monitoring (PHARM) Study. Arch Intern Med 99;159(16):1939–45. Comment in: Arch Intern Med. Jun 12. 2000;160(11):1698. PMID: 10847264. [Rec#: 31818] Exclude at abstract screening: primarily prognosis or trajectories.
Gauthier D M, Swigart V A. The contextual nature of decision making near the end of life: hospice patients' perspectives. Am J Hosp Palliat Care. 2003;20(2):121-8. [Rec#: 2569] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12693644].
Gauthier L, Gauthier S. Assessment of functional changes in Alzheimer's disease. Neuroepidemiology. 90;9(4):183-8. [Rec#: 31820] Exclude at abstract screening: not about end of life. [pmid: 2215842].
Gauthier S, Gelinas I, Gauthier L. Functional disability in Alzheimer's disease. Int Psychogeriatr. 97;9(Suppl 1):163-5. [Rec#: 31823] Exclude at abstract screening: no outcomes specified. [pmid: 9447439].
Gavrin J, Chapman C R. Clinical management of dying patients. West J Med. 95;163(3):268-77. [Rec#: 11471] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 7571591].
Gazelle G. A good death: not just an abstract concept. J Clin Oncol 2001;19(3):917–8. Comment in: J Clin Oncol. Oct 1. 2001;19(19):3999. PMID: 11579126. [Rec#: 11475] Exclude at abstract screening: no outcomes specified.
Gazelle G. The slow code--should anyone rush to its defense? N Engl J Med 98;338(7):467–9. Comment in: N Engl J Med. 1998 Jun 25;338(26):1921–2; author reply 1922–3. PMID: 9643985. Comment in: N Engl J Med. 1998 Jun 25;338(26):1921; author reply 1922–3. PMID: 9643983. Comment in: N Engl J Med. Jun 25. 1998;338(26):1921. author reply 1922-. [Rec#: 11476] Exclude at abstract screening: Title Only.
Geddes D M, Dones L, Hill E, Law K, Harper P G, Spiro S G, Tobias J S, Souhami R L. Quality of life during chemotherapy for small cell lung cancer: assessment and use of a daily diary card in a randomized trial. Eur J Cancer. 90;26(4):484-92. [Rec#: 31831] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Geddes D M. Quality of life in lung cancer. Respir Med. 91;85(Suppl B):7-11. discussion 33–7 [Rec#: 31830] Exclude at abstract screening: no outcomes specified. [pmid: 1661907].
Gehlbach B K, Geppert E. The pulmonary manifestations of left heart failure. Chest. 2004;125(2):669-82. [Rec#: 31835] Exclude at abstract screening: no outcomes specified. [pmid: 14769751].
Gehrman P R, Martin J L, Shochat T, Nolan S, Corey-Bloom J, Ancoli-Israel S. Sleep-disordered breathing and agitation in institutionalized adults with Alzheimer disease. Am J Geriatr Psychiatry. 2003;11(4):426-33. [Rec#: 31837] Exclude at abstract screening: not about end of life. [pmid: 12837671].
Geldmacher D S, Provenzano G, McRae T, Mastey V, Ieni J R. Donepezil is associated with delayed nursing home placement in patients with Alzheimer's disease. J Am Geriatr Soc. 2003;51(7):937-44. [Rec#: 31839] Exclude at abstract screening: Other topic only. [pmid: 12834513].
Gelfand D E, Baker L, Cooney G. Developing end-of-life interdisciplinary programs in universitywide settings. Am J Hosp Palliat Care. 2003;20(3):201-4. [Rec#: 11480] Exclude at abstract screening: no outcomes specified. [pmid: 12785041].
Gelfand D E, Balcazar H, Parzuchowski J, Lenox S. Mexicans and care for the terminally ill: family, hospice, and the church. Am J Hosp Palliat Care. 2001;18(6):391-6. [Rec#: 2588] Exclude at abstract screening: useful only for background. [pmid: 11712720].
Gelinas I, Gauthier S, Cyrus P A. Metrifonate enhances the ability of Alzheimer's disease patients to initiate, organize, and execute instrumental and basic activities of daily living. J Geriatr Psychiatry Neurol. 2000;13(1):9-16. [Rec#: 31841] Exclude at abstract screening: Study Design - Unclear. [pmid: 10753002].
Gelling L H. Death: a concept analysis and application to practice. Nurs Crit Care. 96;1(3):137-40. [Rec#: 2589] Exclude at abstract screening: no outcomes specified. [pmid: 9594102].
Gelo F. Conversations with the dying: tone and texture. Am J Hosp Palliat Care. 2002;19(6):415-6. [Rec#: 11483] Exclude at abstract screening: Title Only. [pmid: 12442978].
Gelo F. Risks of infection to the bereaved. J Pastoral Care. 97;51(4):427-34. [Rec#: 11484] Exclude at abstract screening: Study Design - Unclear. [pmid: 10178811].
Gender disparities in clinical decision making. Council on Ethical and Judicial Affairs, American Medical Association. JAMA 91;266(4):559–62. Comment in: JAMA. 1991 Dec 4;266(21):2984; author reply 2984–5. PMID: 1843802. [Rec#: 31842] Exclude at abstract screening: Title Only
Genovese K. Marketing hospice. Am J Hosp Palliat Care. 95;12(6):30-3. [Rec#: 11485] Exclude at abstract screening: not about end of life. [pmid: 7495637].
Georgaki S, Kalaidopoulou O, Liarmakopoulos I, Mystakidou K. Nurses' attitudes toward truthful communication with patients with cancer. A Greek study. Cancer Nurs. 2002;25(6):436-41. [Rec#: 2590] Exclude at abstract screening: no outcomes specified. [pmid: 12464835].
Georges J J, Grypdonck M, Dierckx de Casterle B. Being a palliative care nurse in an academic hospital: a qualitative study about nurses' perceptions of palliative care nursing. J Clin Nurs. 2002;11(6):785-93. [Rec#: 2593] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12427184].
Georgesen J, Dungan J M. Managing spiritual distress in patients with advanced cancer pain. Cancer Nurs. 96;19(5):376-83. [Rec#: 2594] Exclude at abstract screening: no outcomes specified. [pmid: 8885486].
Georgoff P B. The Rorschach with hospice cancer patients and surviving cancer patients. J Pers Assess. 91;56(2):218-26. [Rec#: 2595] Exclude at abstract screening: Study Design - Unclear. [pmid: 2056417].
Gerard L, Flandre P, Raguin G, Le Gall J R, Vilde J L, Leport C. Life expectancy in hospitalized patients with AIDS: prognostic factors on admission. J Palliat Care. 96;12(1):26-30. [Rec#: 2598] Exclude at abstract screening: primarily prognosis or trajectories.
Gerber L A. Transformations in self-understanding in surgeons whose treatment efforts were not successful. Am J Psychother. 90;44(1):75-84. [Rec#: 2599] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Gerber L H. Cancer rehabilitation into the future. Cancer. 2001;92(4 Suppl):975-9. [Rec#: 2600] Exclude at abstract screening: not about end of life. [pmid: 11519023].
Gerety MB, Cornell JE, Mulrow CD, Tuley M, Hazuda HP, Lichtenstein M, Kanten DN, Aguilar C, Kadri AA, and Rosenberg J. The Sickness Impact Profile for nursing homes (SIP-NH). J Gerontol 94;49(1):M2–8. Erratum in: J Gerontol 1994 Mar;49(2):M43. [Rec#: 41190] Exclude at abstract screening: not about end of life
Germino B B. When a chronic illness becomes terminal. ANNA J. 98;25(6):579-82. [Rec#: 11499] Exclude at abstract screening: no outcomes specified. [pmid: 10188390].
Geron S M, Smith K, Tennstedt S, Jette A, Chassler D, Kasten L. The home care satisfaction measure: a client-centered approach to assessing the satisfaction of frail older adults with home care services. J Gerontol B Psychol Sci Soc Sci. 2000;55(5):S259-70. [Rec#: 41192] Exclude at abstract screening: not about end of life. [pmid: 10985297].
Gerra G, Monti D, Panerai A E, Sacerdote P, Anderlini R, Avanzini P, Zaimovic A, Brambilla F, Franceschi C. Long-term immune-endocrine effects of bereavement: relationships with anxiety levels and mood. Psychiatry Res. 2003;121(2):145-58. [Rec#: 2604] Exclude at abstract screening: Observational study. [pmid: 14656449].
Gessert C E, Forbes S, Bern-Klug M. Planning end-of-life care for patients with dementia: roles of families and health professionals. Omega (Westport). 2000;42(4):273-91. [Rec#: 11502] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12569923].
Getsios D, Caro J J, Caro G, Ishak K. AHEAD Study Group. Assessment of health economics in Alzheimer's disease (AHEAD): galantamine treatment in Canada. Neurology 2001;57(6):972–8. Comment in: Neurology. Sep 25. 2001;57(6):943-4. PMID: 11571313. [Rec#: 31861] Exclude at abstract screening: not about end of life.
Ghali J K. Race, ethnicity, and heart failure. J Card Fail 2002;8(6):387–9. Comment on: J Card Fail. Dec. 2002;8(6):381-6. PMID: 12528090. [Rec#: 50033] Exclude at abstract screening: Title Only.
Ghigo E, Nicolosi M, Arvat E, Marcone A, Danelon F, Mucci M, Franceschi M, Smirne S, Camanni F. Growth hormone secretion in Alzheimer's disease: studies with growth hormone-releasing hormone alone and combined with pyridostigmine or arginine. Dementia. 93;4(6):315-20. [Rec#: 31868] Exclude at abstract screening: not about end of life.
Ghooi R B, Ghooi S R. Freedom from pain--a mirage or a possibility? experience in attempts to change laws and practices in India. J Pain Palliat Care Pharmacother. 2003;17(34):1-9. discussion 11–2. [Rec#: 2615] Exclude at abstract screening: no outcomes specified. [pmid: 15022947].
Ghusn H F, Teasdale T A, Skelly J R. Limiting treatment in nursing homes: knowledge and attitudes of nursing home medical directors. J Am Geriatr Soc. 95;43(10):1131-4. [Rec#: 2617] Exclude at abstract screening: no outcomes specified.
Giannini A, Pessina A, Tacchi E M. End-of-life decisions in intensive care units: attitudes of physicians in an Italian urban setting. Intensive Care Med. 2003;29(11):1902-10. [Rec#: 2622] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 13680120].
Giasson M, Bouchard L. Effect of therapeutic touch on the well-being of persons with terminal cancer. J Holist Nurs. 98;16(3):383-98. [Rec#: 2623] Exclude at abstract screening: Observational study. [pmid: 9849260].
Gibbons L, Coleridge-Smith E, Winstanley F, Dhillon G. Nurses' roles in palliative care. Community Nurse. 96;2(10):18-9. [Rec#: 11506] Exclude at abstract screening: no outcomes specified. [pmid: 9450458].
Gibbons M B. Listening to the lived experience of loss. Pediatr Nurs. 93;19(6):597-9. [Rec#: 2625] Exclude at abstract screening: no outcomes specified. [pmid: 8278234].
Gibbs G. Nurses in private nursing homes: a study of their knowledge and attitudes to pain management in palliative care. Palliat Med. 95;9(3):245-53. [Rec#: 2626] Exclude at abstract screening: no outcomes specified.
Gibbs L M, Ellershaw J E, Williams M D. Caring for patients with HIV disease: the experience of a generic hospice. AIDS Care. 97;9(5):601-7. [Rec#: 2627] Exclude at abstract screening: Observational study.
Giblin M J. Beyond principles: virtue ethics in hospice and palliative care. Am J Hosp Palliat Care. 2002;19(4):235-9. [Rec#: 11509] Exclude at abstract screening: no outcomes specified. [pmid: 12141787].
Gibson J, Grealish L. Relating palliative care principles to the promotion of undisturbed sleep in a hospice setting. Int J Palliat Nurs. 2001;7(3):140-5. [Rec#: 11512] Exclude at abstract screening: no outcomes specified. [pmid: 12192330].
Gibson J M. Death by definition and process. HEC Forum. 96;8(6):340-5. [Rec#: 11513] Exclude at abstract screening: Title Only. [pmid: 10165163].
Gibson M C, Schroder C. The many faces of pain for older, dying adults. Am J Hosp Palliat Care 2001;18(1):19–25. Comment in: Am J Hosp Palliat Care. Jan-Feb. 2001;18(1):5-6. PMID: 11406879. [Rec#: 2629] Exclude at abstract screening: useful only for background.
Gibson R. Palliative care for the poor and disenfranchised: a view from the Robert Wood Johnson Foundation. J R Soc Med. 2001;94(9):486-9. [Rec#: 2630] Exclude at abstract screening: no outcomes specified. [pmid: 11535759]. [pmcid: 1282196].
Gifford B J, Cleary B B. Supporting the bereaved. Am J Nurs. 90;90(2):48-53. [Rec#: 11515] Exclude at abstract screening: Title Only. [pmid: 2305824].
Gifford D R, Holloway R G, Frankel M R, Albright C L, Meyerson R, Griggs R C, Vickrey B G. Improving adherence to dementia guidelines through education and opinion leaders. A randomized, controlled trial. Ann Intern Med. 99;131(4):237-46. [Rec#: 31890] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Gift A G. Clinical measurement of dyspnea. Dimensions of Critical Care Nursing. 89;8:210-216. [Rec#: 50450] Exclude at abstract screening: Title Only. [pmid: 2776607].
Gilbar O, Steiner M. When death comes: where should patients die?. Hosp J. 96;11(1):31-48. [Rec#: 2636] Notes: “EXCLUDE: Location, non-Western”. [pmid: 8920310].
Gilbar O. Length of cancer patients' stay at a hospice: does it affect psychological adjustment to the loss of the spouse?. J Palliat Care. 98;14(4):16-20. [Rec#: 2635] Exclude at abstract screening: Study Design - Unclear.
Gilbar P, Stefaniuk K. The role of the pharmacist in palliative care: results of a survey conducted in Australia and Canada. J Palliat Care. 2002;18(4):287-92. [Rec#: 11517] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12611320].
Gilberg K, Laouri M, Wade S, Isonaka S. Analysis of medication use patterns:apparent overuse of antibiotics and underuse of prescription drugs for asthma, depression, and CHF. J Manag Care Pharm 2003;9(3):232–7. Comment in: J Manag Care Pharm. May-Jun. 2003;9(3):274-5. PMID: 14613472. [Rec#: 31893] Exclude at abstract screening: not about end of life.
Gilbert R, Willan A R, Richardson S, Sellick S. Survey of family physicians: what is their role in cancer patient care?. Can J Oncol. 94;4(3):285-90. [Rec#: 2639] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Giles T. The cost-effective way forward for the management of the patient with heart failure. Cardiology. 96;87(Suppl 1):33-9. [Rec#: 31895] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Gilewski M J, Farberow N L, Gallagher D E, Thompson L W. Interaction of depression and bereavement on mental health in the elderly. Psychol Aging. 91;6(1):67-75. [Rec#: 2640] Exclude at abstract screening: not about end of life.
Gilhooly M L, Murray K, Berkeley J S. Public knowledge of hospices: a street survey in Glasgow. Health Bull (Edinb). 91;49(2):165-70. [Rec#: 2641] Exclude at abstract screening: not about end of life. [pmid: 1917451].
Gillan J. The right to know: the nurse's role in informing patients. Nurs Times. 94;90(35):46-7. [Rec#: 2645] Exclude at abstract screening: no outcomes specified. [pmid: 7937190].
Gilley D W, Wilson R S, Beckett L A, Evans D A. Psychotic symptoms and physically aggressive behavior in Alzheimer's disease. J Am Geriatr Soc. 97;45(9):1074-9. [Rec#: 31899] Exclude at abstract screening: not about end of life.
Gillick M R, Mendes M L. Medical care in old age: what do nurses in long-term care consider appropriate?. J Am Geriatr Soc. 96;44(11):1322-5. [Rec#: 2648] Exclude at abstract screening: no outcomes specified.
Gillick MR, Hesse K, and Mazzapica N. Medical technology at the end of life. What would physicians and nurses want for themselves? Arch Intern Med 93;153(22):2542–7. Erratum in: Arch Intern Med 1994 Feb 28;154(4):468. [Rec#: 2647] Exclude at abstract screening: no outcomes specified
Gillick M R. A broader role for advance medical planning. Annals of Internal Medicine. 95;123(8):621-624. [Rec#: 50453] In abstract review process. [pmid: 7677304].
Gillick M R. Advance care planning. New England Journal of Medicine. 2004;350(1):7-8. [Rec#: 50451] Exclude at abstract screening: Title Only. [pmid: 14702421].
Gillick M R, Fried T. The limits of proxy decision making: undertreatment. Cambridge Quarterly of Healthcare Ethics. 95;4(2):172-7. [Rec#: 50456] Exclude at abstract screening: Title Only. [pmid: 7655668].
Gillick M R. Artificial nutrition and hydration in the patient with advanced dementia: is withholding treatment compatible with traditional Judaism?. Journal of Medical Ethics. 2001;27(1):12-15. [Rec#: 50452] Exclude at abstract screening: useful only for background. [pmid: 11233370].
Gillick M R. Limiting medical care: physicians' beliefs, physicians' behavior. Journal of the American Geriatrics Society. 88;36(8):747-752. [Rec#: 50454] Exclude at abstract screening: Title Only. [pmid: 2457044].
Gillick M R. Rethinking the role of tube feeding in patients with advanced dementia. New England Journal of Medicine. 2000;342(3):206-210. [Rec#: 50455] Exclude at abstract screening: Title Only. [pmid: 10639550].
Gillick M R, Serrell N A, Gillick L S. Adverse consequences of hospitalization in the elderly. Social Science & Medicine. 82;16(10):1033-8. [Rec#: 50457] Exclude at abstract screening: not about end of life.
Gillies B. Current awareness in geriatric psychiatry. Int J Geriatr Psychiatry. 2001;16(1):115-22. [Rec#: 31901] Exclude at abstract screening: no outcomes specified. [pmid: 11180496].
Gilligan T, Raffin T A. Withdrawing life support: extubation and prolonged terminal weans are inappropriate. Crit Care Med 96;24(2):352–3. Comment in: Crit Care Med. 1996 Sep;24(9):1607–8. PMID:8797640. Comment in: Crit Care Med. Sep. 1996;24(9):1607. author reply 1608. PMID: 8797639. [Rec#: 11530] Exclude at abstract screening: Title Only.
Gilliland G, Fleming S. A comparison of spousal anticipatory grief and conventional grief. Death Stud. 98;22(6):541-69. [Rec#: 2649] Exclude at abstract screening: Study Design - Unclear. [pmid: 10342940].
Gillis T A, Cheville A L, Worsowicz G M. Cardiopulmonary rehabilitation and cancer rehabilitation. 4. Oncologic rehabilitation. Arch Phys Med Rehabil. 2001;82(3 Suppl 1):S63-8. [Rec#: 2650] Exclude at abstract screening: not about end of life. [pmid: 11239338].
Gilson A M, Joranson D E. Controlled substances and pain management: changes in knowledge and attitudes of state medical regulators. J Pain Symptom Manage. 2001;21(3):227-37. [Rec#: 2655] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11239742].
Gilson A M, Joranson D E. U.S. policies relevant to the prescribing of opioid analgesics for the treatment of pain in patients with addictive disease. Clin J Pain. 2002;18(4 Suppl):S91-8. [Rec#: 11533] Exclude at abstract screening: useful only for background. [pmid: 12479259].
Ginn D and Zitner D. Cardiopulmonary resuscitation. Not for all terminally ill patients. Can Fam Physician 95;41:649–52, 655–7. [Rec#: 11534] Exclude at abstract screening: no outcomes specified
Ginsburg M. Medical futility and end-of-life care: an inter-organizational approach. HEC Forum. 99;11(2):176-91. [Rec#: 11535] Exclude at abstract screening: no outcomes specified. [pmid: 11184854].
Gioiella M E, Berkman B, Robinson M. Spirituality and quality of life in gynecologic oncology patients. Cancer Pract. 98;6(6):333-8. [Rec#: 41213] Exclude at abstract screening: not about end of life. [pmid: 9824424].
Giordano M. The respiratory therapist and palliative care. Respir Care. 2000;45(12):1468-74. discussion 1475–7. [Rec#: 11536] Exclude at abstract screening: Title Only. [pmid: 11107213].
Giordano M. The respiratory therapist and palliative care. Respiratory Care. 2000;45(12):1468-74. discussion 1475–7. [Rec#: 50458] Exclude at abstract screening: Title Only. [pmid: 11107213].
Girling D M, Barkley C, Paykel E S, Gehlhaar E, Brayne C, Gill C, Mathewson D, Huppert F A. The prevalence of depression in a cohort of the very elderly. J Affect Disord. 95;34(4):319-29. [Rec#: 31914] Exclude at abstract screening: not about end of life.
Giron M S, Forsell Y, Bernsten C, Thorslund M, Winblad B, Fastbom J. Psychotropic drug use in elderly people with and without dementia. Int J Geriatr Psychiatry. 2001;16(9):900-6. [Rec#: 31915] Exclude at abstract screening: not about end of life. [pmid: 11571771].
Giron M S, Wang H X, Bernsten C, Thorslund M, Winblad B, Fastbom J. The appropriateness of drug use in an older nondemented and demented population. J Am Geriatr Soc 2001;49(3):277–83. Comment in: J Am Geriatr Soc. Mar. 2002;50(3):590. author reply 590–1. PMID: 11943065. [Rec#: 31916] Exclude at abstract screening: not about end of life.
Gitlin M C. Pain medicine: a contemporary perspective on environmental analysis and strategic planning. Pain Med. 2003;4(3):213-4. [Rec#: 11538] Exclude at abstract screening: not about end of life. [pmid: 12974819].
Gitlin L N, Winter L, Corcoran M, Dennis M P, Schinfeld S, Hauck W W. Effects of the home environmental skill-building program on the caregiver-care recipient dyad: 6-month outcomes from the Philadelphia REACH Initiative. Gerontologist. 2003;43(4):532-46. [Rec#: 50918] In abstract review process. [pmid: 12937332].
Given J E, Range L M. Life satisfaction and death anxiety in elderly nursing home and public housing residents. J Appl Gerontol. 90;9(2):224-9. [Rec#: 2661] Exclude at abstract screening: Study Design - Qualitative.
Given B, Simmons S. The interdisciplinary health-care team: fact or fiction?. Nursing Forum. 77;16(2):165-84. [Rec#: 50459] Exclude at abstract screening: Title Only. [pmid: 244357].
Given C W, Given B, Azzouz F, Kozachik S, Stommel M. Predictors of pain and fatigue in the year following diagnosis among elderly cancer patients. Journal of Pain & Symptom Management. 2001;21(6):456-66. [Rec#: 50460] Exclude at abstract screening: not about end of life. [pmid: 11397603].
Gjerdingen D K, Neff J A, Wang M, Chaloner K. Older persons' opinions about life-sustaining procedures in the face of dementia. Arch Fam Med. 99;8(5):421-5. [Rec#: 2662] Exclude at abstract screening: Study Design - Qualitative.
Glajchen M, Bookbinder M. Knowledge and perceived competence of home care nurses in pain management: a national survey. J Pain Symptom Manage. 2001;21(4):307-16. [Rec#: 11542] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11312045].
Glare P, Virik K. Independent prospective validation of the PaP score in terminally ill patients referred to a hospital-based palliative medicine consultation service. J Pain Symptom Manage. 2001;22(5):891-8. [Rec#: 2665] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 11728792].
Glare P, Virik K, Jones M, Hudson M, Eychmuller S, Simes J, Christakis N. A systematic review of physicians' survival predictions in terminally ill cancer patients. BMJ 2003;327(7408):195. Comment in: BMJ. Nov 1. 2003;327(7422):1048-9. PMID: 14593055. [Rec#: 11544] Exclude at abstract screening: primarily prognosis or trajectories.
Glare P A, Virik K. Can we do better in end-of-life care? The mixed management model and palliative care. Med J Aust 2001;175(10):530–3. Comment in: Med J Aust. Nov 19. 2001;175(10):534-6. PMID: 11795543. [Rec#: 2669] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Glare P A, Auret K A, Aggarwal G, Clark K J, Pickstock S E, Lickiss J N. The interface between palliative medicine and specialists in acute-care hospitals: boundaries, bridges and challenges. Med J Aust. 2003;179(6 Suppl):S29-31. [Rec#: 11545] Exclude at abstract screening: no outcomes specified. [pmid: 12964933].
Glare P A. Palliative care in acquired immunodeficiency syndrome (AIDS): problems and practicalities. Ann Acad Med Singapore. 94;23(2):235-43. [Rec#: 2667] Exclude at abstract screening: useful only for background.
Glass B C. The role of the nurse in advanced practice in bereavement care. Clin Nurse Spec. 93;7(2):62-6. [Rec#: 11547] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 8364832].
Glass E. Different approaches to transfusion practices used in hospice care. Oncol Nurs Forum. 96;23(1):117-8. [Rec#: 2670] Exclude at abstract screening: Title Only. [pmid: 8628703].
Glass N, Taylor B, Stirling K, McFarlane J. Making a difference with dying people: positive nurse-patient interactions. Contemp Nurse. 99;8(4):159-65. [Rec#: 11549] Exclude at abstract screening: no outcomes specified.
Gleeson C, Spencer D. Blood transfusion and its benefits in palliative care. Palliat Med 95;9(4):307–13. Comment in: Palliat Med. Apr. 1996;10(2):166. PMID: 8800826. [Rec#: 2674] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Glick K L, Mackay K M, Balasingam S, Dolan K R, Casper-Isaac S. Advance directives: barriers to completion. J N Y State Nurses Assoc. 98;29(1):4-8. [Rec#: 11552] Exclude at abstract screening: non-systematic review. [pmid: 9923243].
Glickman L, Hubbard M, Liveright T, Valciukas J A. Fall-off in reporting life events: effects of life change, desirability, and anticipation. Behav Med. 90;16(1):31-8. [Rec#: 31931] Exclude at abstract screening: not about end of life.
Glimelius B, Birgegard G, Hoffman K, Hagnebo C, Hogman G, Kvale G, Nordin K, Nou E, Persson C, Sjoden P. Improved care of patients with small cell lung cancer. Nutritional and quality of life aspects. Acta Oncol. 92;31(8):823-31. [Rec#: 31932] Exclude at abstract screening: not about end of life.
Glimelius B, Hoffman K, Sjoden P O, Jacobsson G, Sellstrom H, Enander L K, Linne T, Svensson C. Chemotherapy improves survival and quality of life in advanced pancreatic and biliary cancer. Ann Oncol. 96;7(6):593-600. [Rec#: 2681] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Glimelius B. Palliative treatment of patients with colorectal cancer. Scand J Surg. 2003;92(1):74-83. [Rec#: 11554] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 12705554].
Glimelius B. Pancreatic and hepatobiliary cancers: adjuvant therapy and management of inoperable disease. Ann Oncol. 2000;11(Suppl 3):153-9. [Rec#: 11555] Exclude at abstract screening: Title Only. [pmid: 11079133].
Gloth F M 3rd, Schwartz J. Developing a physicians' palliative care pain hotline in Maryland. Am J Hosp Palliat Care. 2000;17(1):24-8. [Rec#: 11557] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11094917].
Gloth F M 3rd, Scheve A A, Shah S, Ashton R, McKinney R. The Frail Elderly Functional Assessment questionnaire: its responsiveness and validity in alternative settings. Arch Phys Med Rehabil. 99;80(12):1572-6. [Rec#: 41230] Exclude at abstract screening: not about end of life.
Gloth F M 3rd. Hospice: the most important thing you didn't learn in medical school. Md Med J. 94;43(6):511-3. [Rec#: 11556] Exclude at abstract screening: no outcomes specified. [pmid: 8072395].
Gluhoski V L, Fishman B, Perry S W. The impact of multiple bereavement in a gay male sample. AIDS Educ Prev. 97;9(6):521-31. [Rec#: 11559] Exclude at abstract screening: not about end of life. [pmid: 9451480].
Go A S, Rao R K, Dauterman K W, Massie B M. A systematic review of the effects of physician specialty on the treatment of coronary disease and heart failure in the United States. Am J Med 2000;108(3):216–26. Comment in: Am J Med. Feb 15. 2000;108(3):259-61. PMID: 10723984. [Rec#: 31936] Exclude at abstract screening: not about end of life.
Goddard M, Maher E J, Hutton J, Shah D. Palliative radiotherapy--counting the costs of changing practice. Health Policy. 91;17(3):243-56. [Rec#: 11561] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Godden D R, Ribeiro N F, Hassanein K, Langton S G. Recurrent neck disease in oral cancer. J Oral Maxillofac Surg. 2002;60(7):748-53. discussion753–5. [Rec#: 2688] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 12089686].
Goebeler S, Jylha M, Hervonen A. Medical history, cognitive status and mobility at the age of 90. A population-based study in Tampere Finland. Aging Clin Exp Res. 2003;15(2):154-61. [Rec#: 31938] Exclude at abstract screening: not about end of life. [pmid: 12889848].
Goetschius S K. Families and end-of-life care. How do we meet their needs?. J Gerontol Nurs. 97;23(3):43-9. [Rec#: 11564] Exclude at abstract screening: Title Only. [pmid: 9111421].
Goetzke E. When your patient is in denial. Am J Nurs. 95;95(9):18-21. [Rec#: 2694] Exclude at abstract screening: Title Only. [pmid: 7573214].
Goggin K, Sewell M, Ferrando S, Evans S, Fishman B, Rabkin J. Plans to hasten death among gay men with HIV/AIDS: relationship to psychological adjustment. AIDS Care. 2000;12(2):125-36. [Rec#: 41236] Exclude at abstract screening: not about end of life. [pmid: 10827853].
Goh L G. The do-not-resuscitate order. Singapore Med J 95;36(3):258–9. Comment on: Singapore Med J. Jun. 1995;36(3):267-70. PMID: 8553088. [Rec#: 11568] Exclude at abstract screening: Title Only.
Gold MF. Comfort, compassion, dignity mark end-of-life care. Provider 2003;29(12):20–2, 25–9, 33. [Rec#: 11571] Exclude at abstract screening: Title Only
Goldberg G and Boustead R. Compassion. JEMS 98;23(2):34–5, 37–40. [Rec#: 11574] Exclude at abstract screening: Title Only
Goldberg R J. Management of behavioral complications of dementia. Med Health R I. 2002;85(9):281-5. [Rec#: 31949] Exclude at abstract screening: not about end of life. [pmid: 12371213].
Goldberg S S. Care that soothes patients and families. Provider. 2002;28(5):51-3. [Rec#: 11576] Exclude at abstract screening: Title Only. [pmid: 12017100].
Goldberg R, Guadagnoli E, Silliman R A, Glicksman A. Cancer patients' concerns: congruence between patients and primary care physicians. Journal of Cancer Education. 90;5(3):193-9. [Rec#: 50462] Exclude at abstract screening: not about end of life.
Goldblatt A D. Don't ask, don't tell: practicing minimally invasive resuscitation techniques on the newly dead. Ann Emerg Med 95;25(1):86–90. Comment on: Ann Emerg Med. 1995 Jan;25(1):91–4. PMID: 7802378. Comment in: Ann Emerg Med. 1995 Aug;26(2):242. PMID: 7677900. Comment in: Ann Emerg Med. 1995 Jan;25(1):99–100. PMID: 7802381. Comment in: Ann Emerg Med. Jul. 1995;26(1):106-7. PMID: 779. [Rec#: 11577] Exclude at abstract screening: Title Only.
Goldblum P B, Erickson S. Understanding AIDS bereavement. Focus. 2000;15(3):1-6. [Rec#: 11578] Exclude at abstract screening: Title Only. [pmid: 12180380].
Goldstein C, Anapolsky E, Park J, Immordino M, Ukoha N. Research guiding practice related to cultural issues at end of life care. Geriatr Nurs. 2004;25(1):58-9. [Rec#: 2711] Exclude at abstract screening: Title Only. [pmid: 14976511].
Goldstein J, Alter C L, Axelrod R. A psychoeducational bereavement-support group for families provided in an outpatient cancer center. J Cancer Educ. 96;11(4):233-7. [Rec#: 2712] Exclude at abstract screening: Bereavement only.
Goldstone A R, Callaghan C J, Mackay J, Charman S, Nashef S A. Should surgeons take a break after an intraoperative death? Attitude survey and outcome evaluation. BMJ 2004;328(7436):379. Comment in: BMJ. Feb 14. 2004;328(7436):361-2. PMID: 14962853. [Rec#: 11581] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Goldstone I. Palliative care for HIV disease: the desirable vs the possible. J Palliat Care. 95;11(2):54-7. [Rec#: 11582] Exclude at abstract screening: no outcomes specified. [pmid: 7541080].
Goldstone I L. Trends in hospital utilization in AIDS care 1987-1991: implications for palliative care. J Palliat Care. 92;8(4):22-9. [Rec#: 2715] Exclude at abstract screening: no outcomes specified.
Goldstone I. Palliative care for HIV disease: the desirable vs the possible. Journal of Palliative Care. 95;11(2):54-7. [Rec#: 50463] Exclude at abstract screening: no outcomes specified. [pmid: 7541080].
Gollins S W, Burt P A, Barber P V, Stout R. Long-term survival and symptom palliation in small primary bronchial carcinomas following treatment with intraluminal radiotherapy alone. Clin Oncol (R Coll Radiol). 96;8(4):239-46. [Rec#: 2718] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Gomez Y. The use of syringe drivers in palliative care. Aust Nurs J. 2000;8(2):suppl 1-3. [Rec#: 11586] Exclude at abstract screening: Title Only. [pmid: 11894458].
Gomez-Batiste X, Fontanals M D, Roca J, Borras J M, Viladiu P, Stjernsward J, Rius E. Catalonia WHO Demonstration Project on Palliative Care Implementation 1990-1995: results in 1995. J Pain Symptom Manage. 96;12(2):73-8. [Rec#: 11584] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Gomez-Batiste X, Madrid F, Moreno F, Gracia A, Trelis J, Nabal M, Alcalde R, Planas J, Camell H. Breakthrough cancer pain: prevalence and characteristics in patients in Catalonia Spain. J Pain Symptom Manage. 2002;24(1):45-52. [Rec#: 2719] Exclude at abstract screening: not about end of life. [pmid: 12183094].
Goncalves J A. A Portuguese palliative care unit. Support Care Cancer. 2001;9(1):4-7. [Rec#: 11587] Exclude at abstract screening: no outcomes specified. [pmid: 11147141].
Gonzalez J. Discontinued percutaneous nephrostomy tubes: how to keep patients dry. Urol Nurs. 94;14(4):169. [Rec#: 11589] Exclude at abstract screening: Title Only. [pmid: 7817211].
Good P, Stafford B. Inpatient palliative medicine is evidence based. Palliat Med. 2001;15(6):493-8. [Rec#: 11591] Exclude at abstract screening: useful only for background. [pmid: 12403507].
Good P D, Cavenagh J, Ravenscroft P J. Survival after enrollment in an Australian palliative care program. J Pain Symptom Manage. 2004;27(4):310-5. [Rec#: 2721] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 15050658].
Good P D. Advances in palliative care relevant to the wider delivery of healthcare. Med J Aust. 2003;179(6 Suppl):S44-6. [Rec#: 11592] Exclude at abstract screening: useful only for background. [pmid: 12964938].
Goodlin S J, Fisher E, Patterson J A, Wasson J H. End-of-life care for persons age 80 years or older. J Ambul Care Manage. 98;21(3):34-9. [Rec#: 2727] Exclude at abstract screening: no outcomes specified. [pmid: 10181845].
Goodlin S J, Jette A M, Lynn J, Wasson J H. Community physicians describe management issues for patients expected to live less than twelve months. J Palliat Care. 98;14(1):30-5. [Rec#: 2728] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Goodlin S J. Hospice organizations' role in health care improvement. Hosp J. 97;12(2):71-80. [Rec#: 11594] Exclude at abstract screening: no outcomes specified. [pmid: 9248400].
Goodman C, Knight D, Machen I, Hunt B. Emphasizing terminal care as district nursing work: a helpful strategy in a purchasing environment?. J Adv Nurs. 98;28(3):491-8. [Rec#: 11595] Exclude at abstract screening: no outcomes specified.
Goodman C, Woolley R, Knight D. District nurse involvement in providing palliative care to older people in residential care homes. Int J Palliat Nurs. 2003;9(12):521-7. [Rec#: 2731] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14765008].
Goodman K W. End-of-life algorithms. Psychol Public Policy Law. 98;4(3):719-27. [Rec#: 11596] Exclude at abstract screening: no outcomes specified. [pmid: 12803230].
Goodman, M. L. and Wilkinson, S. Laxatives for the management of constipation in palliative care patients. Cochrane Database of Systematic Reviews 2003;3. [Rec#: 50464] Exclude at abstract screening: Title Only
Goodridge D, Marr H. Factors associated with falls in an inpatient palliative care unit: an exploratory study. Int J Palliat Nurs. 2002;8(11):548-56. [Rec#: 2734] Exclude at abstract screening: Other topic only. [pmid: 12514465].
Goodwin D M, Higginson I J, Edwards A G, Finlay I G, Cook A M, Hood K, Douglas H R, Normand C E. An evaluation of systematic reviews of palliative care services. J Palliat Care. 2002;18(2):77-83. [Rec#: 11598] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 12164104].
Goodwin Z, Kiehl E M, Peterson J Z. King's theory as foundation for an advance directive decision-making model. Nurs Sci Q. 2002;15(3):237-41. [Rec#: 11601] Exclude at abstract screening: no outcomes specified. [pmid: 12125535].
Goold S D, Arnold R M, Siminoff L A. Discussions about limiting treatment in a geriatric clinic. J Am Geriatr Soc. 93;41(3):277-81. [Rec#: 2737] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Gopalkrishnan S. Management of physical symptoms in terminal illness. Nurs J India. 2002;93(11):249-51. [Rec#: 11604] Exclude at abstract screening: no outcomes specified. [pmid: 12718112].
Gordin V, Weaver M A, Hahn M B. Acute and chronic pain management in palliative care. Best Pract Res Clin Obstet Gynaecol. 2001;15(2):203-34. [Rec#: 11605] Exclude at abstract screening: no outcomes specified. [pmid: 11358398].
Gordon A. Hospice marketing and outreach to the orthodox Jewish community revisited. Am J Hosp Palliat Care. 2002;19(1):57-8. discussion 58. [Rec#: 11606] Exclude at abstract screening: Title Only. [pmid: 12171426].
Gordon A K. Deterrents to access and service for blacks and Hispanics: the Medicare Hospice Benefit, healthcare utilization, and cultural barriers. Hosp J. 95;10(2):65-83. [Rec#: 11609] In abstract review process.
Gordon AK. Hospice and minorities: a national study of organizational access and practice. Hosp J 96;11(1):49–70. Erratum in: Hosp J 1996;11(4):97. [Rec#: 11610] Exclude at abstract screening: useful only for background
Gordon D B. Critical pathways: a road to institutionalizing pain management. J Pain Symptom Manage. 96;11(4):252-9. [Rec#: 11614] Exclude at abstract screening: no outcomes specified. [pmid: 8869460].
Gordon E J, Daugherty C K. ‘Hitting you over the head’: oncologists' disclosure of prognosis to advanced cancer patients. Bioethics. 2003;17(2):142-68. [Rec#: 11616] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12812182].
Gorell J M, Johnson C C, Rybicki B A. Parkinson's disease and its comorbid disorders: an analysis of Michigan mortality data, 1970 to 1990. Neurology. 94;44(10):1865-8. [Rec#: 2747] Exclude at abstract screening: primarily prognosis or trajectories.
Gorkin L, Norvell N K, Rosen R C, Charles E, Shumaker S A, McIntyre K M, Capone R J, Kostis J, Niaura R, Woods P, et al. Assessment of quality of life as observed from the baseline data of the Studies of Left Ventricular Dysfunction (SOLVD) trial quality-of-life substudy. Am J Cardiol. 93;71(12):1069-73. [Rec#: 31986] Exclude at abstract screening: not about end of life.
Gornick M, McMillan A, Lubitz J. A longitudinal perspective on patterns of Medicare payments. Health Aff (Millwood). 93;12(2):140-50. [Rec#: 2748] Exclude at abstract screening: useful only for background.
Gorski L A, Johnson K. A disease management program for heart failure: collaboration between a home care agency and a care management organization. Home Healthc Nurse. 2003;21(11):734-44. [Rec#: 31990] Exclude at abstract screening: Title Only. [pmid: 14614384].
Gotlieb W H, Feldman B, Feldman-Moran O, Zmira N, Kreizer D, Segal Y, Elran E, Ben-Baruch G. Intraperitoneal pressures and clinical parameters of total paracentesis for palliation of symptomatic ascites in ovarian cancer. Gynecol Oncol. 98;71(3):381-5. [Rec#: 11628] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Gott M C, Ahmedzai S H, Wood C. How many inpatients at an acute hospital have palliative care needs? Comparing the perspectives of medical and nursing staff. Palliat Med. 2001;15(6):451-60. [Rec#: 2752] Exclude at abstract screening: useful only for background. [pmid: 12403502].
Gottschalk L A, Fronczek J, Buchsbaum M S. The cerebral neurobiology of hope and hopelessness. Psychiatry. 93;56(3):270-81. [Rec#: 11630] Exclude at abstract screening: not about end of life. [pmid: 8416007].
Goudas L, Carr D B, Bloch R, Balk E, Ioannidis J P A, Terrin N, Gialeli-Goudas M, Chew P, and Lau J. Management of cancer pain. Evid Rep Technol Assess (Summ) 2001;(35):1–5. [Rec#: 13371] Exclude at abstract screening: no outcomes specified
Goudas L, Carr D B, Bloch R, Balk E, Ioannidis J P A, Terrin N, Gialeli-Goudas M, Chew P, Lau J. Management of Cancer Pain (Vol 2). 2001;<25 Page(s)>. [Rec#: 50845] Exclude at abstract screening: Non-systematic review
Goudas L, Carr D V, Bloch R, Balk E, Ioannidis J P A, Terrin N, Gialeli-Goudas M, Chew P, Lau J. Management of Cancer Pain (Vol 1). 2001;<25 Page(s)>. [Rec#: 50847] Exclude at abstract screening: Non-systematic review
Gough I R, Dalgleish L I. What value is given to quality of life assessment by health professionals considering response to palliative chemotherapy for advanced cancer?. Cancer. 91;68(1):220-5. [Rec#: 2756] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Gower N H, Rudd R M, Ruiz de Elvira M C, Spiro S G, James L E, Harper P G, Souhami R L. Assessment of ‘quality of life’ using a daily diary card in a randomised trial of chemotherapy in small-cell lung cancer. Ann Oncol. 95;6(6):575-80. [Rec#: 32001] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Goy E and Ganzini L. End-of-life care in geriatric psychiatry. Clin Geriatr Med 2003;19(4):841–56, vii–viii. [Rec#: 2759] Exclude at abstract screening: Non-systematic review
Grabbe L, Demi A, Camann M A, Potter L. The health status of elderly persons in the last year of life: a comparison of deaths by suicide, injury, and natural causes. Am J Public Health. 97;87(3):434-7. [Rec#: 41278] Exclude at abstract screening: sudden/violent/non-chronic deaths.
Grabbe L, Demi A S, Whittington F, Jones J M, Branch L G, Lambert R. Functional status and the use of formal home care in the year before death. J Aging Health. 95;7(3):339-64. [Rec#: 41279] Exclude at abstract screening: data older than 1990.
Grabowski C M, Unger J A, Potish R A. Factors predictive of completion of treatment and survival after palliative radiation therapy. Radiology. 92;184(2):329-32. [Rec#: 2761] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Grady K L, Meyer P, Mattea A, Dressler D, Ormaza S, White-Williams C, Chillcott S, Kaan A, Todd B, Loo A, Klemme A L, Piccione W, Costanzo M R. Predictors of quality of life at 1 month after implantation of a left ventricular assist device. Am J Crit Care. 2002;11(4):345-52. [Rec#: 32004] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 12102435].
Grady K L. Quality of life in patients with chronic heart failure. Crit Care Nurs Clin North Am. 93;5(4):661-70. [Rec#: 32003] Exclude at abstract screening: no outcomes specified. [pmid: 8297555].
Grafstrom M, Winblad B. Family burden in the care of the demented and nondemented elderly--a longitudinal study. Alzheimer Dis Assoc Disord. 95;9(2):78-86. [Rec#: 32007] Exclude at abstract screening: Study Design - Unclear.
Graftstrom M, Norberg A, Hagberg B. Relationships between demented elderly people and their families: a follow-up study of caregivers who had previously reported abuse when caring for their spouses and parents. J Adv Nurs. 93;18(11):1747-57. [Rec#: 2769] Exclude at abstract screening: not about end of life.
Graham C, Ballard C, Sham P. Carers' knowledge of dementia, their coping strategies and morbidity. Int J Geriatr Psychiatry. 97;12(9):931-6. [Rec#: 32008] Exclude at abstract screening: not about end of life.
Graham J E, Rockwood K, Beattie B L, Eastwood R, Gauthier S, Tuokko H, McDowell I. Prevalence and severity of cognitive impairment with and without dementia in an elderly population. Lancet. 97;349(9068):1793-6. [Rec#: 32009] Exclude at abstract screening: not about end of life.
Graham M V, Byhardt R W, Sause W T, Curran W J Jr, Fuller D, Ko B, Komaki R, Weisenburger T H, Kaiser L R, Leibel S A. Non-aggressive, non-surgical treatment of inoperable non-small cell lung cancer (NSCLC). American College of Radiology. ACR Appropriateness Criteria. Radiology. 2000;215(Suppl):1347-62. [Rec#: 11644] Exclude at abstract screening: Title Only. [pmid: 11037551].
Graham P, Boyages J. Economic and quality-of-life aspects of treating small cell lung cancer. Pharmacoeconomics. 93;3(6):446-53. [Rec#: 32012] Exclude at abstract screening: Title Only. [pmid: 10146879].
Gramelspacher G P, Zhou X H, Hanna M P, Tierney W M. Preferences of physicians and their patients for end-of-life care. J Gen Intern Med. 97;12(6):346-51. [Rec#: 2772] Exclude at abstract screening: not about end of life.
Gramsky C, Josephson S, Langford M, Offutt C, Wingate S. Outpatient management of chronic heart failure. Crit Care Nurs Clin North Am. 2003;15(4):501-9. [Rec#: 32014] Exclude at abstract screening: no outcomes specified. [pmid: 14717396].
Grande G E, Addington-Hall J M, Todd C J. Place of death and access to home care services: are certain patient groups at a disadvantage?. Soc Sci Med. 98;47(5):565-79. [Rec#: 2775] Exclude at abstract screening: useful only for background.
Grande G E, Barclay S I, Todd C J. Difficulty of symptom control and general practitioners' knowledge of patients' symptoms. Palliat Med. 97;11(5):399-406. [Rec#: 11647] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Grande G E, McKerral A, Addington-Hall J M, Todd C J. Place of death and use of health services in the last year of life. J Palliat Care. 2003;19(4):263-70. [Rec#: 2776] Exclude at abstract screening: Other topic only. [pmid: 14959597].
Granger C E, George C, Shelly M P. The management of bereavement on intensive care units. Intensive Care Med. 95;21(5):429-36. [Rec#: 11653] Exclude at abstract screening: Study Design - Qualitative. [pmid: 7665753].
Granja C, Teixeira-Pinto A, Costa-Pereira A. Attitudes towards do-not-resuscitate decisions: differences among health professionals in a Portuguese hospital. Intensive Care Med. 2001;27(3):555-8. [Rec#: 11654] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11355125].
Grant D. Spiritual interventions: how, when, and why nurses use them. Holist Nurs Pract. 2004;18(1):36-41. [Rec#: 11657] Exclude at abstract screening: useful only for background. [pmid: 14765691].
Grant J B, Hayes R P, Baker D W, Cangialose C B, Kieszak S M, Ballard D J. Informatics, imaging, and healthcare quality management: imaging quality improvement opportunities and lessons learned form HCFA's Health Care Quality Improvement Program. Clin Perform Qual Health Care. 97;5(3):133-9. [Rec#: 32015] Exclude at abstract screening: no outcomes specified.
Grant L A, Potthoff S J, Ryden M, Kane R A. Staff ratios, training, and assignment in Alzheimer's special care units. J Gerontol Nurs. 98;24(1):9-16. quiz 59. [Rec#: 32016] Exclude at abstract screening: Title Only.
Grasel E. Temporary institutional respite in dementia cases: who utilizes this form of respite care and what effect does it have?. Int Psychogeriatr. 97;9(4):437-48. [Rec#: 32020] Exclude at abstract screening: no outcomes specified.
Grauer P A. Appetite stimulants in terminal care: treatment of anorexia. Hosp J. 93;9(23):73-83. [Rec#: 11662] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 7806182].
Gravitz M A. Perceptual reconstruction in the treatment of inordinate grief. Am J Clin Hypn. 2001;44(1):51-5. [Rec#: 2783] Exclude at abstract screening: no outcomes specified. [pmid: 11417147].
Gray J D, Forster D P. Factors associated with utilization of specialist palliative care services: a population based study. J Public Health Med. 97;19(4):464-9. [Rec#: 2786] Exclude at abstract screening: Other topic only. [pmid: 9467155].
Gray R A. The use of massage therapy in palliative care. Complement Ther Nurs Midwifery. 2000;6(2):77-82. [Rec#: 11667] Exclude at abstract screening: Title Only. [pmid: 10844745].
Gray S W, Zide M R, Wilker H. Using the solution focused brief therapy model with bereavement groups in rural communities: resiliency at its best. Hosp J. 2000;15(3):13-30. [Rec#: 11668] Exclude at abstract screening: no outcomes specified. [pmid: 11249380].
Grbich C, Parker D, Maddocks I. The emotions and coping strategies of caregivers of family members with a terminal cancer. J Palliat Care. 2001;17(1):30-6. [Rec#: 2788] Exclude at abstract screening: no outcomes specified. [pmid: 11324182].
Grealish L. Mini-Mental State Questionnaire: problems with its use in palliative care. Int J Palliat Nurs. 2000;6(6):298-302. [Rec#: 2789] Exclude at abstract screening: no outcomes specified. [pmid: 11249451].
Green J, Passman L J, Wintfeld N. Analyzing hospital mortality. The consequences of diversity in patient mix. JAMA. 91;265(14):1849-53. [Rec#: 2794] Exclude at abstract screening: not about end of life. [pmid: 1900894].
Green J S. An investigation into the use of palliative care services by patients with prostate cancer. Am J Hosp Palliat Care. 2002;19(4):259-62. [Rec#: 2795] Exclude at abstract screening: Other topic only. [pmid: 12141790].
Green S B. Does assessment of quality of life in comparative cancer trials make a difference? A discussion. Control Clin Trials 97;18(4):306–10. Comment on: Control Clin Trials. 1997 Aug;18(4):277–85. PMID: 9257066. Comment on: Control Clin Trials. Aug. 1997;18(4):286-300. PMID: 9257067. [Rec#: 32034] Exclude at abstract screening: no outcomes specified.
Greenberg B, McCorkle R, Vlahov D, Selwyn P A. Palliative care for HIV disease in the era of highly active antiretroviral therapy. J Urban Health. 2000;77(2):150-65. [Rec#: 11680] Exclude at abstract screening: useful only for background. [pmid: 10855997].
Greene J A, Ingram T A, Johnson W. Group psychotherapy for patients with dementia. South Med J. 93;86(9):1033-5. [Rec#: 32040] Exclude at abstract screening: not about end of life. [pmid: 8367749].
Greene J A, Taylor S E, Johnson W. Dementia: physician approaches to the caregiver's problems. South Med J. 93;86(9):1036-9. [Rec#: 32041] Exclude at abstract screening: no outcomes specified. [pmid: 8367750].
Greenstein M, Breitbart W. Cancer and the experience of meaning: a group psychotherapy program for people with cancer. Am J Psychother. 2000;54(4):486-500. [Rec#: 11695] Exclude at abstract screening: not about end of life. [pmid: 11109133].
Greenstreet W. The concept of total pain: a focused patient care study. British Journal of Nursing. 2001;10(19):1248-55. [Rec#: 50466] Exclude at abstract screening: no outcomes specified. [pmid: 11832837].
Greenwald B D, Narcessian E J. Opioids for managing patients with chronic pain: community pharmacists' perspectives and concerns. J Pain Symptom Manage. 99;17(5):369-75. [Rec#: 2803] Exclude at abstract screening: no outcomes specified.
Greer S, Moorey S. Adjuvant psychological therapy for cancer patients. Palliat Med. 97;11(3):240-4. [Rec#: 2804] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 9205658].
Gregory D, English J C. The myth of control: suffering in palliative care. J Palliat Care. 94;10(2):18-22. [Rec#: 11697] Exclude at abstract screening: useful only for background. [pmid: 8089813].
Gregory D. Music listening for maintaining attention of older adults with cognitive impairments. J Music Ther. 2002;39(4):244-64. [Rec#: 32046] Exclude at abstract screening: Observational study. [pmid: 12597728].
Greiner K A, Perera S, Ahluwalia J S. Hospice usage by minorities in the last year of life: results from the National Mortality Followback Survey. J Am Geriatr Soc. 2003;51(7):970-8. [Rec#: 2810] Exclude at abstract screening: useful only for background. [pmid: 12834517].
Greiner L, Buhr B, Phelps D, Ward S. Wisconsin Coalition To Improve Palliative Care. A palliative care needs assessment of health care institutions in Wisconsin. J Palliat Med. 2003;6(4):543-56. [Rec#: 11704] Exclude at abstract screening: no outcomes specified. [pmid: 14516496].
Greipp M E. Decisions to utilize hospice--pilot study results. Am J Hosp Palliat Care. 96;13(6):27-30. [Rec#: 2811] Exclude at abstract screening: Study Design - Qualitative. [pmid: 8945100].
Greipp M E. The hospice choice: ethical decision making. Am J Hosp Palliat Care. 96;13(5):28-34. [Rec#: 11705] Exclude at abstract screening: no outcomes specified. [pmid: 8936199].
Grenvik A. “Terminal weaning”: discontinuance of life-support therapy in the terminally ill patient. Critical Care Medicine. 83;11:394-5. [Rec#: 50467] Exclude at abstract screening: Title Only. [pmid: 6839794].
Grey R. The psychospiritual care matrix: a new paradigm for hospice care giving. Am J Hosp Palliat Care. 96;13(4):19-25. [Rec#: 11713] Exclude at abstract screening: no outcomes specified. [pmid: 8850815].
Greyson B. Posttraumatic stress symptoms following near-death experiences. Am J Orthopsychiatry. 2001;71(3):368-73. [Rec#: 2816] Exclude at abstract screening: not about end of life. [pmid: 11495339].
Greyson B. The near-death experience as a focus of clinical attention. J Nerv Ment Dis. 97;185(5):327-34. [Rec#: 2815] Exclude at abstract screening: no outcomes specified. [pmid: 9171810].
Gridelli C, Hainsworth J. Meeting the chemotherapy needs of elderly and poor performance status patients with NSCLC. Lung Cancer. 2002;38(Suppl 4):37-41. [Rec#: 2821] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 12480193].
Gridelli C, De Vivo R, Monfardini S. Management of small-cell lung cancer in the elderly. Crit Rev Oncol Hematol. 2002;41(1):79-88. [Rec#: 2820] Exclude at abstract screening: no outcomes specified. [pmid: 11796233].
Gridelli C, Perrone F, Nelli F, Ramponi S, De Marinis F. Quality of life in lung cancer patients. Ann Oncol. 2001;12(Suppl 3):S21-5. [Rec#: 32059] Exclude at abstract screening: no outcomes specified. [pmid: 11804379].
Gridelli C. Does chemotherapy have a role as palliative therapy for unfit or elderly patients with non-small-cell lung cancer?. Lung Cancer. 2002;38(Suppl 2):S45-50. [Rec#: 2819] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 12431829].
Griffie J, Nelson-Marten P, Muchka S. Acknowledging the ‘elephant’: communication in palliative care. Am J Nurs. 2004;104(1):48-57. quiz 58. [Rec#: 2823] Exclude at abstract screening: Title Only. [pmid: 14707814].
Griffin J P, Nelson J E, Koch K A, Niell H B, Ackerman T F, Thompson M, Cole F H Jr. American College of Chest Physicians. End-of-life care in patients with lung cancer. Chest. 2003;123(1 Suppl):312S-331S. [Rec#: 11717] Exclude at abstract screening: Non-systematic review. [pmid: 12527587].
Griffith C H 3rd, Wilson J F, Rich E C. A randomized trial of providing house staff with patient social history information. Effect on patient outcomes. Eval Health Prof. 98;21(3):362-76. [Rec#: 32065] Exclude at abstract screening: not about end of life.
Griffith C H 3rd, Wilson J F, Rich E C. Intern call structure and patient satisfaction. J Gen Intern Med 97;12(5):308–10. Comment in: J Gen Intern Med. Sep. 1997;12(9):586. PMID: 9294793. [Rec#: 32064] Exclude at abstract screening: not about end of life.
Griffith C H 3rd, Wilson J F, Rich E C. The effect at one teaching hospital of interns' workloads on the satisfaction of their patients. Acad Med. 98;73(4):427-9. [Rec#: 32063] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Grilli R, Minozzi S, Tinazzi A, Labianca R, Sheldon T A, Liberati A. Do specialists do it better? The impact of specialization on the processes and outcomes of care for cancer patients. Ann Oncol. 98;9(4):365-74. [Rec#: 50135] Exclude at abstract screening: not about end of life.
Grimby A. Bereavement among elderly people: grief reactions, post-bereavement hallucinations and quality of life. Acta Psychiatr Scand. 93;87(1):72-80. [Rec#: 2827] Exclude at abstract screening: Bereavement only. [pmid: 8424323].
Grindley A, Acres J. Alternating pressure mattresses: comfort and quality of sleep. Br J Nurs. 96;5(21):1303-10. [Rec#: 2829] Exclude at abstract screening: not about end of life. [pmid: 9015985].
Grocott P. The palliative management of fungating malignant wounds. J Wound Care. 2000;9(1):4-9. [Rec#: 11721] Exclude at abstract screening: Study Design - Unclear. [pmid: 10827661].
Grodin M A. Religious advance directives: the convergence of law, religion, medicine, and public health. Am J Public Health. 93;83(6):899-903. [Rec#: 11723] Exclude at abstract screening: no outcomes specified.
Groen H J, Smit E F, Haaxma-Reiche H, Postmus P E. Carboplatin as second line treatment for recurrent or progressive brain metastases from small cell lung cancer. Eur J Cancer. 93;29A(12):1696-9. [Rec#: 2832] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Groenewoud J H, van der Heide A, Kester J G, de Graaff C L, van der Wal G, van der Maas P J. A nationwide study of decisions to forego life-prolonging treatment in Dutch medical practice. Arch Intern Med. 2000;160(3):357-63. [Rec#: 2833] Exclude at abstract screening: Title Only. [pmid: 10668838].
Groenvold M. Methodological issues in the assessment of health-related quality of life in palliative care trials. Acta Anaesthesiol Scand. 99;43(9):948-53. [Rec#: 11725] Exclude at abstract screening: useful only for background.
Gronda E, Mangiavacchi M, Andreuzzi B, Municino A, Bologna A, Schweiger C, Barbieri P. A population-based study on overt heart failure in Lombardy (survey of hospitalization in 1996 and 1997). Ital Heart J. 2002;3(2):96-103. [Rec#: 50034] Exclude at abstract screening: not about end of life. [pmid: 11926018].
Grossi F, Pennucci M C, Tixi L, Cafferata M A, Ardizzoni A. Management of malignant pleural effusions. Drugs. 98;55(1):47-58. [Rec#: 11732] Exclude at abstract screening: useful only for background. [pmid: 9463789].
Grossman S A, Benedetti C, Payne R, Syrjala K. National Comprehensive Cancer Network practice guidelines for cancer pain. Oncology. 99;13:33-44. [Rec#: 50468] Exclude at abstract screening: Title Only.
Gruber T, Sharma A, Daneschvar H, Estfan B. The Hawthorne effect in the assessment of pain by house staff. Am J Hosp Palliat Care. 2003;20(3):231-4. [Rec#: 11741] Exclude at abstract screening: Study Design - Unclear. [pmid: 12785046].
Grunberg S M, Srivastava A, Grunberg K J, Weeks J. Intensity of chemotherapy-induced emesis and overall survival as determinants of a global utility score. Support Care Cancer. 2002;10(8):624-9. [Rec#: 2849] Exclude at abstract screening: not about end of life. [pmid: 12436221].
Grunfeld E A, Ramirez A J, Maher E J, Peach D, Young T, Albery I P, Richards M A. Chemotherapy for advanced breast cancer: what influences oncologists' decision-making?. Br J Cancer. 2001;84(9):1172-8. [Rec#: 2853] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11336466].
Grzybowska P, Finlay I. The incidence of suicide in palliative care patients. Palliat Med 97;11(4):313–6. Comment in: Palliat Med. May. 1998;12(3):209. PMID: 9743844. [Rec#: 11743] Exclude at abstract screening: sudden/violent/non-chronic deaths.
Guck T P, Elsasser G N, Kavan M G, Barone E J. Depression and congestive heart failure. Congest Heart Fail. 2003;9(3):163-9. [Rec#: 32088] Exclude at abstract screening: no outcomes specified. [pmid: 12826775].
Guest J F, Hart W M, Cookson R F. Cost analysis of palliative care for terminally ill cancer patients in the UK after switching from weak to strong opioids. Palliative Care Advisory Committee. Pharmacoeconomics. 98;14(3):285-97. [Rec#: 11747] Exclude at abstract screening: not about end of life.
Guggisberg E, Rapin C H, Budtz-Jorgensen E. Care of the mouth in the elderly--experience at the Centre de soins continus. J Palliat Care. 90;6(4):21-3. [Rec#: 11750] Exclude at abstract screening: Title Only. [pmid: 2286857].
Guideline cuts Alzheimer's care down to size. Patient Focus Care Satisf 99;7(9):103–5. [Rec#: 32090] Exclude at abstract screening: Title Only
Gulla J P. Family assessment and its relation to hospice care. Am J Hosp Palliat Care. 92;9(4):30-4. [Rec#: 11755] Exclude at abstract screening: no outcomes specified. [pmid: 1457234].
Gulliford M C, Petruckevitch A, Burney P G. Hospital case notes and medical audit: evaluation of non-response. BMJ 91;302(6785):1128–9. Comment in: BMJ. Jun 29. 1991;302(6792):1605-6. PMID: 1855062. [Rec#: 2863] Exclude at abstract screening: Title Only.
Gum A, Snyder C R. Coping with terminal illness: the role of hopeful thinking. J Palliat Med. 2002;5(6):883-94. [Rec#: 11758] Exclude at abstract screening: useful only for background. [pmid: 12685535].
Gundel H, O'Connor M F, Littrell L, Fort C, Lane R D. Functional neuroanatomy of grief: an FMRI study. Am J Psychiatry. 2003;160(11):1946-53. [Rec#: 2865] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14594740].
Gunderman RB. Medicine and the question of suffering. Second Opin 90;(14):14–25. [Rec#: 2866] Exclude at abstract screening: no outcomes specified
Gunter-Hunt G, Mahoney J E, Sieger C E. A comparison of state advance directive documents. Gerontologist. 2002;42(1):51-60. [Rec#: 11764] Exclude at abstract screening: not about end of life. [pmid: 11815699].
Gupta N K, Boylan C E, Razzaq R, England R E, Mirra L, Martin D F. Self-expanding oesophageal metal stents for the palliation of dysphagia due to extrinsic compression. Eur Radiol. 99;9(9):1893-7. [Rec#: 2873] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Gurland B. The impact of depression on quality of life of the elderly. Clin Geriatr Med. 92;8(2):377-86. [Rec#: 2874] Exclude at abstract screening: not about end of life. [pmid: 1600487].
Gurley R J, Lum N, Sande M, Lo B, Katz M H. Persons found in their homes helpless or dead. N Engl J Med 96;334(26):1710–6. Comment in: N Engl J Med. 1996 Jun 27;334(26):1738–9. PMID: 8637522. Comment in: N Engl J Med. 1996 Nov 21;335(21):1612; author reply 1612–3. PMID: 8927117. Comment in: N Engl J Med. Nov 21. 1996;335(21):1612. author reply 1612–3. PMID: 8927116 [Rec#: 2875] Exclude at abstract screening: not about end of life.
Guthery D, Schumann L. Congestive heart failure. J Am Acad Nurse Pract. 98;10(1):31-8. quiz 39–41. [Rec#: 32106] Exclude at abstract screening: no outcomes specified. [pmid: 9616566].
Guthrie C M, Haddock G, De Beaux A C, Garden O J, Carter D C. Changing trends in the management of extrahepatic cholangiocarcinoma. Br J Surg. 93;80(11):1434-9. [Rec#: 2880] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Guthrie S J, Hill K M, Muers M E. Living with severe COPD. A qualitative exploration of the experience of patients in Leeds. Respir Med. 2001;95(3):196-204. [Rec#: 2881] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11266237].
Gutierrez R. The heart function clinic. Can Nurse. 94;90(5):33-6. [Rec#: 32108] Exclude at abstract screening: Title Only. [pmid: 8076322].
Gutt C N, Held S, Paolucci V, Encke A. Experiences with percutaneous endoscopic gastrostomy. World J Surg. 96;20(8):1006-8. discussion 1108–9. [Rec#: 2886] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Gutterman E M, Markowitz J S, Lewis B, Fillit H. Cost of Alzheimer's disease and related dementia in managed-medicare. J Am Geriatr Soc. 99;47(9):1065-71. [Rec#: 32109] In abstract review process. [pmid: 10484247].
Guyatt G H. Measurement of health-related quality of life in heart failure. J Am Coll Cardiol. 93;22(4 Suppl A):185A-191A. [Rec#: 32111] Exclude at abstract screening: Study Design - Unclear.
Guyatt G H, Cook D J. Health status, quality of life, and the individual. JAMA. 94;272(8):630-1. [Rec#: 50868] Exclude at abstract screening: no outcomes specified. [pmid: 8057520].
Gwilliam B, Bailey C. The nature of terminal malignant bowel obstruction and its impact on patients with advanced cancer. Int J Palliat Nurs. 2001;7(10):474-81. [Rec#: 2888] Exclude at abstract screening: Observational study. [pmid: 11923747].
Gyllenhammar E, Thoren-Todoulos E, Strang P, Strom G, Eriksson E, Kinch M. Predictive factors for home deaths among cancer patients in Swedish palliative home care. Support Care Cancer. 2003;11(9):560-7. [Rec#: 11774] Exclude at abstract screening: Other topic only. [pmid: 12844249].
Haarmann W, Smektala R, Metzger S, Wysocki P, Kozuschek W. The change of therapy in esophagus carcinoma between 1975-1996. Wiad Lek. 97;50(Suppl 1 Pt 1):352-4. [Rec#: 2891] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Haas F. Bereavement care: seeing the body. Nurs Stand. 2003;17(28):33-7. [Rec#: 2892] Exclude at abstract screening: not about end of life. [pmid: 12710299].
Haas W M. Psychotherapy: some guiding principles. Am J Psychother. 97;51(4):593-606. [Rec#: 2893] Exclude at abstract screening: not about end of life. [pmid: 9470964].
Haber D. Minority access to hospice. Am J Hosp Palliat Care. 99;16(1):386-9. [Rec#: 11777] Exclude at abstract screening: useful only for background. [pmid: 10085795].
Haber D. Minority access to hospice. American Journal of Hospice & Palliative Care. 99;16(1):386-9. [Rec#: 50470] Exclude at abstract screening: no outcomes specified. [pmid: 10085795].
Haberman M R, Germino B B, Maliski S, Stafford-Fox V, Rice K. What makes oncology nursing special? Walking the road together. Oncol Nurs Forum. 94;21(8 Suppl):41-7. [Rec#: 2894] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Hacker C, Watson J R, Grimes R M. Following the patient's wishes: living wills and powers of attorney. AIDS Patient Care. 95;9(6):293-6. [Rec#: 11778] Exclude at abstract screening: Title Only. [pmid: 11361438].
Haddad FD. At the end of the continuum--“going home”. Health care needs to focus on providing hospice services to the communities they serve. AHP J 2001;26–9. [Rec#: 2900] Exclude at abstract screening: Title Only
Hadfield N. The role of aromatherapy massage in reducing anxiety in patients with malignant brain tumours. Int J Palliat Nurs. 2001;7(6):279-85. [Rec#: 2901] Exclude at abstract screening: Observational study. [pmid: 12066022].
Hadjistavropoulos H D, Frombach I K, Asmundson G J. Exploratory and confirmatory factor analytic investigations of the Illness Attitudes Scale in a nonclinical sample. Behav Res Ther. 99;37(7):671-84. [Rec#: 2903] Exclude at abstract screening: not about end of life.
Hadorn D, Baker D, Dracup K, Pitt B. Making judgements about treatment effectiveness based on health outcomes: theoretical and practical issues. Jt Comm J Qual Improv. 94;20(10):547-54. [Rec#: 32118] Exclude at abstract screening: primarily prognosis or trajectories.
Hagedoorn M, Sneeuw K C, Aaronson N K. Changes in physical functioning and quality of life in patients with cancer: response shift and relative evaluation of one's condition. J Clin Epidemiol. 2002;55(2):176-83. [Rec#: 2908] Exclude at abstract screening: not about end of life. [pmid: 11809356].
Hagen N A, Elwood T, Ernst S. Cancer pain emergencies: a protocol for management. J Pain Symptom Manage 97;14(1):45–50. Comment in: J Pain Symptom Manage. May. 1998;15(5):264-5. PMID: 9654827. [Rec#: 2909] Exclude at abstract screening: not about end of life.
Hagenhoff B D, Feutz C, Conn V S, Sagehorn K K, Moranville-Hunziker M. Patient education needs as reported by congestive heart failure patients and their nurses. J Adv Nurs. 94;19(4):685-90. [Rec#: 32121] Exclude at abstract screening: not about end of life.
Haggerty J L, Reid R J, Freeman G K, Starfield B H, Adair C E, McKendry R. Continuity of care: a multidisciplinary review. British Medical Journal. 2003;327:1219-1221. [Rec#: 50471] Exclude at abstract screening: Title Only. [pmid: 14630762]. [pmcid: 274066].
Hagland M. Managing diseases by managing IT. Health Manag Technol 98;19(7):18–20, 22, 24–5. [Rec#: 50035] Exclude at abstract screening: not about end of life
Hagman G. Bereavement and neurosis. J Am Acad Psychoanal. 95;23(4):635-53. [Rec#: 2912] Exclude at abstract screening: not about end of life. [pmid: 8809725].
Hagman G. The role of the other in mourning. Psychoanal Q. 96;65(2):327-52. [Rec#: 2913] Exclude at abstract screening: no outcomes specified. [pmid: 8727033].
Hague SB and Moody LE. A study of the public's knowledge regarding advance directives. Nurs Econ 93;11(5):303–7, 323. [Rec#: 2915] Exclude at abstract screening: not about end of life
Hahn J, Bishop G, and Fennell L. Integrating service excellence in a CHF clinical pathway pilot project. J Healthc Qual 2002;24(2):35–9, 44. [Rec#: 32125] Exclude at abstract screening: not about end of life
Haider-Markel D P, Joslyn M R. Just how important is the messenger versus the message? The case of framing physician-assisted suicide. Death Stud. 2004;28(3):243-62. [Rec#: 2918] Exclude at abstract screening: sudden/violent/non-chronic deaths. [pmid: 15053033].
Haidet P, Hamel M B, Davis R B, Wenger N, Reding D, Kussin P S, Connors A F Jr, Lynn J, Weeks J C, Phillips R S. Outcomes, preferences for resuscitation, and physician-patient communication among patients with metastatic colorectal cancer. SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatments. Am J Med. 98;105(3):222-9. [Rec#: 11793] Exclude at abstract screening: Title Only.
Haight B K. Long-term effects of a structured life review process. J Gerontol. 92;47(5):P312-5. [Rec#: 41333] Exclude at abstract screening: not about end of life. [pmid: 1512436].
Haines A and Katona C. Dementia in old age. Occas Pap R Coll Gen Pract 92;(58):62–6. [Rec#: 32129] Exclude at abstract screening: no outcomes specified
Hainsworth M A, Eakes G G, Burke M L. Coping with chronic sorrow. Issues Ment Health Nurs. 94;15(1):59-66. [Rec#: 2929] Exclude at abstract screening: Study Design - Qualitative. [pmid: 8119797].
Hainsworth M A. Helping spouses with chronic sorrow related to multiple sclerosis. J Gerontol Nurs. 95;21(7):29-33. [Rec#: 2925] Exclude at abstract screening: Study Design - Unclear. [pmid: 7615915].
Hainsworth M A. Helping spouses with chronic sorrow related to multiple sclerosis. J Psychosoc Nurs Ment Health Serv. 96;34(6):36-40. [Rec#: 2926] Exclude at abstract screening: Study Design - Unclear.
Hainsworth M A. Living with multiple sclerosis: the experience of chronic sorrow. J Neurosci Nurs. 94;26(4):237-40. [Rec#: 2927] Exclude at abstract screening: Observational study. [pmid: 7814916].
Haisfield-Wolfe ME and Rund C. Malignant cutaneous wounds: a management protocol. Ostomy Wound Manage 97;43(1):56–60, 62, 64–6. [Rec#: 11801] Exclude at abstract screening: useful only for background
Hale M S, Mikita M M. A family-systems model for consultation psychiatry. Adv Psychosom Med. 90;20:17-32. [Rec#: 2934] Exclude at abstract screening: Title Only. [pmid: 2239503].
Halevy A, Neal R C, Brody B A. The low frequency of futility in an adult intensive care unit setting. Arch Intern Med. 96;156(1):100-4. [Rec#: 11804] Exclude at abstract screening: Title Only. [pmid: 8526687].
Haley W E. The costs of family caregiving: implications for geriatric oncology. Crit Rev Oncol Hematol. 2003;48(2):151-8. [Rec#: 2936] Exclude at abstract screening: Non-systematic review. [pmid: 14607378].
Hall B, Hall D A. Learning from the experience of loss: people bereaved during intensive care. Intensive Crit Care Nurs. 94;10(4):265-70. [Rec#: 11808] Exclude at abstract screening: Observational study.
Hall B A. Patterns of spirituality in persons with advanced HIV disease. Res Nurs Health. 98;21(2):143-53. [Rec#: 2939] Exclude at abstract screening: Study Design - Qualitative. [pmid: 9535406].
Hall B A. The struggle of the diagnosed terminally ill person to maintain hope. Nurs Sci Q. 90;3(4):177-84. [Rec#: 11811] Exclude at abstract screening: Study Design - Qualitative. [pmid: 2250837].
Hall J E, Kirschling J M. A conceptual framework for caring for families of hospice patients. Hosp J. 90;6(2):1-28. [Rec#: 2941] Exclude at abstract screening: no outcomes specified. [pmid: 2401468].
Hall M, Baum A, Buysse D J, Prigerson H G, Kupfer D J, Reynolds C F 3rd. Sleep as a mediator of the stress-immune relationship. Psychosom Med. 98;60(1):48-51. [Rec#: 2943] Exclude at abstract screening: not about end of life.
Hall M, Buysse D J, Dew M A, Prigerson H G, Kupfer D J, Reynolds C F 3rd. Intrusive thoughts and avoidance behaviors are associated with sleep disturbances in bereavement-related depression. Depress Anxiety. 97;6(3):106-12. [Rec#: 2944] Exclude at abstract screening: Bereavement only.
Hall P, Stone G, Fiset V J. Palliative care: how can we meet the needs of our multicultural communities?. J Palliat Care. 98;14(2):46-9. [Rec#: 2946] Exclude at abstract screening: no outcomes specified.
Hall R I, Duncan P J, Rocker G. Death in the ICU--the Halifax experience. Can J Anaesth. 99;46(5 Pt 2):R57-69. [Rec#: 11818] Exclude at abstract screening: Title Only. [pmid: 10370831].
Hall S E. Spiritual diversity: a challenge for hospice chaplains. Am J Hosp Palliat Care. 97;14(5):221-3. [Rec#: 11819] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 9341337].
Hallenbeck J, Goldstein M K, Mebane E W. Cultural considerations of death and dying in the United States. Clin Geriatr Med. 96;12(2):393-406. [Rec#: 2948] Exclude at abstract screening: no outcomes specified.
Halligan P, Corcoran P. The impact of patient suicide on rural general practitioners. Br J Gen Pract. 2001;51(465):295-6. [Rec#: 2949] Exclude at abstract screening: sudden/violent/non-chronic deaths. [pmid: 11458483]. [pmcid: 1313980].
Halloran E, Prentice N, Murray C L, O'Carroll R E, Glabus M F, Goodwin G M, Ebmeier K P. Follow-up study of depression in the elderly. Clinical and SPECT data. Br J Psychiatry. 99;175:252-8. [Rec#: 32136] Exclude at abstract screening: not about end of life.
Halstead M T, Hull M. Struggling with paradoxes: the process of spiritual development in women with cancer. Oncol Nurs Forum. 2001;28(10):1534-44. [Rec#: 2951] Exclude at abstract screening: not about end of life. [pmid: 11759301].
Hambridge J A. The grief process in those admitted to regional secure units following homicide. J Forensic Sci. 90;35(5):1149-54. [Rec#: 2953] Exclude at abstract screening: sudden/violent/non-chronic deaths.
Hamel R. Restoring healing to health care. Second Opin. 94;20(1):74-6. [Rec#: 2955] Exclude at abstract screening: Title Only. [pmid: 10136513].
Hamel R P, Lysaught M T. Choosing palliative care: do religious beliefs make a difference?. J Palliat Care. 94;10(3):61-6. [Rec#: 2956] Exclude at abstract screening: Title Only. [pmid: 7531236].
Hamel M B, Phillips R S, Davis R B, Desbiens N, Connors A F Jr, Teno J M, Wenger N, Lynn J, Wu A W, Fulkerson W, Tsevat J. Outcomes and cost-effectiveness of initiating dialysis and continuing aggressive care in seriously ill hospitalized adults. SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatments. Annals of Internal Medicine. 97;127(3):195-202. [Rec#: 50473] In abstract review process.
Hamel M B, Phillips R S, Davis R B, Teno J, Desbiens N, Lynn J, Tsevat J. Are aggressive treatment strategies less cost-effective for older patients? The case of ventilator support and aggressive care for patients with acute respiratory failure. Journal of the American Geriatrics Society. 2001;49(4):382-90. [Rec#: 50475] Exclude at abstract screening: Other topic only. [pmid: 11347780].
Hames C. Helping infants and toddlers when a family member dies. Journal of Hospice and Palliative Medicine. 2003;5(2):103-110. [Rec#: 50478] Notes: “EXCLUDE: Age, not adults”.
Hamilton D G. Believing in patients' beliefs: physician attunement to the spiritual dimension as a positive factor in patient healing and health. Am J Hosp Palliat Care. 98;15(5):276-9. [Rec#: 11836] Exclude at abstract screening: not about end of life.
Hamilton J, Butler L, Wagenaar H, Sveinson T, Ward K A, McLean L, Grant D, MacLellan F. The impact and management of cancer-related fatigue on patients and families. Can Oncol Nurs J. 2001;11(4):192-8. [Rec#: 32143] Exclude at abstract screening: not about end of life. [pmid: 11842451].
Hamner M B. Exacerbation of posttraumatic stress disorder symptoms with medical illness. Gen Hosp Psychiatry. 94;16(2):135-7. [Rec#: 32147] Exclude at abstract screening: not about end of life. [pmid: 8039692].
Han P, Arnold B. The challenge of chronic AIDS-related nausea and vomiting. J Palliat Med. 2001;4(1):65-8. [Rec#: 2967] Exclude at abstract screening: Title Only. [pmid: 11291398].
Handy J R Jr, Asaph J W, Skokan L, Reed C E, Koh S, Brooks G, Douville E C, Tsen A C, Ott G Y, Silvestri G A. What happens to patients undergoing lung cancer surgery? Outcomes and quality of life before and after surgery. Chest 2002;122(1):21–30. Comment in: Chest. Jul. 2002;122(1):4-5. PMID: 12114328. [Rec#: 32156] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Hanger H C, Fogarty B, Wilkinson T J, Sainsbury R. Stroke patients' views on stroke outcomes: death versus disability. Clin Rehabil. 2000;14(4):417-24. [Rec#: 2975] Exclude at abstract screening: Observational study. [pmid: 10945426].
Hanks G W, Conno F, Cherny N, Hanna M, Kalso E, McQuay H J, Mercadante S, Meynadier J, Poulain P, Ripamonti C, Radbruch L, Casas J R, Sawe J, Twycross R G, Ventafridda V. Expert Working Group of the Research Network of the European Association for Palliative, Care. Morphine and alternative opioids in cancer pain: the EAPC recommendations. British Journal of Cancer. 2001;84(5):587-93. [Rec#: 50479] Exclude at abstract screening: no outcomes specified. [pmid: 11237376].
Hanrahan P, Luchins D J. Feasible criteria for enrolling end-stage dementia patients in home hospice care. Hosp J. 95;10(3):47-54. [Rec#: 2982] Exclude at abstract screening: primarily prognosis or trajectories.
Hanratty B, Hibbert D, Mair F, May C, Ward C, Capewell S, Litva A, Corcoran G. Doctors' perceptions of palliative care for heart failure: focus group study. BMJ 2002;325(7364):581–5. Comment in: BMJ. Oct 26. 2002;325(7370):915-6. PMID: 12399323. [Rec#: 11849] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Hansdottir H, Gruman C, Curry L, Judge J O. Preferences for CPR among the elderly: the influence of attitudes and values. Conn Med. 2000;64(10):625-30. [Rec#: 2984] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11100634].
Hansen H E, Bull M J, Gross C R. Interdisciplinary collaboration and discharge planning communication for elders. J Nurs Adm. 98;28(9):37-46. [Rec#: 32162] Exclude at abstract screening: not about end of life.
Hansen S M, Tolle S W, Martin D P. Factors associated with lower rates of in-hospital death. Journal of Palliative Medicine. 2002;5(5):677-85. [Rec#: 50480] Exclude at abstract screening: Other topic only. [pmid: 12572966].
Hansen-Flaschen J. Chronic obstructive pulmonary disease: the last year of life. Respir Care. 2004;49(1):90-8. [Rec#: 2985] Exclude at abstract screening: no outcomes specified. [pmid: 14733625].
Hansen-Flaschen JH. Palliative home care for advanced lung disease. Respir Care 2000;45(12):1478–86; discussion 1486–9. [Rec#: 11852] Exclude at abstract screening: useful only for background
Hanson D, Langemo D K, Olson B, Hunter S, Sauvage T R, Burd C, Cathcart-Silberberg T. The prevalence and incidence of pressure ulcers in the hospice setting: analysis of two methodologies. Am J Hosp Palliat Care. 91;8(5):18-22. [Rec#: 2986] Exclude at abstract screening: Study Design - Unclear.
Hanson D S, Langemo D, Olson B, Hunter S, Burd C. Evaluation of pressure ulcer prevalence rates for hospice patients post-implementation of pressure ulcer protocols. Am J Hosp Palliat Care. 94;11(6):14-9. [Rec#: 2987] Exclude at abstract screening: Other topic only.
Hanson L C, Danis M, Garrett J. What is wrong with end-of-life care? Opinions of bereaved family members. J Am Geriatr Soc. 97;45(11):1339-44. [Rec#: 2991] Exclude at abstract screening: Study Design - Qualitative.
Hanson L C, Henderson M, Menon M. As individual as death itself: a focus group study of terminal care in nursing homes. J Palliat Med. 2002;5(1):117-25. [Rec#: 2993] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11839234].
Hanson L C, Tulsky J A, Danis M. Can clinical interventions change care at the end of life? Ann Intern Med 97;126(5):381–8. Comment in: Ann Intern Med. 1997 Oct 1;127(7):574; author reply 574–5. PMID: 9313031. Comment in: Ann Intern Med. Oct 1. 1997;127(7):574. author reply 574–5. PMID: 9313030. [Rec#: 11862] Exclude at abstract screening: Study Design - Review/Meta.
Hansson L, Lithell H, Skoog I, Baro F, Banki C M, Breteler M, Castaigne A, Correia M, Degaute J P, Elmfeldt D, Engedal K, Farsang C, Ferro J, Hachinski V, Hofman A, James O F, Krisin E, Leeman M, de Leeuw P W, Leys D, Lobo A, Nordby G, Olofsson B, Opolski G, Prince M, Reischies F M. Study on COgnition and Prognosis in the Elderly (SCOPE): baseline characteristics. Blood Press. 2000;9(23):146-51. [Rec#: 32166] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 10855739].
Happ M B, Capezuti E, Strumpf N E, Wagner L, Cunningham S, Evans L, Maislin G. Advance care planning and end-of-life care for hospitalized nursing home residents. J Am Geriatr Soc. 2002;50(5):829-35. [Rec#: 2995] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12028168].
Happ M B, Naylor M D, Roe-Prior P. Factors contributing to rehospitalization of elderly patients with heart failure. J Cardiovasc Nurs. 97;11(4):75-84. [Rec#: 32167] Exclude at abstract screening: not about end of life.
Harding N. A practice-based evaluation of a liquid barrier film. Int J Palliat Nurs. 2002;8(5):233-9. [Rec#: 3005] Exclude at abstract screening: Study Design - Unclear. [pmid: 12048506].
Harding R, Higginson I. Working with ambivalence: informal caregivers of patients at the end of life. Support Care Cancer. 2001;9(8):642-5. [Rec#: 3006] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11762976].
Harding R, Higginson I J. What is the best way to help caregivers in cancer and palliative care? A systematic literature review of interventions and their effectiveness. Palliat Med. 2003;17(1):63-74. [Rec#: 3007] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 12597468].
Harding R, Leam C, Pearce A, Taylor E, Higginson I J. A multi-professional short-term group intervention for informal caregivers of patients using a home palliative care service. J Palliat Care. 2002;18(4):275-81. [Rec#: 11871] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12611318].
Hardman A, Maguire P, Crowther D. The recognition of psychiatric morbidity on a medical oncology ward. Journal of Psychosomatic Research. 89;33(2):235-9. [Rec#: 50481] Exclude at abstract screening: data older than 1990.
Hardy P A. The role of the pain clinic in the management of the terminally ill. Br J Hosp Med. 90;43(2):142-6. [Rec#: 11878] Exclude at abstract screening: no outcomes specified. [pmid: 2178713].
Harjai K J, Nunez E, Stewart Humphrey J, Turgut T, Shah M, Newman J. Does gender bias exist in the medical management of heart failure?. Int J Cardiol. 2000;75(1):65-9. [Rec#: 32175] Exclude at abstract screening: not about end of life. [pmid: 11054508].
Harlow S D, Goldberg E L, Comstock G W. A longitudinal study of risk factors for depressive symptomatology in elderly widowed and married women. Am J Epidemiol. 91;134(5):526-38. [Rec#: 3022] Exclude at abstract screening: data older than 1990.
Harlow S D, Goldberg E L, Comstock G W. A longitudinal study of the prevalence of depressive symptomatology in elderly widowed and married women. Arch Gen Psychiatry. 91;48(12):1065-8. [Rec#: 3023] Exclude at abstract screening: data older than 1990.
Harrington K J, Pandha H S, Kelly S A, Lambert H E, Jackson J E, Waxman J. Palliation of obstructive nephropathy due to malignancy. Br J Urol. 95;76(1):101-7. [Rec#: 3029] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Harrington V, Lackey N R, Gates M F. Needs of caregivers of clinic and hospice cancer patients. Cancer Nurs. 96;19(2):118-25. [Rec#: 3030] Exclude at abstract screening: Title Only. [pmid: 8635165].
Harris P E. Acupressure: a review of the literature. Complementary Therapies in Medicine. 97;5(3):156-161. [Rec#: 50849] Exclude at abstract screening: not about end of life.
Harris T, Kendrick T. Bereavement care in general practice: a survey in South Thames Health Region. Br J Gen Pract 98;48(434):1560–4. Comment in: Br J Gen Pract. 1999 Jan;49(438):66. PMID: 10622028. Comment in: Br J Gen Pract. Jan. 1999;49(438):66. PMID: 10622029. [Rec#: 11901] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Harris Y, Gorelick P B, Cohen D, Dollear W, Forman H, Freels S. Psychiatric symptoms in dementia associated with stroke: a case-control analysis among predominantly African-American patients. J Natl Med Assoc. 94;86(9):697-702. [Rec#: 32189] Exclude at abstract screening: not about end of life.
Harrison M B, Browne G B, Roberts J, Tugwell P, Gafni A, Graham I D. Quality of life of individuals with heart failure: a randomized trial of the effectiveness of two models of hospital-to-home transition. Med Care 2002;40(4):271–82. Comment in: Evid Based Nurs. 2003 Jan;6(1):21. PMID: 12546039. Comment in: Med Care. Apr. 2002;40(4):267-8. PMID: 12021681. [Rec#: 32191] Exclude at abstract screening: not about end of life.
Hart A Jr, Kohlwes R J, Deyo R, Rhodes L A, Bowen D J. Hospice patients' attitudes regarding spiritual discussions with their doctors. Am J Hosp Palliat Care 2003;20(2):135–9. Comment in: Am J Hosp Palliat Care. 2003 Mar-Apr;20(2):88–9. PMID: 12693636. Comment in: Am J Hosp Palliat Care. Mar-Apr. 2003;20(2):90-2. PMID: 12693637. [Rec#: 3040] Exclude at abstract screening: Study Design - Qualitative.
Hart G, Yates P, Clinton M, Windsor C. Mediating conflict and control: practice challenges for nurses working in palliative care. Int J Nurs Stud. 98;35(5):252-8. [Rec#: 3041] Exclude at abstract screening: no outcomes specified.
Harvey H A, Lipton A. The role of bisphosphonates in the treatment of bone metastases--the U.S. experience. Support Care Cancer. 96;4(3):213-7. [Rec#: 11915] Exclude at abstract screening: no outcomes specified.
Harvey S A. S.C.A.L.E.--spiritual care at life's end: a multi-disciplinary approach to end-of-life issues in a hospital setting. Med Ref Serv Q. 2001;20(4):63-71. [Rec#: 11918] Exclude at abstract screening: no outcomes specified. [pmid: 11865764].
Harwood D G, Sultzer D L. “Life is not worth living”: hopelessness in Alzheimer's disease. J Geriatr Psychiatry Neurol. 2002;15(1):38-43. [Rec#: 32209] Exclude at abstract screening: Observational study. [pmid: 11936242].
Harwood D G, Barker W W, Ownby R L, Duara R. Clinical characteristics of community-dwelling black Alzheimer's disease patients. J Natl Med Assoc. 2000;92(9):424-9. [Rec#: 32206] Exclude at abstract screening: not about end of life. [pmid: 11052455].
Harwood D G, Barker W W, Ownby R L, Mullan M, Duara R. Factors associated with depressive symptoms in non-demented community-dwelling elderly. Int J Geriatr Psychiatry. 99;14(5):331-7. [Rec#: 32207] Exclude at abstract screening: not about end of life.
Harwood D G, Barker W W, Ownby R L, Mullan M J, Duara R. Family history of dementia and current depression in nondemented community-dwelling older adults. J Geriatr Psychiatry Neurol. 2000;13(2):65-71. [Rec#: 32208] Exclude at abstract screening: not about end of life. [pmid: 10912727].
Hately J, Laurence V, Scott A, Baker R, Thomas P. Breathlessness clinics within specialist palliative care settings can improve the quality of life and functional capacity of patients with lung cancer. Palliat Med. 2003;17(5):410-7. [Rec#: 3058] Exclude at abstract screening: not about end of life. [pmid: 12882259].
Hauser J M, Kleefield S F, Brennan T A. Minority populations and advanced directives: insights from a focus group methodology. Cambridge Quarterly of Healthcare Ethics. 97;6:58-71. [Rec#: 50485] Exclude at abstract screening: Title Only.
Haverkate I, van Delden J J, van Nijen A B, van der Wal G. Guidelines for the use of do-not-resuscitate orders in Dutch hospitals. Crit Care Med. 2000;28(8):3039-43. [Rec#: 41421] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10966292].
Havranek E P, Masoudi F A, Rumsfeld J S, Steiner J F. A broader paradigm for understanding and treating heart failure. J Card Fail. 2003;9(2):147-52. [Rec#: 32222] Exclude at abstract screening: not about end of life. [pmid: 12751136].
Havranek E P, McGovern K M, Weinberger J, Brocato A, Lowes B D, Abraham W T. Patient preferences for heart failure treatment: utilities are valid measures of health-related quality of life in heart failure. J Card Fail. 99;5(2):85-91. [Rec#: 32223] Exclude at abstract screening: not about end of life.
Havranek E P, Ware M G, Lowes B D. Prevalence of depression in congestive heart failure. Am J Cardiol. 99;84(3):348-50. A9. [Rec#: 32224] Exclude at abstract screening: not about end of life. [pmid: 10496452].
Hawthorne M H, Hixon M E. Functional status, mood disturbance and quality of life in patients with heart failure. Prog Cardiovasc Nurs. 94;9(1):22-32. [Rec#: 32226] Exclude at abstract screening: Study Design - Qualitative.
Hay L, Farncombe M, McKee P. Patient, nurse and physician views of dyspnea. Can Nurse. 96;92(10):26-9. [Rec#: 3072] Exclude at abstract screening: no outcomes specified. [pmid: 9095758].
Hayes R P, Baker D W, Luthi J C, Baggett R L, McClellan W, Fitzgerald D, Abrams F R, Bratzler D, Ballard D J. The effect of external feedback on the management of medicare inpatients with congestive heart failure. Am J Med Qual. 2002;17(6):225-35. [Rec#: 32231] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12487338].
Hayes S, Henshaw D, Rai G S, Stewart K. Audit of resuscitation decisions has little impact on clinical practice. J R Coll Physicians Lond 99;33(4)::348–50. Comment in: J R Coll Physicians Lond. Sep-Oct. 1999;33(5):486. PMID: 10624677. [Rec#: 41425] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Hayley D C, Muir J C, Stocking C, Hougham G, Sachs G. Not ready for hospice: characteristics of patients in a pre-hospice program. Am J Hosp Palliat Care. 2001;18(6):377-82. [Rec#: 3079] Exclude at abstract screening: Title Only. [pmid: 11712718].
Hayley D C, Stern R, Stocking C, Sachs G A. The application of health care surrogate laws to older populations: how good a match?. Journal of the American Geriatric Society. 96;44(2):185-8. [Rec#: 50486] Exclude at abstract screening: not about end of life.
Hayman J A, Langa K M. Estimating the costs of caring for the older breast cancer patient. Crit Rev Oncol Hematol. 2003;46(3):255-60. [Rec#: 3080] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12791425].
Hays J C, Kasl S, Jacobs S. Past personal history of dysphoria, social support, and psychological distress following conjugal bereavement. J Am Geriatr Soc. 94;42(7):712-8. [Rec#: 3083] Exclude at abstract screening: Bereavement only.
Hayter C R, Mackillop W J. Admissions to a radiation oncology inpatient service. Cancer Prev Control. 97;1(2):116-21. [Rec#: 32233] Exclude at abstract screening: not about end of life. [pmid: 9765733].
Hazzard W R, Woolard N, Regenstreif D I. Internal medicine: at the nexus of the health care system in responding to the demographic imperative of an aging population. American Journal of Medicine. 2001;110(6):507-13. [Rec#: 50487] Exclude at abstract screening: Title Only. [pmid: 11331067].
Healy S, McNamara E. Tube feeding controversial patients: what do dietitians think?. J Hum Nutr Diet. 2002;15(6):445-53. [Rec#: 32236] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12460153].
Heaney L, Antonio C. Outpatient infusion clinics: a strategy for the successful management of advanced heart failure. J Cardiovasc Manag. 97;8(1):12-6. [Rec#: 32237] Exclude at abstract screening: Other topic only. [pmid: 10165390].
Hearn J, Higginson I J. Do specialist palliative care teams improve outcomes for cancer patients? A systematic literature review. Palliat Med. 98;12(5):317-32. [Rec#: 11979] Exclude at abstract screening: Study Design - Review/Meta.
Hearn J, Higginson I J. Outcome measures in palliative care for advanced cancer patients: a review. J Public Health Med. 97;19(2):193-9. [Rec#: 11980] Exclude at abstract screening: useful only for background.
Heart failure intervention cuts return trips to hospital. Clin Resour Manag 2001;2(1):12–3, 1. [Rec#: 32238] Exclude at abstract screening: not about end of life
Heath H, McCormack B, Phair L, Ford P. Developing outcome indicators in continuing care: part 2. Nurs Stand. 96;10(47):41-5. [Rec#: 3096] Exclude at abstract screening: no outcomes specified.
Heaven C M, Maguire P. Disclosure of concerns by hospice patients and their identification by nurses. Palliat Med. 97;11(4):283-90. [Rec#: 11983] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Hebert R S, Jenckes M W, Ford D E, O'Connor D R, Cooper L A. Patient perspectives on spirituality and the patient-physician relationship. Journal of General Internal Medicine. 2001;16(10):685-92. [Rec#: 50488] Exclude at abstract screening: Observational study. [pmid: 11679036]. [pmcid: 1495274].
Hecht M J, Graesel E, Tigges S, Hillemacher T, Winterholler M, Hilz M J, Heuss D, Neundorfer B. Burden of care in amyotrophic lateral sclerosis. Palliat Med. 2003;17(4):327-33. [Rec#: 3099] In abstract review process. [pmid: 12822849].
Heedman P A, Starkhammar H. Patterns of referral to a palliative care unit: an indicator of different attitudes toward the dying patient?. J Palliat Med. 2002;5(1):101-6. [Rec#: 3102] Exclude at abstract screening: Other topic only. [pmid: 11839232].
Heeren O, Dixon L, Gavirneni S, Regenold W T. The association between decreasing length of stay and readmission rate on a psychogeriatric unit. Psychiatr Serv. 2002;53(1):76-9. [Rec#: 32245] Exclude at abstract screening: not about end of life. [pmid: 11773653].
Hefferan C, Ludwig-Beymer P. Applying HIM skills in a systemwide congestive heart failure initiative. J AHIMA. 2000;71(2):69-70. [Rec#: 32247] Exclude at abstract screening: Title Only. [pmid: 10977641].
Hefflin B J. Final-year-of life pacemaker recipients. J Am Geriatr Soc. 98;46(11):1396-400. [Rec#: 41446] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 9809761].
Heffner J E, Highland K B. Chronic obstructive pulmonary disease in geriatric critical care. Crit Care Clin. 2003;19(4):713-27. [Rec#: 3110] Exclude at abstract screening: not about end of life. [pmid: 14601716].
Heffner JE. Role of pulmonary rehabilitation in palliative care. Respir Care 2000;45(11):1365–71; discussion 1371–5. [Rec#: 11988] Exclude at abstract screening: Title Only
Hegge M, Fischer C. Grief responses of senior and elderly widows. Practice implications. J Gerontol Nurs. 2000;26(2):35-43. [Rec#: 3114] Exclude at abstract screening: Title Only. [pmid: 10776174].
Hegge M. A qualitative retrospective study of coping strategies of newly widowed elderly. Effects of anticipatory grieving on the caregiver. Am J Hosp Palliat Care. 91;8(4):28-34. [Rec#: 3113] Exclude at abstract screening: Study Design - Qualitative.
Heidenreich A, Hofmann R, Engelmann U H. The use of bisphosphonate for the palliative treatment of painful bone metastasis due to hormone refractory prostate cancer. J Urol. 2001;165(1):136-40. [Rec#: 3115] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11125382].
Heidenreich A. Bisphosphonates in the management of metastatic prostate cancer. Oncology. 2003;65(Suppl 1):5-11. [Rec#: 11996] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 12949427].
Heim E, Augustiny K F, Schaffner L, Valach L. Coping with breast cancer over time and situation. J Psychosom Res. 93;37(5):523-42. [Rec#: 3117] Exclude at abstract screening: not about end of life. [pmid: 8350294].
Heintz L M, Baruss I. Spirituality in late adulthood. Psychol Rep. 2001;88(3 Pt 1):651-4. [Rec#: 3123] Exclude at abstract screening: not about end of life. [pmid: 11507998].
Heller A, Dinges S, Heimerl K, Reitinger E, Wegleitner K. [Palliative culture in the stationary care for the elderly]. Z Gerontol Geriatr. 2003;36(5):360-5. [Rec#: 3125] Exclude at abstract screening: Title Only. [pmid: 14579063].
Hellinger F J, Fleishman J A, Hsia D C. AIDS treatment costs during the last months of life: evidence from the ACSUS. Health Serv Res 94;29(5):569–81. Comment in: Health Serv Res. Dec. 1994;29(5):523-5. PMID: 8002347. [Rec#: 12007] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Helsing M, Bergman B, Thaning L, Hero U. Quality of life and survival in patients with advanced non-small cell lung cancer receiving supportive care plus chemotherapy with carboplatin and etoposide or supportive care only. A multicentre randomised phase III trial. Joint Lung Cancer Study Group. Eur J Cancer. 98;34(7):1036-44. [Rec#: 32265] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Henderson JM and Ord RA. Suicide in head and neck cancer patients. J Oral Maxillofac Surg 97;55(11):1217–21; discussion 1221–2. [Rec#: 3131] Exclude at abstract screening: not about end of life
Henderson M L. Ethics rounds. Living fully while dying. J Pain Symptom Manage 2001;21(4):357–8. Comment on: J Pain Symptom Manage. Apr. 2001;21(4):355-6. PMID: 11312050. [Rec#: 3133] Exclude at abstract screening: Title Only.
Henke C J, Burchmore M J. The economic impact of the tacrine in the treatment of Alzheimer's disease. Clin Ther. 97;19(2):330-45. [Rec#: 32278] Exclude at abstract screening: Other topic only. [pmid: 9152571].
Henneman E A, Baird B, Bellamy P E, Faber L L, Oye R K. Effect of do-not-resuscitate orders on the nursing care of critically ill patients. Am J Crit Care. 94;3(6):467-72. [Rec#: 3139] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Henning R. GP-hospice interaction. When should patients be referred?. Aust Fam Physician. 94;23(7):1242-5. [Rec#: 12017] Exclude at abstract screening: no outcomes specified. [pmid: 8060270].
Henrich W L. Dialysis considerations in the elderly patient. Am J Kidney Dis. 90;16(4):339-41. [Rec#: 32280] Exclude at abstract screening: no outcomes specified. [pmid: 2145757].
Henry R G. Alzheimer's disease and cognitively impaired elderly: providing dental care. J Calif Dent Assoc. 99;27(9):709-17. [Rec#: 32282] Exclude at abstract screening: not about end of life. [pmid: 10740518].
Hepburn K, Reed R. Ethical and clinical issues with Native-American elders. End-of-life decision making. Clin Geriatr Med. 95;11(1):97-111. [Rec#: 3149] Exclude at abstract screening: no outcomes specified.
Hepburn K, Petrie M, Peterson C, VanLoy W. A moving experience: reconfiguring a special care unit for Alzheimer's patients. Gerontologist. 95;35(6):831-5. [Rec#: 50037] Exclude at abstract screening: not about end of life.
Herbst L H, Strause L G. Transdermal fentanyl use in hospice home-care patients with chronic cancer pain. J Pain Symptom Manage. 92;7(3 Suppl):S54-7. [Rec#: 3152] Exclude at abstract screening: Observational study.
Herd E B. Terminal care in a semi-rural area. Br J Gen Pract 90;40(335):248–51. Comment in: Br J Gen Pract. Oct. 1990;40(339):433. PMID: 2271270. [Rec#: 3153] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Hermann C P. Spiritual needs of dying patients: a qualitative study. Oncol Nurs Forum. 2001;28(1):67-72. [Rec#: 3157] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11198899].
Hermann C, Loonery S. The effectiveness of symptoms management in hospice patients during the last sever days of life. Journal of Hospice and Palliative Nursing. 2001;3(3):88-96. [Rec#: 50489] Exclude at abstract screening: Study Design - Unclear.
Hermansson A R, Ternestedt B M. What do we know about the dying patient? Awareness as a means to improve palliative care. Med Law. 2000;19(2):335-44. [Rec#: 3159] Exclude at abstract screening: useful only for background. [pmid: 10994219].
Hern HE Jr, Koenig BA, Moore LJ, and Marshall PA. The difference that culture can make in end-of-life decisionmaking. Camb Q Healthc Ethics 98;7(1):27–40. Comment in: Camb Q Healthc Ethics. 2000 Winter;9(1):123–7. PMID: 10721474. [Rec#: 3160] Exclude at abstract screening: Title Only
Herrmann W M, Stephan K, Gaede K, Apeceche M. A multicenter randomized double-blind study on the efficacy and safety of nicergoline in patients with multi-infarct dementia. Dement Geriatr Cogn Disord. 97;8(1):9-17. [Rec#: 32306] Exclude at abstract screening: Study Design - Unclear.
Hershberger R E, Nauman D, Walker T L, Dutton D, Burgess D. Care processes and clinical outcomes of continuous outpatient support with inotropes (COSI) in patients with refractory endstage heart failure. J Card Fail 2003;9(3):180–7. Comment in: J Card Fail. Jun. 2003;9(3):188-91. PMID: 12815568. [Rec#: 3169] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Hershberger R E, Ni H, Nauman D J, Burgess D, Toy W, Wise K, Dutton D, Crispell K, Vossler M, Everett J. Prospective evaluation of an outpatient heart failure management program. J Card Fail. 2001;7(1):64-74. [Rec#: 32308] Exclude at abstract screening: not about end of life. [pmid: 11264552].
Herskovits E. Struggling over subjectivity: debates about the “self” and Alzheimer's disease. Med Anthropol Q. 95;9(2):146-64. [Rec#: 32310] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Herth K. Contributions of humor as perceived by the terminally ill. Am J Hosp Care. 90;7(1):36-40. [Rec#: 3171] Exclude at abstract screening: Title Only. [pmid: 2361096].
Herth K. Engendering hope in the chronically and terminally ill: nursing interventions. Am J Hosp Palliat Care. 95;12(5):31-9. [Rec#: 3172] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Herth K. Fostering hope in terminally-ill people. J Adv Nurs. 90;15(11):1250-9. [Rec#: 3173] Exclude at abstract screening: Study Design - Qualitative. [pmid: 2269747].
Herth K. Hope in the family caregiver of terminally ill people. J Adv Nurs. 93;18(4):538-48. [Rec#: 3174] Exclude at abstract screening: Study Design - Qualitative. [pmid: 8496501].
Herth K. Relationship of hope, coping styles, concurrent losses, and setting to grief resolution in the elderly widow(er). Res Nurs Health. 90;13(2):109-17. [Rec#: 3175] Exclude at abstract screening: Bereavement only. [pmid: 2320756].
Herth K A, Cutcliffe J R. The concept of hope in nursing 3: hope and palliative care nursing. Br J Nurs. 2002;11(14):977-83. [Rec#: 12044] Exclude at abstract screening: not about end of life. [pmid: 12165729].
Herth K. Abbreviated instrument to measure hope: development and psychometric evaluation. J Adv Nurs. 92;17(10):1251-9. [Rec#: 50869] Exclude at abstract screening: Study Design - Unclear. [pmid: 1430629].
Hess M. The new Palliative Care Outreach Program--a resounding success. Support Care Cancer. 99;7(5):298-301. [Rec#: 12046] Exclude at abstract screening: no outcomes specified. [pmid: 10483814].
Heun R, Papassotiropoulos A, Jessen F, Maier W, Breitner J C. A family study of Alzheimer disease and early- and late-onset depression in elderly patients. Arch Gen Psychiatry. 2001;58(2):190-6. [Rec#: 32314] Exclude at abstract screening: not about end of life. [pmid: 11177121].
Heuser I, Heuser-Link M, Gotthardt U, Grasser A, Holsboer F. Behavioral effects of a synthetic corticotropin 4–9 analog in patients with depression and patients with Alzheimer's disease. J Clin Psychopharmacol. 93;13(3):171-4. [Rec#: 32315] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Hewson D. Coping with loss of ability: “good grief” or episodic stress responses?. Soc Sci Med. 97;44(8):1129-39. [Rec#: 12049] Exclude at abstract screening: not about end of life. [pmid: 9131737].
Heyland D K, Tranmer J, Feldman-Stewart D. End-of-life decision making in the seriously ill hospitalized patient: an organizing framework and results of a preliminary study. J Palliat Care. 2000;16(Suppl):S31-9. [Rec#: 3185] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11075531].
Heyland D K, Tranmer J E. Kingston General Hospital ICU Research Working Group. Measuring family satisfaction with care in the intensive care unit: the development of a questionnaire and preliminary results. J Crit Care. 2001;16(4):142-9. [Rec#: 12052] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11815899].
Hiatt L G. Modifying the home environment or community setting for people with cognitive impairments. Pride Inst J Long Term Home Health Care. 90;9(2):18-27. [Rec#: 32322] Exclude at abstract screening: not about end of life.
Hibbert D, Hanratty B, May C, Mair F, Litva A, Capewell S. Negotiating palliative care expertise in the medical world. Soc Sci Med. 2003;57(2):277-88. [Rec#: 12055] Exclude at abstract screening: useful only for background. [pmid: 12765708].
Hickey A M, Bury G, O'Boyle C A, Bradley F, O'Kelly F D, Shannon W. A new short form individual quality of life measure (SEIQoL-DW): application in a cohort of individuals with HIV/AIDS. BMJ. 96;313(7048):29-33. [Rec#: 50870] Exclude at abstract screening: Study Design - Unclear.
Hickling J A, Nazareth I, Rogers S. The barriers to effective management of heart failure in general practice. Br J Gen Pract. 2001;51(469):615-8. [Rec#: 32325] Exclude at abstract screening: not about end of life. [pmid: 11510388]. [pmcid: 1314069].
Hicks F, Thom V, Alison D, and Corcoran G. Spinal cord compression: the hospice perspective. J Palliat Care 93;9(3):9–13. Comment in: J Palliat Care. 1994 Spring;10(1):56–8. PMID: 8035259. [Rec#: 3193] Exclude at abstract screening: outcome unrelated to pts/family/non-prof
Hietanen P, Lonnqvist J. Cancer and suicide. Ann Oncol 91;2(1):19–23. Comment in: Ann Oncol. Jan. 1991;2(1):8. PMID: 2009240. [Rec#: 3194] Exclude at abstract screening: sudden/violent/non-chronic deaths.
Higginson I, Wade A, McCarthy M. Palliative care: views of patients and their families. BMJ. 90;301(6746):277-81. [Rec#: 3199] Exclude at abstract screening: Title Only. [pmid: 1697189].
Higginson I. Advanced cancer: aiming for the best in care. Qual Health Care. 93;2(2):112-6. [Rec#: 12059] Exclude at abstract screening: Title Only. [pmid: 10145959].
Higginson I. Palliative care services in the community: what do family doctors want?. J Palliat Care. 99;15(2):21-5. [Rec#: 12061] Exclude at abstract screening: useful only for background. [pmid: 10425874].
Higginson I. Palliative care: a review of past changes and future trends. J Public Health Med. 93;15(1):3-8. [Rec#: 12060] Exclude at abstract screening: useful only for background. [pmid: 7682424].
Higginson I J, Hearn J. A multicenter evaluation of cancer pain control by palliative care teams. J Pain Symptom Manage. 97;14(1):29-35. [Rec#: 12070] Exclude at abstract screening: Title Only. [pmid: 9223840].
Higginson I J, Wilkinson S. Marie Curie nurses: enabling patients with cancer to die at home. Br J Community Nurs. 2002;7(5):240-4. [Rec#: 12075] Exclude at abstract screening: Title Only. [pmid: 12048497].
Higginson IJ Gysels M. Improving Supportive and Palliative Care for Adults With Cancer (DRAFT). unpublished and confidential;<25 Page(s)>. [Rec#: 50840] Exclude at abstract screening: Study Design - Review/Meta
Higginson I J, Finlay I, Goodwin D M, Cook A M, Hood K, Edwards A G, Douglas H R, Norman C E. Do hospital-based palliative teams improve care for patients or families at the end of life?. J Pain Symptom Manage. 2002;23(2):96-106. [Rec#: 12067] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 11844629].
Higginson IJ, Finlay IG, Goodwin DM, Cook AM, Edwards AGK, Hood K, Douglas H-R, Normand CE. The Role of Palliative Care Teams: a Systematic Review of Their Effectiveness and Cost-Effectiveness. 2001;<25 Page(s)>. [Rec#: 50835] Exclude at abstract screening: Study Design - Review/Meta
Higginson I J, Finlay I G, Goodwin D M, Hood K, Edwards A G, Cook A, Douglas H R, Normand C E. Is there evidence that palliative care teams alter end-of-life experiences of patients and their caregivers?. J Pain Symptom Manage. 2003;25(2):150-68. [Rec#: 12069] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 12590031].
Higginson I J, Hearn J, Webb D. Audit in palliative care: does practice change?. Eur J Cancer Care (Engl). 96;5(4):233-6. [Rec#: 12072] Exclude at abstract screening: not about end of life. [pmid: 9117067].
Higginson I J, Hearn J, Myers K, Naysmith A. Palliative day care: what do services do? Palliative Day Care Project Group. Palliat Med. 2000;14(4):277-86. [Rec#: 12071] Exclude at abstract screening: useful only for background. [pmid: 10974979].
Higginson I J, Jarman B, Astin P, Dolan S. Do social factors affect where patients die: an analysis of 10 years of cancer deaths in England. J Public Health Med. 99;21(1):22-8. [Rec#: 3203] Exclude at abstract screening: useful only for background.
Higginson IJ, Sen-Gupta G, Dunlop D. Changing Gear - Guidelines for Managing the Last Days of Life in Adults. The Research Evidence. 1997;<25 Page(s)>. [Rec#: 50492] Exclude at abstract screening: Title Only
Higginson I, McCarthy M. Measuring symptoms in terminal cancer: are pain and dyspnoea controlled?. Journal of the Royal Society of Medicine. 89;82(5):264-7. [Rec#: 50490] Exclude at abstract screening: data older than 1990.
Highfield M E. Providing spiritual care to patients with cancer. Clinical Journal of Oncology Nursing. 2000;4(3):115-20. [Rec#: 50493] Exclude at abstract screening: no outcomes specified. [pmid: 11235248].
Hilden J M, Watterson J, Chrastek J. Tell the children. Journal of Clinical Oncology. 2000;18(17):3193-5. [Rec#: 50494] Exclude at abstract screening: Title Only. [pmid: 10963650].
Hill CS Jr. Suffering as contrasted to pain, loss, grief, despair, and loneliness. NLN Publ 92;(15–2461):69–80. [Rec#: 12085] Exclude at abstract screening: Title Only
Hill N. Use of quality-of-life scores in care planning in a hospice setting: a comparative study. Int J Palliat Nurs. 2002;8(11):540-7. [Rec#: 3211] Exclude at abstract screening: Study Design - Unclear. [pmid: 12514464].
Hill N. Use of quality-of-life scores in care planning in a hospice setting: the theme of revelation. Int J Palliat Nurs. 2002;8(12):591-3. [Rec#: 12087] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12560801].
Hill R D, Backman L, Fratiglioni L. Determinants of functional abilities in dementia. J Am Geriatr Soc. 95;43(10):1092-7. [Rec#: 32332] Exclude at abstract screening: Other topic only. [pmid: 7560697].
Hill N, Eveloff S F, Carlisle C C, Goff S G. Efficacy of nocturnal nasal ventilation in patients with restrictive thoracic disease. American Review of Respiratory Diseases. 92;145:365-371. [Rec#: 50495] Exclude at abstract screening: Title Only.
Hilliard R E. Music therapy in pediatric palliative care: complementing the interdisciplinary approach. J Palliat Care. 2003;19(2):127-32. [Rec#: 12089] Exclude at abstract screening: Title Only. [pmid: 12955931].
Hilliard R E. The use of music therapy in meeting the multidimensional needs of hospice patients and families. J Palliat Care. 2001;17(3):161-6. [Rec#: 3214] Exclude at abstract screening: Observational study. [pmid: 11816756].
Hillman K M, Bristow P J, Chey T, Daffurn K, Jacques T, Norman S L, Bishop G F, Simmons G. Antecedents to hospital deaths. Intern Med J 2001;31(6):343–8. Comment in: Intern Med J. Aug. 2001;31(6):321. PMID: 11529584. [Rec#: 41514] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Hilton C, Jolley D. Understanding confusion. Nurs Elder. 90;2(7):24-6. [Rec#: 32334] Exclude at abstract screening: Title Only. [pmid: 2222910].
Hiltunen E F, Medich C, Chase S, Peterson L, Forrow L. Family decision making for end-of-life treatment: the SUPPORT nurse narratives. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatments. J Clin Ethics. 99;10(2):126-34. [Rec#: 3218] Exclude at abstract screening: Title Only.
Hiltunen E F, Puopolo A L, Marks G K, Marsden C, Kennard M J, Follen M A, Phillips R S. The nurse's role in end-of-life treatment discussions: preliminary report from the SUPPORT Project. J Cardiovasc Nurs. 95;9(3):68-77. [Rec#: 12094] Exclude at abstract screening: useful only for background.
Himsworth R L, Goldacre M J. Does time spent in hospital in the final 15 years of life increase with age at death? A population based study. BMJ 99;319(7221):1338–9. Comment in: BMJ. Feb 5. 2000;320(7231):378-9. PMID: 10657344. [Rec#: 3219] Exclude at abstract screening: Title Only.
Hinds C J, Martin R, Quinton P. Intensive care for patients with medical complications of haematological malignancy: is it worth it?. Schweiz Med Wochenschr. 98;128(39):1467-73. [Rec#: 12096] Exclude at abstract screening: Non-systematic review.
Hines S C, Babrow A S, Badzek L, Moss A. From coping with life to coping with death: problematic integration for the seriously ill elderly. Health Commun. 2001;13(3):327-42. [Rec#: 3225] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11550854].
Hinkka H, Kosunen E, Lammi E K, Metsanoja R, Puustelli A, Kellokumpu-Lehtinen P. Decision making in terminal care: a survey of finnish doctors' treatment decisions in end-of-life scenarios involving a terminal cancer and a terminal dementia patient. Palliat Med. 2002;16(3):195-204. [Rec#: 3229] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12046995].
Hinkka H, Kosunen E, Metsanoja R, Lammi U K, Kellokumpu-Lehtinen P. To resuscitate or not: a dilemma in terminal cancer care. Resuscitation. 2001;49(3):289-97. [Rec#: 3232] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11719124].
Hinkka H, Kosunen E, Metsanoja R, Lammi U K, Kellokumpu-Lehtinen P. General practitioners' attitudes and ethical decisions in end-of-life care after a year of interactive Internet-based training. J Cancer Educ. 2002;17(1):12-8. [Rec#: 12100] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12000099].
Hinshaw DB, Carnahan JM, and Johnson DL. Depression, anxiety, and asthenia in advanced illness. J Am Coll Surg 2002;195(2):271–7; discussion 277–8. [Rec#: 12104] Exclude at abstract screening: no outcomes specified
Hinshaw D B, Pawlik T, Mosenthal A C, Civetta J M, Hallenbeck J. When do we stop, and how do we do it? Medical futility and withdrawal of care. J Am Coll Surg. 2003;196(4):621-51. [Rec#: 12105] Exclude at abstract screening: Title Only. [pmid: 12691944].
Hinshaw DB. The spiritual needs of the dying patient. J Am Coll Surg 2002;195(4):565–8; discussion 568–9. [Rec#: 3233] Exclude at abstract screening: Title Only
Hinton J. An assessment of open communication between people with terminal cancer, caring relatives, and others during home care. J Palliat Care. 98;14(3):15-23. [Rec#: 3235] Exclude at abstract screening: Title Only. [pmid: 9770917].
Hirai K, Morita T, Kashiwagi T. Professionally perceived effectiveness of psychosocial interventions for existential suffering of terminally ill cancer patients. Palliat Med. 2003;17(8):688-94. [Rec#: 12107] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14694920].
Hirayama M. Psychological care for the bereaved. Psychiatry Clin Neurosci. 95;49(Suppl 1):S135-7. [Rec#: 3246] Exclude at abstract screening: Title Only. [pmid: 9179958].
Hirose H, Ittetu T, Aoki Y. Aiming at establishment of “palliative day care”--attempt at providing an outpatient salon for cancer patients in the Department of Radiology. Radiat Med. 97;15(5):353-9. [Rec#: 3247] Exclude at abstract screening: no outcomes specified.
Hirschfeld RM. The suicidal patient. Hosp Pract (Off Ed) 98;33(10):119–23, 127–8, 131–3 passim. [Rec#: 3249] Exclude at abstract screening: no outcomes specified
Hirst, A. and Sloan, R. Benzodiazepines and related drugs for insomnia in palliative care. Cochrane Database of Systematic Reviews 2002;(4):CD003346. [Rec#: 50496] Exclude at abstract screening: Other symptoms only
Hisnanick J J, Steele L. Home health care for cancer patients. Insights from the American Indian community. J Long Term Home Health Care. 95;14(3):4-10. [Rec#: 12112] Exclude at abstract screening: Title Only. [pmid: 10151651].
Ho D. Role of community mental health nurses for people with dementia. Br J Nurs. 2000;9(15):986-91. [Rec#: 32352] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11276646].
Hobbs F D, Kenkre J E, Roalfe A K, Davis R C, Hare R, Davies M K. Impact of heart failure and left ventricular systolic dysfunction on quality of life: a cross-sectional study comparing common chronic cardiac and medical disorders and a representative adult population. Eur Heart J 2002;23(23):1867–76. Comment in: Eur Heart J. 2002 Dec;23(23):1806–8. PMID: 12445531. Comment in: Eur Heart J. Sep. 2003;24(18):1700. PMID: 14499236. [Rec#: 32355] Exclude at abstract screening: not about end of life.
Hobbs F D. Primary care physicians: champions of or an impediment to optimal care of the patient with heart failure?. Eur J Heart Fail. 99;1(1):11-5. [Rec#: 50038] Exclude at abstract screening: Title Only. [pmid: 10937973].
Hobbs F D. Unmet need for diagnosis of heart failure: the view from primary care. Heart. 2002;88(Suppl 2):ii9-11. [Rec#: 32354] Exclude at abstract screening: Title Only. [pmid: 12213793].
Hockley J. Psychosocial aspects in palliative care--communicating with the patient and family. Acta Oncol. 2000;39(8):905-10. [Rec#: 3258] Exclude at abstract screening: no outcomes specified. [pmid: 11206995].
Hockley J. Specialist palliative care within the acute hospital setting. Acta Oncol 99;38(4):491–4. Comment in: Acta Oncol. 1999;38(4):403-4. PMID: 10418706. [Rec#: 12129] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Hodges M O, Tolle S W, Stocking C, Cassel C K. Tube feeding. Internists' attitudes regarding ethical obligations. Arch Intern Med. 94;154(9):1013-20. [Rec#: 32360] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Hodson M E. Treatment of cystic fibrosis in the adult. Respiration. 2000;67(6):595-607. [Rec#: 3263] Exclude at abstract screening: not about end of life. [pmid: 11124641].
Hoefler J M. Making decisions about tube feeding for severely demented patients at the end of life: clinical, legal, and ethical considerations. Death Stud. 2000;24(3):233-54. [Rec#: 12135] Exclude at abstract screening: useful only for background. [pmid: 11010629].
Hoffman H G, Patterson D R, Carrougher G J, Sharar S R. Effectiveness of virtual reality-based pain control with multiple treatments. Clin J Pain. 2001;17(3):229-35. [Rec#: 3268] Exclude at abstract screening: not about end of life. [pmid: 11587113].
Hofhuis J, Hautvast J L, Schrijvers A J, Bakker J. Quality of life on admission to the intensive care: can we query the relatives?. Intensive Care Med. 2003;29(6):974-9. [Rec#: 41528] Exclude at abstract screening: not about end of life. [pmid: 12734653].
Hofmann M, Rosler A, Schwarz W, Muller-Spahn F, Krauchi K, Hock C, Seifritz E. Interactive computer-training as a therapeutic tool in Alzheimer's disease. Compr Psychiatry. 2003;44(3):213-9. [Rec#: 32369] Exclude at abstract screening: not about end of life. [pmid: 12764709].
Hogan C, Lunney J, Gabel J, Lynn J. Medicare beneficiaries' costs of care in the last year of life. Health Aff (Millwood). 2001;20(4):188-95. [Rec#: 3274] Exclude at abstract screening: Title Only. [pmid: 11463076].
Hogan D B, Ebly E M. Complementary medicine use in a dementia clinic population. Alzheimer Dis Assoc Disord. 96;10(2):63-7. [Rec#: 32370] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Hohenleitner R. Critical care nurses' role in code status discussion. Dimens Crit Care Nurs. 2002;21(4):140-3. [Rec#: 3279] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12134119].
Holden C M. Nutrition and hydration in the terminally ill cancer patient: the nurse's role in helping patients and families cope. Hosp J. 93;9(23):15-35. [Rec#: 12148] Exclude at abstract screening: useful only for background.
Holden U. Dementia in acute units: confusion. Nurs Stand. 95;9(17):37-9. [Rec#: 32378] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Holland J C, Kash K M, Passik S, Gronert M K, Sison A, Lederberg M, Russak S M, Baider L, Fox B. A brief spiritual beliefs inventory for use in quality of life research in life-threatening illness. Psychooncology. 98;7(6):460-9. [Rec#: 41532] Exclude at abstract screening: Observational study.
Holland J C, Passik S, Kash K M, Russak S M, Gronert M K, Sison A, Lederberg M, Fox B, Baider L. The role of religious and spiritual beliefs in coping with malignant melanoma. Psycho-Oncology. 99;8(1):14-26. [Rec#: 50497] Exclude at abstract screening: not about end of life.
Hollen C J, Hollen C W, Stolte K. Hospice and hospital oncology unit nurses: a comparative survey of knowledge and attitudes about cancer pain. Oncol Nurs Forum. 2000;27(10):1593-9. [Rec#: 3289] Exclude at abstract screening: Other topic only. [pmid: 11103378].
Hollen P J, Gralla R J. Comparison of instruments for measuring quality of life in patients with lung cancer. Semin Oncol. 96;23(2 Suppl 5):31-40. [Rec#: 32380] Exclude at abstract screening: not about end of life.
Hollen P J, Gralla R J, Kris M G, Cox C. Quality of life during clinical trials: conceptual model for the Lung Cancer Symptom Scale (LCSS). Support Care Cancer. 94;2(4):213-22. [Rec#: 32382] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Holley J L. A single-center review of the death notification form: discontinuing dialysis before death is not a surrogate for withdrawal from dialysis. Am J Kidney Dis. 2002;40(3):525-30. [Rec#: 41534] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 12200804].
Hollins S, Esterhuyzen A. Bereavement and grief in adults with learning disabilities. Br J Psychiatry. 97;170:497-501. [Rec#: 3293] Exclude at abstract screening: not about end of life. [pmid: 9330012].
Holloran SD, Starkey GW, Burke PA, Steele G Jr, and Forse RA. An educational intervention in the surgical intensive care unit to improve ethical decisions. Surgery 95;118(2):294–8; discussion 298–9. [Rec#: 12158] Exclude at abstract screening: outcome unrelated to pts/family/non-prof
Holman C, Jackson S. A team education project: an evaluation of a collaborative education and practice development in a continuing care unit for older people. Nurse Educ Today. 2001;21(2):97-103. [Rec#: 3294] Exclude at abstract screening: no outcomes specified. [pmid: 11170795].
Holman WL, Davies JE, Rayburn BK, McGiffin DC, Foley BA, Benza RL, Bourge RC, Blood P, and Kirklin JK. Treatment of end-stage heart disease with outpatient ventricular assist devices. Ann Thorac Surg 2002;73(5):1489–93; discussion 1493–4. [Rec#: 50039] Exclude at abstract screening: Title Only
Holst D P, Kaye D, Richardson M, Krum H, Prior D, Aggarwal A, Wolfe R, Bergin P. Improved outcomes from a comprehensive management system for heart failure. Eur J Heart Fail. 2001;3(5):619-25. [Rec#: 32391] Exclude at abstract screening: not about end of life. [pmid: 11595611].
Holst M, Stromberg A, Lindholm M, Uden G, Willenheimer R. Fluid restriction in heart failure patients: is it useful? The design of a prospective, randomised study. Eur J Cardiovasc Nurs. 2003;2(3):237-42. [Rec#: 32392] Exclude at abstract screening: not about end of life. [pmid: 14622632].
Holstein J, Chatellier G, Piette F, Moulias R. Prevalence of associated diseases in different types of dementia among elderly institutionalized patients: analysis of 3447 records. J Am Geriatr Soc 94;42(9):972–7. Comment in: J Am Geriatr Soc. Apr. 1995;43(4):455-6. PMID: 7706642. [Rec#: 32393] Exclude at abstract screening: not about end of life.
Holtom N, Barraclough J. Is the Hospital Anxiety and Depression Scale (HADS) useful in assessing depression in palliative care?. Palliat Med. 2000;14(3):219-20. [Rec#: 3302] Exclude at abstract screening: Title Only. [pmid: 10858831].
Homsi J, Walsh D, Nelson K A, LeGrand S, Davis M. Methylphenidate for depression in hospice practice: a case series. Am J Hosp Palliat Care. 2000;17(6):393-8. [Rec#: 3310] Exclude at abstract screening: Title Only. [pmid: 11886041].
Homsi J, Walsh D, Nelson K A, Sarhill N, Rybicki L, Legrand S B, Davis M P. A phase II study of hydrocodone for cough in advanced cancer. Am J Hosp Palliat Care. 2002;19(1):49-56. [Rec#: 3312] Exclude at abstract screening: Observational study. [pmid: 12171425].
Homsi J, Walsh D, Panta R, Lagman R, Nelson K A, Longworth D L. Infectious complications of advanced cancer. Support Care Cancer. 2000;8(6):487-92. [Rec#: 3313] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11094994].
Honeybun J, Johnston M, Tookman A. The impact of a death on fellow hospice patients. Br J Med Psychol. 92;65(Pt 1):67-72. [Rec#: 3315] Exclude at abstract screening: Observational study. [pmid: 1571309].
Hontela S, Reddon J R. Medical investigation in the elderly: the geriatrician's dilemma. J Palliat Care. 93;9(3):50-2. [Rec#: 3319] Exclude at abstract screening: Title Only. [pmid: 8271110].
Hoogstraten J, Koele P, van der Laan J. Templer's Death Anxiety Scale revisited: the Dutch version. Percept Mot Skills. 98;87(3 Pt 2):1259-64. [Rec#: 3321] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Hoover D R, Crystal S, Kumar R, Sambamoorthi U, Cantor J C. Medical expenditures during the last year of life: findings from the 1992-1996 Medicare current beneficiary survey. Health Serv Res. 2002;37(6):1625-42. [Rec#: 3324] Exclude at abstract screening: Title Only. [pmid: 12546289]. [pmcid: 1464043].
Hopkins K F, Tookman A J. Rehabilitation and specialist palliative care. Int J Palliat Nurs. 2000;6(3):123-30. [Rec#: 12171] Exclude at abstract screening: no outcomes specified. [pmid: 11051948].
Hopkins V, Sutton L. Dementia in acute units: communication. Nurs Stand. 94;9(4):25-6. [Rec#: 32407] Exclude at abstract screening: no outcomes specified. [pmid: 7999549].
Hopkinson J B, Hallett C E. Patients' perceptions of hospice day care: a phenomenological study. Int J Nurs Stud. 2001;38(1):117-25. [Rec#: 3328] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11137729].
Hopkinson J B, Hallett C E, Luker K A. Caring for dying people in hospital. J Adv Nurs. 2003;44(5):525-33. [Rec#: 3329] Exclude at abstract screening: Study Design - Qualitative. [pmid: 14651701].
Hopkinson J B. The hidden benefit: the supportive function of the nursing handover for qualified nurses caring for dying people in hospital. J Clin Nurs. 2002;11(2):168-75. [Rec#: 12175] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11903716].
Hopmeyer E, Werk A. A comparative study of family bereavement groups. Death Stud. 94;18(3):243-56. [Rec#: 3330] Exclude at abstract screening: Study Design - Qualitative. [pmid: 10135136].
Hopp F P, Duffy S A. Racial variations in end-of-life care. J Am Geriatr Soc. 2000;48(6):658-63. [Rec#: 3331] Exclude at abstract screening: Observational study. [pmid: 10855602].
Hopp F P. Preferences for surrogate decision makers, informal communication, and advance directives among community-dwelling elders: results from a national study. Gerontologist. 2000;40(4):449-57. [Rec#: 50498] Exclude at abstract screening: Study Design - Unclear. [pmid: 10961034].
Hopwood P, Stephens R J. Symptoms at presentation for treatment in patients with lung cancer: implications for the evaluation of palliative treatment. The Medical Research Council (MRC) Lung Cancer Working Party. Br J Cancer. 95;71(3):633-6. [Rec#: 3333] Exclude at abstract screening: useful only for background.
Hopwood P, Thatcher N. Preliminary experience with quality of life evaluation in patients with lung cancer. Oncology (Huntingt). 90;4(5):158-62. discussion 171. [Rec#: 32414] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Hopwood P. Quality of life assessment in chemotherapy trials for non-small cell lung cancer: are theory and practice significantly different?. Semin Oncol. 96;23(5 Suppl 10):60-4. [Rec#: 32408] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Hordern A J, Currow D C. A patient-centred approach to sexuality in the face of life-limiting illness. Med J Aust. 2003;179(6 Suppl):S8-11. [Rec#: 3336] Exclude at abstract screening: no outcomes specified. [pmid: 12964926].
Horowitz C R, Rein S B, Leventhal H. A story of maladies, misconceptions and mishaps: effective management of heart failure. Soc Sci Med. 2004;58(3):631-43. [Rec#: 32416] Exclude at abstract screening: Observational study. [pmid: 14652059].
Horowitz M, Sonneborn D, Sugahara C, Maercker A. Self-regard: a new measure. Am J Psychiatry. 96;153(3):382-5. [Rec#: 3341] Exclude at abstract screening: not about end of life. [pmid: 8610826].
Horowitz M J, Siegel B, Holen A, Bonanno G A, Milbrath C, Stinson C H. Diagnostic criteria for complicated grief disorder. Am J Psychiatry 97;154(7):904–10. Comment in: Am J Psychiatry. Sep. 1998;155(9):1305-6. PMID: 9734570. [Rec#: 3344] Exclude at abstract screening: Bereavement only.
Horton S. Imparting the knowledge of impending death to the intensive care patient who is unable to respond. Nurs Crit Care. 96;1(5):250-3. [Rec#: 12186] Exclude at abstract screening: no outcomes specified.
Horton S. Support for bereaved relatives in ICU. Prof Nurse. 95;10(9):568-70. [Rec#: 3348] Exclude at abstract screening: no outcomes specified. [pmid: 7604054].
Hosaka T, Sugiyama Y. Structured intervention in family caregivers of the demented elderly and changes in their immune function. Psychiatry Clin Neurosci. 2003;57(2):147-51. [Rec#: 50910] In abstract review process. [pmid: 12667160].
Hoskins L M, Walton-Moss B, Clark H M, Schroeder M A, Thiel L Sr. Predictors of hospital readmission among the elderly with congestive heart failure. Home Healthc Nurse. 99;17(6):373-81. [Rec#: 50041] Exclude at abstract screening: not about end of life.
Hospitals cut CHF readmissions with benchmarking. Data Strateg Benchmarks 2000;4(4):49–53. [Rec#: 50042] Exclude at abstract screening: Title Only
Houghton A R, Cowley A J. Managing heart failure in a specialist clinic. J R Coll Physicians Lond. 97;31(3):276-9. [Rec#: 32426] Exclude at abstract screening: Study Design - Unclear. [pmid: 9192328].
Houghton A R, Harrison M, Cowley A J, Hampton J R. Assessing exercise capacity quality of life and haemodynamics in heart failure: do the tests tell us the same thing?. Eur J Heart Fail. 2002;4(3):289-95. [Rec#: 32428] Exclude at abstract screening: not about end of life. [pmid: 12034154].
Houldin A D, McCorkle R, Lowery B J. Relaxation training and psychoimmunological status of bereaved spouses. A pilot study. Cancer Nurs. 93;16(1):47-52. [Rec#: 3360] Exclude at abstract screening: Observational study.
Houston K, Petronis K, Denham K, Kosier M. An interdisciplinary approach to inpatient palliative care. Continuum. 95;15(6):9-16. [Rec#: 12206] Exclude at abstract screening: Title Only. [pmid: 10155855].
Houston S J, Kendall J A. Psychosocial implications of lung cancer. Nurs Clin North Am. 92;27(3):681-90. [Rec#: 32430] Exclude at abstract screening: no outcomes specified. [pmid: 1508739].
Houtepen R, Hendrikx D. Nurses and the virtues of dealing with existential questions in terminal palliative care. Nurs Ethics. 2003;10(4):377-87. [Rec#: 12207] Exclude at abstract screening: useful only for background. [pmid: 12875535].
Howarth G, Willison K B. Preventing crises in palliative care in the home. Role of family physicians and nurses. Can Fam Physician. 95;41:439-45. [Rec#: 12217] Exclude at abstract screening: no outcomes specified.
Howdyshell C. Complementary therapy: aromatherapy with massage for geriatric and hospice care--a call for an holistic approach. Hosp J. 98;13(3):69-75. [Rec#: 3368] Exclude at abstract screening: not about end of life.
Howe EG. Caring for patients with dementia: an indication for “emotional communism”. J Clin Ethics 98;9(1):3–11. Comment on: J Clin Ethics. 1998 Spring;9(1):23–34. PMID: 9598430. Comment on: J Clin Ethics. 1998 Spring;9(1):71–80. PMID: 9598435. [Rec#: 32433] Exclude at abstract screening: Title Only
Howe E G. Challenging patients' personal, cultural, and religious beliefs. J Clin Ethics. 2002;13(4):259-73. [Rec#: 12218] Exclude at abstract screening: Title Only. [pmid: 12793318].
Howell D, Fitch M I, Deane K A. Impact of ovarian cancer perceived by women. Cancer Nurs 2003;26(1):1–9. Comment in: Evid Based Nurs. Oct. 2003;6(4):126-7. PMID: 14577409. [Rec#: 3370] Exclude at abstract screening: not about end of life.
Howland S C. Managing the Alzheimer's patient. Emerg Med Serv. 2000;29(9):89-92. [Rec#: 32435] Exclude at abstract screening: Title Only. [pmid: 11143041].
Hoyer T. Hospice and future of end-of-life care: approaches and funding ideas. J Palliat Med. 2002;5(2):259-62. [Rec#: 12221] Exclude at abstract screening: Title Only. [pmid: 12006227].
Hoyt RE and Bowling LS. Reducing readmissions for congestive heart failure. Am Fam Physician 2001;63(8):1593–8. Comment in: Am Fam Physician. 2001 Apr 15;63(8):1483–4, 1486. PMID: 11327425. Erratum in: Am Fam Physician 2002 Jan 15;65(2):172. [Rec#: 32436] Exclude at abstract screening: no outcomes specified
Hsieh M, Auble T E, Yealy D M. Evidence-based emergency medicine. Predicting the future: can this patient with acute congestive heart failure be safely discharged from the emergency department?. Ann Emerg Med. 2002;39(2):181-9. [Rec#: 32439] Exclude at abstract screening: Title Only. [pmid: 11823774].
Hsu I. Optimal management of heart failure. J Am Pharm Assoc (Wash). 96;NS36(2):92-107. [Rec#: 32440] Exclude at abstract screening: Title Only. [pmid: 8742007].
Huang J, Boyd C, Tyldesley S, Zhang-Salomons J, Groome P A, Mackillop W J. Time spent in hospital in the last six months of life in patients who died of cancer in Ontario. J Clin Oncol. 2002;20(6):1584-92. [Rec#: 3381] Exclude at abstract screening: useful only for background. [pmid: 11896108].
Huang J, Zhou S, Groome P, Tyldesley S, Zhang-Solomans J, Mackillop W J. Factors affecting the use of palliative radiotherapy in Ontario. J Clin Oncol. 2001;19(1):137-44. [Rec#: 3382] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 11134206].
Huber R, Gibson J W. New evidence for anticipatory grief. Hosp J. 90;6(1):49-67. [Rec#: 3387] Exclude at abstract screening: Study Design - Unclear. [pmid: 2379923].
Hudson J E. A profile of Canadian hospital-based palliative care. Am J Hosp Palliat Care. 90;7(3):35-41. [Rec#: 12229] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 2361111].
Hudson P, Aranda S, McMurray N. Intervention development for enhanced lay palliative caregiver support - the use of focus groups. Eur J Cancer Care (Engl). 2002;11(4):262-70. [Rec#: 3391] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12492463].
Hudson P. Home-based support for palliative care families: challenges and recommendations. Med J Aust. 2003;179(6 Suppl):S35-7. [Rec#: 12232] Exclude at abstract screening: no outcomes specified. [pmid: 12964935].
Hudson P. Positive aspects and challenges associated with caring for a dying relative at home. Int J Palliat Nurs. 2004;10(2):58-65. [Rec#: 3390] Exclude at abstract screening: Study Design - Qualitative. [pmid: 15039608].
Hudson P. The experience of research participation for family caregivers of palliative care cancer patients. Int J Palliat Nurs. 2003;9(3):120-3. [Rec#: 12230] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12682574].
Huffman J L, Dunn G P. The paradox of hydration in advanced terminal illness. J Am Coll Surg. 2002;194(6):835-9. [Rec#: 12237] Exclude at abstract screening: Title Only. [pmid: 12081075].
Hughes A, Wilcock A, Corcoran R, Lucas V, King A. Audit of three antimuscarinic drugs for managing retained secretions. Palliat Med. 2000;14(3):221-2. [Rec#: 12239] Exclude at abstract screening: Title Only. [pmid: 10858832].
Hughes D L, Singer P A. Family physicians' attitudes toward advance directives. CMAJ. 92;146(11):1937-44. [Rec#: 41569] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 1596842].
Hughes K M, Broznick B A, Hughes M, Miller S L, Gonzalez L 3rd. Providing comprehensive palliative care through organ donation. Transplant Proc. 2001;33(4):2545-8. [Rec#: 12240] Exclude at abstract screening: Title Only. [pmid: 11406244].
Hughes R, Aspinal F, Addington-Hall J, Chidgey J, Drescher U, Dunckley M, Higginson I J. Professionals' views and experiences of using outcome measures in palliative care. Int J Palliat Nurs. 2003;9(6):234-8. [Rec#: 12242] Exclude at abstract screening: useful only for background. [pmid: 12897694].
Hughes R, Higginson I J, Addington-Hall J, Aspinal F, Thompson M, Dunckley M. Project to impROve management of terminal illnEss (PROMOTE). J Interprof Care. 2001;15(4):398-9. [Rec#: 12243] Exclude at abstract screening: Title Only. [pmid: 11725586].
Huguier M, Houry S, Lacaine F. Is the follow-up of patients operated on for gastric carcinoma of benefit to the patient?. Hepatogastroenterology. 92;39(1):14-6. [Rec#: 3405] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Huijer M, Widdershoven G. Desires in palliative medicine. Five models of the physician-patient interaction on palliative treatments related to Hellenistic therapies of desires. Ethical Theory Moral Pract. 2001;4(2):143-59. [Rec#: 3408] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 15015526].
Hull M M. Coping strategies of family caregivers in hospice homecare. Oncol Nurs Forum. 92;19(8):1179-87. [Rec#: 3411] Exclude at abstract screening: Observational study. [pmid: 1408959].
Hull M M. Hospice nurses. Caring support for caregiving families. Cancer Nurs. 91;14(2):63-70. [Rec#: 3412] Exclude at abstract screening: Study Design - Qualitative. [pmid: 2044063].
Hull M M. Sources of stress for hospice caregiving families. Hosp J. 90;6(2):29-54. [Rec#: 3413] Exclude at abstract screening: Study Design - Qualitative. [pmid: 2401469].
Hulsman R L, Ros W J, Winnubst J A, Bensing J M. Teaching clinically experienced physicians communication skills. A review of evaluation studies. Med Educ. 99;33(9):655-68. [Rec#: 50136] Exclude at abstract screening: useful only for background.
Humana CHF program cuts costs admissions. Healthc Benchmarks 98;5(12):173–5. [Rec#: 32460] Exclude at abstract screening: not about end of life
Humble C G, Samet J M, Skipper B E. Comparison of self- and surrogate-reported dietary information. Am J Epidemiol. 84;119(1):86-98. [Rec#: 50871] Exclude at abstract screening: not about end of life. [pmid: 6691339].
Hume SK. Support in a time of need. The team approach at Mercy Medical Hospice addresses medical, emotional, and spiritual needs. Health Prog 91;72(7):40–5, 54. [Rec#: 12251] Exclude at abstract screening: outcome unrelated to pts/family/non-prof
Hunsucker S C, Frank D I, Flannery J. Meeting the needs of rural families during critical illness: the APN's role. Dimens Crit Care Nurs. 99;18(3):24-32. [Rec#: 41579] Exclude at abstract screening: not about end of life.
Hunt J, Cobb M, Keeley V L, Ahmedzai S H. The quality of spiritual care--developing a standard. Int J Palliat Nurs. 2003;9(5):208-15. [Rec#: 12252] Exclude at abstract screening: Study Design - Unclear. [pmid: 12819598].
Hunt M. Being friendly and informal: reflected in nurses', terminally ill patients' and relatives' conversations at home. J Adv Nurs. 91;16(8):929-38. [Rec#: 41584] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Hunt R, McCaul K. A population-based study of the coverage of cancer patients by hospice services. Palliat Med. 96;10(1):5-12. [Rec#: 3424] Exclude at abstract screening: Other topic only. [pmid: 8821183].
Hunt R, McCaul K. Coverage of cancer patients by hospice services, South Australia, 1990 to 1993. Aust N Z J Public Health. 98;22(1):45-8. [Rec#: 3423] In abstract review process. [pmid: 9599851].
Hunt R, Bonett A, Roder D. Trends in the terminal care of cancer patients: South Australia, 1981-1990. Aust N Z J Med 93;23(3):245–51. Comment in: Aust N Z J Med. Jun. 1993;23(3):239-41. PMID: 7688952. [Rec#: 3421] Exclude at abstract screening: useful only for background.
Hunt R W, Bond M J, Groth R K, King P M. Place of death in South Australia. Patterns from 1910 to 1987. Med J Aust. 91;155(8):549-53. [Rec#: 12257] Exclude at abstract screening: data older than 1990. [pmid: 1943936].
Hunt R W, Fazekas B S, Luke C G, Priest K R, Roder D M. The coverage of cancer patients by designated palliative services: a population-based study, South Australia, 1999. Palliat Med. 2002;16(5):403-9. [Rec#: 3425] Exclude at abstract screening: Other topic only. [pmid: 12380658].
Hunt R W, Radford A J, Maddocks I, Dunsmore E, Badcock K A. The community care of terminally ill patients. Aust Fam Physician. 90;19(12):1835-41. [Rec#: 12258] Exclude at abstract screening: not about end of life. [pmid: 2275665].
Hunt S A, Baker D W, Chin M H, Cinquegrani M P, Feldman A M, Francis G S, Ganiats T G, Goldstein S, Gregoratos G, Jessup M L, Noble R J, Packer M, Silver M A, Stevenson L W, Gibbons R J, Antman E M, Alpert J S, Faxon D P, Fuster V, Jacobs A K, Hiratzka L F, Russell R O, Smith S C Jr. American College of Cardiology/American Heart Association. ACC/AHA guidelines for the evaluation and management of chronic heart failure in the adult: executive summary. A report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee to revise the 1995 Guidelines for the Evaluation and Management of Heart Failure). J Am Coll Cardiol. 2001;38(7):2101-13. [Rec#: 32466] Exclude at abstract screening: not about end of life. [pmid: 11738322].
Hunt S A, Baker D W, Chin M H, Cinquegrani M P, Feldmanmd A M, Francis G S, Ganiats T G, Goldstein S, Gregoratos G, Jessup M L, Noble R J, Packer M, Silver M A, Stevenson L W, Gibbons R J, Antman E M, Alpert J S, Faxon D P, Fuster V, Gregoratos G, Jacobs A K, Hiratzka L F, Russell R O, Smith S C Jr. American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee to Revise the 1995 Guidelines for the Evaluation and Management of Heart Failure), International Society for Heart and Lung Transplantation, Heart Failure Society of America. ACC/AHA Guidelines for the Evaluation and Management of Chronic Heart Failure in the Adult: Executive Summary A Report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee to Revise the 1995 Guidelines for the Evaluation and Management of Heart Failure): Developed in Collaboration With the International Society for Heart and Lung Transplantation; Endorsed by the Heart Failure Society of America. Circulation. 2001;104(24):2996-3007. [Rec#: 32467] Exclude at abstract screening: not about end of life. [pmid: 11739319].
Hunt S M, McKenna S P, McEwen J, Williams J, Papp E. The Nottingham Health Profile: subjective health status and medical consultations. Soc Sci Med [A]. 81;15(3 Pt 1):221-9. [Rec#: 50872] Exclude at abstract screening: not about end of life.
Hunter K A, Florio E R, Langberg R G. Pharmaceutical care for home-dwelling elderly persons: a determination of need and program description. Gerontologist. 96;36(4):543-8. [Rec#: 41586] Exclude at abstract screening: not about end of life.
Hunter R, McGill L, Bosanquet N, Johnson N. Alzheimer's disease in the United Kingdom: developing patient and carer support strategies to encourage care in the community. Qual Health Care. 97;6(3):146-52. [Rec#: 41587] Exclude at abstract screening: no outcomes specified.
Hupcey J E, Zimmerman H E. The need to know: experiences of critically ill patients. Am J Crit Care. 2000;9(3):192-8. [Rec#: 41591] Exclude at abstract screening: not about end of life. [pmid: 10800605].
Hupcey J E. Feeling safe: the psychosocial needs of ICU patients. J Nurs Scholarsh. 2000;32(4):361-7. [Rec#: 41589] Exclude at abstract screening: not about end of life. [pmid: 11140200].
Hupcey J E. The meaning of social support for the critically ill patient. Intensive Crit Care Nurs. 2001;17(4):206-12. [Rec#: 41590] Exclude at abstract screening: not about end of life. [pmid: 11868728].
Huppert F A, Garcia A W. Qualitative differences in psychiatric symptoms between high risk groups assessed on a screening test (GHQ-30). Soc Psychiatry Psychiatr Epidemiol. 91;26(6):252-8. [Rec#: 41592] Exclude at abstract screening: not about end of life.
Hurley A C, Bottino R, Volicer L. Nursing role in advance proxy planning for Alzheimer patients. Caring. 94;13(8):72-6. [Rec#: 3435] Exclude at abstract screening: Study Design - Unclear. [pmid: 10171933].
Hurley A C, Volicer B, Mahoney M A, Volicer L. Palliative fever management in Alzheimer patients. quality plus fiscal responsibility. ANS Adv Nurs Sci. 93;16(1):21-32. [Rec#: 3436] Exclude at abstract screening: Study Design - Unclear.
Hurley AC, Volicer BJ, and Volicer L. Effect of fever-management strategy on the progression of dementia of the Alzheimer type. Alzheimer Dis Assoc Disord 96;10(1):5–10. Comment in: Alzheimer Dis Assoc Disord. 1996 Spring;10(1):3–4. PMID: 8919490. [Rec#: 3437] Exclude at abstract screening: outcome unrelated to pts/family/non-prof
Hurley A C, Volicer L, Rempusheski V F, Fry S T. Reaching consensus: the process of recommending treatment decisions for Alzheimer's patients. ANS Adv Nurs Sci. 95;18(2):33-43. [Rec#: 12262] Exclude at abstract screening: Study Design - Qualitative.
Hurley A C, Volicer L, Blasi Z V. End-of-life care for patients with advanced dementia. JAMA. 2000;284(19):2449-50. [Rec#: 50501] Exclude at abstract screening: Title Only. [pmid: 11074773].
Hurny C, Bernhard J, Joss R, Schatzmann E, Cavalli F, Brunner K, Alberto P, Senn H J, Metzger U. “Fatigue and malaise” as a quality-of-life indicator in small-cell lung cancer patients. The Swiss Group for Clinical Cancer Research (SAKK). Support Care Cancer 93;1(6):316–20. Comment in: Support Care Cancer. Nov. 1993;1(6):285-6. PMID: 8156244 [Rec#: 32468] Exclude at abstract screening: not about end of life.
Hurny C, Bernhard J, Joss R, Willems Y, Cavalli F, Kiser J, Brunner K, Favre S, Alberto P, Glaus A, et al. Feasibility of quality of life assessment in a randomized phase III trial of small cell lung cancer--a lesson from the real world--the Swiss Group for Clinical Cancer Research SAKK. Ann Oncol 92;3(10):825–31. Comment in: Ann Oncol. Jun. 1993;4(6):520. PMID: 8353096. [Rec#: 32469] Exclude at abstract screening: not about end of life.
Husaini B A, Sherkat D E, Moonis M, Levine R, Holzer C, Cain V A. Racial differences in the diagnosis of dementia and in its effects on the use and costs of health care services. Psychiatr Serv 2003;54(1):92–6. Comment in: Psychiatr Serv. Apr. 2003;54(4):574-5. author reply 575. PMID: 12663852. [Rec#: 32471] Exclude at abstract screening: not about end of life.
Huskamp H A, Buntin M B, Wang V, Newhouse J P. Providing care at the end of life: do Medicare rules impede good care?. Health Aff (Millwood). 2001;20(3):204-11. [Rec#: 12267] Exclude at abstract screening: Title Only. [pmid: 11585168].
Hutchison R R, Quartaro E G. High-risk vulnerable populations and volunteers: a model of education and service collaboration. J Community Health Nurs. 95;12(2):111-9. [Rec#: 41596] Exclude at abstract screening: no outcomes specified.
Hutt E, Frederickson E, Ecord M, Kramer A M. Associations among processes and outcomes of care for Medicare nursing home residents with acute heart failure. J Am Med Dir Assoc 2003;4(4):195–9. Comment in: J Am Med Dir Assoc. Jul-Aug. 2003;4(4):220-1. PMID: 12855917. [Rec#: 41597] Exclude at abstract screening: Other symptoms only.
Hutt E, Frederickson E, Ecord M, Kramer A M. Associations among processes and outcomes of care for Medicare nursing home residents with acute heart failure. J Am Med Dir Assoc 2003;4(4):195–9. Comment in: J Am Med Dir Assoc. Jul-Aug. 2003;4(4):220-1. PMID: 12855917. [Rec#: 50043] Exclude at abstract screening: Duplicate already in the flow.
Hwang J P, Tsai S J, Yang C H, Liu K M, Lirng J F. Persecutory delusions in dementia. J Clin Psychiatry. 99;60(8):550-3. [Rec#: 32482] Exclude at abstract screening: not about end of life. [pmid: 10485638].
Hybels C F, Blazer D G, Pieper C F. Toward a threshold for subthreshold depression: an analysis of correlates of depression by severity of symptoms using data from an elderly community sample. Gerontologist. 2001;41(3):357-65. [Rec#: 41600] Exclude at abstract screening: not about end of life. [pmid: 11405433].
Hyman R B, Bulkin W. Physician reported incentives and disincentives for referring patients to hospice. Hosp J. 90;6(4):39-64. [Rec#: 3450] Exclude at abstract screening: Study Design - Qualitative. [pmid: 2088998].
Hyodo I, Eguchi K, Takigawa N, Segawa Y, Hosokawa Y, Kamejima K, Inoue R. Psychological impact of informed consent in hospitalized cancer patients. A sequential study of anxiety and depression using the hospital anxiety and depression scale. Support Care Cancer. 99;7(6):396-9. [Rec#: 32485] Exclude at abstract screening: not about end of life.
Hyrkas K, Kaunonen M, Paunonen M. Recovering from the death of a spouse. J Adv Nurs. 97;25(4):775-9. [Rec#: 3454] Exclude at abstract screening: Bereavement only. [pmid: 9104674].
IASLC workshop on improving quality of life and the supportive management of patients with lung cancer. Cape Town, South Africa 9–11 September 1993. Lung Cancer 94;10(5–6):375–80. [Rec#: 32488] Exclude at abstract screening: Title Only
Ibrahim S A, Kwoh C K, Harper D L, Baker D W. Racial differences in the utilization of oral anticoagulant therapy in heart failure: a study of elderly hospitalized patients. J Gen Intern Med. 2000;15(2):134-7. [Rec#: 32490] Exclude at abstract screening: not about end of life. [pmid: 10672118]. [pmcid: 1495339].
Ickovics J R, Druley J A, Morrill A C, Grigorenko E, Rodin J. “A grief observed”: the experience of HIV-related illness and death among women in a clinic-based sample in New Haven, Connecticut. J Consult Clin Psychol. 98;66(6):958-66. [Rec#: 3458] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Idler E L, Kasl S V, Hays J C. Patterns of religious practice and belief in the last year of life. J Gerontol B Psychol Sci Soc Sci. 2001;56(6):S326-34. [Rec#: 3459] Exclude at abstract screening: Other topic only. [pmid: 11682593].
Iezzoni L I, Henderson M G, Bergman A, Drews R E. Purpose of admission and resource use during cancer hospitalizations. Health Care Financ Rev. 91;13(2):29-40. [Rec#: 3460] Exclude at abstract screening: data older than 1990.
Igoe D, Keogh F, McNamara C. A survey of Irish palliative care services. Ir J Med Sci. 97;166(4):206-11. [Rec#: 3461] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 9394066].
Ikonomidis S, Singer P A. Autonomy, liberalism and advance care planning. J Med Ethics. 99;25(6):522-7. [Rec#: 12291] Exclude at abstract screening: not about end of life. [pmid: 10635509].
Iliescu E A, Coo H, McMurray M H, Meers C L, Quinn M M, Singer M A, Hopman W M. Quality of sleep and health-related quality of life in haemodialysis patients. Nephrol Dial Transplant 2003;18(1):126–32. Comment in: Nephrol Dial Transplant. Sep. 2003;18(9):1947-8. author reply 1948. PMID: 12937259. [Rec#: 32509] Exclude at abstract screening: not about end of life.
In your practice, what experiences of patients and family members could be classified as “a good death” or a positive process of dying? J Gerontol Nurs 98;24(7):47–52. [Rec#: 12299] Exclude at abstract screening: Title Only
Incalzi R A, Pedone C, Pahor M, Carosella L, Bernabei R, Carbonin P. GIFA Investigators. Reasons prompting digitalis therapy in the acute care hospital. J Gerontol A Biol Sci Med Sci. 2001;56(6):M361-5. [Rec#: 32518] Exclude at abstract screening: sudden/violent/non-chronic deaths. [pmid: 11382796].
Indridason O S, Coffman C J, Oddone E Z. Is specialty care associated with improved survival of patients with congestive heart failure? Am Heart J 2003;145(2):300–9. Comment in: Am Heart J. Feb. 2003;145(2):209-13. PMID: 12595835. [Rec#: 32521] Exclude at abstract screening: not about end of life.
Infeld D L, Crum G E, Koshuta M A. Characteristics of patients in a long-term care hospice setting. Hosp J. 90;6(4):81-104. [Rec#: 3472] Exclude at abstract screening: not about end of life. [pmid: 2128484].
Ingham J M, Foley K M. Pain and the barriers to its relief at the end of life: a lesson for improving end of life health care. Hosp J. 98;13(12):89-100. [Rec#: 12305] Exclude at abstract screening: useful only for background.
Ingleton C, Faulkner A. Quality assurance in palliative care: some of the problems. Eur J Cancer Care (Engl). 95;4(1):38-44. [Rec#: 12307] Exclude at abstract screening: no outcomes specified. [pmid: 7620653].
Ingleton C, Seymour J E. Analysing qualitative data: examples from two studies of end-of-life care. Int J Palliat Nurs. 2001;7(5):227-33. [Rec#: 12308] Exclude at abstract screening: not about end of life. [pmid: 12148973].
Ingleton C, Skilbeck J, Clark D. Needs assessment for palliative care: three projects compared. Palliat Med. 2001;15(5):398-404. [Rec#: 12309] Exclude at abstract screening: useful only for background. [pmid: 11591091].
Inouye S K, Foreman M D, Mion L C, Katz K H, Cooney L M Jr. Nurses' recognition of delirium and its symptoms: comparison of nurse and researcher ratings. Arch Intern Med. 2001;161(20):2467-73. [Rec#: 32526] Exclude at abstract screening: not about end of life. [pmid: 11700159].
Inpatient intervention slashes risk of re-hospitalization in CHF patients. Dis Manag Advis 2004;10(1):4–6, 1. [Rec#: 50044] Exclude at abstract screening: not about end of life
Inzeo D, Tyson L. Nursing assessment and management of dyspneic patients with lung cancer. Clin J Oncol Nurs. 2003;7(3):332-3. [Rec#: 32529] Exclude at abstract screening: no outcomes specified. [pmid: 12793341].
Ip S P, Leung Y F, Ip C Y, Mak W P. Outcomes of critically ill elderly patients: is high-dependency care for geriatric patients worthwhile? Crit Care Med 99;27(11):2351–7. Comment in: Crit Care Med. Nov. 1999;27(11):2570-1. PMID: 10579283. [Rec#: 41615] Exclude at abstract screening: primarily prognosis or trajectories.
Irvine B. Developments in palliative nursing in and out of the hospital setting. Br J Nurs. 93;2(4):218-24. [Rec#: 12320] Exclude at abstract screening: Non-systematic review. [pmid: 7682116].
Isaksson R, Soderfeldt B, Nederfors T. Oral treatment need and oral treatment intention in a population enrolled in long-term care in nursing homes and home care. Acta Odontol Scand. 2003;61(1):11-8. [Rec#: 41622] Exclude at abstract screening: not about end of life. [pmid: 12635775].
Iserson K V, Stocking C. Standards and limits: emergency physicians' attitude toward prehospital resuscitation. Am J Emerg Med. 93;11(6):592-4. [Rec#: 41624] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Iserson K V. Foregoing prehospital care: should ambulance staff always resuscitate? J Med Ethics 91;17(1):19–24. Comment in: J Med Ethics. Mar. 1991;17(1):3-4. PMID: 2033627. [Rec#: 41623] Exclude at abstract screening: no outcomes specified.
Ishii H, Tokunaga Y, Kawatani D, Nishizono M. Clinical features of pathological grief reaction in elderly patients. Psychiatry Clin Neurosci. 98;52(6):571-6. [Rec#: 3492] Exclude at abstract screening: Observational study.
Ishizaki J, Meguro K, Ohe K, Kimura E, Tsuchiya E, Ishii H, Sekita Y, Yamadori A. Therapeutic psychosocial intervention for elderly subjects with very mild Alzheimer disease in a community: the tajiri project. Alzheimer Dis Assoc Disord. 2002;16(4):261-9. [Rec#: 32557] Notes: “EXCLUDE: Location, non-Western”. [pmid: 12468901].
Iverson R J. The silent crisis: women and the need for long-term care insurance. Part 2. Caring. 2003;22(11):32-6. [Rec#: 41628] Exclude at abstract screening: no outcomes specified. [pmid: 14658202].
Iwase M, Takemi T, Manabe M, Nagumo M. Hypercalcemic complication in patients with oral squamous cell carcinoma. Int J Oral Maxillofac Surg. 2003;32(2):174-80. [Rec#: 3504] Exclude at abstract screening: not about end of life. [pmid: 12729778].
Iwashyna T J, Chang V W. Racial and ethnic differences in place of death: United States, 1993. J Am Geriatr Soc. 2002;50(6):1113-7. [Rec#: 41629] Exclude at abstract screening: Other topic only. [pmid: 12110074].
Iwashyna T J, Zhang J X, Christakis N A. Disease-specific patterns of hospice and related healthcare use in an incidence cohort of seriously ill elderly patients. J Palliat Med. 2002;5(4):531-8. [Rec#: 3506] Exclude at abstract screening: useful only for background. [pmid: 12243677].
Iwashyna T J, Chang V W. Racial and ethnic differences in place od death: United States, 1993. Journal of the American Geriatrics Society. 2002;50:1113-1117. [Rec#: 50503] Exclude at abstract screening: Title Only. [pmid: 12110074].
Izquierdo-Porrera A M, Trelis-Navarro J, Gomez-Batiste X. Predicting place of death of elderly cancer patients followed by a palliative care unit. J Pain Symptom Manage. 2001;21(6):481-90. [Rec#: 3509] Exclude at abstract screening: Other topic only. [pmid: 11397606].
Jaarsma T, Leventhal M. End-of-life issues in cardiac patients and their families. Eur J Cardiovasc Nurs. 2002;1(4):223-5. [Rec#: 12334] Exclude at abstract screening: Title Only. [pmid: 14622651].
Jaarsma T, Stromberg A. Heart failure clinics in Europe. Prog Cardiovasc Nurs. 2000;15(2):67-8. [Rec#: 32584] Exclude at abstract screening: Title Only. [pmid: 10804598].
Jaarsma T, van Veldhuisen D J. The optimal “dose” of disease management programs in HF. J Am Coll Cardiol. 2002;39(12):2080-1. [Rec#: 50046] Exclude at abstract screening: not about end of life. [pmid: 12084613].
Jaarsma T, Halfens R, Abu-Saad H H, Dracup K, Stappers J, van Ree J. Quality of life in older patients with systolic and diastolic heart failure. Eur J Heart Fail. 99;1(2):151-60. [Rec#: 32581] Exclude at abstract screening: not about end of life.
Jaarsma T, Halfens R J, Huijer-Abu Saad H. Readmission of older heart failure patients. Prog Cardiovasc Nurs. 96;11(1):15-20. [Rec#: 50045] Exclude at abstract screening: Title Only. [pmid: 8657705].
Jaarsma T, van Veldhuisen D J, van der Wal M H. NHF-COACH multicenter trial in The Netherlands: searching for underlying potentially beneficial mechanisms in nurse led heart failure management. Prog Cardiovasc Nurs. 2002;17(2):96-8. [Rec#: 32585] Exclude at abstract screening: Title Only. [pmid: 11986543].
Jaarsma T. Are women different than men? Aspects of heart failure in special populations: elderly women. Eur J Cardiovasc Nurs. 2002;1(1):29-31. [Rec#: 32577] Exclude at abstract screening: no outcomes specified. [pmid: 14622864].
Jack B, Ellershaw J E, Murphy D. A comparison of cancer patients and nurse specialist's symptom-assessment scores, in an acute hospital. Eur J Oncol Nurs. 2003;7(2):130-1. [Rec#: 12335] Exclude at abstract screening: Title Only. [pmid: 12849566].
Jack B, Oldham J, Williams A. A stakeholder evaluation of the impact of the palliative care clinical nurse specialist upon doctors and nurses, within an acute hospital setting. Palliat Med. 2003;17(3):283-8. [Rec#: 12337] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12725482].
Jack B, Oldham J, Williams A. Do hospital-based palliative care clinical nurse specialists de-skill general staff?. Int J Palliat Nurs. 2002;8(7):336-40. [Rec#: 12336] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12165718].
Jack B A, Gambles M, Murphy D, Ellershaw J E. Nurses' perceptions of the Liverpool Care Pathway for the dying patient in the acute hospital setting. Int J Palliat Nurs. 2003;9(9):375-81. [Rec#: 12338] Exclude at abstract screening: Study Design - Unclear. [pmid: 14593273].
Jack C M, Penny L, Nazar W. Effective palliative care for minority ethnic groups: the role of a liaison worker. Int J Palliat Nurs. 2001;7(8):375-80. [Rec#: 3512] Exclude at abstract screening: no outcomes specified. [pmid: 11951781].
Jack B, Oldham J, Williams A. Impact of the palliative care clinical nurse specialist on patients and relatives: a stakeholder evaluation. European Journal of Oncology Nursing. 2002;6(4):236-42. [Rec#: 50504] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12849583].
Jackson I. A study of bereavement in an intensive therapy unit. Nurs Crit Care. 98;3(3):141-50. [Rec#: 3516] Exclude at abstract screening: Study Design - Unclear. [pmid: 9883175].
Jackson I. Bereavement follow-up service in intensive care. Intensive Crit Care Nurs. 92;8(3):163-8. [Rec#: 12344] Exclude at abstract screening: not about end of life. [pmid: 1330116].
Jackson I. Critical care nurses' perception of a bereavement follow-up service. Intensive Crit Care Nurs. 96;12(1):2-11. [Rec#: 3515] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Jackson J C, Hart R P, Gordon S M, Shintani A, Truman B, May L, Ely E W. Six-month neuropsychological outcome of medical intensive care unit patients. Crit Care Med. 2003;31(4):1226-34. [Rec#: 41632] Exclude at abstract screening: not about end of life. [pmid: 12682497].
Jackson K and Lipman A. Drug therapy for anxiety in palliative care. Cochrane Database Syst Rev 2004;1:CD004596. [Rec#: 3517] Exclude at abstract screening: Study Design - Review/Meta
Jackson L D. The role of medications in treating the behavioural disturbances of dementia sufferers. Perspectives. 95;19(3):9-22. [Rec#: 32586] Exclude at abstract screening: Title Only. [pmid: 7572001].
Jackson M A. Peripheral infusion of Diazemuls. Hosp Med. 2000;61(6):412-6. [Rec#: 3518] Exclude at abstract screening: not about end of life. [pmid: 10962657].
Jackson W C, Tavernier L. Olanzapine for intractable nausea in palliative care patients. J Palliat Med. 2003;6(2):251-5. [Rec#: 3521] Exclude at abstract screening: Observational study. [pmid: 12854942].
Jackson W C. When All Else Is Done: The Challenge of Improving Antemortem Care. Prim Care Companion J Clin Psychiatry. 99;1(5):146-153. [Rec#: 3520] Exclude at abstract screening: no outcomes specified.
Jackson-Siegal JM and Siegal AP. Improving elderly patient outcomes: anticonvulsants in agitation. Geriatrics 2002;57(9):suppl 5–8. [Rec#: 32587] Exclude at abstract screening: Title Only
Jacob M J, Markstein C, Liesse M M, Deckers C. What about odor in terminal cancer?. J Palliat Car. 91;7(4):31-4. [Rec#: 3523] Exclude at abstract screening: no outcomes specified.
Jacob S R, Scandrett-Hibdon S. Mothers grieving the death of a child. Case reports of maternal grief. Nurse Pract. 94;19(7):60-5. [Rec#: 3526] Exclude at abstract screening: Observational study. [pmid: 7936456].
Jacob S R. An analysis of the concept of grief. J Adv Nurs 93;18(11):1787–94. Comment in: J Adv Nurs. May. 1996;23(5):1055-7. PMID: 8732536. [Rec#: 3524] Exclude at abstract screening: not about end of life.
Jacobs J R, Bovasso G B. Early and chronic stress and their relation to breast cancer. Psychol Med 2000;30(3):669–78. Comment in: Psychol Med. Apr. 2001;31(3):565-8. PMID: 11305865. [Rec#: 3528] Exclude at abstract screening: not about end of life.
Jacobs L G, Bonuck K, Burton W, Mulvihill M. Hospital care at the end of life: an institutional assessment. J Pain Symptom Manage. 2002;24(3):291-8. [Rec#: 3531] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12458110].
Jacobs S, Prigerson H. Psychotherapy of traumatic grief: a review of evidence for psychotherapeutic treatments. Death Stud. 2000;24(6):479-95. [Rec#: 3537] Exclude at abstract screening: no outcomes specified. [pmid: 11503665].
Jacobs S, Kasl S, Schaefer C, Ostfeld A. Conscious and unconscious coping with loss. Psychosom Med. 94;56(6):557-63. [Rec#: 3535] Exclude at abstract screening: Bereavement only. [pmid: 7871112].
Jacobs S, Mazure C, Prigerson H. Diagnostic criteria for traumatic grief. Death Stud. 2000;24(3):185-99. [Rec#: 3536] Exclude at abstract screening: not about end of life. [pmid: 11010626].
Jacobson J A, Francis L P, Battin M P, Green G J, Grammes C, VanRiper J, Gully J. Dialogue to action: lessons learned from some family members of deceased patients at an interactive program in seven Utah hospitals. J Clin Ethics. 97;8(4):359-71. [Rec#: 12349] Exclude at abstract screening: Title Only.
Jacox, A., Carr, D. B., Payne, R. Management of Cancer Pain: Clinical Practice Guideline, No. 9. 1994;<25 Page(s)>. [Rec#: 50505] Exclude at abstract screening: Title Only
Jacquelinet C, Burgun A, Djabbour S, Delamarre D, Clerc P, Boutin B, Le Beux P. A contextual coding system for transplantation and end stage diseases. Stud Health Technol Inform. 2003;95:457-62. [Rec#: 12353] Exclude at abstract screening: not about end of life. [pmid: 14664029].
Jadad A R, Browman G P. The WHO analgesic ladder for cancer pain management. Stepping up the quality of its evaluation. JAMA. 95;274(23):1870-3. [Rec#: 50137] Exclude at abstract screening: Study Design - Review/Meta.
James C R, Macleod R D. The problematic nature of education in palliative care. J Palliat Care. 93;9(4):5-10. [Rec#: 12358] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 7510805].
Jamison R N. Comprehensive pretreatment and outcome assessment for chronic opioid therapy in nonmalignant pain. J Pain Symptom Manage. 96;11(4):231-41. [Rec#: 12370] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Jang Y, Haley W E, Small B J, Mortimer J A. The role of mastery and social resources in the associations between disability and depression in later life. Gerontologist. 2002;42(6):807-13. [Rec#: 41643] Exclude at abstract screening: not about end of life. [pmid: 12451162].
Janhonen S, Sarja A. Data analysis method for evaluating dialogic learning. Nurse Educ Today. 2000;20(2):106-15. [Rec#: 41644] Exclude at abstract screening: not about end of life. [pmid: 11148833].
Jansen L A, Sulmasy D P. Proportionality, terminal suffering and the restorative goals of medicine. Theor Med Bioeth. 2002;23(45):321-37. [Rec#: 12377] Exclude at abstract screening: no outcomes specified. [pmid: 12516836].
Janson L J, Sloan J A. Determinants of the grief experience of survivors. J Palliat Care. 91;7(4):51-6. [Rec#: 12378] Exclude at abstract screening: Title Only. [pmid: 1783967].
Janson L K, Dudgeon D, Nelson F, Henteleff P, Balneaves L. Evaluation of an interdisciplinary training program in palliative care: addressing the needs of rural and northern communities. J Palliat Care. 97;13(3):5-12. [Rec#: 12379] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Janssens J P, Krause K H. Pneumonia in the very old. Lancet Infect Dis. 2004;4(2):112-24. [Rec#: 3564] Exclude at abstract screening: no outcomes specified. [pmid: 14871636].
Janssens R, Gordijn B. Clinical trials in palliative care: an ethical evaluation. Patient Educ Couns. 2000;41(1):55-62. [Rec#: 12380] Exclude at abstract screening: not about end of life. [pmid: 10900367].
Janzen W. Long-term care for older adults. The role of the family. J Gerontol Nurs. 2001;27(2):36-43. [Rec#: 41646] Exclude at abstract screening: not about end of life. [pmid: 11915264].
Jarrett N, Payne S, Turner P, Hillier R. ‘Someone to talk to’ and ‘pain control’: what people expect from a specialist palliative care team. Palliat Med. 99;13(2):139-44. [Rec#: 12384] Exclude at abstract screening: Study Design - Qualitative.
Jarrett N J, Payne S A, Wiles R A. Terminally ill patients' and lay-carers' perceptions and experiences of community-based services. J Adv Nurs. 99;29(2):476-83. [Rec#: 3567] Exclude at abstract screening: Study Design - Qualitative.
Jarrett P G, Rockwood K, Carver D, Stolee P, Cosway S. Illness presentation in elderly patients. Arch Intern Med. 95;155(10):1060-4. [Rec#: 41649] Exclude at abstract screening: not about end of life. [pmid: 7748049].
Jarvis H, Burge F I, Scott C A. Evaluating a palliative care program: methodology and limitations. J Palliat Care. 96;12(2):23-33. [Rec#: 12385] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Jaslow D, Barbera J A, Johnson E, Moore W. Termination of nontraumatic cardiac arrest resuscitative efforts in the field: a national survey. Acad Emerg Med. 97;4(9):904-7. [Rec#: 3569] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Jatoi A, Kumar S, Sloan J A, Nguyen P L. On appetite and its loss. J Clin Oncol 2000;18(15):2930–2. Comment in: J Clin Oncol. Jan 15. 2001;19(2):594-5. PMID: 11208857. [Rec#: 12386] Exclude at abstract screening: useful only for background.
Jay P. Relatives caring for the terminally ill. Nurs Stand. 90;5(5):30-2. [Rec#: 12387] Exclude at abstract screening: no outcomes specified. [pmid: 2124865].
Jayes R L, Zimmerman J E, Wagner D P, Draper E A, Knaus W A. Do-not-resuscitate orders in intensive care units. Current practices and recent changes. JAMA. 93;270(18):2213-7. [Rec#: 41653] Exclude at abstract screening: data older than 1990.
JCAHO and NPC (National Pharmaceutical council). Pain: Current Understanding of Assessment, Management, and Treatments. 2001;<25 Page(s)>. [Rec#: 50839] Exclude at abstract screening: Non-systematic review
Jecker N S, Schneiderman L J. Is dying young worse than dying old?. Gerontologist. 94;34(1):66-72. [Rec#: 12392] Exclude at abstract screening: no outcomes specified. [pmid: 8150311].
Jecker N S, Schneiderman L J. When families request that ‘everything possible’ be done. J Med Philos. 95;20(2):145-63. [Rec#: 3574] Exclude at abstract screening: no outcomes specified. [pmid: 7543552].
Jecker N S. Medical futility and care of dying patients. West J Med. 95;163(3):287-91. [Rec#: 12391] Exclude at abstract screening: useful only for background. [pmid: 7571593].
Jeffers S L. Stages of grief. Fact or fiction?. Kans Nurse. 2001;76(7):9-10. [Rec#: 12393] Exclude at abstract screening: Title Only. [pmid: 11842497].
Jeffery P, Millard P H. An ethical framework for clinical decision-making at the end of life. J R Soc Med. 97;90(9):504-6. [Rec#: 12394] Exclude at abstract screening: Title Only. [pmid: 9370990].
Jeffrey D. Appropriate palliative care: when does it begin?. Eur J Cancer Care (Engl). 95;4(3):122-6. [Rec#: 12395] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 7551421].
Jelicic M, Kempen G I. Cognitive function in community-dwelling elderly with chronic medical conditions. Int J Geriatr Psychiatry. 97;12(10):1039-41. [Rec#: 41658] Exclude at abstract screening: not about end of life.
Jenkins C L. Care arrangement choices for older widows: decision participants' perspectives. J Women Aging. 2003;15(23):127-43. discussion 185–7. [Rec#: 41659] Exclude at abstract screening: not about end of life. [pmid: 14604005].
Jenkins C L. Resource effects on access to long-term care for frail older people. J Aging Soc Policy. 2001;13(4):35-52. [Rec#: 41660] Exclude at abstract screening: not about end of life. [pmid: 12418381].
Jenkins V, Fallowfield L. Can communication skills training alter physicians' beliefs and behavior in clinics?. Journal of Clinical Oncology. 2002;20(3):765-9. [Rec#: 50506] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11821459].
Jennings A L, Naysmith A. An audit of long-stay patients in an inner city palliative care centre. Palliat Med. 99;13(4):349-52. [Rec#: 3583] Exclude at abstract screening: not about end of life. [pmid: 10659104].
Jennings AL, Davies AN, Higgins JP, and Broadley K. Opioids for the palliation of breathlessness in terminal illness. Cochrane Database Syst Rev 2001;(4):CD002066. [Rec#: 12399] Exclude at abstract screening: Title Only
Jennings B. Hospice and Alzheimer disease: a study in access and simple justice. Hastings Cent Rep 2003;Suppl:S24–6. [Rec#: 12404] Exclude at abstract screening: Title Only
Jennings B. Individual rights and the human good in hospice. Hosp J. 97;12(2):1-7. [Rec#: 12405] Exclude at abstract screening: no outcomes specified. [pmid: 9248391].
Jennings A L, Davies A N, higgins J P, Gibbs J S, Broadley K E. Review: oral or parenteral opoids alleviate dyspnea in palliative care. ACP Journal Club and Best Evidence. 2003;138(3):72. [Rec#: 50507] Exclude at abstract screening: Title Only.
Jensen E, Dehlin O, Hagberg B, Samuelsson G, Svensson T. Medical, psychological, and sociological aspects of drug treatment in 80-year-olds. Z Gerontol. 94;27(2):140-4. [Rec#: 41661] Exclude at abstract screening: not about end of life.
Jensen R. Cross-cultural perspectives in palliative care. J Pain Palliat Care Pharmacother. 2003;17(34):223-9. [Rec#: 3589] Exclude at abstract screening: no outcomes specified. [pmid: 15022965].
Jepson J. Do not attempt resuscitation decisions: the nursing role. Br J Nurs. 2003;12(17):1038-42. [Rec#: 41665] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14512860].
Jett K. Making the connection: seeking and receiving help by elderly African Americans. Qual Health Res. 2002;12(3):373-87. [Rec#: 41667] Exclude at abstract screening: not about end of life. [pmid: 11918102].
Jett L G. Comfort at the end of life: palliative care policy. J Nurs Adm. 95;25(11):55-60. [Rec#: 12407] Exclude at abstract screening: not about end of life. [pmid: 7472631].
Jewett M A, Khakpour G, Moore M J. Supportive care is not the only option in prostate cancer patients resistant to hormone therapy: the argument against. Eur Urol. 96;29(Suppl 2):45-8. [Rec#: 12412] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Jezewski M A, Finnell D S. The meaning of DNR status: oncology nurses' experiences with patients and families. Cancer Nurs. 98;21(3):212-21. [Rec#: 3599] Exclude at abstract screening: Study Design - Unclear.
Jezewski M A, Meeker M A, Schrader M. Voices of oncology nurses: What is needed to assist patients with advance directives. Cancer Nurs. 2003;26(2):105-12. [Rec#: 3600] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12660559].
Jezewski M A, Scherer Y, Miller C, Battista E. Consenting to DNR: critical care nurses' interactions with patients and family members. Am J Crit Care. 93;2(4):302-9. [Rec#: 3601] Exclude at abstract screening: Study Design - Qualitative.
Jezewski M A. Do-not-resuscitate status: conflict and culture brokering in critical care units. Heart Lung. 94;23(6):458-65. [Rec#: 3598] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Jezewski M A. Obtaining consent for do-not-resuscitate status: advice from experienced nurses. Nurs Outlook. 96;44(3):114-9. [Rec#: 41668] Exclude at abstract screening: Title Only. [pmid: 8794451].
Joffrion L P, Douglas D. Grief resolution: facilitating self-transcendence in the bereaved. J Psychosoc Nurs Ment Health Serv. 94;32(3):13-9. [Rec#: 12416] Exclude at abstract screening: no outcomes specified.
Johansen C, Olsen J H. Psychological stress, cancer incidence and mortality from non-malignant diseases. Br J Cancer. 97;75(1):144-8. [Rec#: 12418] Exclude at abstract screening: not about end of life.
Johanson J F, Irizarry F, Doughty A. Risk factors for fecal incontinence in a nursing home population. J Clin Gastroenterol. 97;24(3):156-60. [Rec#: 41669] Exclude at abstract screening: not about end of life.
Johansson A, Dahlberg K, Ekebergh M. Living with experiences following a myocardial infarction. Eur J Cardiovasc Nurs. 2003;2(3):229-36. [Rec#: 12421] Exclude at abstract screening: Observational study. [pmid: 14622631].
Johnson A, Bourgeois S. Essence of caring for a person dying. Nurs Health Sci. 2003;5(2):133-8. [Rec#: 12430] Exclude at abstract screening: no outcomes specified. [pmid: 12709168].
Johnson A S. Palliative care in the home?. J Palliat Care. 95;11(2):42-4. [Rec#: 12431] Exclude at abstract screening: useful only for background. [pmid: 7541075].
Johnson C B, Slaninka S C. Barriers to accessing hospice services before a late terminal stage. Death Stud. 99;23(3):225-38. [Rec#: 12434] Exclude at abstract screening: useful only for background. [pmid: 10848152].
Johnson C B. Hospice: what gets in the way of appropriate and timely access. Holist Nurs Pract. 98;13(1):8-21. [Rec#: 12433] Exclude at abstract screening: Non-systematic review. [pmid: 10196889].
Johnson C S. Nutritional considerations for bereavement and coping with grief. J Nutr Health Aging. 2002;6(3):171-6. [Rec#: 3616] Exclude at abstract screening: Observational study. [pmid: 11887241].
Johnson D C, Kassner C T, Kutner J S. Current use of guidelines, protocols, and care pathways for symptom management in hospice. Am J Hosp Palliat Care. 2004;21(1):51-7. [Rec#: 3617] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14748524].
Johnson D C, Kassner C T, Kutner J S. Current use of guidelines, protocols, and care pathways for symptom management in hospice. Am J Hosp Palliat Care. 2004;21(1):51-7. [Rec#: 41673] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14748524].
Johnson D R, Maggiore W A. Resuscitation decision making by New Mexico emergency medical technicians. Am J Emerg Med. 93;11(2):139-42. [Rec#: 41674] Exclude at abstract screening: sudden/violent/non-chronic deaths.
Johnson I S, Rogers C, Biswas B, Ahmedzai S. What do hospices do? A survey of hospices in the United Kingdom and Republic of Ireland. BMJ 90;300(6727):791–3. Comment in: BMJ. May 5. 1990;300(6733):1194-5. PMID: 1693302. [Rec#: 12441] Exclude at abstract screening: useful only for background.
Johnson J R, Miller A J. The efficacy of choline magnesium trisalicylate (CMT) in the management of metastatic bone pain: a pilot study. Palliat Med. 94;8(2):129-35. [Rec#: 3619] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Johnson K, Cheema K, Ferris J, Wasnick J. A wellness approach to bereavement support. Can Nurse. 2002;98(9):18-21. [Rec#: 12445] Exclude at abstract screening: Title Only. [pmid: 12430525].
Johnson L C, Murphy S A, Dimond M. Reliability, construct validity, and subscale norms of the Brief Symptom Inventory when administered to bereaved parents. J Nurs Meas. 96;4(2):117-27. [Rec#: 3621] Exclude at abstract screening: sudden/violent/non-chronic deaths.
Johnson L E, Dooley P A, Gleick J B. Oral nutritional supplement use in elderly nursing home patients. J Am Geriatr Soc. 93;41(9):947-52. [Rec#: 41675] Exclude at abstract screening: not about end of life.
Johnson M, Moore S. Research into practice: the reality of implementing a non-pharmacological breathlessness intervention into clinical practice. Eur J Oncol Nurs. 2003;7(1):33-8. [Rec#: 12447] Exclude at abstract screening: no outcomes specified. [pmid: 12849573].
Johnson M F, Kramer A M. Physicians' responses to clinical scenarios involving life-threatening illness vary by patients' ageage. J Clin Ethics 2000;11(4):323–7. Comment in: J Clin Ethics. Winter. 2000;11(4):328-33. PMID: 11252916. [Rec#: 3623] Exclude at abstract screening: Title Only.
Johnson M J, Sherry K. How do palliative physicians manage venous thromboembolism?. Palliat Med. 97;11(6):462-8. [Rec#: 12449] Exclude at abstract screening: Other topic only. [pmid: 9519169].
Johnson MJ. Problems of anticoagulation within a palliative care setting: an audit of hospice patients taking warfarin. Palliat Med97;11(4):306–12. Comment in: Palliat Med. 1998 Nov;12(6):463. PMID: 10660347. Erratum in: Palliat Med. 1998 Nov;12(6):463. PMID: 10660347. [Rec#: 12448] Exclude at abstract screening: Other topic only
Johnson N, Cook D, Giacomini M, Willms D. Towards a “good” death: end-of-life narratives constructed in an intensive care unit. Cult Med Psychiatry. 2000;24(3):275-95. [Rec#: 12450] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11012101].
Johnson P, Chaboyer W, Foster M, van der Vooren R. Caregivers of ICU patients discharged home: what burden do they face?. Intensive Crit Care Nurs. 2001;17(4):219-27. [Rec#: 41678] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11868730].
Johnson P. Rural people's experience of critical illness involving inter-hospital transportation: a qualitative study. Aust Crit Care. 99;12(1):12-6. [Rec#: 41677] Exclude at abstract screening: not about end of life.
Johnson R E, Vollmer W M. Comparing sources of drug data about the elderly. J Am Geriatr Soc. 91;39(11):1079-84. [Rec#: 41679] Exclude at abstract screening: not about end of life. [pmid: 1753045].
Johnson T M, Ouslander J G, Uman G C, Schnelle J F. Urinary incontinence treatment preferences in long-term care. J Am Geriatr Soc 2001;49(6):710–8. Comment in: J Am Geriatr Soc. Jun. 2001;49(6):829-30. PMID: 11454125. [Rec#: 41681] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Johnston G, Abraham C. Managing awareness: negotiating and coping with a terminal prognosis. Int J Palliat Nurs. 2000;6(10):485-94. [Rec#: 3627] Exclude at abstract screening: Observational study. [pmid: 12271247].
Johnston G, Burge F. Analytic framework for clinician provision of end-of-life care. J Palliat Care. 2002;18(3):141-9. [Rec#: 12457] In abstract review process. [pmid: 12418364].
Johnston G M, Gibbons L, Burge F I, Dewar R A, Cummings I, Levy I G. Identifying potential need for cancer palliation in Nova Scotia. CMAJ. 98;158(13):1691-8. [Rec#: 3629] Exclude at abstract screening: useful only for background.
Johnston S C, Pfeifer M P, McNutt R. The discussion about advance directives. Patient and physician opinions regarding when and how it should be conducted. End of Life Study Group. Arch Intern Med. 95;155(10):1025-30. [Rec#: 3633] Exclude at abstract screening: not about end of life.
Jonas CM. True presence through music for persons living their dying. NLN Publ 94;(15–2670):97–104. [Rec#: 3638] Exclude at abstract screening: Title Only
Jones A, Peckett W, Clark E, Sharpe C, Krimholtz S, Russell M, Goodwin T. Nurses' knowledge of the resuscitation status of patients and action in the event of cardiorespiratory arrest. BMJ. 93;306(6892):1577-8. [Rec#: 41683] Exclude at abstract screening: Title Only.
Jones A. A ‘bonding between strangers’: a palliative model of clinical supervision. J Adv Nurs. 97;26(5):1028-35. [Rec#: 12471] Exclude at abstract screening: not about end of life. [pmid: 9372410].
Jones A. Actors in an emotional drama. Inter-related grief in terminal care. Prof Nurse. 91;6(10):598-603. [Rec#: 12469] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 1845076].
Jones A. AIDS focus. Empathy in the counselling process. Nurs Stand. 90;4(44):53-5. [Rec#: 12470] Exclude at abstract screening: Title Only. [pmid: 2119698].
Jones A. Death, poetry, psychotherapy and clinical supervision (the contribution of psychodynamic psychotherapy to palliative care nursing). J Adv Nurs. 97;25(2):238-44. [Rec#: 12473] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Jones B, Nackerud L, Boyle D. Differential utilization of hospice services in nursing homes. Hosp J. 97;12(3):41-57. [Rec#: 12484] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Jones C, Griffiths R D, Humphris G, Skirrow P M. Memory, delusions, and the development of acute posttraumatic stress disorder-related symptoms after intensive care. Crit Care Med 2001;29(3):573–80. Comment in: Crit Care Med. Mar. 2001;29(3):687-8. PMID: 11379543. [Rec#: 41684] Exclude at abstract screening: not about end of life.
Jones C, Skirrow P, Griffiths R D, Humphris G H, Ingleby S, Eddleston J, Waldmann C, Gager M. Rehabilitation after critical illness: a randomized, controlled trial. Crit Care Med. 2003;31(10):2456-61. [Rec#: 41688] Exclude at abstract screening: not about end of life. [pmid: 14530751].
Jones C L, King M B, Speck P, Kurowska A, Tookman A J. Development of an instrument to measure terminal restlessness. Palliat Med. 98;12(2):99-104. [Rec#: 12486] Exclude at abstract screening: not about end of life.
Jones D A, Peters T J. Caring for elderly dependents: effects on the carers' quality of life. Age Ageing. 92;21(6):421-8. [Rec#: 41689] Exclude at abstract screening: not about end of life. [pmid: 1471580].
Jones J M, Huggins M A, Rydall A C, Rodin G M. Symptomatic distress, hopelessness, and the desire for hastened death in hospitalized cancer patients. J Psychosom Res. 2003;55(5):411-8. [Rec#: 3649] Exclude at abstract screening: Title Only. [pmid: 14581095].
Jones J W, McCullough L B. Arsenic and old lace: end-of-life care in the postoperative period. Surgery 2002;131(5):583–4. Comment in: Surgery. Jan. 2003;133(1):122. author reply 122. PMID: 12563251. [Rec#: 12493] Exclude at abstract screening: Title Only.
Jones K, Gould M I, Duncan C. Death and deprivation: an exploratory analysis of deaths in the health and lifestyle survey. Soc Sci Med. 2000;50(78):1059-79. [Rec#: 41690] Exclude at abstract screening: Other topic only. [pmid: 10714927].
Jones P S, Martinson I M. The experience of bereavement in caregivers of family members with Alzheimer's disease. Image J Nurs Sch. 92;24(3):172-6. [Rec#: 3651] Exclude at abstract screening: Study Design - Qualitative.
Jones R V, Hansford J, Fiske J. Death from cancer at home: the carers' perspective. BMJ 93;306(6872):249–51. Comment in: BMJ. 1993 Mar 6;306(6878):648–9. PMID: 8461826. Comment in: BMJ. Mar 6. 1993;306(6878):649. PMID: 8461827. [Rec#: 3652] Exclude at abstract screening: Study Design - Qualitative.
Jones R V. Improving terminal care at home: can district nurses act as catalysts?. Eur J Cancer Care (Engl). 95;4(2):80-5. [Rec#: 12494] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Jones S A. Personal unity in dying: alternative conceptions of the meaning of health. J Adv Nurs. 93;18(1):89-94. [Rec#: 3653] Exclude at abstract screening: no outcomes specified. [pmid: 8429173].
Jones S B. Why not the best for the chronically ill?. Hosp J. 98;13(12):101-15. [Rec#: 12495] Exclude at abstract screening: no outcomes specified. [pmid: 9644396].
Jones S F, Kessel A S. The ‘redefinition of death’ debate: western concepts and western bioethics. Sci Eng Ethics. 2001;7(1):63-75. [Rec#: 12496] Exclude at abstract screening: no outcomes specified. [pmid: 11214385].
Jong P, Gong Y, Liu P P, Austin P C, Lee D S, Tu J V. Care and outcomes of patients newly hospitalized for heart failure in the community treated by cardiologists compared with other specialists. Circulation 2003;108(2):184–91. Comment in: Circulation. Jul 15. 2003;108(2):129-31. PMID: 12860891. [Rec#: 50049] In abstract review process.
Jonsson A, Gustafson Y, Schroll M, Hansen F R, Saarela M, Nygaard H, Laake K, Jonsson P V, Valvanne J, Dehlin O. Geriatric rehabilitation as an integral part of geriatric medicine in the Nordic countries. Dan Med Bull. 2003;50(4):439-45. [Rec#: 41692] Exclude at abstract screening: not about end of life. [pmid: 14694856].
Joos S K, Reuler J B, Powell J L, Hickam D H. Outpatients' attitudes and understanding regarding living wills. J Gen Intern Med. 93;8(5):259-63. [Rec#: 3657] Exclude at abstract screening: Study Design - Unclear.
Joranson D E. Availability of opioids for cancer pain: recent trends, assessment of system barriers, New World Health Organization guidelines, and the risk of diversion. J Pain Symptom Manage. 93;8(6):353-60. [Rec#: 12498] Exclude at abstract screening: Title Only.
Joranson D E, Carrow G M, Ryan K M, Schaefer L, Gilson A M, Good P, Eadie J, Peine S, Dahl J L. Pain management and prescription monitoring. J Pain Symptom Manage. 2002;23(3):231-8. [Rec#: 50508] Exclude at abstract screening: not about end of life. [pmid: 11888721].
Joranson D E, Gilson A M, Dahl J L, Haddox J D. Pain management, controlled substances, and state medical board policy: a decade of change. J Pain Symptom Manage. 2002;23(2):138-47. [Rec#: 50509] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11844634].
Joranson D E, Ryan K M, Gilson A M, Dahl J L. Trends in medical use and abuse of opioid analgesics. JAMA. 2000;283(13):1710-4. [Rec#: 50510] Exclude at abstract screening: not about end of life. [pmid: 10755497].
Jordan J R, Neimeyer R A. Does grief counseling work?. Death Stud. 2003;27(9):765-86. [Rec#: 3659] Exclude at abstract screening: Non-systematic review. [pmid: 14577426].
Jordhoy M S, Fayers P, Saltnes T, Ahlner-Elmqvist M, Jannert M, Kaasa S. A palliative-care intervention and death at home: a cluster randomised trial. Lancet. 2000;356(9233):888-93. [Rec#: 3661] Exclude at abstract screening: Title Only. [pmid: 11036893].
Jorm A F, Henderson A S, Scott R, Korten A E, Christensen H, Mackinnon A J. Factors associated with the wish to die in elderly people. Age Ageing. 95;24(5):389-92. [Rec#: 3665] Exclude at abstract screening: not about end of life.
Joseph C L, Wanlass W. Rehabilitation in the nursing home. Clin Geriatr Med. 93;9(4):859-71. [Rec#: 41698] Exclude at abstract screening: not about end of life. [pmid: 8281510].
Joynt G M, Gomersall C D, Tan P, Lee A, Cheng C A, Wong E L. Prospective evaluation of patients refused admission to an intensive care unit: triage, futility and outcome. Intensive Care Med 2001;27(9):1459–65. Comment in: Intensive Care Med. Sep. 2001;27(9):1441-5. PMID: 11685336. [Rec#: 41700] Exclude at abstract screening: Other topic only.
Juozapavicius K P, Weber J A. A reflective study of Alzheimer's caregivers. Am J Alzheimers Dis Other Demen. 2001;16(1):11-20. [Rec#: 3679] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11416944].
Kaasa S, Loge J H. Quality of life in palliative care: principles and practice. Palliat Med. 2003;17(1):11-20. [Rec#: 12517] Exclude at abstract screening: no outcomes specified. [pmid: 12597461].
Kaasa S, Loge J H. Quality-of-life assessment in palliative care. Lancet Oncol. 2002;3(3):175-82. [Rec#: 12516] In abstract review process. [pmid: 11902505].
Kaasa S, Bjordal K, Aaronson N, Moum T, Wist E, Hagen S, Kvikstad A. The EORTC core quality of life questionnaire (QLQ-C30): validity and reliability when analysed with patients treated with palliative radiotherapy. Eur J Cancer. 95;31A(1314):2260-3. [Rec#: 3684] Exclude at abstract screening: Study Design - Unclear.
Kaasa S, Loge J H, Knobel H, Jordhoy M S, Brenne E. Fatigue. Measures and relation to pain. Acta Anaesthesiol Scand. 99;43(9):939-47. [Rec#: 3686] Exclude at abstract screening: not about end of life. [pmid: 10522741].
Kaasa S. Assessment of quality of life in palliative care. J Palliat Med. 2001;4(3):413-6. [Rec#: 12512] Exclude at abstract screening: Title Only. [pmid: 11596553].
Kaasa S. Using quality of life assessment methods in patients with advanced cancer: a clinical perspective. Eur J Cancer. 95;31A(Suppl 6):S15-7. [Rec#: 12513] Exclude at abstract screening: useful only for background.
Kaasalainen V, Vainio A, Ali-Melkkila T. Developments in the treatment of cancer pain in Finland: the third nation-wide survey. Pain. 97;70(23):175-83. [Rec#: 12518] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Kabel A, Roberts D. Professionals' perceptions of maintaining personhood in hospice care. Int J Palliat Nurs. 2003;9(7):283-9. [Rec#: 12519] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12920448].
Kafetz K. What happens when elderly people die? J R Soc Med 2002;95(11):536–8. Comment in: J R Soc Med. Nov. 2002;95(11):529-30. PMID: 12411614. [Rec#: 3693] Exclude at abstract screening: Title Only.
Kagawa-Singer M. The cultural context of death rituals and mourning practices. Oncol Nurs Forum. 98;25(10):1752-6. [Rec#: 12521] Exclude at abstract screening: no outcomes specified. [pmid: 9826841].
Kahana E, Lawrence R H, Kahana B, Kercher K, Wisniewski A, Stoller E, Tobin J, Stange K. Long-term impact of preventive proactivity on quality of life of the old-old. Psychosom Med. 2002;64(3):382-94. [Rec#: 41706] Exclude at abstract screening: not about end of life. [pmid: 12021413].
Kahn D L, Steeves R H. The significance of suffering in cancer care. Semin Oncol Nurs. 95;11(1):9-16. [Rec#: 3700] Exclude at abstract screening: no outcomes specified. [pmid: 7740227].
Kahn E C. A comparison of family needs based on the presence or absence of DNR orders. Dimens Crit Care Nurs. 92;11(5):286-92. [Rec#: 41707] Exclude at abstract screening: Study Design - Unclear. [pmid: 1451616].
Kai I, Ohi G, Yano E, Kobayashi Y, Miyama T, Niino N, Naka K. Communication between patients and physicians about terminal care: a survey in Japan. Soc Sci Med. 93;36(9):1151-9. [Rec#: 3703] Notes: “EXCLUDE: Location, non-Western”. [pmid: 8511644].
Kaisary A V. Patient-Clinician choice in palliation of metastatic prostate cancer. Drugs Aging. 2000;17(5):331-7. [Rec#: 12525] Exclude at abstract screening: no outcomes specified. [pmid: 11190414].
Kaiser H E, Brock D B. Comparative aspects of the quality of life in cancer patients. In Vivo. 92;6(4):333-7. [Rec#: 3704] Exclude at abstract screening: useful only for background. [pmid: 1520836].
Kaiser K S. Removing barriers in hospice pain management--a family matter. Caring. 90;9(11):42-9. [Rec#: 12526] Exclude at abstract screening: no outcomes specified. [pmid: 10145374].
Kales H C, Blow F C, Copeland L A, Bingham R C, Kammerer E E, Mellow A M. Health care utilization by older patients with coexisting dementia and depression. Am J Psychiatry 99;156(4):550–6. Comment in: Am J Psychiatry. Apr. 2000;157(4):661-2. PMID: 10739450. [Rec#: 50050] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Kallenberg K, Soderfeldt B. Three years later: grief, view of life, and personal crisis after death of a family member. J Palliat Care. 92;8(4):13-9. [Rec#: 3710] Exclude at abstract screening: sudden/violent/non-chronic deaths.
Kamholz B A, Mellow A M. Management of treatment resistance in the depressed geriatric patient. Psychiatr Clin North Am. 96;19(2):269-86. [Rec#: 41713] Exclude at abstract screening: not about end of life.
Kane R A. Long-term care and a good quality of life: bringing them closer together. Gerontologist. 2001;41(3):293-304. [Rec#: 41715] Exclude at abstract screening: not about end of life. [pmid: 11405425].
Kane R L, Blewett L A. Quality assurance for a program of comprehensive care for older persons. Health Care Financ Rev. 93;14(4):89-110. [Rec#: 41717] Exclude at abstract screening: no outcomes specified.
Kane R L, Illston L H, Miller N A. Qualitative analysis of the Program of All-inclusive Care for the Elderly (PACE). Gerontologist. 92;32(6):771-80. [Rec#: 41720] Exclude at abstract screening: not about end of life.
Kane R L, Rockwood T, Finch M, Philp I. Consumer and professional ratings of the importance of functional status components. Health Care Financ Rev. 97;19(2):11-22. [Rec#: 41722] Exclude at abstract screening: no outcomes specified.
Kane RL. The implications of assessment. J Gerontol 93;48 Spec No:27–31. [Rec#: 41716] Exclude at abstract screening: Title Only
Kane R S, Burns E A. Cardiopulmonary resuscitation policies in long-term care facilities. J Am Geriatr Soc 97;45(2):154–7. Comment in: J Am Geriatr Soc. Feb. 1997;45(2):245-6. PMID: 9033529. [Rec#: 41723] Exclude at abstract screening: not about end of life.
Kane R S. The defeat of aging versus the importance of death. J Am Geriatr Soc. 96;44(3):321-5. [Rec#: 3723] Exclude at abstract screening: Title Only. [pmid: 8600205].
Kanoti G A, Gombeski W R Jr, Gulledge A D, Konrad D, Collins R, Medendorp S V. The effect of do-not-resuscitate orders on length of stay. Cleve Clin J Med 92;59(6):591–4. Comment in: Cleve Clin J Med. 1992 Nov-Dec;59(6):649–50. PMID: 1424079. Comment in: Cleve Clin J Med. Jan-Feb. 1994;61(1):78-79. PMID: 8124853. [Rec#: 3724] Exclude at abstract screening: data older than 1990.
Kaplow R. Use of nursing resources and comfort of cancer patients with and without do-not-resuscitate orders in the intensive care unit. Am J Crit Care. 2000;9(2):87-95. [Rec#: 41727] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10705422].
Kapp M B. Economic influences on end-of-life care: empirical evidence and ethical speculation. Death Stud. 2001;25(3):251-63. [Rec#: 3729] Exclude at abstract screening: no outcomes specified. [pmid: 11785542].
Kapp M B. Legal anxieties and end-of-life care in nursing homes. Issues Law Med. 2003;19(2):111-34. [Rec#: 3730] Exclude at abstract screening: no outcomes specified. [pmid: 14708257].
Karam E G. The nosological status of bereavement-related depressions. Br J Psychiatry. 94;165(2):48-52. [Rec#: 3732] Exclude at abstract screening: Study Design - Unclear. [pmid: 7953057].
Karasz A, Dyche L, Selwyn P. Physicians' experiences of caring for late-stage HIV patients in the post-HAART era: challenges and adaptations. Soc Sci Med. 2003;57(9):1609-20. [Rec#: 12546] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12948570].
Kari N, Michels P. The Lazarus Project: the politics of empowerment. Am J Occup Ther. 91;45(8):719-25. [Rec#: 41730] Exclude at abstract screening: not about end of life. [pmid: 1908638].
Karim K, Bailey M, Tunna K. Nonwhite ethnicity and the provision of specialist palliative care services: factors affecting doctors' referral patterns. Palliat Med. 2000;14(6):471-8. [Rec#: 12548] Exclude at abstract screening: Observational study. [pmid: 11219877].
Kashiwagi T. Psychosocial and spiritual issues in terminal care. Psychiatry Clin Neurosci. 95;49(Suppl 1):S123-7. [Rec#: 3741] Exclude at abstract screening: no outcomes specified. [pmid: 9179956].
Kashiwagi T. Truth telling and palliative medicine. Intern Med. 99;38(2):190-2. [Rec#: 12554] Exclude at abstract screening: Title Only. [pmid: 10225683].
Kasper J D, Steinbach U, Andrews J. Caregiver role appraisal and caregiver tasks as factors in ending caregiving. J Aging Health. 94;6(3):397-414. [Rec#: 41733] Exclude at abstract screening: data older than 1990.
Kass R M, Ellershaw J. Respiratory tract secretions in the dying patient: a retrospective study. J Pain Symptom Manage. 2003;26(4):897-902. [Rec#: 3745] Exclude at abstract screening: Other symptoms only. [pmid: 14527758].
Kass-Bartelmes, B. and Hughes, R. Advance Care Planning: Preferences for Care at the End of Life. Agency for Healthcare Research and Quality 2003;www.ahrg.gov. [Rec#: 50511] Exclude at abstract screening: Title Only
Kastenbaum R, Herman C. Death personification in the Kevorkian era. Death Stud. 97;21(2):115-30. [Rec#: 3749] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10169687].
Kastenbaum R. Death, suicide and the older adult. Suicide Life Threat Behav. 92;22(1):1-14. [Rec#: 3748] Exclude at abstract screening: sudden/violent/non-chronic deaths. [pmid: 1579979].
Kastenbaum R. The moment of death: is hospice making a difference?. Hosp J. 99;14(34):253-70. [Rec#: 12558] Exclude at abstract screening: useful only for background. [pmid: 10839016].
Kattan MW, Fearn PA, and Miles BJ. Time trade-off utility modified to accommodate degenerative and life-threatening conditions. Proc AMIA Symp 2001;304–8. [Rec#: 12564] Exclude at abstract screening: no outcomes specified
Katz A. AIDS dementia complex. J Palliat Care. 94;10(1):46-50. [Rec#: 12565] Exclude at abstract screening: Title Only. [pmid: 8035256].
Katz IR, Simpson GM, Curlik SM, Parmelee PA, and Muhly C. Pharmacologic treatment of major depression for elderly patients in residential care settings. J Clin Psychiatry 90;51 Suppl:41–7; discussion 48. [Rec#: 41735] Exclude at abstract screening: not about end of life
Katz J, Sidell M, Komaromy C. Death in homes: bereavement needs of residents, relatives and staff. Int J Palliat Nurs. 2000;6(6):274-9. [Rec#: 3756] Exclude at abstract screening: Study Design - Unclear. [pmid: 11249448].
Katz J S, Sidell M, Komaromy C. Dying in long-term care facilities: support needs of other residents, relatives, and staff. Am J Hosp Palliat Care. 2001;18(5):321-6. [Rec#: 3757] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11565185].
Katz P R, Karuza J, Kolassa J, Hutson A. Medical practice with nursing home residents: results from the National Physician Professional Activities Census. J Am Geriatr Soc. 97;45(8):911-7. [Rec#: 41736] Exclude at abstract screening: not about end of life.
Kaub-Wittemer D, Steinbuchel N, Wasner M, Laier-Groeneveld G, Borasio G D. Quality of life and psychosocial issues in ventilated patients with amyotrophic lateral sclerosis and their caregivers. Journal of Pain and Symptom Management. 2003;26(4):890-6. [Rec#: 50512] Exclude at abstract screening: Study Design - Unclear. [pmid: 14527757].
Kaufert J M, Putsch R W, Lavallee M. End-of-life decision making among Aboriginal Canadians: interpretation, mediation, and discord in the communication of “bad news”. J Palliat Care. 99;15(1):31-8. [Rec#: 3759] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Kaufman S R. In the shadow of “death with dignity”: medicine and cultural quandaries of the vegetative state. Am Anthropol. 2000;102(1):69-83. [Rec#: 12572] Exclude at abstract screening: no outcomes specified. [pmid: 12484398].
Kaunonen M, Tarkka M T, Laippala P, Paunonen-Ilmonen M. The impact of supportive telephone call intervention on grief after the death of a family member. Cancer Nurs. 2000;23(6):483-91. [Rec#: 3765] Exclude at abstract screening: Bereavement only. [pmid: 11128128].
Kaunonen M, Tarkka M T, Paunonen M, Laippala P. Grief and social support after the death of a spouse. J Adv Nurs. 99;30(6):1304-11. [Rec#: 3766] Exclude at abstract screening: Study Design - Qualitative. [pmid: 10583640].
Kavanagh D J. Towards a cognitive-behavioural intervention for adult grief reactions. Br J Psychiatry 90;157:373–83. Comment in: Br J Psychiatry. Feb. 1991;158:291. PMID: 2012932. [Rec#: 3771] Exclude at abstract screening: no outcomes specified.
Kavanagh S, Knapp M. The impact on general practitioners of the changing balance of care for elderly people living in institutions. BMJ 98;317(7154):322–7. Comment in: BMJ. Mar 6. 1999;318(7184):666. PMID: 10066217. [Rec#: 41743] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Kaw M, Sekas G. Long-term follow-up of consequences of percutaneous endoscopic gastrostomy (PEG) tubes in nursing home patients. Dig Dis Sci 94;39(4):738–43. Comment in: Dig Dis Sci. Apr. 1995;40(4):920-1. PMID: 7772183. [Rec#: 41744] Exclude at abstract screening: not about end of life.
Kay D W, Forster D P, Newens A J. Long-term survival, place of death, and death certification in clinically diagnosed pre-senile dementia in northern England. Follow-up after 8–12 years. Br J Psychiatry 2000;177:156–62. Comment in: Br J Psychiatry. Dec. 2000;177:565-6. PMID: 11102338. [Rec#: 41745] Exclude at abstract screening: data older than 1990.
Kayashima R, Braun K L. Barriers to good end-of-life care: a physician survey. Hawaii Med J. 2001;60(2):40-4. [Rec#: 12582] Exclude at abstract screening: useful only for background. [pmid: 11258163].
Kaye J M, Fleetwood J, Kaye D. The no-code patient and the infectious diseases consultant. Bull N Y Acad Med. 90;66(3):201-10. [Rec#: 12583] Exclude at abstract screening: useful only for background. [pmid: 2364215].
Kayser-Jones J, Schell E, Lyons W, Kris AE, Chan J, and Beard RL. Factors that influence end-of-life care in nursing homes: the physical environment, inadequate staffing, and lack of supervision. Gerontologist 2003;43 Spec No 2:76–84. [Rec#: 3789] Exclude at abstract screening: Study Design - Qualitative
Kayser-Jones J. The experience of dying: an ethnographic nursing home study. Gerontologist 2002;42 Spec No 3:11–9. Comment in: Gerontologist. 2002 Oct;42 Spec No 3:20–3. PMID: 12415129. [Rec#: 3786] Exclude at abstract screening: Study Design - Qualitative
Kazanjian M A. The spiritual and psychological explanations for loss experience. Hosp J. 97;12(1):17-27. [Rec#: 3790] Exclude at abstract screening: useful only for background. [pmid: 9248404].
Keating H J 3rd. Major surgery in nursing home patients: procedures, morbidity, and mortality in the frailest of the frail elderly. J Am Geriatr Soc. 92;40(1):8-11. [Rec#: 41746] Exclude at abstract screening: data older than 1990.
Keatinge D, Cadd A L, Henssen M, O'Brien L, Parker D, Rohr Y, Schneider J, Thompson J. Nurses' use of patient notes to chart bowel care management for the palliative care patient. Aust J Adv Nurs. 99;16(4):36-41. [Rec#: 12589] Exclude at abstract screening: Study Design - Unclear.
Keay T J, Schonwetter R S. Hospice care in the nursing home. Am Fam Physician 98;57(3):491–4. Comment in: Am Fam Physician. Feb 1. 1998;57(3):424-5. PMID: 9475891. [Rec#: 12593] Exclude at abstract screening: no outcomes specified.
Keay T J, Schonwetter R S. The case for hospice care in long-term care environments. Clin Geriatr Med. 2000;16(2):211-23. [Rec#: 12592] Exclude at abstract screening: useful only for background. [pmid: 10783425].
Keay T J, Fredman L, Taler G A, Datta S, Levenson S A. Indicators of quality medical care for the terminally ill in nursing homes. J Am Geriatr Soc. 94;42(8):853-60. [Rec#: 12591] Exclude at abstract screening: useful only for background.
Kedziera P, Harris D K. End-of-life care: hospice or home?. Cancer Pract. 98;6(3):188-90. [Rec#: 12595] Exclude at abstract screening: Title Only. [pmid: 9652251].
Keeley M P. Final conversations: survivors' memorable messages concerning religious faith and spirituality. Health Commun. 2004;16(1):87-104. [Rec#: 3802] Exclude at abstract screening: no outcomes specified. [pmid: 14979853].
Keeley P W. Clinical guidelines. Palliat Med. 2003;17(4):368-74. [Rec#: 12597] Exclude at abstract screening: not about end of life. [pmid: 12822854].
Keenan C H, Kish S K. The influence of do-not-resuscitate orders on care provided for patients in the surgical intensive care unit of a cancer center. Crit Care Nurs Clin North Am. 2000;12(3):385-90. [Rec#: 41747] Exclude at abstract screening: Study Design - Unclear. [pmid: 11855242].
Keenan S P, Mawdsley C, Plotkin D, Sibbald W J. Interhospital variability in satisfaction with withdrawal of life support: room for improvement?. Critical Care Medicine. 2003;31(2):626-31. [Rec#: 50515] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12576975].
Keenan S P, Mawdsley C, Plotkin D, Webster G K, Priestap F. Withdrawal of life support: how the family feels, and why. Journal of Palliative Care. 2000;16(Suppl):S40-4. [Rec#: 50516] Exclude at abstract screening: Study Design - Unclear. [pmid: 11075532].
Kellehear A. Spirituality and palliative care: a model of needs. Palliat Med. 2000;14(2):149-55. [Rec#: 12609] Exclude at abstract screening: Non-systematic review. [pmid: 10829149].
Kellehear A. The near-death experience as status passage. Soc Sci Med. 90;31(8):933-9. [Rec#: 12608] Exclude at abstract screening: no outcomes specified. [pmid: 2259966].
Kellermann A L, Hackman B B, Somes G. Predicting the outcome of unsuccessful prehospital advanced cardiac life support. JAMA 93;270(12):1433–6. Comment in: JAMA. 1993 Sep 22–29;270(12):1471–2. PMID: 8371449. Comment in: JAMA. 1994 Mar 9;271(10):747–8; author reply 748–9. PMID: 8114209. Comment in: JAMA. 1994 Mar 9;271(10):748. PMID: 8114210. Comment in: JAMA. Mar 9. 1994;271(10):748. autho. [Rec#: 41749] Exclude at abstract screening: primarily prognosis or trajectories.
Kelley M L, Sellick S, Linkewich B. Rural nonphysician providers' perspectives on palliative care services in northwestern Ontario, Canada. J Rural Health. 2003;19(1):55-62. [Rec#: 3812] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12585775].
Kelliher K. “Mr. K”. Imprint 92;39(5):104. [Rec#: 3813] Exclude at abstract screening: not about end of life
Kellogg F R, Brickner P W. Long-term home health care for the impoverished frail homebound aged: a twenty-seven-year experience. J Am Geriatr Soc. 2000;48(8):1002-11. [Rec#: 41750] Exclude at abstract screening: not about end of life. [pmid: 10968309].
Kellogg F R, Crain M, Corwin J, Brickner P W. Life-sustaining interventions in frail elderly persons. Talking about choices. Arch Intern Med. 92;152(11):2317-20. [Rec#: 3814] Exclude at abstract screening: Observational study.
Kelly B, Burnett P, Badger S, Pelusi D, Varghese F T, Robertson M. Doctors and their patients: a context for understanding the wish to hasten death. Psychooncology. 2003;12(4):375-84. [Rec#: 3817] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12748974].
Kelly B, Burnett P, Pelusi D, Badger S, Varghese F, Robertson M. Factors associated with the wish to hasten death: a study of patients with terminal illness. Psychol Med. 2003;33(1):75-81. [Rec#: 3818] Exclude at abstract screening: not about end of life. [pmid: 12537038].
Kelly CM, Wilkins RM, Eckardt JJ, and Ward WG. Treatment of metastatic disease of the tibia. Clin Orthop 2003;(415 Suppl):S219–29. [Rec#: 3822] Exclude at abstract screening: chemo/surg/stents/laser/radiation
Kelly D, Ross S, Gray B, Smith P. Death, dying and emotional labour: problematic dimensions of the bone marrow transplant nursing role?. J Adv Nurs. 2000;32(4):952-60. [Rec#: 12616] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11095235].
Kelly K, Bunn P A Jr. Is it time to reevaluate our approach to the treatment of brain metastases in patients with non-small cell lung cancer?. Lung Cancer. 98;20(2):85-91. [Rec#: 12622] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Kelly WF, Eliasson AH, Stocker DJ, and Hnatiuk OW. Do specialists differ on do-not-resuscitate decisions? Chest 2002;121(3):957–63. Comment in: Chest. 2002 Nov;122(5):1867–8; author reply 1868. PMID: 12426300. [Rec#: 41753] Exclude at abstract screening: outcome unrelated to pts/family/non-prof
Kelly-Powell M L. Personalizing choices: patients' experiences with making treatment decisions. Res Nurs Health. 97;20(3):219-27. [Rec#: 41752] Exclude at abstract screening: Study Design - Qualitative.
Kelman C. The Australian National Death Index: an assessment of accuracy. Aust N Z J Public Health. 2000;24(2):201-3. [Rec#: 41754] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10790942].
Kemeny M E, Dean L. Effects of AIDS-related bereavement on HIV progression among New York City gay men. AIDS Educ Prev. 95;7(5 Suppl):36-47. [Rec#: 3826] Exclude at abstract screening: Bereavement only. [pmid: 8664097].
Kemeny M E, Weiner H, Taylor S E, Schneider S, Visscher B, Fahey J L. Repeated bereavement, depressed mood, and immune parameters in HIV seropositive and seronegative gay men. Health Psychol. 94;13(1):14-24. [Rec#: 3828] Exclude at abstract screening: Study Design - Unclear.
Kemp C. Palliative care for respiratory problems in terminal illness. Am J Hosp Palliat Care. 97;14(1):26-30. [Rec#: 12632] Exclude at abstract screening: useful only for background. [pmid: 9069761].
Kemp C. Culture and the end of life: Hispanic cultures (focus on Mexican Americans). Journal of Hospice and Palliative Nursing. 2001;3(1):29-34. [Rec#: 50517] Exclude at abstract screening: useful only for background.
Kemp C. Palliative care for respiratory problems in terminal illness. American Journal of Hospice & Palliative Care. 97;14(1):26-30. [Rec#: 50518] Exclude at abstract screening: Title Only. [pmid: 9069761].
Kempen G I, van Sonderen E. Psychological attributes and changes in disability among low-functioning older persons: does attrition affect the outcomes?. J Clin Epidemiol. 2002;55(3):224-9. [Rec#: 41756] Exclude at abstract screening: not about end of life. [pmid: 11864791].
Kempen G I, van Heuvelen M J, van Sonderen E, van den Brink R H, Kooijman A C, Ormel J. The relationship of functional limitations to disability and the moderating effects of psychological attributes in community-dwelling older persons. Soc Sci Med. 99;48(9):1161-72. [Rec#: 41755] Exclude at abstract screening: Title Only.
Kemper P, Pezzin L E. The effect of public provision of home care on living and care arrangements: evidence from the channeling experiment. Dev Health Econ Public Policy. 96;5:125-46. [Rec#: 41757] Exclude at abstract screening: Title Only.
Kemper P, Murtaugh C M. Lifetime use of nursing home care. New England Journal of Medicine. 91;324(9):595-600. [Rec#: 50519] Exclude at abstract screening: not about end of life. [pmid: 1992320].
Kendall C, Jeffrey D. Out-of-hours specialist palliative care provision in an oncology centre: is it worthwhile?. Palliat Med. 2003;17(5):461-4. [Rec#: 12634] Exclude at abstract screening: no outcomes specified. [pmid: 12882265].
Kendall M L. A holistic nursing model for spiritual care of the terminally ill. Am J Hosp Palliat Care. 99;16(2):473-6. [Rec#: 12636] Exclude at abstract screening: no outcomes specified. [pmid: 10232124].
Kennett C E. Participation in a creative arts project can foster hope in a hospice day centre. Palliat Med. 2000;14(5):419-25. [Rec#: 3848] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11064789].
Kenny L J. An evaluation-based model for palliative care education: making a difference to practice. Int J Palliat Nurs. 2003;9(5):189-94. [Rec#: 12649] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12819595].
Kenny L J. Education in palliative care: making a difference to practice?. Int J Palliat Nurs. 2001;7(8):401-7. [Rec#: 12648] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11951785].
Keough M E, Field T S, Gurwitz J H. A model of community-based interdisciplinary team training in the care of the frail elderly. Acad Med. 2002;77(9):936. [Rec#: 41758] Exclude at abstract screening: no outcomes specified. [pmid: 12228109].
Keovilay L, Rasbridge L, Kemp C. Cambodian and Laotian Health Beliefs and Practices Related to the End of Life. Journal of Hospice and Palliative Medicine. 2000;2(4):143-151. [Rec#: 50520] Exclude at abstract screening: useful only for background.
Kerr H D, Byrd J C. Nursing home patients transferred by ambulance to a VA emergency department. J Am Geriatr Soc. 91;39(2):132-6. [Rec#: 41762] Exclude at abstract screening: Study Design - Unclear. [pmid: 1991944].
Kerridge I, Lowe M, Mitchell K. Competent patients, incompetent decisions. Ann Intern Med. 95;123(11):878-81. [Rec#: 12657] Exclude at abstract screening: useful only for background. [pmid: 7486472].
Kerrison S H, Pollock A M. Regulating nursing homes: Caring for older people in the private sector in England. BMJ. 2001;323(7312):566-9. [Rec#: 41763] Exclude at abstract screening: Title Only. [pmid: 11546707]. [pmcid: 1121139].
Kerr-Wilson R. Terminal care of gynaecological malignancy. Br J Hosp Med. 94;51(3):113-8. [Rec#: 12656] Exclude at abstract screening: no outcomes specified. [pmid: 8193835].
Kersting A. The psychodynamics of grief hallucinations - a psychopathological phenomenon of normal and pathological grief. Psychopathology. 2004;37(1):50-1. [Rec#: 3857] Exclude at abstract screening: Title Only. [pmid: 14988651].
Khand A U, Gemmell I, Rankin A C, Cleland J G. Clinical events leading to the progression of heart failure: insights from a national database of hospital discharges. Eur Heart J. 2001;22(2):153-64. [Rec#: 50051] In abstract review process. [pmid: 11161917].
Kidby J. Family-witnessed cardiopulmonary resuscitation. Nurs Stand. 2003;17(51):33-6. [Rec#: 12670] Exclude at abstract screening: Non-systematic review. [pmid: 14520820].
Kidd K D, Lane M P. Maximizing foodservice in an inpatient hospice setting. Hosp J. 93;9(23):85-106. [Rec#: 12671] Exclude at abstract screening: no outcomes specified. [pmid: 7806183].
Kidder D. The effects of hospice coverage on Medicare expenditures. Health Serv Res. 92;27(2):195-217. [Rec#: 3874] Exclude at abstract screening: useful only for background. [pmid: 1592605].
Kiel RA. Caring for terminally ill inmates: on-site hospice care or compassionate release? Correctcare 95;9(2):5, 13–14. [Rec#: 12672] Exclude at abstract screening: Title Only
Kiely M T, Alison D L. Palliative care activity in a medical oncology unit: the implications for oncology training. Clin Oncol (R Coll Radiol). 2000;12(3):179-81. [Rec#: 12674] Exclude at abstract screening: useful only for background. [pmid: 10942335].
Kiely S C, Prince P L. Long-term home health care for the aged: the West Penn (Allegheny County, PA) Hospital Home Visit Program experience. J Long Term Home Health Care. 94;13(2):41-53. [Rec#: 41770] Exclude at abstract screening: not about end of life.
Killeen M. The right combination: volunteers as health advocates for homebound elders. J Volunt Adm. 91;9(4):15-22. [Rec#: 41771] Exclude at abstract screening: Title Only. [pmid: 10115904].
Killeen M E. Clinical clowning: humor in hospice care. Am J Hosp Palliat Care. 91;8(3):23-7. [Rec#: 12675] Exclude at abstract screening: Title Only. [pmid: 1931321].
Kilpatrick M G, Kristjanson L J, Tataryn D J. Measuring the information needs of husbands of women with breast cancer: validity and reliability of the Family Inventory of Needs--husbands. Oncology Nursing Forum. 98;25(8):1347-51. [Rec#: 50521] Exclude at abstract screening: not about end of life.
Kilpatrick M G, Kristjanson L J, Tataryn D J, Fraser V H. Information needs of husbands of women with breast cancer. Oncology Nursing Forum. 98;25(9):1595-601. [Rec#: 50522] Exclude at abstract screening: not about end of life.
Kim HJ, Steketee G, and Frost RO. Hoarding by elderly people. Health Soc Work 2001;26(3):176–84. Erratum in: Health Soc Work 2001 Nov;26(4):234. [Rec#: 41772] Exclude at abstract screening: not about end of life
Kim K, Jacobs S. Pathologic grief and its relationship to other psychiatric disorders. J Affect Disord. 91;21(4):257-63. [Rec#: 3886] Exclude at abstract screening: Observational study. [pmid: 1829747].
Kim K S. Long-term care for the Korean American elderly: an exploration for a better way of services. J Long Term Home Health Care. 97;16(2):35-8. [Rec#: 41773] Exclude at abstract screening: not about end of life.
Kim S H, Wolde-Tsadik G, Reuben D B. Predictors of perceived health in hospitalized older persons: a cross-sectional and longitudinal study. J Am Geriatr Soc. 97;45(4):420-6. [Rec#: 41774] Exclude at abstract screening: not about end of life.
Kim S L, Goldschmid S. Palliation of malignant dysphagia: carvers versus plumbers. Am J Gastroenterol. 95;90(3):512-3. [Rec#: 12680] Exclude at abstract screening: no outcomes specified. [pmid: 7532914].
Kimberlin C L, Pendergast J F, Berardo D H, McKenzie L C. Issues related to using a short-form of the Center for Epidemiological Studies-Depression Scale. Psychol Rep. 98;83(2):411-21. [Rec#: 41775] Exclude at abstract screening: not about end of life.
Kindlen M. Loss adaptation. Eur J Cancer Care (Engl). 99;8(4):245-9. [Rec#: 12683] Exclude at abstract screening: no outcomes specified. [pmid: 10889623].
King G, Mackenzie J, Smith H, Clark D. Dying at home: evaluation of a hospice rapid-response service. Int J Palliat Nurs. 2000;6(6):280-7. [Rec#: 12686] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11249449].
King N, Bell D, Thomas K. Family carers' experiences of out-of-hours community palliative care: a qualitative study. Int J Palliat Nurs. 2004;10(2):76-83. [Rec#: 3901] Exclude at abstract screening: Study Design - Qualitative. [pmid: 15039611].
King N, Thomas K, Bell D. An out-of-hours protocol for community palliative care: practitioners' perspectives. Int J Palliat Nurs. 2003;9(7):277-82. [Rec#: 12687] Exclude at abstract screening: no outcomes specified. [pmid: 12920447].
Kinsella G, Cooper B, Picton C, Murtagh D. Factors influencing outcomes for family caregivers of persons receiving palliative care: toward an integrated model. J Palliat Care. 2000;16(3):46-54. [Rec#: 12692] Exclude at abstract screening: Title Only. [pmid: 11019507].
Kinzbrunner B M, Weinreb N J, Merriman M P. Debility, unspecified: a terminal diagnosis. Am J Hosp Palliat Care. 96;13(6):38-44. [Rec#: 3908] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 8945102].
Kinzbrunner B M. Ethical dilemmas in hospice and palliative care. Support Care Cancer. 95;3(1):28-36. [Rec#: 12696] Exclude at abstract screening: no outcomes specified. [pmid: 7535167].
Kinzbrunner B M. The role of the physician in hospice. Hosp J. 97;12(2):49-55. [Rec#: 12698] Exclude at abstract screening: no outcomes specified. [pmid: 9248397].
Kipnes D R, Piper W E, Joyce A S. Cohesion and outcome in short-term psychodynamic groups for complicated grief. Int J Group Psychother. 2002;52(4):483-509. [Rec#: 12699] Exclude at abstract screening: not about end of life. [pmid: 12375484].
Kirchhoff K T, Beckstrand R L. Critical care nurses' perceptions of obstacles and helpful behaviors in providing end-of-life care to dying patients. Am J Crit Care. 2000;9(2):96-105. [Rec#: 3914] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10705423].
Kirchhoff K T, Spuhler V, Walker L, Hutton A, Cole B V, Clemmer T. Intensive care nurses' experiences with end-of-life care. Am J Crit Care. 2000;9(1):36-42. [Rec#: 3915] Exclude at abstract screening: Study Design - Qualitative. [pmid: 10631389].
Kirchhoff K T, Walker L, Hutton A, Spuhler V, Cole B V, Clemmer T. The vortex: families' experiences with death in the intensive care unit. Am J Crit Care. 2002;11(3):200-9. [Rec#: 3916] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12022483].
Kirk K, McManus M. Containing families' grief: therapeutic group work in a hospice setting. Int J Palliat Nurs. 2002;8(10):470-80. [Rec#: 3917] Exclude at abstract screening: Non-systematic review. [pmid: 12419986].
Kirk S, Donnelly M E, Compton S A. A profile of residents of old people's homes. Ulster Med J. 91;60(2):154-8. [Rec#: 41776] Exclude at abstract screening: not about end of life. [pmid: 1785148].
Kirker F J, Oliver D J. The development and implementation of a standardized policy for the management of dysphagia in motor neurone disease. Palliat Med. 2003;17(4):322-6. [Rec#: 12706] Exclude at abstract screening: Study Design - Unclear. [pmid: 12822848].
Kirmse J M. Aggressive implementation of advance directives. Crit Care Nurs Q. 98;21(1):83-9. [Rec#: 3919] In abstract review process. [pmid: 9644364].
Kirschling J M, Luce L. Oregon Hospice Association: statewide data set. Hosp J. 92;8(3):35-44. [Rec#: 3922] Exclude at abstract screening: data older than 1990. [pmid: 1294449].
Kirschling J M, Tilden V P, Butterfield P G. Social support: the experience of hospice family caregivers. Hosp J. 90;6(2):75-93. [Rec#: 3924] Exclude at abstract screening: Study Design - Qualitative. [pmid: 2401471].
Kirstila V, Lenander-Lumikari M, Soderling E, Tenovuo J. Effects of oral hygiene products containing lactoperoxidase, lysozyme, and lactoferrin on the composition of whole saliva and on subjective oral symptoms in patients with xerostomia. Acta Odontol Scand. 96;54(6):391-7. [Rec#: 3925] Exclude at abstract screening: not about end of life.
Kish S K, Martin C G, Price K J. Advance directives in critically ill cancer patients. Crit Care Nurs Clin North Am. 2000;12(3):373-83. [Rec#: 3927] Exclude at abstract screening: Study Design - Unclear. [pmid: 11855241].
Kissane D W, Bloch S. Family grief. Br J Psychiatry. 94;164(6):728-40. [Rec#: 3928] Exclude at abstract screening: Non-systematic review. [pmid: 7952979].
Kissane D W, Smith G C. Consultation-liaison psychiatry in an Australian oncology unit. Aust N Z J Psychiatry. 96;30(3):397-404. [Rec#: 3935] Exclude at abstract screening: not about end of life. [pmid: 8839952].
Kissane D W, Bloch S, Dowe D L, Snyder R D, Onghena P, McKenzie D P, Wallace C S. The Melbourne Family Grief Study, I: Perceptions of family functioning in bereavement. Am J Psychiatry. 96;153(5):650-8. [Rec#: 3929] Exclude at abstract screening: Study Design - Unclear.
Kissane D W, Bloch S, McKenzie M, McDowall A C, Nitzan R. Family grief therapy: a preliminary account of a new model to promote healthy family functioning during palliative care and bereavement. Psychooncology. 98;7(1):14-25. [Rec#: 3931] Exclude at abstract screening: Study Design - Unclear.
Kissane D W, Clarke D M, Street A F. Demoralization syndrome--a relevant psychiatric diagnosis for palliative care. J Palliat Care. 2001;17(1):12-21. [Rec#: 12717] Exclude at abstract screening: no outcomes specified. [pmid: 11324179].
Kissane D W, McKenzie D P, Bloch S. Family coping and bereavement outcome. Palliat Med. 97;11(3):191-201. [Rec#: 3933] Exclude at abstract screening: Bereavement only. [pmid: 9205652].
Kissane D W, Spruyt O, Aranda S. Palliative care--new approaches to the problem of suffering. Aust N Z J Med. 2000;30(3):377-84. [Rec#: 12718] Exclude at abstract screening: no outcomes specified. [pmid: 10914757].
Kissane D W. Family-based grief counselling. Aust Fam Physician. 94;23(4):678-80. [Rec#: 12714] Exclude at abstract screening: no outcomes specified. [pmid: 8198487].
Kissane D W. Managing anger in palliative care. Aust Fam Physician. 94;23(7):1257-9. [Rec#: 12715] Exclude at abstract screening: useful only for background. [pmid: 7520232].
Kissane D W. Psychospiritual and existential distress. The challenge for palliative care. Aust Fam Physician. 2000;29(11):1022-5. [Rec#: 12716] Exclude at abstract screening: no outcomes specified. [pmid: 11127057].
Kissane D W, Bloch S, Miach P, Smith G C, Seddon A, Keks N. Cognitive-existential group therapy for patients with primary breast cancer--techniques and themes. Psycho-Oncology. 97;6(1):25-33. [Rec#: 50523] Exclude at abstract screening: not about end of life.
Kitagawa T, Hara M, Sano T, Sugimura T. The concept of Tenju-gann or “natural-end cancer”. Cancer 98;83(6):1061–5. Comment in: Cancer. 1998 Sep 15;83(6):1066–8. PMID: 9740068. Comment in: Cancer. Mar 1. 1999;85(5):1197-9. PMID: 10091806 [Rec#: 3936] Exclude at abstract screening: Title Only.
Kite S, Jones K, Tookman A. Specialist palliative care and patients with noncancer diagnoses: the experience of a service. Palliat Med. 99;13(6):477-84. [Rec#: 3938] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Kite S. How can different models of organisation or bed utilisation improve the care of patients dying in hospital? (Structured Abstract). 2003;3:<25 Page(s)>. [Rec#: 50164] Exclude at abstract screening: Title Only
Kite S. Q9: How can different models of organisation or bed utilisation improve the care of patients dying in hospital. 1997;<25 Page(s)>. [Rec#: 50852] Exclude at abstract screening: Study Design - Review/Meta
Kitson G C. Adjustment to violent and natural deaths in later and earlier life for black and white widows. J Gerontol B Psychol Sci Soc Sci. 2000;55(6):S341-51. [Rec#: 3939] Exclude at abstract screening: sudden/violent/non-chronic deaths. [pmid: 11078111].
Kitzes J A, Domer T. Palliative care: an emerging issue for American Indians and Alaskan Natives. J Pain Palliat Care Pharmacother. 2003;17(34):201-10. [Rec#: 3940] Exclude at abstract screening: useful only for background. [pmid: 15022963].
Kivett V R, McCulloch B J. Older rural nonsurvivors: their prediction and terminal care. J Appl Gerontol. 92;11(4):407-24. [Rec#: 3942] Exclude at abstract screening: Study Design - Unclear. [pmid: 10122830].
Kjaer M. The therapy of cancer pain and its integration into a comprehensive supportive care strategy. Ann Oncol. 97;8(Suppl 3):S15-9. [Rec#: 12720] Exclude at abstract screening: useful only for background.
Klagsbrun S C. Patient, family and staff suffering. J Palliat Care. 94;10(2):14-7. [Rec#: 3945] Exclude at abstract screening: Title Only. [pmid: 8089812].
Klaschik E, Nauck F, Ostgathe C. Constipation--modern laxative therapy. Support Care Cancer. 2003;11(11):679-85. [Rec#: 3948] Exclude at abstract screening: not about end of life. [pmid: 14505158].
Klausner E J, Clarkin J F, Spielman L, Pupo C, Abrams R, Alexopoulos G S. Late-life depression and functional disability: the role of goal-focused group psychotherapy. Int J Geriatr Psychiatry. 98;13(10):707-16. [Rec#: 41788] Exclude at abstract screening: not about end of life.
Kleinberg K. Technologies to enable home care. Caring. 2001;20(1):36-7. [Rec#: 41791] Exclude at abstract screening: Title Only. [pmid: 11190979].
Kleinpell R M, Ferrans C E. Quality of life of elderly patients after treatment in the ICU. Res Nurs Health. 2002;25(3):212-21. [Rec#: 41794] Exclude at abstract screening: not about end of life. [pmid: 12015783].
Kleinpell R M. Exploring outcomes after critical illness in the elderly. Outcomes Manag. 2003;7(4):159-69. [Rec#: 41792] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 14618774].
Klepper H, Truog R D. Treating the patient to benefit others. Camb Q Healthc Ethics. 97;6(3):306-13. [Rec#: 3953] Exclude at abstract screening: Title Only. [pmid: 9253500].
Klepstad P, Hilton P, Moen J, Fougner B, Borchgrevink P C, Kaasa S. Self-reports are not related to objective assessments of cognitive function and sedation in patients with cancer pain admitted to a palliative care unit. Palliat Med. 2002;16(6):513-9. [Rec#: 3954] Exclude at abstract screening: Observational study. [pmid: 12465699].
Klepstad P, Kaasa S, and Borchgrevink PC. Start of oral morphine to cancer patients: effective serum morphine concentrations and contribution from morphine-6-glucuronide to the analgesia produced by morphine. Eur J Clin Pharmacol 2000;55(10):713–9. Comment in: Eur J Clin Pharmacol. 2000 Nov;56(8):599, 601. PMID: 11151752. [Rec#: 3955] Exclude at abstract screening: outcome unrelated to pts/family/non-prof
Klie T. [Dying with dignity-between autonomy and care. A contribution to the current legal discussion in Germany]. Z Gerontol Geriatr. 2003;36(5):347-54. [Rec#: 3956] Exclude at abstract screening: no outcomes specified. [pmid: 14579061].
Kliebsch U, Siebert H, Brenner H. Extent and determinants of hospitalization in a cohort of older disabled people. J Am Geriatr Soc. 2000;48(3):289-94. [Rec#: 41798] Exclude at abstract screening: not about end of life. [pmid: 10733055].
Kloke M, Scheidt H. Pain and symptom control for cancer patients at the University Hospital in Essen: integration of specialists' knowledge into routine work. Support Care Cancer. 96;4(6):404-7. [Rec#: 12732] Exclude at abstract screening: no outcomes specified.
Klopfenstein KJ. Adolescents, cancer, and hospice. Adolesc Med 99;10(3):437–43, xi. [Rec#: 41799] Notes: “EXCLUDE: Age, not adults”
Knapp E R, DelCampo R L. Developing family care plans: a systems perspective for helping hospice families. Am J Hosp Palliat Care. 95;12(6):39-47. [Rec#: 12737] Exclude at abstract screening: no outcomes specified.
Knaus W A, Harrell F E Jr, Lynn J, Goldman L, Phillips R S, Connors A F Jr, Dawson N V, Fulkerson W J Jr, Califf R M, Desbiens N, et al. The SUPPORT prognostic model. Objective estimates of survival for seriously ill hospitalized adults. Study to understand prognoses and preferences for outcomes and risks of treatments. Ann Intern Med. 95;122(3):191-203. [Rec#: 41800] Exclude at abstract screening: primarily prognosis or trajectories.
Knickman J R, Hunt K A. Medical vulnerability in America: how does the health system respond?. Inquiry. 2003;40(2):198-209. [Rec#: 41803] Exclude at abstract screening: not about end of life. [pmid: 13677566].
Knight A, Meek F. Needs assessment: a tool for hospice expansion. Int J Palliat Nurs. 2003;9(5):195-201. [Rec#: 12742] Exclude at abstract screening: no outcomes specified. [pmid: 12819596].
Knight B. Assuring professional pastoral care for every nursing home resident. J Health Care Chaplain. 99;8(12):89-107. [Rec#: 41804] Exclude at abstract screening: not about end of life. [pmid: 10387595].
Knight C F. Networking with the gay community to meet the needs of AIDS patients: special considerations for volunteer training. Am J Hosp Care. 90;7(1):31-5. [Rec#: 12743] Exclude at abstract screening: no outcomes specified.
Knight K H, Elfenbein M H, Capozzi L. Relationship of recollections of first death experience to current death attitudes. Death Stud. 2000;24(3):201-21. [Rec#: 3968] Exclude at abstract screening: not about end of life. [pmid: 11010627].
Knight C F, Knight P F, Gellula M H, Holman G H. Training our future physicians: a hospice rotation for medical students. Am J Hosp Palliat Care. 92;9(1):23-8. [Rec#: 50873] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Knopman D, Schneider L, Davis K, Talwalker S, Smith F, Hoover T, Gracon S. Long-term tacrine (Cognex) treatment: effects on nursing home placement and mortality, Tacrine Study Group. Neurology 96;47(1):166–77. Comment in: Neurology. Sep. 1997;49(3):897-9. PMID: 9305370. [Rec#: 50052] Exclude at abstract screening: not about end of life.
Kodner D L, Kyriacou C K. Bringing managed care home to people with chronic, disabling conditions: prospects and challenges for policy, practice, and research. J Aging Health. 2003;15(1):189-22. [Rec#: 41813] Exclude at abstract screening: not about end of life. [pmid: 12613468].
Koedoot C G, de Haan R J, Stiggelbout A M, Stalmeier P F, de Graeff A, Bakker P J, de Haes J C. Palliative chemotherapy or best supportive care? A prospective study explaining patients' treatment preference and choice. Br J Cancer. 2003;89(12):2219-26. [Rec#: 3982] Exclude at abstract screening: Study Design - Unclear. [pmid: 14676798].
Koenig B A, Gates-Williams J. Understanding cultural difference in caring for dying patients. West J Med. 95;163(3):244-9. [Rec#: 12758] Exclude at abstract screening: useful only for background. [pmid: 7571587].
Koenig H G, Westlund R E, George L K, Hughes D C, Blazer D G, Hybels C. Abbreviating the Duke Social Support Index for use in chronically ill elderly individuals. Psychosomatics. 93;34(1):61-9. [Rec#: 41815] Exclude at abstract screening: not about end of life.
Koenig K L, Haynes B. Prehospital ‘do-not-resuscitate’ orders--a new option. West J Med. 93;159(5):602-3. [Rec#: 41816] Exclude at abstract screening: Title Only. [pmid: 8279168].
Koenig H G, George L K, Peterson B L. Religiosity and remission of depression in medically ill older patients. American Journal of Psychiatry. 98;155(4):536-42. [Rec#: 50524] Exclude at abstract screening: not about end of life.
Koff S Z, Koff H V. A nursing response to the needs of the elderly. J Health Hum Serv Adm. 97;20(2):182-96. [Rec#: 41817] Exclude at abstract screening: not about end of life. [pmid: 10177077].
Koffman J, Higginson I, Naysmith A. Hospice at home--a new service for patients with advanced HIV/AIDS: a pilot evaluation of referrals and outcomes. Br J Gen Pract 96;46(410):539–40. Comment in: Br J Gen Pract. Feb. 1998;48(427):1006. PMID: 9624779. [Rec#: 3987] Exclude at abstract screening: Study Design - Unclear.
Koger S M, Chapin K, Brotons M. Is Music Therapy an Effective Intervention for Dementia?A Meta-Analytic Review of Literature. J Music Ther. 99;36(1):2-15. [Rec#: 50138] Exclude at abstract screening: Study Design - Review/Meta.
Koh N Y, Koo W H. Polypharmacy in palliative care: can it be reduced? Singapore Med J 2002;43(6):279–83. Comment in: Singapore Med J. Jun. 2002;43(6):273-5. PMID: 12380721. [Rec#: 3994] Notes: “EXCLUDE: Location, non-Western”.
Kojlak J, Keenan S P, Plotkin D, Giles-Fysh N, Sibbald W. Determining the potential need for a bereavement follow-up program: how well are family and health care workers' needs currently being met?. Off J Can Assoc Crit Care Nurs. 98;9(1):12-6. [Rec#: 3996] Exclude at abstract screening: Bereavement only.
Kokoska E R, Stapleton D R, Virgo K S, Johnson F E, Wade T P. Quality of life measurements do not support palliative pancreatic cancer treatments. Int J Oncol. 98;13(6):1323-9. [Rec#: 3997] Exclude at abstract screening: primarily prognosis or trajectories.
Kolarik R C, Arnold R M, Fischer G S, Tulsky J A. Objectives for advance care planning. J Palliat Med. 2002;5(5):697-704. [Rec#: 12765] Exclude at abstract screening: useful only for background. [pmid: 12572968].
Kolcaba K Y, Fisher E M. A holistic perspective on comfort care as an advance directive. Crit Care Nurs Q. 96;18(4):66-76. [Rec#: 3999] Exclude at abstract screening: no outcomes specified. [pmid: 8689455].
Kolden G G, Strauman T J, Ward A, Kuta J, Woods T E, Schneider K L, Heerey E, Sanborn L, Burt C, Millbrandt L, Kalin N H, Stewart J A, Mullen B. A pilot study of group exercise training (GET) for women with primary breast cancer: feasibility and health benefits. Psychooncology. 2002;11(5):447-56. [Rec#: 41820] Exclude at abstract screening: not about end of life. [pmid: 12228878].
Koller P A. Family needs and coping strategies during illness crisis. AACN Clin Issues Crit Care Nurs. 91;2(2):338-45. [Rec#: 41828] Exclude at abstract screening: not about end of life. [pmid: 2021520].
Komurcu S, Nelson K A, Walsh D. The gastrointestinal symptoms of advanced cancer. Support Care Cancer. 2001;9(1):32-9. [Rec#: 12766] Exclude at abstract screening: no outcomes specified. [pmid: 11147140].
Konigova R. Do-not-resuscitate orders and withheld or withdrawn treatment. Acta Chir Plast. 96;38(2):73-7. [Rec#: 12769] Exclude at abstract screening: Non-systematic review. [pmid: 8908735].
Konsler G, Dalton J A, Carlson J, Atkins J. Cancer pain management in North Carolina. Physician knowledge, attitude, and behavior. N C Med J. 95;56(6):289-90. [Rec#: 12772] Exclude at abstract screening: Title Only. [pmid: 7541514].
Koop P M, Strang V. Predictors of bereavement outcomes in families of patients with cancer: a literature review. Can J Nurs Res. 97;29(4):33-50. [Rec#: 12773] Exclude at abstract screening: useful only for background.
Koop P M, Strang V R. The bereavement experience following home-based family caregiving for persons with advanced cancer. Clin Nurs Res. 2003;12(2):127-44. [Rec#: 4016] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12741666].
Koopmanschap M A, van Ineveld B M, Miltenburg T E. Costs of home care for advanced breast and cervical cancer in relation to cost-effectiveness of screening. Soc Sci Med. 92;35(8):979-85. [Rec#: 4017] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Koopmeiners L, Post-White J, Gutknecht S, Ceronsky C, Nickelson K, Drew D, Mackey K W, Kreitzer M J. How healthcare professionals contribute to hope in patients with cancer. Oncol Nurs Forum. 97;24(9):1507-13. [Rec#: 4018] Exclude at abstract screening: Study Design - Qualitative.
Korda L J, Pancrazio J J. Self-esteem and hospice: applying principles to practice. Am J Hosp Palliat Care. 91;8(4):13-6. [Rec#: 12780] Exclude at abstract screening: no outcomes specified. [pmid: 1931325].
Korenman S, Goldman N, Fu H. Misclassification bias in estimates of bereavement effects. Am J Epidemiol. 97;145(11):995-1002. [Rec#: 4022] Exclude at abstract screening: data older than 1990. [pmid: 9169908].
Kornick C A, Santiago-Palma J, Khojainova N, Primavera L H, Payne R, Manfredi P L. A safe and effective method for converting cancer patients from intravenous to transdermal fentanyl. Cancer. 2001;92(12):3056-61. [Rec#: 50527] Exclude at abstract screening: Observational study. [pmid: 11753984].
Kornick C A, Santiago-Palma J, Schulman G, O'Brien P C, Weigand S, Payne R, Manfredi P L. A safe and effective method for converting patients from transdermal to intravenous fentanyl for the treatment of acute cancer-related pain. Cancer. 2003;97(12):3121-4. [Rec#: 50528] Exclude at abstract screening: Observational study. [pmid: 12784350].
Koroknay V J, Werner P, Cohen-Mansfield J, Braun J V. Maintaining ambulation in the frail nursing home resident: a nursing administered walking program. J Gerontol Nurs. 95;21(11):18-24. [Rec#: 41832] Exclude at abstract screening: not about end of life.
Kosco M, Warren N A. Critical care nurses' perceptions of family needs as met. Crit Care Nurs Q. 2000;23(2):60-72. [Rec#: 41834] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11853028].
Koster M E, Bergsma J. Problems and coping behaviour of facial cancer patients. Soc Sci Med. 90;30(5):569-78. [Rec#: 12783] Exclude at abstract screening: not about end of life. [pmid: 2408153].
Kovacs P J, Rodgers A Y. Meeting the social service needs of persons with AIDS: hospices' response. Hosp J. 95;10(4):49-65. [Rec#: 12790] Exclude at abstract screening: useful only for background. [pmid: 8698301].
Koval M, Dobie S. Why do the elderly seek or avoid care? A qualitative analysis. Fam Med. 96;28(5):352-7. [Rec#: 41838] Exclude at abstract screening: not about end of life. [pmid: 8735063].
Kowalski L P, Carvalho A L. Natural history of untreated head and neck cancer. Eur J Cancer. 2000;36(8):1032-7. [Rec#: 4037] Exclude at abstract screening: data older than 1990. [pmid: 10885608].
Kowalski L P, Bagietto R, Lara J R, Santos R L, Silva J F Jr, Magrin J. Prognostic significance of the distribution of neck node metastasis from oral carcinoma. Head Neck. 2000;22(3):207-14. [Rec#: 4036] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 10748442].
Krakauer E L, Crenner C, Fox K. Barriers to optimum end-of-life care for minority patients. J Am Geriatr Soc. 2002;50(1):182-90. [Rec#: 12793] Exclude at abstract screening: useful only for background. [pmid: 12028266].
Krakauer E L, Penson R T, Truog R D, King L A, Chabner B A, Lynch T J Jr. Sedation for intractable distress of a dying patient: acute palliative care and the principle of double effect. Oncologist. 2000;5(1):53-62. [Rec#: 4041] Exclude at abstract screening: Observational study. [pmid: 10706650].
Krakoff I H. Cessation of treatment in advanced cancer. Cancer. 91;67(6 Suppl):1817-9. [Rec#: 12794] Exclude at abstract screening: useful only for background. [pmid: 1705864].
Krassen Covan E. Cultural priorities and elder care: the impact on women. Health Care Women Int. 97;18(4):329-42. [Rec#: 41843] Exclude at abstract screening: Study Design - Unclear. [pmid: 9287560].
Kraus F, Levy J, Oliviere D. Brief report on user involvement at St Christopher's Hospice. Palliat Med. 2003;17(4):375-7. [Rec#: 12800] Exclude at abstract screening: not about end of life. [pmid: 12822855].
Krech R L, Walsh D. Symptoms of pancreatic cancer. J Pain Symptom Manage. 91;6(6):360-7. [Rec#: 4053] Exclude at abstract screening: not about end of life. [pmid: 1880437].
Krell R. Confronting despair: the Holocaust survivor's struggle with ordinary life and ordinary death. CMAJ 97;157(6):741–4. Erratum in: CMAJ 1997 Dec 1;157(11):1517. [Rec#: 12802] Exclude at abstract screening: Title Only
Kreps G J. The impact of communication on cancer risk, incidence, morbidity, mortality, and quality of life. Health Commun. 2003;15(2):161-9. [Rec#: 12804] Exclude at abstract screening: no outcomes specified. [pmid: 12742767].
Kressig R W, Wolf S L, Sattin R W, O'Grady M, Greenspan A, Curns A, Kutner M. Associations of demographic, functional, and behavioral characteristics with activity-related fear of falling among older adults transitioning to frailty. J Am Geriatr Soc. 2001;49(11):1456-62. [Rec#: 41851] Exclude at abstract screening: not about end of life. [pmid: 11890583].
Kris M G, Roila F, De Mulder P H, Marty M. Delayed emesis following anticancer chemotherapy. Support Care Cancer. 98;6(3):228-32. [Rec#: 12806] Exclude at abstract screening: Non-systematic review. [pmid: 9629874].
Krishnasamy M, Corner J, Bredin M, Plant H, Bailey C. Cancer nursing practice development: understanding breathlessness. J Clin Nurs. 2001;10(1):103-8. [Rec#: 12808] Exclude at abstract screening: not about end of life. [pmid: 11820227].
Krishnasamy M. Fatigue in advanced cancer - meaning before measurement?. Int J Nurs Stud. 2000;37(5):401-14. [Rec#: 12807] Exclude at abstract screening: Study Design - Qualitative. [pmid: 10785531].
Krisman-Scott M A, McCorkle R. The tapestry of hospice. Holist Nurs Pract. 2002;16(2):32-9. [Rec#: 12810] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11845764].
Krisman-Scott M A. An historical analysis of disclosure of terminal status. J Nurs Scholarsh. 2000;32(1):47-52. [Rec#: 12809] In abstract review process. [pmid: 10819738].
Kristjanson L J, Balneaves L. Directions for palliative care nursing in Canada: report of a national survey. J Palliat Care. 95;11(3):5-8. [Rec#: 12811] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Kristjanson LJ and White K. Clinical support for families in the palliative care phase of hematologic or oncologic illness. Hematol Oncol Clin North Am 2002;16(3):745–62, xi. [Rec#: 12813] Exclude at abstract screening: Study Design - Unclear
Kristjanson L J, McPhee I, Pickstock S, Wilson D, Oldham L, Martin K. Palliative care nurses' perceptions of good and bad deaths and care expectations: a qualitative analysis. Int J Palliat Nurs. 2001;7(3):129-39. [Rec#: 4064] Exclude at abstract screening: Observational study. [pmid: 12192329].
Kristjanson L J, Nikoletti S, Porock D, Smith M, Lobchuk M, Pedler P. Congruence between patients' and family caregivers' perceptions of symptom distress in patients with terminal cancer. J Palliat Care. 98;14(3):24-32. [Rec#: 4065] Exclude at abstract screening: Title Only.
Kristjanson L J, Toye C, Dawson S. New dimensions in palliative care: a palliative approach to neurodegenerative diseases and final illness in older people. Med J Aust. 2003;179(6 Suppl):S41-3. [Rec#: 4067] Exclude at abstract screening: useful only for background. [pmid: 12964937].
Kristjanson L J. Indicators of quality of palliative care from a family perspective. Journal of Palliative Care. 86;1(2):8-17. [Rec#: 50529] Exclude at abstract screening: no outcomes specified. [pmid: 2453638].
Kristjanson L J. Quality of terminal care: salient indicators identified by families. Journal of Palliative Care. 89;5(1):21-30. [Rec#: 50530] Exclude at abstract screening: Study Design - Unclear.
Kristjanson L J, Atwood J, Degner L F. Validity and reliability of the family inventory of needs (FIN): measuring the care needs of families of advanced cancer patients. Journal of Nursing Measurement. 95;3(2):109-26. [Rec#: 50532] Exclude at abstract screening: Study Design - Unclear.
Krivickas L S, Shockley L, Mitsumoto H. Home care of patients with amyotrophic lateral sclerosis (ALS). J Neurol Sci. 97;152(Suppl 1):S82-9. [Rec#: 4068] Exclude at abstract screening: not about end of life.
Krout R E. Music therapy with imminently dying hospice patients and their families: facilitating release near the time of death. Am J Hosp Palliat Care. 2003;20(2):129-34. [Rec#: 4075] Exclude at abstract screening: Observational study. [pmid: 12693645].
Krozek C F. Helping stressed families on an I.C.U. Nursing. 91;21(1):52-5. [Rec#: 12821] Exclude at abstract screening: Title Only. [pmid: 1988866].
Kruijver I P, Kerkstra A, Francke A L, Bensing J M, van de Wiel H B. Evaluation of communication training programs in nursing care: a review of the literature. Patient Educ Couns. 2000;39(1):129-45. [Rec#: 50139] Exclude at abstract screening: useful only for background. [pmid: 11013554].
Krumholz H M, Chen Y T, Wang Y, Vaccarino V, Radford M J, Horwitz R I. Predictors of readmission among elderly survivors of admission with heart failure. Am Heart J. 2000;139(1 Pt 1):72-7. [Rec#: 50054] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 10618565].
Krumholz H M, Parent E M, Tu N, Vaccarino V, Wang Y, Radford M J, Hennen J. Readmission after hospitalization for congestive heart failure among Medicare beneficiaries. Arch Intern Med 97;157(1):99–104. Comment in: Arch Intern Med. 1997 Jan 13;157(1):17–9. PMID: 8996037. Comment in: Arch Intern Med. Jun 23. 1997;157(12):1393. PMID: 9201020. [Rec#: 50055] Exclude at abstract screening: Title Only.
Kruse W. Early readmission of elderly patients with congestive heart failure. J Am Geriatr Soc 91;39(10):1045–6. Comment on: J Am Geriatr Soc. Dec. 1990;38(12):1290-5. PMID: 2254567. [Rec#: 50056] Exclude at abstract screening: Title Only.
Ku Y, Iwasaki T, Fukumoto T, Tominaga M, Muramatsu S, Kusunoki N, Sugimoto T, Suzuki Y, Kuroda Y, Saitoh Y, Sako M, Matsumoto S, Hirota S, Obara H. Induction of long-term remission in advanced hepatocellular carcinoma with percutaneous isolated liver chemoperfusion. Ann Surg. 98;227(4):519-26. [Rec#: 4082] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Kub J E, Nolan M T, Hughes M T, Terry P B, Sulmasy D P, Astrow A, Forman J H. Religious importance and practices of patients with a life-threatening illness: implications for screening protocols. Appl Nurs Res. 2003;16(3):196-200. [Rec#: 41861] Exclude at abstract screening: not about end of life. [pmid: 12931334].
Kuczewski M G, DeVita M. Managed care and end-of-life decisions: learning to live ungagged. Arch Intern Med 98;158(22):2424–8. Comment in: Arch Intern Med. Dec 7–21. 1998;158(22):2419-22. PMID: 9855378. [Rec#: 4087] Exclude at abstract screening: useful only for background.
Kuebler K K, Bruera E. Interactive collaborative consultation model in end-of-life care. J Pain Symptom Manage. 2000;20(3):202-9. [Rec#: 12830] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11018338].
Kuebler K K. The palliative care advanced practice nurse. J Palliat Med. 2003;6(5):707-14. [Rec#: 12828] Exclude at abstract screening: useful only for background. [pmid: 14622450].
Kuhl D. Dancing across the lines: people in pain. J Palliat Care. 95;11(2):26-9. [Rec#: 4088] Exclude at abstract screening: Title Only. [pmid: 7541073].
Kumar A. Organization and development of pain clinics and palliative care in developing countries. Eur J Anaesthesiol. 2004;21(3):169-72. [Rec#: 4095] Exclude at abstract screening: Title Only. [pmid: 15055887].
Kuntz B. Exploring the grief of adolescents after the death of a parent. J Child Adolesc Psychiatr Ment Health Nurs. 91;4(3):105-9. [Rec#: 41868] Notes: “EXCLUDE: Age, not adults”. [pmid: 1748949].
Kunz R. [Palliative care for patients with advanced dementia: Evidence-based practice replaced by values-based practice]. Z Gerontol Geriatr. 2003;36(5):355-9. [Rec#: 4103] Exclude at abstract screening: useful only for background. [pmid: 14579062].
Kuo L J, Leu S Y, Liu M C, Jian J J, Hongiun Cheng S, Chen C M. How aggressive should we be in patients with stage IV colorectal cancer?. Dis Colon Rectum. 2003;46(12):1646-52. [Rec#: 4105] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 14668590].
Kurrle S E, Sadler P M, Lockwood K, Cameron I D. Elder abuse: prevalence, intervention and outcomes in patients referred to four Aged Care Assessment Teams. Med J Aust 97;166(3):119–22. Comment in: Med J Aust. Feb 3. 1997;166(3):115. PMID: 9059428. [Rec#: 41870] Exclude at abstract screening: not about end of life.
Kutner J S, Blake M, Meyer S A. Predictors of live hospice discharge: data from the National Home and Hospice Care Survey (NHHCS). Am J Hosp Palliat Care. 2002;19(5):331-7. [Rec#: 4120] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 12269779].
Kutner J S, Steiner J F, Corbett K K, Jahnigen D W, Barton P L. Information needs in terminal illness. Soc Sci Med. 99;48(10):1341-52. [Rec#: 4122] Exclude at abstract screening: Study Design - Qualitative. [pmid: 10369435].
Kuuppelomaki M, Lauri S. Cancer patients' reported experiences of suffering. Cancer Nurs. 98;21(5):364-9. [Rec#: 4128] Exclude at abstract screening: Study Design - Qualitative. [pmid: 9775487].
Kuuppelomaki M, Lauri S. Cancer patients' reported experiences of suffering. Clin J Oncol Nurs. 2000;4(1):45-6. [Rec#: 12847] Exclude at abstract screening: Title Only. [pmid: 10865584].
Kuuppelomaki M, Lauri S. Ethical dilemmas in the care of patients with incurable cancer. Nurs Ethics. 98;5(4):283-93. [Rec#: 4129] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Kuuppelomaki M. Emotional support for dying patients--the nurses' perspective. Eur J Oncol Nurs. 2003;7(2):120-9. [Rec#: 4124] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12849565].
Kuuppelomaki M. Ethical decision making on starting terminal care in different health-care units. J Adv Nurs. 93;18(2):276-80. [Rec#: 4125] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Kuuppelomaki M. Spiritual support for terminally ill patients: nursing staff assessments. J Clin Nurs. 2001;10(5):660-70. [Rec#: 4127] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11822517].
Kuyvenhoven M M, Kastein M, Luttik K, de Melker R A. Independently living disabled elderly: first results from an innovative home care project in Haarlem, The Netherlands. Home Health Care Serv Q. 95;15(2):99-110. [Rec#: 41873] Exclude at abstract screening: Title Only.
Kvale J, Berg L, Groff J Y, Lange G. Factors associated with residents' attitudes toward dying patients. Fam Med 99;31(10):691–6. Comment in: Fam Med. Apr. 2000;32(4):226. PMID: 10782365. [Rec#: 4132] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Kwan C. Families' experiences of the last office of deceased family members in the hospice setting. Int J Palliat Nurs. 2002;8(6):266-75. [Rec#: 4135] Notes: “EXCLUDE: Location, non-Western”. [pmid: 12131820].
Kwan C. Families' experiences of the last office of deceased family members in the hospice setting. International Journal of Palliative Nursing. 2002;8(6):266-75. [Rec#: 50533] Notes: “EXCLUDE: Location, non-Western”. [pmid: 12131820].
Kylmala T, Tammela T, Risteli L, Risteli J, Taube T, Elomaa I. Evaluation of the effect of oral clodronate on skeletal metastases with type 1 collagen metabolites. A controlled trial of the Finnish Prostate Cancer Group. Eur J Cancer. 93;29A(6):821-5. [Rec#: 4142] Exclude at abstract screening: not about end of life.
La Puma J, Schiedermayer D, Siegler M. How ethics consultation can help resolve dilemmas about dying patients. West J Med. 95;163(3):263-7. [Rec#: 12855] Exclude at abstract screening: Title Only. [pmid: 7571590].
La Puma J. What a physician can learn in the role of family member. Manag Care. 97;6(11):85-6. [Rec#: 12854] Exclude at abstract screening: Title Only. [pmid: 10176726].
Labrecque M S, Peak T, Toseland R W. Long-term effectiveness of a group program for caregivers of frail elderly veterans. Am J Orthopsychiatry. 92;62(4):575-88. [Rec#: 41875] Exclude at abstract screening: not about end of life.
Lackan N A, Freeman J L, Goodwin J S. Hospice use by older women dying with breast cancer between 1991 and 1996. J Palliat Care. 2003;19(1):49-53. [Rec#: 4154] Exclude at abstract screening: useful only for background. [pmid: 12710115].
Lackan N A, Ostir G V, Freeman J L, Mahnken J D, Goodwin J S. Decreasing variation in the use of hospice among older adults with breast, colorectal, lung, and prostate cancer. Med Care. 2004;42(2):116-22. [Rec#: 4155] Exclude at abstract screening: useful only for background. [pmid: 14734948].
LaDuke S. Terminal dyspnea & palliative care. Am J Nurs. 2001;101(11):26-31. [Rec#: 4160] Exclude at abstract screening: Title Only. [pmid: 11718110].
Lagergren M. The systems of care for frail elderly persons: the case of Sweden. Aging Clin Exp Res. 2002;14(4):252-7. [Rec#: 41879] Exclude at abstract screening: no outcomes specified. [pmid: 12462369].
Lagrand L E. United we cope: support groups for the dying and bereaved. Death Stud. 91;15(2):207-30. [Rec#: 12870] Exclude at abstract screening: useful only for background. [pmid: 10110548].
Lamb V L. A cross-national study of quality of life factors associated with patterns of elderly disablement. Soc Sci Med. 96;42(3):363-77. [Rec#: 41882] Notes: “EXCLUDE: Location, non-Western”. [pmid: 8658231].
Lamers WM Jr. Hospice: enhancing the quality of life. Oncology (Huntingt) 90;4(5):121–6; discussion 129. [Rec#: 12884] Exclude at abstract screening: no outcomes specified
Lammers S R. Making Michigan a model in palliative care. Mich Med. 98;98(9):18-22. [Rec#: 4169] Exclude at abstract screening: useful only for background. [pmid: 9841282].
Lamont EB and Christakis NA. Some elements of prognosis in terminal cancer. Oncology (Huntingt) 99;13(8):1165–70; discussion 1172–4, 1179–80. [Rec#: 12887] Exclude at abstract screening: primarily prognosis or trajectories
Lampley-Dallas V T, Mold J W, Flori D E. Perceived needs of African-American caregivers of elders with dementia. J Natl Med Assoc. 2001;93(2):47-57. [Rec#: 41883] Exclude at abstract screening: not about end of life. [pmid: 12653382].
Lamy O, Jenzer-Closuit A, Burckhardt P. Hypercalcaemia of malignancy: an undiagnosed and undertreated disease. J Intern Med. 2001;250(1):73-9. [Rec#: 12889] Exclude at abstract screening: not about end of life. [pmid: 11454145].
Lander M, Wilson K, Chochinov H M. Depression and the dying older patient. Clin Geriatr Med. 2000;16(2):335-56. [Rec#: 4172] Exclude at abstract screening: no outcomes specified. [pmid: 10783432].
Landi F, Cesari M, Russo A, Onder G, Lattanzio F, Bernabei R. Silvernet-HC Study Group. Potentially reversible risk factors and urinary incontinence in frail older people living in community. Age Ageing. 2003;32(2):194-9. [Rec#: 41885] Exclude at abstract screening: not about end of life. [pmid: 12615564].
Landi F, Cesari M, Russo A, Onder G, Sgadari A, Bernabei R. Silvernet-HC Study Group. Benzodiazepines and the risk of urinary incontinence in frail older persons living in the community. Clin Pharmacol Ther. 2002;72(6):729-34. [Rec#: 41886] Exclude at abstract screening: not about end of life. [pmid: 12496754].
Landi F, Gambassi G, Pola R, Tabaccanti S, Cavinato T, Carbonin P U, Bernabei R. Impact of integrated home care services on hospital use. J Am Geriatr Soc. 99;47(12):1430-4. [Rec#: 41887] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Landi F, Lattanzio F, Gambassi G, Zuccala G, Sgadari A, Panfilo M, Ruffilli M P, Bernabei R. A model for integrated home care of frail older patients: the Silver Network project. SILVERNET-HC Study Group. Aging (Milano). 99;11(4):262-72. [Rec#: 41888] Exclude at abstract screening: no outcomes specified.
Landi F, Onder G, Cattel C, Gambassi G, Lattanzio F, Cesari M, Russo A, Bernabei R. Silvernet-HC Study Group. Functional status and clinical correlates in cognitively impaired community-living older people. J Geriatr Psychiatry Neurol. 2001;14(1):21-7. [Rec#: 41889] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 11281312].
Landi F, Onder G, Russo A, Tabaccanti S, Rollo R, Federici S, Tua E, Cesari M, Bernabei R. A new model of integrated home care for the elderly: impact on hospital use. J Clin Epidemiol. 2001;54(9):968-70. [Rec#: 41891] Exclude at abstract screening: not about end of life. [pmid: 11520658].
Landi F, Onder G, Tua E, Carrara B, Zuccala G, Gambassi G, Carbonin P, Bernabei R. Silvernet-HC Study Group of Bergamo. Impact of a new assessment system, the MDS-HC, on function and hospitalization of homebound older people: a controlled clinical trial. J Am Geriatr Soc. 2001;49(10):1288-93. [Rec#: 41892] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11890486].
Landon L. 2000 Amulree Essay Prize. CPR-when is it acceptable to withhold it? And a hospital survey of ‘not for CPR’ orders. Age Ageing. 2000;29(Suppl 1):9-16. [Rec#: 41894] Exclude at abstract screening: Title Only. [pmid: 10976351].
Lane D A, Lip G Y, Millane T A. Quality of life in adults with congenital heart disease. Heart. 2002;88(1):71-5. [Rec#: 4177] Exclude at abstract screening: not about end of life. [pmid: 12067950]. [pmcid: 1767157].
Lane P, Kuntupis M, MacDonald S, McCarthy P, Panke J A, Warden V, Volicer L. A pain assessment tool for people with advanced Alzheimer's and other progressive dementias. Home Healthc Nurse. 2003;21(1):32-7. [Rec#: 12895] Exclude at abstract screening: useful only for background. [pmid: 12544460].
Langa K M, Chernew M E, Kabeto M U, Katz S J. The explosion in paid home health care in the 1990s: who received the additional services?. Med Care. 2001;39(2):147-57. [Rec#: 41896] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11176552].
Langenhoff B S, Krabbe P F, Wobbes T, Ruers T J. Quality of life as an outcome measure in surgical oncology. Br J Surg. 2001;88(5):643-52. [Rec#: 12897] In abstract review process. [pmid: 11350434].
Langerman A, Angelos P, Johnston C. Opinions and use of advance directives by physicians at a tertiary care hospital. Qual Manag Health Care. 2000;8(3):14-8. [Rec#: 4191] Exclude at abstract screening: not about end of life. [pmid: 10947380].
Langford JM. Death and Dying in Ethnic America: Findings in Lao Lum, Khmu, Hmong, Kher, and Cham Communities. 2000;<25 Page(s)>. [Rec#: 50535] Exclude at abstract screening: Title Only
Langs R. Adaptive insights into death anxiety. Psychoanal Rev. 2003;90(4):565-82. [Rec#: 41898] Exclude at abstract screening: Title Only. [pmid: 14694764].
Lantz E J. Life-or-death decisions and informed consent. Communication key to hospital informed consent policies. QRC Advis. 99;15(6):8-12. [Rec#: 41902] Exclude at abstract screening: Title Only. [pmid: 10351203].
Lapine A, Wang-Cheng R, Goldstein M, Nooney A, Lamb G, Derse A R. When cultures clash: physician, patient, and family wishes in truth disclosure for dying patients. J Palliat Med. 2001;4(4):475-80. [Rec#: 4207] Exclude at abstract screening: useful only for background. [pmid: 11798479].
Lark J, Gatti C. Compliance with advance directives: nursing's view. Crit Care Nurs Q. 99;22(3):65-71. [Rec#: 4209] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10646453].
Larkin G L. Termination of resuscitation: the art of clinical decision making. Curr Opin Crit Care. 2002;8(3):224-9. [Rec#: 41903] Exclude at abstract screening: useful only for background. [pmid: 12386501].
Larsen G. Family members' experiences with do-not-resuscitate (DNR). J Fam Issues. 99;20(2):269-89. [Rec#: 41904] Exclude at abstract screening: Title Only. [pmid: 14509298].
Larson D G, Tobin D R. End-of-life conversations: evolving practice and theory. JAMA. 2000;284(12):1573-8. [Rec#: 12913] Exclude at abstract screening: no outcomes specified. [pmid: 11000655].
Larson J S, Larson K K. Evaluating end-of-life care from the perspective of the patient's family. Eval Health Prof. 2002;25(2):143-51. [Rec#: 4211] Exclude at abstract screening: no outcomes specified. [pmid: 12026749].
Laschinger S J, Fothergill-Bourbonnais F. The experience of pain in persons with HIV/AIDS. J Assoc Nurses AIDS Care. 99;10(5):59-67. [Rec#: 4214] Exclude at abstract screening: not about end of life. [pmid: 10491803].
Last Acts Task Force on Palliative Care. Precepts of Palliative Care. 1997;<25 Page(s)>. [Rec#: 50537] Exclude at abstract screening: Title Only
Last Acts. Means to a Better End: A Report on Dying in America Today. 2002;<25 Page(s)>. [Rec#: 50536] Exclude at abstract screening: Title Only
Latagliata R, Alimena G, Carmosino I, Breccia M, Borza P A, Bongarzoni V, Copia C, Spadea A, Pinazzi B, Frattarelli N, Ferrara F, Petti M C, Mandelli F. Conservative treatment for patients over 80 years with acute myelogenous leukemia. Am J Hematol. 2002;71(4):256-9. [Rec#: 4216] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 12447953].
Latagliata R, Petti M C, Mandelli F. Acute myeloid leukemia in the elderly: ‘per aspera ad astra’?. Leuk Res. 99;23(7):603-13. [Rec#: 4217] Exclude at abstract screening: Title Only. [pmid: 10400181].
Latham D. How the district nurse cares for the terminally ill patient with cachexia. Br J Community Nurs. 2001;6(1):5-10. [Rec#: 12922] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11972110].
Latimer E. Caring for seriously ill and dying patients: the philosophy and ethics. CMAJ. 91;144(7):859-64. [Rec#: 12923] Exclude at abstract screening: not about end of life. [pmid: 1706641].
Latimer E A, Verrilli D, Welch W P. Utilization of physician services at the end of life: differences between the United States and Canada. Inquiry. 99;36(1):90-100. [Rec#: 4218] Exclude at abstract screening: useful only for background.
Latimer E J, Dawson H R. Palliative care: principles and pracice. Section of Palliative Care, Ontario Medical Association. CMAJ 93;148(6):933–6. Comment in: CMAJ. Mar 15. 1993;148(6):891-6. PMID: 7680600. [Rec#: 12926] Exclude at abstract screening: no outcomes specified.
Latimer E J, Porterfield P, Roberts J G. A patient care travelling record for palliative care: a feasibility study. J Palliat Care. 91;7(2):30-6. [Rec#: 4221] Exclude at abstract screening: no outcomes specified.
Latimer E J. Ethical care at the end of life. CMAJ 98;158(13):1741–7. Comment in: CMAJ. 1998 Nov 3;159(9):1081–2. PMID: 9835870. Comment in: CMAJ. Oct 20. 1998;159(8):919-20. PMID: 9834711. [Rec#: 4219] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Latimer E J. The ethics of partial palliative care. J Palliat Care. 94;10(3):107-10. [Rec#: 12925] Exclude at abstract screening: Title Only. [pmid: 7531227].
Lau W Y, Leung K L, Leung T W, Ho S, Chan M, Liew C K, Leung N, Johnson P, Li A K. Obstructive jaundice secondary to hepatocellular carcinoma. Surg Oncol. 95;4(6):303-8. [Rec#: 4225] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Laukhuf G, Werner H. Spirituality: the missing link. J Neurosci Nurs. 98;30(1):60-7. [Rec#: 4231] Exclude at abstract screening: no outcomes specified. [pmid: 9604824].
Laval G, Girardier J, Lassauniere J M, Leduc B, Haond C, Schaerer R. The use of steroids in the management of inoperable intestinal obstruction in terminal cancer patients: do they remove the obstruction?. Palliat Med. 2000;14(1):3-10. [Rec#: 4236] Exclude at abstract screening: Other symptoms only. [pmid: 10717717].
Lavery M. Death and dying, oh no!. Sr Nurse. 93;13(6):32-5. [Rec#: 12933] Exclude at abstract screening: Title Only. [pmid: 8265956].
Law R. The quality of district nursing care for dying patients. Nurs Stand. 97;12(7):41-4. [Rec#: 12934] Exclude at abstract screening: Study Design - Qualitative. [pmid: 9418452].
Lawhorne L W, Walker G, Zweig S C, Snyder J. Who cares for Missouri's Medicaid nursing home residents? Characteristics of attending physicians. J Am Geriatr Soc 93;41(4):454–8. Comment in: J Am Geriatr Soc. Apr. 1993;41(4):459. PMID: 8463536. [Rec#: 50058] Exclude at abstract screening: Title Only.
Lawhorne L W. End-of-life care in the nursing home--is a good death compatible with regulatory compliance?. Bioethics Forum. 99;15(3):23-8. [Rec#: 4244] Exclude at abstract screening: no outcomes specified.
Lawlor P G, Bruera E D. Delirium in patients with advanced cancer. Hematol Oncol Clin North Am. 2002;16(3):701-14. [Rec#: 12937] Exclude at abstract screening: no outcomes specified. [pmid: 12170576].
Lawlor P G. Delirium and dehydration: some fluid for thought? Support Care Cancer 2002;10(6):445–54. Comment in: Support Care Cancer. Sep. 2002;10(6):443-4. PMID: 12362918. [Rec#: 12936] Exclude at abstract screening: Non-systematic review.
Lawlor P G, Turner K S, Hanson J, Bruera E D. Dose ratio between morphine and methadone in patients with cancer pain: a retrospective study. Cancer. 98;82(6):1167-73. [Rec#: 50539] Exclude at abstract screening: Observational study.
Lawlor P G, Watanabe S, Walker P, Bruera E. Re: Memorial Delirium Assessment Scale and commentary. Journal of Pain & Symptom Management. 98;15(2):73-5. [Rec#: 50540] Exclude at abstract screening: not about end of life.
Lawrence L. “Till death do us part”: the application of object relations theory to facilitate mourning in a young widows' group. Soc Work Health Care. 92;16(3):67-81. [Rec#: 4247] Exclude at abstract screening: no outcomes specified.
Lawrie I, Lloyd-Williams M, Waterhouse E. Breakthrough strong opioid analgesia prescription in patients using transdermal fentanyl admitted to a hospice. Am J Hosp Palliat Care 2003;20(3):229–30. Comment in: Am J Hosp Palliat Care. Sep-Oct. 2003;20(5):334. PMID: 14529035. [Rec#: 12939] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Layde P M, Beam C A, Broste S K, Connors A F Jr, Desbiens N, Lynn J, Phillips R S, Reding D, Teno J, Vidaillet H, et al. Surrogates' predictions of seriously ill patients' resuscitation preferences. Arch Fam Med 95;4(6):518–23. Comment in: Arch Fam Med. Jun. 1995;4(6):503-4. PMID: 7773424. [Rec#: 41915] Exclude at abstract screening: Duplicate already in the flow.
Layson RT, Adelman HM, Wallach PM, Pfeifer MP, Johnston S, and McNutt RA. Discussions about the use of life-sustaining treatments: a literature review of physicians' and patients' attitudes and practices. End of Life Study Group. J Clin Ethics 94;5(3):195–203. Comment in: J Clin Ethics. 1994 Fall;5(3):250–1. PMID: 7841478. Comment in: J Clin Ethics. 1994 Fall;5(3):253–6. PMID: 7841479. [Rec#: 12946] Exclude at abstract screening: outcome unrelated to pts/family/non-prof
Lazaro L, Marcos T, Valdes M. Affective disorders, social support, and health status in geriatric patients in a general hospital. Gen Hosp Psychiatry. 95;17(4):299-304. [Rec#: 41917] Exclude at abstract screening: not about end of life.
Lazerowich V. Development of a patient classification system for a home-based hospice program. J Community Health Nurs. 95;12(2):121-6. [Rec#: 12950] Exclude at abstract screening: no outcomes specified.
Lazowski D A, Ecclestone N A, Myers A M, Paterson D H, Tudor-Locke C, Fitzgerald C, Jones G, Shima N, Cunningham D A. A randomized outcome evaluation of group exercise programs in long-term care institutions. J Gerontol A Biol Sci Med Sci. 99;54(12):M621-8. [Rec#: 41918] Exclude at abstract screening: not about end of life.
Leahy J M. Validity and reliability of the Beck Depression Inventory-Short Form in a group of adult bereaved females. J Clin Psychol. 92;48(1):64-8. [Rec#: 4260] Exclude at abstract screening: not about end of life.
Leahy M E. Factors affecting end-stage disease quality of life. Patient and caregiver burdens of terminal illness. Clin J Oncol Nurs. 2000;4(6):285-6. [Rec#: 12956] Exclude at abstract screening: Title Only. [pmid: 11899328].
Lear MW. Should doctors tell the truth? The case against terminal candor. N Y Times Mag 93;16–7. [Rec#: 12958] Exclude at abstract screening: Title Only
Lebowitz B D, Pearson J L, Schneider L S, Reynolds C F 3rd, Alexopoulos G S, Bruce M L. Diagnosis and treatment of depression in late life-consensus statement update. Journal of the American Medical Association. 97;248:1186-119. [Rec#: 50542] Exclude at abstract screening: Title Only.
Lechich A J. The elements of risk for the institutionalized elderly. J Long Term Home Health Care. 97;16(2):56-61. [Rec#: 41919] Exclude at abstract screening: Title Only. [pmid: 10168385].
Lecouturier J, Jacoby A, Bradshaw C, Lovel T, Eccles M. Lay carers' satisfaction with community palliative care: results of a postal survey. South Tyneside MAAG Palliative Care Study Group. Palliat Med. 99;13(4):275-83. [Rec#: 12963] Exclude at abstract screening: Title Only.
Leder S N. Life events, social support, and children's competence after parent and sibling death. J Pediatr Nurs. 92;7(2):110-9. [Rec#: 41920] Notes: “EXCLUDE: Age, not adults”. [pmid: 1373772].
Leduc N, Tannenbaum T N, Bergman H, Champagne F, Clarfield A M, Kogan S. Compliance of frail elderly with health services prescribed at discharge from an acute-care geriatric ward. Med Care. 98;36(6):904-14. [Rec#: 41921] Exclude at abstract screening: not about end of life.
Lee A L. Living benefits: a right of the terminally ill. Boston Univ Public Interest Law J. 92;2(1):55-76. [Rec#: 12967] Exclude at abstract screening: no outcomes specified. [pmid: 11652210].
Lee A O. End-of-life care: challenges and obligations in setting limits to life-sustaining therapy. Ann Acad Med Singapore. 2003;32(6):785-9. [Rec#: 4272] Exclude at abstract screening: no outcomes specified. [pmid: 14716947].
Lee D S, McPherson M L, Zuckerman I H. Quality assurance: documentation of pain assessment in hospice patients. Am J Hosp Palliat Care. 92;9(1):38-43. [Rec#: 12969] Exclude at abstract screening: Title Only. [pmid: 1540427].
Lee F. Future End-of-Life Care: Best Ideas, Practices, and Policies: Proceedings of the W.K.Kellogg Foundation National Leadership Seminar. Warrenton, VA, USA. November 17–20, 2001. Journal of Palliative Medicine. 2002;5(2):239-41. [Rec#: 50163] Exclude at abstract screening: Study Design - Unclear. [pmid: 12006223].
Lee G. Death in the workplace. AAOHN J 94;42(12):590–4. Comment in: AAOHN J. Mar. 1995;43(3):122. PMID: 7702677. [Rec#: 12970] Exclude at abstract screening: sudden/violent/non-chronic deaths.
Lee J A. Balancing elder care responsibilities and work: two empirical studies. J Occup Health Psychol. 97;2(3):220-8. [Rec#: 41922] Exclude at abstract screening: not about end of life. [pmid: 9552292].
Lee K F. Future end-of-life care: partnership and advocacy. J Palliat Med. 2002;5(2):329-34. [Rec#: 12972] Exclude at abstract screening: Title Only. [pmid: 12006236].
Lee L. Interprofessional working in hospice day care and the patients' experience of the service. Int J Palliat Nurs. 2002;8(8):389-400. [Rec#: 4285] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12271260].
Lee O J, Pilkington F B. Practice with persons living their dying: a human becoming perspective. Nurs Sci Q. 99;12(4):324-8. [Rec#: 4295] Exclude at abstract screening: no outcomes specified. [pmid: 11847638].
Lee R. Peaceful passing. Nursing. 95;25(6):17. [Rec#: 4296] Exclude at abstract screening: Title Only. [pmid: 7624066].
Lee S, Cowie S, Slobodian P. Payment by salary or fee-for-service. Effect on health care resource use in the last year of life. Can Fam Physician. 99;45:2091-6. [Rec#: 41924] Exclude at abstract screening: not about end of life.
Lee T, Kovner C T, Mezey M D, Ko I S. Factors influencing long-term home care utilization by the older population: implications for targeting. Public Health Nurs. 2001;18(6):443-9. [Rec#: 41927] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11737813].
Lee T. The relationship between severity of physical impairment and costs of care in an elderly population. Geriatr Nurs. 2000;21(2):102-6. [Rec#: 41926] Exclude at abstract screening: not about end of life. [pmid: 10769337].
Lee W, Eng C, Fox N, and Etienne M. PACE: a model for integrated care of frail older patients. Program of All-inclusive Care for the Elderly. Geriatrics 98;53(6):62, 65–6, 69, 73; quiz 74. [Rec#: 41928] Exclude at abstract screening: not about end of life
Lee Y. The predictive value of self assessed general, physical, and mental health on functional decline and mortality in older adults. J Epidemiol Community Health. 2000;54(2):123-9. [Rec#: 4298] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 10715745].
Lee M A, Smith D M, Fenn D S, Ganzini L. Do patients' treatment decisions match advance statements of their preferences?. Journal of Clinical Ethics. 98;9(3):258-62. [Rec#: 50543] Exclude at abstract screening: Title Only. [pmid: 10029826].
Lee P E, Gill S S, Freedman M, Bronskill S E, Hillmer M P, Rochon P A. A typical antipsychotic drugs in the treatment of behavioural and psychological symptoms of dementia: systematic review. BMJ. 2004;329(7457):75. [Rec#: 50855] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 15194601]. [pmcid: 449807].
Lee, S. J., Back, A. L., Block, S. D., and Stewart, S. K. Enhancing physician-patient communication. Hematology (Am Soc Hematol Educ Program) 2002;464–83. [Rec#: 50544] Exclude at abstract screening: no outcomes specified
Leeson G W. General and specific aspects of emergency response systems in Denmark. Home Health Care Serv Q. 92;13(34):41-55. [Rec#: 41929] Exclude at abstract screening: Title Only. [pmid: 10126448].
Leeson G W. The situation of the elderly in Denmark. Dan Med Bull. 92;39(3):220-3. [Rec#: 41930] Exclude at abstract screening: no outcomes specified. [pmid: 1638881].
Leff E W, Lambert P. Improving the performance of continuous care hospice nurses. Home Healthc Nurse. 2001;19(2):95-102. [Rec#: 12985] Exclude at abstract screening: Title Only. [pmid: 11985226].
Leff EW, Cohen CE, and Wright BJ. Avoiding the pitfalls of hospice continuous care. Home Healthc Nurse 2001;19(1):31–6; quiz 37. [Rec#: 12984] Exclude at abstract screening: Title Only
Lefroy R B, Davey M, Hyndman J, Hobbs M S. A study of the characteristics and needs of people transferred from acute hospitals to nursing homes. Med J Aust. 93;159(6):385-8. [Rec#: 50059] Exclude at abstract screening: Title Only.
Lefroy R B, Hobbs M S, Hyndman J. A five-year study of residents of a special hostel for people with dementia. Aust J Public Health. 92;16(1):98-102. [Rec#: 50060] Exclude at abstract screening: not about end of life.
LeGardeur B Y, Fe-Bornstein M, Lopez A. The use of video tape in teaching how psychological factors influence nutritional status in chronic/terminal illness. J Cancer Educ. 91;6(4):213-7. [Rec#: 4308] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Legendre H, Vanhuyse F, Caroli-Bosc F X, Pector J C. Survival and quality of life after palliative surgery for neoplastic gastrointestinal obstruction. Eur J Surg Oncol. 2001;27(4):364-7. [Rec#: 4309] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 11417981].
Leggat J E Jr, Swartz R D, Port F K. Withdrawal from dialysis: a review with an emphasis on the black experience. Adv Ren Replace Ther. 97;4(1):22-9. [Rec#: 12986] Exclude at abstract screening: Non-systematic review.
LeGrand S B, Tropiano P, Marx J D, Davis M P, Walsh D. Dying at home: emergency medications for terminal symptoms. Am J Hosp Palliat Care. 2001;18(6):421-3. [Rec#: 12989] Exclude at abstract screening: no outcomes specified. [pmid: 11712726].
LeGrand S B. Communication in advanced disease. Curr Oncol Rep. 2000;2(4):358-61. [Rec#: 12988] Exclude at abstract screening: Observational study. [pmid: 11122865].
Leibowitz C, Browing S. The expanded team--hospice in the LTC facility. Am J Hosp Palliat Care. 95;12(2):16-7. [Rec#: 12995] Exclude at abstract screening: Title Only. [pmid: 7605726].
Leibson C, Owens T, O'Brien P, Waring S, Tangalos E, Hanson V, Plevak M, Kokmen E. Use of physician and acute care services by persons with and without Alzheimer's disease: a population-based comparison. J Am Geriatr Soc. 99;47(7):864-9. [Rec#: 50061] Exclude at abstract screening: Title Only.
Leichtentritt R D, Rettig K D. The good death: reaching an inductive understanding. Omega (Westport). 2000;41(3):221-48. [Rec#: 4314] Notes: “EXCLUDE: Location, non-Western”. [pmid: 12557884].
Leichtling B. Dealing with dying, death and grief. Caring. 2004;23(1):38-9. [Rec#: 12996] Exclude at abstract screening: Title Only. [pmid: 14870481].
Leighl N B, Shepherd F A, Kwong R, Burkes R L, Feld R, Goodwin P J. Economic analysis of the TAX 317 trial: docetaxel versus best supportive care as second-line therapy of advanced non-small-cell lung cancer. J Clin Oncol. 2002;20(5):1344-52. [Rec#: 12998] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 11870178].
Leikas J, Salo J, Poramo R. Security alarm system supports independent living of demented persons. Stud Health Technol Inform. 98;48:402-5. [Rec#: 50062] Exclude at abstract screening: Title Only. [pmid: 10186557].
Leipzig R M, Hyer K, Ek K, Wallenstein S, Vezina M L, Fairchild S, Cassel C K, Howe J L. Attitudes toward working on interdisciplinary healthcare teams: a comparison by discipline. Journal of the American Geriatrics Society. 2002;50(6):1141-8. [Rec#: 50545] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12110079].
Lekan-Rutledge D and Colling J. Urinary incontinence in the frail elderly: even when it's too late to prevent a problem, you can still slow its progress. Am J Nurs 2003;Suppl:36–46. [Rec#: 41941] Exclude at abstract screening: Title Only
Leland J. Advance directives and establishing the goals of care. Prim Care. 2001;28(2):349-63. [Rec#: 13001] Exclude at abstract screening: useful only for background. [pmid: 11406440].
Leland J Y, Schonwetter R S. Advances in hospice care. Clin Geriatr Med. 97;13(2):381-401. [Rec#: 4317] Exclude at abstract screening: useful only for background. [pmid: 9115457].
Leland J Y. Death and dying: management of patients with end-stage disease. Clin Geriatr Med. 2000;16(4):875-94. [Rec#: 4316] Exclude at abstract screening: no outcomes specified. [pmid: 10984761].
Leliopoulo C, Wilkinson S M, Fellowes D. Does truth telling improve psychological distress of palliative care patients: a systematic review. 2001;<25 Page(s)>. [Rec#: 50851] Exclude at abstract screening: Study Design - Review/Meta
Lelli G, Montanari M, Gilli G, Scapoli D, Antonietti C, Scapoli D. Treatment of the cancer anorexia-cachexia syndrome: a critical reappraisal. J Chemother. 2003;15(3):220-5. [Rec#: 13002] Exclude at abstract screening: not about end of life. [pmid: 12868546].
Lemkin, P. Cardiac care--the newest treatment in home care. Caring 94;13(2):22–4, 26. [Rec#: 13004] Exclude at abstract screening: not about end of life
Lemkin P. The challenges & rewards of a hospice volunteer program. Caring. 2001;20(2):38-9. [Rec#: 50546] Exclude at abstract screening: no outcomes specified. [pmid: 11219179].
Lens V, Pollack D. Advance directives: legal remedies and psychosocial interventions. Death Stud. 2000;24(5):377-99. [Rec#: 13010] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11067672].
Lentzner H R, Pamuk E R, Rhodenhiser E P, Rothenberg R, Powell-Griner E. The quality of life in the year before death. Am J Public Health. 92;82(8):1093-8. [Rec#: 4322] Exclude at abstract screening: primarily prognosis or trajectories.
Lenze E J, Rogers J C, Martire L M, Mulsant B H, Rollman B L, Dew M A, Schulz R, Reynolds C F 3rd. The association of late-life depression and anxiety with physical disability: a review of the literature and prospectus for future research. Am J Geriatr Psychiatry. 2001;9(2):113-35. [Rec#: 41945] Exclude at abstract screening: not about end of life. [pmid: 11316616].
Leonard K M, Enzle S S, McTavish J, Cumming C E, Cumming D. Prolonged cancer death. A family affair. Cancer Nurs. 95;18(3):222-7. [Rec#: 13015] Exclude at abstract screening: no outcomes specified. [pmid: 7600554].
Lerner E B, Billittier A J, Hallinan K. Out-of-hospital do-not-resuscitate orders by primary care physicians. J Emerg Med 2002;23(4):425–8. Comment in: J Emerg Med. Nov. 2002;23(4):419-20. PMID: 12480029. [Rec#: 41952] Exclude at abstract screening: no outcomes specified.
Leske J S, Jiricka M K. Impact of family demands and family strengths and capabilities on family well-being and adaptation after critical injury. Am J Crit Care. 98;7(5):383-92. [Rec#: 41959] Exclude at abstract screening: sudden/violent/non-chronic deaths.
Leske J S. Comparison ratings of need importance after critical illness from family members with varied demographic characteristics. Crit Care Nurs Clin North Am. 92;4(4):607-13. [Rec#: 41954] Exclude at abstract screening: data older than 1990.
Leske J S. Interventions to decrease family anxiety. Crit Care Nurse. 2002;22(6):61-5. [Rec#: 41956] Exclude at abstract screening: not about end of life. [pmid: 12518569].
Leske J S. Needs of adult family members after critical illness: prescriptions for interventions. Crit Care Nurs Clin North Am. 92;4(4):587-96. [Rec#: 41957] Exclude at abstract screening: useful only for background.
Leske J S. Overview of family needs after critical illness: from assessment to intervention. AACN Clin Issues Crit Care Nurs. 91;2(2):220-9. [Rec#: 41958] Exclude at abstract screening: not about end of life.
Lester D. Death anxiety, death depression, and death obsession. Psychol Rep. 2003;93(3 Pt 1):695-6. [Rec#: 4335] Exclude at abstract screening: not about end of life. [pmid: 14723430].
Lethem W. Nursing home nurses deliver palliative care. Nurs Times. 99;95(44):55. [Rec#: 13030] Exclude at abstract screening: no outcomes specified. [pmid: 10983085].
Letizia M, Zerby B, Hammer K, Tinnon W. The development of a hospice junior volunteer program. Am J Hosp Palliat Care. 2000;17(6):385-8. [Rec#: 41967] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11886039].
Letourneau N, Huber M L, Johnson R S, Vachon M L, McDonnell T P. Talking about death with the terminally ill. Cancer Pract. 96;4(4):177-9. [Rec#: 4352] Exclude at abstract screening: Title Only. [pmid: 8900757].
Leung K K, Chien W T, Mackenzie A E. Needs of Chinese families of critically ill patients. West J Nurs Res. 2000;22(7):826-40. [Rec#: 41969] Exclude at abstract screening: not about end of life. [pmid: 11077550].
Lev E L, McCorkle R. Loss, grief, and bereavement in family members of cancer patients. Semin Oncol Nurs. 98;14(2):145-51. [Rec#: 13035] Exclude at abstract screening: useful only for background. [pmid: 9580938].
Lev E L. Dealing with loss: concerns of patients and families in a hospice setting. Clin Nurse Spec. 91;5(2):87-93. [Rec#: 13034] Exclude at abstract screening: Study Design - Qualitative. [pmid: 2049727].
Levenson J L, Bemis C. The role of psychological factors in cancer onset and progression. Psychosomatics. 91;32(2):124-32. [Rec#: 13036] Exclude at abstract screening: no outcomes specified. [pmid: 2027934].
Levin P D, Sprung C L. Cultural differences at the end of life. Crit Care Med. 2003;31(5 Suppl):S354-7. [Rec#: 13040] Exclude at abstract screening: no outcomes specified. [pmid: 12771582].
Levine K M. The shift to palliative care. New model can improve quality of life in long-term care. Contemp Longterm Care. 2000;23(2):27. [Rec#: 13041] Exclude at abstract screening: Title Only. [pmid: 11066601].
Levine, C. The Many Worlds of Family Caregivers. 2000;<25 Page(s)>. [Rec#: 50547] Exclude at abstract screening: Title Only
Levinsky N G, Yu W, Ash A, Moskowitz M, Gazelle G, Saynina O, Emanuel E J. Influence of age on Medicare expenditures and medical care in the last year of life. JAMA. 2001;286(11):1349-55. [Rec#: 4369] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11560540].
Levorato A, Stiefel F, Mazzocato C, Bruera E. Communication with terminal cancer patients in palliative care: are there differences between nurses and physicians? Support Care Cancer 2001;9(6):420–7. Comment in: Support Care Cancer. Sep. 2001;9(6):401-2. PMID: 11585265. [Rec#: 4370] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Levy LH. Anticipatory grief: its measurement and proposed reconceptualization. Hosp J 91;7(4):1–28. Erratum in: Hosp J 1992;8(4):following 83. [Rec#: 4372] Exclude at abstract screening: Bereavement only
Levy M. Controlling cancer and its symptoms. Am J Hosp Palliat Care. 93;10(1):19-27. [Rec#: 13046] Exclude at abstract screening: Title Only. [pmid: 8461209].
Levy M H, Rosen S M, Ottery F D, Hermann J. Supportive care in oncology. Curr Probl Cancer. 92;16(6):329-418. [Rec#: 13050] Exclude at abstract screening: useful only for background. [pmid: 1282450].
Levy M H, Weinstein S M, Carducci M A. NCCN Palliative Care Practice Guidelines Panel. NCCN: Palliative care. Cancer Control. 2001;8(6 Suppl 2):66-71. [Rec#: 13051] Exclude at abstract screening: no outcomes specified. [pmid: 11760561].
Levy M H. Living with cancer: hospice/palliative care. J Natl Cancer Inst. 93;85(16):1283-7. [Rec#: 13047] Exclude at abstract screening: no outcomes specified. [pmid: 7688053].
Levy M M, Carlet J. Compassionate end-of-life care in the intensive care unit. Crit Care Med. 2001;29(2 Suppl):N1. [Rec#: 4375] Exclude at abstract screening: Title Only. [pmid: 11176149].
Levy M M. End-of-life care in the intensive care unit: can we do better?. Crit Care Med. 2001;29(2 Suppl):N56-61. [Rec#: 13053] Exclude at abstract screening: no outcomes specified. [pmid: 11228575].
Levy M M. Evaluating our end-of-life practice. Crit Care. 2001;5(4):182-3. [Rec#: 13054] Exclude at abstract screening: no outcomes specified. [pmid: 11511329]. [pmcid: 137276].
Levy M M. Palliative care in respiratory care: conference summary. Respiratory Care. 2000;45(12):1534-40. [Rec#: 50548] Exclude at abstract screening: Title Only. [pmid: 11107219].
Lewis I D, McBride M. Anticipatory grief and chronicity: Elders and families in racial/ethnic minority groups. Geriatr Nurs. 2004;25(1):44-7. [Rec#: 4380] Exclude at abstract screening: useful only for background. [pmid: 14976503].
Lewis M, Pearson V, Corcoran-Perry S, Narayan S. Decision making by elderly patients with cancer and their caregivers. Cancer Nurs. 97;20(6):389-97. [Rec#: 4383] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Leydon G M, Boulton M, Moynihan C, Jones A, Mossman J, Boudioni M, McPherson K. Cancer patients' information needs and information seeking behaviour: in depth interview study. BMJ. 2000;320(7239):909-13. [Rec#: 50549] Exclude at abstract screening: Study Design - Qualitative. [pmid: 10742000]. [pmcid: 27332].
Li J M. Pain management in the hospitalized patient. Med Clin North Am. 2002;86(4):771-95. [Rec#: 13069] Exclude at abstract screening: useful only for background. [pmid: 12365340].
Li L W, Seltzer M M, Greenberg J S. Social support and depressive symptoms: differential patterns in wife and daughter caregivers. J Gerontol B Psychol Sci Soc Sci. 97;52(4):S200-11. [Rec#: 41990] Exclude at abstract screening: Study Design - Unclear.
Liao Y, McGee D L, Cao G, Cooper R S. Quality of the last year of life of older adults: 1986 vs 1993. JAMA 2000;283(4):512–8. Comment in: JAMA. 2000 Sep 27;284(12):1513–5. PMID: 11000638. Comment in: JAMA. 2000 Sep 27;284(12):1513; author reply 1514–5. PMID: 11000636. Comment in: JAMA. Sep 27. 2000;284(12):1513. author reply 1514–5. PMID: 11000637. [Rec#: 41991] Exclude at abstract screening: primarily prognosis or trajectories.
Liao S, Ferrell B A. Fatigue in an older population. Journal of the American Geriatrics Society. 2000;48(4):426-30. [Rec#: 50550] Exclude at abstract screening: not about end of life. [pmid: 10798471].
Liaschenko J A. A sense of place for patients: living and dying. Home Care Provid. 96;1(5):270-2. [Rec#: 13076] Exclude at abstract screening: no outcomes specified. [pmid: 9272031].
Librach, S. L. Role of family physicians in end-of-life care. Rhetoric, role, and reality. Canadian Family Physician 2001;47:1941–3, 1949–51. [Rec#: 50551] Exclude at abstract screening: Title Only
Lichtenstein P, Gatz M, Berg S A. A twin study of mortality after spousal bereavement. Psychol Med. 98;28(3):635-43. [Rec#: 4403] Exclude at abstract screening: not about end of life. [pmid: 9626719].
Lichtenstein P, Gatz M, Pedersen N L, Berg S, McClearn G E. A co-twin--control study of response to widowhood. J Gerontol B Psychol Sci Soc Sci. 96;51(5):P279-89. [Rec#: 4404] Exclude at abstract screening: Bereavement only. [pmid: 8809004].
Lichter I, Hunt E. The last 48 hours of life. J Palliat Care. 90;6(4):7-15. [Rec#: 4408] Exclude at abstract screening: Study Design - Unclear. [pmid: 1704917].
Lickiss J N, Hacker N F. Care of the patient close to death. Best Pract Res Clin Obstet Gynaecol. 2001;15(2):333-40. [Rec#: 13084] Exclude at abstract screening: useful only for background. [pmid: 11358407].
Lickiss J N. Palliative care and melanoma: the care of the patient with progressive disease. World J Surg. 92;16(2):282-6. [Rec#: 13083] Exclude at abstract screening: useful only for background. [pmid: 1373258].
Liken M A, Collins C E. Grieving: facilitating the process for dementia caregivers. J Psychosoc Nurs Ment Health Serv. 93;31(1):21-6. [Rec#: 4419] Exclude at abstract screening: Non-systematic review.
Lile J L, Hoffman R. Medication-taking by the frail elderly in two ethnic groups. Nurs Forum. 91;26(4):19-24. [Rec#: 41998] Exclude at abstract screening: not about end of life. [pmid: 1792177].
Limerick M. Communicating with surrogate decision-makers in end-of-life situations: substitutive descriptive language for the healthcare provider. Am J Hosp Palliat Care. 2002;19(6):376-80. [Rec#: 13097] Exclude at abstract screening: useful only for background. [pmid: 12442971].
Lin C C, Lai Y L, Lo E C. Life-extending therapies among patients with advanced cancer: patients' levels of pain and family caregivers' concerns about pain relief. Cancer Nurs. 2001;24(6):430-5. [Rec#: 4434] Notes: “EXCLUDE: Location, non-Western”. [pmid: 11762505].
Lin H R, Bauer-Wu S M. Psycho-spiritual well-being in patients with advanced cancer: an integrative review of the literature. J Adv Nurs. 2003;44(1):69-80. [Rec#: 13098] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 12956671].
Lindemann E. Symptomatology and management of acute grief. 1944. Am J Psychiatry. 94;151(6 Suppl):155-60. [Rec#: 13100] Exclude at abstract screening: Title Only. [pmid: 8192191].
Linden B. Severe heart failure: a focus on the quality of care. Nurs Times. 95;91(33):38-9. [Rec#: 13101] Exclude at abstract screening: no outcomes specified. [pmid: 7545290].
Linden M, Barnow S. 1997 IPA/Bayer Research Awards in Psychogeriatrics. The wish to die in very old persons near the end of life: a psychiatric problem? Results from the Berlin Aging Study. Int Psychogeriatr. 97;9(3):291-307. [Rec#: 4442] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Linder J, Enders S R, Craig E, Richardson J, Meyers F J. Hospice care for the incarcerated in the United States: an introduction. Journal of Palliative Care. 2002;5(4):549-552. [Rec#: 50552] Exclude at abstract screening: useful only for background.
Lindley-Davis B. Process of dying. Defining characteristics. Cancer Nurs. 91;14(6):328-33. [Rec#: 4446] Exclude at abstract screening: Observational study. [pmid: 1760804].
Ling J. Audit in practice: the referral of dying patients to palliative care. Int J Palliat Nurs. 2000;6(8):375-9. [Rec#: 4452] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12411848].
Linkewich B, Setliff A E, Poling M, Bailey S, Sellick S, Kelley M L. Communicating at life's end. Can Nurse. 99;95(5):41-4. [Rec#: 4456] Exclude at abstract screening: useful only for background. [pmid: 10639972].
Linklater G T, Leng M E, Tiernan E J, Lee M A, Chambers W A. Pain management services in palliative care: a national survey. Palliat Med. 2002;16(5):435-9. [Rec#: 13112] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12380662].
Links M, Kramer J. Breaking bad news: realistic versus unrealistic hopes. Support Care Cancer. 94;2(2):91-3. [Rec#: 13113] Exclude at abstract screening: not about end of life. [pmid: 8156271].
Lintz K C, Penson R T, Cassem N, Harmon D C, Chabner B A, Lynch T J. A staff dialogue on aggressive palliative treatment demanded by a terminally ill patient: psychosocial issues faced by patients, their families, and caregivers. Oncologist. 99;4(1):70-6. [Rec#: 4458] Exclude at abstract screening: useful only for background.
Lintz K C, Penson R T, Chabner B A, Mack S, Lynch T J. Schwartz Center Rounds. A Staff Dialogue on Phase I Trials: Psychosocial Issues Faced by Patients, Their Families, and Caregivers. Oncologist. 98;3(5):357-364. [Rec#: 4459] Exclude at abstract screening: no outcomes specified.
Lipman A G, Rajagopal M R, Mazza D. Hospice and palliative care: a universal human imperative-lessons for the world from the innovators. J Pain Palliat Care Pharmacother. 2003;17(34):xxxvii-xlii. [Rec#: 4461] Exclude at abstract screening: Title Only. [pmid: 15022946].
Lipman A G. Analgesic drugs for neuropathic and sympathetically maintained pain. Clinics in Geriatric Medicine. 96;12(3):501-15. [Rec#: 50553] Exclude at abstract screening: no outcomes specified. [pmid: 8853942].
Lipsett P A, Swoboda S M, Campbell K A, Cornwell E 3rd, Dorman T, Pronovost P J. Sickness Impact Profile Score versus a Modified Short-Form survey for functional outcome assessment: acceptability reliability, and validity in critically ill patients with prolonged intensive care unit stays. J Trauma. 2000;49(4):737-43. [Rec#: 42013] Exclude at abstract screening: not about end of life. [pmid: 11038094].
Lipsett P A, Swoboda S M, Dickerson J, Ylitalo M, Gordon T, Breslow M, Campbell K, Dorman T, Pronovost P, Rosenfeld B. Survival and functional outcome after prolonged intensive care unit stay. Ann Surg. 2000;231(2):262-8. [Rec#: 42014] Exclude at abstract screening: not about end of life. [pmid: 10674619]. [pmcid: 1420995].
Lissoni P, Barni S, Fossati V, Ardizzoia A, Cazzaniga M, Tancini G, Frigerio F. A randomized study of neuroimmunotherapy with low-dose subcutaneous interleukin-2 plus melatonin compared to supportive care alone in patients with untreatable metastatic solid tumour. Support Care Cancer. 95;3(3):194-7. [Rec#: 4469] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Liu K. A data perspective on long-term care. Gerontologist. 94;34(4):476-80. [Rec#: 42021] Exclude at abstract screening: not about end of life. [pmid: 7959104].
Liukkonen A. Life in a nursing home for the frail elderly: daily routines. Clin Nurs Res 95;4(4):358–70; discussion 371–2. [Rec#: 42022] Exclude at abstract screening: no outcomes specified
Livadiotakis G, Gutman G, Hollander M J. Rationing home care resources: how discharged seniors cope. Home Health Care Serv Q. 2003;22(2):31-42. [Rec#: 42023] Exclude at abstract screening: not about end of life. [pmid: 12870711].
Livingston G, Watkin V, Milne B, Manela M V, Katona C. Who becomes depressed? The Islington community study of older people. J Affect Disord. 2000;58(2):125-33. [Rec#: 42024] Exclude at abstract screening: not about end of life. [pmid: 10781702].
Llamas K J, Pickhaver A M, Piller N B. Mainstreaming palliative care for cancer patients in the acute hospital setting. Palliat Med. 2001;15(3):207-12. [Rec#: 13127] Exclude at abstract screening: no outcomes specified. [pmid: 11407192].
Llano Escobar A. Human dying has changed. Bull Pan Am Health Organ. 90;24(4):446-53. [Rec#: 13128] Exclude at abstract screening: no outcomes specified. [pmid: 2073559].
Llewellyn-Jones R H, Baikie K A, Castell S, Andrews C L, Baikie A, Pond C D, Willcock S M, Snowdon J, Tennant C C. How to help depressed older people living in residential care: a multifaceted shared-care intervention for late-life depression. Int Psychogeriatr. 2001;13(4):477-92. [Rec#: 42025] Exclude at abstract screening: not about end of life. [pmid: 12003254].
Lloyd Williams M, Payne S. A qualitative study of clinical nurse specialists' views on depression in palliative care patients. Palliat Med. 2003;17(4):334-8. [Rec#: 4502] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12822850].
Lloyd-Williams M, Friedman T. Depression in palliative care patients--a prospective study. Eur J Cancer Care (Engl). 2001;10(4):270-4. [Rec#: 4499] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11806678].
Lloyd-Williams M, Payne S. Nurse specialist assessment and management of palliative care patients who are depressed--a study of perceptions and attitudes. J Palliat Care. 2002;18(4):270-4. [Rec#: 13144] Exclude at abstract screening: useful only for background. [pmid: 12611317].
Lloyd-Williams M, Rashid A. An analysis of calls to an out-of-hours palliative care advice line. Public Health. 2003;117(2):125-7. [Rec#: 13145] Exclude at abstract screening: not about end of life. [pmid: 12802979].
Lloyd-Williams M, Dennis M, Taylor F, Baker I. Is asking patients in palliative care “are you depressed?” Appropriate? Prospective study. BMJ. 2003;327(7411):372-3. [Rec#: 4495] Exclude at abstract screening: Title Only. [pmid: 12919988]. [pmcid: 175105].
Lloyd-Williams M, Friedman T, Rudd N. A survey of psychosocial service provision within hospices. Palliat Med. 99;13(5):431-2. [Rec#: 13142] Exclude at abstract screening: Title Only. [pmid: 10659117].
Lloyd-Williams M, Spiller J, Ward J. Which depression screening tools should be used in palliative care?. Palliat Med. 2003;17(1):40-3. [Rec#: 4504] Exclude at abstract screening: Non-systematic review. [pmid: 12597464].
Lloyd-Williams M, Wilkinson C, Lloyd-Williams F F. Do bereaved children consult the primary health care team more frequently?. Eur J Cancer Care (Engl). 98;7(2):120-4. [Rec#: 42026] Notes: “EXCLUDE: Age, not adults”. [pmid: 9697454].
Lloyd-Williams M. Difficulties in diagnosing and treating depression in the terminally ill cancer patient. Postgrad Med J. 2000;76(899):555-8. [Rec#: 13134] Exclude at abstract screening: Non-systematic review. [pmid: 10964119].
Lloyd-Williams M. Is it appropriate to screen palliative care patients for depression?. Am J Hosp Palliat Care. 2002;19(2):112-4. [Rec#: 4493] Exclude at abstract screening: Study Design - Unclear. [pmid: 11926441].
Lloyd-Williams M. Psychosocial care: setting the research agenda. Palliat Med. 2003;17(1):78-80. [Rec#: 13135] Exclude at abstract screening: Title Only. [pmid: 12597470].
Lloyd-Williams M. Treatment of depression with flupenthixol in terminally ill patients. Eur J Cancer Care (Engl). 94;3(3):133-4. [Rec#: 4494] Exclude at abstract screening: Observational study. [pmid: 7711982].
Lloyd-Williams M. Screening for depression in palliative care patinets: a review. European Journal of Cancer Care. 2001;10:31-35. [Rec#: 50554] Exclude at abstract screening: Title Only. [pmid: 11827265].
Lo B, Quill T, Tulsky J. Discussing palliative care with patients. ACP-ASIM End-of-Life Care Consensus Panel. American College of Physicians-American Society of Internal Medicine. Ann Intern Med. 99;130(9):744-9. [Rec#: 4505] Exclude at abstract screening: Title Only.
Lo B. End-of-life care after termination of SUPPORT. Hastings Cent Rep. 95;25(6):S6-8. [Rec#: 13147] Exclude at abstract screening: Title Only. [pmid: 8609007].
Lo R S, Woo J, Zhoc K C, Li C Y, Yeo W, Johnson P, Mak Y, Lee J. Quality of life of palliative care patients in the last two weeks of life. J Pain Symptom Manage. 2002;24(4):388-97. [Rec#: 13150] Notes: “EXCLUDE: Location, non-Western”. [pmid: 12505207].
Lobb D. Palliative care for women with AIDS: identifying the issues. J Palliat Care. 95;11(2):45-7. [Rec#: 4515] Exclude at abstract screening: useful only for background. [pmid: 7541076].
Lobchuk M M, Stymeist D. Symptoms as meaningful “family culture” symbols in palliative care. J Palliat Care. 99;15(4):24-31. [Rec#: 13153] Exclude at abstract screening: Title Only. [pmid: 10693303].
Lobchuk M M, Kristjanson L, Degner L, Blood P, Sloan J A. Perceptions of symptom distress in lung cancer patients: I. Congruence between patients and primary family caregivers. Journal of Pain and Symptom Management. 97;14(3):136-46. [Rec#: 50555] Exclude at abstract screening: Study Design - Unclear.
Locker D, Matear D, Stephens M, Jokovic A. Oral health-related quality of life of a population of medically compromised elderly people. Community Dent Health. 2002;19(2):90-7. [Rec#: 42028] Exclude at abstract screening: not about end of life. [pmid: 12146588].
Lockery S A, Dunkle R E, Kart C S, Coulton C J. Factors contributing to the early rehospitalization of elderly people. Health Soc Work. 94;19(3):182-91. [Rec#: 42029] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Lockhart C A, Volk-Craft B E, Hamilton G, Aiken L S, Williams F G. The PhoenixCare Program. J Palliat Med. 2003;6(6):1001-12. [Rec#: 42031] Exclude at abstract screening: no outcomes specified. [pmid: 14733694].
Lockhart L K, Bookwala J, Fagerlin A, Coppola K M, Ditto P H, Danks J H, Smucker W D. Older adults' attitudes toward death: links to perceptions of health and concerns about end-of-life issues. Omega (Westport). 2001;43(4):331-47. [Rec#: 4520] Exclude at abstract screening: Study Design - Unclear. [pmid: 12569924].
Loeb SJ, Penrod J, Falkenstern S, Gueldner SH, and Poon LW. Supporting older adults living with multiple chronic conditions. West J Nurs Res 2003;25(1):8–23; discussion 23–9. [Rec#: 42032] Exclude at abstract screening: no outcomes specified
Loewy E H. Terminal sedation, self-starvation, and orchestrating the end of life. Archives of Internal Medicine. 2001;161(3):329-32. [Rec#: 50556] Exclude at abstract screening: no outcomes specified. [pmid: 11176757].
Lofmark R and Nilstun T. Do-not-resuscitate orders - experiences and attitudes of relatives. 2001;12(5):430–434. [Rec#: 4527] Exclude at abstract screening: Observational study
Lofmark R, Nilstun T. Not if, but how: one way to talk with patients about forgoing life support. Postgrad Med J. 2000;76(891):26-8. [Rec#: 13163] Exclude at abstract screening: Observational study. [pmid: 10622776].
Logan J R, Spitze G. Informal support and the use of formal services by older Americans. J Gerontol. 94;49(1):S25-34. [Rec#: 42034] Exclude at abstract screening: not about end of life. [pmid: 8282986].
Logan M, Bourbonnais F F. Continuous subcutaneous infusion of narcotics: an exploratory study of patient, family and nursing concerns. Hosp J. 90;6(1):69-77. [Rec#: 4531] Exclude at abstract screening: Title Only. [pmid: 2379924].
Lonberger E A, Russell C L, Burton S M. The effects of palliative care on patient charges. J Nurs Adm 97;27(11):23–6. Comment in: J Nurs Adm. Apr. 1998;28(4):62. PMID: 9564388. [Rec#: 4542] Exclude at abstract screening: no outcomes specified.
Long M C. Death and dying and recognizing approaching death. Clin Geriatr Med. 96;12(2):359-68. [Rec#: 13174] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 8799353].
Long S O. Living poorly or dying well: cultural decisions about life-supporting treatment for American and Japanese patients. J Clin Ethics. 2000;11(3):236-50. [Rec#: 13176] Exclude at abstract screening: useful only for background. [pmid: 11127638].
Lookinland S, Anson K. Perpetuation of ageist attitudes among present and future health care personnel: implications for elder care. J Adv Nurs. 95;21(1):47-56. [Rec#: 42039] Exclude at abstract screening: not about end of life.
Loos C, Bowd A. Caregivers of persons with Alzheimer's disease: some neglected implications of the experience of personal loss and grief. Death Stud. 97;21(5):501-14. [Rec#: 13180] Exclude at abstract screening: not about end of life.
Lopez M, Delmore B, Ake J M, Kim Y R, Golden P, Bier J, Fulmer T. Implementing a geriatric resource nurse model. J Nurs Adm. 2002;32(11):577-85. [Rec#: 42041] Exclude at abstract screening: no outcomes specified. [pmid: 12464775].
Lopez-Candales A L, Carron C, Schwartz J. Need for hospice and palliative care services in patients with end-stage heart failure treated with intermittent infusion of inotropes. Clin Cardiol. 2004;27(1):23-8. [Rec#: 4547] Exclude at abstract screening: Study Design - Unclear. [pmid: 14743852].
Lord E. Nebulized morphine: one intervention for end-stage chronic obstructive pulmonary disease (COPD). AARN News Letter. 97;53(10):10-1. [Rec#: 50557] Exclude at abstract screening: Title Only. [pmid: 9444084].
Loudon R F, Anderson P M, Gill P S, Greenfield S M. Educating medical students for work in culturally diverse societies. JAMA. 99;282(9):875-80. [Rec#: 50558] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Lovel T. The delivery of palliative care. Cancer Treat Rev. 96;22(Suppl A):145-9. [Rec#: 13189] Exclude at abstract screening: Title Only. [pmid: 8625342].
Lowdermilk D L. Home care of the patient with gynecologic cancer. J Obstet Gynecol Neonatal Nurs. 95;24(2):157-63. [Rec#: 42052] Exclude at abstract screening: no outcomes specified.
Lowenstein A. Intergenerational family relations and social support. Z Gerontol Geriatr. 99;32(6):398-406. [Rec#: 42054] Exclude at abstract screening: useful only for background. [pmid: 10654377].
Loxterkamp D. A good death is hard to find: preliminary reports of a hospice doctor. J Am Board Fam Pract. 93;6(4):415-7. [Rec#: 13196] Exclude at abstract screening: Title Only. [pmid: 8352048].
Lubin S. Palliative care--could your patient have been managed at home? J Palliat Care 92;8(2):18–22. Comment in: J Palliat Care. 1992 Winter;8(4):56. PMID: 1487799. [Rec#: 13198] Exclude at abstract screening: useful only for background
Lubitz J D, Riley G F. Trends in Medicare payments in the last year of life. New England Journal of Medicine. 93;328(15):1092-6. [Rec#: 50560] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Lubitz J, Beebe J, Baker C. Longevity and Medicare expenditures. New England Journal of Medicine. 95;332(15):999-1003. [Rec#: 50559] Exclude at abstract screening: not about end of life. [pmid: 7885430].
Luce J M, Rubenfeld G D. Can health care costs be reduced by limiting intensive care at the end of life?. Am J Respir Crit Care Med. 2002;165(6):750-4. [Rec#: 13201] Exclude at abstract screening: Title Only. [pmid: 11897638].
Luddington L, Cox S, Higginson I, Livesley B. The need for palliative care for patients with non-cancer diseases: a review of the evidence. Int J Palliat Nurs. 2001;7(5):221-6. [Rec#: 13207] Exclude at abstract screening: useful only for background. [pmid: 12148972].
Lundin-Olsson L, Nyberg L, Gustafson Y. Attention, frailty, and falls: the effect of a manual task on basic mobility. J Am Geriatr Soc. 98;46(6):758-61. [Rec#: 42069] Exclude at abstract screening: not about end of life.
Lundstrom S, Strang P. Palliative Care Research Network. Establishing and testing a palliative care research network in Sweden. Palliat Med. 2004;18(2):139. [Rec#: 4599] Exclude at abstract screening: Title Only. [pmid: 15046411].
Lunn J J, Murray M J. Nutritional support in critical illness. Yale J Biol Med. 98;71(6):449-56. [Rec#: 42070] Exclude at abstract screening: not about end of life. [pmid: 10604778].
Lunney J R, O'Mara A. The end of the survival journey. Semin Oncol Nurs. 2001;17(4):274-8. [Rec#: 13222] Exclude at abstract screening: Non-systematic review. [pmid: 11764712].
Lunney J R, Lynn J, Hogan C. Profiles of older medicare decedents. J Am Geriatr Soc. 2002;50(6):1108-12. [Rec#: 4602] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 12110073].
Lunney J R, Lynn J, Foley D J, Lipson S, Guralnik J M. Patterns of functional decline at the end of life. JAMA. 2003;289(18):2387-92. [Rec#: 4601] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 12746362].
Lunney J R. Resources for caregivers of terminally ill cancer patients. Cancer Pract. 2000;8(2):99-100. [Rec#: 13221] Exclude at abstract screening: Title Only. [pmid: 11898184].
Luptak M K, Boult C. A method for increasing elders' use of advance directives. Gerontologist. 94;34(3):409-12. [Rec#: 42071] Exclude at abstract screening: no outcomes specified. [pmid: 8076885].
Lusardi P T, Schwartz-Barcott D. Making sense of it: a neuro-interactional model of meaning emergence in critically ill ventilated patients. J Adv Nurs. 96;23(5):896-903. [Rec#: 42072] Exclude at abstract screening: not about end of life.
Lussier, D. AGS guidelines on persistent pain in older persons: lack of specific pharmacotherapeutic recommendations. Journal of the American Geriatrics Society 2003;51(6):883–4; author reply 889. [Rec#: 50561] Exclude at abstract screening: Title Only
Lutz S T, Huang D T, Ferguson C L, Kavanagh B D, Tercilla O F, Lu J. A retrospective quality of life analysis using the Lung Cancer Symptom Scale in patients treated with palliative radiotherapy for advanced nonsmall cell lung cancer. Int J Radiat Oncol Biol Phys. 97;37(1):117-22. [Rec#: 4608] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Ly K L, Chidgey J, Addington-Hall J, Hotopf M. Depression in palliative care: a systematic review. Part 2 Treatment. Palliat Med. 2002;16(4):279-84. [Rec#: 13229] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 12132540].
Lyall R A, Fleming T A, Newsome-Davis I, Wood C, Leigh P N, Moxham J. A prospective controlled study of the effect of NIPPV on quality of life in amyotrophic lateral sclerosis. American Journal of Respiratory & Critical Care Medicine. 2000;161:A358. [Rec#: 50562] Exclude at abstract screening: Title Only.
Lyke J, Colon M. Practical recommendations for ethnically and racially sensitive hospice services. Am J Hosp Palliat Care. 2004;21(2):131-3. [Rec#: 4612] Exclude at abstract screening: no outcomes specified. [pmid: 15055513].
Lynch M, Abrahm J. Ensuring a good death. Cancer Pract. 2002;10(Suppl 1):S33-8. [Rec#: 13237] Exclude at abstract screening: no outcomes specified. [pmid: 12027967].
Lynch M. Palliative sedation. Clin J Oncol Nurs 2003;7(6):653–7, 667. [Rec#: 13236] Exclude at abstract screening: no outcomes specified
Lyneham J. Death in an emergency unit. Aust Nurses J. 92;21(11):16-7. [Rec#: 4618] Exclude at abstract screening: Title Only. [pmid: 1530508].
Lynn J, Forlini J H. “Serious and complex illness” in quality improvement and policy reform for end-of-life care. J Gen Intern Med 2001;16(5):315–9. Comment in: J Gen Intern Med. 2001 May;16(5):335–8. PMID: 11359553. Comment in: J Gen Intern Med. May. 2001;16(5):339-41. PMID: 11359554. [Rec#: 13247] Exclude at abstract screening: useful only for background.
Lynn J, Goldstein N E. Advance care planning for fatal chronic illness: avoiding commonplace errors and unwarranted suffering. Ann Intern Med. 2003;138(10):812-8. [Rec#: 4624] Exclude at abstract screening: useful only for background. [pmid: 12755553].
Lynn J, Wilkinson A M. Quality end of life care: the case for a MediCaring demonstration. Hosp J. 98;13(12):151-63. [Rec#: 13248] Exclude at abstract screening: no outcomes specified. [pmid: 9644400].
Lynn J, Arkes H R, Stevens M, Cohn F, Koenig B, Fox E, Dawson N V, Phillips R S, Hamel M B, Tsevat J. Rethinking fundamental assumptions: SUPPORT's implications for future reform. Study to Understand Prognoses and Preferences and Risks of Treatment. J Am Geriatr Soc 2000;48(5 Suppl):S214–21. Comment in: Int J Palliat Nurs. Apr. 2003;9(4):140. PMID: 12734449. [Rec#: 13245] Exclude at abstract screening: no outcomes specified.
Lynn J, Ely E W, Zhong Z, McNiff K L, Dawson N V, Connors A, Desbiens N A, Claessens M, McCarthy E P. Living and dying with chronic obstructive pulmonary disease. J Am Geriatr Soc. 2000;48(5 Suppl):S91-100. [Rec#: 4623] Exclude at abstract screening: Title Only. [pmid: 10809462].
Lynn J, Harrell F Jr, Cohn F, Wagner D, Connors A F Jr. Prognoses of seriously ill hospitalized patients on the days before death: implications for patient care and public policy. New Horiz. 97;5(1):56-61. [Rec#: 4625] Exclude at abstract screening: primarily prognosis or trajectories.
Lynn J, Nolan K, Kabcenell A, Weissman D, Milne C, Berwick D M. End-of-Life Care Consensus Panel. Reforming care for persons near the end of life: the promise of quality improvement. Ann Intern Med. 2002;137(2):117-22. [Rec#: 4626] Exclude at abstract screening: no outcomes specified. [pmid: 12118967].
Lynn J, Wilkinson A, Cohn F, Jones S B. Capitated risk-bearing managed care systems could improve end-of-life care. J Am Geriatr Soc. 98;46(3):322-30. [Rec#: 4629] Exclude at abstract screening: useful only for background.
Lynn J. A commentary: where to live while dying. Gerontologist 2002;42 Spec No 3:68–70. Comment on: Gerontologist. 2002 Oct;42 Spec No 3:54–67. PMID: 12415134. [Rec#: 4621] Exclude at abstract screening: Title Only
Lynn J. An 88-year-old woman facing the end of life. JAMA 97;277(20):1633–40. Comment in: JAMA. 1997 Dec 24–31;278(24):2184. PMID: 9417014. Comment in: JAMA. 1997 Sep 24;278(12):977; author reply 978. PMID: 9307338. Comment in: JAMA. 1997 Sep 24;278(12):977; author reply 978. PMID: 9307337. Comment in: JAMA. Sep. 1997;24:27. [Rec#: 4619] Exclude at abstract screening: Title Only.
Lynn J. Better care for the dying. Interview by Yvonne Parsons. Contemp Longterm Care. 99;22(4):90. [Rec#: 4620] Exclude at abstract screening: Title Only. [pmid: 10351624].
Lynn J. Finding the key to reform in end-of-life care. J Pain Symptom Manage 2000;19(3):165–7. Comment on: J Pain Symptom Manage. Mar. 2000;19(3):168-73. PMID: 10760621. [Rec#: 13242] Exclude at abstract screening: Title Only.
Lynn J. Measuring quality of care at the end of life: a statement of principles. J Am Geriatr Soc 97;45(4):526–7. Comment in: J Am Geriatr Soc. Apr. 1997;45(4):528-30. PMID: 9100728. [Rec#: 13243] Exclude at abstract screening: useful only for background.
Lynn J. Perspectives on care at the close of life. Serving patients who may die soon and their families: the role of hospice and other services. JAMA 2001;285(7):925–32. Comment in: JAMA. 2001 May 23–30;285(20):2578–9. PMID: 11368723. Comment in: JAMA. May 23–30. 2001;285(20):2578. author reply 2579. PMID: 11368722. [Rec#: 13244] Exclude at abstract screening: no outcomes specified.
Lynn J. Reforming the Care System to Support Those Coming to the End of Life. Cancer Control. 99;6(2):131-135. [Rec#: 4622] Exclude at abstract screening: no outcomes specified. [pmid: 10758541].
Lynn J. Measuring quality of care at the end of life: a statement of principles. Journal of the American Geriatrics Society. 97;45(4):526-527. [Rec#: 50563] Exclude at abstract screening: Title Only. [pmid: 9100727].
Lyons D, Cohen M, Henderson T, Walker N. Partnership nursing home care for dementia: the Glasgow experience--one-year follow-up. Int J Geriatr Psychiatry. 97;12(8):838-40. [Rec#: 50065] Exclude at abstract screening: not about end of life.
Lyons D, Cohen M, Henderson T, Walker N. Partnership nursing home care for dementia: the Glasgow experience--one-year follow-up. Int J Geriatr Psychiatry. 97;12(7):765-6. [Rec#: 50066] Exclude at abstract screening: Duplicate already in the flow.
Lyttle C P. Bereavement visiting: older people's and nurses' experiences. Br J Community Nurs. 2001;6(12):629-35. [Rec#: 4631] Exclude at abstract screening: not about end of life. [pmid: 11832792].
MacAdam M, Greenberg J, Greenlick M, Gruenberg L, Malone J. Targeting long-term care for the frail elderly: models from the Social/HMO demonstration. J Appl Gerontol. 91;10(4):389-405. [Rec#: 42081] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
MacDonald B. Death with dignity. Can Nurse. 90;86(11):19. [Rec#: 13258] Exclude at abstract screening: Title Only. [pmid: 2285908].
MacDonald D. Hospice patients without primary care givers. A critique of prevailing intervention strategies. Home Healthc Nurse. 92;10(1):24-6. [Rec#: 13260] Exclude at abstract screening: Title Only. [pmid: 1537673].
MacDonald N. A proposed matrix for organisational changes to improve quality of life in oncology. Eur J Cancer. 95;31A(Suppl 6):S18-21. [Rec#: 13275] Exclude at abstract screening: no outcomes specified.
MacDonald N. Nutrition as an integral component of supportive care. Oncology (Huntingt). 2003;17(2 Suppl 2):8-10. discussion 11–2. [Rec#: 13270] Exclude at abstract screening: useful only for background. [pmid: 12632870].
MacDonald N. Oncology and palliative care: the case for co-ordination. Cancer Treat Rev. 93;19(Suppl A):29-41. [Rec#: 13271] Exclude at abstract screening: no outcomes specified. [pmid: 7679317].
MacDonald N. Palliative care and primary care. J Pain Symptom Manage 2002;23(1):58–9. Comment on: J Pain Symptom Manage. Jan. 2002;23(1):54-7. PMID: 11779669. [Rec#: 13273] Exclude at abstract screening: useful only for background.
MacDonald N. Palliative care--an essential component of cancer control. CMAJ. 98;158(13):1709-16. [Rec#: 13272] Exclude at abstract screening: Title Only. [pmid: 9676548].
MacDonald N. Quality of life in clinical and research palliative medicine. J Palliat Care. 92;8(3):46-51. [Rec#: 13276] Exclude at abstract screening: Title Only. [pmid: 1279150].
MacEntee M I, Hole R, Stolar E. The significance of the mouth in old age. Soc Sci Med. 97;45(9):1449-58. [Rec#: 42085] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 9351161].
MacInnis K. The good ending. Am J Nurs. 93;93(5):104. [Rec#: 13285] Exclude at abstract screening: Title Only. [pmid: 8488889].
Mackey K M, Sparling J W. Experiences of older women with cancer receiving hospice care: significance for physical therapy. Phys Ther. 2000;80(5):459-68. [Rec#: 4657] Exclude at abstract screening: Study Design - Qualitative. [pmid: 10792856].
Mackillop W J, Quirt C F. Measuring the accuracy of prognostic judgments in oncology. Journal of Clinical Epidemiology. 97;50(1):21-9. [Rec#: 50564] Exclude at abstract screening: primarily prognosis or trajectories.
Macleod A D, Whitehead L E. Dysgraphia and terminal delirium. Palliat Med. 97;11(2):127-32. [Rec#: 4663] Exclude at abstract screening: Observational study. [pmid: 9156108].
Macpherson C, Cooke C. Pilot of a workbook for children visiting a loved one in a hospice. Int J Palliat Nurs. 2003;9(9):397-403. [Rec#: 42091] Notes: “EXCLUDE: Age, not adults”. [pmid: 14593276].
MacPherson I, Bisset A. Not another questionnaire!: eliciting the views of general practitioners. Fam Pract. 95;12(3):335-8. [Rec#: 50067] Exclude at abstract screening: not about end of life. [pmid: 8536841].
Macran S, Kind P. “Death” and the valuation of health-related quality of life. Med Care. 2001;39(3):217-27. [Rec#: 4664] Exclude at abstract screening: data older than 1990. [pmid: 11242317].
MacStravic S. The death of the four “P”s: a premature obituary. Mark Health Serv. 2000;20(4):16-20. [Rec#: 42092] Exclude at abstract screening: not about end of life. [pmid: 11209475].
Madan T N. Dying with dignity. Soc Sci Med. 92;35(4):425-32. [Rec#: 13317] Exclude at abstract screening: no outcomes specified. [pmid: 1519095].
Maddocks I, Bentley L, Sheedy J. Quality of life issues in patients dying from haematological diseases. Ann Acad Med Singapore. 94;23(2):244-8. [Rec#: 4667] Exclude at abstract screening: Study Design - Unclear.
Madigan E A, Schott D, Matthews C R. Rehospitalization among home healthcare patients: results of a prospective study. Home Healthc Nurse. 2001;19(5):298-305. [Rec#: 50068] Exclude at abstract screening: Title Only. [pmid: 11985040].
Madrid M. Participating in the process of dying. NLN Publ 94;(15–2610):91–100. [Rec#: 4669] Exclude at abstract screening: Title Only
Madsen J, Serup-Hansen N, Kristiansen I S. Future health care costs--do health care costs during the last year of life matter?. Health Policy. 2002;62(2):161-72. [Rec#: 4670] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12354410].
Madsen J, Serup-Hansen N, Kragstrup J, Kristiansen I S. Ageing may have limited impact on future costs of primary care providers. Scand J Prim Health Care. 2002;20(3):169-73. [Rec#: 42093] Exclude at abstract screening: not about end of life. [pmid: 12389755].
Madson S K. Patient self-determination act. Implications for long-term care. J Gerontol Nurs. 93;19(2):15-8. [Rec#: 4671] Exclude at abstract screening: no outcomes specified. [pmid: 8429190].
Maercker A, Bonanno G A, Znoj H, Horowitz M J. Prediction of complicated grief by positive and negative themes in narratives. J Clin Psychol. 98;54(8):1117-36. [Rec#: 4672] Exclude at abstract screening: Study Design - Unclear.
Mafullul Y M. Burden of informal carers of mentally infirm eldery in Lancashire. East Afr Med J 2002;79(6):291–8. Comment in: East Afr Med J. Jun. 2002;79(6):281-3. PMID: 12638817. [Rec#: 42094] Exclude at abstract screening: not about end of life.
Mafullul Y M. Informal carers of mentally infirm elderly in Lancashire. East Afr Med J 2002;79(6):284–90. Comment in: East Afr Med J. Jun. 2002;79(6):281-3. PMID: 12638817. [Rec#: 42095] Exclude at abstract screening: not about end of life.
Magaziner J, Zimmerman S I, Gruber-Baldini A L, Hebel J R, Fox K M. Proxy reporting in five areas of functional status. Comparison with self-reports and observations of performance. Am J Epidemiol. 97;146(5):418-28. [Rec#: 42096] Exclude at abstract screening: not about end of life.
Magaziner J, Simonsick E M, Kashner T M, Hebel J R. Patient-proxy response comparability on measures of patient health and functional status. J Clin Epidemiol. 88;41(11):1065-74. [Rec#: 50875] Exclude at abstract screening: not about end of life.
Magilvy J K, Congdon J G, Martinez R. Circles of care: home care and community support for rural older adults. ANS Adv Nurs Sci. 94;16(3):22-33. [Rec#: 42097] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Magno J B. Hospice care: an overview. Henry Ford Hosp Med J. 91;39(2):72-3. [Rec#: 13328] Exclude at abstract screening: Title Only. [pmid: 1890010].
Magno J B. Management of terminal illness: the hospice concept of care. Henry Ford Hosp Med J. 91;39(2):74-6. [Rec#: 13330] Exclude at abstract screening: no outcomes specified. [pmid: 1890011].
Magno J B. The hospice concept of care: facing the 1990s. Death Stud. 90;14(2):109-19. [Rec#: 13329] Exclude at abstract screening: no outcomes specified. [pmid: 10104360].
Magnusson L, Hanson E, Brito L, Berthold H, Chambers M, Daly T. Supporting family carers through the use of information and communication technology--the EU project ACTION. Int J Nurs Stud. 2002;39(4):369-81. [Rec#: 42098] Exclude at abstract screening: Observational study. [pmid: 11909614].
Maguire P, Pitceathly C. Key communication skills and how to acquire them. BMJ. 2002;325(7366):697-700. [Rec#: 50579] Exclude at abstract screening: Title Only. [pmid: 12351365]. [pmcid: 1124224].
Maguire P. Consequences of poor communication between nurses and patients. Nursing - Oxford. 85;2(38):1115-8. [Rec#: 50565] Exclude at abstract screening: Title Only.
Maguire P. Dementia care: challenges for an ageing Europe. Promotion et Education. 99;6(4):12-5. [Rec#: 50566] Exclude at abstract screening: Title Only.
Maguire P. Improving communication with cancer patients. European Journal of Cancer. 99;35(14):2058-65. [Rec#: 50567] Exclude at abstract screening: no outcomes specified. [pmid: 10711246].
Maguire P. Improving the recognition of concerns and affective disorders in cancer patients. Annals of Oncology. 2002;13(Suppl 4):177-81. [Rec#: 50568] Exclude at abstract screening: Title Only. [pmid: 12401687].
Maguire P. Late adverse psychological sequelae of breast cancer and its treatment. European Journal of Surgical Oncology. 99;25(3):317-20. [Rec#: 50569] Exclude at abstract screening: Title Only. [pmid: 10336815].
Maguire P. Managing psychological morbidity in cancer patients. European Journal of Cancer. 2000;36(5):556-8. [Rec#: 50570] Exclude at abstract screening: Title Only. [pmid: 10847695].
Maguire P. Psychosocial well-being in testicular cancer patients. European Journal of Cancer. 92;28A(45):722. [Rec#: 50572] Exclude at abstract screening: Title Only. [pmid: 1524889].
Maguire P. The psychological consequences of the surgical treatment of cancer of the breast. Surgery Annual. 90;22:77-91. [Rec#: 50571] Exclude at abstract screening: Title Only. [pmid: 2408173].
Maguire P. The use of antidepressants in patients with advanced cancer. Supportive Care in Cancer. 2000;8(4):265-7. [Rec#: 50573] Exclude at abstract screening: Title Only. [pmid: 10923765].
Maguire P, Faulkner A, Regnard C. Eliciting the current problems of the patient with cancer--a flow diagram. Palliative Medicine. 93;7(2):151-6. [Rec#: 50575] Exclude at abstract screening: no outcomes specified.
Maguire P, Faulkner A, Regnard C. Handling the withdrawn patient--a flow diagram. Palliative Medicine. 93;7(4):333-8. [Rec#: 50576] Exclude at abstract screening: no outcomes specified. [pmid: 8261199].
Maguire P, Faulkner A, Regnard C. Managing the anxious patient with advancing disease--a flow diagram. Palliative Medicine. 93;7(3):239-44. [Rec#: 50577] Exclude at abstract screening: no outcomes specified.
Maguire P, Faulkner A, Booth K, Elliott C, Hillier V. Helping cancer patients disclose their concerns. European Journal of Cancer. 96;32A(1):78-81. [Rec#: 50574] Exclude at abstract screening: not about end of life. [pmid: 8695247].
Maguire P, Hopwood P, Tarrier N, Howell T. Treatment of depression in cancer patients. Acta Psychiatrica Scandinavica, Supplementum. 85;320:81-4. [Rec#: 50578] Exclude at abstract screening: not about end of life. [pmid: 3901674].
Maher E J, Mackenzie C, Young T, Marks D. The use of the Hospital Anxiety and Depression Scale (HADS) and the EORTC QLQ-C30 questionnaires to screen for treatable unmet needs in patients attending routinely for radiotherapy. Cancer Treat Rev. 96;22(Suppl A):123-9. [Rec#: 4687] Exclude at abstract screening: Title Only.
Maher E J. Palliative medicine today--a matter for concern. Cancer Treat Rev. 93;19(Suppl A):15-21. [Rec#: 13336] Exclude at abstract screening: no outcomes specified. [pmid: 7679316].
Maher L A. Dignified departures. Many facilities are changing the face of death for their residents, making final exits as dignified as arrivals to aid bereavement. Contemp Longterm Care. 2000;23(12):24-9. [Rec#: 13339] Exclude at abstract screening: Title Only. [pmid: 11138377].
Mahoney D F, Tarlow B J, Jones R N. Effects of an automated telephone support system on caregiver burden and anxiety: findings from the REACH for TLC intervention study. Gerontologist. 2003;43(4):556-67. [Rec#: 50919] In abstract review process. [pmid: 12937334].
Maida V. Factors that promote success in home palliative care: a study of a large suburban palliative care practice. J Palliat Care. 2002;18(4):282-6. [Rec#: 4690] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12611319].
Maier G J, Bertram M, Stephens S. Hospice-assisted deaths in a forensic facility: a comparison of patient reactions. Am J Hosp Palliat Care. 91;8(3):15-22. [Rec#: 4693] Exclude at abstract screening: Title Only. [pmid: 1931320].
Mailis, A. and Furlan, A. Sympathectomy for neuropathic pain. Cochrane Database of Systematic Reviews 2003;(2):CD002918. [Rec#: 50580] Exclude at abstract screening: chemo/surg/stents/laser/radiation
Maillet J O, King D. Nutritional care of the terminally ill adult. Hosp J. 93;9(23):37-54. [Rec#: 13345] Exclude at abstract screening: useful only for background. [pmid: 7806180].
Maillet S. Spiritual care of the dying. CHAC Rev. 91;19(4):11-4. [Rec#: 13346] Exclude at abstract screening: Title Only. [pmid: 10145585].
Mailloux L U, Bellucci A G, Napolitano B, Mossey R T, Wilkes B M, Bluestone P A. Death by withdrawal from dialysis: a 20-year clinical experience. J Am Soc Nephrol. 93;3(9):1631-7. [Rec#: 4697] Exclude at abstract screening: data older than 1990.
Main J. Improving management of bereavement in general practice based on a survey of recently bereaved subjects in a single general practice. Br J Gen Pract. 2000;50(460):863-6. [Rec#: 4698] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11141870]. [pmcid: 1313848].
Main J. Management of relatives of patients who are dying. J Clin Nurs. 2002;11(6):794-801. [Rec#: 13347] Exclude at abstract screening: no outcomes specified. [pmid: 12427185].
Main J. Management of relatives of patients who are dying. Journal of Clinical Nursing. 2002;11(6):794-801. [Rec#: 50581] Exclude at abstract screening: Duplicate already in the flow. [pmid: 12427185].
Mak J M, Clinton M. Promoting a good death: an agenda for outcomes research--a review of the literature. Nurs Ethics. 99;6(2):97-106. [Rec#: 13351] In abstract review process. [pmid: 10358525].
Mak M H. Psychological responses to dying and death. Sr Nurse. 92;12(3):48-51. [Rec#: 13352] Exclude at abstract screening: Title Only. [pmid: 1299883].
Makela J T, Kiviniemi H, Laitinen S. Survival after operations for colorectal cancer in patients aged 75 years or over. Eur J Surg. 2000;166(6):473-9. [Rec#: 4707] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 10890544].
Makosky N R, Lynn J. Improving end-of-life care: what providers need to know. Mich Health Hosp. 99;35(2):8-10. [Rec#: 13354] Exclude at abstract screening: no outcomes specified. [pmid: 10350816].
Malmgren J A, Koepsell T D, Martin D P, Diehr P, LaCroix A Z. Mortality, health services use, and health behavior in a cohort of well older adults. J Am Geriatr Soc. 99;47(1):51-9. [Rec#: 42106] Exclude at abstract screening: data older than 1990.
Malonebeach E E, Zarit S H. Current research issues in caregiving to the elderly. Int J Aging Hum Dev. 91;32(2):103-14. [Rec#: 42108] Exclude at abstract screening: no outcomes specified. [pmid: 2055656].
MaloneBeach E E, Zarit S H, Spore D L. Caregivers' perceptions of case management and community-based services: barriers to service use. J Appl Gerontol. 92;11(2):146-59. [Rec#: 42109] Exclude at abstract screening: not about end of life.
Maltoni M, Nanni O, Naldoni M, Serra P, Amadori D. Evaluation of cost of home therapy for patients with terminal diseases. Curr Opin Oncol. 98;10(4):302-9. [Rec#: 13367] Exclude at abstract screening: no outcomes specified.
Maltoni M, Pirovano M, Nanni O, Marinari M, Indelli M, Gramazio A, Terzoli E, Luzzani M, De Marinis F, Caraceni A, Labianca R. Biological indices predictive of survival in 519 Italian terminally ill cancer patients. Italian Multicenter Study Group on Palliative Care. J Pain Symptom Manage. 97;13(1):1-9. [Rec#: 4734] Exclude at abstract screening: primarily prognosis or trajectories.
Maltoni M, Travaglini C, Santi M, Nanni O, Scarpi E, Benvenuti S, Albertazzi L, Amaducci L, Derni S, Fabbri L, Masi A, Montanari L, Pasini G, Polselli A, Tonelli U, Turci P, Amadori D. Evaluation of the cost of home care for terminally ill cancer patients. Support Care Cancer. 97;5(5):396-401. [Rec#: 4736] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Mancini D M, Katz S D, Lang C C, LaManca J, Hudaihed A, Androne A S. Effect of erythropoietin on exercise capacity in patients with moderate to severe chronic heart failure. Circulation 2003;107(2):294–9. Comment in: Circulation. 2003 Aug 12;108(6):e41–2; author reply e41–2. PMID: 12914016. Comment in: Circulation. Jan 21. 2003;107(2):e9004. PMID: 12538444. [Rec#: 33448] Exclude at abstract screening: Other symptoms only.
Mancini I, Lossignol D, Obiols M, Llop R, Toth C, Body J J. Supportive and palliative care: experience at the Institut Jules Bordet. Support Care Cancer. 2002;10(1):3-7. [Rec#: 4743] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11777185].
Mandler R N, Anderson F A Jr, Miller R G, Clawson L, Cudkowicz M, Del Bene M. ALS C.A.R.E. Study Group. The ALS Patient Care Database: insights into end-of-life care in ALS. Amyotroph Lateral Scler Other Motor Neuron Disord. 2001;2(4):203-8. [Rec#: 4746] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11958732].
Mandler R N, Anderson F A Jr, Miller R G, Clawson L, Cudkowicz M, Del Bene M. Als C. A. R. E. Study Group. The ALS Patient Care Database: insights into end-of-life care in ALS. Amyotrophic Lateral Sclerosis & Other Motor Neuron Disorders. 2001;2(4):203-8. [Rec#: 50583] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11958732].
Manegold C, Schwarz R. Quality of life and supportive care in the treatment of NSCLC. Chest. 96;109(5 Suppl):113S-114S. [Rec#: 13383] Exclude at abstract screening: no outcomes specified. [pmid: 8635387].
Manfredi P L, Gonzales G R. Symptomatic uses of caffeine in patients with cancer. Journal of Palliative Care. 2003;19(1):63-5. [Rec#: 50587] Exclude at abstract screening: not about end of life. [pmid: 12710118].
Manfredi P L, Foley K M, Payne R, Houde R, Inturrisi C E. Parenteral methadone: an essential medication for the treatment of pain. Journal of Pain & Symptom Management. 2003;26(2):687-8. [Rec#: 50586] Exclude at abstract screening: not about end of life. [pmid: 12906950].
Manfredi P L, Gonzales G R, Cheville A L, Kornick C, Payne R. Methadone analgesia in cancer pain patients on chronic methadone maintenance therapy. Journal of Pain & Symptom Management. 2001;21(2):169-74. [Rec#: 50588] Exclude at abstract screening: Observational study. [pmid: 11226767].
Manfredi P L, Gonzales G R, Sady R, Chandler S, Payne R. Neuropathic pain in patients with cancer. Journal of Palliative Care. 2003;19(2):115-8. [Rec#: 50589] Exclude at abstract screening: Study Design - Unclear. [pmid: 12955928].
Manfredi P L, Ribeiro S, Chandler S W, Payne R. Inappropriate use of naloxone in cancer patients with pain. Journal of Pain & Symptom Management. 96;11(2):131-4. [Rec#: 50590] Exclude at abstract screening: Observational study.
Manfredi P L, Shenoy S, Payne R. Sumatriptan for headache caused by head and neck cancer. Headache. 2000;40(9):758-60. [Rec#: 50591] Exclude at abstract screening: not about end of life. [pmid: 11091298].
Manganello TD. Disabling the pacemaker: the heart-rending decision every competent patient has a right to make. Health Care Law Mon 2000;3–15. [Rec#: 4750] Exclude at abstract screening: Title Only
Mangone C A, Sanguinetti R M, Baumann P D, Gonzalez R C, Pereyra S, Bozzola F G, Gorelick P B, Sica R E. Influence of feelings of burden on the caregiver's perception of the patient's functional status. Dementia. 93;4(5):287-93. [Rec#: 33462] Exclude at abstract screening: Observational study.
Manheim L M, Guihan M, Hughes S L. Organizational characteristics, client characteristics, and the delivery of home care services. Med Care Res Rev. 95;52(4):517-31. [Rec#: 42114] Exclude at abstract screening: data older than 1990.
Manifold C A, Storrow A, Rodgers K. Patient and family attitudes regarding the practice of procedures on the newly deceased. Acad Emerg Med. 99;6(2):110-5. [Rec#: 4753] Exclude at abstract screening: not about end of life.
Manima A. Ethical issues in palliative care: considerations. J Pain Palliat Care Pharmacother. 2003;17(34):141-9. [Rec#: 4754] Exclude at abstract screening: no outcomes specified. [pmid: 15022958].
Manion J C. Cancer pain management in the hospice setting. Minn Med. 95;78(2):25-8. [Rec#: 13387] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 7534376].
Manisty C, Waxman J. Doctors should not discuss resuscitation with terminally ill patients: FOR. BMJ. 2003;327(7415):614-5. [Rec#: 13388] Exclude at abstract screening: Title Only. [pmid: 12969934]. [pmcid: 194097].
Mann E, Redwood S. Improving pain management: breaking down the invisible barrier. Br J Nurs. 2000;9(19):2067-72. [Rec#: 13390] Exclude at abstract screening: no outcomes specified. [pmid: 11868183].
Mann S M, Welk T A. Hospice and/or palliative care?. Am J Hosp Palliat Care. 97;14(6):314-5. [Rec#: 13391] Exclude at abstract screening: Title Only. [pmid: 9392730].
Mann S M, Welk T A. Hospice Incorporated: combining high tech and high touch care. Kans Nurse. 97;72(9):3-4. [Rec#: 13392] Exclude at abstract screening: Title Only. [pmid: 9384123].
Mann W C, Marchant T, Tomita M, Fraas L, Stanton K. Elder acceptance of health monitoring devices in the home. Care Manag J. 2001-2002;3(2):91-8. [Rec#: 42116] Exclude at abstract screening: Study Design - Qualitative.
Mann W J, Loesch M, Shurpin K M, Chalas E. Determinants of home versus hospital terminal care for patients with gynecologic cancer. Cancer. 93;71(9):2876-9. [Rec#: 4755] Exclude at abstract screening: data older than 1990.
Manor O, Eisenbach Z. Mortality after spousal loss: are there socio-demographic differences?. Soc Sci Med. 2003;56(2):405-13. [Rec#: 4756] Notes: “EXCLUDE: Location, non-Western”. [pmid: 12473324].
Manser R L, Irving L B, Byrnes G, Abramson M J, Stone C A, Campbell D A. Screening for lung cancer: a systematic review and meta-analysis of controlled trials. Thorax. 2003;58(9):784-9. [Rec#: 33471] Exclude at abstract screening: not about end of life. [pmid: 12947138].
Man-Son-Hing M, Power B, Byszewski A, Dalziel W B. Referral to specialized geriatric services. Which elderly people living in the community are likely to benefit?. Can Fam Physician. 97;43:925-30. [Rec#: 42112] Exclude at abstract screening: not about end of life.
Manton K G, Woodbury M A, Vertrees J C, Stallard E. Use of Medicare services before and after introduction of the prospective payment system. Health Serv Res. 93;28(3):269-92. [Rec#: 42119] Exclude at abstract screening: useful only for background.
Mantz M, Crandall J M. Palliative care crises in the community: a survey. J Palliat Care. 2000;16(4):33-8. [Rec#: 4762] Exclude at abstract screening: Study Design - Unclear. [pmid: 11965933].
Manzetti J D, Ankeny R, Miller D. Psychosocial and ethical issues in surgical approaches to end-stage lung disease. Clin Chest Med. 97;18(2):383-90. [Rec#: 13397] Exclude at abstract screening: no outcomes specified.
Manzullo E F, Escalante C P. Research into fatigue. Hematol Oncol Clin North Am. 2002;16(3):619-28. [Rec#: 13398] Exclude at abstract screening: no outcomes specified. [pmid: 12170571].
Mara C Z. Hospice: an organizational systems model for the integration of acute and long-term care. J Health Hum Serv Adm. 2000;22(4):416-35. [Rec#: 4765] Exclude at abstract screening: no outcomes specified. [pmid: 11211555].
Marcant D, Rapin C H. Role of the physiotherapist in palliative care. J Pain Symptom Manage. 93;8(2):68-71. [Rec#: 4768] Exclude at abstract screening: Other topic only. [pmid: 7684058].
Marchand L, Cloutier V M, Gjerde C, Haq C. Factors influencing rural Wisconsin elders in completing advance directives. WMJ. 2001;100(9):26-31. [Rec#: 4769] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11868517].
Marek K D, Rantz M J, Porter R T. Senior care: making a difference in long-term care of older adults. J Nurs Educ. 2004;43(2):81-3. [Rec#: 42121] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14974516].
Margolis M L, Christie J D, Silvestri G A, Kaiser L, Santiago S, Hansen-Flaschen J. Racial differences pertaining to a belief about lung cancer surgery: results of a multicenter survey. Ann Intern Med 2003;139(7):558–63. Comment in: Ann Intern Med. Oct 7. 2003;139(7):I38. PMID: 14530250. [Rec#: 33494] Exclude at abstract screening: not about end of life.
Marik P E, Zaloga G P. CPR in terminally ill patients?. Resuscitation. 2001;49(1):99-103. [Rec#: 4777] Exclude at abstract screening: Observational study. [pmid: 11334696].
Marik P E. The cost of dying. Am J Crit Care. 95;4(1):56-8. [Rec#: 4776] Exclude at abstract screening: Title Only. [pmid: 7894557].
Marino P, Pampallona S, Preatoni A, Cantoni A, Invernizzi F. Chemotherapy vs supportive care in advanced non-small-cell lung cancer. Results of a meta-analysis of the literature. Chest 94;106(3):861–5. Comment in: Chest. Sep. 1994;106(3):659-61. PMID: 8082331. [Rec#: 13408] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Market report: RAND care in last year of life. Russ Coiles Health Trends 2002;14(11):9–12. [Rec#: 4780] Exclude at abstract screening: useful only for background
Markle-Reid M, Browne G. Conceptualizations of frailty in relation to older adults. J Adv Nurs. 2003;44(1):58-68. [Rec#: 42137] Exclude at abstract screening: useful only for background. [pmid: 12956670].
Markman M. Supportive care. Cancer Chemother Biol Response Modif. 2002;20:627-32. [Rec#: 13413] Exclude at abstract screening: Title Only. [pmid: 12703227].
Markman M. The high cost of terminal care: balancing conflicting goals. Cleve Clin J Med. 98;65(4):219-21. [Rec#: 13412] Exclude at abstract screening: Title Only. [pmid: 9597789].
Markowitz A J, Rabow M. Management of dyspnea in patients with far-advanced lung disease. JAMA 2002;287(17):2261. Comment on: JAMA. Mar 14. 2001;285(10):1331-7. PMID: 11255389. [Rec#: 4784] Exclude at abstract screening: useful only for background.
Markowitz A J, Rabow M W. Alzheimer disease: “it's okay, mama, if you want to go, it's okay”. JAMA 2003;290(1):105. Comment on: JAMA. Nov 13. 2002;288(18):2324-31. PMID: 12425711. [Rec#: 4785] Exclude at abstract screening: Title Only.
Markowitz A J, Rabow M W. Caring for bereaved patients: “All the doctors just suddenly go”. JAMA. 2002;287(7):882. [Rec#: 4786] Exclude at abstract screening: Title Only. [pmid: 11851581].
Markowitz A J, Rabow M W. Overcoming the false dichotomy of “curative” vs “palliative” care for late-stage HIV/AIDS: “let me live the way I want to live, until I can't”. JAMA 2004;291(4):492. Comment on: JAMA. Aug 13. 2003;290(6):806-14. PMID: 12915434. [Rec#: 4787] Exclude at abstract screening: useful only for background.
Markowitz A J, Rabow M W. Practical considerations in dialysis withdrawal: “to have that option is a blessing”. JAMA 2003;290(6):815. Comment on: JAMA. Apr 23–30. 2003;289(16):2113-9. PMID: 12709469. [Rec#: 4788] Exclude at abstract screening: Title Only.
Markson L, Clark J, Glantz L, Lamberton V, Kern D, Stollerman G. The doctor's role in discussing advance preferences for end-of-life care: perceptions of physicians practicing in the VA. J Am Geriatr Soc. 97;45(4):399-406. [Rec#: 4791] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Marren J. The real world experience: death of homebound elderly persons. Staff views from the front lines. Pride Inst J Long Term Home Health Care. 93;12(2):42-5. [Rec#: 42141] Exclude at abstract screening: no outcomes specified.
Marsden C. ‘Do not resuscitate’ orders and end-of-life care planning. Am J Crit Care 93;2(2):177–9. Comment in: Am J Crit Care. Sep. 1993;2(5):431. PMID: 8220677. [Rec#: 13423] Exclude at abstract screening: Title Only.
Marsh G W, Prochoda K P, Pritchett E, Vojir C P. Predicting hospice appropriateness for patients with dementia of the Alzheimer's type. Appl Nurs Res. 2000;13(4):187-96. [Rec#: 4798] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 11078784].
Marshall P A. The SUPPORT Study. Who's talking?. Hastings Cent Rep. 95;25(6):S9-11. [Rec#: 13427] Exclude at abstract screening: Title Only. [pmid: 8609008].
Martens K H. Home care nursing for persons with congestive heart failure: description and relationship to hospital readmission. Home Healthc Nurse. 2000;18(6):404-9. [Rec#: 50069] Exclude at abstract screening: not about end of life. [pmid: 11951301].
Martensson J, Karlsson J E, Fridlund B. Female patients with congestive heart failure: how they conceive their life situation. J Adv Nurs. 98;28(6):1216-24. [Rec#: 33507] Exclude at abstract screening: not about end of life.
Martensson J, Karlsson J E, Fridlund B. Male patients with congestive heart failure and their conception of the life situation. J Adv Nurs. 97;25(3):579-86. [Rec#: 33508] Exclude at abstract screening: no outcomes specified.
Martikainen P, Valkonen T. Mortality after death of spouse in relation to duration of bereavement in Finland. J Epidemiol Community Health. 96;50(3):264-8. [Rec#: 4801] Exclude at abstract screening: data older than 1990.
Martikainen P, Valkonen T. Mortality after the death of a spouse: rates and causes of death in a large Finnish cohort. Am J Public Health. 96;86(8 Pt 1):1087-93. [Rec#: 4802] Exclude at abstract screening: data older than 1990.
Martin B. A place to care: the homebound elderly. Home Care Provid. 99;4(2):76-9. [Rec#: 42150] Exclude at abstract screening: not about end of life. [pmid: 10418400].
Martin D K, Emanuel L L, Singer P A. Planning for the end of life. Lancet 2000;356(9242):1672–6. Comment in: Lancet. Feb 24. 2001;357(9256):640. PMID: 11558521. [Rec#: 13432] Exclude at abstract screening: Title Only.
Martin D K, Thiel E C, Singer P A. A new model of advance care planning: observations from people with HIV. Arch Intern Med. 99;159(1):86-92. [Rec#: 4804] Exclude at abstract screening: Study Design - Qualitative.
Martin E W. Confusion in the terminally ill: recognition and management. Am J Hosp Palliat Care. 90;7(3):20-4. [Rec#: 13433] Exclude at abstract screening: not about end of life. [pmid: 2361108].
Martin E W. Inpatient hospice care: a new option for the terminally ill. R I Med. 95;78(4):118-9. [Rec#: 4805] Exclude at abstract screening: Title Only. [pmid: 7795304].
Martin G. Changing the culture of care for dying patients. Prof Nurse. 97;12(7):498-500. [Rec#: 13435] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 9155460].
Martin G W. Empowerment of dying patients: the strategies and barriers to patient autonomy. J Adv Nurs. 98;28(4):737-44. [Rec#: 13436] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Martin J P. Making terminal care decisions. Caring. 91;10(7):42-5. [Rec#: 4809] Exclude at abstract screening: useful only for background. [pmid: 10112740].
Martinez, M. J., Roque, M., Alonso-Coello, P., Catala, E., Garcia, J. L., and Ferrandiz, M. Calcitonin for metastatic bone pain. Cochrane Database of Systematic Reviews 2003;(3):CD003223. [Rec#: 50593] Exclude at abstract screening: Other topic only
Martinez, M. J., Roque, M., Catala, E., Ferrandiz, M., and Garcia, J. L. Radioisotopes for metastatic bone pain. Cochrane Database of Systematic Reviews 2003;3. [Rec#: 50594] Exclude at abstract screening: Title Only
Martinot A, Grandbastien B, Leteurtre S, Duhamel A, Leclerc F. No resuscitation orders and withdrawal of therapy in French paediatric intensive care units. Groupe Francophone de Reanimation et d'Urgences Pediatriques. Acta Paediatr 98;87(7):769–73. Comment in: Acta Paediatr. 1998 Jul;87(7):721–2. PMID: 9722241. Comment in: Acta Paediatr. Jul. 1999;88(7):790-1. PMID: 10447145. [Rec#: 42157] Notes: “EXCLUDE: Age, not adults”.
Marwick T H, Zuchowski C, Lauer M S, Secknus M A, Williams J, Lytle B W. Functional status and quality of life in patients with heart failure undergoing coronary bypass surgery after assessment of myocardial viability. J Am Coll Cardiol. 99;33(3):750-8. [Rec#: 33525] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Maslow K. Linking persons with dementia to appropriate services: summary of an OTA study. Pride Inst J Long Term Home Health Care. 90;9(2):42-50. [Rec#: 33529] Exclude at abstract screening: not about end of life.
Mason R. Palliation of malignant dysphagia: an alternative to surgery. Ann R Coll Surg Engl. 96;78(5):457-62. [Rec#: 4827] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 8881732].
Masoudi F A, Havranek E P, Krumholz H M. The burden of chronic congestive heart failure in older persons: magnitude and implications for policy and research. Heart Fail Rev. 2002;7(1):9-16. [Rec#: 33531] Exclude at abstract screening: not about end of life. [pmid: 11790919].
Massaro T, McMillan S C. Instruments for assessing quality of life in palliative care settings. Int J Palliat Nurs. 2000;6(9):429-33. [Rec#: 13457] In abstract review process. [pmid: 12388894].
Massarotto A, Carter H, MacLeod R, Donaldson N. Hospital referrals to a hospice: timing of referrals, referrers' expectations, and the nature of referral information. J Palliat Care. 2000;16(3):22-9. [Rec#: 4830] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11019504].
Matheny S C. Clinical dilemmas in palliative care for HIV infection. J R Soc Med. 2001;94(9):449-51. [Rec#: 4838] Exclude at abstract screening: Title Only. [pmid: 11535746]. [pmcid: 1282183].
Matherlee K. Managing advanced illness: a quality and cost challenge to Medicare, Medicaid, and private insurers. NHPF Issue Brief 2002;(779):1–19. [Rec#: 13466] Exclude at abstract screening: useful only for background
Mathew P, Storey P. Subcutaneous methadone in terminally ill patients: manageable local toxicity. J Pain Symptom Manage 99;18(1):49–52. Comment in: J Pain Symptom Manage. Apr. 2000;19(4):237-8. PMID: 10866549. [Rec#: 4840] Exclude at abstract screening: Observational study.
Matteson M A, Reilly M, Moseley M. Needs assessment of homebound elders in a parish church: implications for parish nursing. Geriatr Nurs. 2000;21(3):144-7. [Rec#: 42175] Exclude at abstract screening: not about end of life. [pmid: 10864694].
Matthis E J. Care of frail elders with relinquishing dispositions. Home Healthc Nurse. 94;12(5):30-5. [Rec#: 42176] Exclude at abstract screening: not about end of life. [pmid: 7960881].
Matzo M L, Sherman D W. Palliative care nursing: ensuring competent care at the end of life. Geriatr Nurs. 2001;22(6):288-93. [Rec#: 4854] Exclude at abstract screening: useful only for background. [pmid: 11780001].
Matzo M L. Exploring end-of-life issues. J Gerontol Nurs. 97;23(3):7-8. [Rec#: 4853] Exclude at abstract screening: Title Only. [pmid: 9111415].
Maull F. Dying in prison: sociocultural and psychosocial dynamics. Hosp J. 91;7(12):127-42. [Rec#: 4858] Exclude at abstract screening: data older than 1990. [pmid: 1937434].
May S. Palliation in acute care. Aust Nurs J. 97;5(4):26. [Rec#: 13493] Exclude at abstract screening: no outcomes specified. [pmid: 9386394].
May V, Onarcan M, Olechowski C, Mayron Z. International perspectives on the role of home care and hospice in aging and long-term care. Caring. 2004;23(1):14-7. [Rec#: 4869] Exclude at abstract screening: Title Only. [pmid: 14870475].
Mayer-Oakes S A, Kelman G, Beers M H, De Jong F, Matthias R, Atchison K A, Lubben J E, Schweitzer S O. Benzodiazepine use in older, community-dwelling southern Californians: prevalence and clinical correlates. Ann Pharmacother. 93;27(4):416-21. [Rec#: 42183] Exclude at abstract screening: not about end of life.
Mayo Clinic office visit. End-of-life issues. Mayo Clin Womens Healthsource 2003;7(11):S1-S2. [Rec#: 4874] Exclude at abstract screening: useful only for background
Mayo Clinic office visit. Palliative care. Mayo Clin Womens Healthsource 2001;5(10):S1-S2. [Rec#: 4875] Exclude at abstract screening: useful only for background
Mayo S. Symbol, metaphor and story. The function of group art therapy in palliative care. Palliative Medicine. 96;10(3):209-16. [Rec#: 50596] Exclude at abstract screening: Title Only. [pmid: 8817591].
Mazanec, P, Tyler M K. Cultural considerations in end-of-life care: how ethnicity, age, and spirituality affect decisions when death is imminent. AJN, American Journal of Nursing. 2003;103(3):50-8. Quiz 59. [Rec#: 50597] Exclude at abstract screening: no outcomes specified.
McAlister F A, Lawson F M, Teo K K, Armstrong P W. A systematic review of randomized trials of disease management programs in heart failure. Am J Med. 2001;110(5):378-84. [Rec#: 50140] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 11286953].
McAlister F A, Stewart S, Ferrua S, McMurray J J. Multidisciplinary strategies for the management of heart failure patients at high risk for admission: a systematic review of randomized trials. J Am Coll Cardiol. 2004;44(4):810-9. [Rec#: 50911] In abstract review process. [pmid: 15312864].
McArthur-Rouse F. Critical care outreach services and early warning scoring systems: a review of the literature. J Adv Nurs. 2001;36(5):696-704. [Rec#: 42192] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11737502].
McAulay D. Dehydration in the terminally ill patient. Nurs Stand. 2001;16(4):33-7. [Rec#: 13507] Exclude at abstract screening: no outcomes specified. [pmid: 11977821].
McBride C M, Pollak K I, Garst J, Keefe F, Lyna P, Fish L, Hood L. Distress and motivation for smoking cessation among lung cancer patients' relatives who smoke. J Cancer Educ. 2003;18(3):150-6. [Rec#: 33593] Exclude at abstract screening: not about end of life. [pmid: 14512262].
McCahill L E, Krouse R S, Chu D Z, Juarez G, Uman G C, Ferrell B R, Wagman L D. Decision making in palliative surgery. J Am Coll Surg. 2002;195(3):411-22. discussion 422–3. [Rec#: 4892] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12229950].
McCahill L E, Smith D D, Borneman T, Juarez G, Cullinane C, Chu D Z, Ferrell B R, Wagman L D. A prospective evaluation of palliative outcomes for surgery of advanced malignancies. Ann Surg Oncol. 2003;10(6):654-63. [Rec#: 4893] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 12839850].
McCain N L, Gramling L F. Living with dying: coping with HIV disease. Issues Ment Health Nurs. 92;13(3):271-84. [Rec#: 4895] Exclude at abstract screening: Study Design - Qualitative. [pmid: 1399523].
McCamish M A, Crocker N J. Enteral and parenteral nutrition support of terminally ill patients: practical and ethical perspectives. Hosp J. 93;9(23):107-29. [Rec#: 13515] Exclude at abstract screening: no outcomes specified.
McCandless N J, Conner F P. Working with terminally ill older women: can a feminist perspective add new insight and direction?. J Women Aging. 99;11(23):101-14. [Rec#: 4899] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
McCarberg B. Chronic pain management: a clinical overview. Manag Care. 2002;11(7 Suppl):19-22. [Rec#: 13517] Exclude at abstract screening: Title Only. [pmid: 12181873].
McCarron E G. Supporting the families of cancer patients. Nursing. 95;25(6):48-51. [Rec#: 13518] Exclude at abstract screening: Title Only. [pmid: 7624083].
McCarthy E P, Burns R B, Ngo-Metzger Q, Davis R B, Phillips R S. Hospice use among Medicare managed care and fee-for-service patients dying with cancer. JAMA 2003;289(17):2238–45. Comment in: JAMA. Sep 24. 2003;290(12):1578. author reply 1578–9. PMID: 14506113 [Rec#: 4909] Exclude at abstract screening: useful only for background.
McCarthy M, Higginson I. Clinical audit by a palliative care team. Palliative Medicine. 91;5:215-221. [Rec#: 50598] Exclude at abstract screening: Title Only.
McClain K, Perkins P. Terminally ill patients in the emergency department: a practical overview of end-of-life issues. J Emerg Nurs. 2002;28(6):515-22. [Rec#: 13523] Exclude at abstract screening: Title Only. [pmid: 12509728].
McClatchey S. Disease management as a performance improvement strategy. Top Health Inf Manage. 2001;22(2):15-23. [Rec#: 50071] Exclude at abstract screening: Title Only. [pmid: 11761788].
McClement S E, Degner L F. Expert nursing behaviors in care of the dying adult in the intensive care unit. Heart Lung. 95;24(5):408-19. [Rec#: 4920] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
McClement S E, Degner L F, Harlos M S. Family beliefs regarding the nutritional care of a terminally ill relative: a qualitative study. J Palliat Med. 2003;6(5):737-48. [Rec#: 4921] Exclude at abstract screening: Study Design - Qualitative. [pmid: 14622453].
McClement S E, Woodgate R L, Degner L. Symptom distress in adult patients with cancer. Cancer Nursing. 97;20(4):236-43. [Rec#: 50599] Exclude at abstract screening: no outcomes specified. [pmid: 9265809].
McConnell E S, Lekan-Rutledge D, Nevidjon B, Anderson R. Complexity theory: a long-term care specialty practice exemplar for the education of advanced practice nurses. J Nurs Educ. 2004;43(2):84-7. [Rec#: 42199] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14974517].
McConnell T R, Mandak J S, Sykes J S, Fesniak H, Dasgupta H. Exercise training for heart failure patients improves respiratory muscle endurance, exercise tolerance, breathlessness, and quality of life. J Cardiopulm Rehabil. 2003;23(1):10-6. [Rec#: 33606] Exclude at abstract screening: not about end of life. [pmid: 12576906].
McCord A S. When the patient dies: helping the family and staff to cope. Todays OR Nurse. 90;12(11):17-20. [Rec#: 13536] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
McCorkle R, Pasacreta J V. Enhancing caregiver outcomes in palliative care. Cancer Control. 2001;8(1):36-45. [Rec#: 13537] Exclude at abstract screening: Non-systematic review. [pmid: 11252271].
McCorkle R, Hughes L, Robinson L, Levine B, Nuamah I. Nursing interventions for newly diagnosed older cancer patients facing terminal illness. J Palliat Care. 98;14(3):39-45. [Rec#: 4931] Exclude at abstract screening: useful only for background.
McCorkle R, Robinson L, Nuamah I, Lev E, Benoliel J Q. The effects of home nursing care for patients during terminal illness on the bereaved's psychological distress. Nurs Res. 98;47(1):2-10. [Rec#: 33607] Exclude at abstract screening: Bereavement only.
McCormick T R, Conley B J. Patients' perspectives on dying and on the care of dying patients. West J Med. 95;163(3):236-43. [Rec#: 13540] Exclude at abstract screening: no outcomes specified. [pmid: 7571586].
McCormick W C, Hardy J, Kukull W A, Bowen J D, Teri L, Zitzer S, Larson E B. Healthcare utilization and costs in managed care patients with Alzheimer's disease during the last few years of life. J Am Geriatr Soc 2001;49(9):1156–60. Comment in: J Am Geriatr Soc. Sep. 2001;49(9):1255-6. PMID: 11559389 [Rec#: 33609] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
McCormick W C. A home-based intervention reduced out-of-hospital deaths and hospitalizations in CHF. ACP J Club. 99;131(3):A15. [Rec#: 50072] Exclude at abstract screening: Title Only. [pmid: 10605418].
McCracken C F, Boneham M A, Copeland J R, Williams K E, Wilson K, Scott A, McKibbin P, Cleave N. Prevalence of dementia and depression among elderly people in black and ethnic minorities. Br J Psychiatry. 97;171:269-73. [Rec#: 33610] Exclude at abstract screening: not about end of life.
McCracken S, Colburn K, Pastorik L. Hospice care: mapping the message. Am J Hosp Palliat Care. 94;11(3):30-5. [Rec#: 4936] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 7893555].
McCue J D. The naturalness of dying. JAMA 95;273(13):1039–43. Comment in: JAMA. Oct 4. 1995;274(13):1016. PMID: 7563450 [Rec#: 4938] Exclude at abstract screening: useful only for background.
McCuistion P O. Increasing minority access to hospice care. Am J Hosp Palliat Care. 94;11(5):19-21. [Rec#: 13545] Exclude at abstract screening: Title Only. [pmid: 7880643].
McCullough P K. Evaluation and management of anxiety in the older adult. Geriatrics. 92;47(4):35-38. [Rec#: 50601] Exclude at abstract screening: Title Only. [pmid: 1555778].
McCurdy D B. Personhood, spirituality, and hope in the care of human beings with dementia. J Clin Ethics. 98;9(1):81-91. [Rec#: 33616] Exclude at abstract screening: Title Only. [pmid: 9598436].
McDermott A. Involving patients in discussions of do-not-resuscitate orders. Prof Nurse. 2002;17(8):465-8. [Rec#: 13549] Exclude at abstract screening: no outcomes specified. [pmid: 11997959].
McDevitt J, Porter K, Murray M. A continuum of palliative care. Can Nurse. 92;88(4):39-41. [Rec#: 13551] Exclude at abstract screening: Title Only. [pmid: 1568194].
McDonald K, Ledwidge M, Cahill J, Kelly J, Quigley P, Maurer B, Begley F, Ryder M, Travers B, Timmons L, Burke T. Elimination of early rehospitalization in a randomized, controlled trial of multidisciplinary care in a high-risk, elderly heart failure population: the potential contributions of specialist care, clinical stability and optimal angiotensin-converting enzyme inhibitor dose at discharge. Eur J Heart Fail. 2001;3(2):209-15. [Rec#: 50073] Exclude at abstract screening: not about end of life. [pmid: 11246059].
McDonald K, Ledwidge M, Cahill J, Quigley P, Maurer B, Travers B, Ryder M, Kieran E, Timmons L, Ryan E. Heart failure management: multidisciplinary care has intrinsic benefit above the optimization of medical care. J Card Fail. 2002;8(3):142-8. [Rec#: 33624] Exclude at abstract screening: not about end of life. [pmid: 12140806].
McDonald M V, Passik S D, Dugan W, Rosenfeld B, Theobald D E, Edgerton S. Nurses' recognition of depression in their patients with cancer. Oncology Nursing Forum. 99;26:593-599. [Rec#: 50602] Exclude at abstract screening: Title Only.
McDougall G J, Balyer J. Decreasing mental frailty in at-risk elders. Geriatr Nurs. 98;19(4):220-4. [Rec#: 42205] Exclude at abstract screening: Non-systematic review. [pmid: 9866512].
McDowell E E. Death's challenges from the perspective of three generations of elderly. J Long Term Home Health Care. 97;16(3):4-14. [Rec#: 4949] Exclude at abstract screening: Title Only. [pmid: 10173285].
McGee H M, O'Boyle C A, Hickey A, O'Malley K, Joyce C R. Assessing the quality of life of the individual: the SEIQoL with a healthy and a gastroenterology unit population. Psychol Med. 91;21(3):749-59. [Rec#: 50876] Exclude at abstract screening: not about end of life.
McGilton KS, Rivera TM, and Dawson P. Can we help persons with dementia find their way in a new environment? Aging Ment Health 2003;7(5):363–71. Erratum in: Aging Ment Health. 2003 Nov;7(6):following author index. [Rec#: 50074] In abstract review process
McGloin J M. Dying in Connecticut--the facts. Conn Med. 2002;66(11):665-9. [Rec#: 4963] Exclude at abstract screening: Title Only. [pmid: 12476508].
McGough K and Ladd L. Facilitating communication and collaboration across the continuum: a transportable plan of care. J Nurs Adm 99;29(7–8):42, 56. [Rec#: 13574] Exclude at abstract screening: no outcomes specified
McGouran R C. Dying with dignity. Clin Med. 2002;2(1):43-4. [Rec#: 4964] Exclude at abstract screening: Title Only. [pmid: 11873765].
McGovern M. A nurse-led service to provide palliative care in the community. Prof Nurse. 2001;17(2):127-8. [Rec#: 4965] Exclude at abstract screening: no outcomes specified. [pmid: 12030064].
McGrath P, Vun M, McLeod L. Needs and experiences of non-English-speaking hospice patients and families in an English-speaking country. Am J Hosp Palliat Care 2001;18(5):305–12. Comment in: Am J Hosp Palliat Care. Nov-Dec. 2001;18(6):429. PMID: 11712727 [Rec#: 13581] Exclude at abstract screening: useful only for background.
McGrath P, Yates P, Clinton M, Hart G. “What should I say?”: qualitative findings on dilemmas in palliative care nursing. Hosp J. 99;14(2):17-33. [Rec#: 13582] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
McGrath P. Caregivers' insights on the dying trajectory in hematology oncology. Cancer Nurs. 2001;24(5):413-21. [Rec#: 4972] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 11605712].
McGrath P. Creating a language for ‘spiritual pain’ through research: a beginning. Support Care Cancer 2002;10(8):637–46. Comment in: Support Care Cancer. Jun. 2003;11(6):378-9. author reply 380–1. PMID: 12720071 [Rec#: 4973] Exclude at abstract screening: Observational study.
McGrath P. Dying in the curative system: the haematology/oncology dilemma. Part 1. Aust J Holist Nurs. 2001;8(2):22-30. [Rec#: 4974] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11898758].
McGrath P. End-of-life care for hematological malignancies: the ‘technological imperative’ and palliative care. J Palliat Care. 2002;18(1):39-47. [Rec#: 4975] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12001402].
McGrath P. Palliative care for patients with hematological malignancies--if not, why not?. J Palliat Care. 99;15(3):24-30. [Rec#: 4976] Exclude at abstract screening: useful only for background. [pmid: 10540795].
McGrath P. Putting spirituality on the agenda: hospice research findings on the ‘ignored’ dimension. Hosp J. 97;12(4):1-14. [Rec#: 13579] Exclude at abstract screening: Study Design - Unclear. [pmid: 9305021].
McGrath P. Qualitative findings on the experience of end-of-life care for hematological malignancies. Am J Hosp Palliat Care 2002;19(2):103–11. Comment in: Am J Hosp Palliat Care. Mar-Apr. 2002;19(2):79-80. PMID: 11926447 [Rec#: 4977] Exclude at abstract screening: Study Design - Qualitative.
McGrath P. Religiosity and the challenge of terminal illness. Death Stud. 2003;27(10):881-99. [Rec#: 13580] Exclude at abstract screening: Study Design - Qualitative. [pmid: 14610778].
McGrath P. The burden of the ‘RA RA’ positive: survivors' and hospice patients' reflections on maintaining a positive attitude to serious illness. Support Care Cancer. 2004;12(1):25-33. [Rec#: 4971] Exclude at abstract screening: Observational study. [pmid: 14579137].
McGraw S A, Dobihal E, Baggish R, Bradley E H. How can we improve care at the end of life in Connecticut? Recommendations from focus groups. Conn Med. 2002;66(11):655-64. [Rec#: 13584] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12476507].
McGrew D M. Chronic illnesses and the end of life. Prim Care. 2001;28(2):339-47. [Rec#: 4984] Exclude at abstract screening: useful only for background. [pmid: 11406439].
McIntyre M R. Understanding living with dying. Can Nurse 97;93(1):19–25. Comment in: Can Nurse. Jan. 1997;93(1):3. PMID: 9095766 [Rec#: 4991] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
McKeogh M. Dementia in HIV disease--a challenge for palliative care?. Journal of Palliative Care. 95;11(2):30-3. [Rec#: 50603] Exclude at abstract screening: no outcomes specified. [pmid: 7541074].
McKinlay E M. Within the Circle of Care: patient experiences of receiving palliative care. J Palliat Care. 2001;17(1):22-9. [Rec#: 4999] Exclude at abstract screening: Observational study. [pmid: 11324180].
McKinlay J B, Crawford S L, Tennstedt S L. The everyday impacts of providing informal care to dependent elders and their consequences for the care recipients. J Aging Health. 95;7(4):497-528. [Rec#: 42210] Exclude at abstract screening: not about end of life.
McKinney A A, Deeny P. Leaving the intensive care unit: a phenomenological study of the patients' experience. Intensive Crit Care Nurs. 2002;18(6):320-31. [Rec#: 42213] Exclude at abstract screening: not about end of life. [pmid: 12526870].
McLauchlan C A. ABC of major trauma. Handling distressed relatives and breaking bad news. BMJ. 90;301(6761):1145-9. [Rec#: 13603] Exclude at abstract screening: Title Only. [pmid: 2252928].
McLoughlin P A. Community specialist palliative care: experiences of patients and carers. Int J Palliat Nurs. 2002;8(7):344-53. [Rec#: 13610] Exclude at abstract screening: not about end of life. [pmid: 12165720].
McMillan A, Mentnech R M, Lubitz J, McBean A M, Russell D. Trends and patterns in place of death for Medicare enrollees. Health Care Financ Rev. 90;12(1):1-7. [Rec#: 42218] Exclude at abstract screening: no outcomes specified.
McMillan M, Armitage D. Community palliative care in australia. Nurs Health Sci. 2002;4(3 Suppl):A7. [Rec#: 5012] Exclude at abstract screening: useful only for background.
McMillan S C, Mahon M. Measuring quality of life in hospice patients using a newly developed Hospice Quality of Life Index. Qual Life Res. 94;3(6):437-47. [Rec#: 5018] Exclude at abstract screening: Study Design - Qualitative.
McMillan S C, Tittle M. A descriptive study of the management of pain and pain-related side effects in a cancer center and a hospice. Hosp J. 95;10(1):89-107. [Rec#: 5022] Exclude at abstract screening: Observational study.
McMillan S C, Weitzner M A. Methodologic issues in collecting data from debilitated patients with cancer near the end of life. Oncol Nurs Forum. 2003;30(1):123-9. [Rec#: 13613] Exclude at abstract screening: useful only for background. [pmid: 12515990].
McMillan S C. Quality-of-Life Assessment in Palliative Care. Cancer Control. 96;3(3):223-229. [Rec#: 5014] Exclude at abstract screening: Study Design - Unclear. [pmid: 10765213].
McMurdo M E, Rennie L. A controlled trial of exercise by residents of old people's homes. Age Ageing. 93;22(1):11-5. [Rec#: 42219] Exclude at abstract screening: Other topic only. [pmid: 8438659].
McNamara B, Martin K, Waddell C, Yuen K. Palliative care in a multicultural society: perceptions of health care professionals. Palliat Med. 97;11(5):359-67. [Rec#: 5026] Exclude at abstract screening: Study Design - Unclear.
McNamara B, Waddell C, Colvin M. The institutionalization of the good death. Soc Sci Med. 94;39(11):1501-8. [Rec#: 13616] Exclude at abstract screening: Study Design - Qualitative. [pmid: 7529433].
McNamara N. Nursing the families of critically ill patients. Nurs N Z. 2002;8(7):20. [Rec#: 13617] Exclude at abstract screening: no outcomes specified. [pmid: 12374093].
McNamee P, Gregson B A, Buck D, Bamford C H, Bond J, Wright K. Costs of formal care for frail older people in England: the resource implications study of the MRC cognitive function and ageing study (RIS MRC CFAS). Soc Sci Med. 99;48(3):331-41. [Rec#: 42220] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
McNamee P, Gregson B A, Wright K, Buck D, Bamford C H, Bond J. Estimation of a multiproduct cost function for physically frail older people. Health Econ. 98;7(8):701-10. [Rec#: 42221] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
McNeely P D, Hebert P C, Dales R E, O'Connor A M, Wells G, McKim D, Sullivan K E. Deciding about mechanical ventilation in end-stage chronic obstructive pulmonary disease: how respirologists perceive their role. CMAJ. 97;156(2):177-83. [Rec#: 5033] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
McNeil DG. Racial differences are found in use of feeding tubes. NY Times (Print) 2003;A21. [Rec#: 5034] Exclude at abstract screening: Title Only
McPhee S J, Markowitz A J. Psychological considerations, growth, and transcendence at the end of life: the art of the possible. JAMA. 2001;286(23):3002. [Rec#: 13628] Exclude at abstract screening: Title Only. [pmid: 11743842].
McPherson C J, Addington-Hall J M. Judging the quality of care at the end of life: can proxies provide reliable information?. Soc Sci Med. 2003;56(1):95-109. [Rec#: 13630] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 12435554].
McPherson C J, Higginson I J, Hearn J. Effective methods of giving information in cancer: a systematic literature review of randomized controlled trials. J Public Health Med. 2001;23(3):227-34. [Rec#: 50141] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 11585196].
McPherson C J, Higginson I J, Hearn J. Effective methods of giving information in cancer: a systematic literature review of randomized controlled trials. Journal of Public Health Medicine. 2001;23(3):227-34. [Rec#: 50604] Exclude at abstract screening: not about end of life. [pmid: 11585196].
McQuay J E, Schwartz R, Goldblatt P C, Giangrasso V M. “Death-telling” research project. Crit Care Nurs Clin North Am. 95;7(3):549-55. [Rec#: 42227] Exclude at abstract screening: no outcomes specified. [pmid: 7546520].
McQuay J E. Support of families who had a loved one suffer a sudden injury, illness, or death. Crit Care Nurs Clin North Am. 95;7(3):541-7. [Rec#: 42226] Exclude at abstract screening: sudden/violent/non-chronic deaths.
McQuay, H. J., Moore, R. A., Eccleston, C., Morley, S., and Williams, A. C. Systematic review of outpatient services for chronic pain control. Health Technol Assess 97;1(6):i-iv, 1–135. [Rec#: 50143] Exclude at abstract screening: not about end of life
McQuay H, Carroll D, Jadad A R, Wiffen P, Moore A. Anticonvulsant drugs for management of pain: a systematic review. BMJ. 95;311(7012):1047-52. [Rec#: 50142] Exclude at abstract screening: Study Design - Review/Meta.
McQueen M J, Walsh L. The use of painkillers at the end of life. Linacre Q. 99;66(4):73-8. [Rec#: 13633] Exclude at abstract screening: Title Only. [pmid: 12199281].
McSkimming S, Myrick M, and Wasinger M. Organizational assessment of end-of-life care. Health Prog 2000;81(1):49–53, 58. [Rec#: 5039] Exclude at abstract screening: useful only for background
McVie J G. Chemotherapy for advanced disease. How to raise enthusiasm. Chest. 96;109(5 Suppl):80S-82S. [Rec#: 33664] Exclude at abstract screening: not about end of life. [pmid: 8635393].
McWhan K. Caring for dying patients in acute hospital wards: a review. Nurs Pract. 91;5(1):25-8. [Rec#: 13641] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 1762649].
McWhinney I R, Stewart M A. Home care of dying patients. Family physicians' experience with a palliative care support team. Can Fam Physician. 94;40:240-6. [Rec#: 13643] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Meares C J. Nutritional issues in palliative care. Semin Oncol Nurs. 2000;16(2):135-45. [Rec#: 13649] Exclude at abstract screening: no outcomes specified. [pmid: 10842783].
Meares C J. Primary caregiver perceptions of intake cessation in patients who are terminally Ill. Oncol Nurs Forum. 97;24(10):1751-7. [Rec#: 42229] Exclude at abstract screening: Study Design - Qualitative.
Meares C J. Terminal dehydration: a review. Am J Hosp Palliat Care. 94;11(3):10-4. [Rec#: 13650] Exclude at abstract screening: Non-systematic review. [pmid: 7893550].
Medicare hospice benefit. J Miss State Med Assoc 2000;41(1):457–8. [Rec#: 5047] Exclude at abstract screening: no outcomes specified
Medley L, Cullen M. Best supportive care versus palliative chemotherapy in nonsmall-cell lung cancer. Curr Opin Oncol. 2002;14(4):384-8. [Rec#: 5051] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 12130920].
Meehan T, Robertson S, Vermeer C. The impact of relocation on elderly patients with mental illness. Aust N Z J Ment Health Nurs. 2001;10(4):236-42. [Rec#: 42233] Exclude at abstract screening: not about end of life. [pmid: 11703274].
Meehan T, Robertson S, Vermeer C. The impact of relocation on elderly patients with mental illness. Aust N Z J Ment Health Nurs. 2001;10(4):236-42. [Rec#: 50075] Exclude at abstract screening: Duplicate already in the flow. [pmid: 11703274].
Meeker M A. Family surrogate decision making at the end of life: seeing them through with care and respect. Qual Health Res. 2004;14(2):204-25. [Rec#: 13662] Exclude at abstract screening: Study Design - Qualitative. [pmid: 14768458].
Meeres C, McKenna F. Dying with dignity. Nurs Times. 2001;97(33):36-7. [Rec#: 13664] Exclude at abstract screening: Title Only. [pmid: 11957625].
Meghani S H. A concept analysis of palliative care in the United States. J Adv Nurs. 2004;46(2):152-61. [Rec#: 5054] Exclude at abstract screening: useful only for background. [pmid: 15056328].
Mehr D R, Williams B C, Fries B E. Predicting discharge outcomes of VA nursing home residents. J Aging Health. 97;9(2):244-65. [Rec#: 42234] Exclude at abstract screening: primarily prognosis or trajectories.
Mehra M R, Uber P A. The dilemma of late-stage heart failure Rationale for chronic parenteral inotropic support. Cardiol Clin. 2001;19(4):627-36. [Rec#: 13666] Exclude at abstract screening: no outcomes specified. [pmid: 11715183].
Mehta A, Ezer H. My love is hurting: the meaning spouses attribute to their loved ones' pain during palliative care. J Palliat Care. 2003;19(2):87-94. [Rec#: 5056] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12955924].
Mehta K M, Yaffe K, Covinsky K E. Cognitive impairment, depressive symptoms, and functional decline in older people. J Am Geriatr Soc. 2002;50(6):1045-50. [Rec#: 42236] In abstract review process. [pmid: 12110064].
Mehta NJ, Khan IA, Mehta RN, Tejani F, Vasavada BC, and Sacchi TJ. End-of-life care-related publications in cardiology journals. Am J Cardiol 2001;88(12):1460–3, A9. [Rec#: 13667] Exclude at abstract screening: Title Only
Meier D E, Ahronheim J C, Morris J, Baskin-Lyons S, Morrison R S. High short-term mortality in hospitalized patients with advanced dementia: lack of benefit of tube feeding. Arch Intern Med 2001;161(4):594–9. Comment in: Arch Intern Med. Oct 22. 2001;161(19):2385-6. PMID: 11606159 [Rec#: 33683] Exclude at abstract screening: primarily prognosis or trajectories.
Meier D E, Back A L, Morrison R S. The inner life of physicians and care of the seriously ill. JAMA 2001;286(23):3007–14. Comment in: JAMA. 2002 Mar 6;287(9):1113–4. PMID: 11879103. Comment in: JAMA. 2002 Mar 6;287(9):1114. PMID: 11879104. Comment in: JAMA. Mar 6. 2002;287(9):1114. PMID: 11879105. [Rec#: 42241] Exclude at abstract screening: not about end of life.
Meier D E, Thar W, Jordan A, Goldhirsch S L, Siu A, Morrison R S. Integrating case management and palliative care. J Palliat Med. 2004;7(1):119-34. [Rec#: 5058] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 15000796].
Meier D E. Palliative care programs: what, why, and how?. Physician Exec. 2001;27(6):43-7. [Rec#: 13670] Exclude at abstract screening: no outcomes specified. [pmid: 11769165].
Meijer A, Van Campen C, Kerkstra A. A comparative study of the financing, provision and quality of care in nursing homes. The approach of four European countries: Belgium Denmark Germany and the Netherlands. J Adv Nurs. 2000;32(3):554-61. [Rec#: 42242] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11012796].
Mejhert M, Persson H, Edner M, Kahan T. Epidemiology of heart failure in Sweden--a national survey. Eur J Heart Fail. 2001;3(1):97-103. [Rec#: 50076] Exclude at abstract screening: Title Only. [pmid: 11163742].
Melin A L, Bygren L O. Perceived functional health of frail elderly in a primary home care programme and correlation of self-perception with objective measurements. Scand J Soc Med. 93;21(4):256-63. [Rec#: 42250] Exclude at abstract screening: not about end of life.
Melin A L. A randomized trial of multidisciplinary in-home care for frail elderly patients awaiting hospital discharge. Aging (Milano). 95;7(3):247-50. [Rec#: 42248] Exclude at abstract screening: Title Only. [pmid: 8547388].
Mellish V J. Counselling and support in intensive care. Nurs Crit Care. 96;1(3):116-9. [Rec#: 42251] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 9594098].
Mello M, Jenkinson C. Comparison of medical and nursing attitudes to resuscitation and patient autonomy between a British and an American teaching hospital. Soc Sci Med. 98;46(3):415-24. [Rec#: 42252] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Melmed G Y, Kwan L, Reid K, Litwin M S. Quality of life at the end of life: trends in patients with metastatic prostate cancer. Urology. 2002;59(1):103-9. [Rec#: 5067] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 11796290].
Melville A, Eastwood A. Management of lung cancer. Qual Health Care. 98;7(3):170-7. [Rec#: 13682] Exclude at abstract screening: useful only for background. [pmid: 10185145].
Melville A, Eastwood A, Turner-Boutle M. On the evidence. Lung cancer. Health Serv J. 98;108(5610):30-1. [Rec#: 13683] Exclude at abstract screening: useful only for background. [pmid: 10180430].
Melvin T A. The primary care physician and palliative care. Prim Care. 2001;28(2):239-49. [Rec#: 5069] Exclude at abstract screening: no outcomes specified. [pmid: 11406433].
Melzer D, Guralnik J M, Brock D. Prevalence and distribution of hip and knee joint replacements and hip implants in older Americans by the end of life. Aging Clin Exp Res. 2003;15(1):60-6. [Rec#: 5071] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 12841420].
Mendonca J D, Velamoor V R, Sauve D. Key features of maltreatment of the infirm elderly in home settings. Can J Psychiatry. 96;41(2):107-13. [Rec#: 42258] Exclude at abstract screening: not about end of life.
Mennecier B, Lebitasy M P, Moreau L, Hedelin G, Purohit A, Galichet C, Quoix E. Women and small cell lung cancer: social characteristics, medical history, management and survival: a retrospective study of all the male and female cases diagnosed in Bas-Rhin (Eastern France) between 1981 and 1994. Lung Cancer. 2003;42(2):141-52. [Rec#: 33694] Exclude at abstract screening: not about end of life. [pmid: 14568681].
Menzel L K. Is it worth it? Balancing the benefit of extended life with the cost of suffering during critical illness. Crit Care Nurse. 98;18(4):67-73. [Rec#: 5077] Exclude at abstract screening: Title Only. [pmid: 9814189].
Mercadante S, Simonetti M T. Dobutamine as palliative drug in home-care advanced cancer patients. J Pain Symptom Manage. 94;9(7):480-3. [Rec#: 5101] Exclude at abstract screening: no outcomes specified.
Mercadante S, Fulfaro F, Casuccio A. Pattern of drug use by advanced cancer patients followed at home. J Palliat Care. 2001;17(1):37-40. [Rec#: 5091] Exclude at abstract screening: Other topic only. [pmid: 11324183].
Mercadante S, Fusco F, Valle A, Fulfaro F, Casuccio A, Silvestro S, Donelli E. Factors involved in gastrointestinal bleeding in advanced cancer patients followed at home. Support Care Cancer. 2004;12(2):95-8. [Rec#: 5095] Exclude at abstract screening: Other topic only. [pmid: 14673626].
Mercadante S. Nutrition in cancer patients. Support Care Cancer 96;4(1):10–20. Comment in: Support Care Cancer. Jan. 1996;4(1):1-3. PMID: 8771286. [Rec#: 13692] Exclude at abstract screening: useful only for background.
Mercadante S. Pain treatment and outcomes for patients with advanced cancer who receive follow-up care at home. Cancer 99;85(8):1849–58. Comment in: Cancer. 1999 Apr 15;85(8):1645–8, iii. PMID: 10223555. [Rec#: 5080] Exclude at abstract screening: Title Only
Mercadante S, Casuccio A, Fulfaro F. The couse of symptom frequency and intensity in advanced cancer patients followed at home. Journal of Pain & Symptom Management. 2000;20:104-112. [Rec#: 50605] Exclude at abstract screening: no outcomes specified. [pmid: 10989248].
Mercadante S, Radbruch L, Caraceni A, Cherny N, Kaasa S, Nauck F, Ripamonti C, De Conno F. Steering Committee of the European Association for Palliative Care Research Network. Episodic (breakthrough) pain: consensus conference of an expert working group of the European Association for Palliative Care. Cancer. 2002;94(3):832-9. [Rec#: 50606] Exclude at abstract screening: no outcomes specified. [pmid: 11857319].
Merimsky O, Kollender Y, Inbar M, Lev-Chelouche D, Gutman M, Issakov J, Mazeh D, Shabat S, Bickels J, Meller I. Is forequarter amputation justified for palliation of intractable cancer symptoms?. Oncology. 2001;60(1):55-9. [Rec#: 5103] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 11150909].
Mermann A C. Spiritual aspects of death and dying. Yale J Biol Med. 92;65(2):137-42. [Rec#: 13700] Exclude at abstract screening: useful only for background. [pmid: 1519377].
Mernick M. Caring for the medically frail patient at home: a commentary. Pride Inst J Long Term Home Health Care. 91;10(4):2-4. [Rec#: 5107] Exclude at abstract screening: Title Only. [pmid: 10117654].
Merrill J M, Hill C S, Laux L M, Lorimor R I, Thornby J I, Thorpe D, Weinstein S M. Measuring medical students' reluctance to prescribe opioids for cancer pain. Psychol Rep. 99;84(1):28-30. [Rec#: 42263] Exclude at abstract screening: not about end of life.
Merrill J M, Lorimor R J, Thornby J I, Woods A, Vallbona C. Self-esteem and caregivers' attitudes toward elderly persons. Psychol Rep. 96;79(3 Pt 2):1349-50. [Rec#: 42264] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Meskenas S, Daniels M J, Moore C. Comfort care path strengthens support for terminally ill. Hosp Case Manag. 95;3(9):139-42. [Rec#: 13709] Exclude at abstract screening: Title Only. [pmid: 10153583].
Messecar D C, Archbold P G, Stewart B J, Kirschling J. Home environmental modification strategies used by caregivers of elders. Res Nurs Health. 2002;25(5):357-70. [Rec#: 42266] Exclude at abstract screening: not about end of life. [pmid: 12221690].
Messenger T, Roberts K T. The terminally ill: serenity nursing interventions for hospice clients. J Gerontol Nurs. 94;20(11):17-22. [Rec#: 5115] Exclude at abstract screening: Study Design - Unclear. [pmid: 7995899].
Meuser T M, Marwit S J. A comprehensive, stage-sensitive model of grief in dementia caregiving. Gerontologist. 2001;41(5):658-70. [Rec#: 5120] Exclude at abstract screening: Bereavement only. [pmid: 11574711].
Meyer C. Coming to new terms with death. Am J Nurs 92;92(8):19–20. Comment in: Am J Nurs. 1992 Dec;92(12):16. PMID: 1456310. Comment in: Am J Nurs. 1992 Nov;92(11):16. PMID: 1485621. Comment in: Am J Nurs. 1992 Nov;92(11):16. PMID: 1485620. Comment in: Am J Nurs. Nov. 1992;92(11):18. PMID: 1485622. [Rec#: 13715] Exclude at abstract screening: Title Only.
Meyer K, Laederach-Hofmann K. Effects of a comprehensive rehabilitation program on quality of life in patients with chronic heart failure. Prog Cardiovasc Nurs. 2003;18(4):169-76. [Rec#: 33724] Exclude at abstract screening: Other topic only. [pmid: 14605517].
Meyer K, Samek L, Schwaibold M, Westbrook S, Hajric R, Beneke R, Lehmann M, Roskamm H. Interval training in patients with severe chronic heart failure: analysis and recommendations for exercise procedures. Med Sci Sports Exerc. 97;29(3):306-12. [Rec#: 33725] Exclude at abstract screening: not about end of life.
Meyer K, Samek L, Schwaibold M, Westbrook S, Hajric R, Lehmann M, Essfeld D, Roskamm H. Physical responses to different modes of interval exercise in patients with chronic heart failure--application to exercise training. Eur Heart J. 96;17(7):1040-7. [Rec#: 33726] Exclude at abstract screening: not about end of life.
Meyer R M. Using adult learning concepts to assist patients in completing advance directives. J Contin Educ Nurs. 2000;31(4):174-8. [Rec#: 5125] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11261162].
Meyer R W. Measuring quality of care at the end of life: who? when? where? and how?. West J Med. 2000;172(6):377-8. [Rec#: 13720] Exclude at abstract screening: no outcomes specified. [pmid: 10854382]. [pmcid: 1070921].
Meyers F J, Linder J. Simultaneous care: disease treatment and palliative care throughout illness. J Clin Oncol 2003;21(7):1412–5. Comment in: J Clin Oncol. Dec 1. 2003;21(23):4463. PMID: 14645442. [Rec#: 5127] Exclude at abstract screening: Title Only.
Meystre C J, Burley N M, Ahmedzai S. What investigations and procedures do patients in hospices want? Interview based survey of patients and their nurses. BMJ 97;315(7117):1202–3. Comment in: BMJ. 1998 Apr 11;316(7138):1166–7. PMID: 9569421. Comment in: BMJ. 1998 Apr 11;316(7138):1166; author reply 1167–8. PMID: 9569420. Comment in: BMJ. 1998 Apr 11;316(7138):1167. PMID: 9569422. Comment in: BMJ. Apr 11. 1998;316(7138):1167. [Rec#: 5131] Exclude at abstract screening: Title Only.
Mezey M, Bottrell M M, Ramsey G. Advance directives protocol: nurses helping to protect patient's rights. The NICHE faculty. Geriatr Nurs. 96;17(5):204-9. quiz 210. [Rec#: 5132] Exclude at abstract screening: useful only for background.
Mezey M D, Mitty E L, Bottrell M M, Ramsey G C, Fisher T. Advance directives: older adults with dementia. Clin Geriatr Med. 2000;16(2):255-68. [Rec#: 5134] Exclude at abstract screening: useful only for background. [pmid: 10783428].
Michel J P, Pautex S, Zekry D, Zulian G, Gold G. End-of-life care of persons with dementia. J Gerontol A Biol Sci Med Sci. 2002;57(10):M640-4. [Rec#: 5142] Exclude at abstract screening: no outcomes specified. [pmid: 12242316].
Mick D J, Ackerman M H. New perspectives on advanced practice nursing case management for aging patients. Crit Care Nurs Clin North Am. 2002;14(3):281-91. [Rec#: 42280] Exclude at abstract screening: not about end of life. [pmid: 12168708].
Mickley J R, Pargament K I, Brant C R, Hipp K M. God and the search for meaning among hospice caregivers. Hosp J. 98;13(4):1-17. [Rec#: 5147] Exclude at abstract screening: Other topic only. [pmid: 9883124].
Middel B, Bouma J, de Jongste M, van Sonderen E, Niemeijer M G, Crijns H, van den Heuvel W. Psychometric properties of the Minnesota Living with Heart Failure Questionnaire (MLHF-Q). Clin Rehabil. 2001;15(5):489-500. [Rec#: 33740] Exclude at abstract screening: not about end of life. [pmid: 11594639].
Middleton W, Burnett P, Raphael B, Martinek N. The bereavement response: a cluster analysis. Br J Psychiatry. 96;169(2):167-71. [Rec#: 5149] Exclude at abstract screening: Bereavement only. [pmid: 8871792].
Middleton W, Moylan A, Raphael B, Burnett P, Martinek N. An international perspective on bereavement related concepts. Aust N Z J Psychiatry. 93;27(3):457-63. [Rec#: 5150] Exclude at abstract screening: no outcomes specified.
Middleton W, Raphael B, Burnett P, Martinek N. A longitudinal study comparing bereavement phenomena in recently bereaved spouses, adult children and parents. Aust N Z J Psychiatry. 98;32(2):235-41. [Rec#: 5151] Exclude at abstract screening: Study Design - Qualitative.
Middleton W, Raphael B, Burnett P, Martinek N. Psychological distress and bereavement. J Nerv Ment Dis. 97;185(7):447-53. [Rec#: 5152] Exclude at abstract screening: Bereavement only. [pmid: 9240363].
Miedema F. Withdrawing treatment from the hopelessly ill. Part 1: The ethical case. Dimens Crit Care Nurs. 93;12(1):40-5. [Rec#: 5154] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Mielke J, Martin D K, Singer P A. Priority setting in a hospital critical care unit: qualitative case study. Crit Care Med 2003;31(12):2764–8. Comment in: Crit Care Med. Dec. 2003;31(12):2809-11. PMID: 14668623. [Rec#: 42282] Exclude at abstract screening: not about end of life.
Milch R A, Dunn G P. Communication: part of the surgical armamentarium. J Am Coll Surg. 2001;193(4):449-51. [Rec#: 13735] Exclude at abstract screening: Title Only. [pmid: 11584973].
Milch R A, Schumacher J D. The future of hospice. West J Med. 99;171(4):224. [Rec#: 5161] Exclude at abstract screening: Title Only. [pmid: 10578670].
Milch R A. The dying patient: pain management at the hospice level. Curr Rev Pain. 2000;4(3):215-8. [Rec#: 5160] Exclude at abstract screening: no outcomes specified. [pmid: 10998736].
Milch R A. The surgeon-patient relationship in advanced illness. Surg Oncol Clin N Am. 2001;10(1):25-30. [Rec#: 13734] Exclude at abstract screening: useful only for background. [pmid: 11406448].
Miles A. Caring for the family left behind. Am J Nurs. 93;93(12):34-6. [Rec#: 13736] Exclude at abstract screening: Title Only. [pmid: 8304379].
Miles S H, Koepp R, Weber E P. Advance end-of-life treatment planning. A research review. Arch Intern Med. 96;156(10):1062-8. [Rec#: 13737] Exclude at abstract screening: useful only for background. [pmid: 8638992].
Miles S H, Weber E P, Koepp R. End-of-life treatment in managed care. The potential and the peril. West J Med. 95;163(3):302-5. [Rec#: 13738] Exclude at abstract screening: Title Only. [pmid: 7571596].
Millar B. Palliative care for people with non-malignant diseases. Nurs Times. 98;94(48):52-3. [Rec#: 13739] Exclude at abstract screening: no outcomes specified. [pmid: 9934177].
Miller B, Furner S E. Change in the number of informal helpers of frail older persons. Public Health Rep. 94;109(4):583-6. [Rec#: 42288] Exclude at abstract screening: not about end of life. [pmid: 8041861].
Miller D K, Coe R M, Hyers T M. Achieving consensus on withdrawing or withholding care for critically ill patients. J Gen Intern Med 92;7(5):475–80. Comment in: J Gen Intern Med. 1992 Sep-Oct;7(5):563–5. PMID: 1403216. Comment in: J Gen Intern Med. Mar. 1993;8(3):169. PMID: 8455118. [Rec#: 42290] Exclude at abstract screening: Observational study.
Miller D K, Morrison M J, Blair S D, Miller J P, Morley J E. Predilection for frailty remedial strategies among black and white seniors. South Med J. 98;91(4):375-80. [Rec#: 42291] Exclude at abstract screening: not about end of life.
Miller D L, Bolla L R. Patient values: the guide to medical decision making. Clin Geriatr Med. 98;14(4):813-29. [Rec#: 5169] Exclude at abstract screening: no outcomes specified. [pmid: 9799481].
Miller D L, Gorbien M J, Simbartl L A, Jahnigen D W. Factors influencing physicians in recommending in-hospital cardiopulmonary resuscitation. Arch Intern Med. 93;153(17):1999-2003. [Rec#: 42292] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Miller D L, Jahnigen D W, Gorbien M J, Simbartl L. Cardiopulmonary resuscitation: how useful? Attitudes and knowledge of an elderly population. Arch Intern Med. 92;152(3):578-82. [Rec#: 42293] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Miller F G, Fins J J. A proposal to restructure hospital care for dying patients. N Engl J Med 96;334(26):1740–2. Comment in: N Engl J Med. 1996 Dec 5;335(23):1765–6; author reply 1767. PMID: 8965878. Comment in: N Engl J Med. 1996 Dec 5;335(23):1765; author reply 1767. PMID: 8965877. Comment in: N Engl J Med. Dec 5. 1996;335(23):1766. author reply 1767. PMID. [Rec#: 13753] Exclude at abstract screening: Title Only.
Miller KE, Miller MM, and Jolley MR. Challenges in pain management at the end of life. Am Fam Physician 2001;64(7):1227–34. Comment in: Am Fam Physician. 2001 Oct 1;64(7):1154, 1156, 1158, 1160. PMID: 11601799. [Rec#: 13758] Exclude at abstract screening: outcome unrelated to pts/family/non-prof
Miller K E, Miller M M, Single N. Barriers to hospice care: family physicians' perceptions. Hosp J. 97;12(4):29-41. [Rec#: 5173] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 9305023].
Miller L L, Hornbrook M C, Archbold P G, Stewart B J. Development of use and cost measures in a nursing intervention for family caregivers and frail elderly patients. Res Nurs Health. 96;19(4):273-85. [Rec#: 42295] Exclude at abstract screening: Observational study.
Miller L L, Nelson L L, Mezey M. Comfort and pain relief in dementia: awakening a new beneficence. J Gerontol Nurs. 2000;26(9):32-40. quiz 55–6. [Rec#: 33761] Exclude at abstract screening: Title Only. [pmid: 11883612].
Miller P A, Forbes S, Boyle D K. End-of-life care in the intensive care unit: a challenge for nurses. Am J Crit Care 2001;10(4):230–7. Comment in: Am J Crit Care. Sep. 2001;10(5):369. PMID: 11548574. [Rec#: 5174] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Miller R D, Walsh T D. Psychosocial aspects of palliative care in advanced cancer. J Pain Symptom Manage. 91;6(1):24-9. [Rec#: 5176] Exclude at abstract screening: Other topic only. [pmid: 1703198].
Miller S C, Mor V N. The role of hospice care in the nursing home setting. J Palliat Med. 2002;5(2):271-7. [Rec#: 5183] Exclude at abstract screening: useful only for background. [pmid: 12006229].
Miller S C, Gozalo P, Mor V. Hospice enrollment and hospitalization of dying nursing home patients. Am J Med. 2001;111(1):38-44. [Rec#: 5178] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11448659].
Miller SC, Gozalo P, Mor V. Outcomes and Utilization for Hospice and Non-Hospice Nursing Facility Decedents. 2000;10 January 2004:<25 Page(s)>. [Rec#: 50611] Exclude at abstract screening: Title Only
Miller S C, Kinzbrunner B, Pettit P, Williams J R. How does the timing of hospice referral influence hospice care in the last days of life?. J Am Geriatr Soc. 2003;51(6):798-806. [Rec#: 5179] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12757566].
Miller S C, Weitzen S, Kinzbrunner B. Factors associated with the high prevalence of short hospice stays. J Palliat Med. 2003;6(5):725-36. [Rec#: 5184] Exclude at abstract screening: Other topic only. [pmid: 14622452].
Miller M, Boyer M J, Butow P N, Gattellari M, Dunn S M, Childs A. The use of unproven methods of treatment by cancer patients. Frequency, expectations and cost. Supportive Care in Cancer. 98;6(4):337-47. [Rec#: 50609] Exclude at abstract screening: not about end of life.
Miller P J, Hedlund S C, Murphy K A. Social work assessment at end of life: practice guidelines for suicide and the terminally ill. Social Work in Health Care. 98;26(4):23-36. [Rec#: 50610] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Millichap D, Oliver C, McQuillan S, Kalsy S, Lloyd V, Hall S. Descriptive functional analysis of behavioral excesses shown by adults with Down syndrome and dementia. Int J Geriatr Psychiatry. 2003;18(9):844-54. [Rec#: 33766] Exclude at abstract screening: Observational study. [pmid: 12949853].
Milligan M, Fanning M, Hunter S, Tadjali M, Stevens E. Reflexology audit: patient satisfaction, impact on quality of life and availability in Scottish hospices. Int J Palliat Nurs. 2002;8(10):489-96. [Rec#: 5187] Exclude at abstract screening: Observational study. [pmid: 12419988].
Milligan S, McGill M, Sweeney M P, Malarkey C. Oral care for people with advanced cancer: an evidence-based protocol. Int J Palliat Nurs. 2001;7(9):418-26. [Rec#: 5188] Exclude at abstract screening: useful only for background. [pmid: 11832845].
Millison M, Dudley J R. Providing spiritual support: a job for all hospice professionals. Hosp J. 92;8(4):49-66. [Rec#: 5190] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 1302747].
Millison M B, Dudley J R. The importance of spirituality in hospice work: a study of hospice professionals. Hosp J. 90;6(3):63-78. [Rec#: 5191] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Miranda A F, Miranda S. Quality of life and longterm survival after intensive care discharge. Med J Malaysia. 91;46(1):66-71. [Rec#: 42298] Exclude at abstract screening: primarily prognosis or trajectories.
Miranda D R, de Rijk A, Schaufeli W. Simplified Therapeutic Intervention Scoring System: the TISS-28 items--results from a multicenter study. Crit Care Med. 96;24(1):64-73. [Rec#: 42299] Exclude at abstract screening: not about end of life.
Mirka T. The pain of suffering. Can J Cardiovasc Nurs. 96;7(1):15-8. [Rec#: 5206] Exclude at abstract screening: Title Only. [pmid: 8900815].
Mirotznik J. Responses of noninterviewable long-term care patients before and after interinstitutional relocation. Psychol Rep. 95;76(3 Pt 2):1267-80. [Rec#: 50078] Exclude at abstract screening: Title Only. [pmid: 7480496].
Mirowsky J, Ross C E. Age and depression. J Health Soc Behav. 92;33(3):187-205. discussion 206–12. [Rec#: 42300] Exclude at abstract screening: not about end of life. [pmid: 1401846].
Misbin R, Miller D H. “Make me live”: autonomy and terminal illness. Hastings Cent Rep 90;20(5):42; discussion 42–4. Comment in: Hastings Cent Rep. Jan-Feb. 1992;22(1):45-6. PMID: 1544800. [Rec#: 5207] Exclude at abstract screening: useful only for background.
Mitchell D R. The ‘good’ death: three promises to make at the bedside. Geriatrics. 97;52(8):91-2. [Rec#: 13791] Exclude at abstract screening: Title Only. [pmid: 9261289].
Mitchell P, Koch T. An attempt to give nursing home residents a voice in the quality improvement process: the challenge of frailty. J Clin Nurs. 97;6(6):453-61. [Rec#: 42302] Exclude at abstract screening: not about end of life.
Mitchell S L. Financial incentives for placing feeding tubes in nursing home residents with advanced dementia. Journal of the American Geriatrics Society. 2003;51(1):129-31. [Rec#: 50612] Exclude at abstract screening: Title Only. [pmid: 12534858].
Mitty EL. Ethnicity and end-of-life decision-making. Reflect Nurs Leadersh 2001;27(1):28–31, 46. [Rec#: 13802] Exclude at abstract screening: Title Only
Miyaji N T. The power of compassion: truth-telling among American doctors in the care of dying patients. Soc Sci Med. 93;36(3):249-64. [Rec#: 5231] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Moeller RA. If doctors can't die with dignity, who can? Med Econ 93;70(17):30, 33–4, 36. [Rec#: 5241] Exclude at abstract screening: Title Only
Mohr D C, Moran P J, Kohn C, Hart S, Armstrong K, Dias R, Bergsland E, Folkman S. Couples therapy at end of life. Psychooncology. 2003;12(6):620-7. [Rec#: 5251] Exclude at abstract screening: Observational study. [pmid: 12923802].
Moinpour C M, Lyons B, Grevstad P K, Lovato L C, Crowley J, Czaplicki K, Buckner Z M, Ganz P A, Kelly K, Gandara D R. Quality of life in advanced non-small-cell lung cancer: results of a Southwest Oncology Group randomized trial. Qual Life Res. 2002;11(2):115-26. [Rec#: 33800] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 12018735].
Moinpour C M, Polissar L, Conrad D A. Factors associated with length of stay in hospice. Med Care. 90;28(4):363-8. [Rec#: 5252] Exclude at abstract screening: Title Only. [pmid: 2108287].
Moinpour CM. Do quality of life assessments make a difference in the evaluation of cancer treatments? Control Clin Trials 97;18(4):311–7. Comment on: Control Clin Trials. 1997 Aug;18(4):275–6. PMID: 9257065. Comment on: Control Clin Trials. 1997 Aug;18(4):277–85. PMID: 9257066. Comment on: Control Clin Trials. 1997 Aug;18(4):286–300. PMID: 9257067. Comment on: Control Clin Trials. 19. [Rec#: 13818] Exclude at abstract screening: no outcomes specified
Moinpour CM, Hayden KA, Thompson IM, Feigl P, Metch B. Quality of life assessment in Southwest Oncology Group trials. Oncology (Huntingt) 90;4(5):79–84, 89; discussion 104. [Rec#: 50877] Exclude at abstract screening: no outcomes specified
Mok E, Lee W M, Wong F K. The issue of death and dying: employing problem-based learning in nursing education. Nurse Educ Today. 2002;22(4):319-29. [Rec#: 42312] Exclude at abstract screening: no outcomes specified. [pmid: 12030753].
Molloy D W, Clarnette R M, Braun E A, Eisemann M R, Sneiderman B. Decision making in the incompetent elderly: “The Daughter from California syndrome”. J Am Geriatr Soc. 91;39(4):396-9. [Rec#: 5259] Exclude at abstract screening: Title Only.
Monahan D J, Greene V L, Coleman P D. Caregiver support groups: factors affecting use of services. Soc Work. 92;37(3):254-60. [Rec#: 42315] Exclude at abstract screening: not about end of life. [pmid: 1514134].
Monane M, Bohn R L, Gurwitz J H, Glynn R J, Avorn J. Noncompliance with congestive heart failure therapy in the elderly. Arch Intern Med 94;154(4):433–7. Comment in: Arch Intern Med. Sep 26. 1994;154(18):2109-10. PMID: 8092917. [Rec#: 33812] Exclude at abstract screening: Study Design - Unclear.
Monfardini S. Prescribing anti-cancer drugs in elderly cancer patients. Eur J Cancer. 2002;38(18):2341-6. [Rec#: 42316] Exclude at abstract screening: Title Only. [pmid: 12460777].
Monroe B. Role of the social worker in palliative care. Ann Acad Med Singapore. 94;23(2):252-5. [Rec#: 5264] Exclude at abstract screening: no outcomes specified. [pmid: 7521619].
Monsch A U, Bondi M W, Salmon D P, Butters N, Thal L J, Hansen L A, Wiederholt W C, Cahn D A, Klauber M R. Clinical validity of the Mattis Dementia Rating Scale in detecting Dementia of the Alzheimer type. A double cross-validation and application to a community-dwelling sample. Arch Neurol. 95;52(9):899-904. [Rec#: 33815] Exclude at abstract screening: not about end of life.
Montazeri A, Gillis C R, McEwen J. Quality of life in patients with lung cancer: a review of literature from 1970 to 1995. Chest. 98;113(2):467-81. [Rec#: 13826] Exclude at abstract screening: Study Design - Review/Meta.
Montazeri A, Milroy R, Gillis C R, McEwen J. Quality of life: perception of lung cancer patients. Eur J Cancer. 96;32A(13):2284-9. [Rec#: 33818] Exclude at abstract screening: Study Design - Qualitative. [pmid: 9038611].
Montazeri A, Milroy R, Hole D, McEwen J, Gillis C R. How quality of life data contribute to our understanding of cancer patients' experiences? A study of patients with lung cancer. Qual Life Res. 2003;12(2):157-66. [Rec#: 33820] Exclude at abstract screening: not about end of life. [pmid: 12639062].
Montazeri A, Milroy R, Hole D, McEwen J, Gillis C R. Quality of life in lung cancer patients: as an important prognostic factor. Lung Cancer. 2001;31(23):233-40. [Rec#: 33821] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 11165402].
Monteleoni C, Clark E. Using rapid-cycle quality improvement methodology to reduce feeding tubes in patients with advanced dementia: before and after study. BMJ. 2004;329(7464):491-4. [Rec#: 50912] In abstract review process. [pmid: 15331474]. [pmcid: 515202].
Montgomery C. Personal response systems in the United States. Home Health Care Serv Q. 92;13(34):201-22. [Rec#: 42321] Exclude at abstract screening: not about end of life. [pmid: 10126442].
Montgomery R J, Kosloski K. A longitudinal analysis of nursing home placement for dependent elders cared for by spouses vs adult children. J Gerontol. 94;49(2):S62-74. [Rec#: 42322] Exclude at abstract screening: not about end of life.
Monti M, Castellani L, Berlusconi A, Cunietti E. Use of red blood cell transfusions in terminally ill cancer patients admitted to a palliative care unit. J Pain Symptom Manage 96;12(1):18–22. Comment in: J Pain Symptom Manage. Jun. 1997;13(6):318. PMID: 9204650. [Rec#: 5273] Exclude at abstract screening: primarily prognosis or trajectories.
Moody L E, Webb M, Cheung R, Lowell J. A focus group for caregivers of hospice patients with severe dyspnea. Am J Hosp Palliat Care. 2004;21(2):121-30. [Rec#: 5278] Exclude at abstract screening: Study Design - Qualitative. [pmid: 15055512].
Moore B. Program profile: “I count too”--supporting the children of the terminally ill. Continuum. 96;16(5):18-20. [Rec#: 5281] Exclude at abstract screening: Title Only. [pmid: 10162595].
Moore C. Preparing for a final journey. Nursing. 98;28(7):80. [Rec#: 5282] Exclude at abstract screening: Title Only. [pmid: 9687685].
Moore I. Living with Alzheimer's: understanding the family's and patient's perspective. Geriatrics. 97;52(Suppl 2):S33-6. [Rec#: 13835] Exclude at abstract screening: useful only for background. [pmid: 9307584].
Moore R J, Chamberlain R M, Khuri F R. A voice that wraps around the body--communication problems in the advanced stages of non-small cell lung cancer. Yale J Biol Med. 2001;74(6):367-82. [Rec#: 33826] Exclude at abstract screening: not about end of life. [pmid: 11922184].
Moore S, Corner J, Haviland J, Wells M, Salmon E, Normand C, Brada M, O'Brien M, Smith I. Nurse led follow up and conventional medical follow up in management of patients with lung cancer: randomised trial. BMJ 2002;325(7373):1145. Erratum in: BMJ. Dec 14. 2002;325(7377):1386. [Rec#: 33827] Exclude at abstract screening: Study Design - Unclear.
Moore C, Wisnivesky J, Williams S, McGinn T. Medical errors related to discontinuity of care from an inpatieht to an outpatient setting. Journal of General Internal Medicine. 2003;18:646-651. [Rec#: 50617] Exclude at abstract screening: not about end of life. [pmid: 12911647]. [pmcid: 1494907].
Moorhead L C. Why we all should have living wills. Med Econ. 91;68(10):24-5. [Rec#: 5290] Exclude at abstract screening: Title Only. [pmid: 10110944].
Morasso G, Capelli M, Viterbori P, Di Leo S, Alberisio A, Costantini M, Fiore M, Saccani D, Zeitler G, Verzolatto N, Tirelli W, Lazzari L, Partinico M, Borzoni G, Savian C, Obertino E, Zotti P, Ivaldi G P, Henriquet F. Psychological and symptom distress in terminal cancer patients with met and unmet needs. J Pain Symptom Manage. 99;17(6):402-9. [Rec#: 5298] Exclude at abstract screening: Study Design - Qualitative.
Mor-Barak M E, Miller L S. A longitudinal study of the causal relationship between social networks and health of the poor frail elderly. J Appl Gerontol. 91;10(3):293-310. [Rec#: 42329] Exclude at abstract screening: not about end of life.
Mor-Barak M E. Major determinants of social networks in frail elderly community residents. Home Health Care Serv Q. 97;16(12):121-37. [Rec#: 42328] Exclude at abstract screening: not about end of life.
Morch M M, Timpka T, Granerus A K. Thirty years' experience with cancer and non-cancer patients in palliative home care. J Palliat Care. 99;15(3):43-8. [Rec#: 5300] Exclude at abstract screening: Title Only. [pmid: 10540797].
Moreau D, Goldgran-Toledano D, Alberti C, Jourdain M, Adrie C, Annane D, Garrouste-Orgeas M, Lefrant J Y, Papazian L, Quinio P, Pochard F, Azoulay E. Junior versus senior physicians for informing families of intensive care unit patients. Am J Respir Crit Care Med. 2004;169(4):512-7. [Rec#: 42333] Exclude at abstract screening: not about end of life. [pmid: 14656750].
Moreno R, Morais P. Validation of the simplified therapeutic intervention scoring system on an independent database. Intensive Care Med. 97;23(6):640-4. [Rec#: 42337] Exclude at abstract screening: not about end of life.
Moretti A. Food, water, and a patient's final days. Contemp Longterm Care. 95;18(11):67. [Rec#: 13849] Exclude at abstract screening: Title Only. [pmid: 10153599].
Morey W. A difficult death. Contemp Nurse. 96;5(1):26. [Rec#: 13850] Exclude at abstract screening: Title Only. [pmid: 8717004].
Morgan A K. A grounded theory of nurse-client interactions in palliative care nursing. J Clin Nurs. 2001;10(4):583-4. [Rec#: 13851] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11822506].
Morgan A K. Palliative home care in a rural setting: reflections on selective interactions. Aust J Rural Health. 97;5(1):22-5. [Rec#: 13852] Exclude at abstract screening: no outcomes specified. [pmid: 9437930].
Morgan D G, Stewart N J. The physical environment of special care units: needs of residents with dementia from the perspective of staff and family caregivers. Qual Health Res. 99;9(1):105-18. [Rec#: 33838] Exclude at abstract screening: not about end of life.
Morgan G. Assessment of quality of life in palliative care. Int J Palliat Nurs. 2000;6(8):406-10. [Rec#: 13853] Exclude at abstract screening: not about end of life. [pmid: 12411853].
Morgan J F, Killoughery M. Hospital doctors' management of psychological problems - Mayou & Smith revisited. Br J Psychiatry. 2003;182:153-7. [Rec#: 13854] Exclude at abstract screening: not about end of life. [pmid: 12562744].
Morgan R, King D. What investigations and procedures do patients in hospices want. Providing ineffective treatment is futile. BMJ. 98;316(7138):1166a. [Rec#: 5306] Exclude at abstract screening: Title Only. [pmid: 9569420].
Morgan S. Supportive and palliative care for patients with COPD. Nurs Times. 2003;99(20):46-7. [Rec#: 5308] Exclude at abstract screening: no outcomes specified. [pmid: 12800645].
Morgan W E. The surgical management of lung cancer. Br J Hosp Med. 96;55(10):631-4. [Rec#: 5309] Exclude at abstract screening: Title Only. [pmid: 8762123].
Morin S M, Welsh L A. Adolescents' perceptions and experiences of death and grieving. Adolescence. 96;31(123):585-95. [Rec#: 42339] Notes: “EXCLUDE: Age, not adults”. [pmid: 8874605].
Morita T, Ichiki T, Tsunoda J, Inoue S, Chihara S. A prospective study on the dying process in terminally ill cancer patients. Am J Hosp Palliat Care. 98;15(4):217-22. [Rec#: 5323] Exclude at abstract screening: primarily prognosis or trajectories.
Morita T, Tei Y, Shishido H, Inoue S. Treatable complications of cancer patients referred to an in-patient hospice. Am J Hosp Palliat Care. 2003;20(5):389-91. [Rec#: 5331] Notes: “EXCLUDE: Location, non-Western”. [pmid: 14529042].
Morita T, Tei Y, Tsunoda J, Inoue S, Chihara S. Determinants of the sensation of thirst in terminally ill cancer patients. Support Care Cancer 2001;9(3):177–86. Comment in: Support Care Cancer. May. 2001;9(3):139-40. PMID: 11401096. [Rec#: 5332] Exclude at abstract screening: Other symptoms only.
Morita T, Tsunoda J, Inoue S, Chihara S. Do hospice clinicians sedate patients intending to hasten death?. J Palliat Care. 99;15(3):20-3. [Rec#: 5336] Exclude at abstract screening: Title Only. [pmid: 10540794].
Morita T, Tsunoda J, Inoue S, Chihara S. Effects of high dose opioids and sedatives on survival in terminally ill cancer patients. J Pain Symptom Manage. 2001;21(4):282-9. [Rec#: 5337] Exclude at abstract screening: Other topic only. [pmid: 11312042].
Morita T, Tsunoda J, Inoue S, Chihara S. Risk factors for death rattle in terminally ill cancer patients: a prospective exploratory study. Palliat Med. 2000;14(1):19-23. [Rec#: 5341] Exclude at abstract screening: Other symptoms only. [pmid: 10717719].
Morita T, Tsunoda J, Inoue S, Chihara S. Terminal sedation for existential distress. Am J Hosp Palliat Care 2000;17(3):189–95. Comment in: Am J Hosp Palliat Care. May-Jun. 2000;17(3):148-9. PMID: 11886062. [Rec#: 5343] Notes: “EXCLUDE: Location, non-Western”.
Morita T. Differences in physician-reported practice in palliative sedation therapy. Support Care Cancer 2004. [Rec#: 5316] Exclude at abstract screening: outcome unrelated to pts/family/non-prof
Morita T, Ichiki T, Tsunoda J. A prospective study on the dying process in terminally ill cancer patients. American Journal of Hospice & Palliative Care. 98;15:217-222. [Rec#: 50618] Exclude at abstract screening: Title Only.
Morita, T., Ichiki, T., and Tsunoda, J. A prospective study on the dying process in terminally ill cancer patients followed at home. Journal of Pain & Symptom Management 98. [Rec#: 50619] Exclude at abstract screening: no outcomes specified
Morita T, Tsunoda J, Inoue S, Chihara S. Validity of the palliative performance scale from a survival perspective. Journal of Pain & Symptom Management. 99;18(1):2-3. [Rec#: 50620] Exclude at abstract screening: no outcomes specified.
Morize V, Salomon L, Nguyen D T, Rosenheim M, Desfosses G. Palliative care: are we talking about the same patients. Palliat Med. 2002;16(1):65-6. [Rec#: 5345] Exclude at abstract screening: useful only for background. [pmid: 11963455].
Morris R I, Christie K M. Initiating hospice care. Why, when, and how. Home Healthc Nurse. 95;13(5):21-6. quiz 27–9. [Rec#: 5348] Exclude at abstract screening: no outcomes specified. [pmid: 7591820].
Morris V. Talking about death won't kill you: the patient's perspective. Mo Med. 2003;100(1):87-90. [Rec#: 13874] Exclude at abstract screening: Title Only. [pmid: 12664711].
Morrison R S, Meier D E. Managed care at the end of life. Trends Health Care Law Ethics. 95-96;10(12):91-6. [Rec#: 5353] Exclude at abstract screening: useful only for background. [pmid: 7655244].
Morrison R S, Morris J. When there is no cure: palliative care for the dying patient. Geriatrics 95;50(7):45–51; quiz 52–3. Comment in: Geriatrics. Sep. 1995;50(9):12. PMID: 7545628. [Rec#: 5355] Exclude at abstract screening: no outcomes specified.
Morrison R S, Siu A L. Survival in end-stage dementia following acute illness. JAMA 2000;284(1):47–52. Comment in: JAMA. 2000 Jul 5;284(1):87–9. PMID: 10872019. Comment in: JAMA. 2000 Nov 15;284(19):2447–8. PMID: 11074770. Comment in: JAMA. 2000 Nov 15;284(19):2447; author reply 2448. PMID: 11074769. Comment in: JAMA. Nov 15. 2000;284(19):2447. autho. [Rec#: 5356] Exclude at abstract screening: primarily prognosis or trajectories.
Morrison R S, Meier D E, Cassel C K. Clinical problem-solving. When too much is too little. N Engl J Med 96;335(23):1755–9. Comment in: N Engl J Med. 1997 May 15;336(20):1458–9; author reply 1459. PMID: 9148158. Comment in: N Engl J Med. 1997 May 15;336(20):1458; author reply 1459. PMID: 9148157. Comment in: N Engl J Med. May 15. 1997;336(20):1459. PMID: 9148159. [Rec#: 5354] Exclude at abstract screening: Title Only.
Morrison R S, Siu A L, Leipzig R M, Cassel C K, Meier D E. The hard task of improving the quality of care at the end of life. Arch Intern Med. 2000;160(6):743-7. [Rec#: 13876] Exclude at abstract screening: Title Only. [pmid: 10737273].
Morrison RS. Planning and providing care at the end of life. Hosp Pract (Off Ed) 2000;35(10):61–4, 67–8. [Rec#: 13875] Exclude at abstract screening: Title Only
Morton R, Brown J. Clinical governance and palliative care: a question of synergy. Int J Palliat Nurs. 2000;6(1):43-5. [Rec#: 5365] Exclude at abstract screening: Title Only. [pmid: 12819569].
Morton R. Breaking bad news to patients with cancer. Prof Nurse. 96;11(10):669-71. [Rec#: 13883] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 8718375].
Moryl N, Santiago-Palma J, Kornick C, Derby S, Fischberg D, Payne R, Manfredi P L. Pitfalls of opioid rotation: substituting another opioid for methadone in patients with cancer pain. Pain. 2002;96(3):325-8. [Rec#: 50621] Exclude at abstract screening: Observational study. [pmid: 11973005].
Mosenthal A C, Lee K F. Management of dyspnea at the end of life: relief for patients and surgeons. J Am Coll Surg 2002;194(3):377–86. Comment in: J Am Coll Surg. Sep. 2002;195(3):436. author reply 437. PMID: 12229956. [Rec#: 5368] Exclude at abstract screening: useful only for background.
Mosenthal A C, Lee K F, Huffman J. Palliative care in the surgical intensive care unit. J Am Coll Surg. 2002;194(1):75-83. discussion 83–5. [Rec#: 5369] Exclude at abstract screening: useful only for background. [pmid: 11800342].
Moser D K, Mann D L. Improving outcomes in heart failure: It's not unusual beyond usual care. Circulation 2002;105(24):2810–2. Comment on: Circulation. Jun 18. 2002;105(24):2861-6. PMID: 12070114. [Rec#: 50079] Exclude at abstract screening: Title Only.
Moser D K, Worster P L. Effect of psychosocial factors on physiologic outcomes in patients with heart failure. J Cardiovasc Nurs. 2000;14(4):106-15. [Rec#: 33877] Exclude at abstract screening: Non-systematic review. [pmid: 10902107].
Moser D K, Chung M L, McKinley S, Riegel B, An K, Cherrington C C, Blakely W, Biddle M, Frazier S K, Garvin B J. Critical care nursing practice regarding patient anxiety assessment and management. Intensive Crit Care Nurs. 2003;19(5):276-88. [Rec#: 42350] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14516757].
Moser D K. Psychosocial factors and their association with clinical outcomes in patients with heart failure: why clinicians do not seem to care. Eur J Cardiovasc Nurs. 2002;1(3):183-8. [Rec#: 33876] Exclude at abstract screening: useful only for background. [pmid: 14622672].
Moskowitz J T, Folkman S, Acree M. Do positive psychological states shed light on recovery from bereavement? Findings from a 3-year longitudinal study. Death Stud. 2003;27(6):471-500. [Rec#: 13889] Exclude at abstract screening: Study Design - Unclear. [pmid: 12814129].
Moss A H, DeLaura G, Arnold R C. New WV Board of Medicine Policy Statement on pain management at the end of life. W V Med J. 2001;97(3):160-1. [Rec#: 13894] Exclude at abstract screening: no outcomes specified. [pmid: 11471466].
Moss A H, Holley J L, Davison S N, Dart R A, Germain M J, Cohen L, Swartz R D. Palliative care. Am J Kidney Dis. 2004;43(1):172-3. [Rec#: 5375] Exclude at abstract screening: useful only for background. [pmid: 14712442].
Moss A H. Billing procedures and reimbursement for palliative care consultations. W V Med J. 2001;97(5):260-1. [Rec#: 5372] Exclude at abstract screening: Title Only. [pmid: 11761654].
Moss A H. Patient-centered medicine: achieving outcomes in end-of-life care that will meet with high patient and family satisfaction. W V Med J. 2001;97(6):306-7. [Rec#: 13892] Exclude at abstract screening: Title Only. [pmid: 11828678].
Moss A H. Shared decision-making in dialysis: the new RPA/ASN guideline on appropriate initiation and withdrawal of treatment. Am J Kidney Dis. 2001;37(5):1081-91. [Rec#: 5374] Exclude at abstract screening: Title Only. [pmid: 11325693].
Moss A H. The need for more physician communication with patients/families facing the end of life. W V Med J. 2001;97(4):206-8. [Rec#: 13891] Exclude at abstract screening: no outcomes specified. [pmid: 11558291].
Moss B. Palliative care in acute hospitals. Nurs Times. 2002;98(6):35-6. [Rec#: 13895] Exclude at abstract screening: no outcomes specified. [pmid: 11892484].
Moss MS, Moss SZ, Rubinstein RL, and Black HK. The metaphor of “family” in staff communication about dying and death. J Gerontol B Psychol Sci Soc Sci 2003;58(5):S290–6. Erratum in: J Gerontol B Psychol Sci Soc Sci. 2003 Nov;58(6):S326. [Rec#: 5379] Exclude at abstract screening: Study Design - Qualitative
Moss V. Terminal care for people with AIDS. Practitioner. 91;235(1502):446-9. [Rec#: 13898] Exclude at abstract screening: Title Only. [pmid: 1924127].
Mosterd A, Hoes A W. Reducing hospitalizations for heart failure. Eur Heart J 2002;23(11):842–5. Comment on: Eur Heart J. Jun. 2002;23(11):877-85. PMID: 12042009. [Rec#: 50080] Exclude at abstract screening: Title Only.
Moulin D E, Clark A J, Speechley M, Morley-Forster P K. Chronic pain in Canada--prevalence, treatment, impact and the role of opioid analgesia. Pain Res Manag 2002;7(4):179–84. Comment in: Pain Res Manag. Winter. 2002;7(4):170-3. PMID: 12518172. [Rec#: 42358] Exclude at abstract screening: not about end of life.
Moulin D E, Kreeft J H, Murray-Parsons N, Bouquillon A I. Comparison of continuous subcutaneous and intravenous hydromorphone infusions for management of cancer pain. Lancet 91;337(8739):465–8. Comment in: Lancet. Apr 20. 1991;337(8747):979. PMID: 1714029. [Rec#: 5384] Exclude at abstract screening: Observational study.
Mount B M, Hamilton P. When palliative care fails to control suffering. Journal of Palliative Care. 94;10(2):24-6. discussion 27–30. [Rec#: 50624] Exclude at abstract screening: no outcomes specified. [pmid: 8089814].
Mount B M, Scott J F. Whither hospice evaluation. J Chronic Dis. 83;36(11):731-6. [Rec#: 50878] Exclude at abstract screening: no outcomes specified. [pmid: 6643643].
Mount B M. Volunteer support services, a key component of palliative care. Journal of Palliative Care. 92;8(1):59-64. [Rec#: 50623] Exclude at abstract screening: no outcomes specified. [pmid: 1583571].
Mount B M, Jones A, Patterson A. Death and dying: attitudes in a teaching hospital. Urology. 74;4(6):741-8. [Rec#: 50625] Exclude at abstract screening: Title Only. [pmid: 4454119].
Mountain G, Pighills A. Pre-discharge home visits with older people: time to review practice. Health Soc Care Community. 2003;11(2):146-54. [Rec#: 42359] Exclude at abstract screening: not about end of life. [pmid: 14629217].
Movsas B, Scott C. Quality-of-life trials in lung cancer: past achievements and future challenges. Hematol Oncol Clin North Am. 2004;18(1):161-86. [Rec#: 33884] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 15005287].
Moyle W, Edwards H, Clinton M. Living with loss: dementia and the family caregiver. Aust J Adv Nurs. 2002;19(3):25-31. [Rec#: 5388] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12002626].
Muego C. Dying at home. Nurs BC. 92;24(5):22-6. [Rec#: 5392] Exclude at abstract screening: Title Only. [pmid: 1420547].
Mueller P S, Hook C C, Hayes D L. Ethical analysis of withdrawal of pacemaker or implantable cardioverter-defibrillator support at the end of life. Mayo Clin Proc. 2003;78(8):959-63. [Rec#: 5393] Exclude at abstract screening: no outcomes specified. [pmid: 12911044].
Mui A C. Caring for frail elderly parents: a comparison of adult sons and daughters. Gerontologist. 95;35(1):86-93. [Rec#: 42363] Exclude at abstract screening: not about end of life. [pmid: 7890208].
Mui A C. The Program of All-Inclusive Care for the Elderly (PACE): an innovative long-term care model in the United States. J Aging Soc Policy. 2001;13(23):53-67. [Rec#: 42364] Exclude at abstract screening: no outcomes specified. [pmid: 12216362].
Muir J C, Arnold R M. Palliative care and the hospitalist: an opportunity for cross-fertilization. Am J Med. 2001;111(9B):10S-14S. [Rec#: 13913] Exclude at abstract screening: useful only for background. [pmid: 11790362].
Muir J C, Arnold R M. Palliative care and the hospitalist: an opportunity for cross-fertilization. Dis Mon. 2002;48(4):207-16. [Rec#: 13914] Exclude at abstract screening: useful only for background. [pmid: 12021753].
Muir J C, Krammer L M, Cameron J R, von Gunten C F. Symptom control in hospice--state of the art. Hosp J. 99;14(34):33-61. [Rec#: 13915] Exclude at abstract screening: useful only for background. [pmid: 10839001].
Muir N. Dealing with death. Nurs Stand. 2002;17(3):33. [Rec#: 13917] Exclude at abstract screening: Title Only. [pmid: 12382483].
Mukamel D B, Bajorska A, Temkin-Greener H. Health care services utilization at the end of life in a managed care program integrating acute and long-term care. Med Care 2002;40(12):1136–48. Comment in: Med Care. Dec. 2002;40(12):1133-5. PMID: 12458296. [Rec#: 5399] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Mularski RA and Osborne ML. End-of-life care in the critically ill geriatric population. Crit Care Clin 2003;19(4):789–810, viii. [Rec#: 5400] Exclude at abstract screening: no outcomes specified
Mullan J T. The bereaved caregiver: a prospective study of changes in well-being. Gerontologist. 92;32(5):673-83. [Rec#: 5402] Exclude at abstract screening: Study Design - Unclear. [pmid: 1427280].
Muller H. Combined regional and systemic chemotherapy for advanced and inoperable non-small cell lung cancer. Eur J Surg Oncol. 2002;28(2):165-71. [Rec#: 5405] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 11884052].
Mulligan M A. The innovative use of a patient-controlled analgesia pump for the management of cardiac angina. J Palliat Care. 98;14(4):47-9. [Rec#: 5408] Exclude at abstract screening: Title Only. [pmid: 9893398].
Mullner R M, Jewell M A, Mease M A. Monitoring changes in home health care: a comparison of two national surveys. J Med Syst. 99;23(1):21-6. [Rec#: 5409] Exclude at abstract screening: useful only for background.
Mungas D, Cooper J K, Weiler P G, Gietzen D, Franzi C, Bernick C. Dietary preference for sweet foods in patients with dementia. J Am Geriatr Soc 90;38(9):999–1007. Comment in: J Am Geriatr Soc. May. 1991;39(5):535-6. PMID: 2022811. [Rec#: 33910] Exclude at abstract screening: not about end of life.
Munley A, Powers C S, Williamson J B. Humanizing nursing home environments: the relevance of hospice principles. International Journal of Aging & Human Development. 82;15(4):263-84. [Rec#: 50626] Exclude at abstract screening: no outcomes specified.
Munson ML. Characteristics of elderly home health care users: data from the 1996 National Home and Hospice Care Survey. Adv Data 99;(309):1–11. [Rec#: 5412] Exclude at abstract screening: not about end of life
Murakami J F, Wong W F. The decision to withdraw tube feeding. Hawaii Med J. 95;54(4):485-9. [Rec#: 5414] Exclude at abstract screening: no outcomes specified. [pmid: 7601671].
Murberg T A, Bru E. Social relationships and mortality in patients with congestive heart failure. J Psychosom Res. 2001;51(3):521-7. [Rec#: 33915] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 11602222].
Murberg T A, Bru E, Aarsland T, Svebak S. Functional status and depression among men and women with congestive heart failure. Int J Psychiatry Med. 98;28(3):273-91. [Rec#: 33916] Exclude at abstract screening: not about end of life.
Murkofsky R L, Phillips R S, McCarthy E P, Davis R B, Hamel M B. Length of stay in home care before and after the 1997 Balanced Budget Act. JAMA. 2003;289(21):2841-8. [Rec#: 50627] Exclude at abstract screening: not about end of life. [pmid: 12783915].
Murphy C, Sweeney M A. Conflict resolution with end of life decisions in critical care settings. Medinfo. 95;8(Pt 2):1696. [Rec#: 5417] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Murphy M, Patterson G, O'Doherty C. Improving terminal care. Community Nurse. 96;2(8):28. [Rec#: 5420] Exclude at abstract screening: Title Only. [pmid: 9450432].
Murphy N M. AIDS & the soul of the physician. J Int Assoc Physicians AIDS Care. 96;2(6):6-8. [Rec#: 13939] Exclude at abstract screening: Title Only. [pmid: 11363701].
Murphy P, Kreling B, Kathryn E, Stevens M, Lynn J, Dulac J. Description of the SUPPORT intervention. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatments. J Am Geriatr Soc. 2000;48(5 Suppl):S154-61. [Rec#: 5421] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10809469].
Murphy D J, Burrows D, Santilli S, Kemp A W, Tenner S, Kreling B, Teno J. The influence of the probability of survival on patients' preferences regarding cardiopulmonary resuscitation. New England Journal of Medicine. 94;330(8):545-9. [Rec#: 50628] Exclude at abstract screening: not about end of life.
Murphy S T, Palmer J M, Azen S, Frank G, Michel V, Blackhall L J. Ethnicity and advance care directives. Journal of Law Medicine & Ethics. 96;24(2):108-17. [Rec#: 50629] Exclude at abstract screening: Study Design - Unclear.
Murray M A, O'Connor A M, Fiset V, Viola R. Women's decision-making needs regarding place of care at end of life. J Palliat Care. 2003;19(3):176-84. [Rec#: 5440] Exclude at abstract screening: Observational study. [pmid: 14606329].
Murray MF. When it comes to advance directives, we can't afford question marks. Imprint 98;45(3):27, 30. [Rec#: 5441] Exclude at abstract screening: Title Only
Murray P K, Singer M, Dawson N V, Thomas C L, Cebul R D. Outcomes of rehabilitation services for nursing home residents. Arch Phys Med Rehabil. 2003;84(8):1129-36. [Rec#: 33929] Exclude at abstract screening: not about end of life. [pmid: 12917850].
Murray S A, Boyd K, Kendall M, Worth A, Benton T F, Clausen H. Dying of lung cancer or cardiac failure: prospective qualitative interview study of patients and their carers in the community. BMJ 2002;325(7370):929. Comment in: BMJ. Oct 26. 2002;325(7370):915-6. PMID: 12399323. [Rec#: 5442] Exclude at abstract screening: Study Design - Qualitative.
Murray S A, Grant E, Grant A, Kendall M. Dying from cancer in developed and developing countries: lessons from two qualitative interview studies of patients and their carers. BMJ 2003;326(7385):368. Comment in: BMJ. 2003 Jul 26;327(7408):222. PMID: 12881274. Comment in: BMJ. May 24. 2003;326(7399):1146. PMID: 12764005. [Rec#: 5443] Exclude at abstract screening: Study Design - Qualitative.
Murray S A, Kendall M, Boyd K, Worth A, Benton T F. Exploring the spiritual needs of people dying of lung cancer or heart failure: a prospective qualitative interview study of patients and their carers. Palliat Med. 2004;18(1):39-45. [Rec#: 5444] Exclude at abstract screening: Study Design - Qualitative. [pmid: 14982206].
Murrell S A, Meeks S, Walker J. Protective functions of health and self-esteem against depression in older adults facing illness or bereavement. Psychol Aging. 91;6(3):352-60. [Rec#: 5445] Exclude at abstract screening: not about end of life.
Murtagh F E, Preston M, Higginson I. Patterns of dying: palliative care for non-malignant disease. Clin Med. 2004;4(1):39-44. [Rec#: 5446] Exclude at abstract screening: useful only for background. [pmid: 14998265].
Musgrave C F. Terminal dehydration. To give or not to give intravenous fluids?. Cancer Nurs. 90;13(1):62-6. [Rec#: 13955] Exclude at abstract screening: useful only for background. [pmid: 2407341].
Muszbek K, Ruzsa A. Supportive palliative treatment, psychological care and the hospice movement in Hungary. Support Care Cancer. 96;4(1):7-9. [Rec#: 13958] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Muzzin L J, Anderson N J, Figueredo A T, Gudelis S O. The experience of cancer. Soc Sci Med. 94;38(9):1201-8. [Rec#: 13959] Exclude at abstract screening: no outcomes specified. [pmid: 8016685].
Myers K G, Trotman I F. Palliative care needs in a district general hospital: a survey of patients with cancer. Eur J Cancer Care (Engl). 96;5(2):116-21. [Rec#: 5457] Exclude at abstract screening: Study Design - Unclear.
Myrdal G, Valtysdottir S, Lambe M, Stahle E. Quality of life following lung cancer surgery. Thorax 2003;58(3):194–7. Comment in: Thorax. Mar. 2003;58(3):189. PMID: 12612288. [Rec#: 33943] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Mystakidou K, Parpa E, Tsilika E, Katsouda E, Kouloulias V, Kouvaris J, Georgaki S, Vlahos L. Pain management of cancer patients with transdermal fentanyl: A study of 1828 step I, II, & III transfers. J Pain. 2004;5(2):119-32. [Rec#: 5461] Exclude at abstract screening: Study Design - Qualitative. [pmid: 15042520].
Mystakidou K, Tsilika E, Befon S, Kululias V, Vlahos L. Optimizing hospital-based home care for dying cancer patients: a population-based study. Palliat Med. 99;13(5):385-92. [Rec#: 5462] Exclude at abstract screening: Study Design - Qualitative.
Mystakidou K, Tsilika E, Kouloulias V, Parpa E, Katsouda E, Kouvaris J, Vlahos L. The “Palliative Care Quality of Life Instrument (PQLI)” in terminal cancer patients. Health Qual Life Outcomes. 2004;2(1):8. [Rec#: 5464] Exclude at abstract screening: Study Design - Qualitative. [pmid: 14962348]. [pmcid: 368445].
Myths of pain control in the dying addressed. Hosp Ethics 93;9(2):14–5. [Rec#: 13966] Exclude at abstract screening: no outcomes specified
Mytko J J, Knight S J. Body, mind and spirit: towards the integration of religiosity and spirituality in cancer quality of life research. Psycho-Oncology. 99;85:439-450. [Rec#: 50630] Exclude at abstract screening: Title Only.
Nagaratnam N, Lewis-Jones M. Predictive properties of referral communications for mental illness and dementia in a community. Dement Geriatr Cogn Disord. 98;9(2):117-20. [Rec#: 33949] Exclude at abstract screening: not about end of life.
Nally AT. Hospice care eases the transition while preserving dignity. ONS News 98;13(8):1, 4–5. [Rec#: 13978] Exclude at abstract screening: Title Only
National Advisory Committee on Palliative Care. Report of the National Advisory Committee on Palliative Care. 2001;<25 Page(s)>. [Rec#: 50631] Exclude at abstract screening: Title Only
National Comprehensive Cancer Network. Distress Management - v.1.2003. 2003;<25 Page(s)>. [Rec#: 50632] Exclude at abstract screening: Title Only
National Comprehensive Cancer Network. NCCN Practice Guidelines For The Management Of Psychosocial Distress. National Comprehensive Cancer Network. Oncology (Huntington). 99;13(5A):113-147. [Rec#: 50633] Exclude at abstract screening: Title Only.
National Comprehensive Cancer Network. Palliative Care - v1.2003. 2003;<25 Page(s)>. [Rec#: 50635]. Exclude at abstract screening: Title Only
National Comprehensive Cancer Network. Palliative Care Clinical Practice Guidelines in Oncology. 2002;<25 Page(s)>. [Rec#: 50634] Exclude at abstract screening: Title Only
National Consensus Project. National Consensus Project for Quality Palliative Care: Clinical Practice Guidelines. 2004;<25 Page(s)>. [Rec#: 50836] Exclude at abstract screening: Non-systematic review
National Council for Hospice and Specialist Palliative Care Services (Great Britain). Care for the dying at home: guidelines. Bull Med Ethics. 93;88:8-11. [Rec#: 13985] Exclude at abstract screening: Title Only.
National Council For Hospice And Specialist Palliative Care Services. Definitions of palliative and supportive care. 2002;<25 Page(s)>. [Rec#: 50636] Exclude at abstract screening: Title Only
National Council For Hospice And Specialist Palliative Care Services. Dilemmas and Directions: The Future of Specialist Palliative Care. A Discussion Paper. 1997;<25 Page(s)>. [Rec#: 50637] Exclude at abstract screening: Title Only
National Health Service Quality Improvement Scotland. Clinical Standards for Specialist Palliative Care. 2002;<25 Page(s)>. [Rec#: 50638] Exclude at abstract screening: Title Only
National Institute of Health Consensus Development Program. NIH State-of-the-Science Conference on Symptom Management in Cancer: Pain, Depression and Fatigue-Final statement. 2002;<25 Page(s)>. [Rec#: 50640] Exclude at abstract screening: Non-systematic review
National Institute of Health Consensus Development Program. NIH State-of-the-Science Conference on Symptom Management in Cancer: Pain, Depression and Fatigue - conference program and abstracts. 2002;<25 Page(s)>. [Rec#: 50837] Exclude at abstract screening: useful only for background
National Institute of Health. Symptoms in Terminal Illness: A Research Workshop. 1997;<25 Page(s)>. [Rec#: 50639] Exclude at abstract screening: Title Only
Nauck F, Klaschik E, Ostgathe C. Symptom control during the last three days of life. European Journal of Palliative Care. 2000;7:81-84. [Rec#: 50641] Exclude at abstract screening: Title Only.
Nazerali N. Counseling the elderly on decision making for the end of life. Practical issues for physicians. Can Fam Physician. 95;41:829-33. [Rec#: 5495] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Neale A. The cultural basis of inadequate care. To provide supportive care of the dying, our society must learn to live with our mortality. Health Prog 96;77(3):50–1, 70. [Rec#: 13991] Exclude at abstract screening: Title Only
Needham D S, Wong I C, Campion P D. Hull and East Riding Pharmacy Developmnet Group. Evaluation of the effectiveness of UK community pharmacists' interventions in community palliative care. Palliat Med. 2002;16(3):219-25. [Rec#: 5499] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12046998].
Neff M S. To be or not to be: the decision to withdraw or be withdrawn from dialysis. Am J Kidney Dis. 99;33(3):601-3. discussion 603–6. [Rec#: 13996] Exclude at abstract screening: Title Only. [pmid: 10070928].
Neff P, Lyckholm L, Smith T. Truth or consequences: what to do when the patient doesn't want to know. J Clin Oncol 2002;20(13):3035–7. Comment in: J Clin Oncol. Nov 1. 2002;20(21):4403-4. PMID: 12409343. [Rec#: 13997] Exclude at abstract screening: Title Only.
Neithercut W D, Chattington P. Routine clinical biochemistry tests collected from patients dying in hospital. Br J Clin Pract. 95;49(5):241-2. [Rec#: 5507] Exclude at abstract screening: Title Only. [pmid: 7492459].
Nekolaichuk C L, Bruera E. On the nature of hope in palliative care. J Palliat Care. 98;14(1):36-42. [Rec#: 14006] Exclude at abstract screening: no outcomes specified. [pmid: 9575712].
Nekolaichuk C L, Bruera E, Spachynski K, MacEachern T, Hanson J, Maguire T O. A comparison of patient and proxy symptom assessments in advanced cancer patients. Palliat Med. 99;13(4):311-23. [Rec#: 5508] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Nekolaichuk C L, Jevne R F, Maguire T O. Structuring the meaning of hope in health and illness. Soc Sci Med. 99;48(5):591-605. [Rec#: 5509] Exclude at abstract screening: not about end of life. [pmid: 10080361].
Nelson J E, Danis M. End-of-life care in the intensive care unit: where are we now?. Crit Care Med. 2001;29(2 Suppl):N2-9. [Rec#: 5514] Exclude at abstract screening: no outcomes specified. [pmid: 11228566].
Nelson K A, Walsh D, Behrens C, Zhukovsky D S, Lipnickey V, Brady D. The dying cancer patient. Semin Oncol. 2000;27(1):84-9. [Rec#: 14015] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10697024].
Nelson C J, Rosenfeld B J, Breitbart W, Galietta M. Spirituality, religion, and depression in the terminally ill. Psychosomatics. 2002;43:213-220. [Rec#: 50642] Exclude at abstract screening: Duplicate already in the flow. [pmid: 12075036].
Nelson-Marten P, Braaten J, English N K. Critical caring. Promoting good end-of-life care in the intensive care unit. Crit Care Nurs Clin North Am. 2001;13(4):577-85. [Rec#: 14016] Exclude at abstract screening: not about end of life. [pmid: 11778345].
Ness, David E, Ende, Jack. Denial in the medical interview. Recognition and Management. JAMA. 94;272(22):1777-81. [Rec#: 50643] Exclude at abstract screening: Title Only. [pmid: 7966927].
Neu S, Kjellstrand C M. Stopping long-term dialysis. An empirical study of withdrawal of life-supporting treatment. New England Journal of Medicine. 86;314(1):14-20. [Rec#: 50644] Exclude at abstract screening: data older than 1990.
Neubauer B J, Hamilton C L. Racial differences in attitudes toward hospice care. Hosp J. 90;6(1):37-48. [Rec#: 5525] Exclude at abstract screening: data older than 1990. [pmid: 2379922].
Neubecker J. Hospice: a comprehensive program. Health Prog 94;75(9):28–31, 40. [Rec#: 5526] Exclude at abstract screening: no outcomes specified
Neuberger J. A healthy view of dying. BMJ 2003;327(7408):207–8. Erratum in: BMJ. Aug 23. 2003;327(7412):422. [Rec#: 14025] Exclude at abstract screening: Title Only.
Neuberger R J. Commentary: a “good death” is possible in the NHS. BMJ 2003;326(7379):30–4. Comment on: BMJ. Jan 4. 2003;326(7379):30-4. PMID: 12511460. [Rec#: 14026] Exclude at abstract screening: Title Only.
Neuenschwander H, Bruera E, Cavalli F. Matching the clinical function and symptom status with the expectations of patients with advanced cancer, their families, and health care workers. Support Care Cancer. 97;5(3):252-6. [Rec#: 5529] Exclude at abstract screening: useful only for background.
Neumann P J, Kuntz K M, Leon J, Araki S S, Hermann R C, Hsu M A, Weinstein M C. Health utilities in Alzheimer's disease: a cross-sectional study of patients and caregivers. Med Care. 99;37(1):27-32. [Rec#: 5533] Exclude at abstract screening: not about end of life.
Neumark D E. Providing information about advance directives to patients in ambulatory care and their families. Oncol Nurs Forum. 94;21(4):771-5. [Rec#: 5534] Exclude at abstract screening: no outcomes specified.
Neville A. Lung cancer. Clin Evid 2002;(7):1369–83. Update in: Clin Evid. 2002 Dec;(8):1558–74. PMID: 12603954. [Rec#: 14028] Exclude at abstract screening: no outcomes specified
New England Medical Center EPC (Boston MA) for AHRQ. Management of Cancer Symptoms: Pain, Depression, and Fatigue (Evidence Report/Technology Assessment). 2002;<25 Page(s)>. [Rec#: 50838] Exclude at abstract screening: Study Design - Review/Meta
New Medicare legislation expands hospice benefit. Caring 2004;23(2):64–5. [Rec#: 5540] Exclude at abstract screening: no outcomes specified
New report card compares end-of-life care initiatives across the country. Qual Lett Healthc Lead 2003;15(1):10–1. [Rec#: 14031] Exclude at abstract screening: useful only for background
Newbury J, Hatherell C A. Audit on discharging patients from community specialist palliative care nursing services. Int J Palliat Nurs. 2004;10(1):24-31. [Rec#: 14033] Exclude at abstract screening: not about end of life. [pmid: 14966442].
Newport D J, Nemeroff C B. Assessment and treatment of depression in the cancer patient. J Psychosom Res. 98;45(3):215-37. [Rec#: 14041] Exclude at abstract screening: not about end of life. [pmid: 9776368].
Ni H, Nauman D, Burgess D, Wise K, Crispell K, Hershberger R E. Factors influencing knowledge of and adherence to self-care among patients with heart failure. Arch Intern Med. 99;159(14):1613-9. [Rec#: 34026] Exclude at abstract screening: not about end of life.
Ni H, Nauman D J, Hershberger R E. Analysis of trends in hospitalizations for heart failure. J Card Fail. 99;5(2):79-84. [Rec#: 50081] In abstract review process. [pmid: 10404346].
Ni H, Toy W, Burgess D, Wise K, Nauman D J, Crispell K, Hershberger R E. Comparative responsiveness of Short-Form 12 and Minnesota Living With Heart Failure Questionnaire in patients with heart failure. J Card Fail. 2000;6(2):83-91. [Rec#: 34028] Exclude at abstract screening: not about end of life. [pmid: 10908081].
Nichols J, Riegel B. The contribution of chronic illness to acceptance of death in hospitalized patients. Clin Nurs Res. 2002;11(1):103-15. [Rec#: 14051] Exclude at abstract screening: not about end of life. [pmid: 11845511].
Nichols K. Hospice patient advocacy through complete documentation. Home Care Provid 2000;5(3):104–7. Comment in: Home Care Provid. Jun. 2000;5(3):84. PMID: 10835157. [Rec#: 14052] Exclude at abstract screening: no outcomes specified.
Nicholson, A., Davies, A. N., and Reid, C. M. Methadone for cancer pain. Cochrane Library 2003;3. [Rec#: 50645] Exclude at abstract screening: Title Only
NIH (Karen Patrias, editor. Current Bibliographies in Medicine on: Symptom Management in Cancer: Pain, Depression, and Fatigue. Jan 1990-June 2002. 2002;<25 Page(s)>. [Rec#: 50841] Exclude at abstract screening: Non-systematic review
Nixon LL and Roscoe L. How can you improve end-of-life decision making? Trustee 99;52(6):suppl 1–4 following 12. [Rec#: 14067] Exclude at abstract screening: Title Only
Noddings N. Moral obligation or moral support for high-tech home care. Hastings Cent Rep. 94;24(5 Suppl):S6-10. [Rec#: 5585] Exclude at abstract screening: no outcomes specified.
Nohria A, Chen Y T, Morton D J, Walsh R, Vlasses P H, Krumholz H M. Quality of care for patients hospitalized with heart failure at academic medical centers. Am Heart J 99;137(6):1028–34. Comment in: Am Heart J. Jun. 1999;137(6):987-8. PMID: 10347316. [Rec#: 34062] Exclude at abstract screening: not about end of life.
Nohria A, Lewis E, Stevenson L W. Medical management of advanced heart failure. JAMA 2002;287(5):628–40 Comment in: JAMA. 2002 May 1;287(17);2209–10; author reply 2210. PMID: 11980514. Comment in: JAMA. May 1. 2002;287(17):2209. author reply 2210. PMID: 11980512. [Rec#: 14072] Exclude at abstract screening: useful only for background.
Nolan M T, Bruder M. Patients' attitudes toward advance directives and end-of-life treatment decisions. Nurs Outlook. 97;45(5):204-8. [Rec#: 5588] Exclude at abstract screening: useful only for background.
Norberg A, Asplund K. Caregivers' experience of caring for severely demented patients. West J Nurs Res. 90;12(1):75-84. [Rec#: 5599] Exclude at abstract screening: Title Only. [pmid: 2301173].
Norbergh K G, Asplund K, Rassmussen B H, Nordahl G, Sandman P O. How patients with dementia spend their time in a psycho-geriatric unit. Scand J Caring Sci. 2001;15(3):215-21. [Rec#: 34073] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11564228].
Norbergh K G, Hellzen O, Sandman P O, Asplun K. The relationship between organizational climate and the content of daily life for people with dementia living in a group-dwelling. J Clin Nurs. 2002;11(2):237-46. [Rec#: 34074] Exclude at abstract screening: Observational study. [pmid: 11903723].
Nordgren L, Olsson H. Palliative care in a coronary care unit: a qualitative study of physicians' and nurses' perceptions. J Clin Nurs. 2004;13(2):185-93. [Rec#: 14079] Exclude at abstract screening: no outcomes specified. [pmid: 14723670].
Norlander L, McSteen K. The kitchen table discussion: a creative way to discuss end-of-life issues. Home Healthc Nurse. 2000;18(8):532-9. quiz 539–40. [Rec#: 5608] Exclude at abstract screening: no outcomes specified. [pmid: 11951306].
Norman A, Sisler J, Hack T, and Harlos M. Family physicians and cancer care. Palliative care patients' perspectives. Can Fam Physician 2001;47:2009–12, 2015–6. [Rec#: 5609] Exclude at abstract screening: Study Design - Qualitative
Northouse L L, Mood D, Templin T, Mellon S, George T. Couples' patterns of adjustment to colon cancer. Social Science & Medicine. 2000;50(2):271-84. [Rec#: 50647] Exclude at abstract screening: not about end of life. [pmid: 10619695].
Norton S A, Bowers B J. Working toward consensus: providers' strategies to shift patients from curative to palliative treatment choices. Res Nurs Health 2001;24(4):258–69. Comment in: Evid Based Nurs. Apr. 2002;5(2):64. PMID: 11995667. [Rec#: 14082] Exclude at abstract screening: Study Design - Qualitative.
Norton S A, Talerico K A. Facilitating end-of-life decision-making: strategies for communicating and assessing. J Gerontol Nurs. 2000;26(9):6-13. [Rec#: 50908] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11883616].
Norton S A, Tilden V P, Tolle S W, Nelson C A, Eggman S T. Life support withdrawal: communication and conflict. Am J Crit Care. 2003;12(6):548-55. [Rec#: 50909] Exclude at abstract screening: Study Design - Qualitative. [pmid: 14619361].
Norum J, Risberg T, Solberg E. Faith among patients with advanced cancer. A pilot study on patients offered “no more than” palliation. Support Care Cancer. 2000;8(2):110-4. [Rec#: 5620] Exclude at abstract screening: Study Design - Qualitative. [pmid: 10739357].
Norwood M. Home care of the terminally ill. Am J Hosp Pharm. 90;47(8 Suppl):S23-6. [Rec#: 14083] Exclude at abstract screening: no outcomes specified. [pmid: 2389792].
Novak B, Kolcaba K, Steiner R, Dowd T. Measuring comfort in caregivers and patients during late end-of-life care. Am J Hosp Palliat Care. 2001;18(3):170-80. [Rec#: 14085] Exclude at abstract screening: Study Design - Unclear. [pmid: 11406893].
Nunez Olarte J M, Guillen D G. Cultural issues and ethical dilemmas in palliative and end-of-life care in Spain. Cancer Control. 2001;8(1):46-54. [Rec#: 50648] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11176035].
Nurses tip sheet on. Advance medical directives. Tex Nurs 92;66(4):9. [Rec#: 14096] Exclude at abstract screening: no outcomes specified
Nyman D J, Sprung C L. End-of-life decision making in the intensive care unit. Intensive Care Med. 2000;26(10):1414-20. [Rec#: 14103] Exclude at abstract screening: no outcomes specified. [pmid: 11126250].
O'Boyle C A, Waldron D. Quality of life issues in palliative medicine. J Neurol. 97;244(Suppl 4):S18-25. [Rec#: 14106] Exclude at abstract screening: useful only for background. [pmid: 9402549].
O'Brien K. Palliative care. Collegian. 2000;7(2):42. [Rec#: 14107] Exclude at abstract screening: no outcomes specified.
O'Callaghan C. Bringing music to life: a study of music therapy and palliative care experiences in a cancer hospital. J Palliat Care. 2001;17(3):155-60. [Rec#: 5638] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11816755].
O'Connell B, Kristjanson L, Orb A. Models of integrated cancer care: a critique of the literature. Australian Health Review. 2000;23(1):163-78. [Rec#: 50650] Exclude at abstract screening: no outcomes specified. [pmid: 10947600].
O'Connor D W, Pollitt P A, Roth M. Coexisting depression and dementia in a community survey of the elderly. Int Psychogeriatr. 90;2(1):45-53. [Rec#: 34100] Exclude at abstract screening: not about end of life.
Oddone E Z, Weinberger M, Giobbie-Hurder A, Landsman P, Henderson W. Enhanced access to primary care for patients with congestive heart failure. Veterans Affairs Cooperative Study Group on Primary Care and Hospital Readmission. Eff Clin Pract. 99;2(5):201-9. [Rec#: 34116] Exclude at abstract screening: not about end of life.
Odling G, Danielson E, Christensen S B, Norberg A. Living with breast cancer: care givers' perceptions in a surgical ward. Cancer Nurs. 98;21(3):187-95. [Rec#: 5672] Exclude at abstract screening: Study Design - Qualitative.
Odom S R, Barone J E, Docimo S, Bull S M, Jorgensson D. Emergency department visits by demented patients with malfunctioning feeding tubes. Surg Endosc. 2003;17(4):651-3. [Rec#: 50083] Exclude at abstract screening: Other topic only. [pmid: 12545272].
O'Donnell D E, Aaron S, Bourbeau J, Hernandez P, Marciniuk D, Balter M, Ford G, Gervais A, Goldstein R, Hodder R, Maltais F, Road J. Canadian Thoracic Society. Canadian Thoracic Society recommendations for management of chronic obstructive pulmonary disease--2003. Can Respir J. 2003;10(Suppl A):11A-65A. [Rec#: 14123] Exclude at abstract screening: not about end of life.
O'Donovan S. Reflections on breaking news of a family death. Nurs Times. 99;95(45):54-5. [Rec#: 14127] Exclude at abstract screening: Title Only. [pmid: 11000806].
O'Driscoll M, Corner J, Bailey C. The experience of breathlessness in lung cancer. Eur J Cancer Care (Engl). 99;8(1):37-43. [Rec#: 34102] Exclude at abstract screening: Study Design - Qualitative. [pmid: 10362952].
Oechsner M, Moller A A, Zaudig M. Cognitive impairment, dementia and psychosocial functioning in human immunodeficiency virus infection. A prospective study based on DSM-III-R and ICD-10. Acta Psychiatr Scand. 93;87(1):13-7. [Rec#: 34120] Exclude at abstract screening: not about end of life.
Ogle K, Mavis B, Wang T. Hospice and primary care physicians: attitudes, knowledge, and barriers. Am J Hosp Palliat Care 2003;20(1):41–51. Comment in: Am J Hosp Palliat Care. May-Jun. 2003;20(3):173-4. PMID: 12785037. [Rec#: 5678] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Ogle K S, Mavis B, Wyatt G K. Physicians and hospice care: attitudes, knowledge, and referrals. J Palliat Med. 2002;5(1):85-92. [Rec#: 5679] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11839230].
O'Gorman ML. Spiritual care at the end of life. Crit Care Nurs Clin North Am 2002;14(2):171–6, viii. [Rec#: 14130] Exclude at abstract screening: useful only for background
O'Gorman S M. Death and dying in contemporary society: an evaluation of current attitudes and the rituals associated with death and dying and their relevance to recent understandings of health and healing. J Adv Nurs. 98;27(6):1127-35. [Rec#: 14131] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
O'Hara P A, Harper D W, Chartrand L D, Johnston S F. Patient death in a long-term care hospital. A study of the effect on nursing staff. J Gerontol Nurs. 96;22(8):27-35. [Rec#: 5653] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Ohldin A. Observations from a home-based congestive heart failure intervention. Home Care Provid. 2001;6(6):212-7. [Rec#: 34129] Exclude at abstract screening: not about end of life. [pmid: 11744898].
Oka R K, De Marco T, Haskell W L, Botvinick E, Dae M W, Bolen K, Chatterjee K. Impact of a home-based walking and resistance training program on quality of life in patients with heart failure. Am J Cardiol. 2000;85(3):365-9. [Rec#: 34133] Exclude at abstract screening: not about end of life. [pmid: 11078308].
Oka R K, DeMarco T, Haskell W L. Perceptions of physical fitness in patients with heart failure. Prog Cardiovasc Nurs. 99;14(3):97-102. [Rec#: 34134] Exclude at abstract screening: not about end of life.
O'Keeffe S T, Noel J, Lavan J N. Cardiopulmonary resuscitation preferences in the elderly. Eur J Med. 93;2(1):33-5. [Rec#: 5655] Exclude at abstract screening: not about end of life. [pmid: 8258004].
Olt G J. Managing pain and psychological issues in palliative care. Best Pract Res Clin Obstet Gynaecol. 2001;15(2):235-51. [Rec#: 14186] Exclude at abstract screening: useful only for background. [pmid: 11358399].
Olver I N, Eliott J A, Blake-Mortimer J. Cancer patients' perceptions of do not resuscitate orders. Psychooncology. 2002;11(3):181-7. [Rec#: 5735] Exclude at abstract screening: Observational study. [pmid: 12112478].
Olweny C L. Effective communication with cancer patients. The use of analogies--a suggested approach. Ann N Y Acad Sci. 97;809:179-87. [Rec#: 14190] Exclude at abstract screening: Title Only. [pmid: 9103569].
O'Mahony S, Coyle N, and Payne R. Multidisciplinary care of the terminally ill patient. Surg Clin North Am 2000;80(2): 729–45, xi. [Rec#: 14133] Exclude at abstract screening: useful only for background
O'Mahony S, McHugh M, Zallman L, Selwyn P. Ventilator withdrawal: procedures and outcomes. Report of a collaboration between a critical care division and a palliative care service. J Pain Symptom Manage. 2003;26(4):954-61. [Rec#: 5659] Exclude at abstract screening: Observational study. [pmid: 14575056].
O'Malley S. Care of the dying: can we do better?. Qual Lett Healthc Lead. 96;8(7):2-11. [Rec#: 14134] Exclude at abstract screening: useful only for background.
OMara A M, Arenella C. Minority representation, prevalence of symptoms, and utilization of services in a large metropolitan hospice. J Pain Symptom Manage. 2001;21(4):290-7. [Rec#: 5738] Exclude at abstract screening: useful only for background. [pmid: 11312043].
Onega L L, Abraham I L. Factor structure of the Dementia Mood Assessment Scale in a cohort of community-dwelling elderly. Int Psychogeriatr. 97;9(4):449-57. [Rec#: 34168] Exclude at abstract screening: not about end of life.
O'Neill B, Rodway A. ABC of palliative care. Care in the community. BMJ. 98;316(7128):373-7. [Rec#: 14137] Exclude at abstract screening: Title Only. [pmid: 9487177].
O'Neill J. A peaceful death. BMJ. 99;319(7205):327. [Rec#: 14138] Exclude at abstract screening: Title Only. [pmid: 10426772].
O'Neill M T. Caring at the end of life. J Health Care Chaplain. 92;4(12):103-9. [Rec#: 14142] Exclude at abstract screening: Title Only. [pmid: 10124189].
O'Neill J, Marconi K. Underserved populations, resource-poor settings, and HIV: innovative palliative care projects. Journal of Palliative Medicine. 2003;6(3):457-459. [Rec#: 50651] Exclude at abstract screening: Title Only. [pmid: 14509495].
O'Neill, J. F., Selwyn, P. A., Schietinger, H. A Clinical Guide to Supportive & Palliative Care for HIV/AIDS. 2003;<25 Page(s)>. [Rec#: 50652] Exclude at abstract screening: Title Only
Oneschuk D, Fennell L, Hanson J, Bruera E. The use of complementary medications by cancer patients attending an outpatient pain and symptom clinic. Journal of Palliative Care. 98;14(4):21-6. [Rec#: 50653] Exclude at abstract screening: Study Design - Unclear.
Opie J, Rosewarne R, O'Connor D W. The efficacy of psychosocial approaches to behaviour disorders in dementia: a systematic literature review. Aust N Z J Psychiatry. 99;33(6):789-99. [Rec#: 50144] Exclude at abstract screening: Study Design - Review/Meta.
O'Rourke KD. Withdrawal of life support: mistaken assumptions. Health Prog 96;77(6):60–1, 65. [Rec#: 14144] Exclude at abstract screening: Title Only
Osborne C. The ABCs of bereavement volunteers: acquire, build, cherish. Am J Hosp Palliat Care. 99;16(1):380-5. [Rec#: 14212] Exclude at abstract screening: Title Only. [pmid: 10085794].
Osoba D. Health-related quality-of-life assessment in clinical trials of supportive care in oncology. Support Care Cancer. 2000;8(2):84-8. [Rec#: 14215] Exclude at abstract screening: no outcomes specified. [pmid: 10739353].
Osoba D. Rationale for the timing of health-related quality-of-life (HQL) assessments in oncological palliative therapy. Cancer Treat Rev. 96;22(Suppl A):69-73. [Rec#: 14216] Exclude at abstract screening: Title Only. [pmid: 8625352].
Ostermann M E, Keenan S P, Seiferling R A, Sibbald W J. Sedation in the intensive care unit: a systematic review. JAMA. 2000;283(11):1451-9. [Rec#: 50655] Exclude at abstract screening: not about end of life. [pmid: 10732935].
Owens M R, McConvey G G, Weeks D, Zeisberg L. A pilot program to evaluate pain assessment skills of hospice nurses. Am J Hosp Palliat Care. 2000;17(1):44-8. [Rec#: 5786] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11094919].
Owens M R, Simmons B, Gibson P S, Weeks D. A longitudinal study of pain in hospice and pre-hospice patients. Am J Hosp Palliat Care. 2001;18(2):124-8. [Rec#: 5787] Exclude at abstract screening: Study Design - Unclear. [pmid: 11407128].
Ownby R L, Harwood D G, Acevedo A, Barker W, Duara R. Factor structure of the Cornell Scale for Depression in Dementia for Anglo and Hispanic patients with dementia. Am J Geriatr Psychiatry. 2001;9(3):217-24. [Rec#: 34211] Exclude at abstract screening: not about end of life. [pmid: 11481129].
Oz M C, Gelijns A C, Miller L, Wang C, Nickens P, Arons R, Aaronson K, Richenbacher W, van Meter C, Nelson K, Weinberg A, Watson J, Rose E A, Moskowitz A J. Left ventricular assist devices as permanent heart failure therapy: the price of progress. Ann Surg. 2003;238(4):577-83. discussion 583–5 [Rec#: 50084] Exclude at abstract screening: not about end of life. [pmid: 14530729]. [pmcid: 1360116].
Pace K B, Sakulkoo S, Hoffart N, Cobb A K. Barriers to successful implementation of a clinical pathway for CHF. J Healthc Qual. 2002;24(5):32-8. [Rec#: 34212] Exclude at abstract screening: not about end of life. [pmid: 12240541].
Paesmans M. Benefits of chemotherapy for quality of life in patients with advanced nonsmall-cell lung cancer. Curr Opin Oncol. 2002;14(4):389-93. [Rec#: 34216] Exclude at abstract screening: Other symptoms only. [pmid: 12130921].
Pai C W, Finnegan G K, Satwicz M J. The combined effect of public profiling and quality improvement efforts on heart failure management. Jt Comm J Qual Improv. 2002;28(11):614-24. [Rec#: 34220] Exclude at abstract screening: not about end of life. [pmid: 12425256].
Paice J A, Muir J C, Shott S. Palliative care at the end of life: comparing quality in diverse settings. Am J Hosp Palliat Care. 2004;21(1):19-27. [Rec#: 5799] Exclude at abstract screening: Study Design - Unclear. [pmid: 14748519].
Palliative Care Australia. Standards for Palliative Care Provision - Third Edition. 1999;<25 Page(s)>. [Rec#: 50656] Exclude at abstract screening: Title Only
Palliative Care Australia. Standards for Palliative Care Provision - Third Edition. 1999;<25 Page(s)>. [Rec#: 50657] Exclude at abstract screening: Title Only
Palliative care. Guidelines for good practice and audit measures. Report of a Working Group of the Research Unit, Royal College of Physicians. J R Coll Physicians Lond 91;25(4):325–8. Comment in: J R Coll Physicians Lond. Jan. 1992;26(1):112. PMID: 1573577. [Rec#: 14261] Exclude at abstract screening: useful only for background.
Pan C X, Morrison R S, Meier D E, Natale D K, Goldhirsch S L, Kralovec P, Cassel C K. How prevalent are hospital-based palliative care programs? Status report and future directions. J Palliat Med 2001;4(3):315–24. Comment in: J Palliat Med. Fall. 2001;4(3):307-8. PMID: 11596540. [Rec#: 14269] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Pan C X, Morrison R S, Ness J, Fugh-Berman A, Leipzig R M. Complementary and alternative medicine in the management of pain, dyspnea, and nausea and vomiting near the end of life. A systematic review. J Pain Symptom Manage. 2000;20(5):374-87. [Rec#: 50145] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 11068159].
Panel. American College of Chest Physicians Society of Critical Care Medicine Consensus. Ethical and moral guidelines for the intitiation, continuation, and withdrawal of intensive care. Chest. 90;97:949-958. [Rec#: 50658] Exclude at abstract screening: Title Only.
Panico K, Manfredi P. Institutional patterns of symptomatic medication in hospitalized patients with advanced cancer. Am J Hosp Palliat Care. 2004;21(2):134-6. [Rec#: 5819] Exclude at abstract screening: Study Design - Unclear. [pmid: 15055514].
Pantilat S Z, Billings J A. Prevalence and structure of palliative care services in California hospitals. Arch Intern Med. 2003;163(9):1084-8. [Rec#: 14277] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12742807].
Parkash R, Burge F. The family's perspective on issues of hydration in terminal care. J Palliat Care. 97;13(4):23-7. [Rec#: 5843] Exclude at abstract screening: Study Design - Qualitative. [pmid: 9447808].
Parker S G, Peet S M, McPherson A, Cannaby A M, Abrams K, Baker R, Wilson A, Lindesay J, Parker G, Jones D R. A systematic review of discharge arrangements for older people. Health Technol Assess. 2002;6(4):1-183. [Rec#: 50146] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 12065067].
Parker-Oliver D. Hospice experience and perceptions in nursing homes. J Palliat Med. 2002;5(5):713-20. [Rec#: 14294] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12572970].
Parle M, Jones B, Maguire P. Maladaptive coping and affective disorders among cancer patients. Psychological Medicine. 96;26(4):735-44. [Rec#: 50659] Exclude at abstract screening: not about end of life.
Parle M, Maguire P, Heaven C. The development of a training model to improve health professionals' skills, self-efficacy and outcome expectancies when communicating with cancer patients. Social Science & Medicine. 97;44(2):231-40. [Rec#: 50660] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Parry C, Coleman E A, Smith J D, Frank J, Kramer A M. The care transitions intervention: a patient-centered approach to ensuring effective transfers between sites of geriatric care. Home Health Care Services Quarterly. 2003;22(3):1-17. [Rec#: 50661] Exclude at abstract screening: no outcomes specified. [pmid: 14629081].
Pasacreta J V, McCorkle R. Cancer care: impact of interventions on caregiver outcomes. Annu Rev Nurs Res. 2000;18:127-48. [Rec#: 14307] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 10918934].
Passik S D, Whitcomb L A, Kirsh K L, Donaghy K, Theobald D, Holtsclaw E, Edgerton S, Dugan W. A pilot study of oncology staff perceptions of palliative care and psycho-oncology services in rural and community settings in Indiana. J Rural Health. 2002;18(1):31-4. [Rec#: 14312] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12043753].
Patnaik A, Doyle C, Oza A M. Palliative therapy in advanced ovarian cancer: balancing patient expectations, quality of life and cost. Anticancer Drugs. 98;9(10):869-78. [Rec#: 14326] Exclude at abstract screening: useful only for background.
Paton L. The Sacred Circle: a conceptual framework for spiritual care in hospice. Am J Hosp Palliat Care. 96;13(2):52-6. [Rec#: 14327] Exclude at abstract screening: no outcomes specified. [pmid: 8716329].
Patrick D L, Curtis J R, Engelberg R A, Nielsen E, McCown E. Measuring and improving the quality of dying and death. Ann Intern Med. 2003;139(5 Pt 2):410-5. [Rec#: 14329] Exclude at abstract screening: useful only for background. [pmid: 12965967].
Patterson L B, Dorfman L T. Family support for hospice caregivers. Am J Hosp Palliat Care. 2002;19(5):315-23. [Rec#: 5886] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12269777].
Patterson R J, Spottswood S. The African American perspective on end-of-life care. W V Med J. 2002;98(3):126-7. [Rec#: 14333] Exclude at abstract screening: Title Only. [pmid: 12099101].
Pattison M, Romer A L. Improving Care Through the End of Life: launching a primary care clinic-based program. J Palliat Med. 2001;4(2):249-54. [Rec#: 14334] Exclude at abstract screening: Title Only. [pmid: 11441634].
Pattison N. Integration of critical care and palliative care at end of life. Br J Nurs 2004;13(3):132–6, 138–9. [Rec#: 5889] Exclude at abstract screening: no outcomes specified
Patton M, Mooney D. The nature of care delivered to terminally ill cancer patients in the acute care hospital. Prog Clin Biol Res. 90;339:455-63. [Rec#: 5890] Exclude at abstract screening: useful only for background.
Paul Diaz L, Pinto Pabon I, Fernandez Lobato R, Montes Lopez C. Palliative treatment of malignant colorectal strictures with metallic stents. Cardiovasc Intervent Radiol. 99;22(1):29-36. [Rec#: 5891] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Paul S and Sneed N. Patient perceptions of quality of life and treatment in an outpatient congestive heart failure clinic. Congest Heart Fail 2002;8(2):74–6, 77–9. [Rec#: 34290] Exclude at abstract screening: Study Design - Unclear
Pautex S, Berger A, Chatelain C, Herrmann F, Zulian G B. Symptom assessment in elderly cancer patients receiving palliative care. Crit Rev Oncol Hematol. 2003;47(3):281-6. [Rec#: 5895] Exclude at abstract screening: Other symptoms only. [pmid: 12962902].
Pavis H, Wilcock A. Prescribing of drugs for use outside their licence in palliative care: survey of specialists in the United Kingdom. BMJ. 2001;323(7311):484-5. [Rec#: 14338] Exclude at abstract screening: Title Only. [pmid: 11532839]. [pmcid: 48132].
Payne K. Critical factors for improved end-of-life care. Changing the culture of a hospital. QRC Advis. 99;15(6):1-7. [Rec#: 14339] Exclude at abstract screening: Title Only. [pmid: 10351202].
Payne R, Medina E, Hampton J W. Quality of life concerns in patients with breast cancer: evidence for disparity of outcomes and experiences in pain management and palliative care among African-American women. Cancer. 2003;97(1 Suppl):311-7. [Rec#: 14341] In abstract review process. [pmid: 12491494].
Payne S, Relf M. The assessment of need for bereavement follow-up in palliative and hospice care. Palliat Med. 94;8(4):291-7. [Rec#: 14348] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Payne S, Sheldon F, Jarrett N, Large S, Smith P, Davis C L, Turner P, George S. Differences in understanding of specialist palliative care amongst service providers and commissioners in South London. Palliat Med. 2002;16(5):395-402. [Rec#: 14349] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12380657].
Payne S A, Dean S J, Kalus C. A comparative study of death anxiety in hospice and emergency nurses. J Adv Nurs 98;28(4):700–6. Comment in: J Adv Nurs. Aug. 2001;35(3):384-5. PMID: 11489019. [Rec#: 5904] In abstract review process.
Payne S A, Langley-Evans A, Hillier R. Perceptions of a ‘good’ death: a comparative study of the views of hospice staff and patients. Palliat Med. 96;10(4):307-12. [Rec#: 14350] Exclude at abstract screening: Study Design - Qualitative.
Payne S A. Coping with palliative chemotherapy. J Adv Nurs. 90;15(6):652-8. [Rec#: 5902] Exclude at abstract screening: Study Design - Qualitative. [pmid: 1694870].
Payne K, Taylor R M, Stocking C, Sachs G A. Physicians' attitudes about the care of patients in the persistent vegetative state: a national survey. Annals of Internal Medicine. 96;125(2):104-10. [Rec#: 50662] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Pearce M J, Chen J, Silverman G K, Kasl S V, Rosenheck R, Prigerson H G. Religious coping, health, and health service use among bereaved adults. Int J Psychiatry Med. 2002;32(2):179-99. [Rec#: 5908] Exclude at abstract screening: Bereavement only. [pmid: 12269598].
Pearson M L, Kahn K L, Harrison E R, Rubenstein L V, Rogers W H, Brook R H, Keeler E B. Differences in quality of care for hospitalized elderly men and women. JAMA. 92;268(14):1883-9. [Rec#: 34304] Exclude at abstract screening: data older than 1990.
Pentz R D, Lenzi R, Holmes F, Khan M M, Verschraegen C. Discussion of the do-not-resuscitate order: a pilot study of perceptions of patients with refractory cancer. Support Care Cancer. 2002;10(8):573-8. [Rec#: 5940] Exclude at abstract screening: Observational study. [pmid: 12436216].
Pepe P E, Swor R A, Ornato J P, Racht E M, Blanton D M, Griswell J K, Blackwell T, Dunford J, Turtle Creek Conference I I. Resuscitation in the out-of-hospital setting: medical futility criteria for on-scene pronouncement of death. Prehosp Emerg Care. 2001;5(1):79-87. [Rec#: 5941] Exclude at abstract screening: no outcomes specified. [pmid: 11194075].
Pepler C J, Lynch A. Relational messages of control in nurse-patient interactions with terminally ill patients with AIDS and cancer. J Palliat Care. 91;7(1):18-29. [Rec#: 5942] Exclude at abstract screening: Study Design - Qualitative.
Pereira J, Bruera E, Quan H. Palliative care on the net: an online survey of health care professionals. J Palliat Care. 2001;17(1):41-5. [Rec#: 5945] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11324184].
Pereira J, Bruera E, Macmillan K, Kavanagh S. Palliative cancer patients and their families on the Internet: motivation and impact. J Palliat Care. 2000;16(4):13-9. [Rec#: 5944] Exclude at abstract screening: useful only for background. [pmid: 11965929].
Pereira J, Bruera E. Depression with psychomotor retardation: diagnostic challenges and the use of psychostimulants. Journal of Palliative Medicine. 2001;4(1):15-21. [Rec#: 50663] Exclude at abstract screening: no outcomes specified. [pmid: 11291390].
Pereira J, Bruera E. The Internet as a resource for palliative care and hospice: a review and proposals. Journal of Pain & Symptom Management. 98;16(1):59-68. [Rec#: 50664] Exclude at abstract screening: not about end of life.
Pereira J L, Bruera E D. Comment: opioid-induced muscle activity. Annals of Pharmacotherapy. 96;30(9):1042-3. [Rec#: 50667] Exclude at abstract screening: Title Only. [pmid: 8876879].
Pereira J L, Koski S, Hanson J, Bruera E D, Mackey J R. Internet usage among women with breast cancer: an exploratory study. Clinical Breast Cancer. 2000;1(2):148-53. discussion 154–5 [Rec#: 50668] Exclude at abstract screening: Other topic only. [pmid: 11899653].
Pereira J, Macmillan A, Bruera E. Launching a palliative care homepage: the Edmonton experience. Palliative Medicine. 97;11(6):435-43. [Rec#: 50666] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Periyakoil V S, Hallenbeck J. Identifying and managing preparatory grief and depression at the end of life. Am Fam Physician. 2002;65(5):883-90. [Rec#: 5953] Exclude at abstract screening: no outcomes specified. [pmid: 11898960].
Perkins H S, Cortez J D, Hazuda H P. Advance care planning: does patient gender make a difference?. Am J Med Sci. 2004;327(1):25-32. [Rec#: 5955] Exclude at abstract screening: Observational study. [pmid: 14722393].
Perrin, J. M. Shayne M. Bloom S. Home and Community Care for Chronically Ill Children. 1993;<25 Page(s)>. [Rec#: 50669] Exclude at abstract screening: Title Only
Peruselli C, Marinari M, Brivio B, Castagnini G, Cavana M, Centrone G, Magni C, Merlini M, Scaccabarozzi G L, Paci E. Evaluating a home palliative care service: development of indicators for a continuous quality improvement program. J Palliat Care. 97;13(3):34-42. [Rec#: 14403] Exclude at abstract screening: Title Only.
Pessin H, Rosenfeld B, Burton L, Breitbart W. The role of cognitive impairment in desire for hastened death: a study of patients with advanced AIDS. Gen Hosp Psychiatry. 2003;25(3):194-9. [Rec#: 5974] Exclude at abstract screening: Other topic only. [pmid: 12748032].
Peters J, Large R G, Elkind G. Follow-up results from a randomised controlled trial evaluating in- and outpatient pain management programmes. Pain. 92;50(1):41-50. [Rec#: 14408] Exclude at abstract screening: not about end of life.
Peters P G, Ely J W, Zweig S C, Elder N C, Schneider F D. Physician willingness to withhold tube feeding after Cruzan: an empirical study. Missouri Law Review. 92;57:831-48. [Rec#: 50670] Exclude at abstract screening: Title Only. [pmid: 11654076].
Petersen S. Beyond hospice care: a survey of community outreach programs. Am J Hosp Palliat Care. 92;9(1):15-22. [Rec#: 14411] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Peterson J, Hartman H. A pathway for patients who die within a week of hospice admission. Int J Palliat Nurs. 2000;6(1):39-42. [Rec#: 5985] Exclude at abstract screening: no outcomes specified. [pmid: 12819568].
Petrasch S, Bauer M, Reinacher-Schick A, Sandmann M, Kissler M, Kuchler T, Kruskemper G, Dorr T, Schmiegel W. Assessment of satisfaction with the communication process during consultation of cancer patients with potentially curable disease, cancer patients on palliative care, and HIV-positive patients. Wien Med Wochenschr. 98;148(21):491-9. [Rec#: 5989] Exclude at abstract screening: not about end of life.
Petrisek A C, Mor V. Hospice in nursing homes: a facility-level analysis of the distribution of hospice beneficiaries. Gerontologist. 99;39(3):279-90. [Rec#: 50671] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Philadelphia Panel evidence-based clinical practice guidelines on selected rehabilitation interventions: overview and methodology. Phys Ther 2001;81(10):1629–40 [Rec#: 50110] Exclude at abstract screening: not about end of life
Philbin E F, DiSalvo T G. Influence of race and gender on care process, resource use, and hospital-based outcomes in congestive heart failure. Am J Cardiol. 98;82(1):76-81. [Rec#: 34366] Exclude at abstract screening: Study Design - Unclear.
Philbin E F, DiSalvo T G. Prediction of hospital readmission for heart failure: development of a simple risk score based on administrative data. J Am Coll Cardiol. 99;33(6):1560-6. [Rec#: 50086] Exclude at abstract screening: not about end of life.
Philbin E F, Rocco T A Jr, Lynch L J, Rogers V A, Jenkins P. Predictors and determinants of hospital length of stay in congestive heart failure in ten community hospitals. J Heart Lung Transplant. 97;16(5):548-55. [Rec#: 34371] Exclude at abstract screening: not about end of life.
Phillips C O, Wright S M, Kern D E, Singa R M, Shepperd S, Rubin H R. Comprehensive discharge planning with postdischarge support for older patients with congestive heart failure: a meta-analysis. JAMA. 2004;291(11):1358-67. [Rec#: 34375] Exclude at abstract screening: not about end of life. [pmid: 15026403].
Phillips C O, Wright S M, Kern D E, Singa R M, Shepperd S, Rubin H R. Comprehensive discharge planning with postdischarge support for older patients with congestive heart failure: a meta-analysis. JAMA. 2004;291(11):1358-67. [Rec#: 50905] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 15026403].
Phillips D E. Special care dementia units: the nature of existing knowledge. Perspectives. 96;20(2):9-13. [Rec#: 34376] Exclude at abstract screening: no outcomes specified. [pmid: 8900745].
Phillips R S, Hamel M B, Teno J M, Bellamy P, Broste S K, Califf R M, Vidaillet H, Davis R B, Muhlbaier L H, Connors A F Jr. Race, resource use, and survival in seriously ill hospitalized adults. The SUPPORT Investigators. J Gen Intern Med. 96;11(7):387-96. [Rec#: 6012] Exclude at abstract screening: Other topic only.
Phipps E J, True G, Murray G F. Community perspectives on advance care planning: report from the community ethics program. J Cult Divers. 2003;10(4):118-23. [Rec#: 6016] Exclude at abstract screening: Study Design - Qualitative. [pmid: 15000054].
Pickett M, Barg F K, Lynch M P. Development of a home-based family caregiver cancer education program. Hosp J. 2001;15(4):19-40. [Rec#: 14447] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11876342].
Pickett M. Cultural awareness in the context of terminal illness. Cancer Nurs. 93;16(2):102-6. [Rec#: 14446] Exclude at abstract screening: no outcomes specified. [pmid: 8477396].
Pickett M. Cultural awareness in the context of terminal illness. Cancer Nursing. 93;16(2):102-6. [Rec#: 50673] Exclude at abstract screening: no outcomes specified. [pmid: 8477396].
Pierce S F. Improving end-of-life care: gathering suggestions from family members. Nurs Forum. 99;34(2):5-14. [Rec#: 6020] Exclude at abstract screening: Study Design - Qualitative. [pmid: 10603852].
Piggott M, McGee H, Feuer D. Has CONSORT improved the reporting of randomized controlled trials in the palliative care literature? A systematic review. Palliat Med. 2004;18(1):32-8. [Rec#: 14457] Exclude at abstract screening: useful only for background. [pmid: 14982205].
Pillon L R, Joannides G. An 11-year evaluation of a Living With Cancer program. Oncol Nurs Forum. 91;18(4):707-11. [Rec#: 6030] Exclude at abstract screening: not about end of life. [pmid: 2067960].
Pincombe J, Tooth B. Carers of the terminally ill: an Australian study. Am J Hosp Palliat Care. 96;13(4):44-55. [Rec#: 6035] Exclude at abstract screening: Study Design - Qualitative. [pmid: 8850819].
Pincombe J, Brown M, McCutcheon H. No time for dying: a study of the care of dying patients in two acute care Australian hospitals. J Palliat Care. 2003;19(2):77-86. [Rec#: 6034] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12955923].
Pinderhughes S T, Morrison R S. Evidence-based approach to management of fever in patients with end-stage dementia. Journal of Palliative Medicine. 2003;6(3):351-354. [Rec#: 50674] Exclude at abstract screening: Title Only. [pmid: 14509480].
Piper W E, Ogrodniczuk J S, Joyce A S, McCallum M, Rosie J S. Relationships among affect, work, and outcome in group therapy for patients with complicated grief. Am J Psychother. 2002;56(3):347-61. [Rec#: 6044] Exclude at abstract screening: Study Design - Unclear. [pmid: 12400202].
Pitceathly C, Maguire P. The psychological impact of cancer on patients' partners and other key relatives: a review. European Journal of Cancer. 2003;39(11):1517-24. [Rec#: 50675] Exclude at abstract screening: not about end of life. [pmid: 12855257].
Plataniotis G A, Kouvaris J R, Dardoufas C, Kouloulias V, Theofanopoulou M A, Vlahos L. A short radiotherapy course for locally advanced non-small cell lung cancer (NSCLC): effective palliation and patients' convenience. Lung Cancer. 2002;35(2):203-7. [Rec#: 6055] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 11804694].
Plotkin K, Roche J. The future of home and hospice care. Linking interventions to outcomes. Home Healthc Nurse. 2000;18(7):442-9. quiz 450. [Rec#: 14485] Exclude at abstract screening: no outcomes specified. [pmid: 11951754].
Plunkett T A, Chrystal K F, Harper P G. Quality of life and the treatment of advanced lung cancer. Clin Lung Cancer. 2003;5(1):28-32. [Rec#: 14491] Exclude at abstract screening: no outcomes specified. [pmid: 14596700].
Pohjasvaara T, Ylikoski R, Leskela M, Kalska H, Hietanen M, Kaste M, Erkinjuntti T. Evaluation of various methods of assessing symptoms of cognitive impairment and dementia. Alzheimer Dis Assoc Disord. 2001;15(4):184-93. [Rec#: 34422] Exclude at abstract screening: not about end of life. [pmid: 11723369].
Poirier N. Comparison of CMA joint statement on resuscitative interventions and New Brunswick hospital corporations' policies on end-of-life treatments. J Palliat Care 2000;16(1):15–22. Comment in: J Palliat Care. Autumn. 2000;16(3):55-7. PMID: 11019508 [Rec#: 14495] Exclude at abstract screening: useful only for background.
Polanczyk C A, Newton C, Dec G W, Di Salvo T G. Quality of care and hospital readmission in congestive heart failure: an explicit review process. J Card Fail 2001;7(4):289–98. Comment in: J Card Fail. Dec. 2001;7(4):299-301. PMID: 11782851. [Rec#: 34431] Exclude at abstract screening: not about end of life.
Polednak A P, Shevchenko I P. Hospital charges for terminal care of cancer patients dying before age 65. J Health Care Finance. 98;25(1):26-34. [Rec#: 6067] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Pooler J, McCrory F, Steadman Y, Westwell H, Peers S. Dying at home: a care pathway for the last days of life in a community setting. Int J Palliat Nurs. 2003;9(6):258-64. [Rec#: 14513] Exclude at abstract screening: no outcomes specified. [pmid: 12897698].
Poppel D M, Cohen L M, Germain M. The renal palliative care initiative. Journal of Palliative Care. 2003;6(2):321-326. [Rec#: 50676] Exclude at abstract screening: no outcomes specified.
Porchet-Munro S. Music therapy perspectives in palliative care education. J Palliat Care. 93;9(4):39-42. [Rec#: 14518] Exclude at abstract screening: no outcomes specified. [pmid: 7510803].
Porock D, Kristjanson L J, Tinnelly K, Duke T, Blight J. An exercise intervention for advanced cancer patients experiencing fatigue: a pilot study. J Palliat Care. 2000;16(3):30-6. [Rec#: 6082] Exclude at abstract screening: Study Design - Unclear. [pmid: 11019505].
Porock D, Martin K, Oldham L, Underwood R. Relocation stress syndrome: the case of palliative care patients. Palliat Med. 97;11(6):444-50. [Rec#: 14519] Exclude at abstract screening: no outcomes specified.
Porta M, Busquet X, Jariod M. Attitudes and views of physicians and nurses towards cancer patients dying at home. Palliat Med. 97;11(2):116-26. [Rec#: 6084] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Portenoy R K, Coyle N. Controversies in the long-term management of analgesic therapy in patients with advanced cancer. J Pain Symptom Manage. 90;5(5):307-19. [Rec#: 14522] Exclude at abstract screening: useful only for background.
Portenoy R K. Opioid therapy for chronic nonmalignant pain: clinician's perspective. Journal of Law, Medicine & Ethics. 96;24(4):296-309. [Rec#: 50677] Exclude at abstract screening: no outcomes specified.
Portenoy R K. Pharmacologic management of cancer pain. Seminars in Oncology. 95;22(2 Suppl 3):112-20. [Rec#: 50678] Exclude at abstract screening: no outcomes specified. [pmid: 7537897].
Portnow J, Lim C, Grossman S A. Assessment of pain caused by invasive procedures in cancer patients. Journal of the National Comprehensive Cancer Network. 2003;1(3):435-439. [Rec#: 50680] Exclude at abstract screening: Title Only. [pmid: 19761075].
Porzsolt F, Wirth A, Mayer-Steinacker R, Schulte M, Negri G, Suhr P, Link K H, Gaus W, Rottinger E M. Quality assurance by specification and achievement of goals in palliative cancer treatment. Cancer Treat Rev. 96;22(Suppl A):41-9. [Rec#: 6091] Exclude at abstract screening: Other topic only.
Poses R M, Smith W R, McClish D K, Huber E C, Clemo F L, Schmitt B P, Alexander-Forti D, Racht E M, Colenda C C 3rd, Centor R M. Physicians' survival predictions for patients with acute congestive heart failure. Arch Intern Med. 97;157(9):1001-7. [Rec#: 34458] Exclude at abstract screening: primarily prognosis or trajectories.
Position of The American Dietetic Association: issues in feeding the terminally ill adult. J Am Diet Assoc 92;92(8):996–1002, 1005. [Rec#: 6093] Exclude at abstract screening: Title Only
Post S G. Tube feeding and advanced progressive dementia. Hastings Cent Rep. 2001;31(1):36-42. [Rec#: 6096] Exclude at abstract screening: Title Only. [pmid: 11478092].
Potocky M. Effective services for bereaved spouses: a content analysis of the empirical literature. Health Soc Work. 93;18(4):288-301. [Rec#: 6100] Exclude at abstract screening: Bereavement only. [pmid: 8288152].
Potter J. Fatigue experience in advanced cancer: a phenomenological approach. Int J Palliat Nurs. 2004;10(1):15-23. [Rec#: 6101] Exclude at abstract screening: Study Design - Qualitative. [pmid: 14966441].
Powe B D. Cancer fatalism among elderly Caucasians and African Americans. Oncol Nurs Forum. 95;22(9):1355-9. [Rec#: 6112] Exclude at abstract screening: not about end of life. [pmid: 8539176].
Pozehl B, Duncan K, Krueger S, VerMaas P. Adjunctive effects of exercise training in heart failure patients receiving maximum pharmacologic therapy. Prog Cardiovasc Nurs. 2003;18(4):177-83. [Rec#: 34477] Exclude at abstract screening: not about end of life. [pmid: 14605518].
Preece J. Introducing abdominal massage in palliative care for the relief of constipation. Complement Ther Nurs Midwifery. 2002;8(2):101-5. [Rec#: 14560] Exclude at abstract screening: Study Design - Unclear. [pmid: 12188155].
Prendergast T J. Futility and the common cold. How requests for antibiotics can illuminate care at the end of life. Chest. 95;107(3):836-44. [Rec#: 14563] Exclude at abstract screening: no outcomes specified.
Prendergast T J, Luce J M. Increasing incidence of withholding and withdrawal of life support from the critically ill. American Journal of Respiratory & Critical Care Medicine. 97;155(1):15-20. [Rec#: 50681] Exclude at abstract screening: data older than 1990.
Prendergast T J, Puntillo K A. Withdrawal of life support: intensive caring at the end of life. JAMA. 2002;288(21):2732-40. [Rec#: 50682] Exclude at abstract screening: no outcomes specified. [pmid: 12460097].
Pressley J C, Trott C, Tang M, Durkin M, Stern Y. Dementia in community-dwelling elderly patients: A comparison of survey data, medicare claims, cognitive screening, reported symptoms, and activity limitations. J Clin Epidemiol. 2003;56(9):896-905. [Rec#: 34490] Exclude at abstract screening: useful only for background. [pmid: 14505776].
Prigerson H G, Bierhals A J, Kasl S V, Reynolds C F 3rd, Shear M K, Newsom J T, Jacobs S. Complicated grief as a disorder distinct from bereavement-related depression and anxiety: a replication study. Am J Psychiatry. 96;153(11):1484-6. [Rec#: 6141] Exclude at abstract screening: Bereavement only.
Prigerson H G, Frank E, Kasl S V, Reynolds C F 3rd, Anderson B, Zubenko G S, Houck P R, George C J, Kupfer D J. Complicated grief and bereavement-related depression as distinct disorders: preliminary empirical validation in elderly bereaved spouses. Am J Psychiatry. 95;152(1):22-30. [Rec#: 6144] Exclude at abstract screening: Bereavement only.
Prigerson H G. Determinants of hospice utilization among terminally ill geriatric patients. Home Health Care Serv Q. 91;12(4):81-112. [Rec#: 6139] Exclude at abstract screening: Study Design - Qualitative.
Proctor E K, Morrow-Howell N, Chadiha L, Braverman A C, Darkwa O, Dore P. Physical and cognitive functioning among chronically ill African-American and white elderly in home care following hospital discharge. Med Care. 97;35(8):782-91. [Rec#: 34506] Exclude at abstract screening: not about end of life.
Proctor E K, Morrow-Howell N, Li H, Dore P. Adequacy of home care and hospital readmission for elderly congestive heart failure patients. Health Soc Work 2000; 25(2):87–96. Erratum in: Health Soc Work. Aug. 2000;25(3):168. [Rec#: 50087] In abstract review process.
Prodger N, Hurley J, Clarke C, Bauer D. Queen Elizabeth Behavioural Assessment Graphical System. Aust J Adv Nurs. 92;9(3):4-11. [Rec#: 34507] Exclude at abstract screening: not about end of life. [pmid: 1295511].
Pronovost P, Angus D C. Economics of end-of-life care in the intensive care unit. Crit Care Med. 2001;29(2 Suppl):N46-51. [Rec#: 14586] Exclude at abstract screening: Non-systematic review. [pmid: 11228573].
Proot I M, Abu-Saad H H, Crebolder H F, Goldsteen M, Luker K A, Widdershoven G A. Vulnerability of family caregivers in terminal palliative care at home; balancing between burden and capacity. Scand J Caring Sci. 2003;17(2):113-21. [Rec#: 6165] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12753511].
Proot I M, Abu-Saad H H, ter Meulen R H, Goldsteen M, Spreeuwenberg C, Widdershoven G A. The needs of terminally ill patients at home: directing one's life, health and things related to beloved others. Palliat Med. 2004;18(1):53-61. [Rec#: 6166] Exclude at abstract screening: no outcomes specified. [pmid: 14982208].
Ptacek J T, Ellison N M. Health care providers' perspectives on breaking bad news to patients. Crit Care Nurs Q. 2000;23(2):51-9. [Rec#: 6172] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11853027].
Puchalski C M. Spirituality and end-of-life care: a time for listening and caring. J Palliat Med. 2002;5(2):289-94. [Rec#: 6173] Exclude at abstract screening: Title Only. [pmid: 12006231].
Puchalski C M, Romer A L. Taking a spiritual history allows clinicians to understand patients more fully. Journal of Palliative Medicine. 2000;3:129-137. [Rec#: 50683] Exclude at abstract screening: Title Only. [pmid: 15859737].
Pugh E M. An investigation of general practitioner referrals to palliative care services. Palliat Med. 96;10(3):251-7. [Rec#: 14591] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Puntillo K A, Benner P, Drought T. End of life issues in intensive care units: A national random survey of nurses' knowledge and beliefs. American Journal of Critical Care. 2001;10(4):216-229. [Rec#: 50684] Exclude at abstract screening: Title Only. [pmid: 11432210].
Pusey H, Richards D. A systematic review of the effectiveness of psychosocial interventions for carers of people with dementia. Aging Ment Health. 2001;5(2):107-19. [Rec#: 50147] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 11511058].
QI project improves patient outcomes. Hosp Peer Rev 2002;27(6):77–8. [Rec#: 34528] Exclude at abstract screening: Title Only
Quan K H, Vigano A, Fainsinger R L. Evaluation of a data collection tool (TELEform) for palliative care research. J Palliat Med. 2003;6(3):401-8. [Rec#: 14606] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14509485].
Quddus A M, Kerr G R, Price A, Gregor A. Long-term survival in patients with non-small cell lung cancer treated with palliative radiotherapy. Clin Oncol (R Coll Radiol) 2001;13(2):95–8. Comment in: Clin Oncol (R Coll Radiol). 2001;13(3):202-3. PMID: 11527296. [Rec#: 6190] Exclude at abstract screening: data older than 1990.
Quigley C, Joel S, Patel N, Baksh A, Slevin M. A phase I/II study of nebulized morphine-6-glucuronide in patients with cancer-related breathlessness. Journal of Pain & Symptom Management. 2002;23:7-9. [Rec#: 50685] Exclude at abstract screening: no outcomes specified. [pmid: 11779662].
Quill T E, Barold S S, Sussman B L. Discontinuing an implantable cardioverter defibrillator as a life-sustaining treatment. Am J Cardiol 94;74(2):205–7. Comment in: Am J Cardiol. Mar 1. 1995;75(7):553. PMID: 7864019. [Rec#: 6196] Exclude at abstract screening: Title Only.
Quill T E, Brody H. Physician recommendations and patient autonomy: finding a balance between physician power and patient choice. Annals of Internal Medicine. 96;125(9):763-9. [Rec#: 50687] Exclude at abstract screening: no outcomes specified.
Quill T E, Cassel C K. Nonabandonment: a central obligation for physicians. Annals of Internal Medicine. 95;122(5):368-74. [Rec#: 50688] Exclude at abstract screening: no outcomes specified. [pmid: 7847649].
Quinn D C. Proving the effectiveness of community programs in jeopardy: the role of formative evaluation. Qual Manag Health Care. 2001;9(4):33-46. [Rec#: 34543] Exclude at abstract screening: not about end of life. [pmid: 11499350].
Quittan M, Sturm B, Wiesinger G F, Pacher R, Fialka-Moser V. Quality of life in patients with chronic heart failure: a randomized controlled trial of changes induced by a regular exercise program. Scand J Rehabil Med. 99;31(4):223-8. [Rec#: 34547] Exclude at abstract screening: not about end of life.
Rabady S. Influence of gender on the provision of palliative care. Eur J Gen Pract. 2003;9(3):101-2. [Rec#: 14622] Exclude at abstract screening: Title Only. [pmid: 14712910].
Rabey J M, Neufeld M Y, Treves T A, Sifris P, Korczyn A D. Cognitive effects of scopolamine in dementia. J Neural Transm Gen Sect. 96;103(7):873-81. [Rec#: 34554] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Rabow M W, Petersen J J, Schanche K. Volunteer patient advocacy: an interdisciplinary course on attending to patients at the end of life. J Palliat Med. 2002;5(5):754-5. [Rec#: 14625] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12572979].
Rabow M W, Schanche K, Petersen J, Dibble S L, McPhee S J. Patient perceptions of an outpatient palliative care intervention: “It had been on my mind before, but I did not know how to start talking about death…”. J Pain Symptom Manage. 2003;26(5):1010-5. [Rec#: 6212] Exclude at abstract screening: Study Design - Qualitative. [pmid: 14585552].
Radbruch L, Nauck F, Ostgathe C, Elsner F, Bausewein C, Fuchs M, Lindena G, Neuwohner K, Schulenberg D. What are the problems in palliative care? Results from a representative survey. Support Care Cancer. 2003;11(7):442-51. [Rec#: 14627] Exclude at abstract screening: Other topic only. [pmid: 12774219].
Radzewitz A, Miche E, Herrmann G, Nowak M, Montanus U, Adam U, Stockmann Y, Barth M. Exercise and muscle strength training and their effect on quality of life in patients with chronic heart failure. Eur J Heart Fail. 2002;4(5):627-34. [Rec#: 34563] Exclude at abstract screening: not about end of life. [pmid: 12413507].
Rainville E C. Impact of pharmacist interventions on hospital readmissions for heart failure. Am J Health Syst Pharm. 99;56(13):1339-42. [Rec#: 34575] Exclude at abstract screening: Title Only. [pmid: 10683133].
Randall-David E, Wright J, Porterfield D S, Lesser G. Barriers to cancer pain management: home-health and hospice nurses and patients. Support Care Cancer. 2003;11(10):660-5. [Rec#: 6247] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12898368].
Ransford H E, Smith M L. Grief resolution among the bereaved in hospice and hospital wards. Soc Sci Med. 91;32(3):295-304. [Rec#: 14655] Exclude at abstract screening: Bereavement only. [pmid: 2024139].
Ranson M R, White S, Thatcher N. Management of elderly patients with lung cancer. Curr Oncol Rep. 2000;2(1):90-5. [Rec#: 34590] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 11122829].
Raphaely D. Informed consent near death: myth and actuality. Fam Syst Med. 91;9(4):343-70. [Rec#: 14658] Exclude at abstract screening: Title Only. [pmid: 11660608].
Rasmussen B H, Sandman P O. How patients spend their time in a hospice and in an oncological unit. J Adv Nurs. 98;28(4):818-28. [Rec#: 6269] Exclude at abstract screening: Other topic only. [pmid: 9829671].
Rasmussen B H, Jansson L, Norberg A. Striving for becoming at-home in the midst of dying. Am J Hosp Palliat Care. 2000;17(1):31-43. [Rec#: 6267] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11094918].
Rathore S S, Foody J M, Wang Y, Smith G L, Herrin J, Masoudi F A, Wolfe P, Havranek E P, Ordin D L, Krumholz H M. Race, quality of care, and outcomes of elderly patients hospitalized with heart failure. JAMA 2003;289(19):2517–24. Comment in: JAMA. Sep 10. 2003;290(10):1316. author reply 1316–7. PMID: 12966121. [Rec#: 34605] Exclude at abstract screening: not about end of life.
Raudonis B M, Kirschling J M. Family caregivers' perspectives on hospice nursing care. J Palliat Care. 96;12(2):14-9. [Rec#: 14670] Exclude at abstract screening: Study Design - Qualitative. [pmid: 8708845].
Raudonis B M. The meaning and impact of empathic relationships in hospice nursing. Cancer Nurs. 93;16(4):304-9. [Rec#: 6282] Exclude at abstract screening: Observational study. [pmid: 8402607].
Ravenscroft A J, Bell M D. ‘End-of-life’ decision making within intensive care--objective, consistent, defensible?. Journal of Medical Ethics. 2000;26(6):435-40. [Rec#: 50690] Exclude at abstract screening: Study Design - Unclear. [pmid: 11129843].
Raynes N V, Leach J, Rawlings B, Bryson R J. Palliative care services: views of terminally ill patients. Palliat Med. 2000;14(2):159-60. [Rec#: 6296] Exclude at abstract screening: no outcomes specified. [pmid: 10829151].
Raynes N V, Leach J M, Rawlings B, Bryson R J. Using focus groups to seek the views of patients dying from cancer about the care they receive. Health Expect. 2000;3(3):169-175. [Rec#: 6297] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11281926].
Razavi D, Merckaert I, Marchal S, Libert Y, Conradt S, Boniver J, Etienne A M, Fontaine O, Janne P, Klastersky J, Reynaert C, Scalliet P, Slachmuylder J L, Delvaux N. How to optimize physicians' communication skills in cancer care: results of a randomized study assessing the usefulness of posttraining consolidation workshops. Journal of Clinical Oncology. 2003;21(16):3141-9. [Rec#: 50691] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12915605].
Readmission analysis leads to heart failure intervention that cuts returns to hospital. Data Strateg Benchmarks 2000;4(4):53–4. [Rec#: 50088] Exclude at abstract screening: Title Only
Rector T S, Johnson G, Dunkman W B, Daniels G, Farrell L, Henrick A, Smith B, Cohn J N. Evaluation by patients with heart failure of the effects of enalapril compared with hydralazine plus isosorbide dinitrate on quality of life. V-HeFT II. The V-HeFT VA Cooperative Studies Group. Circulation. 93;87(6 Suppl):VI71-7. [Rec#: 34621] Exclude at abstract screening: not about end of life.
Rector T S. Effect of ACE inhibitors on the quality of life of patients with heart failure. Coron Artery Dis. 95;6(4):310-4. [Rec#: 34618] Exclude at abstract screening: not about end of life. [pmid: 7655714].
Rector T S. Outcome assessment: functional status measures as therapeutic endpoints for heart failure. Top Hosp Pharm Manage. 90;10(2):37-43. [Rec#: 34619] Exclude at abstract screening: no outcomes specified.
Redd W H, Montgomery G H, DuHamel K N. Behavioral intervention for cancer treatment side effects. J Natl Cancer Inst. 2001;93(11):810-23. [Rec#: 50148] Exclude at abstract screening: Non-systematic review. [pmid: 11390531].
Reddy P, Dunn A B. The effect of beta-blockers on health-related quality of life in patients with heart failure. Pharmacotherapy. 2000;20(6):679-89. [Rec#: 34625] Exclude at abstract screening: not about end of life. [pmid: 10853624].
Redfield M M. The Breathing Not Proper trial: enough evidence to change heart failure guidelines?. J Card Fail. 2002;8(3):120-3. [Rec#: 34626] Exclude at abstract screening: not about end of life. [pmid: 12140802].
Reed P G. Preferences for spiritually related nursing interventions among terminally ill and nonterminally ill hospitalized adults and well adults. Appl Nurs Res. 91;4(3):122-8. [Rec#: 6319] Exclude at abstract screening: Other topic only.
Rees W D. Opioid needs of terminal care patients: variations with age and primary site. Clin Oncol (R Coll Radiol). 90;2(2):79-83. [Rec#: 6324] Exclude at abstract screening: Study Design - Unclear.
Reese D, Raymer M, Richardson J. National hospice social work survery: Summary of final results. 2000;<25 Page(s)>. [Rec#: 50692] Exclude at abstract screening: Title Only
Reese D J, Brown D R. Psychosocial and spiritual care in hospice: differences between nursing, social work, and clergy. Hosp J. 97;12(1):29-41. [Rec#: 14705] Exclude at abstract screening: Study Design - Unclear.
Reese D J, Ahern R E, Nair S, O'Faire J D, Warren C. Hospice access and use by African Americans: addressing cultural and institutional barriers through participatory action research. Soc Work. 99;44(6):549-59. [Rec#: 14704] Exclude at abstract screening: Study Design - Qualitative.
Reese R, Rosenfeld-Bernstein R. Hospice in a managed care environment: an integrated team approach. Health Care Innov. 95;5(2):35-40. [Rec#: 6327] Exclude at abstract screening: Title Only. [pmid: 10151082].
Reeves R R, Reynolds M. Spirituality and end-of-life care. Journal of the American Osteopathic Association. 2002;102(2):67. [Rec#: 50693] Exclude at abstract screening: Title Only. [pmid: 11866393].
Regan J, Yarnold J, Jones P W, Cooke N T. Palliation and life quality in lung cancer; how good are clinicians at judging treatment outcome?. Br J Cancer. 91;64(2):396-400. [Rec#: 34629] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Reid, C. M., Davies, A. N., and Hanks, G. W. Oxycodone for cancer-related pain. The Cochrane Library 2003;3. [Rec#: 50694] Exclude at abstract screening: Title Only
Reilly R B, Teasdale T A, McCullough L B. Projecting patients' preferences from living wills: an invalid strategy for management of dementia with life-threatening illness. J Am Geriatr Soc 94;42(9):997–1003. Comment in: J Am Geriatr Soc. Aug. 1995;43(8):938-9. PMID: 7636106. [Rec#: 6345] Exclude at abstract screening: not about end of life.
Reis S E, Holubkov R, Edmundowicz D, McNamara D M, Zell K A, Detre K M, Feldman A M. Treatment of patients admitted to the hospital with congestive heart failure: specialty-related disparities in practice patterns and outcomes. J Am Coll Cardiol. 97;30(3):733-8. [Rec#: 50089] Exclude at abstract screening: Title Only.
Reisberg B, Finkel S, Overall J, Schmidt-Gollas N, Kanowski S, Lehfeld H, Hulla F, Sclan S G, Wilms H U, Heininger K, Hindmarch I, Stemmler M, Poon L, Kluger A, Cooler C, Bergener M, Hugonot-Diener L, Robert P H, Antipolis S, Erzigkeit H. The Alzheimer's disease activities of daily living international scale (ADL-IS). Int Psychogeriatr. 2001;13(2):163-81. [Rec#: 34643] Exclude at abstract screening: not about end of life. [pmid: 11495392].
Rempusheski V F, Hurley A C. Advance directives and dementia. J Gerontol Nurs. 2000;26(10):27-34. [Rec#: 6355] Exclude at abstract screening: useful only for background. [pmid: 11883496].
Rhymes J A. Barriers to effective palliative care of terminal patients. An international perspective. Clin Geriatr Med. 96;12(2):407-16. [Rec#: 14736] Exclude at abstract screening: useful only for background.
Riantawan P, Titayanpong A, Chaisuksuwan R. Survival in patients with advanced non-small-cell lung cancer receiving supportive care. J Med Assoc Thai. 99;82(4):336-40. [Rec#: 6393] Notes: “EXCLUDE: Location, non-Western”. [pmid: 10410493].
Ribeiro, M. D. C. and Zeppetella, G. Fentanyl for chronic pain. The Cochrane Library 2003;3. [Rec#: 50695] Exclude at abstract screening: Title Only
Rice A. Sexuality in cancer and palliative care 1: Effects of disease and treatment. Int J Palliat Nurs. 2000;6(8):392-7. [Rec#: 14741] Exclude at abstract screening: useful only for background. [pmid: 12411851].
Rice D P, Fineman N. Economic implications of increased longevity in the United States. Annu Rev Public Health. 2004;25:457-73. [Rec#: 6400] Exclude at abstract screening: useful only for background. [pmid: 15015930].
Rich M W, Vinson J M, Sperry J C, Shah A S, Spinner L R, Chung M K, Davila-Roman V. Prevention of readmission in elderly patients with congestive heart failure: results of a prospective, randomized pilot study. J Gen Intern Med. 93;8(11):585-90. [Rec#: 50091] Exclude at abstract screening: not about end of life.
Rich M W. Heart failure disease management: a critical review. J Card Fail. 99;5(1):64-75. [Rec#: 34662] Exclude at abstract screening: not about end of life. [pmid: 10194662].
Rich M W. Heart failure in the elderly: strategies to optimize outpatient control and reduce hospitalizations. Am J Geriatr Cardiol. 2003;12(1):19-24. quiz 25–7. [Rec#: 50090] Exclude at abstract screening: Title Only. [pmid: 12502911].
Richards W R, Burgess D E, Petersen F R, McCarthy D L. Genograms: a psychosocial assessment tool for hospice. Hosp J. 93;9(1):1-12. [Rec#: 14751] Exclude at abstract screening: no outcomes specified. [pmid: 8406398].
Richards K C, Gibson R, Overton-McCoy A L. Effects of massage in acute and critical care. AACN Clin Issues. 2000;11(1):77-96. [Rec#: 50149] Exclude at abstract screening: not about end of life. [pmid: 11040555].
Richardson A, Lee L, Birchall M. Learning from patients with cancer and their spouses: a focus group study. J Laryngol Otol. 2002;116(12):1028-35. [Rec#: 14752] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12537617].
Richardson J. Health promotion in palliative care: the patients' perception of therapeutic interaction with the palliative nurse in the primary care setting. J Adv Nurs. 2002;40(4):432-40. [Rec#: 6416] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12421402].
Richardson L G. Psychosocial issues in patients with congestive heart failure. Prog Cardiovasc Nurs. 2003;18(1):19-27. [Rec#: 34670] Exclude at abstract screening: no outcomes specified. [pmid: 12624569].
Richter J, Eisemann M, Zgonnikova E. Doctors' authoritarianism in end-of-life treatment decisions. A comparison between Russia, Sweden and Germany. J Med Ethics. 2001;27(3):186-91. [Rec#: 6421] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11417027].
Richter J M, Roberto K A, Bottenberg D J. Communicating with persons with Alzheimer's disease: experiences of family and formal caregivers. Arch Psychiatr Nurs. 95;9(5):279-85. [Rec#: 34672] Exclude at abstract screening: not about end of life.
Rideout E. Chronic heart failure and quality of life: the impact of nursing. Can J Cardiovasc Nurs. 92;3(1):4-8. [Rec#: 34673] Exclude at abstract screening: not about end of life. [pmid: 1290581].
Riedinger M S, Dracup K A, Brecht M L. Predictors of quality of life in women with heart failure. SOLVD Investigators. Studies of Left Ventricular Dysfunction. J Heart Lung Transplant. 2000;19(6):598-608. [Rec#: 34676] Exclude at abstract screening: not about end of life. [pmid: 10867341].
Riedinger M S, Dracup K A, Brecht M L. SOLVD Investigatos. Studies of Left Ventricular Dysfunction. Quality of life in women with heart failure, normative groups, and patients with other chronic conditions. Am J Crit Care. 2002;11(3):211-9. [Rec#: 34678] Exclude at abstract screening: not about end of life. [pmid: 12022484].
Riedinger M S, Dracup K A, Brecht M L, Padilla G, Sarna L, Ganz P A. Quality of life in patients with heart failure: do gender differences exist?. Heart Lung. 2001;30(2):105-16. [Rec#: 34677] Exclude at abstract screening: not about end of life. [pmid: 11248713].
Riegel B, Bennett J A, Davis A, Carlson B, Montague J, Robin H, Glaser D. Cognitive impairment in heart failure: issues of measurement and etiology. Am J Crit Care. 2002;11(6):520-8. [Rec#: 34679] Exclude at abstract screening: not about end of life. [pmid: 12425402].
Riegel B, Moser D K, Carlson B, Deaton C, Armola R, Sethares K, Shively M, Evangelista L, Albert N. Gender differences in quality of life are minimal in patients with heart failure. J Card Fail. 2003;9(1):42-8. [Rec#: 34683] Exclude at abstract screening: not about end of life. [pmid: 12612872].
Riegel B, Moser DK, Glaser D, Carlson B, Deaton C, Armola R, Sethares K, Shively M, Evangelista L, and Albert N. The Minnesota Living With Heart Failure Questionnaire: sensitivity to differences and responsiveness to intervention intensity in a clinical population. Nurs Res 2002;51(4):209–18. Erratum in: Nurs Res 2002 Sep-Oct;51(5):291. [Rec#: 34684] Exclude at abstract screening: Title Only
Riegel B, Naylor M, Stewart S, McMurray J J, Rich M W. Interventions to prevent readmission for congestive heart failure. JAMA. 2004;291(23):2816. author reply 2816–7. [Rec#: 50888] Exclude at abstract screening: no outcomes specified. [pmid: 15199026].
Riley G F, Potosky A L, Lubitz J D, Kessler L G. Medicare payments from diagnosis to death for elderly cancer patients by stage at diagnosis. Medical Care. 95;33(8):828-41. [Rec#: 50696] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Ringbaek T J, Viskum K, Lange P. Non-continuous home oxygen therapy: utilization, symptomatic effect and prognosis, data from a national register on home oxygen therapy. Respir Med. 2001;95(12):980-5. [Rec#: 34696] Exclude at abstract screening: not about end of life. [pmid: 11778796].
Ringdal G I, Jordhoy M S, Kaasa S. Measuring quality of palliative care: psychometric properties of the FAMCARE Scale. Qual Life Res. 2003;12(2):167-76. [Rec#: 6434] Exclude at abstract screening: Title Only. [pmid: 12639063].
Ringdal G I, Jordhoy M S, Ringdal K, Kaasa S. Factors affecting grief reactions in close family members to individuals who have died of cancer. J Pain Symptom Manage. 2001;22(6):1016-26. [Rec#: 6435] Exclude at abstract screening: Bereavement only. [pmid: 11738164].
Ringdal G I, Jordhoy M S, Ringdal K, Kaasa S. The first year of grief and bereavement in close family members to individuals who have died of cancer. Palliat Med. 2001;15(2):91-105. [Rec#: 6436] Exclude at abstract screening: Bereavement only. [pmid: 11301674].
Ripamonti C, Bruera E. Dyspnea: pathophysiology and assessment. Journal of Pain & Symptom Management. 97;13(4):220-32. [Rec#: 50697] Exclude at abstract screening: Study Design - Unclear. [pmid: 9136233].
Ripamonti C, Bruera E. Rectal, buccal, and sublingual narcotics for the management of cancer pain. Journal of Palliative Care. 91;7(1):30-5. [Rec#: 50698] Exclude at abstract screening: Study Design - Unclear.
Ripamonti C, Fulfaro F. Pathogenesis and pharmacological treatment of bone pain in skeletal metastases. Quarterly Journal of Nuclear Medicine. 2001;45(1):65-77. [Rec#: 50700] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11456377].
Ripamonti C, Fusco F. Respiratory problems in advanced cancer. Supportive Care in Cancer. 2002;10(3):204-16. [Rec#: 50703] Exclude at abstract screening: Non-systematic review. [pmid: 11904785].
Ripamonti C, De Conno F, Groff L, Belzile M, Pereira J, Hanson J, Bruera E. Equianalgesic dose/ratio between methadone and other opioid agonists in cancer pain: comparison of two clinical experiences. Annals of Oncology. 98;9(1):79-83. [Rec#: 50699] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Ripamonti C, Fulfaro F, Bruera E. Dyspnoea in patients with advanced cancer: incidence, causes and treatments. Cancer Treatment Reviews. 98;24(1):69-80. [Rec#: 50701] Exclude at abstract screening: Title Only. [pmid: 9606369].
Ripamonti C, Fulfaro F, Ticozzi C, Casuccio A, De Conno F. Role of pamidronate disodium in the treatment of metastatic bone disease. Tumori. 98;84(4):442-55. [Rec#: 50702] Exclude at abstract screening: Study Design - Review/Meta.
Rittman M, Paige P, Rivera J, Sutphin L, Godown I. Phenomenological study of nurses caring for dying patients. Cancer Nurs. 97;20(2):115-9. [Rec#: 14773] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Rivera S, Kim D, Garone S, Morgenstern L, Mohsenifar Z. Motivating factors in futile clinical interventions. Chest. 2001;119(6):1944-7. [Rec#: 6444] Exclude at abstract screening: Title Only. [pmid: 11399728].
Robbins M A, Jackson P, Prentice A. Statutory and voluntary sector palliative care in the community setting: National Health Service professionals' perceptions of the interface. Eur J Cancer Care (Engl). 96;5(2):96-102. [Rec#: 14785] Exclude at abstract screening: useful only for background.
Robbins, M. Evaluating Palliative Care: Establishing the Evidence Base. 1998;<25 Page(s)>. [Rec#: 50704] Exclude at abstract screening: Title Only
Robert Wood Johnson Foundation. ESRD Workgroup Final Report Summary on End-of-Life Care: recommendations to the field. Nephrol Nurs J. 2003;30(1):59-63. [Rec#: 14787] Exclude at abstract screening: no outcomes specified. [pmid: 12674951].
Roberts D K, Thorne S E, Pearson C. The experience of dyspnea in late-stage cancer. Patients' and nurses' perspectives. Cancer Nurs. 93;16(4):310-20. [Rec#: 6453] Exclude at abstract screening: Study Design - Unclear.
Roberts J, Browne G, Gafni A, Varieur M, Loney P, De Ruijter M. Specialized continuing are models for persons with dementia: a systematic review of the research literature. Canadian Journal on Aging. 2000;19(1):106-126. [Rec#: 50853] Exclude at abstract screening: Study Design - Review/Meta.
Roberts S L, Johnson L H, Keely B. Fostering hope in the elderly congestive heart failure patient in critical care. Geriatr Nurs. 99;20(4):195-9. [Rec#: 34719] Exclude at abstract screening: no outcomes specified.
Roberts, L., Ahmed, I., and Hall, S. Intercessory prayer for the alleviation of ill health. Cochrane Database of Systematic Reviews 2003;3. [Rec#: 50705] Exclude at abstract screening: Title Only
Roberts S, Black C, Todd K. The Living with Cancer Education Programme. II. Evaluation of an Australian education and support programme for cancer patients and their family and friends. European Journal of Cancer Care. 2002;11(4):280-9. [Rec#: 50706] Exclude at abstract screening: not about end of life. [pmid: 12492465].
Robertson G S. Resuscitation and senility: a study of patients' opinions. J Med Ethics 93;19(2):104–7. Comment in: J Med Ethics. Mar. 1994;20(1):53. PMID: 8035443. [Rec#: 6460] Exclude at abstract screening: not about end of life.
Robinson B E, Pham H. Cost-effectiveness of hospice care. Clin Geriatr Med. 96;12(2):417-28. [Rec#: 14800] Exclude at abstract screening: useful only for background. [pmid: 8799358].
Robinson E M. Wives' struggle in living through treatment decisions for husbands with advanced Alzheimer's disease. J Nurs Law. 2000;7(1):21-39. [Rec#: 6463] Exclude at abstract screening: Title Only. [pmid: 12545984].
Robinson L, Stacy R. Palliative care in the community: setting practice guidelines for primary care teams. Br J Gen Pract 94;44(387):461–4. Comment in: Br J Gen Pract. Jun. 1995;45(395):327. PMID: 7619594. [Rec#: 14805] Exclude at abstract screening: useful only for background.
Robinson W R, Morris K, Luck M, Pruitt B. Hospice utilization by male and female cancer patients in an end-of-life transition program. J Am Med Womens Assoc. 2002;57(2):82-4. [Rec#: 6474] Exclude at abstract screening: Other topic only. [pmid: 11991426].
Robinson K, Bruera E. The management of pain in patients with advanced cancer: the importance of multidimensional assessments. Journal of Palliative Care. 95;11(4):51-3. [Rec#: 50707] Exclude at abstract screening: Study Design - Unclear.
Rocha E. Prediction of hospital readmission for heart failure: development of a simple risk score based on administrative data. Rev Port Cardiol. 99;18(9):855-6. [Rec#: 50092] Exclude at abstract screening: Title Only. [pmid: 10610100].
Rock W. Interdisciplinary teamwork in palliative care and hospice settings. Am J Hosp Palliat Care. 2003;20(5):331-3. [Rec#: 14814] Exclude at abstract screening: Title Only. [pmid: 14529033].
Rocke C, Cherry K E. Death at the end of the 20th century: individual processes and developmental tasks in old age. Int J Aging Hum Dev. 2002;54(4):315-33. [Rec#: 6477] Exclude at abstract screening: no outcomes specified. [pmid: 12243449].
Rocker G, Heyland D. New research initiatives in Canada for end-of-life and palliative care. CMAJ 2003;169(4):300–1. Comment in: CMAJ. Feb 3. 2004;170(3):319-20. author reply 320. PMID: 14757654. [Rec#: 14816] Exclude at abstract screening: useful only for background.
Rockwood K, Graham J E, Fay S. ACADIE Investigators. Goal setting and attainment in Alzheimer's disease patients treated with donepezil. J Neurol Neurosurg Psychiatry 2002;73(5):500–7. Comment in: J Neurol Neurosurg Psychiatry. Nov. 2002;73(5):471-2. PMID: 12397135. [Rec#: 34730] Exclude at abstract screening: not about end of life.
Rockwood K. Delays in the discharge of elderly patients. J Clin Epidemiol. 90;43(9):971-5. [Rec#: 34728] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 2170587].
Rodgers L S. Meaning of bereavement among older African American widows. Geriatr Nurs. 2004;25(1):10-6. [Rec#: 6481] Exclude at abstract screening: useful only for background. [pmid: 14976498].
Rogatz P, Schwartz F, Dennis J. A community-based hospice program. N Y State J Med. 91;91(11):500-2. [Rec#: 14825] Exclude at abstract screening: Title Only. [pmid: 1771046].
Rogers A, Addington-Hall J M, McCoy A S, Edmonds P M, Abery A J, Coats A J, Gibbs J S. A qualitative study of chronic heart failure patients' understanding of their symptoms and drug therapy. Eur J Heart Fail. 2002;4(3):283-7. [Rec#: 34750] Exclude at abstract screening: not about end of life. [pmid: 12034153].
Rogers A, Karlsen S, Addington-Hall J M. Dying for care: the experiences of terminally ill cancer patients in hospital in an inner city health district. Palliat Med. 2000;14(1):53-4. [Rec#: 14827] Exclude at abstract screening: Title Only. [pmid: 10717722].
Rogers A E, Addington-Hall J M, Abery A J, McCoy A S, Bulpitt C, Coats A J, Gibbs J S. Knowledge and communication difficulties for patients with chronic heart failure: qualitative study. BMJ. 2000;321(7261):605-7. [Rec#: 34751] Exclude at abstract screening: Observational study. [pmid: 10977838]. [pmcid: 27476].
Rogers M S, Barclay S I, Todd C J. Developing the Cambridge palliative audit schedule (CAMPAS): a palliative care audit for primary health care teams. Br J Gen Pract. 98;48(430):1224-7. [Rec#: 14829] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Rogers W J, Johnstone D E, Yusuf S, Weiner D H, Gallagher P, Bittner V A, Ahn S, Schron E, Shumaker S A, Sheffield L T. Quality of life among 5,025 patients with left ventricular dysfunction randomized between placebo and enalapril: the Studies of Left Ventricular Dysfunction. The SOLVD Investigators. J Am Coll Cardiol. 94;23(2):393-400. [Rec#: 34756] Exclude at abstract screening: not about end of life.
Rolland J S. Anticipatory loss: a family systems developmental framework. Fam Process. 90;29(3):229-44. [Rec#: 6496] Exclude at abstract screening: not about end of life. [pmid: 2209827].
Romanowski J, Barnes N G. Attributes to consider in the marketing of hospice services. Health Mark Q. 94;12(1):37-47. [Rec#: 14836] Exclude at abstract screening: Title Only. [pmid: 10139721].
Ronaldson S, Devery K. The experience of transition to palliative care services: perspectives of patients and nurses. Int J Palliat Nurs. 2001;7(4):171-7. [Rec#: 6501] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11951284].
Rooda L A, Clements R, Jordan M L. Nurses' attitudes toward death and caring for dying patients. Oncol Nurs Forum 99;26(10):1683–7. Comment in: Oncol Nurs Forum. May. 2000;27(4):601. PMID: 10833682. [Rec#: 6502] Exclude at abstract screening: Study Design - Qualitative.
Rose K. How informal carers cope with terminal cancer. Nurs Stand. 97;11(30):39-42. [Rec#: 6508] Exclude at abstract screening: Study Design - Qualitative. [pmid: 9165899].
Rose K E. A qualitative analysis of the information needs of informal carers of terminally ill cancer patients. J Clin Nurs. 99;8(1):81-8. [Rec#: 14846] Exclude at abstract screening: Study Design - Qualitative.
Rose K E. Perceptions related to time in a qualitative study of informal carers of terminally ill cancer patients. J Clin Nurs. 98;7(4):343-50. [Rec#: 6509] Exclude at abstract screening: no outcomes specified.
Rosen J, Mittal V, Mulsant B H, Degenholtz H, Castle N, Fox D. Educating the families of nursing home residents: a pilot study using a computer-based system. J Am Med Dir Assoc. 2003;4(3):128-34. [Rec#: 34774] Exclude at abstract screening: Observational study. [pmid: 12854985].
Rosenbaum E, Gautier H, Fobair P, Andrews A, Hawn M, Kurshner R, Festa B, Kramer P, Manuel F, Hirschberger N, Selim S, Spiegel D. Developing a free supportive care program for cancer patients within an integrative medicine clinic. Support Care Cancer. 2003;11(5):263-9. [Rec#: 6513] Exclude at abstract screening: no outcomes specified. [pmid: 12690540].
Rosenblatt L, Block S D. Depression, decision making, and the cessation of life-sustaining treatment. West J Med. 2001;175(5):320-5. [Rec#: 6515] Exclude at abstract screening: Title Only. [pmid: 11694480]. [pmcid: 1071609].
Rosenfeld K, Wenger N S. Measuring quality in end-of-life care. Clin Geriatr Med. 2000;16(2):387-400. [Rec#: 14859] Exclude at abstract screening: useful only for background. [pmid: 10783435].
Rosenfeld K E, Wenger N S, Kagawa-Singer M. End-of-life decision making: a qualitative study of elderly individuals. J Gen Intern Med 2000;15(9):620–5. Comment in: J Gen Intern Med. Sep. 2000;15(9):673-4. PMID: 11029683. [Rec#: 6518] Exclude at abstract screening: Study Design - Qualitative.
Rosenquist A, Bergman K, Strang P. Optimizing hospital-based home care for dying cancer patients: a population-based study. Palliat Med. 99;13(5):393-7. [Rec#: 6519] Exclude at abstract screening: Study Design - Unclear.
Rosin A J, Sonnenblick M. Autonomy and paternalism in geriatric medicine. The Jewish ethical approach to issues of feeding terminally ill patients, and to cardiopulmonary resuscitation. J Med Ethics. 98;24(1):44-8. [Rec#: 6523] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Ross C, Cornbleet M. Attitudes of patients and staff to research in a specialist palliative care unit. Palliat Med. 2003;17(6):491-7. [Rec#: 6525] Exclude at abstract screening: not about end of life. [pmid: 14526881].
Ross C S, Hamilton J, Macrae G, Docherty C, Gould A, Cornbleet M A. A pilot study to evaluate the effect of reflexology on mood and symptom rating of advanced cancer patients. Palliat Med. 2002;16(6):544-5. [Rec#: 6526] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12465705].
Ross L A. Elderly patients' perceptions of their spiritual needs and care: a pilot study. J Adv Nurs. 97;26(4):710-5. [Rec#: 6529] Exclude at abstract screening: Study Design - Qualitative. [pmid: 9354982].
Ross M M, McDonald B. Providing palliative care to older adults: context and challenges. J Palliat Care. 94;10(4):5-10. [Rec#: 6532] Exclude at abstract screening: Study Design - Qualitative. [pmid: 7535351].
Ross M M, Fisher R, Maclean M J. End-of-life care for seniors: the development of a national guide. J Palliat Care. 2000;16(4):47-53. [Rec#: 6531] Exclude at abstract screening: Title Only. [pmid: 11965935].
Rossi Ferrario S, Cardillo V, Vicario F, Balzarini E, Zotti A M. Advanced cancer at home: caregiving and bereavement. Palliat Med. 2004;18(2):129-36. [Rec#: 6537] Exclude at abstract screening: Bereavement only. [pmid: 15046409].
Roter D L, Larson S, Fischer G S, Arnold R M, Tulsky J A. Experts practice what they preach: A descriptive study of best and normative practices in end-of-life discussions. Arch Intern Med. 2000;160(22):3477-85. [Rec#: 6541] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11112242].
Roth A J, Breitbart W. Psychiatric emergencies in terminally ill cancer patients. Hematol Oncol Clin North Am. 96;10(1):235-59. [Rec#: 14876] Exclude at abstract screening: no outcomes specified. [pmid: 8821570].
Roush C V, Cox J E. The meaning of home: how it shapes the practice of home and hospice care. Home Healthc Nurse. 2000;18(6):388-94. [Rec#: 34800] Exclude at abstract screening: no outcomes specified. [pmid: 11951299].
Rousseau P. Palliative care in managed Medicare: reasons for hope--and for concern. Geriatrics 98;53(11):59–60, 63–5; quiz 66. [Rec#: 6558] Exclude at abstract screening: no outcomes specified
Rowa-Dewar N. Do interventions make a difference to bereaved parents? A systematic review of controlled studies. Int J Palliat Nurs. 2002;8(9):452-7. [Rec#: 14891] Exclude at abstract screening: Bereavement only. [pmid: 12362126].
Rowan M S, Lawson B, MacLean C, Burge F. Upholding the principles of primary care in preceptors' practices. Family Medicine. 2002;34(10):744-9. [Rec#: 50709] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12448644].
Rowbotham M C, Twilling L, Davies P S, Reisner L, Taylor K, Mohr D. Oral opioid therapy for chronic peripheral and central neuropathic pain. [see comment]. New England Journal of Medicine. 2003;348(13):1223-32. [Rec#: 50710] Exclude at abstract screening: not about end of life. [pmid: 12660386].
Rozans M, Dreisbach A, Lertora J, Kahn M. Palliative uses of methylphenidate in patients with cancer: a review. Journal of Clinical Oncology. 2002;20:335-339. [Rec#: 50711] Exclude at abstract screening: Title Only. [pmid: 11773187].
Rubenfeld G D, Curtis J R. Improving care for patients dying in the intensive care unit. Clin Chest Med. 2003;24(4):763-73. [Rec#: 14899] Exclude at abstract screening: no outcomes specified. [pmid: 14710703].
Rubenfeld G D, Randall Curtis J. End-of-Life Care in the ICU Working Group. End-of-life care in the intensive care unit: a research agenda. Crit Care Med 2001;29(10):2001–6. Comment in: Crit Care Med. 2001 Oct;29(10):2037–8. PMID: 11588487. Comment in: Crit Care Med. Nov. 2002;30(11):2612-3. author reply 2613. PMID: 12441792. [Rec#: 14900] Exclude at abstract screening: useful only for background.
Rubenfeld G D, Randall Curtis J. The End-of-Life Care in the, I. C. U. Working Group. End-of-life care in the intensive care unit: a research agenda. Critical Care Medicine. 2001;29(10):2001-6. [Rec#: 50712] Exclude at abstract screening: Duplicate already in the flow. [pmid: 11588471].
Rubenstein L V, Kahn K L, Reinisch E J, Sherwood M J, Rogers W H, Kamberg C, Draper D, Brook R H. Changes in quality of care for five diseases measured by implicit review, 1981 to 1986. JAMA 90;264(15):1974–9. Comment in: JAMA. Oct 17. 1990;264(15):1995-6. PMID: 2120479. [Rec#: 34811] Exclude at abstract screening: not about end of life.
Rubenstein SA. Improving access to supportive therapies for cancer patients. Health Care Innov 95; 5(3):25–9, 36. [Rec#: 14905] Exclude at abstract screening: Title Only
Rubenstein L Z, Schairer C, Wieland G D, Kane R. Systematic biases in functional status assessment of elderly adults: effects of different data sources. J Gerontol. 84;39(6):686-91. [Rec#: 50880] Exclude at abstract screening: not about end of life.
Rudberg M A, Teno J M, Lynn J. Developing and implementing measures of quality of care at the end of life: a call for action. J Am Geriatr Soc 97;45(4):528–30. Comment on: J Am Geriatr Soc. Apr. 1997;45(4):526-7. PMID: 9100727. [Rec#: 14908] Exclude at abstract screening: no outcomes specified.
Rudberg M A, Sachs G A, Cassel C K. “The trajectory of dying”: commentary and response. Journal of the American Geriatric Society. 90;38(9):1059-60. [Rec#: 50713] Exclude at abstract screening: Title Only.
Rudd M G, Viney L L, Preston C A. The grief experienced by spousal caregivers of dementia patients: the role of place of care of patient and gender of caregiver. Int J Aging Hum Dev. 99;48(3):217-40. [Rec#: 6583] Exclude at abstract screening: Study Design - Qualitative.
Rueth T W, Hall S E. Dealing with the anger and hostility of those who grieve. Am J Hosp Palliat Care 99;16(6):743–6. Comment in: Am J Hosp Palliat Care. Nov-Dec. 1999;16(6):692-3. PMID: 11094902. [Rec#: 14913] Exclude at abstract screening: no outcomes specified.
Rummans T A, Bostwick J M, Clark M M. Mayo Clinic Cancer Center Quality of Life Working Group. Maintaining quality of life at the end of life. Mayo Clin Proc. 2000;75(12):1305-10. [Rec#: 6589] Exclude at abstract screening: useful only for background. [pmid: 11126840].
Rundall T G, Shortell S M, Wang M C, Casalino L, Bodenheimer T, Gillies R R, Schmittdiel J A, Oswald N, Robinson J C. As good as it gets? Chronic care management in nine leading US physician organisations. BMJ 2002;325(7370):958–61. Comment in: BMJ. Oct 26. 2002;325(7370):914-5. PMID: 12399322. [Rec#: 34823] Exclude at abstract screening: Title Only.
Rushton CH, Williams MA, and Sabatier KH. The integration of palliative care and critical care: one vision, one voice. Crit Care Nurs Clin North Am 2002; 14(2):133–40, vii. [Rec#: 14923] Exclude at abstract screening: no outcomes specified
Russell C K, Geraci T, Hooper A, Shull L, Gregory D M. Patients' explanatory models for heart failure and COPD exacerbations. Clin Nurs Res. 98;7(2):164-88. [Rec#: 34830] Exclude at abstract screening: not about end of life.
Rustom R, Daly K. Quality of life after intensive care. Br J Nurs. 93;2(6):316-20. [Rec#: 6599] Exclude at abstract screening: not about end of life. [pmid: 8481636].
Rutman D, Parke B. Palliative care needs of residents, families, and staff in long-term care facilities. J Palliat Care. 92;8(2):23-9. [Rec#: 14933] Exclude at abstract screening: no outcomes specified.
Rutsohn P, Ibrahim N. An analysis of provider attitudes toward end-of-life decision-making. Am J Hosp Palliat Care. 2003;20(5):371-81. [Rec#: 14934] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14529040].
Rutten F H, Grobbee D E, Hoes A W. Diagnosis and management of heart failure: a questionnaire among general practitioners and cardiologists. Eur J Heart Fail. 2003;5(3):345-8. [Rec#: 50094] Exclude at abstract screening: Title Only. [pmid: 12798833].
Ryan C W. Association between administrative and ownership characteristics of hospices and their proportion of inpatient deaths. Hosp J. 2000;15(3):63-74. [Rec#: 14935] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11249382].
Ryan L S. Psychosocial issues and lung cancer: a behavioral approach. Semin Oncol Nurs. 96;12(4):318-23. [Rec#: 34839] Exclude at abstract screening: no outcomes specified. [pmid: 8936648].
Ryan P Y. Perceptions of the most helpful nursing behaviors in a home-care hospice setting: caregivers and nurses. Am J Hosp Palliat Care. 92;9(5):22-31. [Rec#: 6607] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Rydholm M, Strang P. Acupuncture for patients in hospital-based home care suffering from xerostomia. J Palliat Care. 99;15(4):20-3. [Rec#: 14940] Exclude at abstract screening: Other symptoms only. [pmid: 10693302].
Rydholm M, Strang P. Physical and psychosocial impact of xerostomia in palliative cancer care: a qualitative interview study. Int J Palliat Nurs. 2002;8(7):318-23. [Rec#: 6609] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12165715].
Rykov M, Salmon D. Bibliography for music therapy in palliative care, 1963-1997. Am J Hosp Palliat Care. 98;15(3):174-80. [Rec#: 14941] Exclude at abstract screening: Title Only. [pmid: 9729964].
Sachs G A, Miles S H, Levin R A. Limiting resuscitation: emerging policy in the emergency medical system. Annals of Internal Medicine. 91;114(2):151-4. [Rec#: 50714] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Sachs G A, Stocking C B, Miles S H. Empowerment of the older patient? A randomized, controlled trial to increase discussion and use of advance directives. Journal of the American Geriatric Society. 92;40(3):269-73. [Rec#: 50715] Exclude at abstract screening: not about end of life.
Saggino A, Kline P. Item factor analysis of the Italian version of the Death Anxiety Scale. J Clin Psychol. 96;52(3):329-33. [Rec#: 6627] Exclude at abstract screening: not about end of life. [pmid: 8835696].
Sahlberg-Blom E, Ternestedt B M, Johansson J E. Patient participation in decision making at the end of life as seen by a close relative. Nurs Ethics. 2000;7(4):296-313. [Rec#: 6631] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11221407].
Sahlberg-Blom E, Ternestedt B M, Johansson J E. The last month of life: continuity, care site and place of death. Palliat Med. 98;12(4):287-96. [Rec#: 6630] Exclude at abstract screening: Study Design - Unclear.
Sakakibara M, Kongoji K, Samejima H, Shiota K, Takagi A, Miyake F, Murayama M. Specialty-related disparities of readmission in patients with chronic heart failure: the importance of hospital-clinic cooperation. Intern Med. 99;38(9):705-9. [Rec#: 50095] Exclude at abstract screening: Title Only.
Salisbury C. What is the impact of different models of care of patients' quality of life, psychological well being or motivation? 1997;<25 Page(s)>. [Rec#: 50842] Exclude at abstract screening: Study Design - Review/Meta
Salisbury C, Bosanquet N, Wilkinson E K, Franks P J, Kite S, Lorentzon M, Naysmith A. The impact of different models of specialist palliative care on patients' quality of life: a systematic literature review. Palliat Med. 99;13(1):3-17. [Rec#: 50150] Exclude at abstract screening: Non-systematic review.
Salisbury C, Bosanquet N, Wilkinson E K, Franks P J, Kite S, Lorentzon M, Naysmith A. The impact of different models of specialist palliative care on patients' quality of life: a systematic literature review. Palliative Medicine. 99;13(1):3-17. [Rec#: 50716] Exclude at abstract screening: Duplicate already in the flow.
Salman G F, Mosier M C, Beasley B W, Calkins D R. Rehabilitation for patients with chronic obstructive pulmonary disease: meta-analysis of randomized controlled trials. J Gen Intern Med. 2003;18(3):213-21. [Rec#: 50151] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 12648254]. [pmcid: 1494836].
Salmon D. Music and emotion in palliative care. J Palliat Care. 93;9(4):48-52. [Rec#: 6652] Exclude at abstract screening: no outcomes specified. [pmid: 7510804].
Salmon D. Music therapy as psychospiritual process in palliative care. J Palliat Care. 2001;17(3):142-6. [Rec#: 6653] Exclude at abstract screening: no outcomes specified. [pmid: 11816753].
Salomon L, Belouet C, Vinant-Binam P, Sicard D, Vidal-Trecan G. A terminal care support team in a Paris university hospital: care providers' views. J Palliat Care. 2001;17(2):109-16. [Rec#: 14970] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11477985].
Salt N, Robertson S J. A hidden client group? Communication impairment in hospice patients. Int J Lang Commun Disord. 98;33(Suppl):96-101. [Rec#: 6657] Exclude at abstract screening: useful only for background.
Salt S, Wilson L, Edwards A. The use of specialist palliative care services by patients with human immunodeficiency virus-related illness in the Yorkshire Deanery of the northern and Yorkshire region. Palliat Med. 98;12(3):152-60. [Rec#: 14971] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Sandberg J, Lundh U, Nolan M R. Placing a spouse in a care home: the importance of keeping. J Clin Nurs 2001;10(3):406–16. Comment in: Evid Based Nurs. Jan. 2002;5(1):32. PMID: 11915810. [Rec#: 6667] Exclude at abstract screening: no outcomes specified.
Sander R, Russell P. Care for dying people in nursing homes. Nurs Older People 2001;13(2):21–5; quiz 26. Comment in: Nurs Older People. Nov. 2001;13(8):39. PMID: 12008482. [Rec#: 6671] Exclude at abstract screening: useful only for background.
Sander R, Hagenmueller F, Sander C, Riess G, Classen M. Laser versus laser plus afterloading with iridium-192 in the palliative treatment of malignant stenosis of the esophagus: a prospective, randomized, and controlled study. Gastrointest Endosc. 91;37(4):433-40. [Rec#: 6670] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Sankar A. Ritual and dying: a cultural analysis of social support for caregivers. Gerontologist. 91;31(1):43-50. [Rec#: 6678] Exclude at abstract screening: Study Design - Qualitative. [pmid: 2007474].
Sarhill N, Mahmoud F A, Christie R, Tahir A. Assessment of nutritional status and fluid deficits in advanced cancer. Am J Hosp Palliat Care. 2003;20(6):465-73. [Rec#: 15004] Exclude at abstract screening: useful only for background. [pmid: 14649565].
Sarna L, McCorkle R. Burden of care and lung cancer. Cancer Pract. 96;4(5):245-51. [Rec#: 34901] Exclude at abstract screening: Non-systematic review. [pmid: 9004570].
Sarna L, Lindsey AM, Dean H, Brecht ML, and McCorkle R. Nutritional intake, weight change, symptom distress, and functional status over time in adults with lung cancer. Oncol Nurs Forum 93;20(3):481–9. Erratum in: Oncol Nurs Forum 1993 Jul; 20(6):851. [Rec#: 34900] Exclude at abstract screening: Observational study
Sarna L. Fluctuations in physical function: adults with non-small cell lung cancer. J Adv Nurs. 93;18(5):714-24. [Rec#: 34894] Exclude at abstract screening: Observational study. [pmid: 8390495].
Satlin A, Volicer L, Ross V, Herz L, Campbell S. Bright light treatment of behavioral and sleep disturbances in patients with Alzheimer's disease. Am J Psychiatry. 92;149(8):1028-32. [Rec#: 34908] Exclude at abstract screening: not about end of life.
Saunders M M. Family caregivers need support with heart failure patients. Holist Nurs Pract. 2003;17(3):136-42. [Rec#: 34917] Exclude at abstract screening: no outcomes specified. [pmid: 12784897].
Saunderson E M, Ridsdale L. General practitioners' beliefs and attitudes about how to respond to death and bereavement: qualitative study. BMJ 99;319(7205):293–6. Comment in: BMJ. 1999 Jul 31; 319(7205):296. PMID: 10495220. Comment in: BMJ. Oct 16. 1999;319(7216):1071. PMID: 10521216. [Rec#: 15021] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Sauvaget C, Yamada M, Fujiwara S, Sasaki H, Mimori Y. Dementia as a predictor of functional disability: a four-year follow-up study. Gerontology. 2002;48(4):226-33. [Rec#: 34920] Notes: “EXCLUDE: Location, non-Western”. [pmid: 12053112].
Savage S R, Joranson D E, Covington E C, Schnoll S H, Heit H A, Gilson A M. Definitions related to the medical use of opioids: evolution towards universal agreement. J Pain Symptom Manage. 2003;26(1):655-67. [Rec#: 50718] Exclude at abstract screening: no outcomes specified. [pmid: 12850648].
Savenstedt S, Brulin C, Sandman P O. Family members' narrated experiences of communicating via video-phone with patients with dementia staying at a nursing home. J Telemed Telecare. 2003;9(4):216-20. [Rec#: 34923] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12952692].
Saxena S, O'Connell K, and Underwood L. A commentary: cross-cultural quality-of-life assessment at the end of life. Gerontologist 2002;42 Spec No 3:81–5. [Rec#: 6722] Exclude at abstract screening: Title Only
Saysell E, Routley C. Telemedicine in community-based palliative care: evaluation of a videolink teleconference project. Int J Palliat Nurs. 2003;9(11):489-95. [Rec#: 15025] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14676726].
Scanlon C. Defining standards for end-of-life care. Am J Nurs. 97;97(11):58-60. [Rec#: 15027] Exclude at abstract screening: Title Only. [pmid: 9372712].
Scanlon C, Rushton C H. A road map for navigating end-of-lfe care. Medical & Surgical Nursing. 98;7(1):57-59. [Rec#: 50721] Exclude at abstract screening: Title Only.
Scanlon C. Defining standards for end-of-life care. American Journal of Nursing. 97;97(11):58-60. [Rec#: 50719] Exclude at abstract screening: Title Only. [pmid: 9372712].
Scanlon C. End-of-life decisions: the role of the nurse. Seminars in Perioperative Nursing. 96;5(2):92-7. [Rec#: 50720] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 8718401].
Schaafsma J, Coy P. Response of global quality of life to high-dose palliative radiotherapy for non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2000;47(3):691-701. [Rec#: 15033] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 10837953].
Schaefer K M, Shober Potylycki M J. Fatigue associated with congestive heart failure: use of Levine's Conservation Model. J Adv Nurs. 93;18(2):260-8. [Rec#: 34941] Exclude at abstract screening: Study Design - Qualitative.
Schag C A, Ganz P A, Heinrich R L. CAncer Rehabilitation Evaluation System--short form (CARES-SF). A cancer specific rehabilitation and quality of life instrument. Cancer. 91;68(6):1406-13. [Rec#: 50881] Exclude at abstract screening: not about end of life.
Schim S M, Jackson F, Seely S, Grunow K, Baker J. Knowledge and attitudes of home care nurses toward hospice referral. J Nurs Adm. 2000;30(5):273-7. [Rec#: 15050] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10823179].
Schipper H. The evolution of palliative care: a perspective from the European community. J Palliat Care. 91;7(4):37-40. [Rec#: 15051] Exclude at abstract screening: Title Only. [pmid: 1783962].
Schmidt T A, Tolle S W. Emergency physicians' responses to families following patient death. Ann Emerg Med. 90;19(2):125-8. [Rec#: 15064] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Schmitt R. Quality of life issues in lung cancer. New symptom management strategies. Chest. 93;103(1 Suppl):51S-55S. [Rec#: 34974] Exclude at abstract screening: no outcomes specified. [pmid: 8093233].
Schneider S, Kastenbaum R. Patterns and meanings of prayer in hospice caregivers: an exploratory study. Death Stud. 93;17(6):471-85. [Rec#: 15071] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Schneider E C, Zaslavsky A M, Epstein A M. Racial disparities in the quality of care for enrollees in medicare managed care. JAMA. 2002;287(10):1288-94. [Rec#: 50722] Exclude at abstract screening: not about end of life. [pmid: 11886320].
Schofield P, Payne S A. pilot study into the use of a multisensory environment (Snoezelen) within a palliative day-care setting.[erratum appears in International Journal of Palliative Nursing. 2003 Apr;9(4):178]. International Journal of Palliative Nursing. 2003;9(3):124-30. [Rec#: 50725] Exclude at abstract screening: Duplicate already in the flow. [pmid: 12682575].
Schonwetter R S, Han B, Small B J, Martin B, Tope K, Haley W E. Predictors of six-month survival among patients with dementia: an evaluation of hospice Medicare guidelines. Am J Hosp Palliat Care. 2003;20(2):105-13. [Rec#: 6797] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 12693642].
Schonwetter R S, Soendker S, Perron V, Martin B, Robinson B E, Thal A E. Review of Medicare's proposed hospice eligibility criteria for select noncancer patients. Am J Hosp Palliat Care. 98;15(3):155-8. [Rec#: 15079] Exclude at abstract screening: primarily prognosis or trajectories.
Schonwetter R S, Walker R M, Robinson B E. The lack of advance directives among hospice patients. Hosp J. 95;10(3):1-11. [Rec#: 6801] Exclude at abstract screening: Study Design - Unclear. [pmid: 8606047].
Schreml W, Staub J P. Integrated palliative care within a general hospital. Support Care Cancer. 2000;8(2):80-3. [Rec#: 15083] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10739352].
Schroeder MR. Guidelines for care of the dying patient: an interdisciplinary effort. Continuum 97;17(2):1, 3–10. [Rec#: 15087] Exclude at abstract screening: Title Only
Schulman-Green D J. Psychosocial issues in palliative care: physicians' self-perceived role and collaboration with hospital staff. Am J Hosp Palliat Care. 2003;20(1):34-40. [Rec#: 6816] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12568435].
Schulz R, Belle S H, Czaja S J, McGinnis K A, Stevens A, Zhang S. Long-term care placement of dementia patients and caregiver health and well-being. JAMA. 2004;292(8):961-7. [Rec#: 50921] In abstract review process. [pmid: 15328328].
Schwarte A. Ethical decisions regarding nutrition and the terminally ill. Gastroenterol Nurs. 2001;24(1):29-33. [Rec#: 6838] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11847719].
Schwarte AM. Withdrawal of nutritional support in the terminally ill. Crit Care Nurs Clin North Am 2002;14(2):193–6, ix. [Rec#: 15103] Exclude at abstract screening: outcome unrelated to pts/family/non-prof
Schwartz C, Lennes I, Hammes B, Lapham C, Bottner W, Ma Y. Honing an advance care planning intervention using qualitative analysis: the Living Well interview. J Palliat Med. 2003;6(4):593-603. [Rec#: 6839] Exclude at abstract screening: Study Design - Qualitative. [pmid: 14516501].
Schwartzstein R M. The language of dyspnea: using verbal clues to the diagnosis. Journal of Critical Illness. 99;14:435-441. [Rec#: 50727] Exclude at abstract screening: Title Only.
Schwarz J K. Understanding and responding to patients' requests for assistance in dying. J Nurs Scholarsh. 2003;35(4):377-84. [Rec#: 6846] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14735682].
Scialla S, Cole R, Scialla T, Bednarz L, Scheerer J. Rehabilitation for elderly patients with cancer asthenia: making a transition to palliative care. Palliat Med. 2000;14(2):121-7. [Rec#: 6850] Exclude at abstract screening: Study Design - Unclear. [pmid: 10829146].
Sciortino A D, Carlton D C, Axelrod A, Eng M, Zhukovsky D S, Vinciguerra V. The efficacy of administering blood transfusions at home to terminally ill cancer patients. J Palliat Care. 93;9(3):14-7. [Rec#: 15107] Exclude at abstract screening: Observational study.
Scocco P, Meneghel G, Caon F, Dello Buono M, De Leo D. Death ideation and its correlates: survey of an over-65-year-old population. J Nerv Ment Dis. 2001;189(4):210-8. [Rec#: 6857] Exclude at abstract screening: not about end of life. [pmid: 11339316].
Scott G. A study of family carers of people with a life-threatening illness. 2: Implications of the needs assessment. Int J Palliat Nurs. 2001;7(7):323-30. [Rec#: 6864] Exclude at abstract screening: Study Design - Unclear. [pmid: 11951400].
Scott J F, Lynch J. Bedside assessment of competency in palliative care. J Palliat Care. 94;10(3):101-5. [Rec#: 15118] Exclude at abstract screening: Title Only. [pmid: 7531226].
Scott J P, Caldwell J. Needs and program strengths: perceptions of hospice volunteers. Hosp J. 96;11(1):19-30. [Rec#: 6867] Exclude at abstract screening: no outcomes specified. [pmid: 8920309].
Scott L D. Caregiving and care receiving among a technologically dependent heart failure population. ANS Adv Nurs Sci. 2000;23(2):82-97. [Rec#: 35012] Exclude at abstract screening: Observational study. [pmid: 11104326].
Scott M B. Exploration of factors that impact mode of death in the hemodialysis patient. ANNA J. 99;26(6):577-83. discussion 584–5. [Rec#: 6868] Exclude at abstract screening: primarily prognosis or trajectories.
Scott P A. Autonomy, power, and control in palliative care. Camb Q Healthc Ethics. 99;8(2):139-47. [Rec#: 6869] Exclude at abstract screening: Title Only. [pmid: 10067185].
Seale C. Theories in health care and research: theories and studying the care of dying people. BMJ. 98;317(7171):1518-20. [Rec#: 15127] Exclude at abstract screening: Title Only. [pmid: 9831588].
Seamark D A, Lawrence C, Gilbert J. Characteristics of referrals to an inpatient hospice and a survey of general practitioner perceptions of palliative care. J R Soc Med. 96;89(2):79-84. [Rec#: 15131] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Seamark D A, Thorne C P, Jones R V, Gray D J, Searle J F. Knowledge and perceptions of a domiciliary hospice service among general practitioners and community nurses. Br J Gen Pract. 93;43(367):57-9. [Rec#: 15132] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Seamark D A, Williams S, Hall M, Lawrence C J, Gilbert J. Palliative terminal cancer care in community hospitals and a hospice: a comparative study. Br J Gen Pract. 98;48(431):1312-6. [Rec#: 15135] Exclude at abstract screening: Title Only.
Seamens CM and Wrenn K. Breathlessness. Strategies aimed at identifying and treating the cause of dyspnea. Postgrad Med 95;98(4):215–6, 219–22, 225–7. [Rec#: 35016] Exclude at abstract screening: not about end of life
Sebag-Lanoe R, Lefebvre-Chapiro S, Feteanu D, Trivalle C. Palliative care in a long-term care setting: a 25-year French experience. Journal of Palliative Care. 2003;19(3):209-13. [Rec#: 50728] Exclude at abstract screening: no outcomes specified. [pmid: 14606335].
Sebastian P, Varghese C, Sankaranarayanan R, Zaina C P, Nirmala G, Jeevy G, Nair M K. Evaluation of symptomatology in planning palliative care. Palliat Med. 93;7(1):27-34. [Rec#: 6881] Notes: “EXCLUDE: Location, non-Western”. [pmid: 7506976].
Seddon D, Robinson C A. Carers of older people with dementia: assessment and the Carers Act. Health Soc Care Community. 2001;9(3):151-8. [Rec#: 35018] Exclude at abstract screening: not about end of life. [pmid: 11560731].
Seidman J J, Bass E P, Rubin H R. Review of studies that compare the quality of cardiovascular care in HMO versus non-HMO settings. Med Care. 98;36(12):1607-25. [Rec#: 50152] Exclude at abstract screening: not about end of life.
Sekeres M A, Stern T A. On the Edge of Life, I: Assessment of, Reaction to, and Management of the Terminally Ill Recorded in an Intensive Care Unit Journal. Prim Care Companion J Clin Psychiatry. 2002;4(5):178-183. [Rec#: 6896] Exclude at abstract screening: useful only for background. [pmid: 15014705]. [pmcid: 327132].
Seligman P A, Dignon C, Ross D D, Steen P D, Abrahm J L, Boston P H, Ferris F, Foley J, Nelson-Marten P, O'Mara A M, von Gunten C F, Weissman D E. Development of a teaching module for quality-of-life assessment of terminal patients. The AACE Multi-Institutional Palliative Cancer Education Section. American Association for Cancer Education. J Cancer Educ. 99;14(3):129-31. [Rec#: 15146] Exclude at abstract screening: no outcomes specified.
Sellick S M, Zaza C. Critical review of 5 nonpharmacologic strategies for managing cancer pain. Cancer Prev Control. 98;2(1):7-14. [Rec#: 50153] Exclude at abstract screening: Study Design - Review/Meta.
Selwyn P A, Forstein M. Overcoming the false dichotomy of curative vs palliative care for late-stage HIV/AIDS: “let me live the way I want to live, until I can't”. JAMA 2003;290(6):806–14. Comment in: JAMA. Jan 28. 2004;291(4):492. PMID: 14747507. [Rec#: 6905] Exclude at abstract screening: useful only for background.
Selwyn P A, Rivard M. Palliative care for AIDS: challenges and opportunities in the era of highly active anti-retroviral therapy. Journal of Palliative Medicine. 2003;6(3):475-487. [Rec#: 50729] Exclude at abstract screening: Title Only. [pmid: 14509497].
Seo Y. A preliminary study on the emotional distress of patients with terminal-stage cancer: a questionnaire survey of 1380 bereaved families over a 12-year period. Jpn J Clin Oncol. 97;27(2):80-3. [Rec#: 6915] Notes: “EXCLUDE: Location, non-Western”.
Sepulveda C, Marlin A, Yoshida T, Ullrich A. Palliative Care: the World Health Organization's global perspective. J Pain Symptom Manage. 2002;24(2):91-6. [Rec#: 15161] Exclude at abstract screening: useful only for background. [pmid: 12231124].
Serra-Prat M, Gallo P, Picaza J M. Home palliative care as a cost-saving alternative: evidence from Catalonia. Palliat Med. 2001;15(4):271-8. [Rec#: 6921] Exclude at abstract screening: Other topic only. [pmid: 12054144].
Serwint J R. Not always a happy ending: the complexities of the doctor-patient relationship in end-of life care. J Palliat Med. 2004;7(1):77-8. [Rec#: 6924] Exclude at abstract screening: no outcomes specified. [pmid: 15000788].
Sese J C. Letting go of Abuelo. Redefining ‘survival’ in a profession that does so much business with death. Am J Nurs. 98;98(8):53. [Rec#: 6925] Exclude at abstract screening: no outcomes specified.
Sessa C, Pampallona S, Carobbio M, Neuenschwander H, Cavalli F. Palliative care of cancer patients: audit of current hospital procedures. Support Care Cancer. 98;6(3):266-72. [Rec#: 6927] Exclude at abstract screening: useful only for background.
Sessa C, Roggero E, Pampallona S, Regazzoni S, Ghielmini M, Lang M, Marx B, Neuenschwander H, Pagani O, Vasilievic V, Cavalli F. The last 3 months of life of cancer patients: medical aspects and role of home-care services in southern Switzerland. Support Care Cancer 96;4(3):180–5. Comment in: Support Care Cancer. May. 1996;4(3):157. PMID: 8739645. [Rec#: 6928] Exclude at abstract screening: Other topic only.
Severs M P, Wilkins P S. A hospital palliative care ward for elderly people. Age Ageing. 91;20(5):361-4. [Rec#: 6932] Exclude at abstract screening: no outcomes specified. [pmid: 1721764].
Seymour J, Clark D, Hughes P, Bath P, Beech N, Corner J, Douglas H R, Halliday D, Haviland J, Marples R, Normand C, Skilbeck J, Webb T. Clinical nurse specialists in palliative care. Part 3. Issues for the Macmillan Nurse role. Palliat Med. 2002;16(5):386-94. [Rec#: 15173] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12380656].
Seymour J E. Revisiting medicalisation and ‘natural’ death. Soc Sci Med. 99;49(5):691-704. [Rec#: 6935] Exclude at abstract screening: Study Design - Qualitative. [pmid: 10452423].
Shadinger M, Hinninger K, Lester D. Belief in life after death, religiosity and fear of death. Psychol Rep. 99;84(3 Pt 1):868. [Rec#: 6940] Exclude at abstract screening: not about end of life. [pmid: 10408209].
Shah M R, Hasselblad V, Stinnett S S, Kramer J M, Grossman S, Gheorghiade M, Adams K F Jr, Swedberg K, Califf R M, O'Connor C M. Dissociation between hemodynamic changes and symptom improvement in patients with advanced congestive heart failure. Eur J Heart Fail. 2002;4(3):297-304. [Rec#: 35063] Exclude at abstract screening: Other symptoms only. [pmid: 12034155].
Shanafelt T, Adjei A, Meyskens F L. When your favorite patient relapses: physician grief and well-being in the practice of oncology. J Clin Oncol. 2003;21(13):2616-9. [Rec#: 6953] Exclude at abstract screening: Title Only. [pmid: 12829683].
Shapiro E R. Grief in family and cultural context: learning from Latino families. Cult Divers Ment Health. 95;1(2):159-76. [Rec#: 6958] Exclude at abstract screening: Study Design - Unclear. [pmid: 9225556].
Shaughnessy P W, Hittle D F, Crisler K S, Powell M C, Richard A A, Kramer A M, Schlenker R E, Steiner J F, Donelan-McCall N S, Beaudry J M, Mulvey-Lawlor K L, Engle K. Improving patient outcomes of home health care: findings from two demonstration trials of outcome-based quality improvement. Journal of the American Geriatrics Society. 2002;50(8):1354-64. [Rec#: 50731] Exclude at abstract screening: not about end of life. [pmid: 12164991].
Shearer R, Davidhizar R. It can never be the way it was: helping elderly women adjust to change and loss. Home Healthc Nurse. 94;12(4):60-5. [Rec#: 6978] Exclude at abstract screening: no outcomes specified.
Sheehan D C, Forman W B. Symptomatic management of the older person with cancer. Clin Geriatr Me. 97;13(1):203-19. [Rec#: 6979] Exclude at abstract screening: no outcomes specified.
Sheehan DK and Schirm V. End-of-life care of older adults. Am J Nurs 2003;103(11):48–51, 54–8; quiz 59. [Rec#: 6980] Exclude at abstract screening: Title Only
Sheehan M N. Ethics rounds. Words unspoken. J Pain Symptom Manage 2001;21(4):356–7. Comment on: J Pain Symptom Manage. Apr. 2001;21(4):355-6. PMID: 11312050. [Rec#: 6983] Exclude at abstract screening: Title Only.
Shega J W, Hougham G W, Stocking C B, Cox-Hayley D, Sachs G A. Barriers to limiting the practice of feeding tube placement in advanced dementia. J Palliat Med. 2003;6(6):885-93. [Rec#: 35079] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14733680].
Shega J W, Levin A, Houghman G W, Cox-Hayley D, Luchins D, Hanrahan P, Stocking C, Sachs G. Palliative excellence in Alzheimer care efforts (PEACE): a program description. Journal of Palliative Medicine. 2003;6(2):315-320. [Rec#: 50732] Exclude at abstract screening: Title Only. [pmid: 12854952].
Sheldon J E. Patient education: adding to quality of care. Am J Hosp Palliat Care. 98;15(4):239-42. [Rec#: 6985] Exclude at abstract screening: Title Only. [pmid: 9729976].
Shelton P, Schraeder C, Dworak D, Fraser C, Sager M A. Caregivers' utilization of health services: results from the Medicare Alzheimer's Disease Demonstration, Illinois site. J Am Geriatr Soc 2001;49(12):1600–5. Comment in: Evid Based Ment Health. Aug. 2002;5(3):95. PMID: 12180462. [Rec#: 50096] In abstract review process.
Shepardson L B, Youngner S J, Speroff T, Rosenthal G E. Increased risk of death in patients with do-not-resuscitate orders. Med Care 99;37(8):727–37. Comment in: Med Care. 1999 Aug;37(8):719–21. PMID: 10448714. Comment in: Med Care. Aug. 1999;37(8):722-6. PMID: 10448715. [Rec#: 6990] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Shephard R J, Franklin B. Changes in the quality of life: a major goal of cardiac rehabilitation. J Cardiopulm Rehabil. 2001;21(4):189-200. [Rec#: 35084] Exclude at abstract screening: not about end of life. [pmid: 11508178].
Sherbourne C D, Meredith L S, Rogers W, Ware J E Jr. Social support and stressful life events: age differences in their effects on health-related quality of life among the chronically ill. Qual Life Res. 92;1(4):235-46. [Rec#: 6995] Exclude at abstract screening: not about end of life.
Sherman D A, Branum K. Critical care nurses' perceptions of appropriate care of the patient with orders not to resuscitate. Heart Lung. 95;24(4):321-9. [Rec#: 6998] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Sherwood GD, McNeill JA, Starck PL, and Disnard G. Changing acute pain management outcomes in surgical patients. AORN J 2003;77(2):374,377–80, 384–90 passim. [Rec#: 7003] Exclude at abstract screening: not about end of life
Sherwood PR, Given BA, Doorenbos AZ, and Given CW. Forgotten voices: lessons from bereaved caregivers of persons with a brain tumour. Int J Palliat Nurs 2004;10(2):67–75; discussion 75. [Rec#: 7004] Exclude at abstract screening: Study Design - Qualitative
Shickle D. Public preferences for health care: prioritisation in the United Kingdom. Bioethics. 97;11(34):277-90. [Rec#: 7007] Exclude at abstract screening: not about end of life. [pmid: 11654782].
Shidler S. A systemic perspective of life-prolonging treatment decision making. Qual Health Res. 98;8(2):254-69. [Rec#: 7008] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Shields C E. Giving patients bad news. Prim Care. 98;25(2):381-90. [Rec#: 7009] Exclude at abstract screening: no outcomes specified. [pmid: 9628957].
Shimoyama N, Shimoyama M. Nebulized furosemide as a novel treatment for dyspnea in terminal cancer patients. Journal of Pain & Symptom Management. 2002;23:73-76. [Rec#: 50734] Exclude at abstract screening: no outcomes specified. [pmid: 11779672].
Shipman C, Addington-Hall J, Barclay S, Briggs J, Cox I, Daniels L, Millar D. How and why do GPs use specialist palliative care services?. Palliat Med. 2002;16(3):241-6. [Rec#: 7028] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12047001].
Shipman C, Addington-Hall J, Barclay S, Briggs J, Cox I, Daniels L, Millar D. Providing palliative care in primary care: how satisfied are GPs and district nurses with current out-of-hours arrangements? Br J Gen Pract 2000;50(455):477–8. Comment in: Br J Gen Pract. Aug. 2001;51(469):677. PMID: 11510411. [Rec#: 7029] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Shipman C, Addington-Hall J, Thompson M, Pearce A, Barclay S, Cox I, Maher J, Millar D. Building bridges in palliative care: evaluating a GP Facilitator programme. Palliat Med. 2003;17(7):621-7. [Rec#: 15236] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14594154].
Shipton S L. Congestive heart failure readmission. Home Care Provid. 97;2(4):171-5. [Rec#: 50097] Exclude at abstract screening: Non-systematic review. [pmid: 9335688].
Shochat T, Martin J, Marler M, Ancoli-Israel S. Illumination levels in nursing home patients: effects on sleep and activity rhythms. J Sleep Res. 2000;9(4):373-9. [Rec#: 35125] Exclude at abstract screening: not about end of life. [pmid: 11386204].
Sholevar G P, Perkel R. Family systems intervention and physical illness. Gen Hosp Psychiatry. 90;12(6):363-72. [Rec#: 7036] Exclude at abstract screening: no outcomes specified. [pmid: 2245920].
Shortell S M, Zimmerman J E, Rousseau D M, Gillies R R, Wagner D P, Draper E A, Knaus W A, Duffy J. The performance of intensive care units: does good management make a difference?. Medical Care. 94;32(5):508-25. [Rec#: 50735] Exclude at abstract screening: not about end of life.
Should patients with anorexia nervosa receive palliative care? BMJ 98;317(7152):C. [Rec#: 7038] Exclude at abstract screening: Title Only
Shuff I M, Horne A M, Westberg N G, Mooney S P, Mitchell C W. Volunteers under threat: AIDS hospice volunteers compared to volunteers in a traditional hospice. Hosp J. 91;7(12):85-107. [Rec#: 7039] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Shugarman L R, Campbell D E, Bird C E, Gabel J, A Louis T, Lynn J. Differences in medicare expenditures during the last 3 years of life. J Gen Intern Med. 2004;19(2):127-35. [Rec#: 7040] Exclude at abstract screening: useful only for background. [pmid: 15009792]. [pmcid: 1492140].
Shuler P A, Huebscher R, Hallock J. Providing wholistic health care for the elderly: utilization of the Shuler Nurse Practitioner Practice Model. J Am Acad Nurse Pract. 2001;13(7):297-303. [Rec#: 7041] Exclude at abstract screening: no outcomes specified. [pmid: 11930602].
Shuster J L Jr. Palliative care for advanced dementia. Clin Geriatr Med. 2000;16(2):373-86. [Rec#: 7044] Exclude at abstract screening: useful only for background. [pmid: 10783434].
Shuster J L Jr, Breitbart W, Chochinov H M. Psychiatric aspects of excellent end-of-life care. Ad Hoc Committee on End-of-Life Care. The Academy of Psychosomatic Medicine. Psychosomatics. 99;40(1):1-4. [Rec#: 50736] Exclude at abstract screening: Title Only.
Siefken S. The Hispanic perspective on death and dying: a combination of respect, empathy, and spirituality. Pride Inst J Long Term Home Health Care. 93;12(2):26-8. [Rec#: 7049] Exclude at abstract screening: Title Only. [pmid: 10126831].
Siegel J M, Kuykendall D H. Loss, widowhood, and psychological distress among the elderly. J Consult Clin Psychol. 90;58(5):519-24. [Rec#: 7053] Exclude at abstract screening: Study Design - Unclear. [pmid: 2254497].
Siegel K, Karus D G, Raveis V H, Christ G H, Mesagno F P. Depressive distress among the spouses of terminally ill cancer patients. Cancer Pract. 96;4(1):25-30. [Rec#: 7054] Exclude at abstract screening: Bereavement only. [pmid: 8788767].
Siegel K, Raveis V H, Bettes B, Mesagno F P, Christ G, Weinstein L. Perceptions of parental competence while facing the death of a spouse. Am J Orthopsychiatry. 90;60(4):567-76. [Rec#: 7056] Exclude at abstract screening: Study Design - Unclear.
Siegler E L, Del Monte M L, Rosati R J, von Gunten C F. What role should the nephrologist play in the provision of palliative care?. J Palliat Med. 2002;5(5):759-62. [Rec#: 7058] Exclude at abstract screening: Title Only. [pmid: 12572982].
Sikkema K J, Hansen N B, Kochman A, Tate D C, Difranceisco W. Outcomes from a randomized controlled trial of a group intervention for HIV positive men and women coping with AIDS-related loss and bereavement. Death Stud. 2004;28(3):187-209. [Rec#: 7066] Exclude at abstract screening: Study Design - Unclear. [pmid: 15053030].
Sikkema K J, Kalichman S C, Kelly J A, Koob J J. Group intervention to improve coping with AIDS-related bereavement: model development and an illustrative clinical example. AIDS Care. 95;7(4):463-75. [Rec#: 7068] Exclude at abstract screening: Observational study.
Sikkema K J, Kochman A, DiFranceisco W, Kelly J A, Hoffmann R G. AIDS-related grief and coping with loss among HIV-positive men and women. J Behav Med. 2003;26(2):165-81. [Rec#: 7069] Exclude at abstract screening: Bereavement only. [pmid: 12776385].
Sillevis Smitt P, Tsafka A, van den Bent M, de Bruin H, Hendriks W, Vecht C, Teng-van de Zande F. Spinal epidural abscess complicating chronic epidural analgesia in 11 cancer patients: clinical findings and magnetic resonance imaging. J Neurol. 99;246(9):815-20. [Rec#: 7073] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Silverman H J, Fry S T, Armistead N. Nurses' perspectives on implementation of the Patient Self-Determination Act. J Clin Ethics. 94;5(1):30-7. [Rec#: 7077] Exclude at abstract screening: no outcomes specified.
Silvestri G A, Sherman C, Williams T, Leong S S, Flume P, Turrisi A. Caring for the dying patient with lung cancer. Chest. 2002;122(3):1028-36. [Rec#: 35152] Exclude at abstract screening: no outcomes specified. [pmid: 12226050].
Silvestri GA. Palliation for the dying patient with lung cancer. Respir Care 2000;45(12):1490–6; discussion 1497–500 [Rec#: 15270] Exclude at abstract screening: useful only for background
Simione R J, Simione K A. Financial management of a hospice program. Caring. 2002;21(7):34-9. [Rec#: 7085] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12132183].
Simione R J, Simione W J 3rd. Preparing for the new hospice cost report. Caring. 2001;20(2):44. [Rec#: 7086] Exclude at abstract screening: no outcomes specified. [pmid: 11219180].
Simonds A K. Ethics and decision making in end stage lung disease. Thorax. 2003;58(3):272-7. [Rec#: 35157] Exclude at abstract screening: no outcomes specified. [pmid: 12612311].
Simons J P, Aaronson N K, Vansteenkiste J F, ten Velde G P, Muller M J, Drenth B M, Erdkamp F L, Cobben E G, Schoon E J, Smeets J B, Schouten H C, Demedts M, Hillen H F, Blijham G H, Wouters E F. Effects of medroxyprogesterone acetate on appetite, weight, and quality of life in advanced-stage non-hormone-sensitive cancer: a placebo-controlled multicenter study. J Clin Oncol. 96;14(4):1077-84. [Rec#: 35158] Exclude at abstract screening: Other symptoms only.
Simonton S, Sherman A. An integrated model of group treatment for cancer patients. Int J Group Psychother. 2000;50(4):487-506. [Rec#: 7095] Exclude at abstract screening: no outcomes specified. [pmid: 11004771].
Simpson C. A process of dying by default. Aust Fam Physician. 93;22(7):1279-81. 1283. [Rec#: 7096] Exclude at abstract screening: no outcomes specified. [pmid: 8373320].
Simpson S H. Reconnecting: the experiences of nurses caring for hopelessly ill patients in intensive care. Intensive Crit Care Nurs. 97;13(4):189-97. [Rec#: 7101] Exclude at abstract screening: Study Design - Qualitative.
Sinding C. Disarmed complaints: unpacking satisfaction with end-of-life care. Soc Sci Med. 2003;57(8):1375-85. [Rec#: 7105] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12927468].
Singer G R. Disconnecting the ventilator: life saving or death delaying?. J Fla Med Assoc. 97;84(8):498-501. [Rec#: 7106] Exclude at abstract screening: no outcomes specified. [pmid: 9401345].
Singer P A, Bowman K W. Quality end-of-life care: A global perspective. BMC Palliat Care. 2002;1(1):4. [Rec#: 7107] Exclude at abstract screening: useful only for background. [pmid: 12139768]. [pmcid: 122082].
Singer P A, Martin D K, Kelner M. Quality end-of-life care: patients' perspectives. JAMA 99;281(2):163–8. Comment in: JAMA. Apr 28. 1999;281(16):1488. PMID: 10227311. [Rec#: 7108] Exclude at abstract screening: Study Design - Qualitative.
Singer P A, Martin D K, Lavery J V, Thiel E C, Kelner M, Mendelssohn D C. Reconceptualizing advance care planning from the patient's perspective. Arch Intern Med. 98;158(8):879-84. [Rec#: 7109] Exclude at abstract screening: Study Design - Qualitative.
Singer P A. Advance directives in palliative care. J Palliat Care. 94;10(3):111-6. [Rec#: 15293] Exclude at abstract screening: Title Only. [pmid: 7531228].
Singer Y, Shvartzman P. The feasibility and advisability of administering home blood transfusions to the terminally ill patient. J Palliat Care. 98;14(3):46-8. [Rec#: 7112] Exclude at abstract screening: Title Only. [pmid: 9770921].
Singer P A, MacDonald N. Bioethics for clinicians: 15. Quality end-of-life care. CMAJ Canadian Medical Association Journal. 98;159(2):159-62. [Rec#: 50739] Exclude at abstract screening: no outcomes specified.
Singer P, Martin D K, Kelner M, Marm M. Domains of quality end-of-lofe care from the patients perspective. JAMA. 99;281:163-168. [Rec#: 50738] Exclude at abstract screening: Title Only. [pmid: 9917120].
Sivesind D, Parker P A, Cohen L, Demoor C, Bumbaugh M, Throckmorton T, Volker D L, Baile W F. Communicating with patients in cancer care; what areas do nurses find most challenging?. J Cancer Educ. 2003;18(4):202-9. [Rec#: 7128] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14766330].
Skeel RT. Quality of life dimensions that are most important to cancer patients. Oncology (Huntingt) 93;7(12):55–61; discussion 65–6, 69–70. [Rec#: 15303] Exclude at abstract screening: no outcomes specified
Skiba L A, Clark E J, Kalmer K A. The Forget-Me-Not Program: incorporating bereavement care into the continuum. Continuum. 97;17(2):11-5. [Rec#: 15304] Exclude at abstract screening: Title Only. [pmid: 10167254].
Skilbeck J, Seymour J. Meeting complex needs: an analysis of Macmillan nurses' work with patients. Int J Palliat Nurs. 2002;8(12):574-82. [Rec#: 7134] Exclude at abstract screening: no outcomes specified. [pmid: 12560799].
Skilbeck J, Corner J, Bath P, Beech N, Clark D, Hughes P, Douglas H R, Halliday D, Haviland J, Marples R, Normand C, Seymour J, Webb T. Clinical nurse specialists in palliative care. Part 1. A description of the MacMillan Nurse caseload. Palliat Med 2002;16(4):285–96. Comment in: Palliat Med. Jul. 2002;16(4):275-7. PMID: 12132539. [Rec#: 7132] Exclude at abstract screening: not about end of life.
Skilbeck J, Mott L, Page H, Smith D, Hjelmeland-Ahmedzai S, Clark D. Palliative care in chronic obstructive airways disease: a needs assessment. Palliat Med. 98;12(4):245-54. [Rec#: 7133] Exclude at abstract screening: Study Design - Unclear.
Skobel S W, Cullom B A, Showalter S E. When a nurse is not enough: why the hospice interdisciplinary team may be a nurse's best gift. Am J Hosp Palliat Care. 97;14(4):201-4. [Rec#: 7136] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Skrinskas G, Reichenfeld H F. Quality end-of-life care. Ann R Coll Physicians Surg Can. 2002;35(4):245-6. [Rec#: 7138] Exclude at abstract screening: Title Only. [pmid: 14982087].
Sloan P A, Plymale M, LaFountain P, Johnson M, Snapp J, Sloan D A. Equipping medical students to manage cancer pain: A comparison of three educational methods. J Pain Symptom Manage. 2004;27(4):333-42. [Rec#: 7142] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 15050661].
Sloan S L. The hospice movement: a study in the diffusion of innovative palliative care. Am J Hosp Palliat Care. 92;9(3):24-31. [Rec#: 15321] Exclude at abstract screening: Title Only. [pmid: 1280960].
Sloan R P, Bagiella E. Claims about religious involvement and health outcomes. Annals of Behavioral Medicine. 2002;24(1):14-21. [Rec#: 50741] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12008790].
Sloan R P, Bagiella E, Powell T. Religion, spirituality, and medicine. Lancet. 99;353(9153):664-7. [Rec#: 50742] Exclude at abstract screening: Title Only. [pmid: 10030348].
Sloan P, Bagiella E, VandeCreek L, Hover M, Casalone C, Jinpu Hirsch T, Hasan Y, Kreger R, Poulos P. Should physicians prescribe religious activities?. New England Journal of Medicine. 2000;342(25):1913-6. [Rec#: 50743] Exclude at abstract screening: Title Only. [pmid: 10861331].
Sloman R, Ahern M, Wright A, Brown L. Nurses' knowledge of pain in the elderly. J Pain Symptom Manage. 2001;21(4):317-22. [Rec#: 7145] Exclude at abstract screening: no outcomes specified. [pmid: 11312046].
Slone M, Stephany T. Stressors of hospice home care nurses caring for AIDS patients: a pilot study. Am J Hosp Palliat Care. 95;12(1):32-6. [Rec#: 7147] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Sloss E M, Solomon D H, Shekelle P G, Young R T, Saliba D, MacLean C H, Rubenstein L Z, Schnelle J F, Kamberg C J, Wenger N S. Selecting target conditions for quality of care improvement in vulnerable older adults. J Am Geriatr Soc. 2000;48(4):363-9. [Rec#: 7148] Exclude at abstract screening: useful only for background. [pmid: 10798460].
Slutsman J, Emanuel L L, Fairclough D, Bottorff D, Emanuel E J. Managing end-of-life care: comparing the experiences of terminally Ill patients in managed care and fee for service. J Am Geriatr Soc. 2002;50(12):2077-83. [Rec#: 7149] Exclude at abstract screening: Title Only. [pmid: 12473022].
Small M, Engler A J, Rushton C H. Saying goodbye in the intensive care unit: helping caregivers grieve. Pediatr Nurs. 91;17(1):103-5. [Rec#: 15327] Exclude at abstract screening: no outcomes specified. [pmid: 2000235].
Smeenk F W, Ament A J, van Haastregt J C, de Witte L P, Crebolder H F. Cost analysis of transmural home care for terminal cancer patients. Patient Educ Couns. 98;35(3):201-11. [Rec#: 7153] Exclude at abstract screening: Other topic only.
Smeenk F W, van Haastregt J C, de Witte L P, Crebolder H F. Effectiveness of home care programmes for patients with incurable cancer on their quality of life and time spent in hospital: systematic review. BMJ. 98;316(7149):1939-44. [Rec#: 15331] Exclude at abstract screening: Study Design - Review/Meta.
Smeijsters H, van Den Hurk J. Music Therapy Helping to Work Through Grief and Finding a Personal Identity. J Music Ther. 99;36(3):222-252. [Rec#: 7158] Exclude at abstract screening: no outcomes specified.
Smith A L. Managing patients with “refractory” heart failure. J Med Assoc Ga. 2001;90(4):32-5. [Rec#: 35207] Exclude at abstract screening: Study Design - Unclear. [pmid: 11845682].
Smith D M. Are we missing an important segment of the population?. RDH. 92;12(3):30-42. [Rec#: 7163] Exclude at abstract screening: Title Only. [pmid: 1410613].
Smith E D. Addressing the psychospiritual distress of death as reality: a transpersonal approach. Soc Work. 95;40(3):402-13. [Rec#: 15343] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Smith G P 2nd. Euphemistic codes and tell-tale hearts: humane assistance in end-of-life cases. Health Matrix Clevel. 2000;10(2):175-203. [Rec#: 7167] Exclude at abstract screening: Title Only. [pmid: 14655527].
Smith M, Yuen K. Palliative care in the home. The GP/home hospice team. Aust Fam Physician. 94;23(7):1260-5. [Rec#: 15359] Exclude at abstract screening: no outcomes specified. [pmid: 7520233].
Smith N, Regnard C. Managing family problems in advanced disease--a flow diagram. Palliat Med. 93;7(1):47-58. [Rec#: 15363] Exclude at abstract screening: no outcomes specified. [pmid: 8287199].
Smith P C, Westfall J M, Nichols R A. Primary care family physicians and 2 hospitalist models: comparison of outcomes, processes, and costs. J Fam Pract 2002;51(12):1021–7. Comment in: J Fam Pract. Dec. 2002;51(12):1028-9. PMID: 12540327. [Rec#: 7175] Exclude at abstract screening: not about end of life.
Smith S A. Controversies in hydrating the terminally ill patient. J Intraven Nurs 97;20(4):193–200. Comment in: J Intraven Nurs. May-Jun. 1998;21(3):138-9. PMID: 9652270. [Rec#: 7177] Exclude at abstract screening: no outcomes specified.
Smith S A. Facing the challenge of the hospice and palliative care marriage. Am J Hosp Palliat Care. 98;15(3):181-3. [Rec#: 15369] Exclude at abstract screening: Title Only. [pmid: 9729965].
Smith S A. Patient-induced dehydration--can it ever be therapeutic?. Oncol Nurs Forum. 95;22(10):1487-91. [Rec#: 7178] Exclude at abstract screening: Title Only. [pmid: 8577617].
Smith S H. “Fret no more my child … for I'm all over heaven all day”: religious beliefs in the bereavement of African American, middle-aged daughters coping with the death of an elderly mother. Death Stud. 2002;26(4):309-23. [Rec#: 7179] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11980451].
Smith T J, Coyne P, Cassel B, Penberthy L, Hopson A, Hager M A. A high-volume specialist palliative care unit and team may reduce in-hospital end-of-life care costs. J Palliat Med. 2003;6(5):699-705. [Rec#: 15378] Exclude at abstract screening: Other topic only. [pmid: 14622449].
Smith T J, Desch C E, Grasso M A, McCue M J, Buonaiuto D, Grasso K, Johantgen M E, Hackney M H, Shaw J E, Simonson C J. The Rural Cancer Outreach Program: clinical and financial analysis of palliative and curative care for an underserved population. Cancer Treat Rev. 96;22(Suppl A):97-101. [Rec#: 15379] Exclude at abstract screening: Title Only.
Smith T J. Health service studies in the terminally ill cancer patient. Cancer Treat Res. 98;97:81-97. [Rec#: 15377] Exclude at abstract screening: no outcomes specified. [pmid: 9711411].
Smith W B, Gracely R H, Safer M A. The meaning of pain: cancer patients' rating and recall of pain intensity and affect. Pain. 98;78(2):123-9. [Rec#: 7183] Exclude at abstract screening: Study Design - Qualitative.
Smith W R, Kellerman A, Brown J S. The impact of nursing home transfer policies at the end of life on a public acute care hospital. J Am Geriatr Soc. 95;43(9):1052-7. [Rec#: 7184] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Smith, M. C., Holcombe, J. K., and Stullenbarger, E. A meta-analysis of intervention effectiveness for symptom management in oncology nursing research. Oncol Nurs Forum 94;21(7):1201–9; discussion 1209–10. [Rec#: 50154] Exclude at abstract screening: Study Design - Review/Meta
Smith S P, Varoglu G. Hospice: a supportive working environment for nurses. Journal of Palliative Care. 85;1(1):16-23. [Rec#: 50744] Exclude at abstract screening: no outcomes specified. [pmid: 3870936].
Smith-Stoner M, Frost A L. How to build your “hope skills”. Nursing. 99;29(9):49-51. [Rec#: 7181] Exclude at abstract screening: Title Only. [pmid: 10540619].
Smith-Stoner M. There's still no place like home: results of the Home Healthcare Nurse 2002 survey of nurses working in home care and hospice for 20+ years. Home Healthc Nurse. 2002;20(10):657-62. [Rec#: 15372] Exclude at abstract screening: Title Only. [pmid: 12394338].
SMS commission updates guidelines on terminal care in long-term care facilities and at home. Wis Med J 94;93(3):138–40. [Rec#: 7189] Exclude at abstract screening: Title Only
Sneed N V, Paul S, Michel Y, Vanbakel A, Hendrix G. Evaluation of 3 quality of life measurement tools in patients with chronic heart failure. Heart Lung. 2001;30(5):332-40. [Rec#: 35231] Exclude at abstract screening: not about end of life. [pmid: 11604975].
Snyder J R. Therapeutic touch and the terminally ill: healing power through the hands. Am J Hosp Palliat Care. 97;14(2):83-7. [Rec#: 15395] Exclude at abstract screening: useful only for background.
Snyder R D. A peaceful death. Ann Emerg Med. 94;24(6):1195-6. [Rec#: 7199] Exclude at abstract screening: Title Only. [pmid: 7978610].
Soares L G. Poor social conditions, criminality and urban violence: Unmentioned barriers for effective cancer pain control at the end of life. Journal of Pain & Symptom Management. 2003;26(2):693-5. [Rec#: 50746] Exclude at abstract screening: useful only for background. [pmid: 12906953].
Society, American Thoracic. Dyspnea mechansims, assessment, adn management: A concensus statement. American Jouranl of Respiratory and Critical Care Medicine 99;159:321–340. [Rec#: 50747] Exclude at abstract screening: Title Only
Soden K, Hoy A, Hoy W, Clelland S. Artificial hydration during the last week of life in patients dying in a district general hospital. Palliat Med. 2002;16(6):542-3. [Rec#: 7201] Exclude at abstract screening: Title Only. [pmid: 12465704].
Soderberg A, Gilje F, Norberg A. Transforming desolation into consolation: the meaning of being in situations of ethical difficulty in intensive care. Nurs Ethics. 99;6(5):357-73. [Rec#: 7203] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Soeda S, Terao T, Nishimura M, Nakamura J, Iwata N. Aging and visual hallucinations in elderly psychiatric outpatients. Prog Neuropsychopharmacol Biol Psychiatry. 2004;28(2):401-4. [Rec#: 7204] Exclude at abstract screening: not about end of life. [pmid: 14751440].
Sogaard J, Gyrd-Hansen D. Counting and discounting gained life-years. Dev Health Econ Public Policy. 98;6:51-74. [Rec#: 7208] Exclude at abstract screening: Study Design - Unclear. [pmid: 10662409].
Soloman NRZ. Death and Dying in Ethnic America: Findings in Eritrean, Oromo, and Somali Communities. 2000;<25 Page(s)>. [Rec#: 50748] Exclude at abstract screening: Title Only
Solomon M Z. How physicians talk about futility: making words mean too many things. J Law Med Ethics. 93;21(2):231-7. [Rec#: 7214] Exclude at abstract screening: Title Only. [pmid: 8130833].
Solomon M Z. The enormity of the task. SUPPORT and changing practice. Hastings Cent Rep. 95;25(6):S28-32. [Rec#: 50882] Exclude at abstract screening: no outcomes specified. [pmid: 8609004].
Soltys FG, Brookins M, and Seney J. Why hospice? The case for ESRD patients and their families. ANNA J 98;25(6):619–24, 578. [Rec#: 7218] Exclude at abstract screening: useful only for background
Sommers L S, Marton K I, Barbaccia J C, Randolph J. Physician, nurse, and social worker collaboration in primary care for chronically ill seniors. Archives of Internal Medicine. 2000;160(12):1825-33. [Rec#: 50749] Exclude at abstract screening: not about end of life. [pmid: 10871977].
Sontag M A. A comparison of hospice programs based on Medicare certification status. Am J Hosp Palliat Care. 96;13(2):32-41. [Rec#: 15422] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Sontag M A. Characteristics of hospice programs, directors, and selected staff in one western state. Am J Hosp Palliat Care. 95;12(4):29-37. [Rec#: 7227] Exclude at abstract screening: not about end of life.
Sontag M A. Hospice values, access to services, and the Medicare hospice benefit. Am J Hosp Palliat Care 92;9(6):17–21. Comment in: Am J Hosp Palliat Care. May-Jun. 1993;10(3):3-4. PMID: 8312078. [Rec#: 15423] Exclude at abstract screening: no outcomes specified.
Sopata M, Luczak J, Glocwacka A. managing pressure sores in palliative care. J Wound Care. 97;6(1):10-1. [Rec#: 7229] Exclude at abstract screening: useful only for background. [pmid: 9117825].
Sorajjakool S. Gerontology, spirituality, and religion. J Pastoral Care. 98;52(2):147-56. [Rec#: 7230] Exclude at abstract screening: no outcomes specified. [pmid: 10180930].
Sorbye L W. A longitudinal study on dying in a Norwegian hospital. Int J Palliat Nurs. 2000;6(2):71-9. [Rec#: 7232] Exclude at abstract screening: data older than 1990. [pmid: 11035626].
Sorbye L W. Cancer patients who prefer to die at home. Characterizations of municipalities with several or few occurrences of home deaths. Scand J Caring Sci. 99;13(2):102-8. [Rec#: 15425] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Sorbye L W. Homecare at the end of life. A study of fifteen patients. Scand J Caring Sci. 90;4(3):107-13. [Rec#: 7231] Exclude at abstract screening: Observational study. [pmid: 2218201].
Soriano-Pacheco J A, Lopez-Navidad A, Caballero F, Leal J, Garcia-Sousa S, Linares J L. Psychopathology of bereavement in the families of cadaveric organ donors. Transplant Proc. 99;31(6):2604-5. [Rec#: 7234] Exclude at abstract screening: Title Only.
Soudry E, Sprung C L, Levin P D, Grunfeld G B, Einav S. Forgoing life-sustaining treatments: comparison of attitudes between Israeli and North American intensive care healthcare professionals. Isr Med Assoc J. 2003;5(11):770-4. [Rec#: 7239] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14650099].
Souter J. Using a model for structured reflection on palliative care nursing: exploring the challenges raised. Int J Palliat Nurs. 2003;9(1):6-12. [Rec#: 7242] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12560791].
Soutter J, Craft A. A strategy for caring for families in bereavement. Nurs Times. 94;90(30):37-9. [Rec#: 7244] Notes: “EXCLUDE: Age, not adults”. [pmid: 8058514].
Sowell R L, Bramlett M H, Gueldner S H, Gritzmacher D, Martin G. The lived experience of survival and bereavement following the death of a lover from AIDS. Image J Nurs Sch. 91;23(2):89-94. [Rec#: 7246] Exclude at abstract screening: Observational study.
Spector, N. and Klein, D. Assessing and managing dyspnea. Nursing Profile 2002;20–24. [Rec#: 50750] Exclude at abstract screening: Title Only
Spector, N., Klein, D., and Rice-Wiley, L. Terminally ill patients breathe easier with nebulized morphine. Nursing Spectrum 2000;1–6. [Rec#: 50751] Exclude at abstract screening: Title Only
Speer D C, Robinson B E, Reed M P. The relationship between hospice length of stay and caregiver adjustment. Hosp J. 95;10(1):45-58. [Rec#: 7256] Exclude at abstract screening: Bereavement only. [pmid: 7789940].
Spencer L. How do nurses deal with their own grief when a patient dies on an intensive care unit, and what help can be given to enable them to overcome their grief effectively?. J Adv Nurs. 94;19(6):1141-50. [Rec#: 7262] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Spettigue B, Uglow A, Stewart G. A multidisciplinary approach to palliative transfusions at home. Nurs Times. 98;94(28):54-5. [Rec#: 7265] Exclude at abstract screening: no outcomes specified. [pmid: 9767012].
Spieker E D, Motzer S A. Sleep-disordered breathing in patients with heart failure: pathophysiology, assessment, and management. J Am Acad Nurse Pract. 2003;15(11):487-93. [Rec#: 35287] Exclude at abstract screening: no outcomes specified. [pmid: 14685985].
Spiller J A, Alexander D A. Domiciliary care: a comparison of the views of terminally ill patients and their family caregivers. Palliat Med. 93;7(2):109-15. [Rec#: 7270] Exclude at abstract screening: Study Design - Unclear.
Spillman B C, Lubitz J. The effect of longevity on spending for acute and long-term care. New England Journal of Medicine. 2000;342(19):1409-15. [Rec#: 50752] Exclude at abstract screening: useful only for background. [pmid: 10805827].
Spinsanti S. Obtaining consent from the family: a horizon for clinical ethics. J Clin Ethics 92;3(3):188–92. Comment in: J Clin Ethics. 1992 Fall;3(3):219–20. PMID: 1392043. Comment in: J Clin Ethics. 1992 Fall;3(3):221–4. PMID: 1392044. Comment in: J Clin Ethics. 1992 Fall;3(3):224–8. PMID: 1392045. [Rec#: 7277] Exclude at abstract screening: no outcomes specified
Sprangers M A, Aaronson N K. The role of health care providers and significant others in evaluating the quality of life of patients with chronic disease: a review. J Clin Epidemiol. 92;45(7):743-60. [Rec#: 50884] Exclude at abstract screening: no outcomes specified.
St Clair M. An unfortunate family: terminal illness and the altering of the attachment bond. Am J Psychother. 2000;54(4):512-8. [Rec#: 7290] Exclude at abstract screening: Observational study. [pmid: 11109135].
Stajduhar K I, Davies B. Death at home: challenges for families and directions for the future. J Palliat Care. 98;14(3):8-14. [Rec#: 15476] Exclude at abstract screening: Title Only. [pmid: 9770916].
Stajduhar K I, Davies B. Palliative care at home: reflections on HIV/AIDS family caregiving experiences. J Palliat Care. 98;14(2):14-22. [Rec#: 7294] Exclude at abstract screening: Observational study.
Stajduhar K I. Examining the perspectives of family members involved in the delivery of palliative care at home. J Palliat Care. 2003;19(1):27-35. [Rec#: 15475] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12710112].
Stajduhar K I. Loss and bereavement: HIV/AIDS family caregiving experiences. Can J Nurs Res. 97;29(4):73-86. [Rec#: 7293] Exclude at abstract screening: Observational study. [pmid: 9697436].
Stanley K J. Silence is not golden: conversations with the dying. Clin J Oncol Nurs. 2000;4(1):34-40. [Rec#: 7300] Exclude at abstract screening: no outcomes specified. [pmid: 10865582].
Stark D, Kiely A, Smith G, Velikova A, Selbi P. Anxiety disorders in cancer patients: their nature, associations, and relations to quality of life. Journal of Clinical Oncology. 2002;20:3137-3148. [Rec#: 50753] Exclude at abstract screening: Title Only. [pmid: 12118028].
Stassen N A, Lukan J K, Mizuguchi N N, Spain D A, Carrillo E H, Polk H C Jr. Thermal injury in the elderly: when is comfort care the right choice?. Am Surg. 2001;67(7):704-8. [Rec#: 7306] Exclude at abstract screening: not about end of life. [pmid: 11450794].
State-by-state report card on care for the dying finds mediocre care nationwide. J Pain Palliat Care Pharmacother 2003 17 (2) 111 5 [Rec#: 15491] Exclude at abstract screening: useful only for background
Stats and facts. Costs at the end of life. Manag Care Interface 99;12(8):40–1. [Rec#: 7308] Exclude at abstract screening: Title Only
Stausmire J M. Sexuality at the end of life. Am J Hosp Palliat Care. 2004;21(1):33-9. [Rec#: 7310] Exclude at abstract screening: useful only for background. [pmid: 14748521].
Stearns S C, Norton E C. Time to include time to death? The future of health care expenditure predictions. Health Econ. 2004;13(4):315-27. [Rec#: 7314] Exclude at abstract screening: useful only for background. [pmid: 15067670].
Stearns S C, Kovar M G, Hayes K, Koch G G. Risk indicators for hospitalization during the last year of life. Health Serv Res. 96;31(1):49-69. [Rec#: 7313] Exclude at abstract screening: Other topic only. [pmid: 8617609].
Steel K, Ribbe M, Ahronheim J, Hedrick H, Selwyn P A, Forman W, Keay T. Incorporating education on palliative care into the long-term care setting. National Consensus Conference on Medical Education for Care Near the End of Life. J Am Geriatr Soc. 99;47(7):904-7. [Rec#: 15495] Exclude at abstract screening: no outcomes specified.
Steel, K, Whang P. Standardized comprehensive assessment for end-of-life and palliative care. Journal of Pain & Symptom Management. 2000;19(5):324-5. [Rec#: 50755] Exclude at abstract screening: no outcomes specified. [pmid: 10928850].
Steel K, Vitale C, Whang P. Annotated bibliography of palliative care and end of life care. Journal of the American Geriatrics Society. 2000;48(3):325-32. [Rec#: 50754] Exclude at abstract screening: Title Only. [pmid: 10733062].
Steele L L. The death surround: factors influencing the grief experience of survivors. Oncol Nurs Forum. 90;17(2):235-41. [Rec#: 7317] Exclude at abstract screening: Bereavement only. [pmid: 2315187].
Steele R G, Fitch M I. Needs of family caregivers of patients receiving home hospice care for cancer. Oncol Nurs Forum. 96;23(5):823-8. [Rec#: 7321] Exclude at abstract screening: Observational study.
Steen KF. A comprehensive approach to bereavement. Nurse Pract 98;23(3):54,59–64,66–8. [Rec#: 7322] Exclude at abstract screening: no outcomes specified
Steeves R H. Loss, grief, and the search for meaning. Oncol Nurs Forum. 96;23(6):897-903. [Rec#: 7327] Exclude at abstract screening: useful only for background. [pmid: 8829160].
Steeves R H. The rhythms of bereavement. Fam Community Health. 2002;25(1):1-10. [Rec#: 7328] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11966412].
Steffens D C, Skoog I, Norton M C, Hart A D, Tschanz J T, Plassman B L, Wyse B W, Welsh-Bohmer K A, Breitner J C. Prevalence of depression and its treatment in an elderly population: the Cache County study. Arch Gen Psychiatry. 2000;57(6):601-7. [Rec#: 7329] Exclude at abstract screening: not about end of life. [pmid: 10839339].
Stein N, Folkman S, Trabasso T, Richards T A. Appraisal and goal processes as predictors of psychological well-being in bereaved caregivers. J Pers Soc Psychol. 97;72(4):872-84. [Rec#: 7333] Exclude at abstract screening: Bereavement only.
Stein W M, Min Y K. Nebulized morphine for paroxysmal cough and dyspnea in a nursing home resident with metastatic cancer. Am J Hosp Palliat Care. 97;14(2):52-6. [Rec#: 7335] Exclude at abstract screening: useful only for background.
Stein G L, Bonuck K A. Attitudes on end-of-life care and advance care planning in the lesbian and gay community. Journal of Palliative Medicine. 2001;4(2):173-90. [Rec#: 50757] Exclude at abstract screening: not about end of life. [pmid: 11441626].
Stein G L, Bonuck K. Attitudes on end-of-life care and advance care planning in the lesbian and gay community. Journal of Palliative Medicine. 2001;4(2):173-190. [Rec#: 50756] Exclude at abstract screening: Title Only. [pmid: 11441626].
Steiner J. Pathological organizations as obstacles to mourning: the role of unbearable guilt. Int J Psychoanal. 90;71(Pt 1):87-94. [Rec#: 7338] Exclude at abstract screening: no outcomes specified.
Steinhauser K E, Clipp E C, Tulsky J A. Evolution in measuring the quality of dying. J Palliat Med. 2002;5(3):407-14. [Rec#: 15509] Exclude at abstract screening: Non-systematic review. [pmid: 12133245].
Steinhauser K E, Clipp E C, McNeilly M, Christakis N A, McIntyre L M, Tulsky J A. In search of a good death: observations of patients, families, and providers. Ann Intern Med. 2000;132(10):825-32. [Rec#: 7342] Exclude at abstract screening: Study Design - Qualitative. [pmid: 10819707].
Stephany T. Antidepressants in hospice care. Am J Hosp Palliat Care. 95;12(4):4-5. [Rec#: 15516] Exclude at abstract screening: Title Only. [pmid: 7632491].
Stephany T. Caring for the primary caregiver. Home Healthc Nurse. 92;10(4):39. [Rec#: 15517] Exclude at abstract screening: Title Only. [pmid: 1644585].
Stephany T. Competency test for basic, low-tech pain control. Am J Hosp Palliat Care. 96;13(1):10-16. [Rec#: 15518] Exclude at abstract screening: Title Only. [pmid: 8634174].
Stephany T. Hospice home health aides. Home Healthc Nurse. 93;11(2):71. [Rec#: 15519] Exclude at abstract screening: Title Only. [pmid: 8478202].
Stephany T. Hospice nursing in the neighborhood. Am J Hosp Palliat Care. 97;14(3):119-20. [Rec#: 15520] Exclude at abstract screening: Title Only. [pmid: 9295416].
Stephany T. Low-tech hospice home care for end-stage heart disease. Am J Hosp Palliat Care. 96;13(3):35-6. Erratum in: Am J Hosp Palliat Care;1996 Nov-Dec;13(6):5. [Rec#: 15521] Exclude at abstract screening: no outcomes specified.
Stephany T. Low-tech hospice home care nursing guidelines. Am J Hosp Palliat Care. 97;14(3):108. [Rec#: 15522] Exclude at abstract screening: no outcomes specified. [pmid: 9295413].
Stephany T. Low-tech nursing guidelines for hospice patients with degenerative neurological disease. Am J Hosp Palliat Care 97;14(6):305–6. Comment in: Am J Hosp Palliat Care. Jul-Aug. 1998;15(4):200-1. PMID: 9729970. [Rec#: 15523] Exclude at abstract screening: no outcomes specified.
Stephany T. Palliative nursing care during end-stage COPD. Am J Hosp Palliat Care. 96;13(5):20-1. [Rec#: 15525] Exclude at abstract screening: no outcomes specified. [pmid: 8936197].
Stephany T. Supplies for home care of the terminally ill. Home Healthc Nurse. 90;8(1):53. [Rec#: 15526] Exclude at abstract screening: Title Only. [pmid: 2298605].
Stephany T. Vacations and the hospice nurse. Home Healthc Nurse. 91;9(2):49-50. [Rec#: 15527] Exclude at abstract screening: Title Only. [pmid: 2061069].
Stephany T M. AIDS does not fit the cancer model of hospice care. Am J Hosp Palliat Care. 92;9(1):13-4. [Rec#: 15528] Exclude at abstract screening: Title Only. [pmid: 1540421].
Stephens RL. Oncology patients and the living will. Oncology (Huntingt) 92;6(5):77–84; discussion 87–8. [Rec#: 15542] Exclude at abstract screening: no outcomes specified
Stepnick A, Perry T. Preventing spiritual distress in the dying client. J Psychosoc Nurs Ment Health Serv. 92;30(1):17-24. [Rec#: 7352] Exclude at abstract screening: no outcomes specified. [pmid: 1738133].
Stepp L and Pakiz TS. Anorexia and cachexia in advanced cancer. Nurs Clin North Am 2001; 36(4):735–44, vii. [Rec#: 15543] Exclude at abstract screening: useful only for background
Stern B. The grief suite. Posit Aware. 2003;14(4):25-8. [Rec#: 15544] Exclude at abstract screening: Title Only. [pmid: 12951946].
Stern E J. Developing a community services model: home care, day care, and residential services. Pride Inst J Long Term Home Health Care. 90;9(2):35-41. [Rec#: 35339] Exclude at abstract screening: Title Only. [pmid: 10170574].
Stetz K M. Survival work: the experience of the patient and the spouse involved in experimental treatment for cancer. Semin Oncol Nurs. 93;9(2):121-6. [Rec#: 7357] Exclude at abstract screening: Study Design - Unclear.
Stevens L, Cook D, Guyatt G, Griffith L, Walter S, McMullin J. Education, ethics, and end-of-life decisions in the intensive care unit. Crit Care Med. 2002;30(2):290-6. [Rec#: 7361] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11889295].
Stevens L. When your patient is dying. Allow yourself to grieve. Adv Nurse Pract. 97;5(3):68-9. [Rec#: 15551] Exclude at abstract screening: Title Only. [pmid: 9459886].
Stevens M J, Begbie S D. Hypofractionated irradiation for inoperable non-small cell lung cancer. Australas Radiol. 95;39(3):265-70. [Rec#: 7363] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Stevens RD and Katsekas BS. Nursing the terminally ill. Being with people in difficult times. Home Healthc Nurse 99;17(8):504–9; quiz 509–10. [Rec#: 15552] Exclude at abstract screening: no outcomes specified
Stevensen C. The role of shiatsu in palliative care. Complement Ther Nurs Midwifery. 95;1(2):51-8. [Rec#: 7364] Exclude at abstract screening: no outcomes specified. [pmid: 9456709].
Stewart A L, Teno J, Patrick D L, Lynn J. The concept of quality of life of dying persons in the context of health care. J Pain Symptom Manage. 99;17(2):93-108. [Rec#: 15556] Exclude at abstract screening: no outcomes specified.
Stewart BM. End-of-life family decision-making from disclosure of HIV through bereavement. Sch Inq Nurs Pract 94;8(4):321–52; discussion 353–9. [Rec#: 7368] Exclude at abstract screening: Study Design - Qualitative
Stewart J M, O'Shea E, Donaldson C, Shackley P. Do ordering effects matter in willingness-to-pay studies of health care?. J Health Econ. 2002;21(4):585-99. [Rec#: 15559] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12146592].
Stewart M, Craig D, MacPherson K, Alexander S. Promoting positive affect and diminishing loneliness of widowed seniors through a support intervention. Public Health Nurs. 2001;18(1):54-63. [Rec#: 7369] Exclude at abstract screening: Bereavement only. [pmid: 11251874].
Stewart M. Reflecting on the psychosocial care of patients with a terminal illness. Prof Nurse. 2003;18(7):402-5. [Rec#: 15560] Exclude at abstract screening: no outcomes specified. [pmid: 12674049].
Stewart S, Horowitz J D. Home-based intervention in congestive heart failure: long-term implications on readmission and survival. Circulation 2002;105(24):2861–6. Comment in: Circulation. Jun 18. 2002;105(24):2810-2. PMID: 12070104. [Rec#: 50099] Exclude at abstract screening: not about end of life.
Stewart S, Vandenbroek A J, Pearson S, Horowitz J D. Prolonged beneficial effects of a home-based intervention on unplanned readmissions and mortality among patients with congestive heart failure. Arch Intern Med 99;159(3):257–61. Comment in: ACP J Club. Jul-Aug. 1999;131(1):6. [Rec#: 50101] Exclude at abstract screening: not about end of life.
Stewart W B. Health care. Transformation of systems and soul?. West J Med. 94;160(3):273-4. [Rec#: 15561] Exclude at abstract screening: Title Only. [pmid: 8191771].
Stiefel F, Guex P. Palliative and supportive care: at the frontier of medical omnipotence. Ann Oncol 96;7(2):135–8. Comment in: Ann Oncol. Aug. 1996;7(6):645. PMID: 8879385. [Rec#: 15563] Exclude at abstract screening: no outcomes specified.
Stiefel R, Die Trill M, Berney A, Olarte J M, Razavi A. Depression in palliative care: a pragmatic report from the Expert Working Group of the European Association for Palliative Care. Support Care Cancer. 2001;9(7):477-88. [Rec#: 15564] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 11680829].
Stiefel F, Bruera E. Psychostimulants for hypoactive-hypoalert delirium?. Journal of Palliative Care. 91;7(3):25-6. [Rec#: 50758] Exclude at abstract screening: no outcomes specified. [pmid: 1941359].
Stiggelbout A M, de Haes J C, Kiebert G M, Kievit J, Leer J W. Tradeoffs between quality and quantity of life: development of the QQ Questionnaire for Cancer Patient Attitudes. Med Decis Making. 96;16(2):184-92. [Rec#: 7373] Exclude at abstract screening: not about end of life.
Stiles M K. The shining stranger: application of the phenomenological method in the investigation of the nurse--family spiritual relationship. Cancer Nurs. 94;17(1):18-26. [Rec#: 7374] Exclude at abstract screening: Study Design - Qualitative.
Stillman A E, Braitman L E, Grant R J. Are critically ill older patients treated differently than similarly ill younger patients?. West J Med. 98;169(3):162-5. [Rec#: 7375] Exclude at abstract screening: not about end of life.
Stjernsward J, Colleau S M, Ventafridda V. The World Health Organization Cancer Pain and Palliative Care Program. Past, present, and future. J Pain Symptom Manage. 96;12(2):65-72. [Rec#: 15569] Exclude at abstract screening: Title Only.
Stjernsward J. Uganda: initiating a government public health approach to pain relief and palliative care. J Pain Symptom Manage. 2002;24(2):257-64. [Rec#: 15568] Exclude at abstract screening: Title Only. [pmid: 12231159].
Stoddard S. Hospice: approaching the 21st century. Am J Hosp Palliat Care. 90;7(2):27-30. [Rec#: 15571] Exclude at abstract screening: Title Only. [pmid: 2193678].
Stoeckle M L, Doorley J E, McArdle R M. Identifying compliance with end-of-life care decision protocols. Dimens Crit Care Nurs. 98;17(6):314-21. [Rec#: 7384] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Stokes S A, Gordon S E. Common stressors experienced by the well elderly. Clinical implications. J Gerontol Nurs. 2003;29(5):38-46. [Rec#: 7386] Exclude at abstract screening: not about end of life. [pmid: 12765010].
Stolick M. Dying to meet you: facing mortality and enabling patient styles. Am J Hosp Palliat Care. 2003;20(4):269-73. [Rec#: 15578] Exclude at abstract screening: no outcomes specified. [pmid: 12911071].
Stolick M. Overcoming the tendency to lie to dying patients. Am J Hosp Palliat Care. 2002;19(1):29-34. [Rec#: 15579] Exclude at abstract screening: no outcomes specified. [pmid: 12171423].
Stone C. Prescribed hydration in palliative care. Br J Nurs. 93;2(7):353-7. [Rec#: 15582] Exclude at abstract screening: no outcomes specified. [pmid: 8508016].
Stone P, Hardy J, Broadley K, Tookman A J, Kurowska A, A'Hern R. Fatigue in advanced cancer: a prospective controlled cross-sectional study. Br J Cancer. 99;79(910):1479-86. [Rec#: 7388] Exclude at abstract screening: not about end of life.
Stone P, Phillips C, Spruyt O, Waight C. A comparison of the use of sedatives in a hospital support team and in a hospice. Palliat Med 97;11(2):140–4. Comment in: Palliat Med. Nov. 1997;11(6):493-4. PMID: 9519175. [Rec#: 7389] Exclude at abstract screening: not about end of life.
Stone P, Rees E, Hardy J R. End of life care in patients with malignant disease. Eur J Cancer. 2001;37(9):1070-5. [Rec#: 15584] Exclude at abstract screening: no outcomes specified. [pmid: 11378335].
Stooker T, van Acht J W, van Barneveld E M, van Vliet R C, van Hout B A, Hessing D J, Busschbach J J. Costs in the last year of life in The Netherlands. Inquiry. 2001;38(1):73-80. [Rec#: 15586] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11381724].
Storch J L, Dossetor J. Public attitudes towards end-of-life treatment decisions: implications for nurse clinicians and nursing administrators. Can J Nurs Adm. 94;7(3):65-89. [Rec#: 7391] Exclude at abstract screening: not about end of life.
Storey L, O'Donnell L, Howard A. Developing palliative care practice in the community. Nurs Stand. 2002;17(8):40-2. [Rec#: 15587] Exclude at abstract screening: no outcomes specified. [pmid: 12476808].
Storey P, Perkins F, Loughner J. Advanced pain & symptom management (a case study-workshop discussion). Am J Hosp Palliat Care. 96;13(1):30-9. [Rec#: 7393] Exclude at abstract screening: Title Only. [pmid: 8634179].
Storey P. Goals of hospice care. Tex Med. 90;86(2):50-4. [Rec#: 15588] Exclude at abstract screening: no outcomes specified. [pmid: 1689874].
Storey P. Hospice settings around the world. Am J Hosp Palliat Care. 93;10(4):4-5. [Rec#: 15589] Exclude at abstract screening: Title Only. [pmid: 8329247].
Storey P. Social workers and volunteers at different stages of palliative care. Am J Hosp Palliat Care. 94;11(2):5-7. [Rec#: 15590] Exclude at abstract screening: Title Only. [pmid: 7880639].
Storey P. Spiritual care at the end of life. Tex Med. 2001;97(8):56-9. [Rec#: 7392] Exclude at abstract screening: no outcomes specified. [pmid: 11503479].
Storey P. The vision of hospice and total pain relief. Am J Hosp Palliat Care. 96;13(1):40-9. [Rec#: 15591] Exclude at abstract screening: Title Only. [pmid: 8634180].
Storey P. What is the role of the hospice physician?. Am J Hosp Palliat Care. 90;7(6):6-7. [Rec#: 15592] Exclude at abstract screening: Title Only. [pmid: 14686464].
Storey P. What is the role of the hospice physician?. Am J Hosp Palliat Care. 92;9(6):4-5. [Rec#: 15593] Exclude at abstract screening: Title Only. [pmid: 1297388].
Storey P. Social workers and volunteers at different stages of palliative care. American Journal of Hospice & Palliative Care. 94;11(2):5-7. [Rec#: 50759] Exclude at abstract screening: Title Only. [pmid: 7880639].
Strahan GW. An overview of home health and hospice care patients: 1994 National Home and Hospice Care Survey. Adv Data 96;(274):1?8. [Rec#: 7398] Exclude at abstract screening: useful only for background
Strahan GW. An overview of home health and hospice care patients: preliminary data from the 1993 National Home and Hospice Care Survey. Adv Data 94;(256):1?12. [Rec#: 7399] Exclude at abstract screening: useful only for background
Strahan GW. Overview of home health and hospice care patients. Preliminary data from the 1992 National Home and Hospice Care Survey. Adv Data 93;(235):1?12. [Rec#: 15594] Exclude at abstract screening: useful only for background
Strang P, Strang S, Hultborn R, Arner S. Existential pain--an entity, a provocation, or a challenge?. J Pain Symptom Manage. 2004;27(3):241-50. [Rec#: 7401] Exclude at abstract screening: outcome unrelated to pts/family/non–prof. [pmid: 15010102].
Strang S, Strang P. Questions posed to hospital chaplains by palliative care patients. J Palliat Med. 2002;5(6):857-64. [Rec#: 7402] Exclude at abstract screening: Study Design – Qualitative. [pmid: 12685532].
Strang V R, Koop P M. Factors which influence coping: home-based family caregiving of persons with advanced cancer. J Palliat Care. 2003;19(2):107-14. [Rec#: 7403] Exclude at abstract screening: Study Design – Qualitative. [pmid: 12955927].
Strang V R, Koop P M, Peden J. The experience of respite during home-based family caregiving for persons with advanced cancer. J Palliat Care. 2002;18(2):97-104. [Rec#: 7404] Exclude at abstract screening: Study Design – Qualitative. [pmid: 12164107].
Strasser F, Bruera E D. Update on anorexia and cachexia. Hematol Oncol Clin North Am. 2002;16(3):589-617. [Rec#: 15598] Exclude at abstract screening: no outcomes specified. [pmid: 12170570].
Street A, Blackford J. Communication issues for the interdisciplinary community palliative care team. J Clin Nurs. 2001;10(5):643-50. [Rec#: 15602] Exclude at abstract screening: outcome unrelated to pts/family/non–prof. [pmid: 11822515].
Street A F, Kissane D W. Constructions of dignity in end-of-life care. J Palliat Care. 2001;17(2):93-101. [Rec#: 15603] Exclude at abstract screening: no outcomes specified. [pmid: 11477991].
Stringer S. Managing dysphagia in palliative care. Prof Nurse. 99;14(7):489-92. [Rec#: 15606] Exclude at abstract screening: no outcomes specified. [pmid: 10347531].
Stroebe M, Stroebe W. Does “grief work” work?. J Consult Clin Psychol. 91;59(3):479-82. [Rec#: 7411] Exclude at abstract screening: Bereavement only. [pmid: 2071736].
Stroebe M, Stroebe W, Schut H, Zech E, van den Bout J. Does disclosure of emotions facilitate recovery from bereavement? Evidence from two prospective studies. J Consult Clin Psychol. 2002;70(1):169-78. [Rec#: 7412] Exclude at abstract screening: Non–systematic review. [pmid: 11860043].
Stroebe M, van Son M, Stroebe W, Kleber R, Schut H, van den Bout J. On the classification and diagnosis of pathological grief. Clin Psychol Rev. 2000;20(1):57-75. [Rec#: 15611] Exclude at abstract screening: no outcomes specified. [pmid: 10660828].
Stroebe M S. New directions in bereavement research: exploration of gender differences. Palliat Med. 98;12(1):5-12. [Rec#: 15612] Exclude at abstract screening: no outcomes specified. [pmid: 9616454].
Stroebe W, Stroebe M, Abakoumkin G, Schut H. The role of loneliness and social support in adjustment to loss: a test of attachment versus stress theory. J Pers Soc Psychol. 96;70(6):1241-9. [Rec#: 7413] Exclude at abstract screening: Study Design – Unclear.
Stroud R. The withdrawal of life support in adult intensive care: an evaluative review of the literature. Nurs Crit Care. 2002;7(4):176-84. [Rec#: 7418] Exclude at abstract screening: Non–systematic review. [pmid: 12238709].
Stroud R. The withdrawal of life support in adult intensive care: an evaluative review of the literature. Nursing in Critical Care. 2002;7(4):176-84. [Rec#: 50760] Exclude at abstract screening: no outcomes specified. [pmid: 12238709].
Stuart B. Nurse–physician communication in home care and hospice: a physician's point of view. Home Care Provid. 96;1(5):264-6. [Rec#: 15617] Exclude at abstract screening: not about end of life. [pmid: 9272029].
Stuart B. The NHO Medical Guidelines for Non–Cancer Disease and local medical review policy: hospice access for patients with diseases other than cancer. Hosp J. 99;14(34):139-54. [Rec#: 15616] Exclude at abstract screening: useful only for background.
Stuart M E, Weinrich M. Beyond managing Medicaid costs: restructuring care. Milbank Q. 98;76(2):251-80. [Rec#: 7425] Exclude at abstract screening: not about end of life. [pmid: 9614422].
Stuart–Harris R. The Sacred Heart Hospice: an Australian centre for palliative medicine. Support Care Cancer. 95;3(5):280-4. [Rec#: 15618] Exclude at abstract screening: no outcomes specified.
Studnicki J, Schapira D V, Straumfjord J V, Clark R A, Marshburn J, Werner D C. A national profile of the use of intensive care by Medicare patients with cancer. Cancer. 94;74(8):2366-73. [Rec#: 43249] Exclude at abstract screening: Study Design – Unclear.
Stulginsky M. Colors of the spectrum. Hospice nursing: a loving practice. Nurs Spectr (Wash D C). 94;4(24):16. [Rec#: 15620] Exclude at abstract screening: Title Only. [pmid: 7994424].
Stutts J C. Veterinarians and their human clients. J Am Vet Med Assoc. 97;210(12):1742-4. [Rec#: 15622] Exclude at abstract screening: Title Only. [pmid: 9187721].
Subramanian U, Fihn S D, Weinberger M, Plue L, Smith F E, Udris E M, McDonell M B, Eckert G J, Temkit M, Zhou X H, Chen L, Tierney W M. A controlled trial of including symptom data in computer-based care suggestions for managing patients with chronic heart failure. Am J Med. 2004;116(6):375-84. [Rec#: 35410] Exclude at abstract screening: outcome unrelated to pts/family/non–prof. [pmid: 15006586].
Subratty A H, Manraj M, Baligadoo S. A new visual analogue scale for assessment of dyspnoea in congestive heart failure. Int J Clin Pharmacol Ther. 94;32(5):259-61. [Rec#: 35412] Exclude at abstract screening: Title Only. [pmid: 7921521].
Sugawara Y, Akechi T, Shima Y, Okuyama T, Akizuki N, Nakano T, Uchitomi Y. Efficacy of methylphenidate for fatigue in advanced cancer patients: a preliminary study. Palliat Med. 2002;16(3):261-3. [Rec#: 7430] Exclude at abstract screening: Title Only. [pmid: 12047006].
Sugden S, Dunbar C, KA KA. Is there a need for an interactive teaching tool on pain management in cancer?. Int J Palliat Nurs. 2003;9(11):485-8. [Rec#: 15625] Exclude at abstract screening: Title Only. [pmid: 14676725].
Suh E S, Bartlett G, Inguanti M, Folstad J. Evaluation of a pharmacist pain management education program and associated medication use in a palliative care population. Am J Health Syst Pharm. 2004;61(3):277-80. [Rec#: 7433] Exclude at abstract screening: Title Only. [pmid: 14986559].
Sullivan A M, Lakoma M D, Block S D. The status of medical education in end–of–life care: a national report. J Gen Intern Med. 2003;18(9):685-95. Comment in: J Gen Intern Med. 2003 Sep;18(9):770–1. PMID: 12950488. [Rec#: 15628] Exclude at abstract screening: outcome unrelated to pts/family/non–prof. [pmid: 12950476]. [pmcid: 1494921].
Sullivan J M, Mackey D M. Pressure ulcer care for a terminally ill patient being cared for at home. J Wound Ostomy Continence Nurs. 95;22(3):153-5. [Rec#: 7434] Exclude at abstract screening: Title Only. [pmid: 7599725].
Sullivan K E, Hebert P C, Logan J, O'Connor A M, McNeely P D. What do physicians tell patients with end–stage COPD about intubation and mechanical ventilation? Chest 96;109(1):258–64. Comment in: Chest. Jan. 1996;109(1):11-2. PMID: 8549170. [Rec#: 15629] Exclude at abstract screening: outcome unrelated to pts/family/non–prof.
Sullivan M C. Lost in translation: how Latinos view end-of-life care. Plast Surg Nurs. 2001;21(2):90-1. [Rec#: 7435] Exclude at abstract screening: no outcomes specified. [pmid: 12025132].
Sullivan M C. The changing order of things. Bioethics Forum. 98;14(1):37-40. [Rec#: 15630] Exclude at abstract screening: Title Only. [pmid: 11656890].
Sullivan M D. Hope and hopelessness at the end of life. Am J Geriatr Psychiatry. 2003;11(4):393-405. [Rec#: 7436] Exclude at abstract screening: no outcomes specified. [pmid: 12837668].
Sullivan M D. Maintaining good morale in old age. West J Med. 97;167(4):276-84. [Rec#: 7437] Exclude at abstract screening: not about end of life. [pmid: 9348760].
Sullivan M D. The illusion of patient choice in end–of–life decisions. Comment in: Am J Geriatr Psychiatry. 2002 Jul–Aug;10(4):362–4. PMID: 12095895. Comment in: Am J Geriatr Psychiatry. Jan-Feb. 2003;11(1):113-4. PMID: 12527550. [Rec#: 15632] Exclude at abstract screening: no outcomes specified.
Sullivan M D. Treatment of Depression at the End of Life: Clinical and Ethical Issues. Semin Clin Neuropsychiatry. 98;3(2):151-156. [Rec#: 7438] Exclude at abstract screening: useful only for background.
Sullivan M F, Guntzelman J. The grieving process in cultural change. Health Care Superv. 91;10(2):28-33. [Rec#: 15633] Exclude at abstract screening: not about end of life. [pmid: 10114918].
Sulmasy D P, Lynn J. End-of-life care. JAMA 97;277(23):1854–5. Comment in: JAMA. Oct 8. 1997;278(14):1150-1. PMID: 9326471. [Rec#: 15640] Exclude at abstract screening: Title Only.
Sulmasy D P, Dwyer M, Marx E. Do the ward notes reflect the quality of end–of–life care?. J Med Ethics. 96;22(6):344-8. [Rec#: 15638] Exclude at abstract screening: Observational study. [pmid: 8961119].
Sulmasy DP. A biopsychosocial-spiritual model for the care of patients at the end of life. Gerontologist 2002;42 Spec No 3:24–33. Comment in: Gerontologist. 2002 Oct;42 Spec No 3:34–9. PMID: 12415131. [Rec#: 15635] Exclude at abstract screening: useful only for background
Sulmasy D P. Addressing the religious and spiritual needs of dying patients. West J Med. 2001;175(4):251-4. [Rec#: 7439] Exclude at abstract screening: Title Only. [pmid: 11577054]. [pmcid: 1071572].
Sulmasy D P. At wit's end: forgiveness, dignity, and the care of the dying. J Gen Intern Med 2001;16(5):335–8. Comment on: J Gen Intern Med. 2001 May;16(5):315–9. PMID: 11359550. Comment in: J Gen Intern Med. May. 2001;16(5):339-41. PMID: 11359554. [Rec#: 15634] Exclude at abstract screening: not about end of life.
Sulzbach?Hoke LM, Kagan SH, and Craig K. Weighing behavior and symptom distress of clinic patients with CHF. Medsurg Nurs 97;6(5):288?93, 314. [Rec#: 35427] Exclude at abstract screening: Study Design ? Unclear
Sumaya–Smith I. Caregiver/resident relationships: surrogate family bonds and surrogate grieving in a skilled nursing facility. J Adv Nurs. 95;21(3):447-51. [Rec#: 7444] Exclude at abstract screening: not about end of life.
Summers J. Dying patients: ethical issues and management perspectives. J Healthc Mater Manage. 93;11(5):60-1. [Rec#: 7448] Exclude at abstract screening: Title Only. [pmid: 10126478].
Sunvisson H, Ekman S L. Environmental influences on the experiences of people with Parkinson's disease. Nurs Inq. 2001;8(1):41-50. [Rec#: 7456] Exclude at abstract screening: Study Design – Qualitative. [pmid: 11882200].
Super A, Plutko L A. Danger signs. Coalition points to causes and consequences of inadequate care of the dying. Health Prog. 96;77(2):50-4. [Rec#: 15647] Exclude at abstract screening: no outcomes specified.
Super A. Going one step further: skilled pain assessment and the art of adjuvant analgesia. Am J Hosp Palliat Care. 97;14(6):279-84. [Rec#: 7457] Exclude at abstract screening: no outcomes specified.
Super A. Improving pain management practice. A medical center moves beyond education to document and manage patient care. Health Prog. 96;77(4):50-4. [Rec#: 15646] Exclude at abstract screening: not about end of life.
SUPPORT Principal Investigators. A controlled trial to improve care for seriously ill hospitalized patients. The study to understand prognoses and preferences for outcomes and risks of treatments (SUPPORT). JAMA 95;274(20):1591?8. [Rec#: 50761] Exclude at abstract screening: Duplicate already in the flow
Supportive care pathway comforts the terminally ill. Hosp Case Manag 98;6(4):69–72. [Rec#: 15651] Exclude at abstract screening: no outcomes specified
Supportive care. Curr Opin Oncol 97;9(4):B89–99. [Rec#: 15650] Exclude at abstract screening: Title Only
Surtees P G, Miller P M. Partners in adversity. III. Mood status after the event. Eur Arch Psychiatry Clin Neurosci. 94;243(6):311-8. [Rec#: 7467] Exclude at abstract screening: Bereavement only. [pmid: 8043616].
Surtees P G, Miller P M. Partners in adversity: I Study design and context. Eur Arch Psychiatry Clin Neurosci. 93;242(4):224-32. [Rec#: 7466] Exclude at abstract screening: Study Design – Unclear. [pmid: 8461349].
Surtees P G, Wainwright N W. Surviving adversity: event decay, vulnerability and the onset of anxiety and depressive disorder. Eur Arch Psychiatry Clin Neurosci. 99;249(2):86-95. [Rec#: 7468] Exclude at abstract screening: not about end of life.
Surtees P G. In the shadow of adversity: the evolution and resolution of anxiety and depressive disorder. Br J Psychiatry 95;166(5):583–94. Comment in: Br J Psychiatry. Aug. 1995;167(2):266. Comment in: Br J Psychiatry. 1995 Aug;167(2):266. PMID: 7582684. [Rec#: 7465] Exclude at abstract screening: not about end of life.
Sutcliffe J, Holmes S. Dehydration: burden or benefit to the dying patient?. J Adv Nurs. 94;19(1):71-6. [Rec#: 15655] Exclude at abstract screening: no outcomes specified. [pmid: 8138633].
Sutherland A. Gypsies and health care. West J Med. 92;157(3):276-80. [Rec#: 15657] Exclude at abstract screening: no outcomes specified. [pmid: 1413769].
Sutherland D D, Morgan R C. Dying and social policy in the new millennium. J Aging Soc Policy. 2000;11(23):145-55. [Rec#: 7470] Exclude at abstract screening: Title Only. [pmid: 11185040].
Sutherland L. Island of strength. Nurs Times. 92;88(27):44-5. [Rec#: 15659] Exclude at abstract screening: Title Only. [pmid: 1625980].
Sutton L M, Demark-Wahnefried W, Clipp E C. Management of terminal cancer in elderly patients. Lancet Oncol. 2003;4(3):149-57. [Rec#: 7471] Exclude at abstract screening: useful only for background. [pmid: 12623360].
Sutton P M, Khan S M, Khan M. Cancer pain can be relieved. World Health Forum. 90;11(2):210-3. [Rec#: 7472] Notes: “EXCLUDE: Location, non–Western”. [pmid: 1702971].
Sutton R B. Supporting the bereaved relative: reflections on the actor's experience. Med Educ. 98;32(6):622-9. [Rec#: 15661] Exclude at abstract screening: outcome unrelated to pts/family/non–prof.
Swanson E A, Maas M L, Buckwalter K C. Alzheimer's residents' cognitive and functional measures: special and traditional care unit comparison. Clin Nurs Res. 94;3(1):27-41. [Rec#: 35449] Exclude at abstract screening: not about end of life.
Swanson J W, McCrary S V. Medical futility decisions and physicians' legal defensiveness: the impact of anticipated conflict on thresholds for end–of–life treatment. Soc Sci Med. 96;42(1):125-32. [Rec#: 7475] Exclude at abstract screening: primarily prognosis or trajectories.
Swartz R D, Perry E, Schneider C, Burdette T, Curtis G, O'Neil M. The option to withdraw from chronic dialysis treatment. Adv Ren Replace Ther. 94;1(3):264-73. [Rec#: 7479] Exclude at abstract screening: no outcomes specified.
Sweeney M P, Bagg J. Oral care for hospice patients with advanced cancer. Dent Update. 95;22(10):424-7. [Rec#: 15671] Exclude at abstract screening: Study Design – Unclear. [pmid: 8948189].
Sweeney M P, Bagg J, Baxter W P, Aitchison T C. Clinical trial of a mucin–containing oral spray for treatment of xerostomia in hospice patients. Palliat Med. 97;11(3):225-32. [Rec#: 7482] Exclude at abstract screening: outcome unrelated to pts/family/non–prof.
Sweeney C, Beattie-Palmer L, Palmer J L, Bruera E. Changing patterns of symptom control and palliative care paper presentations at the annual meeting of the American Society of Clinical Oncology. Journal of Clinical Oncology. 2001;19(14):3438-9. [Rec#: 50762] Exclude at abstract screening: Title Only. [pmid: 11454893].
Sweeting H N, Gilhooly M L. Anticipatory grief: a review. Soc Sci Med. 90;30(10):1073-80. [Rec#: 7483] Exclude at abstract screening: Non–systematic review. [pmid: 2194293].
Swisher L A, Nieman L Z, Nilsen G J, Spivey W H. Death notification in the emergency department: a survey of residents and attending physicians. Ann Emerg Med. 93;22(8):1319-23. [Rec#: 15675] Exclude at abstract screening: outcome unrelated to pts/family/non–prof.
Sykes N, Thorns A. Sedative use in the last week of life and the implications for end-of-life decision making. Arch Intern Med. 2003;163(3):341-4. [Rec#: 7488] Exclude at abstract screening: Other topic only. [pmid: 12578515].
Sykes N, Thorns A. The use of opioids and sedatives at the end of life. Lancet Oncol. 2003;4(5):312-8. [Rec#: 15677] Exclude at abstract screening: useful only for background. [pmid: 12732169].
Sykes N P. An investigation of the ability of oral naloxone to correct opioid–related constipation in patients with advanced cancer. Palliat Med. 96;10(2):135-44. [Rec#: 7489] Exclude at abstract screening: Other topic only.
Sykes N P. Current approaches to the management of constipation. Cancer Surv. 94;21:137-46. [Rec#: 15678] Exclude at abstract screening: no outcomes specified. [pmid: 8564989].
Sykes N P. The relationship between opioid use and laxative use in terminally ill cancer patients. Palliat Med. 98;12(5):375-82. [Rec#: 15679] Exclude at abstract screening: Other symptoms only. [pmid: 9924600].
Symons D M. Palliative response team. Can Nurse. 92;88(9):36-7. [Rec#: 15681] Exclude at abstract screening: Title Only. [pmid: 1477840].
Symptom management strategies for dying patients. Mich Nurse 2000;73(1):10–7. [Rec#: 15682] Exclude at abstract screening: Title Only
Symptom management strategies for dying patients. Mich Nurse 2000;73(2):10–3; quiz 14–5 [Rec#: 15683] Exclude at abstract screening: no outcomes specified
Syrjala K L, Donaldson G W, Davis M W, Kippes M E, Carr J E. Relaxation and imagery and cognitive–behavioral training reduce pain during cancer treatment: a controlled clinical trial. Pain. 95;63(2):189-98. [Rec#: 7491] Exclude at abstract screening: not about end of life.
Taboada P, Bruera E. Ethical decision–making on communication in palliative cancer care: a personalist approach. Support Care Cancer 2001;9(5):335–43. Comment in: Support Care Cancer. Jul. 2001;9(5):329. Comment in: Support Care Cancer. 2001 Jul;9(5):329. PMID: 11497384. [Rec#: 7502] Exclude at abstract screening: no outcomes specified.
Tache S, Chapuis V, Goehring C, Loutan L. Access to palliative care in Bosnia-Herzegovina: a primary care issue. Eur J Gen Pract. 2004;10(1):31-2. [Rec#: 7504] Exclude at abstract screening: Title Only. [pmid: 15060480].
Tada T, Hashimoto F, Matsushita Y, Terashima Y, Tanioka T, Nagamine I, Fujioka H, Akiyama N. Investigation of QOL of hospice patients by using EORTC-QLQ-C30 questionnaire. J Med Invest. 2004;51(12):125-31. [Rec#: 7507] Notes: “EXCLUDE: Location, non–Western”. [pmid: 15000266].
Taenzer P, Bultz B D, Carlson L E, Speca M, DeGagne T, Olson K, Doll R, Rosberger Z. Impact of computerized quality of life screening on physician behaviour and patient satisfaction in lung cancer outpatients. Psychooncology. 2000;9(3):203-13. [Rec#: 35469] Exclude at abstract screening: not about end of life. [pmid: 10871716].
Tait A, Maguire P, Faulkner A, Brooke M, Wilkinson S, Thomson L, Sellwood R. Improving communication skills. Nursing Times. 82;78(51):2181-4. [Rec#: 50763] Exclude at abstract screening: Title Only. [pmid: 6925224].
Takahashi Y. Informing a patient of malignant illness: commentary from a cross–cultural viewpoint. Death Stud. 90;14(1):83-91. [Rec#: 15693] Exclude at abstract screening: Title Only. [pmid: 11651015].
Takkinen S, Ruoppila I. Meaning in life in three samples of elderly persons with high cognitive functioning. Int J Aging Hum Dev. 2001;53(1):51-73. [Rec#: 7515] Exclude at abstract screening: not about end of life. [pmid: 11678356].
Talerico K A. Grief & older adults. Differences, issues, and clinical approaches. J Psychosoc Nurs Ment Health Serv. 2003;41(7):12-6. [Rec#: 7520] Exclude at abstract screening: Title Only.
Talmi Y P, Bercovici M, Waller A, Horowitz Z, Adunski A, Kronenberg J. Home and inpatient hospice care of terminal head and neck cancer patients. J Palliat Care. 97;13(1):9-14. [Rec#: 7522] Notes: “EXCLUDE: Location, non–Western”. [pmid: 9105152].
Tam L Q. Care of the dying at the John A. Burns School of Medicine University of Hawaii. Hawaii Med J. 96;55(12):293. [Rec#: 15702] Exclude at abstract screening: Title Only. [pmid: 9009464].
Tamburini J K. Lessons on a minimally acceptable quality of life. Bioethics Forum. 97;13(2):38-41. [Rec#: 7527] Exclude at abstract screening: not about end of life. [pmid: 11655289].
Tamburini M, Brunelli C, Rosso S, Ventafridda V. Prognostic value of quality of life scores in terminal cancer patients. J Pain Symptom Manage. 96;11(1):32-41. [Rec#: 7528] Exclude at abstract screening: primarily prognosis or trajectories.
Tamm M E. Personification of life and death among Swedish health care professionals. Death Stud. 96;20(1):1-22. [Rec#: 7529] Exclude at abstract screening: not about end of life. [pmid: 10160529].
Tanaka A, Iwamoto T, Kaneyasu H, Petrini M A. Thoughts and feelings of in–patients with advanced terminal cancer: implications for terminal care improvement. Nurs Health Sci. 99;1(3):189-93. [Rec#: 7540] Notes: “EXCLUDE: Location, non–Western”.
Tanaka K, Shima Y, Kakinuma R, Kubota K, Ohe Y, Hojo F, Matsumoto T, Ohmatsu H, Goto K, Nagai K, Nishiwaki Y. Effect of nebulized morphine in cancer patients with dyspnea: a pilot study. Jpn J Clin Oncol. 99;29(12):600-3. [Rec#: 35496] Exclude at abstract screening: Observational study.
Tanaka K, Akechi T, Okuyama T, Nishiwaki Y, Uchitomi Y. Development and validation of the cancer dyspnoea scale: a multidimensional, brief, self-rating scale. British Journal of Cancer. 2000;82:800-805. [Rec#: 50764] Exclude at abstract screening: Title Only. [pmid: 10732749].
Tang S T, McCorkle R. Determinants of place of death for terminal cancer patients. Cancer Invest. 2001;19(2):165-80. [Rec#: 15731] Exclude at abstract screening: Non–systematic review. [pmid: 11296621].
Tang S T, McCorkle R. Use of family proxies in quality of life research for cancer patients at the end of life: a literature review. Cancer Invest. 2002;20(78):1086-104. [Rec#: 15732] Exclude at abstract screening: Non–systematic review. [pmid: 12449742].
Tarrant J. Aspects of palliative care: pain management and hydration. Aust Nurs J. 2001;8(10):suppl 1-3. [Rec#: 15738] Exclude at abstract screening: Title Only. [pmid: 11894483].
Tarumi Y, Taube A, Watanabe S. Clinical pastoral education: a physician's experience and reflection on the meaning of spiritual care in palliative care. J Pastoral Care Counsel. 2003;57(1):27-31. [Rec#: 15740] Exclude at abstract screening: not about end of life. [pmid: 12728761].
Tarumi Y, Watanabe s, Bruera E, Ishitani K. High-dose ketamine in the management of cancer-related neuropathic pain. Journal of Pain & Symptom Management. 2000;19(6):405-7. [Rec#: 50765] Exclude at abstract screening: no outcomes specified. [pmid: 10991642].
Tarzian A J, Davidson S M, Hoffmann D E. Management of cancer-related and noncancer-related chronic pain in Connecticut: successes and failures. Conn Med. 2002;66(11):683-9. [Rec#: 7556] Exclude at abstract screening: not about end of life. [pmid: 12476511].
Tarzian A J. Caring for dying patients who have air hunger. J Nurs Scholarsh. 2000;32(2):137-43. [Rec#: 7555] Exclude at abstract screening: Observational study. [pmid: 10887712].
Tatara K. On putting life first. Lancet 95;346(8971):327–8. Comment on: Lancet. 1995 Aug 5;346(8971):356–9. PMID: 7623536. Comment in: Lancet. Oct 7. 1995;346(8980):970-1. PMID: 7564756. [Rec#: 15742] Exclude at abstract screening: no outcomes specified.
Tate T. Palliative medicine: its content and training. Br J Hosp Med 90;44(2):140–1. Comment in: Br J Hosp Med. Oct. 1990;44(4):242. PMID: 1701105. [Rec#: 15744] Exclude at abstract screening: no outcomes specified.
Tattersall M H, Butow P N, Clayton J M. Insights from cancer patient communication research. Hematol Oncol Clin North Am. 2002;16(3):731-43. [Rec#: 15746] Exclude at abstract screening: no outcomes specified. [pmid: 12170578].
Taube A W, Bruera E. Collegial disagreements over appropriate palliative care: a case study. J Pain Symptom Manage. 99;18(1):67-71. [Rec#: 7562] Exclude at abstract screening: not about end of life. [pmid: 10439576].
Taugher T. Helping patients search for meaning in their lives. Clin J Oncol Nurs. 2002;6(4):239-40. [Rec#: 15748] Exclude at abstract screening: Title Only. [pmid: 12180376].
Taylor A, Box M. Multicultural Palliative Care Guidelines. 1999;<25 Page(s)>. [Rec#: 50766] Exclude at abstract screening: Title Only
Taylor B, Bulmer B, Hill L, Luxford C, McFarlane J, Reed J, Stirling K. Exploring idealism in palliative nursing care through reflective practice and action research. Int J Palliat Nurs. 2002;8(7):324-30. [Rec#: 7570] Exclude at abstract screening: outcome unrelated to pts/family/non–prof. [pmid: 12165716].
Taylor B, Glass N, McFarlane J, Stirling K. Views of nurses, patients and patients' families regarding palliative nursing care. Int J Palliat Nurs. 2001;7(4):186-91. [Rec#: 7571] Exclude at abstract screening: outcome unrelated to pts/family/non–prof. [pmid: 11951286].
Taylor C. Patients' experiences of 'feeling on their own' following a diagnosis of colorectal cancer: a phenomenological approach. Int J Nurs Stud. 2001;38(6):651-61. [Rec#: 15753] Exclude at abstract screening: not about end of life. [pmid: 11602269].
Taylor E J, Amenta M. Midwifery to the soul while the body dies: spiritual care among hospice nurses. Am J Hosp Palliat Care. 94;11(6):28-35. [Rec#: 7573] Exclude at abstract screening: no outcomes specified.
Taylor E J, Highfield M F, Amenta M. Predictors of oncology and hospice nurses' spiritual care perspectives and practices. Appl Nurs Res. 99;12(1):30-7. [Rec#: 7574] Exclude at abstract screening: outcome unrelated to pts/family/non–prof.
Taylor J. Coping with the stress on carers. Practitioner. 90;234(1485):300-1. [Rec#: 15756] Exclude at abstract screening: Title Only. [pmid: 2284270].
Taylor M A. Benefits of dehydration in terminally ill patients. Geriatr Nurs. 95;16(6):271-2. [Rec#: 15758] Exclude at abstract screening: Title Only. [pmid: 7498817].
Taylor P, Ferszt G. The nurse as patient advocate. Nursing. 98;28(8):70-1. [Rec#: 15760] Exclude at abstract screening: not about end of life. [pmid: 9739262].
Taylor P B, Ferszt G G. Spiritual healing. Holist Nurs Pract. 90;4(4):32-8. [Rec#: 15762] Exclude at abstract screening: Title Only. [pmid: 2365751].
Taylor E J, Amenta M, Highfield M. Spiritual care practices of oncology nurses. Oncology Nursing Forum. 95;22(1):31-9. [Rec#: 50768] Exclude at abstract screening: outcome unrelated to pts/family/non–prof. [pmid: 7708523].
Tearnan B H, Ward C H. Assessment of the terminally ill patient with pain: the example of cancer. Hosp J. 92;8(12):49-71. [Rec#: 15768] Exclude at abstract screening: Study Design – Unclear. [pmid: 1286852].
Tecca M. Performance measurement now. Caring. 2002;21(10):32-7. [Rec#: 15770] Exclude at abstract screening: no outcomes specified. [pmid: 12395631].
Teel C S, Meek P, McNamara A M, Watson L. Perspectives unifying symptom interpretation. Image J Nurs Sch. 97;29(2):175-81. [Rec#: 15772] Exclude at abstract screening: not about end of life. [pmid: 9212516].
Teel C S. Chronic sorrow: analysis of the concept. J Adv Nurs. 91;16(11):1311-9. [Rec#: 15771] Exclude at abstract screening: not about end of life. [pmid: 1753027].
Tehan C. The cost of caring for patients with HIV infection in hospice. Hosp J. 91;7(12):41-59. [Rec#: 15774] Exclude at abstract screening: outcome unrelated to pts/family/non–prof. [pmid: 1937438].
Tempero M A. Walking a difficult path is easier with a friend. Thoughts from a practicing oncologist. Ann N Y Acad Sci. 97;809:237-42. [Rec#: 15779] Exclude at abstract screening: Title Only. [pmid: 9103574].
Templer D I, Lavoie M, Chalgujian H, Thomas-Dobson S. The measurement of death depression. J Clin Psychol. 90;46(6):834-9. [Rec#: 7590] Exclude at abstract screening: Study Design – Unclear. [pmid: 2286679].
Tengs T O, Adams M E, Pliskin J S, Safran D G, Siegel J E, Weinstein M C, Graham J D. Five–hundred life–saving interventions and their cost–effectiveness. Risk Ana 95;15(3):369–90. Comment in: Risk Anal. Apr. 1996;16(2):100. Comment in: Risk Anal. 1996 Apr;16(2):131. PMID: 8638035. [Rec#: 15783] Exclude at abstract screening: not about end of life.
Teno J, Fleishman J, Brock D W, Mor V. The use of formal prior directives among patients with HIV–related diseases. J Gen Intern Med. 90;5(6):490-4. [Rec#: 15786] Exclude at abstract screening: Study Design – Qualitative.
Teno J, Lynn J, Connors A F Jr, Wenger N, Phillips R S, Alzola C, Murphy D P, Desbiens N, Knaus W A. The illusion of end–of–life resource savings with advance directives. SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatment. J Am Geriatr Soc. Comment in: J Am Geriatr Soc. Apr. 1997;45(4):519-20. Comment in: J Am Geriatr Soc. 1997 Apr;45(4):519–20. PMID: 9100724. [Rec#: 7591] Exclude at abstract screening: Other topic only.
Teno J. Time: Toolkit of Instruments to Measure End–of–life Care. 2004;<25 Page(s)>. [Rec#: 50904] Exclude at abstract screening: Study Design – Review/Meta
Teno J M, Coppola K M. For every numerator, you need a denominator: a simple statement but key to measuring the quality of care of the “dying”. J Pain Symptom Manage. 99;17(2):109-13. [Rec#: 15791] Exclude at abstract screening: useful only for background.
Teno J M, Lynn J. Putting advance–care planning into action. J Clin Ethics. 96;7(3):205-13. [Rec#: 15793] Exclude at abstract screening: Title Only. [pmid: 8981191].
Teno J M, Byock I, Field M J. Research agenda for developing measures to examine quality of care and quality of life of patients diagnosed with life–limiting illness. J Pain Symptom Manage. 99;17(2):75-82. [Rec#: 15789] Exclude at abstract screening: no outcomes specified.
Teno J M, Casey V A, Welch L C, Edgman-Levitan S. Patient-focused, family-centered end-of-life medical care: views of the guidelines and bereaved family members. J Pain Symptom Manage. 2001;22(3):738-51. [Rec#: 15790] Exclude at abstract screening: Study Design – Qualitative. [pmid: 11532587].
Teno J M, Field M J, Byock I. Preface: The road taken and to be traveled in improving end-of-life care. J Pain Symptom Manage. 2001;22(3):713-6. [Rec#: 15792] Exclude at abstract screening: Title Only. [pmid: 11532584].
Teno J M, Fisher E S, Hamel M B, Coppola K, Dawson N V. Medical care inconsistent with patients' treatment goals: association with 1-year Medicare resource use and survival. J Am Geriatr Soc. 2002;50(3):496-500. [Rec#: 43329] Exclude at abstract screening: Title Only. [pmid: 11943046].
Teno J M, Landrum K, Lynn J. Defining and measuring outcomes in end–stage dementia. Alzheimer Dis Assoc Disord. 97;11(Suppl 6):25-9. [Rec#: 7595] Exclude at abstract screening: useful only for background.
Teno JM, Lynn J, Phillips RS, Murphy D, Youngner SJ, Bellamy P, Connors AF Jr, Desbiens NA, Fulkerson W, and Knaus WA. Do formal advance directives affect resuscitation decisions and the use of resources for seriously ill patients? SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatments. J Clin Ethics 94;5(1):23?30. Comment in: J Clin Ethics. 1994 Spring;5(1):55?6. PMID: 8003727. Comment in: J Clin Ethics. 1994 Spring;5(1):57?60. PMID: 8003728. Comment in: J Clin Ethics. 1994 Spring;5(1):60?1. PMID: 8003729. [Rec#: 43330] Exclude at abstract screening: Title Only
Teno J M. Palliative care teams: self-reflection - past, present, and future. J Pain Symptom Manage. 2002;23(2):94-5. [Rec#: 15787] Exclude at abstract screening: no outcomes specified. [pmid: 11844628].
Teno J M. Putting patient and family voice back into measuring quality of care for the dying. Hosp J. 99;14(34):167-76. [Rec#: 15788] Exclude at abstract screening: no outcomes specified. [pmid: 10839009].
Teno J M, Hakim R B, Knaus W A, Wenger N S, Phillips R S, Wu A W, Layde P, Connors A F Jr, Dawson N V, Lynn J. Preferences for cardiopulmonary resuscitation: physician–patient agreement and hospital resource use. The SUPPORT Investigators. Journal of General Internal Medicine. 95;10(4):179-86. [Rec#: 50770] Exclude at abstract screening: Study Design – Unclear.
Teno J M, Harrell F E Jr, Knaus W, Phillips R S, Wu A W, Connors A Jr, Wenger N S, Wagner D, Galanos A, Desbiens N A, Lynn J. Prediction of survival for older hospitalized patients: the HELP survival model. Hospitalized Elderly Longitudinal Project. Journal of the American Geriatrics Society. 2000;48(5 Suppl):S16-24. [Rec#: 50771] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 10809452].
Teno J M, Mor V, Fleishman J. Preferences of HIV–infected patients for aggressive versus palliative care. New England Journal of Medicine. 91;324(16):1140. [Rec#: 50774] Exclude at abstract screening: Title Only. [pmid: 1706820].
Teno J M, Mor V, DeSilva D, Kabumoto G, Roy J, Wetle T. Use of feeding tubes in nursing home residents with severe cognitive impairment. JAMA. 2002;287(24):3211-2. [Rec#: 50773] Exclude at abstract screening: Title Only. [pmid: 12076216].
Teno J M, Murphy D, Murphy D, Lynn J, Tosteson A, Desbiens N, Connors A F Jr, Hamel M B, Wu A, Phillips R, Wenger N. Prognosis–based futility guidelines: does anyone win? SUPPORT Investigators. Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatment. Journal of the American Geriatrics Society. 94;42(11):1202-7. [Rec#: 50775] Exclude at abstract screening: primarily prognosis or trajectories.
Teno J M, Stevens M, Spernak S, Lynn J. Role of written advance directives in decision making: insights from qualitative and quantitative data. Journal of General Internal Medicine. 98;13(7):439-46. [Rec#: 50776] Exclude at abstract screening: Observational study.
Teno J M, Weitzen S, Wetle T, Mor V. Persistent pain in nursing home residents. JAMA. 2001;285(16):2081. [Rec#: 50777] Exclude at abstract screening: Title Only. [pmid: 11311096].
Tepper D. Randomized trial of an education and support intervention to prevent readmission of patients with heart failure. Congest Heart Fail. 2002;8(1):58. [Rec#: 50102] Exclude at abstract screening: Title Only. [pmid: 11821631].
Teri L. Behavioral treatment of depression in patients with dementia. Alzheimer Dis Assoc Disord. 94;8(Suppl 3):66-74. [Rec#: 35541] Exclude at abstract screening: not about end of life. [pmid: 7999348].
Terminal care: not just pain management. Prescrire Int 98;7(34):57–63. [Rec#: 15795] Exclude at abstract screening: no outcomes specified
Terminally ill patients' perception of home care. Prof Nurse 94;10(1):52. [Rec#: 15796] Exclude at abstract screening: Title Only
Ternestedt B M, Andershed B M, Eriksson, Johansson I. A good death: Development of a nursing model of care. Journal of Hospice and Palliative Nursing. 2002;4(3):153-160. [Rec#: 50778] Exclude at abstract screening: Study Design – Unclear.
Terry M, Zweig S. Residents talk about end–of–life issues. J Long Term Care Adm. 94;22(3):11-5. [Rec#: 7598] Exclude at abstract screening: Title Only. [pmid: 10139524].
Terry PB, Vettese M, Song J, Forman J, Haller KB, Miller DJ, Stallings R, and Sulmasy DP. End-of-life decision making: when patients and surrogates disagree. J Clin Ethics 99;10(4):286–93. Comment in: J Clin Ethics. 2000 Fall;11(3):284. PMID: 11127643. [Rec#: 7599] Exclude at abstract screening: Title Only
Thalhuber W. Palliative care in Minnesota. Minn Med. 2000;83(5):52-3. [Rec#: 15801] Exclude at abstract screening: no outcomes specified. [pmid: 10832317].
Thalhuber W H. Overcoming physician barriers to hospice care. Minn Med. 95;78(2):18-22. [Rec#: 7608] Exclude at abstract screening: no outcomes specified. [pmid: 7891645].
Thatcher N, Niven R M, Anderson H. Aggressive vs nonaggressive therapy for metastatic NSCLC. Chest. 96;109(5 Suppl):87S-92S. [Rec#: 35562] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Thatcher N. The role of chemotherapy (CT) and supportive care (SC) in advanced non-small cell lung cancer (NSCLC). Lung Cancer. 2002;38(Suppl 3):S71-3. [Rec#: 15803] Exclude at abstract screening: Title Only. [pmid: 12468151].
Thayre K, Hadfield-Law L. Never going to be easy: giving bad news (continuing education credit). Nurs Stand. 93;8(12 Suppl NU):3-8. quiz 11–3. [Rec#: 7611] Exclude at abstract screening: no outcomes specified.
Thayre K, Hadfield-Law L. Never going to be easy: giving bad news. Nurs Stand. 95;9(50 Suppl Nu):3-8. quiz 12. [Rec#: 15805] Exclude at abstract screening: not about end of life. [pmid: 7547266].
The SUPPORT study: can one die a “good death” in the hospital? Study to Understand Prognoses and Preferences for Outcomes and Risks of Treatment. J Health Hosp Law 96;29(5):312–4. [Rec#: 15649] Exclude at abstract screening: Title Only
Theut S K, Jordan L, Ross L A, Deutsch S I. Caregiver's anticipatory grief in dementia: a pilot study. Int J Aging Hum Dev. 91;33(2):113-8. [Rec#: 7614] Exclude at abstract screening: Observational study. [pmid: 1955206].
Thielemann P. Educational needs of home caregivers of terminally ill patients: literature review. Am J Hosp Palliat Care. 2000;17(4):253-7. [Rec#: 15808] Exclude at abstract screening: Non-systematic review. [pmid: 11883801].
Thielemann P. Educational needs of home caregivers of terminally ill patients: literature review. American Journal of Hospice & Palliative Care. 2000;17(4):253-7. [Rec#: 50779] Exclude at abstract screening: Duplicate already in the flow. [pmid: 11883801].
Thobaben M. Helping terminally ill clients experience a “good death”. Home Care Provid. 2000;5(6):202-3. [Rec#: 15812] Exclude at abstract screening: Title Only. [pmid: 11113780].
Thomas D. Where there's a Will … planning for difficult times. Pract Midwife. 2003;6(10):24-5. [Rec#: 15814] Exclude at abstract screening: Title Only. [pmid: 14639916].
Thomas J R, von Gunten C F. Pain in terminally ill patients: guidelines for pharmacological management. CNS Drugs. 2003;17(9):621-31. [Rec#: 15817] Exclude at abstract screening: useful only for background. [pmid: 12828498].
Thomas J R, Von Gunten C F. Treatment of dyspnea in cancer patients. Oncology (Huntingt). 2002;16(6):745-50. discussion 750, 755, 758–60. [Rec#: 15818] Exclude at abstract screening: useful only for background. [pmid: 12088297].
Thomas K L, Aaron G B. Hospital provides hospice are through palliative care service. Oncol Nurs Forum. 96;23(1):117. [Rec#: 15820] Exclude at abstract screening: Title Only. [pmid: 8628702].
Thomas M B, Quinn C. Palliative care: rapid redesign to support systemwide quality improvement. J Healthc Qual. 2002;24(1):25-9. [Rec#: 15821] Exclude at abstract screening: Study Design-Unclear. [pmid: 11813531].
Thomas N D. The importance of culture throughout all of life and beyond. Holist Nurs Pract. 2001;15(2):40-6. [Rec#: 15823] Exclude at abstract screening: no outcomes specified. [pmid: 12119918].
Thomas R. Patients' perceptions of visiting: a phenomenological study in a specialist palliative care unit. Palliat Med. 2001;15(6):499-504. [Rec#: 15824] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12403508].
Thomas S, MacMahon D. Parkinson's disease, palliative care and older people: Part 1. Nurs Older People. 2004;16(1):22-6. [Rec#: 7622] Exclude at abstract screening: no outcomes specified.
Thomas S. Community care. Lessons to be learnt. Nurs Times. 93;89(26):38-9. [Rec#: 7621] Exclude at abstract screening: Title Only. [pmid: 8327346].
Thomas S A, Friedmann E, Khatta M, Cook L K, Lann A L. Depression in patients with heart failure: physiologic effects, incidence, and relation to mortality. AACN Clin Issues. 2003;14(1):3-12. [Rec#: 35574] Exclude at abstract screening: no outcomes specified. [pmid: 12574698].
Thomas Z, Bruera E. Use of methadone in a highly tolerant patient receiving parenteral hydromorphone. J Pain Symptom Manage. 95;10(4):315-7. [Rec#: 7623] Exclude at abstract screening: Observational study.
Thomasma D C. Telling the truth to patients: a clinical ethics exploration. Camb Q Healthc Ethics. 94;3(3):375-82. [Rec#: 7625] Exclude at abstract screening: Title Only. [pmid: 7994462].
Thome B, Dykes A K, Hallberg I R. Home care with regard to definition, care recipients, content and outcome: systematic literature review. J Clin Nurs. 2003;12(6):860-72. [Rec#: 7627] Exclude at abstract screening: not about end of life. [pmid: 14632979].
Thompson A R, Savidge M A, Fulper-Smith M, Strode S W. Testing a multimedia module in cancer pain management. J Cancer Educ. 99;14(3):161-3. [Rec#: 15828] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Thompson A R. The Arkansas Cancer Pain Initiative. J Ark Med Soc. 94;90(11):536-8. [Rec#: 15827] Exclude at abstract screening: Title Only. [pmid: 7516324].
Thompson B. Amyotrophic lateral sclerosis: integrating care for patients and their families. Am J Hosp Palliat Care. 90;7(3):29-32. [Rec#: 15829] Exclude at abstract screening: not about end of life.
Thompson B L, Lawson D, Croughan-Minihane M, Cooke M. Do patients' ethnic and social factors influence the use of do-not-resuscitate orders?. Ethn Dis. 99;9(1):132-9. [Rec#: 7628] Exclude at abstract screening: data older than 1990.
Thompson D. Toward a pharmacoeconomic model of neuropathic pain. Clin J Pain. 2002;18(6):366-72. [Rec#: 15830] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12441830].
Thompson G, McClement S. Defining and determining quality in end-of-life care. Int J Palliat Nurs. 2002;8(6):288-93. [Rec#: 15832] Exclude at abstract screening: no outcomes specified. [pmid: 12131823].
Thompson G. Determining the process of providing quality end-of-life care to hospitalized adult medical patients: the perspectives of nurses. Can Oncol Nurs J. 2003;13(2):131-2. [Rec#: 7630] Exclude at abstract screening: Title Only. [pmid: 12793159].
Thompson L M. The future of death: death in the hands of science. Nurs Outlook. 94;42(4):175-80. [Rec#: 15834] Exclude at abstract screening: Title Only. [pmid: 7527140].
Thompson L W, Gallagher-Thompson D, Futterman A, Gilewski M J, Peterson J. The effects of late-life spousal bereavement over a 30-month interval. Psychol Aging. 91;6(3):434-41. [Rec#: 7633] Exclude at abstract screening: Study Design - Unclear.
Thompson M, Rose C, Wainwright W, Mattar L, Scanlan M. Activities of counsellors in a hospice/palliative care environment. J Palliat Care. 2001;17(4):229-35. [Rec#: 15835] Exclude at abstract screening: not about end of life. [pmid: 11813339].
Thompson P K. St. John of the Cross and palliative care. Natl Cathol Bioeth Q. 2002;2(2):235-41. [Rec#: 15836] Exclude at abstract screening: Title Only. [pmid: 12854581].
Thompson P M. Communicating with dementia patients on hospice. Am J Hosp Palliat Care 2002;19(4):263–6. Comment in: Am J Hosp Palliat Care. Nov-Dec. 2002;19(6):372. PMID: 12442969. [Rec#: 7634] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Thompson P M. Communicating with dementia patients on hospice. Am J Alzheimers Dis Other Demen. 2002;17(5):299-302. [Rec#: 7635] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12392267].
Thomson G E, Hurzeler R J, Fraunhar G, Howe K. Physician Assisted Living: the PAL partner initiative. Conn Med. 97;61(12):775-8. [Rec#: 15838] Exclude at abstract screening: Title Only. [pmid: 9465458].
Thomson J E, Jordan M R. Depth oriented brief therapy: an ideal technique as hospice lengths-of-stay continue to shorten. J Pastoral Care Counsel. 2002;56(3):221-5. [Rec#: 7636] Exclude at abstract screening: no outcomes specified. [pmid: 12385135].
Thomson J E. The place of spiritual well-being in hospice patients' overall quality of life. Hosp J. 2000;15(2):13-27. [Rec#: 15839] Exclude at abstract screening: Other topic only. [pmid: 11271157].
Thongprasert S. Lung cancer and quality of life. Aust N Z J Med. 98;28(3):397-9. [Rec#: 7638] Exclude at abstract screening: Study Design - Unclear. [pmid: 9673757].
Thorne C P, Seamark D A, Lawrence C, Gray D J. The influence of general practitioner community hospitals on the place of death of cancer patients. Palliat Med. 94;8(2):122-8. [Rec#: 7641] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Thorns A, Gannon C. The potential role for automatic external defibrillators in palliative care units. Palliat Med 2003;17(5):465–7. Comment in: Palliat Med. Jan. 2004;18(1):75. PMID: 14982214. [Rec#: 15842] Exclude at abstract screening: no outcomes specified.
Thorns A R, Ellershaw J E. A survey of nursing and medical staff views on the use of cardiopulmonary resuscitation in the hospice. Palliat Med 99;13(3):225–32. Comment in: Palliat Med. Jan. 2000;14(1):75. PMID: 10717729. [Rec#: 15843] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Thorogood J, Bulman A S, Collins T, Ash D. The use of discriminant analysis to guide palliative treatment for lung cancer patients. Clin Oncol (R Coll Radiol). 92;4(1):22-6. [Rec#: 7644] Exclude at abstract screening: primarily prognosis or trajectories.
Thorpe G. Enabling more dying people to remain at home. BMJ. 93;307(6909):915-8. [Rec#: 15846] Exclude at abstract screening: Non-systematic review. [pmid: 7694718].
Thorsen A B, Yung N S, Leung A C. Administration of drugs by infusion pumps in palliative medicine. Ann Acad Med Singapore. 94;23(2):209-11. [Rec#: 15847] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Thorson J A, Powell F C. Meanings of death and intrinsic religiosity. J Clin Psychol. 90;46(4):379-91. [Rec#: 7646] Exclude at abstract screening: useful only for background. [pmid: 2212038].
Thorson J A, Powell F C. Medical students' attitudes towards ageing and death: a cross-sequential study. Med Educ. 91;25(1):32-7. [Rec#: 7647] Exclude at abstract screening: Study Design - Unclear. [pmid: 1997826].
Thulesius H, Hakansson A, Petersson K. Balancing: a basic process in end-of-life cancer care. Qual Health Res. 2003;13(10):1353-77. [Rec#: 7653] Exclude at abstract screening: Study Design - Qualitative. [pmid: 14658351].
Thulesius H, Petersson C, Petersson K, Hakansson A. Learner-centred education in end-of-life care improved well being in home care staff: a prospective controlled study. Palliat Med. 2002;16(4):347-54. [Rec#: 7654] Exclude at abstract screening: Study Design - Unclear. [pmid: 12132548].
Tiernan E, Kearney M, Lynch A M, Holland N, Pyne P. Effectiveness of a teaching programme in pain and symptom management for junior house officers. Support Care Cancer. 2001;9(8):606-10. [Rec#: 15852] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11762971].
Tiernan E, O'Connor M, O'Siorain L, Kearney M. A prospective study of preferred versus actual place of death among patients referred to a palliative care home-care service. Ir Med J 2002;95(8):232–5. Comment in: Ir Med J. Apr. 2003;96(4):120-1. PMID: 12793479. [Rec#: 15853] Exclude at abstract screening: Other topic only.
Tierney A J, Sladden S, Anderson J, King M, Lapsley I, Llewellyn S. Measuring the costs and quality of palliative care: a discussion paper. Palliat Med. 94;8(4):273-81. [Rec#: 15854] Exclude at abstract screening: no outcomes specified.
Tierney J, Wilson D. The effect of the Medicare regulations on hospice practice: enhancing staff performance. Am J Hosp Palliat Care. 93;10(2):26-31. [Rec#: 15855] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Tierney W M, McKinley E D. When the physician-researcher gets cancer: understanding cancer, its treatment, and quality of life from the patient's perspective. Med Care 2002;40(6 Suppl):III20–7. Comment in: Med Care. Jun. 2002;40(6 Suppl):III28-30. PMID: 12064754. [Rec#: 7663] Exclude at abstract screening: Observational study.
Tilden V P, Nelson C A, Dunn P M, Donius M, Tolle S W. Nursing's perspective on improving communication about nursing home residents' preferences for medical treatments at end of life. Nurs Outlook. 2000;48(3):109-15. [Rec#: 15861] Exclude at abstract screening: no outcomes specified. [pmid: 10870018].
Tilden VP, Tolle S, Drach L, and Hickman S. Measurement of quality of care and quality of life at the end of life. Gerontologist 2002;42 Spec No 3:71–80. [Rec#: 15862] Exclude at abstract screening: no outcomes specified
Tilden V P, Tolle S W, Drach L L, Perrin N A. Out-of-Hospital Death: Advance Care Planning, Decedent Symptoms, and Caregiver Burden. J Am Geriatr Soc. 2004;52(4):532-9. [Rec#: 7664] Exclude at abstract screening: Title Only. [pmid: 15066067].
Tilden V P. Advance directives. Am J Nurs. 2000;100(12):49-51. [Rec#: 15858] Exclude at abstract screening: Title Only. [pmid: 11202785].
Tilden V P, Tolle S W, Nelson C A, Fields J. Family decision-making to withdraw life-sustaining treatments from hospitalized patients. Nurs Res. 2001;50(2):105-15. [Rec#: 50907] Exclude at abstract screening: Study Design - Unclear. [pmid: 11302290].
Till J E. An introduction to the framework project. Cancer Prev Control. 97;1(3):192-5. [Rec#: 15863] Exclude at abstract screening: not about end of life. [pmid: 9765744].
Timmins F, Kaliszer M. Aspects of nurse education programmes that frequently cause stress to nursing students -- fact-finding sample survey. Nurse Educ Today. 2002;22(3):203-11. [Rec#: 15864] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12027601].
Ting S M, Li P, Lau F L, Chan Y C, Chan Y K, Lai P W, Choi K, Au A, Cheung B, Tse C Y. Acute bereavement care in the emergency department: does the professional-supported volunteers model work?. Eur J Emerg Med. 99;6(3):237-43. [Rec#: 7666] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Tinnelly K, Kristjanson L J, McCallion A, Cousins K. Technology in palliative care: steering a new direction or accidental drift?. Int J Palliat Nurs. 2000;6(10):495-500. [Rec#: 15866] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12271248].
Tinsley E S, Baldwin A S, Steeves R H, Himel H N, Edlich R F. Surgeons', nurses' and bereaved families' attitudes toward dying in the burn centre. Burns. 94;20(1):79-82. [Rec#: 7668] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Tips for helping bereaved elders. Am J Hosp Palliat Care 95;12(3):12–3. [Rec#: 7669] Exclude at abstract screening: Title Only
Tirrell S E. The cultural divide between medical providers and their patients--aligning two world views. Bioethics Forum. 2001;17(34):24-30. [Rec#: 15867] Exclude at abstract screening: no outcomes specified. [pmid: 12166436].
Tishelman C, Bernhardson B M, Blomberg K, Borjeson S, Franklin L, Johansson E, Levealahti H, Sahlberg-Blom E, Ternestedt B M. Complexity in caring for patients with advanced cancer. J Adv Nurs. 2004;45(4):420-9. [Rec#: 15869] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14756836].
Tobin B, Cameron I D. End-of-life issues: case 1. Med J Aust 2001;175(8):424–5. Comment in: Med J Aust. Jul 1. 2002;177(1):54. author reply 55. PMID: 12088486. [Rec#: 7671] Exclude at abstract screening: no outcomes specified.
Todd C, Still A. General practitioners' strategies and tactics of communication with the terminally ill. Fam Pract. 93;10(3):268-76. [Rec#: 15871] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Todd C J, Grande G E, Barclay S I, Farquhar M C. General practitioners' and district nurses' views of hospital at home for palliative care. Palliat Med. 2002;16(3):251-4. [Rec#: 15872] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12047003].
Todd J, Edmonds P. Caring for patients wanting a home death. Practitioner. 2000;244(1611):580-6. [Rec#: 15873] Exclude at abstract screening: Title Only. [pmid: 10962851].
Todd J, Rees E, Gwilliam B, Davies A. An assessment of the efficacy and tolerability of a ‘double dose’ of normal-release morphine sulphate at bedtime. Palliat Med 2002; 16(6):507–12. Comment in: Palliat Med. Dec. 2003;17(8):721. author reply 722. PMID: 14694927. [Rec#: 7673] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Tolle S W, Girard D E. The physician's role in the events surrounding patient death. Archives of Internal Medicine. 83;143(7):1447-9. [Rec#: 50783] Exclude at abstract screening: Title Only. [pmid: 6870415].
Tolle S W, Bascom P B, Hickam D H, Benson J A Jr. Communication between physicians and surviving spouses following patient deaths. Journal of General Internal Medicine. 86;1(5):309-14. [Rec#: 50781] Exclude at abstract screening: Study Design - Unclear.
Tolle S W, Elliot D L, Hickam D H. Physician attitudes and practices at the time of patient death. Archives of Internal Medicine. 84;144(12):2389-91. [Rec#: 50782] Exclude at abstract screening: Title Only. [pmid: 6508446].
Tolle S W, Hickam D H, Elliot D L. A comparison of men and women physicians' management of patient death. Western Journal of Medicine. 85;143(5):691-3. [Rec#: 50784] Exclude at abstract screening: Title Only. [pmid: 4082578].
Tolley N S. Oncology social work, family systems theory, and workplace consultations. Health Soc Work. 94;19(3):227-30. [Rec#: 7682] Exclude at abstract screening: no outcomes specified. [pmid: 7959406].
Tomezak D and Quig L. Needed: a conceptual model for a comfortable death. Caring 94;13(5):8–9, 78–9. [Rec#: 7690] Exclude at abstract screening: no outcomes specified
Tomiska M, Tomiskova M, Salajka F, Adam Z, Vorlicek J. Palliative treatment of cancer anorexia with oral suspension of megestrol acetate. Neoplasma. 2003;50(3):227-33. [Rec#: 7691] Exclude at abstract screening: Other symptoms only. [pmid: 12937858].
Tomita T, Kitamura T. Clinical and research measures of grief: a reconsideration. Compr Psychiatry. 2002;43(2):95-102. [Rec#: 15879] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11893986].
Tom-Johnson C. Talking through grief. Nurs Times. 90;86(1):44-6. [Rec#: 7684] Exclude at abstract screening: Title Only. [pmid: 2296551].
Toms M E. Patients with ALS: empowerment through hospice care. Am J Hosp Palliat Care. 90;7(3):32-4. [Rec#: 15883] Exclude at abstract screening: Title Only. [pmid: 2361110].
Tomsic K T. Pastoral care in the LTC setting. Just as death is part of life, spiritual care should be part of long-term care. Health Prog. 2002;83(2):24-7. [Rec#: 7695] Exclude at abstract screening: Title Only. [pmid: 11924258].
Tonelli M R. End-of-life care in cystic fibrosis. Curr Opin Pulm Med. 98;4(6):332-6. [Rec#: 7696] Exclude at abstract screening: no outcomes specified. [pmid: 10813211].
Tong E, McGraw S A, Dobihal E, Baggish R, Cherlin E, Bradley E H. What is a good death? Minority and non-minority views. Journal of Palliative Medicine. 2003;19:168-175. [Rec#: 50785] Exclude at abstract screening: Title Only.
Toscani F, Borreani C, Boeri P, Miccinesi G. Life at the end of life: beliefs about individual life after death and “good death” models - a qualitative study. Health Qual Life Outcomes. 2003;1(1):65. [Rec#: 7704] Exclude at abstract screening: Observational study. [pmid: 14613557]. [pmcid: 280703].
Toscani F. Is palliation “medicine”? Ethical and epistemological problems. J Palliat Care. 91;7(3):33-7. [Rec#: 15893] Exclude at abstract screening: Title Only. [pmid: 1719170].
Toscani F. Overcoming professional opposition. J Palliat Care. 90;6(4):40-2. [Rec#: 15894] Exclude at abstract screening: no outcomes specified. [pmid: 1704912].
Toseland R W, McCallion P, Gerber T, Banks S. Predictors of health and human services use by persons with dementia and their family caregivers. Soc Sci Med. 2002;55(7):1255-66. [Rec#: 35636] Exclude at abstract screening: not about end of life. [pmid: 12365535].
Tourigny S C. Patient autonomy as the prerequisite for care: opioids for chronic pain of non-malignant origin. Health Care Anal 95;3(4):345–50; discussion 350–2. Comment on: Health Care Anal. Feb. 1995;3(1):5-11. PMID: 10141140. [Rec#: 15895] Exclude at abstract screening: Title Only.
Tout L R, Shama D D. A burnout instrument for hospice. Hosp J. 90;6(4):31-8. [Rec#: 15896] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 2088997].
Towers A, MacDonald N, Wallace E. Ethical issues in palliative care. Views of patients, families, and nonphysician staff. Can Fam Physician. 2003;49:1626-31. [Rec#: 15897] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14708928]. [pmcid: 2214167].
Towlson K, Rubens R. Quality of life: outcome evaluation. J Palliat Care. 92;8(3):22-4. [Rec#: 15898] Exclude at abstract screening: Title Only. [pmid: 1279146].
Tracey J, Bramley D. The acceptability of chronic disease management programmes to patients, general practitioners and practice nurses. N Z Med J. 2003;116(1169):U331. [Rec#: 35647] Exclude at abstract screening: not about end of life. [pmid: 12601408].
Tracy S L. From here to eternity. Most of us bury our feelings about death. Emerg Med Serv. 94;23(9):67-8. [Rec#: 15902] Exclude at abstract screening: Title Only. [pmid: 10136965].
Trainor A, Ezer H. Rebuilding life: the experience of living with AIDS after facing imminent death. Qual Health Res. 2000;10(5):646-60. [Rec#: 7712] Exclude at abstract screening: not about end of life. [pmid: 11066870].
Trauger-Querry B, Haghighi K R. Balancing the focus: art and music therapy for pain control and symptom management in hospice care. Hosp J. 99;14(1):25-38. [Rec#: 7717] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Travers E, Grady A. Hospice at home 1: the development of a crisis intervention service. Int J Palliat Nurs. 2002;8(4):162-8. [Rec#: 15908] Exclude at abstract screening: no outcomes specified. [pmid: 12048445].
Travis L A, Lyness J M. Minor depression. Diagnosis and management in primary care. Geriatrics. 2002;57(5):65-6. [Rec#: 7718] Exclude at abstract screening: no outcomes specified. [pmid: 12040597].
Travis S S, Bernard M, Dixon S, McAuley W J, Loving G, McClanahan L. Obstacles to palliation and end-of-life care in a long-term care facility. Gerontologist 2002;42(3):342–9. Comment in: Gerontologist. Dec. 2002;42(6):877. author reply 877–8. PMID: 12451170. [Rec#: 7719] Exclude at abstract screening: Title Only.
Travis S S, Conway J, Daly M, Larsen P. Terminal restlessness in the nursing facility: assessment, palliation, and symptom management. Geriatr Nurs. 2001;22(6):308-12. [Rec#: 15909] Exclude at abstract screening: no outcomes specified. [pmid: 11780004].
Travis S S, Loving G, McClanahan L, Bernard M. Hospitalization patterns and palliation in the last year of life among residents in long-term care. Gerontologist. 2001;41(2):153-60. [Rec#: 7720] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11327480].
Traylor E S, Hayslip B Jr, Kaminski P L, York C. Relationships between grief and family system characteristics: a cross lagged longitudinal analysis. Death Stud. 2003;27(7):575-601. [Rec#: 15910] Exclude at abstract screening: Bereavement only. [pmid: 12962122].
Tremblay A, Breitbart W. Psychiatric dimensions of palliative care. Neurology Clinics. 2001;19:949-967. [Rec#: 50786] Exclude at abstract screening: Title Only.
Tremont-Lukats, I. W., Teixeira, G. M., and Backonja, M. M. Systemic lidocaine and local anesthetic-type drugs for neuropathic pain. Cochrane Database of Systematic Reviews 2003;3. [Rec#: 50787] Exclude at abstract screening: Title Only
Trill M D, Holland J. Cross-cultural differences in the care of patients with cancer. A review. Gen Hosp Psychiatry. 93;15(1):21-30. [Rec#: 7727] Exclude at abstract screening: no outcomes specified. [pmid: 8436282].
Trinkaus J, Giacalone J A. Entrepreneurial “mining” of the dying: viatical transactions, tax strategies and mind games. J Bus Ethics. 2002;36(12):187-94. [Rec#: 7728] Exclude at abstract screening: no outcomes specified. [pmid: 12625344].
Trivelpiece K, MacDonald D. Empowering the eyes and ears of hospice: The Aide Specialist program. Am J Hosp Palliat Care. 97;14(1):17-23. [Rec#: 15919] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Trollor J. Rural general practitioners and palliative care in the north-west of New South Wales. Aust Fam Physician 95;24(6):1106–9, 1112–3. [Rec#: 7730] Exclude at abstract screening: outcome unrelated to pts/family/non-prof
Tropiano P, Walsh D. Organization of services and nursing care: hospice and palliative medicine. Semin Oncol. 2000;27(1):7-13. [Rec#: 15920] Exclude at abstract screening: no outcomes specified. [pmid: 10697017].
Trueman C. VNA of western Pennsylvania. Raising the bar of excellence in home care & hospice. Caring. 2003;22(3):24-30. [Rec#: 15923] Exclude at abstract screening: no outcomes specified. [pmid: 12690815].
Trueman I. Specialist palliative care in the UK: its future and the effects of NHS reforms. Int J Palliat Nurs. 2001;7(4):198-203. [Rec#: 15924] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11951288].
Truog R D, Berde C B, Mitchell C, Grier H E. Barbiturates in the care of the terminally ill. N Engl J Med 92;327(23):1678–82. Comment in: N Engl J Med. 1993 May 6; 328(18):1350–1. PMID: 7682291. Comment in: N Engl J Med. 1993 May 6;328(18):1350; author reply 1351. PMID: 7682289. Comment in: N Engl J Med. May 6. 1993;328(18):1350. author reply 1351. PMID: 7682290. [Rec#: 7737] Exclude at abstract screening: Title Only.
Tsay S L, Chao Y F. Effects of perceived self-efficacy and functional status on depression in patients with chronic heart failure. J Nurs Res. 2002;10(4):271-8. [Rec#: 35677] Notes: “EXCLUDE: Location, non-Western”. [pmid: 12522740].
Tsuchihashi M, Tsutsui H, Kodama K, Kasagi F, Setoguchi S, Mohr M, Kubota T, Takeshita A. Medical and socioenvironmental predictors of hospital readmission in patients with congestive heart failure. Am Heart J. 2001;142(4):E7. [Rec#: 50103] Exclude at abstract screening: useful only for background. [pmid: 11431650].
Tsuyuki R T, Shibata M C, Nilsson C, Hervas-Malo M. Contemporary burden of illness of congestive heart failure in Canada. Can J Cardiol. 2003;19(4):436-8. [Rec#: 50104] Exclude at abstract screening: Title Only. [pmid: 12704492].
Tucakovic M, Bascom R, Bascom P B. Pulmonary medicine and palliative care. Best Pract Res Clin Obstet Gynaecol. 2001;15(2):291-304. [Rec#: 7744] Exclude at abstract screening: no outcomes specified. [pmid: 11358403].
Tuch H, Parrish P, Romer A L. Integrating palliative care into nursing homes. J Palliat Med. 2003;6(2):297-309. [Rec#: 15934] Exclude at abstract screening: Title Only. [pmid: 12854950].
Tuch H. Commentary on “Lower respiratory infections in nursing home residents with dementia: a tale of two countries”: dying in the nursing home. Gerontologist 2003;43 Spec No 2:94–5. Comment on: Gerontologist. 2003 Apr;43 Spec No 2:85–93. PMID: 12711728. [Rec#: 7745] Exclude at abstract screening: Title Only
Tucker D A. Working with the patient designated “Do not resuscitate”--how the nurse copes. Focus Crit Care. 92;19(1):35-40. [Rec#: 7747] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Tucker P L. Communication improves care for terminally ill residents. Provider. 92;18(2):42. [Rec#: 15935] Exclude at abstract screening: Title Only. [pmid: 10119638].
Tucker T L. Family presence during resuscitation. Crit Care Nurs Clin North Am. 2002;14(2):177-85. [Rec#: 15936] Exclude at abstract screening: no outcomes specified. [pmid: 12038504].
Tudiver F, Hilditch J, Permaul J A. A comparison of psychosocial characteristics of new widowers and married men. Fam Med. 91;23(7):501-5. [Rec#: 7750] Exclude at abstract screening: not about end of life.
Tudiver F, Permaul-Woods J A, Hilditch J, Harmina J, Saini S. Do widowers use the health care system differently? Does intervention make a difference?. Can Fam Physician. 95;41:392-400. [Rec#: 7751] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Tuffrey-Wijne I. The palliative care needs of people with intellectual disabilities: a literature review. Palliat Med. 2003;17(1):55-62. [Rec#: 7754] Exclude at abstract screening: useful only for background. [pmid: 12597467].
Tully J. Grief and loss. ‘I'm not myself anymore’. Aust Fam Physician. 2003;32(9):697-700. [Rec#: 15937] Exclude at abstract screening: no outcomes specified. [pmid: 14524204].
Tulsky J A, Chesney M A, Lo B. How do medical residents discuss resuscitation with patients?. J Gen Intern Med. 95;10(8):436-42. [Rec#: 7755] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Tulsky J A, Fischer G S, Rose M R, Arnold R M. Opening the black box: how do physicians communicate about advance directives?. Annals of Internal Medicine. 98;129(6):441-9. [Rec#: 50788] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Tunnicliffe R, Briggs D. Introducing a bereavement support programme in ICU. Nurs Stand. 97;11(47):38-40. [Rec#: 15941] Exclude at abstract screening: Study Design - Unclear. [pmid: 9355533].
Turk D C, Feldman C S. Facilitating the use of noninvasive pain management strategies with the terminally ill. Hosp J. 92;8(12):193-214. [Rec#: 15945] Exclude at abstract screening: no outcomes specified.
Turk D C, Feldman C S. Noninvasive approaches to pain control in terminal illness: the contribution of psychological variables. Hosp J. 92;8(12):1-23. [Rec#: 15946] Exclude at abstract screening: useful only for background.
Turk D C. Clinical effectiveness and cost-effectiveness of treatments for patients with chronic pain. Clin J Pain. 2002;18(6):355-65. [Rec#: 15943] Exclude at abstract screening: not about end of life. [pmid: 12441829].
Turkoski B, Lance B. The use of guided imagery with anticipatory grief. Home Healthc Nurse. 96;14(11):878-88. [Rec#: 7762] Exclude at abstract screening: Non-systematic review. [pmid: 9060286].
Turner G. Oral care for patients who are terminally ill (continuing education credit). Nurs Stand. 94;8(41):49-54. quiz 55–6. [Rec#: 15949] Exclude at abstract screening: no outcomes specified. [pmid: 8060888].
Turner J A. Nursing care of the terminal lung cancer patient. Nurs Clin North Am. 92;27(3):691-702. [Rec#: 35699] Exclude at abstract screening: no outcomes specified. [pmid: 1508740].
Turner N J, Haward R A, Mulley G P, Selby P J. Cancer in old age--is it inadequately investigated and treated?. BMJ. 99;319(7205):309-12. [Rec#: 7767] Exclude at abstract screening: Title Only. [pmid: 10426753].
Turner P. Palliative care. Caring more, doing less. Nurs Times. 96;92(34):59-61. [Rec#: 15952] Exclude at abstract screening: no outcomes specified. [pmid: 8850730].
Turner R, Clark J, Root T, McElligott L, Hardy J. An audit of morphine prescribing in a specialist cancer hospital. Palliat Med. 94;8(1):5-10. [Rec#: 15953] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Turner S L, Higby D, Rososky J. Reasons for exceeding average length of stay in the terminal patient: one center's experience. Prog Clin Biol Res. 90;339:449-54. [Rec#: 15955] Exclude at abstract screening: Study Design - Unclear.
Turvey C L, Klein D M, Pies C J, Arndt S. Attitudes about impairment and depression in elders suffering from chronic heart failure. Int J Psychiatry Med. 2003;33(2):117-32. [Rec#: 35702] Exclude at abstract screening: not about end of life. [pmid: 12968825].
Tuttas C A. The facts of end-of-life care. J Nurs Care Qual. 2002;16(2):10-6. [Rec#: 15956] Exclude at abstract screening: no outcomes specified. [pmid: 11797475].
Twaddle M. The meaning of palliative care for the professional caregiver. J Pain Symptom Manage 2002;23(1):57–8. Comment on: J Pain Symptom Manage. Jan. 2002;23(1):54-7. PMID: 11779669. [Rec#: 15957] Exclude at abstract screening: no outcomes specified.
Twaddle M L, Sheehan M, Romer A L. Filling the gaps in service for patients who need supportive care. J Palliat Med. 2003;6(1):117-27. [Rec#: 15959] Exclude at abstract screening: Title Only. [pmid: 12710584].
Twaddle M L. The process of dying and managing the death event. Prim Care. 2001;28(2):329-38. [Rec#: 15958] Exclude at abstract screening: no outcomes specified. [pmid: 11406438].
Twycross R G. Palliative care: an international necessity. J Pain Palliat Care Pharmacother. 2002;16(1):61-79. [Rec#: 15962] Exclude at abstract screening: no outcomes specified. [pmid: 14650450].
Twycross R G. The challenge of palliative care. Int J Clin Oncol. 2002;7(4):271-8. [Rec#: 15961] Exclude at abstract screening: no outcomes specified. [pmid: 12202981].
Twycross R G. Why palliative medicine?. Henry Ford Hosp Med J. 91;39(2):77-80. [Rec#: 15963] Exclude at abstract screening: Title Only. [pmid: 1716248].
Tyler J. Nonverbal communication and the use of art in the care of the dying. Palliat Med. 98;12(2):123-6. [Rec#: 7771] Exclude at abstract screening: no outcomes specified. [pmid: 9616450].
Tyler P A, Ellison R N. Sources of stress and psychological well-being in high-dependency nursing. J Adv Nurs. 94;19(3):469-76. [Rec#: 7772] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Tyler P A, Carroll D, Cunningham S E. Stress and well-being in nurses: a comparison of the public and private sectors. Int J Nurs Stud. 91;28(2):125-30. [Rec#: 15965] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Tyni-Lenne R, Dencker K, Gordon A, Jansson E, Sylven C. Comprehensive local muscle training increases aerobic working capacity and quality of life and decreases neurohormonal activation in patients with chronic heart failure. Eur J Heart Fail. 2001;3(1):47-52. [Rec#: 35708] Exclude at abstract screening: not about end of life. [pmid: 11163735].
Tyni-Lenne R, Gordon A, Sylven C. Improved quality of life in chronic heart failure patients following local endurance training with leg muscles. J Card Fail. 96;2(2):111-7. [Rec#: 35712] Exclude at abstract screening: not about end of life.
Tyrer S. Psychiatric assessment of chronic pain. Br J Psychiatry 92;160:733–41. Comment in: Br J Psychiatry. Sep. 1992;161:422. PMID: 1393323. [Rec#: 7773] Exclude at abstract screening: Title Only.
Tzidkiahu T, Sazbon L, Solzi P. Characteristic reactions of relatives of post-coma unawareness patients in the process of adjusting to loss. Brain Inj. 94;8(2):159-65. [Rec#: 7777] Exclude at abstract screening: Title Only. [pmid: 8193635].
U.S. end-of-life care gets a (barely) passing grade. Healthcare Benchmarks Qual Improv 2003;10(1):9–10. [Rec#: 15968] Exclude at abstract screening: no outcomes specified
U.S. Preventive Services Task Forces. Screening for Depression: Recommendations and Rationale. 2000;<25 Page(s)>. [Rec#: 50789] Exclude at abstract screening: Title Only
Ubel P A, Loewenstein G, Scanlon D, Kamlet M. Value measurement in cost-utility analysis: explaining the discrepancy between rating scale and person trade-off elicitations. Health Policy. 98;43(1):33-44. [Rec#: 7780] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Ubel P A. How stable are people's preferences for giving priority to severely ill patients?. Soc Sci Med. 99;49(7):895-903. [Rec#: 7779] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Ufema J. Communication: let your patients lead you. Nursing. 2002;32(10):28. [Rec#: 15972] Exclude at abstract screening: Title Only.
Ufema J. Death & dying. Nursing. 90;20(5):22-5. [Rec#: 15973] Exclude at abstract screening: Title Only. [pmid: 2362695].
Ufema J. Helping loved ones say good-bye. Nursing 91;21(10):42–3. Comment in: Nursing. 1991 Dec;21(12):4, 6. PMID: 1749548. [Rec#: 15974] Exclude at abstract screening: Title Only
Ufema J. It takes more than knowledge: it takes assertiveness. Am J Hosp Palliat Care 91;8(1):3–4. Comment in: Am J Hosp Palliat Care. Jan-Feb. 1992;9(1):12. PMID: 1637377. [Rec#: 15977] Exclude at abstract screening: Title Only.
Ufema J. Pain control survey results: not good. Am J Hosp Palliat Care. 92;9(1):11-2. [Rec#: 15980] Exclude at abstract screening: no outcomes specified. [pmid: 1540420].
Ufema J. Pain Management. Worlds apart. Nursing 98;28(9): 20, 22. [Rec#: 15981] Exclude at abstract screening: no outcomes specified
Ufema J. Reflections on death and dying. Nursing. 99;29(6):56-9. [Rec#: 15982] Exclude at abstract screening: Title Only. [pmid: 10418510].
Ufema J. Terminal illness: nothing more we can do? Nursing 2002;32(10):28, 30. [Rec#: 15983] Exclude at abstract screening: Title Only
Ullman T. The ‘hidden’ victims of Alzheimer's disease. FDA Consum. 2003;37(4):40. [Rec#: 15986] Exclude at abstract screening: Title Only. [pmid: 12971350].
Understanding costs and cost-effectiveness in critical care: report from the second American Thoracic Society workshop on outcomes research. Am J Respir Crit Care Med 2002;165(4):540–50. [Rec#: 15991] Exclude at abstract screening: not about end of life
United Hospital Fund. The Challenge of Caring for Patients Near the End-of-Life: Findings from the Hospital Palliative Care Initiative. 1998;<25 Page(s)>. [Rec#: 50790] Exclude at abstract screening: Title Only
University of York NHS Centre for Reviews. Dissemination, Management of lung cancer. Effective Health Care. 98;4(3):12. [Rec#: 50844] Exclude at abstract screening: Title Only.
University of York. Dessemination, Informing, communicating and sharing decisions with people who have cancer. Effective Health Care. 2000;6(6):8. [Rec#: 50850] Exclude at abstract screening: Non-systematic review.
Urba S G. Nonpharmacologic pain management in terminal care. Clin Geriatr Med. 96;12(2):301-11. [Rec#: 15995] Exclude at abstract screening: no outcomes specified. [pmid: 8799349].
Ury W A, Rahn M, Tolentino V, Pignotti M G, Yoon J, McKegney P, Sulmasy D P. Can a pain management and palliative care curriculum improve the opioid prescribing practices of medical residents?. J Gen Intern Med. 2002;17(8):625-31. [Rec#: 7804] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12213144]. [pmcid: 1495092].
Uzych L. End-of-life decision making and developing international law. Pa Med. 94;97(10):16-8. [Rec#: 16002] Exclude at abstract screening: no outcomes specified. [pmid: 7816466].
Vaccarino V, Chen Y T, Wang Y, Radford M J, Krumholz H M. Sex differences in the clinical care and outcomes of congestive heart failure in the elderly. Am Heart J. 99;138(5 Pt 1):835-42. [Rec#: 50105] Exclude at abstract screening: Title Only.
Vachon M L, Kristjanson L, Higginson I. Psychosocial issues in palliative care: the patient, the family, and the process and outcome of care. J Pain Symptom Manage. 95;10(2):142-50. [Rec#: 16007] Exclude at abstract screening: useful only for background.
Vachon M L. Caring for the caregiver in oncology and palliative care. Semin Oncol Nurs. 98;14(2):152-7. [Rec#: 16003] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 9580939].
Vachon M L. Psychosocial needs of patients and families. J Palliat Care. 98;14(3):49-56. [Rec#: 16004] Exclude at abstract screening: Title Only. [pmid: 9770922].
Vachon M L. Staff stress in hospice/palliative care: a review. Palliat Med. 95;9(2):91-122. [Rec#: 16006] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 7541687].
Vachon M S. Staff stress in hospice/palliative care: a review. Palliative Medicine. 95;9:91-122. [Rec#: 50791] Exclude at abstract screening: Title Only. [pmid: 7541687].
Vader B, Wrubel B, Vader M. Death, dying, and the patient with acquired immunodeficiency syndrome. Clin Podiatr Med Surg. 92;9(4):993-6. [Rec#: 16008] Exclude at abstract screening: no outcomes specified.
Vafiadis P. Palliative care. Aust Fam Physician. 97;26(Suppl 2):S110-1. [Rec#: 16009] Exclude at abstract screening: no outcomes specified. [pmid: 9304394].
Vainio A. Treatment of terminal cancer pain in Finland: a second look. Acta Anaesthesiol Scand. 92;36(1):89-95. [Rec#: 16010] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Vainio A. Treatment of terminal cancer pain in France: a questionnaire study. Pain. 95;62(2):155-62. [Rec#: 16011] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 8545140].
Valente S M, Saunders J M, Cohen M Z. Evaluating depression among patients with cancer. Cancer Pract. 94;2(1):65-71. [Rec#: 16017] Exclude at abstract screening: no outcomes specified. [pmid: 8055008].
Valente S M. End-of-life issues. Geriatr Nurs. 2001;22(6):294-8. [Rec#: 16014] Exclude at abstract screening: no outcomes specified. [pmid: 11780002].
Valente, S. M. and Saunders, J. M. Diagnosis and treatment of major depression among patients with cancer. Cancer Nursing 97;10(168–177). [Rec#: 50792] Exclude at abstract screening: Title Only
Valentinuzzi M E. The dignity of life and death and the power of music. Pacing Clin Electrophysiol. 2001;24(5):891-2. [Rec#: 16019] Exclude at abstract screening: Title Only. [pmid: 11388110].
Vamos M. Survivor guilt and chronic illness. Aust N Z J Psychiatry. 97;31(4):592-6. [Rec#: 7819] Exclude at abstract screening: Observational study. [pmid: 9272270].
van Baarsen B. Theories on coping with loss: the impact of social support and self-esteem on adjustment to emotional and social loneliness following a partner's death in later life. J Gerontol B Psychol Sci Soc Sci. 2002;57(1):S33-42. [Rec#: 7821] Exclude at abstract screening: Bereavement only. [pmid: 11773231].
van Boxell P, Anderson K, Regnard C. The effectiveness of palliative care education delivered by videoconferencing compared with face-to-face delivery. Palliat Med. 2003;17(4):344-58. [Rec#: 16021] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12822852].
van den Bent-Kelly D. Communication breakdown. Nursing (Lond). 91;4(40):12-4. [Rec#: 16023] Exclude at abstract screening: Title Only. [pmid: 1923057].
van den Berg J P, Kalmijn S, Lindeman E, Wokke J H, van den Berg L H. Rehabilitation care for patients with ALS in The Netherlands. Amyotroph Lateral Scler Other Motor Neuron Disord. 2003;4(3):186-90. [Rec#: 16024] Exclude at abstract screening: not about end of life. [pmid: 13129805].
Van den Eynden B, Hermann I, Schrijvers D, Van Royen P, Maes R, Vermeulen L, Herweyers K, Smits W, Verhoeven A, Clara R, Denekens J. Factors determining the place of palliative care and death of cancer patients. Support Care Cancer. 2000;8(1):59-64. [Rec#: 7828] Exclude at abstract screening: Study Design - Qualitative. [pmid: 10650900].
van der Poel C J. Ethical aspects in palliative care. Am J Hosp Palliat Care. 96;13(3):49-55. [Rec#: 16026] Exclude at abstract screening: Title Only. [pmid: 8716378].
van der Steen J T, Ooms M E, Mehr D R, van der Wal G, Ribbe M W. Severe dementia and adverse outcomes of nursing home-acquired pneumonia: evidence for mediation by functional and pathophysiological decline. J Am Geriatr Soc 2002;50(3):439–48. Comment in: J Am Geriatr Soc. May. 2003;51(5):721. PMID: 12752853. [Rec#: 7833] Exclude at abstract screening: primarily prognosis or trajectories.
van der Steen J T, Ooms M E, Ribbe M W, van der Wal G. Decisions to treat or not to treat pneumonia in demented psychogeriatric nursing home patients: evaluation of a guideline. Alzheimer Dis Assoc Disord 2001;15(3):119–28. Comment in: Alzheimer Dis Assoc Disord. 2001 Jul-Sep;15(3):118. PMID: 11522928. Erratum in: Alzheimer Dis Assoc Disord. Jan-Mar. 2002;16(1):48. [Rec#: 7834] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
van Dongen E. Paradise regained: how elderly people who are chronically mentally ill reinvent a social self. Med Anthropol 2001;19(4):383–409. Comment in: Med Anthropol. 2001;19(4):411-3. PMID: 11800321. [Rec#: 7840] Exclude at abstract screening: no outcomes specified.
van Dongen R T, Crul B J, van Egmond J. Intrathecal coadministration of bupivacaine diminishes morphine dose progression during long-term intrathecal infusion in cancer patients. Clin J Pain. 99;15(3):166-72. [Rec#: 7842] Exclude at abstract screening: not about end of life.
Van Doren E S, Bowman J, Landstrom G L, Graves S Y. Structure and process variables affecting outcomes for heart failure clients. Lippincotts Case Manag. 2004;9(1):21-6. [Rec#: 50106] Exclude at abstract screening: Title Only. [pmid: 15076834].
van Eijk J T, de Haan M. Care for the chronically ill: the future role of health care professionals and their patients. Patient Educ Couns. 98;35(3):233-40. [Rec#: 16035] Exclude at abstract screening: not about end of life.
Van Gossum A. Clinical profile of home parenteral nutrition patients. Acta Gastroenterol Belg. 95;58(56):366-9. [Rec#: 7846] Exclude at abstract screening: not about end of life. [pmid: 8775992].
van Grootheest D S, Beekman A T, Broese van Groenou M I, Deeg D J. Sex differences in depression after widowhood. Do men suffer more?. Soc Psychiatry Psychiatr Epidemiol. 99;34(7):391-8. [Rec#: 7847] Exclude at abstract screening: not about end of life.
van Hooft S. Pain and communication. Med Health Care Philos. 2003;6(3):255-62. [Rec#: 16036] Exclude at abstract screening: Title Only. [pmid: 14620462].
Van Loon R A. Desire to die in terminally ill people: a framework for assessment and intervention. Health Soc Work. 99;24(4):260-8. [Rec#: 16039] Exclude at abstract screening: no outcomes specified.
van Ooijen E. One minute wisdom. We must stop feeling so embarrassed and awkward about death. Nurs Stand. 95;9(19):43. [Rec#: 16043] Exclude at abstract screening: no outcomes specified. [pmid: 7703080].
van Staa A L, Visser A, van der Zouwe N. Caring for caregivers: experiences and evaluation of interventions for a palliative care team. Patient Educ Couns. 2000;41(1):93-105. [Rec#: 7853] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10900371].
Van Tilburg E. Being at the bedside of dying patients. CHAC Rev. 95;23(1):19-22. [Rec#: 16048] Exclude at abstract screening: Title Only. [pmid: 10142510].
Van Tilburg E. Meditation and palliative care. CHAC Rev. 91;19(2):9-12. [Rec#: 16049] Exclude at abstract screening: no outcomes specified. [pmid: 10145647].
van Vliet R C, Lamers L M. The high costs of death: should health plans get higher payments when members die?. Med Care. 98;36(10):1451-60. [Rec#: 7854] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
van Weel C, Michels J. Dying, not old age, to blame for costs of health care. Lancet 97;350(9085):1159–60. Comment in: Lancet. Jan 10. 1998;351(9096):140-1. PMID: 9439517. [Rec#: 7858] Exclude at abstract screening: Title Only.
van Weel C. Teamwork. Lancet. 94;344(8932):1276-9. [Rec#: 16050] Exclude at abstract screening: Title Only. [pmid: 7967991].
van Zyl MA. Coping with death. Nurs RSA 93;8(9):22,24–5. [Rec#: 16051] Exclude at abstract screening: Title Only
VandeCreek L, Frankowski D, Johnson M. Variables that predict interest in and the completion of living wills. J Pastoral Care. 95;49(2):212-20. [Rec#: 7862] Exclude at abstract screening: Non-systematic review.
VandeKieft G K, Ogle K S, Wang T. Internet resources for end-of-life care. Am J Hosp Palliat Care. 2001;18(5):313-20. [Rec#: 16055] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11565184].
VandeKieft G K. Breaking bad news. Am Fam Physician 2001;64(12):1975-8. Comment in: Am Fam Physician. 2001 Dec 15;64(12):1946, 1948. PMID: 11775761. Comment in: Am Fam Physician. Oct 1. 2002;66(7):1155. PMID: 12387428. [Rec#: 16054] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Vanezis M, McGee A. Mediating factors in the grieving process of the suddenly bereaved. Br J Nurs. 99;8(14):932-7. [Rec#: 16056] Exclude at abstract screening: no outcomes specified. [pmid: 10711016].
Vanezis P, Leadbeatter S. Next of kin clinics: a new role for the pathologist. J Clin Pathol 99;52(10):723–4. Comment in: J Clin Pathol. 2000 Aug;53(8):646. PMID: 11002779. Comment in: J Clin Pathol. Jun. 2001;54(6):495. PMID: 11376031. [Rec#: 16057] Exclude at abstract screening: no outcomes specified.
VanGeest J B. Process evaluation of an educational intervention to improve end-of-life care: the Education for Physicians on End-of-Life Care (EPEC) program. Am J Hosp Palliat Care. 2001;18(4):233-8. [Rec#: 16058] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11467097].
Vansteenkiste J F, Simons J P, Wouters E F, Demedts M G. Hormonal treatment in advanced non-small cell lung cancer: fact or fiction?. Eur Respir J. 96;9(8):1707-12. [Rec#: 35806] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Vargo B, Osnes J. Help is on the way. Caring. 2002;21(10):6-8. [Rec#: 16064] Exclude at abstract screening: no outcomes specified. [pmid: 12395626].
Vassallo B M. The spiritual aspects of dying at home. Holist Nurs Pract. 2001;15(2):17-29. [Rec#: 16066] Exclude at abstract screening: no outcomes specified. [pmid: 12119915].
Vassilas C A, Donaldson J. Telling the truth: what do general practitioners say to patients with dementia or terminal cancer? Br J Gen Pract 98;48(428):1081–2. Comment in: Br J Gen Pract. Jun. 1998;48(431):1343-4. PMID: 9747558. [Rec#: 16067] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Vazquez E. Hospice living. Posit Aware. 96;7(2):16-9. [Rec#: 16069] Exclude at abstract screening: Title Only. [pmid: 11363360].
Veatch R M, Veatch L L. Hospital roommates: an interview with a terminally ill patient. Camb Q Healthc Ethics. 94;3(1):71-80. [Rec#: 7873] Exclude at abstract screening: Title Only. [pmid: 7518290].
Vendlinski S, Kolcaba K Y. Comfort care: a framework for hospice nursing. Am J Hosp Palliat Care. 97;14(6):271-6. [Rec#: 7876] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 9392722].
Venneri A, Shanks M F, Staff R T, Della Sala S. Nurturing syndrome: a form of pathological bereavement with delusions in Alzheimer's disease. Neuropsychologia. 2000;38(2):213-24. [Rec#: 7877] Exclude at abstract screening: no outcomes specified. [pmid: 10660231].
Venning M. Helping people to die at home. Aust Nurses J. 90;20(2):17-9. [Rec#: 16073] Exclude at abstract screening: Title Only. [pmid: 1702615].
Ventafridda V, de Conno F, Blumhuber H. Palliative care in Europe. J Pain Symptom Manage. 93;8(6):369-71. [Rec#: 16075] Exclude at abstract screening: no outcomes specified. [pmid: 7525753].
Ventafridda V, Ripamonti C, Caraceni A, Spoldi E, Messina L, De Conno F. The management of inoperable gastrointestinal obstruction in terminal cancer patients. Tumori. 90;76(4):389-93. [Rec#: 7880] Exclude at abstract screening: Study Design - Unclear.
Ventafridda V. Palliative care: a new reality in medicine. Recent Results Cancer Res. 91;121:393-8. [Rec#: 16074] Exclude at abstract screening: no outcomes specified. [pmid: 1713340].
Ventafridda V, De Conno F, Vigano A, Ripamonti C, Gallucci M, Gamba A. Comparison of home and hospital care of advanced cancer patients. Tumori. 89;75(6):619-25. [Rec#: 50793] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Ventafridda V, Ripamonti C, De Conno F, Bianchi M, Pazzuconi F, Panerai A E. Antidepressants increase bioavailability of morphine in cancer patients. Lancet. 87;1(8543):1204. [Rec#: 50794] Exclude at abstract screening: Title Only. [pmid: 2437418].
Ventafridda V, Saita L, Ripamonti C, De Conno F. WHO guidelines for the use of analgesics in cancer pain. International Journal of Tissue Reactions. 85;7(1):93-6. [Rec#: 50795] Exclude at abstract screening: no outcomes specified.
Ventres W B. Communicating about resuscitation: problems and prospectsJ Am Board Fam Pract 93;6(2):137–41. Comment in: J Am Board Fam Pract. Mar-Apr. 1993;6(2):191-3. PMID: 8452072. [Rec#: 16076] Exclude at abstract screening: no outcomes specified.
Verdery R B. ‘Wasting away’ of the old old: can it--and should it--be treated?. Geriatrics. 90;45(6):26-31. [Rec#: 7890] Exclude at abstract screening: not about end of life. [pmid: 2111267].
Vergara M, Lynn-McHale D J. Ethical issues: withdrawing life support: who decides?. Am J Nurs. 95;95(11):47-9. [Rec#: 7891] Exclude at abstract screening: Title Only. [pmid: 7485280].
Verheul K. Assessing chronic pain in cognitively impaired elderly adults. Nursingconnections. 2000;13(2):19-24. [Rec#: 7893] Exclude at abstract screening: not about end of life. [pmid: 12016665].
Verres R. Straight talking about cancer. Duty or danger?. Ann N Y Acad Sci. 97;809:367-81. [Rec#: 16080] Exclude at abstract screening: Title Only. [pmid: 9103588].
Viatical proceeds tax-free if individuals qualify. Oncology (Huntingt) 97;11(2):266–7. [Rec#: 16082] Exclude at abstract screening: Title Only
Vibarel N, Hayot M, Ledermann B, Messner Pellenc P, Ramonatxo M, Prefaut C. Effect of aerobic exercise training on inspiratory muscle performance and dyspnoea in patients with chronic heart failure. Eur J Heart Fail. 2002;4(6):745-51. [Rec#: 35843] Exclude at abstract screening: not about end of life. [pmid: 12453545].
Vickio C J. Together in spirit: keeping our relationships alive when loved ones die. Death Stud. 99;23(2):161-75. [Rec#: 16084] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Victoroff J, Mack W J, Nielson K A. Psychiatric complications of dementia: impact on caregivers. Dement Geriatr Cogn Disord. 98;9(1):50-5. [Rec#: 35845] Exclude at abstract screening: not about end of life.
Victoroff J, Nielson K, Mungas D. Caregiver and clinician assessment of behavioral disturbances: the California Dementia Behavior Questionnaire. Int Psychogeriatr. 97;9(2):155-74. [Rec#: 35846] Exclude at abstract screening: not about end of life.
Viederman M. An artist's defense against the fear of loss of creativity toward the end of life. Psychoanal Q. 95;64(4):691-8. [Rec#: 16086] Exclude at abstract screening: not about end of life. [pmid: 8584595].
Vielhaber A, Portenoy R K. Advances in cancer pain management. Hematol Oncol Clin North Am. 2002;16(3):527-41. [Rec#: 16087] Exclude at abstract screening: no outcomes specified. [pmid: 12170566].
Vig E K, Pearlman R A. Quality of life while dying: a qualitative study of terminally ill older men. J Am Geriatr Soc. 2003;51(11):1595-601. [Rec#: 7906] Exclude at abstract screening: Study Design - Qualitative. [pmid: 14687389].
Vig E K, Davenport N A, Pearlman R A. Good deaths, bad deaths, and preferences for the end of life: a qualitative study of geriatric outpatients. J Am Geriatr Soc. 2002;50(9):1541-8. [Rec#: 7905] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12383152].
Vigano A, Bruera E, Suarez-Almazor M E. Terminal cancer syndrome: myth or reality? J Palliat Care 99;15(4):32–9. Comment in: J Palliat Care. Summer. 2000;16(2):59-60. PMID: 10887736. [Rec#: 7907] Exclude at abstract screening: Title Only.
Vigano A, Watanabe S, Bruera E. Anorexia and cachexia in advanced cancer patients. Cancer Surv. 94;21:99-115. [Rec#: 16089] Exclude at abstract screening: no outcomes specified. [pmid: 8565002].
Vigano A, Fan D, Bruera E. Individualized use of methadone and opioid rotation in the comprehensive management of cancer pain associated with poor prognostic indicators. Pain. 96;67(1):115-9. [Rec#: 50797] Exclude at abstract screening: Observational study.
Vigano A, Watanabe S, Bruera E. Methylphenidate for the management of somatization in terminal cancer patients. Journal of Pain & Symptom Management. 95;10(2):167-70. [Rec#: 50798] Exclude at abstract screening: not about end of life.
Viitasalo V, Nissinen A, Kivinen P, Takala J. The last year of life: mortality, cause of death and need for help among old men. Scand J Soc Med. 96;24(2):132-9. [Rec#: 43509] Exclude at abstract screening: Study Design - Unclear.
Villarruel A M, Ortiz de Montellano B O. Culture and pain: a Mesoamerican perspective. Advances in Nursing Science. 92;15(1):21-32. [Rec#: 50799] Exclude at abstract screening: Title Only. [pmid: 1519908].
Vinkers D J, Gussekloo J, Stek M L, Westendorp R G, Van Der Mast R C. The 15-item Geriatric Depression Scale (GDS-15) detects changes in depressive symptoms after a major negative life event. The Leiden 85-plus Study. Int J Geriatr Psychiatry. 2004;19(1):80-4. [Rec#: 7913] Exclude at abstract screening: not about end of life. [pmid: 14716703].
Viola R A, Wells G A, Peterson J. The effects of fluid status and fluid therapy on the dying: a systematic review. J Palliat Care. 97;13(4):41-52. [Rec#: 7914] Exclude at abstract screening: Title Only. [pmid: 9447811].
Virani R, Sofer D. Improving the quality of end-of-life care. Am J Nurs 2003;103(5):52–60; quiz 61. Comment in: Am J Nurs. Aug. 2003;103(8):13. author reply 13. PMID: 12920707 [Rec#: 7918] Exclude at abstract screening: no outcomes specified.
Virik K, Glare P. Pain management in palliative care. Reviewing the issues. Aust Fam Physician. 2000;29(11):1027-33. [Rec#: 7920] Exclude at abstract screening: useful only for background. [pmid: 11127058].
Virmani J, Schneiderman L J, Kaplan R M. Relationship of advance directives to physician-patient communication. Arch Intern Med. 94;154(8):909-13. [Rec#: 7922] Exclude at abstract screening: Study Design - Qualitative.
Virnig B A, Fisher E S, McBean A M, Kind S. Hospice use in Medicare managed care and fee-for-service systems. Am J Manag Care 2001;7(8):777–86. Comment in: Am J Manag Care. Aug. 2001;7(8):831-3. PMID: 11519241. [Rec#: 7923] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Virnig B A, Kind S, McBean M, Fisher E. Geographic variation in hospice use prior to death. J Am Geriatr Soc. 2000;48(9):1117-25. [Rec#: 7924] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10983913].
Virnig B A, Marshall McBean A, Kind S, Dholakia R. Hospice use before death: variability across cancer diagnoses. Med Care 2002;40(1):73–8. Comment in: Med Care. Dec. 2002;40(12):1301-2. PMID: 12458311. [Rec#: 7925] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Virnig B A, Persily N A, Morgan R O, DeVito C A. Do Medicare HMOs Medicare FFS differ in their use of the Medicare hospice benefit?. Hosp J. 99;14(1):1-12. [Rec#: 7926] Exclude at abstract screening: Study Design - Unclear.
Visser A, van Leeuwen A F, Voogt E, van der Heide A, van der Rijt K. Clinical decision-making at the end of life: the role of the patient's wish. Patient Educ Couns. 2003;50(3):263-4. [Rec#: 7929] Exclude at abstract screening: Observational study. [pmid: 12900096].
Viswanathan R. Death anxiety, locus of control, and purpose in life of physicians. Their relationship to patient death notification. Psychosomatics. 96;37(4):339-45. [Rec#: 7930] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Vitetta L, Kenner D, Kissane D, Sali A. Clinical outcomes in terminally ill patients admitted to hospice care: diagnostic and therapeutic interventions. J Palliat Care. 2001;17(2):69-77. [Rec#: 7932] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 11477988].
Vittone SB. Ethics in the ICU. Crit Care Nurs Clin North Am 2002;14(2):157–63, viii. [Rec#: 16101] Exclude at abstract screening: no outcomes specified
Vladeck B C. From the Health Care Financing Administration. JAMA. 95;274(6):449. [Rec#: 16102] Exclude at abstract screening: Title Only. [pmid: 7629940].
Vogel W, Peterson L E. A variant of guided exposure to mourning for use with treatment resistant patients. J Behav Ther Exp Psychiatry. 91;22(3):217-9. [Rec#: 7938] Exclude at abstract screening: not about end of life.
Vogelzang J L. Quality end-of-life care: where does nutrition fit?. Home Healthc Nurse. 2001;19(2):110-2. [Rec#: 16105] Exclude at abstract screening: Title Only. [pmid: 11985221].
Vogelzang N J, Breitbart W, Cella D, Curt G A, Groopman J E, Horning S J, Itri L M, Johnson D H, Scherr S L, Portenoy R K. Patient, caregiver, and oncologist perceptions of cancer-related fatigue: results of a tripart assessment survey. The Fatigue Coalition. Seminars in Hematology. 97;34(3 Suppl 2):4-12. [Rec#: 50800] In abstract review process.
Vogl D, Rosenfeld B, Breitbart W, Thaler H, Passik S, McDonald M, Portenoy R K. Symptom prevalence, characteristics, and distress in AIDS outpatients. Journal of Pain & Symptom Management. 99;18(4):253-62. [Rec#: 50801] Exclude at abstract screening: Study Design - Unclear.
Volicer L, Volicer B J, Hurley A C. Is hospice care appropriate for Alzheimer patients?. Caring. 93;12(11):50-5. [Rec#: 7950] Exclude at abstract screening: no outcomes specified. [pmid: 10171736].
Volicer L. End-of-life care and bereavement: effect on family carers. Lancet Neurol. 2004;3(3):144. [Rec#: 7945] Exclude at abstract screening: Title Only. [pmid: 14980528].
Volicer L. Management of severe Alzheimer's disease and end-of-life issues. Clin Geriatr Med. 2001;17(2):377-91. [Rec#: 7946] Exclude at abstract screening: useful only for background. [pmid: 11375141].
Volicer L, Ganzini L. Health professionals' views on standards for decision-making capacity regarding refusal of medical treatment in mild Alzheimer's disease. Journal of the American Geriatrics Society. 2003;51(9):1270-4. [Rec#: 50803] Exclude at abstract screening: not about end of life. [pmid: 12919240].
Volicer L, Hurley A C. Impact of dementia special care units: resource use and outcomes. Gerontologist. 95;35(5):581-2. [Rec#: 50804] Exclude at abstract screening: Title Only. [pmid: 8543213].
Volicer L, Cantor M D, Derse A R, Edwards D M, Prudhomme A M, Gregory D C, Reagan J E, Tulsky J A, Fox E. National Ethics Committee Of The Veterans Health Administration. Advance care planning by proxy for residents of long-term care facilities who lack decision-making capacity. Journal of the American Geriatrics Society. 2002;50(4):761-7. [Rec#: 50802] Exclude at abstract screening: no outcomes specified. [pmid: 11982681].
Voljc B. On the spirituality of the doctor-patient relationship. Ann N Y Acad Sci. 97;809:80-2. [Rec#: 16108] Exclude at abstract screening: not about end of life. [pmid: 9103559].
Voltz R, Borasio G D. Palliative therapy in the terminal stage of neurological disease. J Neurol. 97;244(Suppl 4):S2-10. [Rec#: 7954] Exclude at abstract screening: no outcomes specified. [pmid: 9402547].
Voltz R, Akabayashi A, Reese C, Ohi G, Sass H M. Attitudes of healthcare professionals toward clinical decisions in palliative care: a cross-cultural comparison. J Clin Ethics. 99;10(4):309-15. [Rec#: 7951] Exclude at abstract screening: Title Only.
Voltz R, Akabayashi A, Reese C, Ohi G, Sass H M. Organization and patients' perception of palliative care: a crosscultural comparison. Palliat Med. 97;11(5):351-7. [Rec#: 7953] Exclude at abstract screening: Study Design - Unclear.
von Engelhardt D. Subjectivity and ethics: the patient. Lancet. 99;354(Suppl):SIV47. [Rec#: 16114] Exclude at abstract screening: Title Only. [pmid: 10691460].
von Gunten C, Weissman D E. Information for patients and families about ventilator withdrawal. J Palliat Med. 2003;6(5):775-6. [Rec#: 16115] Exclude at abstract screening: Title Only. [pmid: 14622460].
Von Gunten C, Weissman D E. Symptom control for ventilator withdrawal in the dying patient. J Palliat Med. 2003;6(5):774-5. [Rec#: 16116] Exclude at abstract screening: Title Only. [pmid: 14622459].
von Gunten C, Weissman D E. Ventilator withdrawal protocol. J Palliat Med. 2003;6(5):773-4. [Rec#: 16117] Exclude at abstract screening: Title Only. [pmid: 14622458].
von Gunten C F, Martinez J. Role of palliative medicine in cancer patient care. Cancer Treat Res. 2000;102:65-76. [Rec#: 16119] Exclude at abstract screening: Title Only. [pmid: 10650481].
von Gunten C F, Twaddle M L. Terminal care for noncancer patients. Clin Geriatr Med. 96;12(2):349-58. [Rec#: 35872] Exclude at abstract screening: useful only for background. [pmid: 8799352].
Von Gunten C F, Von Roenn J H. Barriers to pain control: ethics & knowledge. J Palliat Care. 94;10(3):52-4. [Rec#: 16122] Exclude at abstract screening: Title Only. [pmid: 7531235].
von Gunten C F, Weissman D E. Discussing do-not-resuscitate orders in the hospital setting: part 1. J Palliat Med. 2002;5(3):415-7. [Rec#: 16125] Exclude at abstract screening: Title Only. [pmid: 12133246].
von Gunten C F, Neely K J, Martinez J. Hospice and palliative care: program needs and academic issues. Oncology (Huntingt). 96;10(7):1070-4. discussion 1074, 1079–80 [Rec#: 16121] Exclude at abstract screening: no outcomes specified.
von Gunten C F, Von Roenn J H, Johnson-Neely K, Martinez J, Weitzman S. Hospice and palliative care: attitudes and practices of the physician faculty of an academic hospital. Am J Hosp Palliat Care. 95;12(4):38-42. [Rec#: 16124] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
von Gunten C F. Secondary and tertiary palliative care in US hospitals. JAMA 2002;287(7):875–81. Comment in: JAMA. Sep 11. 2002;288(10):1279. PMID: 12215136. [Rec#: 7957] Exclude at abstract screening: no outcomes specified.
von Klitzing W. Evaluation of reflective learning in a psychodynamic group of nurses caring for terminally ill patients. J Adv Nurs. 99;30(5):1213-21. [Rec#: 7958] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Von Roenn J H, von Gunten C F. Setting goals to maintain hope. Journal of Clinical Oncology. 2003;21(3):570-4. [Rec#: 50806] Exclude at abstract screening: Title Only. [pmid: 12560453].
Von Roenn J H, Cleeland C S, Gonin R, Hatfield A K, Pandya K J. Physician attitudes and practice in cancer pain management. A survey from the Eastern Cooperative Oncology Group. Annals of Internal Medicine. 93;119(2):121-6. [Rec#: 50805] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Voth A J, Fainsinger R L. Is this a palliative care patient? J Pain Symptom Manage 99;17(6):448–9. Comment on: J Pain Symptom Manage. Sep. 1998;16(3):145-52. PMID: 9769616. [Rec#: 7962] Exclude at abstract screening: Title Only.
Vousden M. What's so good about natural pain? Nurs Times 98;94(44):27. Comment on: Nurs Times. Nov 4–10. 1998;94(44):26-7. PMID: 9919247. [Rec#: 16128] Exclude at abstract screening: Title Only.
Waddell C, Clarnette R M, Smith M, Oldham L. Advance directives affecting medical treatment choices. J Palliat Care. 97;13(2):5-8. [Rec#: 7967] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Waddington P. Towards care in the community: a carer's tale. Br J Nurs. 96;5(1):48-50. [Rec#: 7968] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 8696113].
Wadhwa S, Lavizzo-Mourey R. Tools, methods, and strategies. Do innovative models of health care delivery improve quality of care for selected vulnerable populations? A systematic review. Jt Comm J Qual Improv. 99;25(8):408-33. [Rec#: 16133] Exclude at abstract screening: Study Design - Review/Meta.
Wagner A W, Teri L, Orr-Rainey N. Behavior problems of residents with dementia in special care units. Alzheimer Dis Assoc Disord. 95;9(3):121-7. [Rec#: 35885] Exclude at abstract screening: not about end of life.
Wagner L. Providing comfort to dying residents. Provider 99;25(5):52–4, 57–8, 61–5 [Rec#: 16136] Exclude at abstract screening: Title Only
Wagner R E, Hexel M, Bauer W W, Kropiunigg U. Crying in hospitals: a survey of doctors', nurses' and medical students' experience and attitudes. Med J Aust. 97;166(1):13-6. [Rec#: 7974] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Wagstaff R, Berlin A, Stacy R, Spencer J, Bhopal R A. Information about patients' deaths: general practitioners' current practice and views on receiving a death register. Br J Gen Pract. 94;44(384):315-6. [Rec#: 16139] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Wahlin A, Nilsson E, Fastbom J. Cognitive performance in very old diabetic persons: the impact of semantic structure, preclinical dementia, and impending death. Neuropsychology. 2002;16(2):208-16. [Rec#: 7977] Exclude at abstract screening: not about end of life. [pmid: 11949713].
Wakefield A. Nurses' responses to death and dying: a need for relentless self-care. Int J Palliat Nurs. 2000;6(5):245-51. [Rec#: 16143] Exclude at abstract screening: no outcomes specified. [pmid: 12419996].
Wakefield M A, Beilby J, Ashby M A. General practitioners and palliative care. Palliat Med. 93;7(2):117-26. [Rec#: 7980] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 7505171].
Walding M and Andrews C. Preventing and managing pressure sores in palliative care. Prof Nurse 95;11(1):33–4, 37–8. [Rec#: 16147] Exclude at abstract screening: Other topic only
Walker C. Life-sustaining treatment: the physician's role in decision-making. Geriatrics. 92;47(1):68-70. [Rec#: 7982] Exclude at abstract screening: no outcomes specified. [pmid: 1729148].
Walker L, Wetle T, Blechner B. Do-not-resuscitate orders in nursing homes: institutional policies and practices. J Ethics Law Aging. 95;1(2):97-106. [Rec#: 16148] Exclude at abstract screening: Title Only. [pmid: 11654401].
Walker R J, Pomeroy E C. Depression or grief? The experience of caregivers of people with dementia. Health Soc Work. 96;21(4):247-54. [Rec#: 7987] Exclude at abstract screening: Study Design - Unclear.
Walker R J, Pomeroy E C, McNeil J S, Franklin C. Anticipatory grief AIDS: strategies for intervening with caregivers. Health Soc Work. 96;21(1):49-57. [Rec#: 16149] Exclude at abstract screening: no outcomes specified.
Walker R M, Schonwetter R S, Kramer D R, Robinson B E. Living wills and resuscitation preferences in an elderly population. Arch Intern Med. 95;155(2):171-5. [Rec#: 7990] Exclude at abstract screening: no outcomes specified.
Walker Z, McKinnon M, Townsend J. Shared care for high-dependency patients: mental illness, neurological disorders and terminal care--a review. Health Serv Manage Res. 99;12(4):205-11. [Rec#: 16151] Exclude at abstract screening: useful only for background.
Walker P, Nordell C, Cace, Neumann C M, Bruera E. Impact of the Edmonton Labeled Visual Information System on physician recall of metastatic cancer patient histories. a randomized controlled trial. Journal of Pain & Symptom Management. 2001;21(1):4-11. [Rec#: 50807] Exclude at abstract screening: Study Design - Unclear. [pmid: 11223309].
Wall L M. Changes in hope and power in lung cancer patients who exercise. Nurs Sci Q. 2000;13(3):234-42. [Rec#: 35897] Exclude at abstract screening: not about end of life. [pmid: 11847803].
Wall M G, Wellman N S, Curry K R, Johnson P M. Feeding the terminally ill: dietitians' attitudes and beliefs. J Am Diet Assoc. 91;91(5):549-52. [Rec#: 16153] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Wallace B. Suffering, meaning, and the goals of hospice care. Am J Hosp Palliat Care 95;12(3):6–8, 9. [Rec#: 16155] Exclude at abstract screening: Title Only
Wallace P. Improving palliative care through effective communication. Int J Palliat Nurs. 2001;7(2):86-90. [Rec#: 16157] Exclude at abstract screening: no outcomes specified. [pmid: 12271254].
Wallace W E. Hospice AIDS: clinical issues which affect care. Am J Hosp Palliat Care. 90;7(3):13-6. [Rec#: 7995] Exclude at abstract screening: Title Only. [pmid: 2361107].
Waller A, Hershkowitz M, Adunsky A. The effect of intravenous fluid infusion on blood and urine parameters of hydration and on state of consciousness in terminal cancer patients. Am J Hosp Palliat Care 94;11(6):22–7 Comment in: Am J Hosp Palliat Care. 1995 Mar-Apr;12(2):2. PMID: 7605728 Comment in: Am J Hosp Palliat Care. 1996 Mar-Apr;13(2):3. PMID: 8716319. Comment in: Am J Hosp Palliat Care. Sep-Oct. 1998;15(5):255-6. PMID: 9807253. [Rec#: 16158] Exclude at abstract screening: Observational study.
Walling AD. The odd couple. Am Fam Physician 91;44(6):1967, 1970. [Rec#: 16160] Exclude at abstract screening: not about end of life
Wallis M E. A healing journey. Nursing. 2000;30(11):64. [Rec#: 16164] Exclude at abstract screening: Title Only. [pmid: 11111660].
Wallwork L. Palliative care in non-malignant disease: a pragmatic response. Int J Palliat Nurs. 2000;6(4):186-91. [Rec#: 16165] Exclude at abstract screening: no outcomes specified. [pmid: 11143645].
Walsh D, Gordon S. The terminally ill: dying for palliative medicine? Am J Hosp Palliat Care 2001;18(3):203–5. Comment in: Am J Hosp Palliat Care. May-Jun. 2002;19(3):161. author reply 161–5. PMID: 12026038 [Rec#: 16172] Exclude at abstract screening: Title Only.
Walsh D, Regan J. Terminal care in the home--the general practice perspective. Ir Med J. 2001;94(1):9-11. [Rec#: 16173] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11322231].
Walsh D, Gombeski W R Jr, Goldstein P, Hayes D, Armour M. Managing a palliative oncology program: the role of a business plan. J Pain Symptom Manage. 94;9(2):109-18. [Rec#: 16171] Exclude at abstract screening: no outcomes specified.
Walsh D. Helping people to start living again. Interview by Anne Manchester. Nurs N Z. 2002;8(5):14-5. [Rec#: 16169] Exclude at abstract screening: Title Only. [pmid: 12136573].
Walsh D. Palliative care: management of the patient with advanced cancer. Semin Oncol. 94;21(4 Suppl 7):100-6. [Rec#: 16170] Exclude at abstract screening: no outcomes specified. [pmid: 7522348].
Walsh D. The Harry R. Horvitz Center for Palliative Medicine (1987-1999): development of a novel comprehensive integrated program. Am J Hosp Palliat Care. 2001;18(4):239-50. [Rec#: 16168] Exclude at abstract screening: no outcomes specified. [pmid: 11467098].
Walsh K, King M, Jones L, Tookman A, Blizard R. Spiritual beliefs may affect outcome of bereavement: prospective study. BMJ. 2002;324(7353):1551. [Rec#: 8005] Exclude at abstract screening: Bereavement only. [pmid: 12089091]. [pmcid: 116607].
Walsh M E. Can we be connected while remaining separate? Forging partnerships between all-volunteer & Medicare-certified hospices. Caring. 2003;22(11):26-8. [Rec#: 16175] Exclude at abstract screening: not about end of life. [pmid: 14658201].
Walsh S M, Hogan N S. Oncology nursing education: nursing students' commitment of “presence” with the dying patient and the family. Nurs Educ Perspect. 2003;24(2):86-90. [Rec#: 16176] Exclude at abstract screening: no outcomes specified. [pmid: 12743978].
Walsh T D, Rivera N I, Kaiko R. Oral morphine and respiratory function amongst hospice inpatients with advanced cancer. Support Care Cancer. 2003;11(12):780-4. [Rec#: 8007] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 14577019].
Walsh T D. Symptom control in patients with advanced cancer. Am J Hosp Palliat Care. 90;7(6):20-9. [Rec#: 16177] Exclude at abstract screening: Title Only. [pmid: 14686467].
Walsh R A, Girgis A, Sanson-Fisher R W. Breaking bad news. 2: What evidence is available to guide clinicians?. Behav Med. 98;24(2):61-72. [Rec#: 50155] Exclude at abstract screening: Study Design - Review/Meta.
Walsh T D, MacDonald N, Bruera E, Shepard K V, Michaud M, Zanes R. A controlled study of sustained-release morphine sulfate tablets in chronic pain from advanced cancer. American Journal of Clinical Oncology. 92;15(3):268-72. [Rec#: 50808] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Walsh-Burke K. Matching bereavement services to level of need. Hosp J. 2000;15(1):77-86. [Rec#: 16167] Exclude at abstract screening: useful only for background. [pmid: 11033660].
Walter T. Historical and cultural variants on the good death. BMJ. 2003;327(7408):218-20. [Rec#: 16179] Exclude at abstract screening: Title Only. [pmid: 12881270]. [pmcid: 1126582].
Walter T. Spirituality in palliative care: opportunity or burden?. Palliat Med. 2002;16(2):133-9. [Rec#: 16181] Exclude at abstract screening: no outcomes specified. [pmid: 11969144].
Walter T. The ideology and organization of spiritual care: three approaches. Palliat Med. 97;11(1):21-30. [Rec#: 16180] Exclude at abstract screening: no outcomes specified. [pmid: 9068682].
Walter T. Hospices and rituals after death: a survey of British hospice chaplains. International Journal of Palliative Nursing. 2003;9(2):80-5. [Rec#: 50809] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12668943].
Walters A J. The comforting role in critical care nursing practice: a phenomenological interpretation. Int J Nurs Stud. 94;31(6):607-16. [Rec#: 16182] Exclude at abstract screening: not about end of life.
Walters A J. The lifeworld of relatives of critically ill patients: a phenomenological hermeneutic study. Int J Nurs Pract. 95;1(1):18-25. [Rec#: 43555] Exclude at abstract screening: Observational study.
Waltman N L, Zimmerman L. Variations among nurses in behavioral intentions toward the dying. Hosp J. 91;7(4):37-49. [Rec#: 8010] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Waltman N L. Attitudes, subjective norms, and behavioral intentions of nurses toward dying patients and their families. Oncol Nurs Forum. 90;17(3 Suppl):55-60. discussion 60–2 [Rec#: 8009] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Waltman R E. When a spouse dies. Nursing. 92;22(7):48-51. [Rec#: 8014] Exclude at abstract screening: Title Only. [pmid: 1407781].
Wang X T. Domain-specific rationality in human choices: violations of utility axioms and social contexts. Cognition. 96;60(1):31-63. [Rec#: 8027] Exclude at abstract screening: not about end of life.
Wansaicheong G K. Eventually all of us must die. Ann Emerg Med. 97;29(1):184-5. [Rec#: 16188] Exclude at abstract screening: Title Only. [pmid: 8998105].
Wanta B A. Planning for death and dying while healthy: lessons from the Gulf War mobilization. Holist Nurs Pract. 98;13(1):22-31. [Rec#: 8028] Exclude at abstract screening: not about end of life. [pmid: 10196890].
Ward C. The need for palliative care in the management of heart failure. Heart. 2002;87(3):294-8. [Rec#: 16190] Exclude at abstract screening: no outcomes specified. [pmid: 11847180]. [pmcid: 1767047].
Ward C G. “The die is cast”: telling patients they are going to die. J Burn Care Rehabil 92;13(2 Pt 1):272–4. Comment in: J Burn Care Rehabil. May-Jun. 1993;14(3):398-9. PMID: 8360251. [Rec#: 8029] Exclude at abstract screening: no outcomes specified.
Ward E, Jemal A, Cokkinides V, Singh G K, Cardinez C, Ghafoor A, Thun M. Cancer disparities by race/ethnicity and socioeconomic status. CA Cancer J Clin. 2004;54(2):78-93. [Rec#: 8030] Exclude at abstract screening: not about end of life. [pmid: 15061598].
Ward N S, O'Brien A. End of life issues in the critically ill. Med Health R I. 2002;85(2):60-2. [Rec#: 16191] Exclude at abstract screening: Title Only. [pmid: 11881168].
Warner J, Metcalfe C, King M. Evaluating the use of benzodiazepines following recent bereavement. Br J Psychiatry. 2001;178(1):36-41. [Rec#: 8037] Exclude at abstract screening: Bereavement only. [pmid: 11136208].
Warner J E. Involvement of families in pain control of terminally ill patients. Hosp J. 92;8(12):155-70. [Rec#: 16195] Exclude at abstract screening: no outcomes specified. [pmid: 1286848].
Warr T. The physician's role in maintaining hope and spirituality. Bioethics Forum. 99;15(1):31-7. [Rec#: 16198] Exclude at abstract screening: no outcomes specified. [pmid: 11813723].
Warren N A. Bereavement care in the critical care setting. Crit Care Nurs Q. 97;20(2):42-7. [Rec#: 16200] Exclude at abstract screening: no outcomes specified. [pmid: 9313426].
Warren N A. Critical care family members' satisfaction with bereavement experiences. Crit Care Nurs Q. 2002;25(2):54-60. [Rec#: 8040] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12211336].
Warren S, Janzen W, Andiel-Hett C, Liu L, McKim H R, Schalm C. Innovative dementia care: functional status over time of persons with Alzheimer disease in a residential care centre compared to special care units. Dement Geriatr Cogn Disord. 2001;12(5):340-7. [Rec#: 43569] Exclude at abstract screening: not about end of life. [pmid: 11455135].
Warren S C, Emmett M K. Palliative care consultation in West Virginia. W V Med J. 2002;98(3):94-9. [Rec#: 16201] Exclude at abstract screening: no outcomes specified. [pmid: 12099102].
Warren S C, Hines S C, Moss A H. Concerns and self-reported competencies in end-of-life care: a survey of physicians in WV. W V Med J. 2000;96(3):455-7. [Rec#: 8042] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14619138].
Wasow M. When I'm gone: mourning the dearly departed… slightly before departure. New Dir Ment Health Serv 99;(83):21–9. [Rec#: 8050] Exclude at abstract screening: no outcomes specified
Wasson J H, Bubolz T A, Lynn J., Teno J. Can we afford comprehensive, supportive care for the very old?. Journal of the American Geriatrics Society. 98;46(7):829-32. [Rec#: 50810] Exclude at abstract screening: not about end of life.
Watanabe S, Pereira J, Hanson J, Bruera E. Fentanyl by continuous subcutaneous infusion for the management of cancer pain: a retrospective study. J Pain Symptom Manage. 98;16(5):323-6. [Rec#: 8053] Exclude at abstract screening: not about end of life.
Watanabe S, Bruera E. Corticosteroids as adjuvant analgesics. Journal of Pain & Symptom Management. 94;9(7):442-5. [Rec#: 50812] Exclude at abstract screening: not about end of life. [pmid: 7822883].
Waters C M. End-of-life care directives among African Americans: lessons learned--a need for community-centered discussion and education. J Community Health Nurs. 2000;17(1):25-37. [Rec#: 8055] Exclude at abstract screening: Study Design - Unclear. [pmid: 10778027].
Watson J. Becoming aware: knowing yourself to care for others. Home Healthc Nurse. 99;17(5):317-22. [Rec#: 16210] Exclude at abstract screening: not about end of life. [pmid: 10562005].
Watson MA. Bereavement in the elderly. AORN J 94;59(5):1079–80, 1083–4. [Rec#: 8066] Exclude at abstract screening: no outcomes specified
Watson P, Feld A. Factors in stress and burnout among paediatric nurses in a general hospital. Nurs Prax N Z. 96;11(3):38-46. [Rec#: 8067] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Watts C, Hall B. Loss adjusters. Nurs Times. 97;93(2):40-1. [Rec#: 16213] Exclude at abstract screening: no outcomes specified. [pmid: 9016126].
Watts D T, McCaulley B L, Priefer B A. Physician-nurse conflict: lessons from a clinical experience. J Am Geriatr Soc. 90;38(10):1151-2. [Rec#: 8069] Exclude at abstract screening: Title Only. [pmid: 2121815].
Watts T, Jenkins K. Palliative care nurses' feelings about death rattle. J Clin Nurs. 99;8(5):615-6. [Rec#: 16214] Exclude at abstract screening: no outcomes specified. [pmid: 10786536].
Waun J, Kilway JB, and VanGoor K. Implementing advance directives. Mich Med 98;97(4):18–9, 51. [Rec#: 16216] Exclude at abstract screening: no outcomes specified
Waun J. For dying patients and their families. Bioethics Forum. 99;15(1):38-41. [Rec#: 16215] Exclude at abstract screening: Title Only. [pmid: 11813724].
Waun J E. The spiritual basis of medical practice. Mich Med. 98;97(12):33-5. [Rec#: 16217] Exclude at abstract screening: Title Only. [pmid: 9855752].
Wax M L, Ray S E. Dilemmas within the surgical intensive care unit. J Am Coll Surg. 2002;195(5):721-8. [Rec#: 16218] Exclude at abstract screening: Title Only. [pmid: 12437263].
Weatherill G. Thro' the night: family care when the patient is dying. Caring. 95;14(4):50-3. [Rec#: 16220] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 10141827].
Weatherill G G. Pharmacologic symptom control during the withdrawal of life support: lessons in palliative care. AACN Clin Issues. 95;6(2):344-51. [Rec#: 16221] Exclude at abstract screening: no outcomes specified.
Webb C. How can you help the bereaved patient? Practitioner 2000;244(1610):455–8, 460, 462. [Rec#: 16224] Exclude at abstract screening: Title Only
Webb M, Amchin J. Do-not-resuscitate decisions on a psychiatric unit. Hosp Community Psychiatry. 90;41(3):319-21. [Rec#: 8077] Exclude at abstract screening: Title Only. [pmid: 2312080].
Webber J. Palliative care. A model response. Nurs Times. 94;90(25):66-8. [Rec#: 16227] Exclude at abstract screening: no outcomes specified. [pmid: 7518080].
Weber D. The last phase of life: innovative approaches improve end-of-life care inexpensively. Strateg Healthc Excell. 99;12(8):1-7. [Rec#: 16228] Exclude at abstract screening: Title Only.
Weber M, Ochsmann R, Huber C. Laying out and viewing the body at home--a forgotten tradition?. J Palliat Care. 98;14(4):34-7. [Rec#: 16230] Exclude at abstract screening: Title Only. [pmid: 9893396].
Webster J, Kristjanson L J. Long-term palliative care workers: more than a story of endurance. J Palliat Med. 2002;5(6):865-75. [Rec#: 8085] Exclude at abstract screening: useful only for background. [pmid: 12685533].
Weeks W B, Kofoed L L, Wallace A E, Welch H G. Advance directives and the cost of terminal hospitalization. Arch Intern Med. 94;154(18):2077-83. [Rec#: 8090] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Weggel J M. Barriers to the physician decision to offer hospice as an option for terminal care. WMJ. 99;98(3):49-53. [Rec#: 8091] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Weggel J M. Palliative care: new challenges for advanced practice nursing. Hosp J. 97;12(1):43-56. [Rec#: 16235] Exclude at abstract screening: no outcomes specified. [pmid: 9248406].
Weil M H, Wiel C J. How to respond to family demands for futile life support and cardiopulmonary resuscitation. Crit Care Med. 2000;28(9):3339-40. [Rec#: 16238] Exclude at abstract screening: Title Only. [pmid: 11008999].
Weil M H. Clinical decision making during resuscitation and guidelines for termination of the resuscitation effort. Minerva Anestesiol. 2003;69(4):180-3. [Rec#: 16237] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12766704].
Wein S. Sedation in the imminently dying patient. Oncology. 2000;14:585-592. [Rec#: 50813] Exclude at abstract screening: Title Only. [pmid: 10826317].
Weinberg N. Does apologizing help? The role of self-blame and making amends in recovery from bereavement. Health Soc Work. 95;20(4):294-9. [Rec#: 8096] Exclude at abstract screening: Bereavement only. [pmid: 8722212].
Weiner M F, Doody R S, Sairam R, Foster B, Liao T Y. Prevalence and incidence of major depressive disorder in Alzheimer's disease: findings from two databases. Dement Geriatr Cogn Disord. 2002;13(1):8-12. [Rec#: 35950] Exclude at abstract screening: not about end of life. [pmid: 11731709].
Weinrich S, Egbert C, Eleazer G P, Haddock K S. Agitation: measurement, management, and intervention research. Arch Psychiatr Nurs. 95;9(5):251-60. [Rec#: 35959] Exclude at abstract screening: not about end of life.
Weinstein S M. Integrating palliative care in oncology. Cancer Control. 2001;8(1):32-5. [Rec#: 16243] Exclude at abstract screening: no outcomes specified. [pmid: 11176034].
Weis J. Support groups for cancer patients. Support Care Cancer. 2003;11(12):763-8. [Rec#: 16244] Exclude at abstract screening: useful only for background. [pmid: 14564493].
Weisfeld V, Miller D, Gibson R, Schroeder S A. Improving care at the end of life: what does it take?. Health Aff (Millwood). 2000;19(6):277-83. [Rec#: 16277] Exclude at abstract screening: no outcomes specified.
Weisman A D. Counselor of quality. J Health Care Chaplain. 92;4(12):23-8. [Rec#: 16245] Exclude at abstract screening: no outcomes specified. [pmid: 10124192].
Weisman E. Counselor humanizes hospital for dying patients' families. Hospitals. 90;64(12):54-5. [Rec#: 16246] Exclude at abstract screening: Title Only. [pmid: 2190906].
Weiss R. St. Francis Hospice shares its message to build success. Health Prog 2000;81(1):55, 58. [Rec#: 16247] Exclude at abstract screening: Title Only
Weissert W G, Hedrick S C. Lessons learned from research on effects of community-based long-term care. J Am Geriatr Soc. 94;42(3):348-53. [Rec#: 16249] Exclude at abstract screening: not about end of life.
Weissert W G, Lafata J E, Williams B, Weissert C S. Toward a strategy for reducing potentially avoidable hospital admissions among home care clients. Med Care Res Rev. 97;54(4):439-55. [Rec#: 8111] Exclude at abstract screening: Title Only.
Weissman D. Medical oncology and palliative care: the intersection of end-of-life care. J Palliat Med. 2003;6(6):859-61. [Rec#: 8112] Exclude at abstract screening: useful only for background. [pmid: 14740617].
Weissman D E, Griffie J. The Palliative Care Consultation Service of the Medical College of Wisconsin. J Pain Symptom Manage. 94;9(7):474-9. [Rec#: 16260] Exclude at abstract screening: no outcomes specified.
Weissman D E, Griffie J, Muchka S, Matson S. Improving pain management in long-term care facilities. J Palliat Med 2001;4(4):567–73. Comment in: J Palliat Med. Winter. 2001;4(4):557-66. PMID: 11798491. [Rec#: 16261] Exclude at abstract screening: Title Only.
Weissman D E, Mullan P B, Ambuel B, von Gunten C. End-of-life curriculum reform: outcomes and impact in a follow-up study of internal medicine residency programs. J Palliat Med. 2002;5(4):497-506. [Rec#: 16263] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12353496].
Weissman D E. Consultation in palliative medicine. Arch Intern Med. 97;157(7):733-7. [Rec#: 16251] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 9125004].
Weissman D E. Doctors, opioids, and the law: the effect of controlled substances regulations on cancer pain management. Semin Oncol. 93;20(2 Suppl 1):53-8. [Rec#: 16252] Exclude at abstract screening: no outcomes specified.
Weissman D E. Measuring the quality of pain management. J Palliat Med. 2003;6(2):185-7. [Rec#: 16253] Exclude at abstract screening: no outcomes specified. [pmid: 12854933].
Weissman D E. Pre-clinical palliative medicine education at the Medical College of Wisconsin. J Cancer Educ. 93;8(3):191-5. [Rec#: 16255] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Weitzen S, Teno J M, Fennell M, Mor V. Factors assocatied with site of death: a national study of where people die. Medical Care. 2003;41:323-335. [Rec#: 50814] Exclude at abstract screening: Title Only. [pmid: 12555059].
Weitzner M A, Moody L N, McMillan S C. Symptom management issues in hospice care. Am J Hosp Palliat Care. 97;14(4):190-5. [Rec#: 16265] Exclude at abstract screening: Title Only. [pmid: 9295429].
Welch K, Morse A. Adult Spectrum of Disease Project in New Orleans. The clinical profile of end-stage AIDS in the era of highly active antiretroviral therapy. AIDS Patient Care STDS. 2002;16(2):75-81. [Rec#: 8118] Exclude at abstract screening: Other topic only. [pmid: 11874639].
Welk T A, Smith W B Jr. Family surveys: measuring more than just satisfaction. Am J Hosp Palliat Care. 99;16(3):533-40. [Rec#: 16271] Exclude at abstract screening: no outcomes specified. [pmid: 10661061].
Welk T A. Clinical and ethical considerations of fluid and electrolyte management in the terminally ill client. J Intraven Nurs. 99;22(1):43-7. [Rec#: 16268] Exclude at abstract screening: no outcomes specified.
Welk T A. Life-support and end-of-life questions: treatment or intervention?. J Intraven Nurs. 95;18(4):191-7. [Rec#: 16270] Exclude at abstract screening: no outcomes specified. [pmid: 7629639].
Wells M, Dryden H, Guild P, Levack P, Farrer K, Mowat P. The knowledge and attitudes of surgical staff towards the use of opioids in cancer pain management: can the Hospital Palliative Care Team make a difference?. Eur J Cancer Care (Engl). 2001;10(3):201-11. [Rec#: 8125] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11829383].
Welman M, Faber P A. The dream in terminal illness: a Jungian formulation. J Anal Psychol. 92;37(1):61-81. [Rec#: 8128] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 1372305].
Welsbacher A. Lessons from the monastery. Helping people ‘die well’. Minn Med. 97;80(11):6-8. [Rec#: 16276] Exclude at abstract screening: no outcomes specified. [pmid: 9385805].
Welsh C. Touch with oils: a pertinent part of holistic hospice care. Am J Hosp Palliat Care. 97;14(1):42-4. [Rec#: 16278] Exclude at abstract screening: Title Only. [pmid: 9069764].
Wendell M. Palliative care at Killam General Hospital. AARN News Lett. 95;51(2):38. [Rec#: 16279] Exclude at abstract screening: no outcomes specified. [pmid: 7539976].
Wenger N S, Oye R K, Desbiens N A, Phillips R S, Teno J M, Connors A F Jr, Liu H, Zemsky M F, Kussin P. The stability of DNR orders on hospital readmission. The SUPPORT Investigators. Study to Understand Prognoses Preferences for Outcomes Risks of Treatments. J Clin Ethics. 96;7(1):48-54. [Rec#: 8133] Exclude at abstract screening: Title Only.
Wenger N S, Greengold N L, Oye R K, Kussin P, Phillips R S, Desbiens N A, Liu H, Hiatt J R, Teno J M, Connors A F Jr. Patients with DNR orders in the operating room: surgery, resuscitation, and outcomes. SUPPORT Investigators. Study to Understand Prognoses Preferences for Outcomes Risks of Treatments. Journal of Clinical Ethics. 97;8(3):250-7. [Rec#: 50815] Exclude at abstract screening: Title Only.
Wennman-Larsen A, Tishelman C. Advanced home care for cancer patients at the end of life: a qualitative study of hopes and expectations of family caregivers. Scand J Caring Sci. 2002;16(3):240-7. [Rec#: 16282] Exclude at abstract screening: Observational study. [pmid: 12191035].
Wenrich M D, Curtis J R, Ambrozy D A, Carline J D, Shannon S E, Ramsey P G. Dying patients' need for emotional support and personalized care from physicians: perspectives of patients with terminal illness, families, and health care providers. J Pain Symptom Manage. 2003;25(3):236-46. [Rec#: 8139] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12614958].
Wenrich M D, Curtis J R, Shannon S E, Carline J D, Ambrozy D M, Ramsey P G. Communicating with dying patients within the spectrum of medical care from terminal diagnosis to death. Arch Intern Med 2001;161(6):868–74. Comment in: Arch Intern Med. Nov 26. 2001;161(21):2623-4. PMID: 11718602. [Rec#: 16283] Exclude at abstract screening: Study Design - Qualitative.
Werko L. Health technology assessment at the end of life. A realistic view of death and palliative care. Int J Technol Assess Health Care. 2000;16(3):903-6. [Rec#: 16286] Exclude at abstract screening: no outcomes specified. [pmid: 11028145].
Werner P, Carmel S, Ziedenberg H. Nurses' and social workers' attitudes and beliefs about and involvement in life-sustaining treatment decisions. Health Soc Work. 2004;29(1):27-35. [Rec#: 8143] Exclude at abstract screening: no outcomes specified. [pmid: 15024916].
Werth J L Jr, Gordon J R, Johnson R R Jr. Psychosocial issues near the end of life. Aging Ment Health. 2002;6(4):402-12. [Rec#: 8144] Exclude at abstract screening: no outcomes specified. [pmid: 12425774].
Wesley C, Tunney K, Duncan E. Educational needs of hospice social workers: spiritual assessment and interventions with diverse populationss. Am J Hosp Palliat Care. 2004;21(1):40-6. [Rec#: 8145] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14748522].
Wesley C A. Social work and end-of-life decisions: self-determination and the common good. Health Soc Work. 96;21(2):115-21. [Rec#: 16290] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
West J P, West C M. Analysis of comfort care for the terminally ill: the hospice approach. J Health Hum Serv Adm. 98;20(3):281-99. [Rec#: 8146] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
West R. Nursing the spirit. Aust Nurs J. 96;4(1):34-5. [Rec#: 16293] Exclude at abstract screening: not about end of life. [pmid: 8920389].
West S K, Levi L. Culturally Appropriate End-of-Life Care for the Black American. Home Healthc Nurse. 2004;22(3):164-168. [Rec#: 8148] Exclude at abstract screening: no outcomes specified. [pmid: 15017318].
West T S. A milestone for hospices in the United States. Am J Hosp Care. 90;7(1):19-21. [Rec#: 16294] Exclude at abstract screening: no outcomes specified. [pmid: 2361093].
Westert G P, Lagoe R J, Keskimaki I, Leyland A, Murphy M. An international study of hospital readmissions and related utilization in Europe and the USA. Health Policy. 2002;61(3):269-78. [Rec#: 50107] Exclude at abstract screening: not about end of life. [pmid: 12098520].
Westhoff L J, Schaefer J C. Long-term care survey reveals challenges. Facilities grapple with five broad issues, including changes in leadership AIDS. Health Prog. 93;74(4):38-42. [Rec#: 16299] Exclude at abstract screening: no outcomes specified.
Westman A S. Existential anxiety as related to conceptualization of self and of death, denial of death, and religiosity. Psychol Rep. 92;71(3 Pt 2):1064-6. [Rec#: 8150] Exclude at abstract screening: not about end of life.
Wetherbee L L. Powerlessness and the hospice client. Home Healthc Nurse. 95;13(5):37-41. [Rec#: 8153] Exclude at abstract screening: no outcomes specified. [pmid: 7591822].
Weyer G, Erzigkeit H, Kanowski S, Ihl R, Hadler D. Alzheimer's Disease Assessment Scale: reliability and validity in a multicenter clinical trial. Int Psychogeriatr. 97;9(2):123-38. [Rec#: 35991] Exclude at abstract screening: not about end of life.
Whall A L. The measurement of need-driven dementia-compromised behavior. Achieving higher levels of interrater reliability. J Gerontol Nurs. 99;25(9):33-7. quiz 50–1 [Rec#: 35993] Exclude at abstract screening: not about end of life.
What has been your experience with hypodermoclysis? What have been the burdens and benefits to your clients for whom it was used? J Gerontol Nurs 2000;26(5):48–50[Rec#: 8160] Exclude at abstract screening: Title Only
Whedon M B. Revisiting the road not taken: integrating palliative care into oncology nursing. Clin J Oncol Nurs. 2002;6(1):27-33. [Rec#: 16305] Exclude at abstract screening: Title Only. [pmid: 11842485].
Wheeler E C, Plowfield L. Clinical education initiative in the community: caring for patients with congestive heart failure. Nurs Educ Perspect. 2004;25(1):16-21. [Rec#: 35994] Exclude at abstract screening: not about end of life. [pmid: 15017795].
Wheeler S R. Helping families cope with death and dying. Nursing. 96;26(7):25-30. quiz 31 [Rec#: 16306] Exclude at abstract screening: Title Only. [pmid: 8717756].
Whellan D J, Gaulden L, Gattis W A, Granger B, Russell S D, Blazing M A, Cuffe M S, O'Connor C M. The benefit of implementing a heart failure disease management program. Arch Intern Med. 2001;161(18):2223-8. [Rec#: 50108] In abstract review process. [pmid: 11575979].
When pain becomes never ending. Tecnologica 98;1–6, 13–14. [Rec#: 16308] Exclude at abstract screening: Title Only
When traditional strategies don't apply. Publicity campaign raises yearly census 36 percent. Hospice Care of Rhode Island, Pawtucket. Profiles Healthc Mark 94;(62):22–31 [Rec#: 16309] Exclude at abstract screening: Title Only
Whisnant R. Easing the grief at ground zero. Minn Med. 2002;85(5):22-3. [Rec#: 16310] Exclude at abstract screening: Title Only. [pmid: 12043336].
White F. Laughing through the pain. Nurs Stand. 2003;17(34):20-1. [Rec#: 16311] Exclude at abstract screening: Title Only.
White G. An inquiry into the concepts of spirituality and spiritual care. Int J Palliat Nurs. 2000;6(10):479-84. [Rec#: 16312] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12271246].
White J L. Home care coverage improvements anticipated under health care reform. Caring. 94;13(6):16-9. [Rec#: 8170] Exclude at abstract screening: no outcomes specified. [pmid: 10134537].
White K, Davies M, Smeal T. An ongoing challenge. Providing palliative care nursing in the community. Lamp 97;54(5):15, 17. [Rec#: 16314] Exclude at abstract screening: no outcomes specified
White K R, Cochran C E, Patel U B. Hospital provision of end-of-life services: who, what, and where? Med Care 2002;40(1):17–25. Comment in: Med Care. Jan. 2002;40(1):4-6. PMID: 11748421. [Rec#: 16315] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
White K R, Coyne P J, Patel U B. Are nurses adequately prepared for end-of-life care? J Nurs Scholarsh 2001;33(2):147–51. Comment in: J Nurs Scholarsh. 2001;33(4):306. PMID: 11775295. [Rec#: 8171] Exclude at abstract screening: outcome unrelated to pts/family/non–prof.
White K S, Hall J C. Ethical dilemmas in artificial nutrition and hydration: food for thought. Nurs Case Manag. 99;4(1):34-6. [Rec#: 8173] Exclude at abstract screening: Title Only. [pmid: 10232221].
White K S, Hall J C. Ethical dilemmas in artificial nutrition and hydration: decision–making. Nurs Case Manag. 99;4(3):152-7. [Rec#: 16316] Exclude at abstract screening: Title Only. [pmid: 10476185].
White M L, Fletcher J C. The story of Mr., Mrs. Doe: “You can't tell my husband he's dying; it will kill him.”. J Clin Ethics. 90;1(1):59-62. [Rec#: 8174] Exclude at abstract screening: Title Only. [pmid: 2131061].
White T. Palliative care. Dealing with constipation. Nurs Times. 95;91(14):57-8. [Rec#: 16320] Exclude at abstract screening: no outcomes specified. [pmid: 7537371].
White Y, Grenyer B F. The biopsychosocial impact of end–stage renal disease: the experience of dialysis patients and their partners. J Adv Nurs. 99;30(6):1312-20. [Rec#: 8180] Exclude at abstract screening: Observational study.
Whitecar PS, Jonas AP, and Clasen ME, Managing pain in the dying patient. Am Fam Physician 2000;61(3):755–64. Comment in: Am Fam Physician. 2000 Feb 1;61(3):636, 641–2. PMID: 10695577. [Rec#: 16321] Exclude at abstract screening: no outcomes specified
Whitehead C M. The specialist nurse in HIV/AIDS medicine. Postgrad Med J. 96;72(846):211-3. [Rec#: 8181] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 8733527].
Whitehouse P J. The end of Alzheimer disease II: commentary on “Decisions to treat or not to treat pneumonia in demented psychogeriatric nursing home patients”. Alzheimer Dis Assoc Disord 2001;15(3):118. Comment on: Alzheimer Dis Assoc Disord. Jul-Sep. 2001;15(3):119-28. PMID: 11522929. [Rec#: 8182] Exclude at abstract screening: Title Only.
Whitlatch C J, Zarit S H, von Eye A. Efficacy of interventions with caregivers: a reanalysis. Gerontologist. 91;31(1):9-14. [Rec#: 36006] Exclude at abstract screening: not about end of life. [pmid: 2007480].
Whitmer M M. Dietary considerations for hospice clients. Caring. 96;15(2):60-2. [Rec#: 8184] Exclude at abstract screening: Title Only. [pmid: 10156987].
Whitney PJ. Role of hospice in Alzheimer's care. Provider 99;25(9):87, 89–91. [Rec#: 16322] Exclude at abstract screening: Title Only
Whitney S N, Spiegel D. The patient, the physician, and the truth. Hastings Cent Rep. 99;29(3):24. discussion 24–5. [Rec#: 8186] Exclude at abstract screening: Title Only. [pmid: 10420301].
Whitten P, Cook D J, Doolittle G. An analysis of provider perceptions for telehospice. Am J Hosp Palliat Care. 98;15(5):267-74. [Rec#: 16324] Exclude at abstract screening: Title Only. [pmid: 9807255].
Whitten P, Doolittle G, Mackert M, Rush T. Telehospice carries end-of-life care over the lines. Nurs Manage. 2003;34(11):36-9. [Rec#: 16325] Exclude at abstract screening: useful only for background. [pmid: 14671449].
Whyte A. Changing the perceptions of palliative care. Nurs Times. 2003;99(48):24-5. [Rec#: 16327] Exclude at abstract screening: Title Only.
Wiener P K, Kiosses D N, Klimstra S, Murphy C, Alexopoulos G S. A short-term inpatient program for agitated demented nursing home residents. Int J Geriatr Psychiatry. 2001;16(9):866-72. [Rec#: 36017] Exclude at abstract screening: Observational study. [pmid: 11571766].
Wiese K T. Grief, loss and bereavement. Prairie Rose. 2003-2004;72(4):20-6. quiz 27 [Rec#: 8195] Exclude at abstract screening: Title Only. [pmid: 14679615].
Wiesendanger H, Werthmuller L, Reuter K, Walach H. Chronically ill patients treated by spiritual healing improve in quality of life: results of a randomized waiting-list controlled study. J Altern Complement Med 2001;7(1):45–51. Comment in: J Altern Complement Med. Feb. 2001;7(1):5-7. PMID: 11246936. [Rec#: 8196] Exclude at abstract screening: not about end of life.
Wiffen P J. Resources in The Cochrane Library: Issue number 2, 2002. Journal of Pain Palliative Care Pharmacotherapy. 2002;16(4):85-8. [Rec#: 50819] Exclude at abstract screening: useful only for background. [pmid: 14635830].
Wiffen P., Collins S., McQuay H., Carroll D., Jadad A., Moore, A. Anticonvulsant drugs for acute and chronic pain. Cochrane Database of Systematic Reviews 2003;4. [Rec#: 50817] Exclude at abstract screening: Title Only
Wiffen P., Edwards J., Barden J., McQuay, H. Oral morphine for cancer pain. Cochrane Database of Systematic Reviews 2003;3. [Rec#: 50818] Exclude at abstract screening: Title Only
Wilde Larsson B, Larsson G. Development of a short form of the Quality from the Patient's Perspective (QPP) questionnaire. J Clin Nurs. 2002;11(5):681-7. [Rec#: 50922] In abstract review process. [pmid: 12201896].
Wildiers H, Menten J. Death rattle: prevalence, prevention and treatment. J Pain Symptom Manage. 2002;23(4):310-7. [Rec#: 8202] Exclude at abstract screening: Other symptoms only. [pmid: 11997200].
Wiles R, Jarrett N, Payne S, Field D. Referrals for bereavement counselling in primary care: a qualitative study. Patient Educ Couns. 2002;48(1):79-85. [Rec#: 16338] Exclude at abstract screening: Study Design - Qualitative. [pmid: 12220753].
Wiles R, Payne S, Jarrett N. Improving palliative care services: a pragmatic model for evaluating services and assessing unmet need. Palliat Med. 99;13(2):131-7. [Rec#: 8203] Exclude at abstract screening: no outcomes specified.
Wilford T. Developing effective palliative care within a prison setting. Int J Palliat Nurs. 2001;7(11):528-30. [Rec#: 16339] Exclude at abstract screening: no outcomes specified. [pmid: 11775927].
Wilhite M. Chronically dead persons. ABNF J. 91;2(4):85-6. [Rec#: 16340] Exclude at abstract screening: Title Only. [pmid: 1764613].
Wilkening K, Martin M. [Quality of life at the end of live: experiences, models and perspectives]. Z Gerontol Geriatr. 2003;36(5):333-8. [Rec#: 8204] Exclude at abstract screening: Study Design - Unclear. [pmid: 14579059].
Wilker H I, Lowell B. Bereavement services development in a rural setting. Hosp J. 96;11(4):25-39. [Rec#: 16342] Exclude at abstract screening: no outcomes specified. [pmid: 9256679].
Wilkes L, Tracy S, White K. The future of palliative care nursing research in Australia. Int J Nurs Pract. 2000;6(1):32-8. [Rec#: 16343] Exclude at abstract screening: useful only for background. [pmid: 10839039].
Wilkes L, White K, O'Riordan L. Empowerment through information: supporting rural families of oncology patients in palliative care. Aust J Rural Health. 2000;8(1):41-6. [Rec#: 8205] Exclude at abstract screening: Observational study. [pmid: 11040579].
Wilkes L, White K, Smeal T, Beale B. Malignant wound management: what dressings do nurses use? J Wound Care 2001;10(3):65–9. Erratum in: J Wound Care. Apr. 2002;10(4):122. [Rec#: 16344] Exclude at abstract screening: Study Design - Unclear.
Wilkes L M, Beale B. Palliative care at home: stress for nurses in urban and rural New South Wales, Australia. Int J Nurs Pract. 2001;7(5):306-13. [Rec#: 16345] Exclude at abstract screening: Observational study. [pmid: 11811428].
Wilkes L M, Boxer E, White K. The hidden side of nursing: why caring for patients with malignant malodorous wounds is so difficult. J Wound Care. 2003;12(2):76-80. [Rec#: 8206] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12655971].
Wilkie D J, Kampbell J, Cutshall S, Halabisky H, Harmon H, Johnson L P, Weinacht L, Rake-Marona M. Effects of massage on pain intensity, analgesics and quality of life in patients with cancer pain: a pilot study of a randomized clinical trial conducted within hospice care delivery. Hosp J. 2000;15(3):31-53. [Rec#: 8207] Exclude at abstract screening: Title Only. [pmid: 11315685].
Wilkie D J, Keefe F J, Dodd M J, Copp L A. Behavior of patients with lung cancer: description and associations with oncologic and pain variables. Pain. 92;51(2):231-40. [Rec#: 36034] Exclude at abstract screening: not about end of life.
Wilkie D J, Williams A R, Grevstad P, Mekwa J. Coaching persons with lung cancer to report sensory pain. Literature review and pilot study findings. Cancer Nurs. 95;18(1):7-15. [Rec#: 36035] Exclude at abstract screening: not about end of life.
Wilkie, D. J., Brown M. A., Corless, I., Farber S., Judge, K., Shannon, S., Wells, M. Toolkit for Nursing Excellence at End-of-Life Transition. 2001;<25 Page(s)>. [Rec#: 50820] Exclude at abstract screening: Title Only
Wilkinson A M, Harrold J K, Kopits I, Ayers E. New endeavors and innovative programs in end of life care. Hosp J. 98;13(12):165-80. [Rec#: 16348] Exclude at abstract screening: no outcomes specified. [pmid: 9644401].
Wilkinson E K, Salisbury C, Bosanquet N, Franks P J, Kite S, Lorentzon M, Naysmith A. Patient and carer preference for, and satisfaction with, specialist models of palliative care: a systematic literature review. Palliat Med. 99;13(3):197-216. [Rec#: 16349] Exclude at abstract screening: Study Design - Review/Meta.
Wilkinson S, Bailey K, Aldridge J, Roberts A. A longitudinal evaluation of a communication skills programme. Palliat Med. 99;13(4):341-8. [Rec#: 8213] Exclude at abstract screening: Study Design - Unclear. [pmid: 10659103].
Wilkinson S, Roberts A, Aldridge J. Nurse-patient communication in palliative care: an evaluation of a communication skills programme. Palliat Med. 98;12(1):13-22. [Rec#: 8214] Exclude at abstract screening: Study Design - Unclear.
Wilkinson S M, Leliopoulou C, Gambles M, Roberts A. Can intensive three-day programmes improve nurses' communication skills in cancer care?. Psychooncology. 2003;12(8):747-59. [Rec#: 8215] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14681949].
Willan A R, O'Brien B J, Leyva R A. Cost-effectiveness analysis when the WTA is greater than the WTP. Stat Med. 2001;20(21):3251-9. [Rec#: 16351] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11746316].
Willard C. Cardiopulmonary resuscitation for palliative care patients: a discussion of ethical issues. Palliat Med 2000;14(4):308–12. Comment in: Palliat Med. Sep. 2001;15(5):440-1. PMID: 11591098. [Rec#: 16352] Exclude at abstract screening: useful only for background.
Willenheimer R, Erhardt L, Cline C, Rydberg E, Israelsson B. Exercise training in heart failure improves quality of life and exercise capacity. Eur Heart J. 98;19(5):774-81. [Rec#: 36038] Exclude at abstract screening: not about end of life.
Williams A. Dependency scoring in palliative care. Nurs Stand. 95;10(5):27-30. [Rec#: 16354] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 8546939].
Williams A C, Richardson P H, Nicholas M K, Pither C E, Harding V R, Ridout K L, Ralphs J A, Richardson I H, Justins D M, Chamberlain J H. Inpatient vs. outpatient pain management: results of a randomised controlled trial. Pain. 96;66(1):13-22. [Rec#: 8221] Exclude at abstract screening: not about end of life.
Williams A G, O'Brien D L, Laughton K J, Jelinek G A. Improving services to bereaved relatives in the emergency department: making healthcare more human. Med J Aust 2000;173(9):480–3. Comment in: Med J Aust. Nov 6. 2000;173(9):456. PMID: 11149299. [Rec#: 16357] Exclude at abstract screening: no outcomes specified.
Williams B, Roberts P. Friends in passing: social interaction at an adult day care center. Int J Aging Hum Dev. 95;41(1):63-78. [Rec#: 8222] Exclude at abstract screening: not about end of life. [pmid: 8530194].
Williams B R. Dying young, dying poor: a sociological examination of existential suffering among low-socioeconomic status patients. J Palliat Med. 2004;7(1):27-37. [Rec#: 8223] Exclude at abstract screening: Study Design - Qualitative. [pmid: 15000780].
Williams D, Sidani S. An analysis of the nurse practitioner role in palliative care. Can J Nurs Leadersh. 2001;14(4):13-9. [Rec#: 16360] Exclude at abstract screening: not about end of life. [pmid: 11803941].
Williams E, Berrien V, Trubey P. The family with AIDS: multiple challenges for caregivers. Am J Hosp Palliat Care. 97;14(6):293-9. [Rec#: 8224] Exclude at abstract screening: no outcomes specified. [pmid: 9392725].
Williams J. Who cares for the carer?. Nurs Prax N Z. 91;6(2):15-8. [Rec#: 16362] Exclude at abstract screening: Title Only. [pmid: 1816887].
Williams M A, Wheeler M S. Palliative care: what is it?. Home Healthc Nurse. 2001;19(9):550-6. quiz 557 [Rec#: 16369] Exclude at abstract screening: no outcomes specified. [pmid: 11982194].
Williams N. Sometimes, death means you don't go by the book. Med Econ. 99;76(7):133-4. [Rec#: 16373] Exclude at abstract screening: Title Only. [pmid: 10351785].
Williams R, Harris S, Randall L, Nichols R, Brown S. A bereavement after-care service for intensive care relatives and staff: the story so far. Nurs Crit Care. 2003;8(3):109-15. [Rec#: 16374] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12859081].
Williams R W. Documentation: how to prove you did what you say you did. Am J Hosp Palliat Care. 91;8(3):7-13. [Rec#: 16375] Exclude at abstract screening: Title Only.
Williams R W. Hospice care of the future… now. Am J Hosp Palliat Care. 2001;18(1):17-8. [Rec#: 16376] Exclude at abstract screening: Title Only. [pmid: 11406872].
Williams R W. Imagination: the lost art. Am J Hosp Palliat Care. 92;9(3):8-9. [Rec#: 16377] Exclude at abstract screening: Title Only. [pmid: 1457226].
Williams R W. Successful management through delegation, humility and communication. Am J Hosp Palliat Care. 92;9(1):7-9. [Rec#: 16379] Exclude at abstract screening: Title Only. [pmid: 1540429].
Williams S G. Stress in hospice nursing? Oh what a relief!. Home Healthc Nurse. 98;16(1):35-6. [Rec#: 16381] Exclude at abstract screening: Title Only. [pmid: 9469071].
Williams P D, Williams A R, Graff J C, Hanson S, Stanton A, Hafeman C, Liebergen A, Leuenberg K, Setter R K, Ridder L, Curry H, Barnard M, Sanders S. A community-based intervention for siblings and parents of children with chronic illness or disability: the ISEE study. Journal of Pediatrics. 2003;143(3):386-93. [Rec#: 50821] Exclude at abstract screening: not about end of life. [pmid: 14517525].
Willson S. Imminent change. Dealing with an administrator's terminal illness. MGMA Connex 2004;4(2):46–50, 1. [Rec#: 16387] Exclude at abstract screening: no outcomes specified
Wilmot S, Legg L, Barratt J. Ethical issues in the feeding of patients suffering from dementia: a focus group study of hospital staff responses to conflicting principles. Nurs Ethics. 2002;9(6):599-611. [Rec#: 36045] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12449997].
Wilson D. Continuity of End of Life Care. draft in press;<25 Page(s)> [Rec#: 50894] Exclude at abstract screening: Study Design - Review/Meta
Wilson D. Culture End of Life Care. draft in press;<25 Page(s)>. [Rec#: 50899] Exclude at abstract screening: Study Design - Review/Meta
Wilson D. End of Life Care in Acute Care Hospitals. draft in press;<25 Page(s)> [Rec#: 50897] Exclude at abstract screening: Study Design - Review/Meta
Wilson D. End of Life Care in Intensive Care Units. draft in press;<25 Page(s)> [Rec#: 50902] Exclude at abstract screening: Study Design - Review/Meta
Wilson D. End of Life Care in Residential Continuing-Care Facilities. draft in press;<25 Page(s)> [Rec#: 50898] Exclude at abstract screening: Study Design - Review/Meta
Wilson D. End of Life Care in Rural or Remote Areas. draft in press;<25 Page(s)>. [Rec#: 50903] Exclude at abstract screening: Study Design - Review/Meta
Wilson D. End of Life Case Management. draft in press;<25 Page(s)>. [Rec#: 50892] Exclude at abstract screening: Study Design - Review/Meta
Wilson D. End of Life Spiritual Psychosocial Issues. draft in press;<25 Page(s)>. [Rec#: 50896] Exclude at abstract screening: Study Design - Review/Meta
Wilson D. Gender Differences in the Experience of the Dying Process. draft in press;<25 Page(s)>. [Rec#: 50901] Exclude at abstract screening: Study Design - Review/Meta
Wilson D. Interdisciplinary group meets to identify and help resolve ethical and practical issues of long-term tube feeding. AARN News Lett. 93;49(8):14. [Rec#: 16389] Exclude at abstract screening: Title Only. [pmid: 8213008].
Wilson D. Managing End of Life Pain Other Symptoms Through Non-Pharmacological Means. draft in press;<25 Page(s)>. [Rec#: 50895] Exclude at abstract screening: Study Design - Review/Meta
Wilson D. Outcomes Evaluation of End of Life Care. draft in press;<25 Page(s)>. [Rec#: 50890] Exclude at abstract screening: Study Design - Review/Meta
Wilson D. The Home As a Place of End of Life Care. draft in press;<25 Page(s)>. [Rec#: 50900] Exclude at abstract screening: Study Design - Review/Meta
Wilson D. The Needs of Dying Persons. draft in press;<25 Page(s)>. [Rec#: 50891] Exclude at abstract screening: Study Design - Review/Meta
Wilson D. The Needs of the Families of Dying Persons. draft in press;<25 Page(s)>. [Rec#: 50893] Exclude at abstract screening: Study Design - Review/Meta
Wilson D M, Northcott H C, Truman C D, Smith S L, Anderson M C, Fainsinger R L, Stingl M J. Location of death in Canada. A comparison of 20th-century hospital and nonhospital locations of death and corresponding population trends. Eval Health Prof. 2001;24(4):385-403. [Rec#: 8233] Exclude at abstract screening: useful only for background. [pmid: 11817198].
Wilson G R, Reisfield G M. More patients served by hospice, but still a last resort. Am J Hosp Palliat Care 2003;20(3):173–4. Comment on: Am J Hosp Palliat Care. Jan-Feb. 2003;20(1):41-51. PMID: 12568436. [Rec#: 16391] Exclude at abstract screening: no outcomes specified.
Wilson I M, Bunting J S, Curnow R N, Knock J. The need for inpatient palliative care facilities for noncancer patients in the Thames Valley. Palliat Med. 95;9(1):13-8. [Rec#: 16392] Exclude at abstract screening: Study Design - Qualitative.
Wilson J S. The return of Marcus Welby? Physicians making house calls. Home Healthc Nurse. 92;10(5):61-3. [Rec#: 16394] Exclude at abstract screening: Title Only. [pmid: 1526804].
Wilson M M. The management of dehydration in the nursing home. J Nutr Health Aging. 99;3(1):53-61. [Rec#: 8240] Exclude at abstract screening: useful only for background. [pmid: 10888485].
Wilson P E. Hospice volunteer training: making the experience more meaningful. Am J Hosp Palliat Care. 2000;17(2):107-10. [Rec#: 16400] Exclude at abstract screening: no outcomes specified. [pmid: 11406954].
Wilson S A, Daley B J. Family perspectives on dying in long-term care settings. J Gerontol Nurs 99;25(11):19–25. Comment in: J Gerontol Nurs. Nov. 1999;25(11):6. PMID: 10776155. [Rec#: 8244] Exclude at abstract screening: Study Design - Qualitative.
Wilson S A, Kovach C R, Stearns S A. Hospice concepts in the care of end-stage dementia. Geriatr Nurs. 96;17(1):6-10. [Rec#: 16403] Exclude at abstract screening: Title Only. [pmid: 8707146].
Wilson S A. Hospice Medicare benefits: overview, issues, and implications. J Holist Nurs. 93;11(4):356-67. [Rec#: 16402] Exclude at abstract screening: no outcomes specified. [pmid: 8228139].
Wilson V C, Jacobson E. How can we dignify death in the ICU?. Am J Nurs. 90;90(5):38-42. [Rec#: 8245] Exclude at abstract screening: Title Only. [pmid: 2337137].
Wilwerding M B, Loprinzi C L, Mailliard J A, O'Fallon J R, Miser A W, van Haelst C, Barton D L, Foley J F, Athmann L M. A randomized, crossover evaluation of methylphenidate in cancer patients receiving strong narcotics. Support Care Cancer. 95;3(2):135-8. [Rec#: 8249] Exclude at abstract screening: Other symptoms only.
Wimmer DW and Hackler JM. Some further thoughts on adjustment, coping, and bereavement. New Dir Ment Health Serv 2000;(87):45–50. [Rec#: 16407] Exclude at abstract screening: no outcomes specified
Windham B G, Bennett R G, Gottlieb S. Care management interventions for older patients with congestive heart failure. Am J Manag Care. 2003;9(6):447-59. quiz 460–1. [Rec#: 36058] Exclude at abstract screening: not about end of life. [pmid: 12816174].
Winkel P, Statland B E, Brammer M E, Christau B, Ostergaard E R. Present and projected consumption of hospital bed-days as a function of terminal days before death. Scand J Soc Med. 90;18(1):39-44. [Rec#: 8254] Exclude at abstract screening: data older than 1990.
Winland-Brown J E. Death, denial, and defeat: older patients and advance directives. Adv Pract Nurs Q. 98;4(2):36-40. [Rec#: 8256] Exclude at abstract screening: Observational study. [pmid: 9874949].
Winstead-Fry P, Kijek J. An integrative review and meta-analysis of therapeutic touch research. Altern Ther Health Med. 99;5(6):58-67. [Rec#: 50156] Exclude at abstract screening: not about end of life.
Winter S M. Terminal nutrition: framing the debate for the withdrawal of nutritional support in terminally ill patients. Am J Med 2000;109(9):723–6. Comment in: Am J Med. Dec 15. 2000;109(9):740-1. PMID: 11137493. [Rec#: 16410] Exclude at abstract screening: no outcomes specified.
Winters G, Glass E, Sakurai C. Ethical issues in oncology nursing practice: an overview of topics and strategies. Oncol Nurs Forum. 93;20(10 Suppl):21-34. [Rec#: 8266] Exclude at abstract screening: no outcomes specified.
Wirth G, Gudat H, Henke H. Palliative care in a small medical clinic in Zurich Switzerland. Support Care Cancer. 2000;8(1):5-9. [Rec#: 16412] Exclude at abstract screening: no outcomes specified. [pmid: 10650890].
Wise T N, Mann L S. The relationship between somatosensory amplification, alexithymia, and neuroticism. J Psychosom Res. 94;38(6):515-21. [Rec#: 8268] Exclude at abstract screening: not about end of life.
Wise T N, Mann L S, Mitchell J D, Hryvniak M, Hill B. Secondary alexithymia: an empirical validation. Compr Psychiatry. 90;31(4):284-8. [Rec#: 36064] Exclude at abstract screening: not about end of life. [pmid: 2387144].
Wiseman C. Bereavement care in an acute ward. Nurs Times. 92;88(20):34-5. [Rec#: 16413] Exclude at abstract screening: Title Only. [pmid: 1598277].
Witkowski A and Carlsson ME. Support group programme for relatives of terminally ill cancer patients. Support Care Cancer 2004. [Rec#: 8271] Exclude at abstract screening: Study Design - Qualitative
Wittenberg J. An interrupted death. Am J Hosp Palliat Care. 96;13(3):15-9. [Rec#: 8274] Exclude at abstract screening: Title Only. [pmid: 8716371].
Witter D M Jr, Tolle S W, Moseley J R. A bereavement program: good care, quality assurance, and risk management. Hosp Health Serv Adm. 90;35(2):263-75. [Rec#: 16416] Exclude at abstract screening: no outcomes specified.
Witthaus E, Ott A, Barendregt J J, Breteler M, Bonneux L. Burden of mortality and morbidity from dementia. Alzheimer Dis Assoc Disord. 99;13(3):176-81. [Rec#: 36070] Exclude at abstract screening: useful only for background. [pmid: 10485578].
Wodinsky H B. The costs of caring for cancer patients. J Palliat Care. 92;8(1):24-7. [Rec#: 16418] Exclude at abstract screening: Title Only. [pmid: 1583563].
Wolfe B. Grief and the family. Minn Med. 2000;83(5):55-6. [Rec#: 16421] Exclude at abstract screening: Title Only. [pmid: 10832318].
Wolfe S L. Quality of life through rehabilitation at end of life. Cancer Pract. 2002;10(4):174-8. [Rec#: 8286] Exclude at abstract screening: Title Only. [pmid: 12100101].
Wolfelt A D. Toward an understanding of complicated grief: a comprehensive overview. Am J Hosp Palliat Care. 91;8(2):28-30. [Rec#: 16423] Exclude at abstract screening: Title Only. [pmid: 1931314].
Wolinsky F D, Tierney W M. Self-rated health and adverse health outcomes: an exploration and refinement of the trajectory hypothesis. J Gerontol B Psychol Sci Soc Sci. 98;53(6):S336-40. [Rec#: 8288] Exclude at abstract screening: primarily prognosis or trajectories.
Wolinsky F D, Smith D M, Stump T E, Overhage J M, Lubitz R M. The sequelae of hospitalization for congestive heart failure among older adults. J Am Geriatr Soc. 97;45(5):558-63. [Rec#: 50109] Exclude at abstract screening: Title Only.
Wolinsky F D, Wyrwich K W, Babu A N, Kroenke K, Tierney W M. Age, aging, and the sense of control among older adults: a longitudinal reconsideration. J Gerontol B Psychol Sci Soc Sci. 2003;58(4):S212-20. [Rec#: 36086] Exclude at abstract screening: not about end of life. [pmid: 12878654].
Wolinsky F D, Wyrwich K W, Nienaber N A, Tierney W M. Generic versus disease-specific health status measures. An example using coronary artery disease and congestive heart failure patients. Eval Health Prof. 98;21(2):216-43. [Rec#: 36087] Exclude at abstract screening: not about end of life.
Wolinsky F D, Overhage J M, Stump T E, Lubitz R M, Smith D M. The risk of hospitalization for congestive heart failure among older adults. Medical Care. 97;35(10):1031-43. [Rec#: 50822] Exclude at abstract screening: not about end of life.
Wollin D A, Avanzato J. Physicians' obligations to withhold or withdraw life-sustaining medical treatment. R I Med. 94;77(11):387-9. [Rec#: 16429] Exclude at abstract screening: Title Only. [pmid: 7812057].
Wolski J C. Supporting the dying. Last chance?. J Christ Nurs. 2000;17(2):32-3. [Rec#: 16432] Exclude at abstract screening: Title Only. [pmid: 11912712].
Wood A, Seymour L M. Psychodynamic group therapy for older adults: the life experiences group. J Psychosoc Nurs Ment Health Serv. 94;32(7):19-24. [Rec#: 8298] Exclude at abstract screening: not about end of life.
Wood C G, Whittet S, Bradbeer C S. ABC of palliative care. HIV infection AIDS. BMJ. 97;315(7120):1433-6. [Rec#: 16441] Exclude at abstract screening: Title Only. [pmid: 9418094].
Wood J D. Compassion 101. Am J Hosp Palliat Care. 97;14(1):10-1. [Rec#: 16444] Exclude at abstract screening: Title Only. [pmid: 9069758].
Woodall H E, Dennis W. Comfort always. The Rainey Hospice House: South Carolina's first inpatient hospice. J S C Med Assoc. 2003;99(8):224-6. [Rec#: 8302] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 14508898].
Woodroffe M A, Hays H. Fentanyl transdermal system. Pain management at home. Can Fam Physician. 97;43:268-72. [Rec#: 8304] Exclude at abstract screening: not about end of life. [pmid: 9040914].
Woodruff R K, Jordan L, Eicke J P, Chan A. Palliative care in a general teaching hospital. 2. Establishment of a service. Med J Aust. 91;155(10):662-5. [Rec#: 16447] Exclude at abstract screening: Study Design - Unclear.
Woods M L, Sloan L, Arena C. Reacting swiftly to oncologic emergencies. JAAPA. 2003;16(10):35-9. [Rec#: 36098] Exclude at abstract screening: Title Only. [pmid: 14758675].
Woods P, Ashley J. Simulated presence therapy: using selected memories to manage problem behaviors in Alzheimer's disease patients. Geriatr Nurs. 95;16(1):9-14. [Rec#: 36099] Exclude at abstract screening: Title Only. [pmid: 7860003].
Woodward C A, King B. Survivor focus groups: a quality assurance technique. Palliat Med. 93;7(3):229-34. [Rec#: 16449] Exclude at abstract screening: not about end of life. [pmid: 7505184].
Woodward V M. Caring, patient autonomy and the stigma of paternalism. J Adv Nurs. 98;28(5):1046-52. [Rec#: 16450] Exclude at abstract screening: not about end of life. [pmid: 9840876].
Woof W R, Carter Y H. The grieving adult and the general practitioner: a literature review in two parts (Part 1). Br J Gen Pract. 97;47(420):443-8. [Rec#: 8307] Exclude at abstract screening: Non-systematic review.
Woof W R. The future of bereavement care in British general practice. Eur J Cancer Care (Engl). 97;6(2):133-6. [Rec#: 16451] Exclude at abstract screening: no outcomes specified. [pmid: 9233164].
Woolf L. Pain management in palliative care. Community Nurse. 98;4(10):41-3. [Rec#: 16453] Exclude at abstract screening: no outcomes specified. [pmid: 10326382].
Wootton M. Morphine is not the only analgesic in palliative care: literature review. J Adv Nurs. 2004;45(5):527-32. [Rec#: 8313] Exclude at abstract screening: useful only for background. [pmid: 15009356].
Worden J W. Grieving a loss from AIDS. Hosp J. 91;7(12):143-50. [Rec#: 8316] Exclude at abstract screening: no outcomes specified. [pmid: 1937436].
Workman S, McKeever P, Harvey W, Singer P A. Intensive care nurses' and physicians' experiences with demands for treatment: some implications for clinical practice. J Crit Care 2003;18(1):17–21. Comment on: J Crit Care. Mar. 2003;18(1):22-4. PMID: 12640609. [Rec#: 16457] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
World Health Organization. Cancer Pain Relief. 1996;<25 Page(s)>. [Rec#: 50823] Exclude at abstract screening: Title Only
World Health Organization. Symptom Relief in Terminal Illness. 1998;<25 Page(s)>. [Rec#: 50824] Exclude at abstract screening: Title Only
Woyka J. Hospice at home. BMJ. 95;311(7021):1687-8. [Rec#: 16460] Exclude at abstract screening: Title Only. [pmid: 8541758].
Wrede-Seaman L. Symptom management algorithms for palliative care. Am J Hosp Palliat Care 99;16(3):517–26. Comment in: Am J Hosp Palliat Care. Nov-Dec. 1999;16(6):701-4. PMID: 11094905. [Rec#: 16461] Exclude at abstract screening: chemo/surg/stents/laser/radiation.
Wrede-Seaman L D. Management of emergent conditions in palliative care. Prim Care. 2001;28(2):317-28. [Rec#: 16462] Exclude at abstract screening: useful only for background. [pmid: 11406437].
Wrede-Seaman L D. Treatment options to manage pain at the end of life. Am J Hosp Palliat Care. 2001;18(2):89-101. [Rec#: 16463] Exclude at abstract screening: no outcomes specified. [pmid: 11407138].
Wrenn R L, Levinson D, Papadatou D. End-of-life series Part 3. Working with dying patients: caregivers need support too!. Tex Nurs. 99;73(10):6-8. [Rec#: 16465] Exclude at abstract screening: Title Only. [pmid: 11949087].
Wright D. Home massage for hospice patients. Nurs Spectr (Wash D C). 99;9(2):7. [Rec#: 16467] Exclude at abstract screening: Title Only. [pmid: 10542807].
Wright F, Cohen S, Caroselli C. Diverse decisions. How culture affects ethical decision making. Crit Care Nurs Clin North Am. 97;9(1):63-74. [Rec#: 16468] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Wright K, Flemons D. Dying to know: qualitative research with terminally ill persons and their families. Death Stud. 2002;26(3):255-71. [Rec#: 16470] Exclude at abstract screening: no outcomes specified. [pmid: 11973838].
Wright K. Caring for the terminally ill: the district nurse's perspective. Br J Nurs. 2002;11(18):1180-5. [Rec#: 16469] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12388902].
Wright K. Relationships with death: the terminally ill talk about dying. J Marital Fam Ther. 2003;29(4):439-53. [Rec#: 8326] Exclude at abstract screening: Study Design - Qualitative. [pmid: 14593687].
Wright L D. The extreme importance of insignificance. J Palliat Med. 2003;6(4):623-4. [Rec#: 16473] Exclude at abstract screening: Title Only. [pmid: 14516506].
Wright M C. Chaplaincy in hospice and hospital: findings from a survey in England Wales. Palliat Med. 2001;15(3):229-42. [Rec#: 16474] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11407194].
Wright M C. The essence of spiritual care: a phenomenological enquiry. Palliat Med. 2002;16(2):125-32. [Rec#: 16475] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11969143].
Wright P M. A critical pathway for interdisciplinary hospice care. Am J Hosp Palliat Care. 2001;18(1):31-4. [Rec#: 16476] Exclude at abstract screening: no outcomes specified. [pmid: 11406875].
Wu A W, Damiano A M, Lynn J, Alzola C, Teno J, Landefeld C S, Desbiens N, Tsevat J, Mayer-Oakes A, Harrell F E Jr. Predicting future functional status for seriously ill hospitalized adults. The SUPPORT prognostic model. Annals of Internal Medicine. 95;122(5):342-50. [Rec#: 50825] Exclude at abstract screening: primarily prognosis or trajectories.
Wu A W, Yasui Y, Alzola C, Galanos A N, Tsevat J, Phillips R S, Connors A F Jr, Teno J M, Wenger N S, Lynn J. Predicting functional status outcomes in hospitalized patients aged 80 years and older. Journal of the American Geriatrics Society. 2000;48(5 Suppl):S6-15. [Rec#: 50826] Exclude at abstract screening: primarily prognosis or trajectories. [pmid: 10809451].
Wurzbach M E. End-of-life treatment decisions in long-term care. J Gerontol Nurs. 2002;28(6):14-21. [Rec#: 16483] Exclude at abstract screening: Title Only. [pmid: 12071269].
Wurzbach M E. The dilemma of withholding or withdrawing nutrition. Image J Nurs Sch. 90;22(4):226-30. [Rec#: 16482] Exclude at abstract screening: no outcomes specified. [pmid: 1705534].
Wyatt P. The role of nurses in counselling the terminally ill patient. Br J Nurs. 93;2(14):701-4. [Rec#: 16485] Exclude at abstract screening: no outcomes specified. [pmid: 8364310].
Wyche C J, Kerschbaum W E. Michigan hospice oral healthcare needs survey. J Dent Hyg. 94;68(1):35-41. [Rec#: 16486] Exclude at abstract screening: no outcomes specified. [pmid: 8006695].
Yalom I. Response to discussion of “Bereavement Groups: Techniques Themes”. Int J Group Psychother. 90;40(1):105-7. [Rec#: 16489] Exclude at abstract screening: Title Only. [pmid: 2318552].
Yalom I D, Lieberman M A. Bereavement and heightened existential awareness. Psychiatry. 91;54(4):334-45. [Rec#: 8343] Exclude at abstract screening: Study Design - Unclear. [pmid: 1788364].
Yampolskaya S, Winston N. Hospice care in prison: general principles and outcomes. Am J Hosp Palliat Care. 2003;20(4):290-6. [Rec#: 16490] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12911074].
Yang M H, McIlfatrick S. Intensive care nurses' experiences of caring for dying patients: a phenomenological study. Int J Palliat Nurs. 2001;7(9):435-41. [Rec#: 8357] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 11832847].
Yang Z, Norton E C, Stearns S C. Longevity and health care expenditures: the real reasons older people spend more. J Gerontol B Psychol Sci Soc Sci. 2003;58(1):S2-10. [Rec#: 8358] Exclude at abstract screening: useful only for background. [pmid: 12496303].
Yang-Lewis T, Moody H R. The forgetful mourner. Hastings Cent Rep. 95;25(1):32. discussion 32–3. [Rec#: 8355] Exclude at abstract screening: Title Only. [pmid: 7730049].
Yanok J, Beifus J A. Communicating about loss and mourning: death education for individuals with mental retardation. Ment Retard. 93;31(3):144-7. [Rec#: 8360] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Yarling RR and McElmurry BJ. Rethinking the nurse's role in “do not resuscitate” orders: a clinical policy proposal in nursing ethics. NLN Publ 90;(20–2294):327–34. [Rec#: 16494] Exclude at abstract screening: Title Only
Yates J A, Rutsohn P, Ibrahim N. An analysis of provider attitudes toward end-of-life decision-making. Am J Hosp Palliat Care 2003;20(5):371–81. Erratum in: Am J Hosp Palliat Care. Jan-Feb. 2004;21(1):9. [Rec#: 43701] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Yates P, Stetz K M. Families' awareness of and response to dying. Oncol Nurs Forum. 99;26(1):113-20. [Rec#: 8365] Exclude at abstract screening: Study Design - Qualitative. [pmid: 9921574].
Yates P, Stetz K M. Families' awareness of and response to dying. Clin J Oncol Nurs. 2000;4(1):46. [Rec#: 16500] Exclude at abstract screening: Title Only. [pmid: 10865585].
Yates P, Hart G, Clinton M, McGrath P, Gartry D. Exploring empathy as a variable in the evaluation of professional development programs for palliative care nurses. Cancer Nurs. 98;21(6):402-10. [Rec#: 16499] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Yates P. Towards a reconceptualization of hope for patients with a diagnosis of cancer. J Adv Nurs. 93;18(5):701-6. [Rec#: 16498] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Yates R, Lyons M, Horstman A. Symptom control in advanced cancer: meeting the challenge. JAAPA 2003;16(10):40–2, 45–9. Erratum in: JAAPA. Nov. 2003;16(11):42. [Rec#: 16501] Exclude at abstract screening: Title Only.
Yedidia M J, MacGregor B. Confronting the prospect of dying. reports of terminally ill patients. J Pain Symptom Manage. 2001;22(4):807-19. [Rec#: 8366] Exclude at abstract screening: Study Design - Qualitative. [pmid: 11576797].
Yeo W, Lam K K, Chan A T, Leung T W, Nip S Y, Johnson P J. Transdermal fentanyl for severe cancer-related pain. Palliat Med. 97;11(3):233-9. [Rec#: 8370] Notes: “EXCLUDE: Location, non-Western”. [pmid: 9205657].
Yeung E W, French P, Leung A O. The impact of hospice inpatient care on the quality of life of patients terminally ill with cancer. Cancer Nurs. 99;22(5):350-7. [Rec#: 8372] Notes: “EXCLUDE: Location, non-Western”. [pmid: 10526428].
Yin T, Zhou Q, Bashford C. Burden on family members: caring for frail elderly: a meta-analysis of interventions. Nurs Res. 2002;51(3):199-208. [Rec#: 50157] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 12063419].
Yoo D. Who should be the medical director of a hospice program?. J Palliat Care. 91;7(2):37-8. [Rec#: 16509] Exclude at abstract screening: Title Only. [pmid: 1870044].
Youll J, Wilson K. A therapeutic approach to bereavement counselling. Nurs Times. 96;92(16):40-2. [Rec#: 8387] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 8710593].
Youn G. Evaluating questions used to assess cognitive orientation for very old adults. Psychol Rep. 96;78(3 Pt 1):827-33. [Rec#: 36181] Exclude at abstract screening: not about end of life. [pmid: 8711036].
Young A J, Ofori-Boateng T, Rodriguez K L, Plowman J L. Meaning and agency in discussing end-of-life care: a study of elderly veterans' values and interpretations. Qual Health Res. 2003;13(8):1039-62. [Rec#: 8388] Exclude at abstract screening: no outcomes specified. [pmid: 14556418].
Young J B. Hospital-based systems to improve quality of care for heart-failure patients. Rev Cardiovasc Med. 2002;3(Suppl 3):S36-41. [Rec#: 36183] Exclude at abstract screening: no outcomes specified. [pmid: 12447160].
Young-Mason J. Aesthetic research: film. Clin Nurse Spec. 98;12(5):185-7. [Rec#: 16512] Exclude at abstract screening: Title Only. [pmid: 9987227].
Young-Mason J. Aesthetic research: literature. Clin Nurse Spec. 99;13(2):74-5. [Rec#: 16513] Exclude at abstract screening: Title Only. [pmid: 10382402].
Young-Mason J. Music therapy: a healing art. Clin Nurse Spec. 2002;16(3):153-4. [Rec#: 16515] Exclude at abstract screening: not about end of life. [pmid: 12021615].
Youssef M S, Atkinson R E. Comparison of Teflon cannulas and metal needles for subcutaneous infusion in terminal care: a pilot study. BMJ. 90;300(6728):847. [Rec#: 16527] Exclude at abstract screening: Title Only. [pmid: 2337698].
Yuen K J, Behrndt M M, Jacklyn C, Mitchell G K. Palliative care at home: general practitioners working with palliative care teams. Med J Aust. 2003;179(6 Suppl):S38-40. [Rec#: 16529] Exclude at abstract screening: no outcomes specified. [pmid: 12964936].
Yun Y H, Lee C G, Kim S Y, Lee S W, Heo D S, Kim J S, Lee K S, Hong Y S, Lee J S, You C H. The attitudes of cancer patients and their families toward the disclosure of terminal illness. J Clin Oncol. 2004;22(2):307-14. [Rec#: 8400] Notes: “EXCLUDE: Location, non-Western”. [pmid: 14722040].
Yuval R, Uziel K, Gordon N, Merdler A, Khader N, Karkabi B, Flugelman M Y, Halon D A, Lewis B S. Perceived benefit after participating in positive or negative/neutral heart failure trials: the patients' perspective. Eur J Heart Fail. 2001;3(2):217-23. [Rec#: 36197] Exclude at abstract screening: not about end of life. [pmid: 11246060].
Zabalegui A. Palliative nursing care in Spain. Eur J Cancer Care (Engl). 2001;10(4):280-3. [Rec#: 16530] Exclude at abstract screening: no outcomes specified. [pmid: 11806680].
Zachrisson U, Furst C J. Drug infusors in palliative medicine: a Swedish inquiry. J Pain Symptom Manage. 98;15(5):299-304. [Rec#: 16531] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Zadoff M. Viatical settlements--a financial resource for the terminally ill. Nurs Case Manag. 2000;5(1):46-8. [Rec#: 8405] Exclude at abstract screening: Title Only. [pmid: 10855158].
Zakotnik B. To tell or not to tell? Communication with cancer patients. Ann N Y Acad Sci. 97;809:500-7. [Rec#: 16532] Exclude at abstract screening: Title Only. [pmid: 9103600].
Zambroski C H. Hospice as an alternative model of care for older patients with end-stage heart failure. J Cardiovasc Nurs. 2004;19(1):76-83. quiz 84–5. [Rec#: 8408] Exclude at abstract screening: no outcomes specified. [pmid: 14994785].
Zambroski C H. Qualitative analysis of living with heart failure. Heart Lung. 2003;32(1):32-40. [Rec#: 36205] Exclude at abstract screening: not about end of life. [pmid: 12571546].
Zamierowski M J, Gordon A. The use of creative art forms to enhance counselling skills of hospice professionals in dealing with the bereaved. Am J Hosp Palliat Care. 95;12(1):5-8. [Rec#: 16534] Exclude at abstract screening: Title Only.
Zanetti O, Frisoni G B, De Leo D, Dello Buono M, Bianchetti A, Trabucchi M. Reality orientation therapy in Alzheimer disease: useful or not? A controlled study. Alzheimer Dis Assoc Disord. 95;9(3):132-8. [Rec#: 36209] Exclude at abstract screening: Observational study.
Zappa S B, Cassileth B R. Complementary approaches to palliative oncological care. J Nurs Care Qual. 2003;18(1):22-6. [Rec#: 16538] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 12518835].
Zarate C A, Baldessarini R J, Siegel A J, Nakamura A, McDonald J, Muir-Hutchinson L A. Risperidone in the elderly: a pharmacoepidemiologic study. Journal of Clinical Psychiatry. 97;58:311-317. [Rec#: 50827] Exclude at abstract screening: Title Only.
Zarbock S F. Compassionate care for dying patients. Home Care Provid. 96;1(1):39-40. [Rec#: 16539] Exclude at abstract screening: Title Only. [pmid: 9157902].
Zauszniewski J A, Ahmad M. Patterns of depressive symptoms in three groups of depressed adults. Issues Ment Health Nurs. 2000;21(7):711-20. [Rec#: 8411] Exclude at abstract screening: not about end of life. [pmid: 11855046].
Zautra A J, Reich J W, Guarnaccia C A. Some everyday life consequences of disability and bereavement for older adults. J Pers Soc Psychol. 90;59(3):550-61. [Rec#: 8413] Exclude at abstract screening: not about end of life.
Zaw-Tun N, Bruera E. Active metabolites of morphine. Journal of Palliative Care. 92;8(2):48-50. [Rec#: 50828] Exclude at abstract screening: not about end of life. [pmid: 1635007].
Zaza C, Sellick S. Assessing the impact of evidence-based continuing education on nonpharmacologic management of cancer pain. J Cancer Educ. 99;14(3):164-7. [Rec#: 16541] Exclude at abstract screening: not about end of life.
Zaza C, Baine N. Cancer pain and psychosocial factors: a critical review of the literature. J Pain Symptom Manage. 2002;24(5):526-42. [Rec#: 50158] Exclude at abstract screening: Study Design - Review/Meta. [pmid: 12547052].
Zeitlin S V. Grief and bereavement. Prim Care. 2001;28(2):415-25. [Rec#: 8415] Exclude at abstract screening: no outcomes specified. [pmid: 11406444].
Zekry H A, Reddy S K. Opioid Nonopioid Therapy in Cancer Pain: The Traditional and the New. Curr Rev Pain. 99;3(3):237-247. [Rec#: 8416] Exclude at abstract screening: useful only for background. [pmid: 10998679].
Zekry H A, Bruera E. Regional pain syndromes in cancer patients. Current Review of Pain. 2000;4(3):179-86. [Rec#: 50829] Exclude at abstract screening: no outcomes specified. [pmid: 10998731].
Zelewsky M G, Birchfield M. Common ground: the nurse's role in caring for terminally ill patients with cancer or human immunodeficiency virus disease. Home Healthc Nurse. 92;10(4):12-7. [Rec#: 16542] Exclude at abstract screening: not about end of life.
Zenz M. Germany: status of cancer pain and palliative care. J Pain Symptom Manage. 93;8(6):416-8. [Rec#: 16543] Exclude at abstract screening: Title Only. [pmid: 7525765].
Zepetella, G. The palliation of dyspnea in terminal disease. American Journal of Hospice & Palliative Care 98;322–330. [Rec#: 50830] Exclude at abstract screening: Title Only
Zeppetella G. An assessment of the safety, efficacy, and acceptability of intranasal fentanyl citrate in the management of cancer-related breakthrough pain: a pilot study. J Pain Symptom Manage. 2000;20(4):253-8. [Rec#: 8421] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 11027906].
Zeppetella G. How do terminally ill patients at home take their medication?. Palliat Med. 99;13(6):469-75. [Rec#: 8422] Exclude at abstract screening: Other topic only. [pmid: 10715753].
Zeppetella G. Nebulized morphine in the palliation of dyspnoea. Palliat Med. 97;11(4):267-75. [Rec#: 8423] Exclude at abstract screening: no outcomes specified. [pmid: 9373577].
Zeppetella G. The palliation of dyspnea in terminal disease. Am J Hosp Palliat Care. 98;15(6):322-30. [Rec#: 16544] Exclude at abstract screening: no outcomes specified. [pmid: 9866455].
Zeppetella G. An assessment of the safety, efficacy, and acceptability of intranasal fentanyl citrate in the management of cancer-related breakthrough pain: a pilot study. Journal of Pain & Symptom Management. 2000;20(4):253-8. [Rec#: 50831] Exclude at abstract screening: Observational study. [pmid: 11027906].
Zeppetella G., Ribeiro, M. Opioids for the management of episodic pain in cancer patients. The Cochrane Library 2003;3. [Rec#: 50832] Exclude at abstract screening: Title Only
Zerwekh J. The truth-tellers. How hospice nurses help patients confront death. Am J Nurs. 94;94(2):30-4. [Rec#: 16547] Exclude at abstract screening: Title Only. [pmid: 8304394].
Zerwekh J. Transcending life: the practice wisdom of nursing hospice experts. Am J Hosp Palliat Care. 93;10(5):26-31. [Rec#: 16546] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Zerwekh J V. A family caregiving model for hospice nursing. Hosp J. 95;10(1):27-44. [Rec#: 16549] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 7789939].
Zerwekh J V. Do dying patients really need i.v. fluids? Am J Nurs 97;97(3):26–30; quiz 31. Comment in: Am J Nurs. May. 1997;97(5):16. PMID: 9155786. [Rec#: 16548] Exclude at abstract screening: Title Only.
Zerwekh J V. Wisdom and falsehoods: naming the practice wisdom of nursing in the home and the falsehoods opposing that practice. Holist Nurs Pract. 97;11(4):46-55. [Rec#: 16550] Exclude at abstract screening: outcome unrelated to pts/family/non-prof.
Zhang A Y, Siminoff L A. The role of the family in treatment decision making by patients with cancer. Oncol Nurs Forum. 2003;30(6):1022-8. [Rec#: 8429] Exclude at abstract screening: Study Design - Qualitative. [pmid: 14603359].
Zhukovsky D S. A model of palliative care: the palliative medicine program of the Cleveland Clinic Foundation. A World Health Organization Demonstrations Project. Support Care Cancer. 2000;8(4):268-77. [Rec#: 16552] Exclude at abstract screening: no outcomes specified. [pmid: 10923766].
Zhukovsky DS. Fever and sweats in the patient with advanced cancer. Hematol Oncol Clin North Am 2002;16(3):579–88, viii. [Rec#: 16551] Exclude at abstract screening: no outcomes specified
Zick C D, Smith K R. Patterns of economic change surrounding the death of a spouse. J Gerontol. 91;46(6):S310-20. [Rec#: 8434] Exclude at abstract screening: Bereavement only. [pmid: 1940097].
Ziegler J. Money is no obstacle to end-of-life care. Bus Health 97;15(11):27, 30–2. [Rec#: 16555] Exclude at abstract screening: no outcomes specified
Zielinski C C. Making treatment choices: a physician's discussion of patients' needs. Semin Oncol. 2003;30(2 Suppl 3):27-9. [Rec#: 16556] Exclude at abstract screening: no outcomes specified. [pmid: 12722023].
Zimmer J G, Groth-Juncker A, McCusker J. A randomized controlled study of a home health care team. American Journal of Public Health. 85;75(2):134-41. [Rec#: 50834] Exclude at abstract screening: data older than 1990.
Zimmer J G, Groth-Juncker A, McCusker J. Effects of a physician-led home care team on terminal care. Journal of the American Geriatric Society. 84;32(4):288-92. [Rec#: 50833] Exclude at abstract screening: data older than 1990.
Zimmerman S, Sloane P D, Hanson L, Mitchell C M, Shy A. Staff perceptions of end-of-life care in long-term care. J Am Med Dir Assoc. 2003;4(1):23-6. [Rec#: 16557] Exclude at abstract screening: outcome unrelated to pts/family/non-prof. [pmid: 12807593].
Zimmermann C, Rodin G. The denial of death thesis: sociological critique and implications for palliative care. Palliat Med. 2004;18(2):121-8. [Rec#: 8439] Exclude at abstract screening: no outcomes specified. [pmid: 15046408].
Zinn C. Hospice: from grassroots to the mainstream. W V Med J. 95;91(4):136-8. [Rec#: 16558] Exclude at abstract screening: no outcomes specified. [pmid: 7610646].
Zisook S, Shuchter S R. Depression through the first year after the death of a spouse. Am J Psychiatry 91;148(10):1346–52. Comment in: Am J Psychiatry. Apr. 1992;149(4):579-80. PMID: 1510748. [Rec#: 8445] Exclude at abstract screening: Bereavement only.
Zisook S, Shuchter S R. Early psychological reaction to the stress of widowhood. Psychiatry. 91;54(4):320-33. [Rec#: 8446] Exclude at abstract screening: Bereavement only. [pmid: 1788363].
Zisook S, Shuchter S R. Uncomplicated bereavement. J Clin Psychiatry. 93;54(10):365-72. [Rec#: 8447] Exclude at abstract screening: Bereavement only. [pmid: 8262878].
Zisook S, Chentsova-Dutton Y, Shuchter S R. PTSD following bereavement. Ann Clin Psychiatry. 98;10(4):157-63. [Rec#: 8442] Exclude at abstract screening: Bereavement only. [pmid: 9988056].
Zisook S, Schneider D, Shuchter S R. Anxiety and bereavement. Psychiatr Med. 90;8(2):83-96. [Rec#: 8444] Exclude at abstract screening: Study Design - Unclear. [pmid: 2185504].
Zisook S, Shuchter S R, Irwin M, Darko D F, Sledge P, Resovsky K. Bereavement, depression, and immune function. Psychiatry Res. 94;52(1):1-10. [Rec#: 8448] Exclude at abstract screening: Observational study. [pmid: 8047615].
Zisook S, Shuchter S R, Pedrelli P, Sable J, Deaciuc S C. Bupropion sustained release for bereavement: results of an open trial. J Clin Psychiatry. 2001;62(4):227-30. [Rec#: 8449] Exclude at abstract screening: chemo/surg/stents/laser/radiation. [pmid: 11379835].
Zisook S, Shuchter S R, Sledge P, Mulvihill M. Aging and bereavement. J Geriatr Psychiatry Neurol. 93;6(3):137-43. [Rec#: 8450] Exclude at abstract screening: Study Design - Unclear. [pmid: 8397757].
Zisook S, Shuchter S R, Sledge P A, Paulus M, Judd L L. The spectrum of depressive phenomena after spousal bereavement. J Clin Psychiatry. 94;55(Suppl):29-36. [Rec#: 8451] Exclude at abstract screening: Bereavement only. [pmid: 8077167].
Zitman F G, Linssen A C, Van H R. Chronic pain beyond patienthood. J Nerv Ment Dis. 92;180(2):97-100. [Rec#: 8452] Exclude at abstract screening: not about end of life. [pmid: 1371142].
Zoloth L. Limiting access to medical treatment in an age of medical progress: developing a Catholic consensus: a response from Jewish tradition. Christ Bioeth. 2001;7(2):193-201. [Rec#: 16563] Exclude at abstract screening: not about end of life. [pmid: 12168627].
Zuccala G, Onder G, Pedone C, Cocchi A, Carosella L, Cattel C, Carbonin P U, Bernabei R. Cognitive dysfunction as a major determinant of disability in patients with heart failure: results from a multicentre survey. On behalf of the GIFA (SIGG-ONLUS) Investigators. J Neurol Neurosurg Psychiatry. 2001;70(1):109-12. [Rec#: 36250] Exclude at abstract screening: not about end of life. [pmid: 11118258].
Zuckerman AM and Johnson TK. Niche services. Fifth in a series examining revenue growth strategies in a difficult health care market. Health Prog 2002;83(1):23–8, 51. [Rec#: 16566] Exclude at abstract screening: not about end of life
Zuckerman C, Wollner D. End of life care and decision making: how far we have come, how far we have to go. Hosp J. 99;14(34):85-107. [Rec#: 8460] Exclude at abstract screening: no outcomes specified. [pmid: 10839004].
Zuckerman C. Issues concerning end-of-life care. J Long Term Home Health Care. 97;16(2):26-34. [Rec#: 8459] Exclude at abstract screening: Title Only. [pmid: 10168380].
Zuin D, Ortiz H, Boromei D, Lopez O L. Motor vehicle crashes and abnormal driving behaviours in patients with dementia in Mendoza Argentina. Eur J Neurol. 2002;9(1):29-34. [Rec#: 36253] Exclude at abstract screening: not about end of life. [pmid: 11784373].
Zwart H. The resurgence of nature-speak. Health Care Anal. 94;2(3):221-6. [Rec#: 16568] Exclude at abstract screening: not about end of life. [pmid: 10184198].
Zweig S, Mehr D R. Helping older patients and their families decide about end-of-life care. Mo Med. 2003;100(1):62-8. [Rec#: 8462] Exclude at abstract screening: no outcomes specified. [pmid: 12664707].