# Appendix H

## Appendix H1. Methodological Issues in Measurement

Our literature review also identified a number of articles that dealt with specific methodological issues that are prominent in end-of-life care research. Our search strategy captured challenges to measurement in end-of-life care during the undertaking of identifying validated measures. Two recently published expert opinion compilations provide additional data: a series of 6 articles in the Journal of Palliative Medicine ^1–6^ and 3 articles in a special issue of the Gerontologist. ^7–9^ Also, an on-line symptom research text provides an review of methodological challenges and research approaches in this field.(Interactive Textbook on Clinical Symptom Research. Eds. Max MB and Lynn J. http://symptomresearch.nih.gov/tablecontents.htm)

Ten articles looked at the concordance between raters or proxy determinations. One study found that inter-rater kappa values were poor for pain, anxiety, and depression. A number of articles reported that current patient-proxy ratings had higher agreement with each other than with relatives' retrospective ratings, and that knowledge ratings were better matched overall agreement of family proxy evaluations to patient evaluation is moderate. ^10,^ ^11,^ ^12^ An examination of patient-caregiver congruence in QOL assessment in newly-diagnosed lung cancer patients reported large differences. Low congruence was related to low patient-related self-efficacy, high patient psychological distress, and caregiver strain. ^13^ Another study reported that family members were better proxies than staff for symptoms. ^14^ A study of patient-proxy perception of the quality of care found that agreement was best when both lived together and shared everyday experiences. ^15^ A comparison of patient and surrogate satisfaction ratings found low correlation. ^16^ A study between patients, physicians, and proxy demonstrated that significant others and physicians had poor agreement on symptoms experience in the last week of life with kappa values across multiple symptoms <= 0.4. ^17^ Sulmasy, et. al. explored the accuracy of substituted judgments by proxy compared to patients with terminal diseases with hypthetical scenarios and explored associations that affected the congruence. ^18^ On average, agreement was 66% and was increased if patient and surrogate had spoken about end-of-life issues (OR 1.9), if patient had private insurance (OR 1.5), and if the patient was more educated (OR 1.7). Clipp and George explored the reliability of spouse informants finding that caregivers agreed with patients on objective but not subjective measures of functioning and viewed patients' functioning more negatively than patients in domains such as depression and fear of the future. ^19^

Agreement between professional health care providers and patients revealed similar shortcomings. A comparison of patient and nurse assessments reported good agreement for symptom control but differences for anxiety, personal thoughts, practical matters, and information received. ^20^ Another comparison of patients and nurses found low correlations between patients and providers and symptoms; nurses tended to rate patients' symptoms more highly than patients rated their own symptoms. ^21^ An article evaluating the number of symptom ratings needed for reliability found that 3 raters on 1 occasion or 2 raters on 2 occasions were needed. ^22^ An evaluation of patient-physician concordance reported that patients and clinicians disagreed in 26% of cases about whether end-of-life communication had occurred. ^23^ Agreement for symptoms assessed by the Rotterdam Symptom Checklist in over 33,000 cases between physician and patients showed 78% agreement with the highest discordance in severity assessment where providers demonstrated a consistent bias toward underestimation. ^24^ Fatigue showed marked omissions by nurse recognition. ^25^ Another study documented that proxy and physician reports agree with patient self-reports for prevalence of chronic diseases but that proxy respondents missed certain diagnoses in after-death interviews. ^17^ Three articles compared the usefulness of different tools. A comparison of FACT-G, Spitzer QLI, ECOG-PS, VAS, and a 5 point word anchor categorical scale concluded that a single-item global measure of quality of life was as effective as the multidimensional ones (although QOL didn't change much during the study). ^26^ One study evaluated the content validity of EORTC QLQ-C30, ESAS, POS, MQOL, and MSAS by comparing the content of each to the symptoms and problems noted in records of admitted palliative cancer patients. They found that the EORTC QLQ-C30 covered 10 and the MSAS 11 of the 12 most frequent problems. ^27^ One article described a surgical palliative workgroup that identified validated measures which were potentially applicable to the palliative population. ^28^

One article evaluated the use of instruments designed for healthier populations for use at the end of life. An evaluation of a needs assessment found that some items did not apply for hospice patients (such as work issues). ^29^

Cassarett, et. al. compared 2-week post-death survey to 6-week post-death survey timing and found no differences in response rates or self-report of distress. ^30^

Two articles compared thresholds with different instruments. A study evaluating the impact of measuring somatic symptoms when diagnosing depression in the terminally ill reported that this inflated the rate of diagnosis only with a low-threshold approach to diagnosing depression. ^31^ Another study comparing pain intensity markers, the pain relief scale, a pain satisfaction scale, and 3 pain management indices reported that the proportion of inadequately treated patients ranged from 16–91% depending on the measure. ^32^

Five studies evaluated feasibility issues in assessing patients near the end of life. One study using a number of scales reported that 66% of eligible palliative care patients were able to participate with significant help, although much data was incomplete. ^33^ One group devised a 3-word choice to use instead of a numerical scale. ^14^ One study reported that missing data was an indicator of more severe illness. ^34^ One study described methods for increasing sample size for proxy reports in after death studies with extensive case-finding strategies. ^35^ Hopwood, et. al. report limitations in QOL questionnaires in lung and head and neck cancer trials including logistical problems with patients being too ill to complete evaluations, organizational problems administering questionnaires, and differential quality in administration of measures between type of staff member. ^36^

A number of articles looked at potential sources of bias introduced by methodology in end-of-life and palliative care research. One study reported an assessment bias that pain was much more likely to be documented on the MDS in nursing home residents enrolled in hospice. ^37^ Another study examined selection bias with cluster randomization as is often done when comparing different programs or centers of care and reported differences in demographic characteristics and diseases representations that were attributable to the specialty mix of the groups. ^38^

### Reference List

1 Storey C P Jr. Trying trials. J Palliat Med. 2004;7(3):393-4. [pmid: 15265344].
2 Kapo J, Casarett D. Working to improve palliative care trials. J Palliat Med. 2004;7(3):395-7. [pmid: 15265345].
3 Penrod J D, Morrison R S. Challenges for palliative care research. J Palliat Med. 2004;7(3):398-402. [pmid: 15265346].
4 Buss M K, Arnold R M. Challenges in palliative care research: one experience. J Palliat Med. 2004;7(3):405-7. [pmid: 15265348].
5 Wallen G R, Berger A. Mixed methods: in search of truth in palliative care medicine. J Palliat Med. 2004;7(3):403-4. [pmid: 15265347].
6 Ferrell B. Palliative care research: the need to construct paradigms. J Palliat Med. 2004;7(3):408-10. [pmid: 15265349].
7 George LK. Research design in end-of-life research: state of science. Gerontologist 2002;42 Spec No 3:86–98.
8 Tennstedt SL. Commentary on “Research Design in End-of-Life Research: State of Science”. Gerontologist 2002;42 Spec No 3:99–103.
9 Tilden VP, Tolle S, Drach L, et al. Measurement of quality of care and quality of life at the end of life. Gerontologist 2002;42 Spec No 3:71–80.
10 Hinton J. How reliable are relatives' retrospective reports of terminal illness? Patients and relatives' accounts compared. Soc Sci Med. 1996;43(8):1229-36. [pmid: 8903127].
11 Higginson I, Priest P, McCarthy M. Are bereaved family members a valid proxy for a patient's assessment of dying?. Soc Sci Med. 1994;38(4):553-7. [pmid: 7514313].
12 Lobchuk M M, Vorauer J D. Family caregiver perspective-taking and accuracy in estimating cancer patient symptom experiences. Soc Sci Med. 2003;57(12):2379-84. [pmid: 14572844].
13 Porter L S, Keefe F J, McBride C M, et al. Perceptions of patients' self-efficacy for managing pain and lung cancer symptoms: correspondence between patients and family caregivers. Pain. 2002;98(12):169-78. [pmid: 12098629].
14 Sterkenburg C A, King B, Woodward C A. A reliability and validity study of the McMaster Quality of Life Scale (MQLS) for a palliative population. J Palliat Care. 1996;12(1):18-25. [pmid: 8857243].
15 Larsson B W, Larsson G, Carlson S R. Advanced home care: patients' opinions on quality compared with those of family members. J Clin Nurs. 2004;13(2):226-33. [pmid: 14723675].
16 Sulmasy D P, McIlvane J M, Pasley P M, et al. A scale for measuring patient perceptions of the quality of end-of-life care and satisfaction with treatment: the reliability and validity of QUEST. J Pain Symptom Manage. 2002;23(6):458-70. [pmid: 12067770].
17 Klinkenberg M, Smit J H, Deeg D J, et al. Proxy reporting in after-death interviews: the use of proxy respondents in retrospective assessment of chronic diseases and symptom burden in the terminal phase of life. Palliat Med. 2003;17(2):191-201. [pmid: 12701851].
18 Sulmasy D P, Terry P B, Weisman C S, et al. The accuracy of substituted judgments in patients with terminal diagnoses. Ann Intern Med 1998;128(8):621–9. Comment in: Ann Intern Med. Dec 15. 1998;129(12):1082-3. PMID: 9867782.
19 Clipp E C, George L K. Patients with cancer and their spouse caregivers. Perceptions of the illness experience. Cancer. 1992;69(4):1074-9. [pmid: 1735074].
20 Horton R. Differences in assessment of symptoms and quality of life between patients with advanced cancer and their specialist palliative care nurses in a home care setting. Palliat Med. 2002;16(6):488-94. [pmid: 12465695].
21 Rhodes V A, McDaniel R W, Matthews C A. Hospice patients' and nurses' perceptions of self-care deficits based on symptom experience. Cancer Nurs. 1998;21(5):312-9. [pmid: 9775481].
22 Nekolaichuk C L, Maguire T O, Suarez-Almazor M, et al. Assessing the reliability of patient, nurse, and family caregiver symptom ratings in hospitalized advanced cancer patients. J Clin Oncol. 1999;17(11):3621-30. [pmid: 10550162].
23 Curtisa J R, Patrick D L, Caldwell E, et al. The quality of patient-doctor communication about end-of-life care: a study of patients with advanced AIDS and their primary care clinicians. AIDS. 1999;13(9):1123-31. [pmid: 10397544].
24 Stephens R J, Hopwood P, Girling D J, et al. Randomized trials with quality of life endpoints: are doctors' ratings of patients' physical symptoms interchangeable with patients' self-ratings?. Qual Life Res. 1997;6(3):225-36. [pmid: 9226980].
25 Ekman I, Ehrenberg A. Fatigued elderly patients with chronic heart failure: do patient reports and nurse recordings correspond?. Int J Nurs Terminol Classif. 2002;13(4):127-36. [pmid: 12629682].
26 Donnelly S, Rybicki L, Walsh D. Quality of life measurement in the palliative management of advanced cancer. Support Care Cancer. 2001;9(5):361-5. [pmid: 11497390].
27 Stromgren A S, Groenvold M, Pedersen L, et al. Symptomatology of cancer patients in palliative care: content validation of self-assessment questionnaires against medical records. Eur J Cancer. 2002;38(6):788-94. [pmid: 11937313].
28 Surgeons Palliative Care Workgroup. Office of Promoting Excellence in End-of-Life Care: Surgeon's Palliative Care Workgroup report from the field. J Am Coll Surg. 2003;197(4):661-86. [pmid: 14562800].
29 Gates M F, Lackey N R, White M R. Needs of hospice and clinic patients with cancer. Cancer Pract 1995;3(4):226–32. Comment in: Cancer Pract. Jul-Aug. 1995;3(4):201. PMID: 7620483.
30 Casarett D J, Crowley R, Hirschman K B. Surveys to assess satisfaction with end-of-life care: does timing matter?. J Pain Symptom Manage. 2003;25(2):128-32. [pmid: 12590028].
31 Chochinov H M, Wilson K G, Enns M, et al. Prevalence of depression in the terminally ill: effects of diagnostic criteria and symptom threshold judgments. Am J Psychiatry. 1994;151(4):537-40. [pmid: 7511875].
32 de Wit R, van Dam F, Abu-Saad H H, et al. Empirical comparison of commonly used measures to evaluate pain treatment in cancer patients with chronic pain. J Clin Oncol. 1999;17(4):1280. [pmid: 10561190].
33 Stromgren A S, Goldschmidt D, Groenvold M, et al. Self-assessment in cancer patients referred to palliative care: a study of feasibility and symptom epidemiology. Cancer. 2002;94(2):512-20. [pmid: 11900236].
34 Kopp I, Lorenz W, Rothmund M, et al. Relation between severe illness and non-completion of quality-of-life questionnaires by patients with rectal cancer. J R Soc Med. 2003;96(9):442-8. [pmid: 12949200]. [pmcid: 539599].
35 Tilden V P, Drach L L, Tolle S W, et al. Sampling challenges in end-of-life research: case-finding for family informants. Nurs Res. 2002;51(1):66-9. [pmid: 11822572].
36 Hopwood P, Harvey A, Davies J, et al. Survey of the Administration of quality of life (QL) questionnaires in three multicentre randomised trials in cancer. The Medical Research Council Lung Cancer Working Party the CHART Steering Committee. Eur J Cancer. 1998;34(1):49-57. [pmid: 9624237].
37 Wu N, Miller S C, Lapane K, et al. The problem of assessment bias when measuring the hospice effect on nursing home residents' pain. J Pain Symptom Manage. 2003;26(5):998-1009. [pmid: 14585551].
38 Jordhoy M S, Fayers P M, Ahlner-Elmqvist M, et al. Lack of concealment may lead to selection bias in cluster randomized trials of palliative care. Palliat Med. 2002;16(1):43-9. [pmid: 11963450].

## Appendix H2. VERSION

Table H-2 Reliability and Validity Data for Measures Identified

Measure name | Population Setting | Validity Testing
Domain(s) | Brief description | Reliability Data
Agitation Distress Scale ^1^ | Mixed cancer | Principal components analysis reveal only 1 component; significantly correlated with agitation items on MDAS & DRS (0.61) but scale was not correlated with cognitive items
Domain(s): Emotional symptoms | 6-item; clinician-rating scale | Cronbach's 0.91; inter-rater kappa 0.72–1.0
Anticipatory Grief Scale ^2^ ^ Toolkit^ | Mixed diseases | See Toolkit for details
Domain(s): Grief and bereavement | 27 items; interviewer or self-administered | See Toolkit for details
“Are you depressed? ^3^ ” | Mixed diseases | Correctly identified diagnosis of depression in all patients
Domain(s): Emotional symptoms | Single-item screening for depression | Kappa=0.76 between interviewers and observers
Barthel Index ^2^ ^ Toolkit^ | Mixed diseases | see Toolkit for details
Domain(s): Functional status | 10 item; self-administered and a 15 item version that is medical professional administered | see Toolkit for details
Bereavement Phenomenology Questionnaire (BPQ) ^4^ | Mixed diseases | Discriminate MANOVA showed decreasing scores over time; factor analysis reveals only one factor despite being designed to assess four dimensions
Domain(s): Grief and bereavement | 22-items, 4 point Likert scale | Cronbach's alpha 0.93
Bereavement Risk Index (BRI) ^5^ | Mixed diseases | Significant differences were found between low and high-risk groups in the Brief Symptom Inventory; results persisted 25 months after death.
Domain(s): Grief and bereavement | Uses an adapted 8-item version | NR
Brief Hospice Inventory ^6^ | Mixed diseases | Factor analysis reveals 2 factors
Domain(s): Quality of life; Physical symptoms; Emotional symptoms | NR | Cronbach's alpha 0.84–0.94
Brief scale ^7^ | Lung cancer patients of mixed severity | Reported against HADS (outlook correlation 0.61, support 0.43) and RSCL (outlook 0.64, support 0.18); correlation to corresponding Spitzer QL-Index (outlook 0.55, support 0.53)
Domain(s): Quality of life | (uses 2 of 5 items from Spitzer Quality of Life index); consists of 2 separate implicit scores on 3 tier scale for mood/outlook (based on 3 structured questions) and social support (based on 2 questions); clinician assessment | NR
Cambridge Palliative Assessment Schedule (CAMPAS-R) ^8^ | Mixed diseases | Correlated with EORTC & HADS items and scales for some symptoms but not others; significant differences between patients who did and who didn't survive
Domain(s): Physical symptoms | Patient physical and psychological symptoms; patients-rated caregiver psychological symptoms; VAS | Cronbach's alpha 0.77–0.8
Cancer Patient Need Survey ^9^ | Mixed cancer | Discriminate validity with different scores for hospice and clinic patients - may need different instrument for hospice patients
Domain(s): Needs assessment (Quality of care) | 51 items, 5 categories - coping needs, help needs, information needs, work needs, cancer shock needs | Cronbach's alpha 0.91
Caregiver Reaction Assessment ^2^ ^ Toolkit^ | Mixed diseases | See Toolkit for details
Domain(s): Caregiver well-being | 24 items; interviewer administered | See Toolkit for details
Caregiver Strain Index ^2^ ^ Toolkit^ | Mixed diseases | See Toolkit for details
Domain(s): Caregiver well-being | 13 items; interviewer administered | See Toolkit for details
Center for Epidemilogic Studies (CES-D) ^2^ ^ Toolkit^ | Mixed diseases | See Toolkit for details
Domain(s): Emotional symptoms | 20 items; interviewer or self-administered | See Toolkit for details
Chao Patient Perception ^2^ ^ Toolkit^ | Mixed diseases | See Toolkit for details
Domain(s): Continuity of care | 23 items; self-administered mailed survey and medical record review | See Toolkit for details
Comfort Assessment in Dying with Dementia (CAD-EOLD) ^10^ | Single disease -advanced dementia | Item-total correlations range 0.39 to 0.79; correlation for symptom items on SM-EOLD r = 0.475 to 0.559
Domain(s): Physical symptoms, Emotional symptoms | 14 items; 4 subscales (physical distress, dying symptoms, emotional distress, well being) | Cronbach's alpha 0.85 overall; subscales (physical distress r=0.74, dying symptoms r=0.70, emotional distress r=0.82, well being r=0.80)
Communication Capacity Scale ^1^ | Mixed cancer | Principal components analysis show only 1 component; highly associated with cognitive items on MDAS and Delirium Rating Scale (0.83); not correlated with agitation items
Domain(s): Emotional symptoms | 5 item; clinician-rating scale | Cronbach's 0.96; inter-rater kappa 0.78–0.95
Concept of a Good Death measure ^11^ | Mixed diseases; not used with patients | Factor analysis - 3 subscales; small-to moderate association with other measures suggesting that these are distinct but related constructs; some items with low variability
Domain(s): Multidimensional measure (Palliative Outcomes) | 17 descriptive statements of components that might be related to concept of good death; 3 subscales: closure, personal control, clinical criteria | Test-retest: ICC 0.66–0.83.
Core Bereavement Items (CBI) ^12^ | Mixed diseases | Factor analysis to develop subscales; face validity examines -kept subscales that described key components of bereavement; discriminant validity to time and group effects
Domain(s): Grief and bereavement | 17 items, 3 subscales, measuring bereavement phenomena (developed from Bereavement Phenomenology Questionnaire) | Cronbach's alpha 0.91
Cornell Scale for Depression in Dementia (CSDD) ^13^ | Single disease - dementia; elderly nursing home residents | Oblique rotation 4-factor matrix with eigenvalues >1.0 account 50% variance; inter-factor correlation 0.30 for depression and disturbed sleep, others <0.181; criterion-validity done; no testing with external scales
Domain(s): Emotional symptoms | 19 items (16 items retained in 4 domains), 3 level scale; 2 steps - clinician interview of caregiver, brief patient interview and clinical observation | Internal consistency 0.76 total 16 item, depression subscale 0.75, somatic 0.72; Cronbach's 0.76
Cost and Reciprocity Index (CRI) ^14^ | NR | Testing was done of the original instrument in healthy populations - relations between subscales are consistent with theoretical framework.
Domain(s): Caregiver well-being | 25 items(modified), 4 subscales, face-to face for hospice caregivers; concepts of social support, reciprocity, cost, and conflict | Cronbach's alpha 0.68–0.83
Death Attitude Profile ^2^ ^Toolkit^ | Mixed diseases | See Toolkit for details
Domain(s): Spirituality | 21 items; self-administered | See Toolkit for details
Death Transcendence Scale ^2^ ^ Toolkit^ | Mixed diseases | See Toolkit for details
Domain(s): Spirituality | 25 items; self-administered | See Toolkit for details
Decisional Conflict Scale (DCS) ^15^ | Mixed diseases; applied scale to cancer patients | Construct validity among subscales 0.58 – 0.76; criterion validity significant between certain vs. uncertain groups; 3 factor model rejected (4 factor suggested in exploratory work)
Domain(s): Advance care planning (Treatment decisions) | 16 items, 5 point Likert scales; 3 subscales (uncertainty, factors contributing, and effective decision making) | Prior testing - internal consistency 0.78–0.89; test-retest >0.80; in combined subscales in this study - uncertainty 0.75, factor contributing 0.82, and decision making 0.82
Duke-UNC Social Support Scale ^16^ | Single disease - lung cancer | NR
Domain(s): Quality of life | NR | Cronbach's overall 0.94, subscales 0.88 to 0.92
Dyspnea Descriptor Questionnaire ^17^ | Single disease -heart failure; study done as convenience sample at single emergency department | Factor analysis done - 4 factor 71%
Domain(s): Physical symptoms (dyspnea) | 13 descriptors asked retrospectively (derived from literature search) | Cronbach's 0.95; inter-item correlation 0.60
Edmonton Functional Assessment Tool (EFAT-2) ^18,^ ^19,^ ^20^ | Mixed diseases | Concurrent validity shows it to be highly correlated with KPS and ECOG; total score highly correlated with global scale. Construct validity distinguished between inpatients and home palliative care patients. EFAT -2 (revision of EFAT) ^19^ not correlated with pain; significantly different in different groups based on discharge location; factor analysis: 2 components - physical & cognitive/affective
Domain(s): Functional status | 10 items (revised version); professional grading and evaluation scale describing symptoms and functions, one summary functional assessment; 0–4 scale | Inter-rater, ICC 0.71; Cronbach's alpha 0.86; Interrater ICC 0.97 for self trained clinicians (n = 2) and 0.95 for formal trained (n = 2); kappa on items ranged from 0.25 to 0.96 for self trained clinician pair and 0.17 to 0.95 for formal trained
Edmonton Symptom Assessment Scale (ESAS) ^2^ ^ Toolkit^ ^21^ | Mixed diseases | See Toolkit for additional details
Domain(s): Physical Symptoms | 9 items on 100mm visual analogue scale; self-administered or proxy | Correlation to MSAS Global Distress r = 0.73; concurrent validity ESAS summary distress score to MSAS demonstrated; TMSAS scale (0.72), GDI (0.73), physical symptom subscale (0.74), and psychologic symptom subscale (0.56); ESAS summary distress score to FACT demonstrated: physical well being subscale (-0.75), sum QOL (-0.69), functional well being (-0.63), emotional well being (-0.52) and social/family well being (-0.25); all item correlations reported as significant; calibration studies showed overlap for median values within scales for all items
| | Cronbach alpha 0.79; test-retest Spearman correlation 0.86 at 2 days and 0.45 at 1 week; all items significantly correlated at 2 days (r = 0.43 to 0.86) but at 1 week only pain (0.75), activity (0.65), depression (0.54), shortness of breath (0.53) and distress (0.45) were significantly correlated;
European Organization for Research and Treatment Core Quality of Life Questionnaire, version 3.0 (EORTC QLQ-C30) ^22^ ^ Toolkit^ ^2^ ^16^ | Mixed diseases | See Toolkit for additional details; Inter-scale correlations were moderate in general, statistically significant - weak correlations where they should have been weak; discriminative by functional status (p=0.01); responsiveness to changes in health status over time - significant difference (p<0.001) for pre & post treatment; construct - exploratory factor analysis - 6 factors.
Domain(s): Quality of life | 30 items; self-administered | Cronbach's overall 0.93, subscales 0.69 to 0.89 (7 or 12 subscales > 0.80); in palliative population Cronbach's 0.56–0.79
FACT/FACIT (Fact-G) ^23^ ^2^ ^ Toolkit^ | Mixed diseases | See Toolkit for details
Domain(s): Quality of life | 27 items; self-administered | See Toolkit for details
FAMCARE ^2^ ^ Toolkit^ ^24^ ^25^ | Mixed diseases | See Toolkit for details
Domain(s): Satisfaction | 20 items; interviewer administered | Inter-item correlations met criterion (minimum 50% with r = 0.3 to 0.7) for 18 of 20 items; item correlation to total score 0.4 to 0.75 for 12 of 12 items; Cronbach's alpha 0.93
Family Assessment Device (FAD) ^24^ | Mixed disease | NR
Domain(s): Satisfaction, Caregiver well-being | 12 items; assess family functioning | Inter-item correlations met criterion (minimum 50% with r = 0.3 to 0.7) for 18 of 20 items; item correlation to total score 0.4 to 0.75 for 12 of 12 items; Cronbach's alpha 0.88
Family Caregiver Medication Administration Hassles Scale ^26^ | Community study (details of patients not given) - looks at problems caregivers experience with assisting elderly with medications | Principal components and factor analysis done (66.5% cumulative variance; construct validity to Medication Complexity Index (r=0.19) & modified Caregiver Strain Index (r=0.44)
Domain(s): Caregiver well-being | 24 items paper survey; 4 subscales (Information, Safety Issues, Scheduling, & Polypharmacy); scale 0–5 for each item | Test-Retest at 2 weeks (n=53) 0.84 (0.78–0.85 Pearson correlation across subscales); internal consistency 0.95; Cronbach's alpha (0.80–0.92 across subscales)
F-Care Expectations Scale ^24^ | Mixed diseases | NR
Domain(s): Satisfaction | 16 items; assess family care expectations | Inter-item correlations met criterion (minimum 50% with r = 0.3 to 0.7) for 13 of 16 items; item correlation to total score 0.4 to 0.72 for 12 of 16 items; Cronbach's alpha 0.88
F-Care Perceptions Scale ^24^ | Mixed diseases | NR
Domain(s): Satisfaction | 21 items; sssess family members care perceptions | Inter-item correlations met criterion (minimum 50% with r = 0.3 to 0.7) for 18 of 21 items; item correlation to total score 0.4 to 0.72 for 13 of 21 items; Cronbach's alpha 0.86
FIM™ Instrument ^2^ ^ Toolkit^ | Mixed diseases | See Toolkit for details
Domain(s): Functional status | 18 items; interviewer administered | See Toolkit for details
Frail Elderly Functional Assessment Questionnaire (FEFA) ^27^ | Mixed diseases; age > 65 years; homebound and nursing home | Correlation to direct observation (r=0.90); also Katz's ADL index (r=0.86), Barthel index (r=0.91), Lawton's IADL index (r=0.67)
Domain(s): Functional status | 19 items; assess function in elderly at very low activity level; interviewer administered | Test-retest in n = 29 at 2 week interval - kappa 0.82 overall, all items > 0.40 (0.45–0.91)
Grief Experience Inventory (GEI) ^28^ | NR | Discriminate validity bereaved versus non-bereaved reported significant at 0.001 level on all subscales
Domain(s): Grief and bereavement | 102 statement self-administered inventory scaled yes/no; nine composite scales including 3 validity and 6 domains | Test-retest coefficients 0.53–0.87; Cronbach's alpha 0.52–0.84 on bereavements scales
Grief Resolution Index ^2^ ^ Toolkit^ | Mixed diseases | See Toolkit for details
Domain(s): Grief and bereavement | 7 items; interviewer or self-administered | See Toolkit for details
Hebrew Rehabilitation Center for Aged index (HRCA-QL) ^29^ | Adapted for patients with advanced cancer | Scores declined as patients became closer to death; sensitive to change in status; criterion validity correlated with KPS and IADL index
Domain(s): Quality of life | Version of the Spitzer Quality of Life index | Cronbach's alpha 0.7–0.78; test-retest: 0.89; inter-rater 0.67
Herth Hope Index ^2^ ^ Toolkit^ | Mixed diseases | See Toolkit for details
Domain(s): Spirituality | 12 items; interviewer administered; | See Toolkit for details
Hogan Grief Reaction Checklist (HGRC) ^30^ | Mixed diseases | Convergent validity to TRIG, GEI and IES ranged from r = 0.20 to 0.78 with significant correlations across subscales; discriminant validity in subset of mothers who experienced death of a child by different mechanisms (illness, accident, suicide, or homicide) revealed differences in blame and anger; discriminate validity with subset of mothers with deaths <or>3 years in past revealed difference in intensity of grief and personal growth; factor analysis reported
Domain(s): Grief and bereavement | 61 items; six constructs, (despair, panic behavior, blame and anger, disorganization, detachment, and personal growth) | Cronbach's alpha overall 0.90 (despair 0.89, panic behavior 0.90, blame and anger 0.79, disorganization 0.84, detachment 0.87, and personal growth 0.82); test-retest over 4 week interval significant at p<0.001 (despair r = 0.79, blame and anger r = 0.56, disorganization r = 0.85, detachment r = 0.77 and personal growth r = 0.81)
Hospice Pressure Ulcer Risk Assessment Scale (HoRT) ^31^ | Mixed diseases | discriminant validity with statistically significant differences between patients with and without ulcers. PPV 50%, NPV 100%.
Domain(s): Clinical assessment tool | assess physical activity, age, mobility | NR
Hospital Anxiety and Depression Scale (HADS) ^32^ | Breast cancer | Using cutoff value of tool, sensitivity/specificity (depression) 75%, 75%, misclassification rate 25%; (anxiety) 75%, 90%, 12%
Domain(s): Emotional symptoms | self-report, 7-items depression, 7-items anxiety; tries to discriminate between anxiety and depression | NR
Index of Independence in ADLs ^2^ | Mixed diseases | See Toolkit for details
Domain(s): Functional status | 6 items; medical professional rating | See Toolkit for details
Index of support; done as part of Canadian Study of Health and Aging (CSHA) ^33^ | Community study of elderly | 4 phases: factor analysis (item correlations 0.26 to 0.83), item response theory analysis, external (construct and predictive validity on 2nd half of study population), and IRT(r=0.53 to network size)/classical (r=0.61) comparison
Domain(s): Instrumental support available to older Canadian community residents | 6 items; 4 level scales; interview | Cronbach's alpha 0.76; IRT marginal reliability 0.85
Kansas City Cardiomyopathy Questionnaire ^34^ | Single disease - CHF | Convergent validity 0.46 – 0.74 across 7 domains; physical limitation to 6-minute walk (r=0.48), SF-36 (r=0.84), LiHFe (0.65); responsiveness higher than LiHFe and SF-36 for admission with CHF exacerbation
Domain(s): Quality of life; Physical symptoms; Functional status | Self-administered, 23-items, HRQOL in CHF | Cronbach's alpha 0.62–0.95 across 7 domains; test-retest at 3 months without exacerbation 0.8 to 4 point changes in 1–100 point scale
Life Closure Scale (LCS) ^35^ | Mixed cancer diagnoses | Content validity with interviews and experts evaluation
Domain(s): Spirituality | 45 items; assess psychological adaptation in dying | Cronbach's alpha 0.80
Life Evaluation Questionnaire (LEQ) ^36^ | Mixed diseases | Convergent validity to RSCL ranged from 0.01 to 0.62 (sufficient only for freedom, resentment, and social integration); convergent to MacAdam and Smith Support scale factor ranged from 0.02 to 0.62 and similarly sufficient only for freedom, resentment, and social integration; analysis with five components reported.
Domain(s): Quality of life | 121 items, 0–60 scale; self-administered; five subscales (freedom, appreciation of life, contentment, resentment, social integration) | Cronbach's alpha (freedom 0.70, appreciation of life 0.76, contentment 0.76, resentment 0.85, social integration 0.78); test-retest n=40, at 2–3 days (freedom r=0.80, appreciation of life r=0.91, contentment r=0.77, resentment r=0.92, social integration r=0.84)
Linear Analogue Scale (LAS) for quality of life in cancer patients ^37^ | Mixed cancer | Correlation between LAS and performance status (r=0.46); questionnaire and performance status (r=0.38) - overall poor performance noted
Domain(s): Quality of life | 5 questions, linear analogue scale, self-assessment | Cronbach's alpha 0.75; subgroup LAS (alpha 0.58) compared to questionnaire (0.93); n=41 test-retest LAS (29.3% of cases judged reliable), questionnaire (82.9%)
Lung Cancer Symptom Scale (LCCS) ^38,^ ^39,^ ^40^ | Single disease - lung cancer | Construct validity with KPS 0.15–0.63 across items (symptomatic distress 0.49, effect on activities 0.63, QOL 0.43); criterion validity (patient scale / observer scale respectively) - KPS (r=0.63, NA), SIP(0.40, 0.56), POMS(0.67,0.54), ATS 29 cough (0.56, 0.65) and dyspnea (0.46, 0.64), SF-MPQ (items range 0.51 – 0.67); content validity (high agreement noted without specific data); construct validity between scales: cough (r=0.74), dyspnea (r=0.66), hemoptysis (r=0.71), pain (r=0.71), wt loss (r=0.61); criterion validity to Karnofsky r=0.59
Domain(s): Quality of life; Physical symptoms; Emotional symptoms; Functional status | 2 scales; patient - 9 items visual scale (100mm) and observer - 6 items (4 point or none scale) | Cronbach's alpha 0.82 (patient scale) and 0.75 (observer); internal consistency to BSI (r=0.93), SIP (r=0.94), POMS (r=0.94), SF-MPQ (r=0.91, r=0.64–0.74 for 3 components); test-retest r>0.75 for all items; interobserver r>0.75 for all items except cough (r=0.65) and weakness (r=0.54); note weakness has subsequently been dropped
McCusker Scale ^2^ ^ Toolkit^ | Mixed diseases | See Toolkit for details
Domain(s): Continuity of care | 4 items; interviewer administered | See Toolkit for details
McGill Pain Questionnaire ^2^ ^ Toolkit^ | Mixed diseases | See Toolkit for details
Domain(s): Physical symptoms | 11 items; interviewer or self-administered | See Toolkit for details
McGill QOL Questionnaire ^2^ ^ Toolkit^ | Mixed diseases | See Toolkit for details
Domain(s): Quality of life | 17 items, 0–10 scale; self-administered | See Toolkit for details
McMaster Quality of Life Scale ^41^ | Mixed cancer | Concurrent validity as correlated well with Spitzer QOL (r=0.7); those able to rate it themselves rated QOL higher than those who needed to have it read to them (p-0.04); days until death explained 7% of the variance in QOL
Domain(s): Quality of life | Administered to proxies or patients; responsive to perceptions of change in clinical status (p=0.01) | Interobserver r = 0.83‐0.95; intrarater 1 week 0.63 (lower than on same day); Cronbach's 0.8
Meaning in Life Scale ^2^ | Mixed diseases | See Toolkit for details
Domain(s): Spirituality | 15 items; interviewer administered | See Toolkit for details
Measure of patients' assessment of the quality of communication about end-of-life care ^42^ | Single disease - HIV/AIDS | Correlated with overall satisfaction with medical care (0.76); those with higher-rated communication had clinicians more likely to know if the had a DPOA
Domain(s): Advance care planning | 4 items | Cronbach's alpha 0.81
Medical Outcome Study Satisfaction Survey ^2^ ^ Toolkit^ | Mixed diseases; | See Toolkit for details
Domain(s): Satisfaction | 21 items; self-administered; | See Toolkit for details
Memorial Pain Assessment Card ^2^ | Mixed diseases | See Toolkit for details
Domain(s): Quality of life | 8 descriptors and 3 visual analogue scales; self-administered; | See Toolkit for details
Memorial Symptom Assessment Scale ^2^ ^ Toolkit^ ^43^ ^44^ | Mixed diseases | See Toolkit for additional details. Convergent validity to the Piper Fatigue Scale ranged from r=0.15 to 0.56 for cancer patients and 0.29 to 0.61 for noncancer patients ^43^ (best for behavioral and sensory subscales of the PFS); factor analysis yielded one psychological factor and one physical symptom with 3 subgroups; separate study ^44^ showed univariate correlations to MHI well being -0.60 (-0.53 to 0.66 for 3 subscales), MHI distress 0.65 (0.48 to 0.80), FLIC -0.78 (-0.61 to -0.78, subscales of FLIC range -0.45 to -0.73), SDS 0.79 (0.57 to 0.81), and Karnofsky -0.58 (-0.31 to -0.65); the physical and global distress index subscales performed better than the psychological symptom subscale
Domain(s): Physical symptoms, Emotional symptoms | 32 items; interviewer or self-administered; | Cronbach's alpha 0.85 in cancer patients (n = 66) and 0.77 in noncancer end-stage group (n = 69);
Missoula-VITAS QOL Index ^2^ ^ Toolkit^ | Mixed diseases | See Toolkit for details
Domain(s): Quality of life | 27 items; self-administered | See Toolkit for details
Pain Assessment in Advanced Dementia (PAINAD) ^45^ | Single disease - advanced dementia patients in nursing home | Factor analysis done; convergent analysis to DS-DAT & DS-VAS (r=0.76, n=19) and PAIN-VAS (r=0.75, n=18) - note also done in different conditions (r>=0.82 in activity)
Domain(s): Physical symptoms | 5 items with 5 subdomains of pain each with scale 3 levels (29 choices); overall additive score 0–10 | Multiple observations across 44 patients; Cronbach's alpha 0.57 – 0.83 in multiple phases
Palliative Care Outcome Scale (POS) ^46^ | Mixed diseases | Construct validity r=0.43–0.80 against ETORTC QLC-C30 AND STAS (n=29 patients, 43 staff); change over time not statistically significant; face validity by patient survey (n=12 - qualitative)
Domain(s): Quality of life; Physical symptoms; Functional status; Continuity of care; Multidimensional measure | 2 parts - patient & staff; each 12 items, most 0–4 scale; general audit designed as a palliative care outcome measure, eight site study | Test-retest for seven items kappa -0.08–0.62 with % agreement 74–100%; Cronbach's alpha patient part (0.65) & staff part (0.70); Kappa > 0.3 staff compared to patient responses for 8 out of 10 items
Palliative Care Quality of Life Instrument (PQLI) ^47^ | Mixed cancer | Face validity: expert review, patients asked to pick most important issues, rate scales; compared patients with better & worse ECOG performance status (significant); responsiveness before and after treatment; factor analysis; construct - correlated with AQEL (correlation coefficients 0.44–0.94) and EORTC - QLQ-C30 (0.79–0.97); criterion: ability to predict independent criterion variables (p<0.001); convergent & discriminative: related to corresponding & not to non-corresponding variables on interview (p<0.001)
Domain(s): Quality of life | 28 items, 6 scales | Cronbach's alpha 0.79; test-retest coefficients of agreement 0.82
Physical Disability Index (PDI) ^48^ | NR | Discriminate validity against Folstein Mini-Mental State Exam (r=0.11); convergent validity Physical Self-Maintenance Scale (r=-0.71) and Sickness Impact Profile (r=-0.59);
Domain(s): Functional status | 54 items, for use with frail individuals; requires calibrated specialized performance measuring equipment | Test-retest in n = 36 at 2–5 days 0.97 overall, 4 subscales 0.92–0.96; interrater reliability 0.81–0.99 (mobility scale -0.02–0.70)
Physical Self-Maintenance Scale ^2,^ ^Toolkit^ | Mixed diseases | See Toolkit for details
Domain(s): Functional status | 6 items; interviewer or self-administered | See Toolkit for details
Picker-Commonwealth Surve^y2, Toolkit^ | Mixed diseases | See Toolkit for details
Domain(s): Continuity of care, Satisfaction | 62 items; self-administered | See Toolkit for details
Postal questionnaire to examine career satisfaction with palliative care ^49^ | Mixed diseases | Discriminant validity tested with 36 attitudinal questions when health problems identified - only 4 were significant by Chi square; convergent testing reported in tabular form in reference
Domain(s): Satisfaction | 89 question; after-death postal survey of caregivers | Cronbach's alpha 0.68 to 0.84 across 7 subsets
Profile of Mood States ^2^ ^ Toolkit^ | Mixed diseases | See Toolkit for details
Domain(s): Emotional symptoms | 11 items; interviewer administered | See Toolkit for details
Quality of Dying and Death (QODD) ^50–53^ | Mixed diseases | Measure development included qualitative data from multiple focus groups and interviews. QODD 31-item family after-death measure: construct validity r=-0.52 against MSAS, r=-0.47 MSAS psychological sub-score, r=-0.42 MSAS physical sub-score; discriminative study with independent symptom questionnaire significant at p<0.01, preferences at p<0.01, and communication p<0.001; correlation to global rating of last 7 days of life r=0.55, moment of death r=0.51 (two factors explaining 38% of QODD variance)
Domain(s): Quality of life, Functional status, Survival time and aggressiveness of care, Advance care planning, Spirituality, Grief and bereavement, Caregiver well-being, Multidimensional | 31 item family after-death interview across 6 domains; separate 23-item ICU version; 2 parts assess frequency and quality ratings; also 14-item nurse caregiver measure | Overall 31-items QODD Cronbach's alpha 0.89; Cronbach's alpha 0.96 for 14 item RN version; interobserver reliability 0.44 for overall QODD (23-item ICU version) after-death survey; components ranged from 0.15 to 1.0 for frequency components (mean 0.54), 0.16 to 0.59 for quality rating component (mean 0.32)
Quality of End-of-Life Care and Satisfaction with Treatment (QUEST) ^54^ | Mixed diseases | Reviewed by experts; construct - correlate with PSI (Patient Satisfaction Index) 0.38–0.47; subscales correlated with each other (0.47–0.69); not correlated with unrelated constructs; positive skew distribution for many items; negative correlation with symptoms; patients scores were lower for patients with DNR orders
Domain(s): Satisfaction | 4 scales (MD care, MD satisfaction, RN care, RN satisfaction); patients & surrogates, rate RNs & MDs | Test-retest: kappa 0.43–0.86 (1–2 days); Cronbach's 0.83–0.95
QUAL-E (Quality of Life at End of Life) ^55^ | Mixed diseases | Factor analysis reveals 5 domains: life completion, relationships with the health care system, preparation/anticipatory concerns, symptom impact, connectedness and affective social support.
Domain(s): Quality of life | 24 items | Cronbach's alpha 0.6–0.84
RAND Mental Health Inventory (MHI-5) ^2^ ^ Toolkit^ | Mixed diseases | See Toolkit for details
Domain(s): Emotional symptoms | 5 items; self-administered | See Toolkit for details
Rapid Disability Rating Scale ^2^ ^ Toolkit^ | Mixed diseases | See Toolkit for details
Domain(s): Functional status | 18 items; medical professional rating | See Toolkit for details
Relatives' patient management questionnaire ^56^ | Mixed cancer | Construct validity inter-scale correlations 0.6–0.86; discriminant low correlation with unrelated items
Domain(s): Advance care planning; Satisfaction | 21 items, 5 scales in final version: families' attitudes, perceptions, and patterns of choice in management of terminal cancer patients | Cronbach's alpha 0.5–0.69
Resident Assessment Instrument for Palliative Care (RAI-PC) ^57^ | NR | NR
Domain(s): Physical symptoms; Emotional symptoms; Functional status; Advance care planning; Spirituality; Palliative Outcomes | Builds on RAI for NH resident assessment; 9 domains; for clinician assessment in NH | Interobserver - kappa 0.77–0.9
Rotterdam Symptom Checklist (RSCL) ^32^ | Single disease - breast cancer | Using cutoff value of tool, sensitivity/specificity 75%, 80%; misclassification rate 21%
Domain(s): Physical symptoms; Emotional symptoms; Functional status | Self-report; 3 subscales: physical (22 items), psychological (8 items), ADL (8 items); 4 point scale | NR
Santa Clara Strength of Religious Faith Questionnaire (SCSORF) ^58^ | Mixed cancer | Convergent: strongly correlated with intrinsic religiosity, moderately correlated with religious practice, perception of self as spiritual, comfort derived from religion.
Domain(s): Spirituality | 10-items developed to evaluate links with psychological health | Test-retest: 0.82; Cronbach's alpha 0.95.
Satisfaction With Care at the End of Life in Dementia (SWC-EOLD) ^10^ | Single disease - dementia | Item-total correlations range 0.33 to 0.79
Domain(s): Satisfaction | 10 items; 4-point scale; one-factor | Cronbach's alpha 0.90
Smith-Falvo Paitent-Doctor Interaction Scale ^2^ ^ Toolkit^ | Mixed diseases | See Toolkit for details
Domain(s): Continuity of care | 17 items; self-administered | See Toolkit for details
Spiritual Perspective Scale ^2^ ^ Toolkit^ | Mixed disease; | See Toolkit for details
Domain(s): Spirituality | 10 items; self-administered | See Toolkit for details
Spiritual Well-Being Scale ^2^ ^ Toolkit^ | Mixed diseases | See Toolkit for details
Domain(s): Spirituality | 20 items; self-administered | See Toolkit for details
Stanford Health Assessment Questionnaire ^2^ ^ Toolkit^ | Mixed diseases | See Toolkit for details
Domain(s): Functional status | 20 items; interviewer/telephone or self-administered | See Toolkit for details
Support Team Assessment Schedule (STAS) ^59,^ ^60^ | Mixed diseases - broadly across hospice patients; one study ^60^ applied to acute care oncology unit and a palliative care unit | Validity by comparison of type of rater: kappa for patient to staff (n=62–78) ranged from 0.12–0.78, total score Spearman rho 0.66; kappa for family to staff (n=58–67) ranged from -0.06–0.51, total score Spearman rho 0.44. Validity by comparison to patient rating - overall r=-0.09 palliative care and r=0.28 oncology (p>0.05); to family rating overall r=0.38 palliative care and r=0.37 oncology (p>0.05); item kappa 0.00 – 0.61.
Domain(s): Physical symptoms; Multidimensional measure | 17 items, scale 0–4; 7 items grouped into a) patient and family items (4) and b) service items (3); interview administered | Interobserver reliability mostly r=0.4–0.6 (range 0.27–1.0) ; intraobserver reliability (r=-0.33–0.88) for overall score and range 0.1–1.0 for items; test-retest 0.50 for palliative care team and 0.71 for oncology team
Symptom Distress Scale (SDS) ^61^ | Mixed diseases - applied to symptoms in females with lung cancer | Factor analysis with principal components and varimax rotation - 5 factor 65% variance; also correlation of certain items to parts of Karnofsky Performance Status (r= -0.27 to -0.48) overall r=-0.58
Domain(s): Physical symptoms | 10 items, self-report; modified to 13 items for lung cancer in 1980s | NR
Symptom Management at the End of Life in Dementia (SM-EOLD) ^10^ | Single disease - dementia | Item-total correlations range 0.18 to 0.66; correlations for symptom items on CAD-EOLD r = 0.475 to 0.559
Domain(s): Physical symptoms, Emotional symptoms | 9 items; frequency ratings of multiple symptoms | Cronbach's alpha 0.78
Symptom Monitor ^62^ | Mixed diseases | NR
Domain(s): Physical symptoms | 10-item diary for physical symptoms | Inter-rater ICCs > 0.75
Toolkit After-Death Bereaved Family Member Interview ^63^ ^2^ ^ Toolkit^ | Mixed diseases (hospice, nursing homes, & hospital) | See Toolkit for additional details; scales moderately correlated with overall satisfaction and with corresponding individual rating question for the construct; families of those who died in hospice reported better care - significant for three of the eight scores
Domain(s): Satisfaction | 8 domains, telephone survey with family member 3–6 months after death; up to 133 items | Cronbach's >0.7 for >3 item scales, 0.58 for 3-item scales; test-retest: 34 items had Kappa/ICC <0.4 - low ICC question dropped.
Willingness to Accept Life-sustaining Treatment instrument (WALT) ^64^ | Mixed diseases; associated with age, ethnicity, & functional impairment | face: reviewed by patients & experts; correlated with simpler measure of preference
Domain(s): Advance care planning | No description provided | inter-rater 0.73–0.95; test-retest 0.49–0.93
Wisconsin Brief Pain Questionnaire ^2^ ^ Toolkit^ | Mixed diseases | See Toolkit for details
Domain(s): Physical symptoms | 17 items; self-administered | See Toolkit for details

### Reference List

1 Morita T, Tsunoda J, Inoue S, et al. Communication Capacity Scale and Agitation Distress Scale to measure the severity of delirium in terminally ill cancer patients: a validation study. Palliat Med. 2001;15(3):197-206. [pmid: 11407191].
2 Teno J. Time: Toolkit of Instruments to Measure End-of-life Care. available at URL: http://www.chcr.brown.edu/pcoc/toolkit.htm. Accessed 8/6/2004.
3 Chochinov H M, Wilson K G, Enns M, et al. “Are you depressed?” Screening for depression in the terminally ill. Am J Psychiatry 1997;154(5):674–6. Comment in: Am J Psychiatry. Jul. 1998;155(7):994-5. PMID: 9659876.
4 Kissane D W, Bloch S, McKenzie D P. The bereavement phenomenology questionnaire: a single factor only. Aust N Z J Psychiatry. 1997;31(3):370-4. [pmid: 9226082].
5 Robinson L A, Nuamah I F, Lev E, et al. A prospective longitudinal investigation of spousal bereavement examining Parkes and Weiss' Bereavement Risk Index. J Palliat Care. 1995;11(4):5-13. [pmid: 8648524].
6 Guo H, Fine P G, Mendoza T R, et al. A preliminary study of the utility of the brief hospice inventory. J Pain Symptom Manage. 2001;22(2):637-48. [pmid: 11495710].
7 Abratt R, Viljoen G. Assessment of quality of life by clinicians--experience of a practical method in lung cancer patients. S Afr Med J. 1995;85(9):896-8. [pmid: 8545754].
8 Ewing G, Todd C, Rogers M, et al. Validation of a symptom measure suitable for use among palliative care patients in the community: CAMPAS-R. J Pain Symptom Manage. 2004;27(4):287-299. [pmid: 15050656].
9 Gates M F, Lackey N R, White M R. Needs of hospice and clinic patients with cancer. Cancer Pract 1995;3(4):226–32. Comment in: Cancer Pract. Jul-Aug. 1995;3(4):201. PMID: 7620483.
10 Volicer L, Hurley A C, Blasi Z V. Scales for evaluation of End-of-Life Care in Dementia. Alzheimer Dis Assoc Disord. 2001;15(4):194-200. [pmid: 11723370].
11 Schwartz C E, Mazor K, Rogers J, et al. Validation of a new measure of concept of a good death. J Palliat Med. 2003;6(4):575-84. [pmid: 14516499].
12 Burnett P, Middleton W, Raphael B, et al. Measuring core bereavement phenomena. Psychol Med. 1997;27(1):49-57. [pmid: 9122308].
13 Kurlowicz L H, Evans L K, Strumpf N E, et al. A psychometric evaluation of the Cornell Scale for Depression in Dementia in a frail, nursing home population. Am J Geriatr Psychiatry. 2002;10(5):600-8. [pmid: 12213695].
14 Kirschling J M, Tilden V P, Butterfield P G. Social support: the experience of hospice family caregivers. Hosp J. 1990;6(2):75-93. [pmid: 2401471].
15 Koedoot N, Molenaar S, Oosterveld P, et al. The decisional conflict scale: further validation in two samples of Dutch oncology patients. Patient Educ Couns. 2001;45(3):187-93. [pmid: 11722854].
16 Herndon J E 2nd, Fleishman S, Kosty M P, et al. A longitudinal study of quality of life in advanced non-small cell lung cancer: Cancer and Leukemia Group B (CALGB) 8931. Control Clin Trials 1997;18 (4):286–300. Comment in: Control Clin Trials. 1997 Aug;18(4):306–10. PMID: 9257069. Comment in: Control Clin Trials. Aug. 1997;18(4):311-7. PMID: 9257070.
17 Parshall M B, Welsh J D, Brockopp D Y, et al. Reliability and validity of dyspnea sensory quality descriptors in heart failure patients treated in an emergency department. Heart Lung. 2001;30(1):57-65. [pmid: 11174368].
18 Kaasa T, Loomis J, Gillis K, et al. The Edmonton Functional Assessment Tool: preliminary development and evaluation for use in palliative care. J Pain Symptom Manage. 1997;13(1):10-9. [pmid: 9029857].
19 Kaasa T, Wessel J. The Edmonton Functional Assessment Tool: further development and validation for use in palliative care. J Palliat Care. 2001;17(1):5-11. [pmid: 11324186].
20 Kaasa T, Wessel J, Darrah J, et al. Inter-rater reliability of formally trained and self-trained raters using the Edmonton Functional Assessment Tool. Palliat Med. 2000;14(6):509-17. [pmid: 11219881].
21 Chang V T, Hwang S S, Feuerman M. Validation of the Edmonton Symptom Assessment Scale. Cancer. 2000;88(9):2164-71. [pmid: 10813730].
22 Kyriaki M, Eleni T, Efi P, et al. The EORTC core quality of life questionnaire (QLQ-C30, version 3.0) in terminally ill cancer patients under palliative care: validity and reliability in a Hellenic sample. Int J Cancer. 2001;94(1):135-9. [pmid: 11668488].
23 Cella D F, Tulsky D S, Gray G, et al. The Functional Assessment of Cancer Therapy scale: development and validation of the general measure. J Clin Oncol. 1993;11(3):570-9. [pmid: 8445433].
24 Kristjanson L J, Leis A, Koop P M, et al. Family members' care expectations, care perceptions, and satisfaction with advanced cancer care: results of a multi-site pilot study. J Palliat Care. 1997;13(4):5-13. [pmid: 9447806].
25 Kristjanson L J. Validity and reliability testing of the FAMCARE Scale: measuring family satisfaction with advanced cancer care. Social Science & Medicine. 1993;36(5):693-701. [pmid: 8456339].
26 Travis S S, Bernard M A, McAuley W J, et al. Development of the family caregiver medication administration hassles scale. Gerontologist. 2003;43(3):360-8. [pmid: 12810899].
27 Gloth F M, Walston J, Meyer J, et al. Reliability and validity of the Frail Elderly Functional Assessment questionnaire. Am J Phys Med Rehabil. 1995;74(1):45-53. [pmid: 7873113].
28 Feldstein M A, Gemma P B. Oncology nurses and chronic compounded grief. Cancer Nurs. 1995;18(3):228-36. [pmid: 7600555].
29 Llobera J, Esteva M, Benito E, et al. Quality of life for oncology patients during the terminal period. Validation of the HRCA-QL index. Support Care Cancer. 2003;11(5):294-303. [pmid: 12690543].
30 Hogan N S, Greenfield D B, Schmidt L A. Development and validation of the Hogan Grief Reaction Checklist. Death Stud. 2001;25(1):1-32. [pmid: 11503760].
31 Henoch I, Gustafsson M. Pressure ulcers in palliative care: development of a hospice pressure ulcer risk assessment scale. Int J Palliat Nurs. 2003;9(11):474-84. [pmid: 14676724].
32 Hopwood P, Howell A, Maguire P. Screening for psychiatric morbidity in patients with advanced breast cancer: validation of two self-report questionnaires. British Journal of Cancer. 1991;64(2):353-6. [pmid: 1892763].
33 Kristjansson B, Breithaupt K, McDowell I. Development and validation of an indicator of support for community-residing older Canadians. Int Psychogeriatr. 2001;13(Supp 1):125-35. [pmid: 11892959].
34 Green C P, Porter C B, Bresnahan D R, et al. Development and evaluation of the Kansas City Cardiomyopathy Questionnaire: a new health status measure for heart failure. J Am Coll Cardiol. 2000;35(5):1245-55. [pmid: 10758967].
35 Dobratz M C. The Life Closure Scale: a measure of psychological adaptation in death and dying. Hosp J. 1990;6(3):1-15. [pmid: 2276714].
36 Salmon P, Manzi F, Valori R M. Measuring the meaning of life for patients with incurable cancer: the life evaluation questionnaire (LEQ). Eur J Cancer. 1996;32A(5):755-60. [pmid: 9081350].
37 Giorgi F, Cellerino R, Gramazio A, et al. Assessing quality of life in patients with cancer: a comparison of a visual-analogue and a categorical model. Am J Clin Oncol. 1996;19(4):394-9. [pmid: 8677913].
38 Hollen P J, Gralla R J, Kris M G, et al. Normative data and trends in quality of life from the Lung Cancer Symptom Scale (LCSS). Support Care Cancer. 1999;7(3):140-8. [pmid: 10335932].
39 Hollen P J, Gralla R J, Kris M G, et al. Measurement of quality of life in patients with lung cancer in multicenter trials of new therapies. Psychometric assessment of the Lung Cancer Symptom Scale. Cancer. 1994;73(8):2087-98. [pmid: 8156514].
40 Hollen P J, Gralla R J, Kris M G, et al. Quality of life assessment in individuals with lung cancer: testing the Lung Cancer Symptom Scale (LCSS). Eur J Cancer. 1993;29A(Suppl 1):S51-8. [pmid: 8381294].
41 Sterkenburg C A, King B, Woodward C A. A reliability and validity study of the McMaster Quality of Life Scale (MQLS) for a palliative population. J Palliat Care. 1996;12(1):18-25. [pmid: 8857243].
42 Curtisa J R, Patrick D L, Caldwell E, et al. The quality of patient-doctor communication about end-of-life care: a study of patients with advanced AIDS and their primary care clinicians. AIDS. 1999;13(9):1123-31. [pmid: 10397544].
43 Tranmer J E, Heyland D, Dudgeon D, et al. Measuring the symptom experience of seriously ill cancer and noncancer hospitalized patients near the end of life with the memorial symptom assessment scale. J Pain Symptom Manage. 2003;25(5):420-9. [pmid: 12727039].
44 Chang V T, Thaler H T, Polyak T A, et al. Quality of life and survival: the role of multidimensional symptom assessment. Cancer. 1998;83(1):173-9. [pmid: 9655308].
45 Warden V, Hurley A C, Volicer L. Development and psychometric evaluation of the Pain Assessment in Advanced Dementia (PAINAD) scale. J Am Med Dir Assoc 2003;4(1):9–15. Comment in: J Am Med Dir Assoc. Jan-Feb. 2003;4(1):50-1. PMID: 12807599.
46 Hearn J, Higginson I J. Development and validation of a core outcome measure for palliative care: the palliative care outcome scale. Palliative Care Core Audit Project Advisory Group. Qual Health Care. 1999;8(4):219-27. [pmid: 10847883].
47 Mystakidou K, Tsilika E, Kouloulias V, et al. The “Palliative Care Quality of Life Instrument (PQLI)” in terminal cancer patients. Health Qual Life Outcomes. 2004;2(1):8. [pmid: 14962348]. [pmcid: 368445].
48 Gerety M B, Mulrow C D, Tuley M R, et al. Development and validation of a physical performance instrument for the functionally impaired elderly: the Physical Disability Index (PDI). J Gerontol. 1993;48(2):M33-8. [pmid: 8473692].
49 Jacoby A, Lecouturier J, Bradshaw C, et al. Feasibility of using postal questionnaires to examine carer satisfaction with palliative care: a methodological assessment. South Tyneside MAAG Palliative Care Study Group. Palliat Med. 1999;13(4):285-98. [pmid: 10659098].
50 Curtis J R, Patrick D L, Engelberg R A, et al. A measure of the quality of dying and death. Initial validation using after-death interviews with family members. J Pain Symptom Manage. 2002;24(1):17-31.
51 Patrick D L, Engelberg R A, Curtis J R. Evaluating the quality of dying and death. J Pain Symptom Manage. 2001;22(3):717-26. [pmid: 11532585].
52 Hodde N M, Engelberg R A, Treece P D, et al. Factors associated with nurse assessment of the quality of dying and death in the intensive care unit. Crit Care Med. 2004;32(8):1648-53. [pmid: 15286539].
53 Mularski R, Randall C, Osborne M, Engelberg R, Ganzini L. Agreement Among Family Members in Their Assessment of the Quality of Dying and Death. Journal of pain and symptom management. 2004;(In Press).
54 Sulmasy D P, McIlvane J M, Pasley P M, et al. A scale for measuring patient perceptions of the quality of end-of-life care and satisfaction with treatment: the reliability and validity of QUEST. J Pain Symptom Manage. 2002;23(6):458-70. [pmid: 12067770].
55 Steinhauser K E, Bosworth H B, Clipp E C, et al. Initial assessment of a new instrument to measure quality of life at the end of life. J Palliat Med. 2002;5(6):829-41. [pmid: 12685529].
56 Mystakidou K, Parpa E, Tsilika E, et al. The families evaluation on management, care and disclosure for terminal stage cancer patients. BMC Palliat Care. 2002;1(1):3. [pmid: 11945181]. [pmcid: 102762].
57 Steel K, Ljunggren G, Topinkova E, et al. The RAI-PC: an assessment instrument for palliative care in all settings. Am J Hosp Palliat Care. 2003;20(3):211-9. [pmid: 12785043].
58 Sherman A C, Simonton S, Adams D C, et al. Measuring religious faith in cancer patients: reliability and construct validity of the Santa Clara Strength of Religious Faith questionnaire. Psycho-Oncology. 2001;10(5):436-43. [pmid: 11536422].
59 Higginson I J, McCarthy M. Validity of the support team assessment schedule: do staffs' ratings reflect those made by patients or their families?. Palliat Med. 1993;7(3):219-28. [pmid: 7505183].
60 Carson M G, Fitch M I, Vachon M L. Measuring patient outcomes in palliative care: a reliability and validity study of the Support Team Assessment Schedule. Palliat Med. 2000;14(1):25-36. [pmid: 10717720].
61 Sarna L, Brecht M L. Dimensions of symptom distress in women with advanced lung cancer: a factor analysis. Heart Lung. 1997;26(1):23-30. [pmid: 9013218].
62 Hoekstra J, Bindels P J, van Duijn N P, et al. The symptom monitor. A diary for monitoring physical symptoms for cancer patients in palliative care: feasibility, reliability and compliance. J Pain Symptom Manage. 2004;27(1):24-35. [pmid: 14711466].
63 Teno J M, Clarridge B, Casey V, et al. Validation of Toolkit After-Death Bereaved Family Member Interview. J Pain Symptom Manage. 2001;22(3):752-8. [pmid: 11532588].
64 Fried T R, Bradley E H, Towle V R. Assessment of patient preferences: integrating treatments and outcomes. J Gerontol B Psychol Sci Soc Sci. 2002;57(6):S348-54. [pmid: 12426443].