# Appendix G. Cambridge Ballot

Southern California Evidence-based Practice Center End of Life Care and Outcomes Project

Matrix for Prioritizing Outcomes

We have developed a matrix of principles vs. outcomes to help us in our decision making process about which outcomes to prioritize. To score this modified Cambridge Ballot, first score each “cell” (0–10, 10 being the most important), and then give a summary hierarchical ranking of each item.

When you have completed it, please fax to Cony Rolon, RAND (fax: 310-451-6930).

| 1. Relative Importance at EOL (0–10) | 2. Relationship to Patient Experience (0–10) | 3. Feasibility (0–10) | 4. Relevance to care and policy (0–10) | 5. Recent Reviews (0–10) | 6. Differences by Selected Diseases (0–10) | 7. Modifiability (0–10) | Total [Col 1–7] (0–70) | Overall Rank* (1–11)
Pain
Affective Symptoms
Other symptoms
QOL / HRQOL
Spiritual / existential wellbeing
Caregiver/ family well-being and satisfaction
Provider communication
Advance care planning
Continuity and coordination
Utilization of Services
Site of Death

*Rank each outcome hierarchically where 1 is the most important outcome and 11 is the least important.